# Acknowledgments

The research team would like to acknowledge the efforts of Maxine A. Gere, M.S., for general editorial assistance and program support; Carol Gold-Boyd for administrative support; and Tina Murray, R.N., M.A.S., Senior Health Policy Analyst, Agency for Healthcare Research and Quality Center for Outcomes and Evidence, for advice as our Task Order Officer.