# Discussion and Future Research

Osteoarthritis (OA) of the knee is a common condition and the three interventions reviewed in this report are widely used in the treatment of OA of the knee. Yet the best available evidence reports that glucosamine/chondroitin and arthroscopic surgery are no more effective than placebo. The Glucosamine/Chondroitin Arthritis Intervention Trial (GAIT) (n=1,583) found that neither glucosamine hydrochloride, chondroitin sulfate, nor the combination was superior to placebo and that all were inferior to celecoxib. The double-blind, randomized, controlled trial by Moseley, O'Malley, Petersen, et al. (2002, n=180) found that arthroscopic lavage with or without debridement was not superior to sham arthroscopy. Results from 42 randomized controlled trials (RCTs), all but one of which were synthesized in various combinations in six meta-analyses, generally show positive effects of viscosupplementation on pain and function scores compared to placebo. However, the evidence on viscosupplementation is accompanied by considerable uncertainty due to variable trial quality, potential publication bias, and unclear clinical significance of the changes reported.

Are we to conclude, then, that all three interventions are ineffective? It is erroneous to conclude that “no evidence of effect” is the same as “evidence of no effect.” The distinction between no evidence and no effect applies somewhat differently to each intervention.

- While the overall results of GAIT show no benefit, in the subgroup of knee OA patients with moderate-to-severe pain at baseline, the combination of glucosamine hydrochloride and chondroitin sulfate significantly improved pain. Although this subgroup analysis was not explicitly prespecified in the GAIT protocol, the stratified randomization by disease severity yields statistically valid comparisons. The nonsignificant statistical result in the celecoxib arm in the same patient subgroup may be a function of insufficient power. Given the small number of patients in the moderate-to-severe subgroup, and the large number of such patients in the general population, a further trial can be justified. These subgroup results, although suggestive, do not override the overall results of GAIT, which must stand unless equally compelling evidence of benefit to a selected subgroup is produced.
- The existing evidence does not definitively show that arthroscopic lavage with or without debridement is only as effective as placebo. However, additional placebo-controlled RCTs showing clinically significant advantage for arthroscopy would be necessary to refute the Mosley results, which show equivalence between placebo and arthroscopy. The recently published (Weinstein, Tosteson, Lurie, et al., 2006) Spine Patient Outcomes Research Trial (SPORT) offers an alternative study design that could be informative, a rigorous RCT comparing surgery to conservative management, rather than sham.
- The existing evidence leaves uncertainty whether viscosupplementation achieves minimal clinically important improvement compared to placebo. Higher-quality trials are in the minority and show smaller effects; there are numerous patients lost to follow-up, and a substantial portion of studies (25 percent of total patients) have not been published as full-text articles. The clinical significance of reported changes in pain and function scores is uncertain, as almost all studies compare only mean difference between arms. Although the overall pooled estimate suggests that hylan G-F 20 may have a larger effect than other hyaluronans, whether this represents a meaningful clinical effect or limitations in the quality and completeness of study reporting is unknown. A rigorous RCT that showed strong evidence of improvement in pain and function would be necessary to conclude that viscosupplementation is beneficial.

Overall, our recommendations for future research reach beyond the specific treatments addressed in this report, and are intended broadly to improve the quality of research and reporting on interventions for osteoarthritis of the knee.

## Minimal Clinically Important Improvement in Pain and Function Should be the Measure of Success for all Trials

Clinically meaningful results require outcome measures establishing that patients experience improvement that is important to them—meaningful clinically important improvement. The range of magnitude of improvement clinically important to patients has been estimated for VAS pain and WOMAC measures, while to a lesser degree for the Lequesne Index (see Methods). Few RCTs reported results in terms of response: the proportion achieving a meaningful clinically important improvement in pain and function. The vast majority of trials compared only mean change between groups. Follow up duration and intervals for measurement, appropriate to each intervention, should be established by expert consensus.

Common measures and intervals will produce a more robust body of cumulative evidence and improve the ability to compare and pool results among trials. As a result of the variety of measures and intervals used in primary studies, meta-analyses available for this type of evidence often report pooled outcomes as the standardized mean difference, a statistical construct that lacks meaning to clinicians and patients.

## Unpublished Studies Should be Made Available as Full-Text Publications

Among RCTs of viscosupplementation, those that have not been published in full-text comprise approximately 25 percent of the total patient population. Several meta-analyses of glucosamine report that trials of the Rotta product, glucosamine sulfate, show outcomes superior to trials of glucosamine hydrochloride. Yet key studies that provide some of the data supporting superior efficacy have not been published as full-text studies. Existing studies should be published in full. Finally, all trials should be registered at inception at ClinicalTrials.gov along with anticipated date for full release of results.

## The Pitfalls of Meta-Analysis Should be More Widely Recognized and Acknowledged

Our evidence report draws heavily on six study level meta-analyses of glucosamine/chondroitin and five of viscosupplementation. While we used a validated instrument to appraise the quality of the systematic reviews, the instrument does not address the question of when meta-analysis is appropriate to a systematic review. Meta-analysis is a technique with underlying assumptions that may or may not hold when a particular collection of results are pooled. Furthermore, meta-analyses may fail to convey the real uncertainty and potential bias accompanying pooled estimates.

In many respects, the focus on meta-analysis in the systematic reviews available for this evidence report, served to obscure the overall weakness of the primary literature. For example, the Oxman and Guyatt meta-analysis quality assessment tool asked if conclusions made by authors were supported by the data. However, the tool does not adequately address whether quality concerns of the underlying literature were incorporated into conclusions, which was a frequent flaw in the meta-analyses reviewed here. Building on the Oxman and Guyatt tool, Shea, Grimshaw, Wells et al. 2007 have developed a new scale which more clearly assesses whether conclusions took appropriate account of the quality of included studies and the potential for publication bias.

For RCTs of both glucosamine/chondroitin and viscosupplementation, potential sources of bias included lack of reporting intention-to-treat results, high drop-out or loss to follow-up rates, poor quality, and lack of a priori sample size calculations. A number of these characteristics were noted by meta-analysts to influence results.

Uncertainty in the magnitude of effects pooled is influenced by factors intrinsic to the underlying trials. Among these are variable patient characteristics, trial characteristics, and the indication that a few trial results were outliers and influential on pooled estimates. The meta-analyses frequently reported high inter-trial heterogeneity. Random effects models were used in the face of high heterogeneity, but a consequence is to increase the influence of smaller trials on the pooled results. The meta-analyses did not address a threshold question, one that has not been clearly resolved by practitioners of meta-analysis: when is heterogeneity too high to justify pooling trial results. A related concern is the practice of reporting on multiple outcome measures and time intervals, which may be represented by a small portion of studies, thus potentially introducing bias.

## Specific Research Recommendations

Table 91 summarizes recommendations for future research on interventions addressed in this report, using the “Evidence, Population, Intervention, Comparison, Outcome, Timestamp,” or “EPICOT” framework (Brown, Brunnhuber, Chalkidou, et al., 2006). Note that all the recommendations in Table 91 delineate the evidence that is needed to establish that each of these interventions achieve a clinically meaningful improvement in OA of the knee. However, our population is aging, there is increasing prevalence of obesity, and increasing burden of knee osteoarthritis, together with inconsistent evidence regarding disease treatments. Given the public health impact, research on new approaches to prevention and treatment should be given high priority.

Table 91 Future Research Recommendations for Osteoarthritis of the Knee --- EPICOT Framework

| Viscosupplementation | Glucosamine/Chondroitin | Arthroscopy
Evidence (What is the current state of the evidence?) | Current evidence consists largely of trials with high loss to follow-up and lack rigorous measurement to test whether intra-articular hyaluronans achieve meaningful clinically important improvement in pain and function. The evidence does not clearly demonstrate that intra-articular hyaluronans achieve clinically significant improvement in pain and function compared to placebo. | Based on GAIT, neither glucosamine, chondroitin or their combination provide meaningful clinically important improvement in pain or function. | A single placebo-controlled RCT found arthroscopic lavage with or without debridement to be equivalent to placebo.
| A rigorous multi-center RCT, preferably with independent sponsorship, is needed to either establish or refute whether hylan G-F 20 is beneficial. | A subgroup analysis found that the combination of glucosamine hydrochloride and chondroitin sulfate significantly improved pain in patients with moderate-to-severe OA of the knee. Given the small number of patients in the moderate to severe subgroup, and the large number of such patients in the general population, confirmation in a large, rigorous multi-center RCT, preferably with independent sponsorship, is desirable. | Adverse events have not been systematically studied.
| Adverse events, reportedly uncommon, have not been systematically studied. | No conclusions concerning metabolic effects of chronic glucosamine use in the general population can be drawn.
Population (What is the population of interest?) | Individuals with OA of the knee of varying severity. Future trials should be accompanied by stratified randomization according to disease severity and duration. | Individuals with moderate-to-severe OA of the knee. Inclusion of diabetic individuals with metabolic testing and long-term observational follow-up. | The target population consists of patients with clinically diagnosed OA of the knee and who have tried conservative treatments with transient or unsatisfactory results.
Intervention (What are the interventions of interest?) | Pooled estimate suggests effect obtained with hylan G-F 20 may be larger than with other hyaluronans, whether this represents a meaningful clinical effect or study limitations is unknown. | 1 glucosamine hydrochloride and chondroitin sulfate; 2 glucosamine sulfate, preferably the Rotta product | Arthroscopic lavage, with or without debridement,