# Methods

This report is a systematic review of the effectiveness of three technologies to treat osteoarthritis (OA) of the knee: intra-articular hyaluronan injections (viscosupplements), enteral glucosamine and chondroitin given alone or in combination, and arthroscopic lavage and debridement. This chapter describes the search strategies used to identify literature; criteria and methods used for selecting eligible articles; methods for data abstraction; methods for quality assessment; and, finally, the process for technical expert advice and peer review.

The methods of this review are generally applicable to all Key Questions. However, as noted, there were variations in specific aspects of the methods as necessary to satisfy requirements of each question.

## Peer Review

A technical expert panel provided consultation for the systematic review and reviewed the draft report. The draft report was also reviewed by 12 external reviewers, including invited clinical experts and stakeholders (Appendix D *). Revisions were made to the draft report based on reviewers' comments.

* Appendixes cited in this report are available electronically at http://www.ahrq.gov/clinic/tp/oakneetp.htm

## Study Selection Criteria

This Evidence Report takes a tiered approach to evidence of the effectiveness of the three key interventions. The primary focus is on whether interventions have beneficial effects exceeding those of a comparative placebo. We first determined whether existing systematic reviews and meta-analyses adequately addressed the Key Questions and whether they identified all relevant primary studies. If additional primary studies are found, this Evidence Report integrates their findings with systematic reviews and meta-analyses. If evidence from randomized, placebo-controlled trials (RCTs) clearly shows benefits beyond placebo, then comparisons between these interventions and other active interventions would be relevant.

The diagram in Figure 1 describes how reviewers proceeded through this systematic review, beginning with applying study selection criteria to literature search results. Further steps included data extraction and summary (see Data Extraction and Analysis), quality assessment (see Assessment of Study Quality), and finally evidence synthesis and interpretation. Assessment of the quality of RCTs and meta-analyses is an important part of how we conducted this review; however, interpretation of the body of evidence for a particular class of interventions entailed more than that. Quality assessment informed the critical appraisal of the results and conclusions of meta-analyses, but rating classes did not give a complete picture of the strength of the body of evidence. Beyond quality ratings, we explored the methodologic strengths and weaknesses of RCTs and meta-analyses, inquired whether meta-analyses addressed the clinical importance of treatment effects, and assessed how well meta-analyses attempted to explain hetereogeneity of effects. All of these activities contributed to interpreting the overall strength of the evidence and determining whether conclusions could be drawn with respect to key questions.

Figure 1. Systematic review process

### Types of Studies

We sought systematic reviews, meta-analyses, RCTs, including abstracts of unpublished placebo-controlled RCTs, examining the clinical effectiveness of one or more of the interventions of interest among patients with primary or secondary OA of the knee; and reporting at least one outcome of interest.

RCTs had to be published either as articles in any language or English-language abstracts (if the study was only presented as an abstract). No minimum number of patients per study arm was required for RCTs. Because there were few RCTs available to address arthroscopy and Key Question 4 (comparative outcomes), we sought additional study designs. For arthroscopy, we also sought English-language articles of nonrandomized comparative trials (i.e., quasi-experimental studies), administrative database analyses, and case series with samples of 50 or more. For Key Question 4, we sought randomized and nonrandomized comparative studies.

Studies were excluded if no outcome of interest to this review was reported. Studies were also excluded if the patient population of interest was fewer than 80 percent of included patients, or, alternatively, results for the patient population of interest were not separately reported. When multiple reports were available for the same study, it was counted as a single trial and outcome data from the report with the longest followup were used.

### Types of Participants

The populations of interest are patients with primary or secondary OA of the knee, as defined by the American Academy of Orthopaedic Surgeons (American Academy of Orthopaedic Surgeons, 2004):

- Primary osteoarthritis of the knee is a process in which articular degeneration occurs in the absence of any obvious underlying abnormality (unknown cause); and
- Secondary OA is often the result of injury (trauma) or repetitive motion in certain occupations, but it can also result from congenital conditions and systemic metabolic diseases, endocrine diseases, bone dysplasias, and calcium crystal deposition diseases.

Subpopulations of interest include: age, race or ethnicity, sex, disease severity and duration, weight (body mass index), and prior treatments

### Types of Interventions

#### Glucosamine or Chondroitin

- Enteral (i.e., orally administered) glucosamine (sulfate or hydrochloride) given alone
- Enteral chondroitin given alone
- Enteral glucosamine and chondroitin given in combination.

Glucosamine is given orally at 1,500 mg daily, usually as a single dose, or divided into two or three doses. Chondroitin is administered orally, usually a total of 800 to 1,200 mg daily, or in divided doses. At minimum, treatment duration is 1 to 3 months, and may be continued indefinitely if the patient experiences improvement.

Intra-Articular Injections Hyaluronan Preparations. The first group of products, derived from sodium hyaluronate, is the most commonly used viscosupplement in RCTs and is followed by hylan G-F 20 as the next most common class. Additionally, unapproved non-animal stabilized hyaluronic acid (NASHA) derived from streptococci has been used in two RCTs (Altman, Akermark, Beaulieu, et al., 2004; Pham, Le Henanff, Ravaud, et al., 2004). One trial (Petrella, DiSilvestro, Hildebrand, et al., 2002) administered a hyaluronan that is not approved by the U.S. Food and Drug Administration (FDA). Intra-articular injections performed in RCT protocols were most often weekly for 3 to 5 weeks, although different schedules also were used.

Arthroscopy. Studies were selected if arthroscopic treatment of OA involved lavage with or without debridement, and debridement was not specifically required to include procedures beyond nonabrasion chondroplasty and removal of loose bodies. Thus, studies were excluded if they focused only on arthroscopic meniscectomy or abrasion chondroplasty, for example.

### Types of Outcomes

Primary Outcomes. The primary outcomes of interest are:

- Pain severity or intensity
- Self-reported physical function
- Patient global assessment
- Quality of life.

Secondary Outcomes. Secondary outcomes of interest include:

- Need for or time to total knee replacement or other surgeries.
- Concomitant analgesic use.

Harms or Adverse Effects. Any adverse events reported, including:

- Hyaluron Preparations. Local: injection site redness, edema, pain, joint swelling, joint stiffness, worsened osteoarthritis, infection, pseudoseptic reactions. Systemic: severe acute inflammatory reaction or pseudosepsis, anaphylaxis, arthralgias, rash, urticaria, back pain, headache.
- Glucosamine and Chondroitin. Alterations in blood glucose, hypersensitivity reactions, and local gastrointestinal toxicities.
- Arthroscopy. Infection, prolonged drainage from arthroscopic portals, effusion, hemarthrosis and deep vein thrombosis.

### Pain and Function Measurement Issues

Instruments. Pain and function should be measured by instruments with established validity and reliability. Although results are frequently reported as mean change in the intervention compared to control arms, this is not the preferred method of measuring outcomes. More informative, is a comparison of response, that is the proportion of patients achieving an improvement that is established representing a minimum clinically important improvement. (Tubach, Wells, Ravaud, et al., 2005).

Among established instruments, pain severity may be assessed by a visual analog scale (VAS) or a numeric rating scale (NRS) or from a subscale included in a knee-specific validated OA instrument. The horizontal 100-mm VAS has a left-hand or 0-mm endpoint labeled “no pain” and a right-hand or 100-mm endpoint usually labeled with a statement such as “extreme pain” or “pain as bad as it could possibly be.” While the amount of improvement required may not be definitively established (Tubach, Ravaud, Baron et al. 2005; Pham, van der Heijde, Altman, et al. 2004), the best available estimates for OA of the knee are between 20 and 40 percent improvements have been used in hyaluronan and glucosamine/chondroitin trials (Nuestadt et al. 2005, Altman et al. 2004, Clegg et al). A clinically significant change in VAS score depends on the baseline pain (Campbell and Patterson, 1998). For example, in knee OA an absolute 20 mm or 40 percent relative reduction in VAS pain score could be considered a minimal clinically important improvement (MCII) (Tubach, Wells, Ravaud, et al., 2005) and define clinically meaningful response. Accordingly, a decrease of 10–12 mm may be clinically significant from a baseline of 25 mm, while a reduction of 20–31 mm may be necessary to achieve a clinically significant reduction for patients with high baseline pain (e.g., VAS 75–100 mm).

Among 2 widely used OA instruments, the Western Ontario and McMaster University Osteoarthritis Index (WOMAC, McConnell, Kolopack, and Davis, 2001; Bellamy, Buchanan, Goldsmith, et al., 1988) evaluates 3 dimensions, pain, stiffness, and physical function with 5, 2, and 17 questions, respectively. WOMAC assesses pain using either the sum of scores from 5 items or the VAS. WOMAC outcomes can be based on the total, or a subset score. A 20- to 40-percent reduction in the WOMAC pain subscore is a positive response criterion for pain used in knee OA studies and represents achieving a MCII (Tubach, Wells, Ravaud, et al., 2005).

Another commonly used OA instrument is the Lequesne Index, a validated numerical scale in which points are assessed for various levels of pain, distance walking, and ability to perform activities of daily living (Lequesne, Mery, Samson, et al., 1987). It sums scores from 5 adjectival items, producing scores ranging from 1 to 24 points. The severity of handicap related to the knee can be categorized by point score: mild (1–4 points); moderate (5–7 points); severe (8–10 points); very severe (11–13 points); and extremely severe (>14 points) (Bellamy, 1993). What constitutes a MCII is likely approximately 20 percent (Bellamy, 1993).

Physical function may be appraised through reported difficulty performing specific daily activities affected by knee OA (Bellamy, Buchanan, Goldsmith, et al., 1988; Lequesne, Mery, Samson, et al., 1987). Patient global assessment (generally defined as the “patient's assessment of overall disease activity or improvement”) can be assessed by VAS, NRS, or other specific instruments (Pham, van der Heijde, Altman, et al. 2004). The MCII for patient global assessment on a 100 mm VAS has been suggested to be 18 mm, or a relative improvement of 40 percent.

Both generic measures and disease-specific quality of life (QOL) measures may be relevant (Salaffi, Carotti, and Grassi, 2005) assessing disease impact. The SF-36 and Arthritis Impact Measurement Scales (Meenan, 1986) are acceptable scales to assess the impact of osteoarthritis on QOL.

Pooled Outcome Measures. Meta-analyses may pool outcome measures using the metric of the original scale, or a metric related to it.

The “weighted mean difference” (WMD) combines (pools) differences between treatment and control from multiple trials on the scale of the original instrument. It can be reported as either a difference between treatment and control at some followup time or a difference in change scores. While intuitive to interpret as a difference or difference in change for some outcome measure, the WMD has doe not define proportions achieving a MCII or response (Senn 1997, page 226; Tubach, Ravaud, Giraudeau 2005).

“Relative risks” (or the approximately equal odds ratio) can be pooled for dichotomous outcome measures (e.g., patient global assessment and adverse events). It is a ratio comparing the outcome probability among treated compared placebo groups. The relative risk clearly conveys increased risk, but does not directly reflect clinical benefit in terms of response unless a comparison of meaningful clinical response rates.

“Sums of differences” in outcome measures between treatment and placebo groups (e.g., pain and function) over the course of a study can also be pooled. The measure is expressed as a percentage reflecting how much greater relief is provided by treatment compared to placebo. Although commonly used in pain research, the measure does not have direct clinical meaning with respect to response.

“Standardized effect sizes” expressed as differences or differences in change, standardized by their variability (divided by the standard deviation) can also be pooled. Standardized effect sizes are typically used when scales pooled have different metrics (e.g., a 0- to 100-mm VAS and a 25-point WOMAC scale). The clinical meaning of standardized effect sizes when different scales are pooled and variability differs across studies is difficult to intuit. While small, medium, and large referents corresponding to 0.3, 0.5 and 0.8, respectively, were suggested by Cohen (1988), they pertain to sample size calculations not clinical meaning, and were qualified substantially.^*^ Others have pointed out problematic aspects of standardized effect sizes including: incomparability across studies (Rothman and Greenland, 1998) and that studies with identical results may appear to differ (Greenland, Schlesselman, Criqui, 1986). Most importantly, one cannot infer individual response Senn (1997).^†^

* “For each statistical test's ES [effect size], the author proposes, as a convention, ES values to serve as operational definitions the qualitative adjectives ‘small,’ ‘medium,’ and ‘large.’ This is an operation fraught with many dangers: The definitions are arbitrary, such qualitative concepts as “large” are sometimes understood as absolute, sometimes as relative; and thus they run a risk of being misunderstood...” (Cohen, 1988, page 12.)

† “The probability associated with an effect size calculates the probability of observing such a superiority [of treatment A over B]. However, to know whether a given patient will be better off treated with A or B, or even to know what proportion of patients will be better off is quite another matter. No simple comparison of means whether scaled by the standard deviation or not can answer this question.” (Senn 1997, page 226.)

## Search Strategy and Review

### Search Strategy

Electronic Databases. The following databases were searched for citations. The full search strategy is displayed in Appendix A *. The search was not limited to English-language references; however, foreign-language references without abstracts were disregarded.

- MEDLINE^®^ (through March 29, 2007)
- EMBASE (through March 16, 2006)
- Cochrane Controlled Trials Register (through November 27, 2006).

EMBASE was updated with abbreviated searches through November 27, 2006.

Additional Sources of Evidence. The Technical Expert Panel and individuals and organizations providing peer review were asked to inform the project team of any studies relevant to the key questions that were not included in the draft list of selected studies.

We examined the bibliographies of all retrieved articles for citations to any RCT that was missed in the database searches. In addition, we sought RCTs published in conference proceedings and abstracts from the American Association of Orthopaedic Surgeons (AAOS), American College of Rheumatology (ACR) and the Osteoarthritis Research Society International (OARSI) over the past 2 years. We also consulted product inserts of U.S.-marketed viscosupplement products.

### Search Screen

Search results were stored in a ProCite^®^ database. Using the study selection criteria for screening titles and abstracts, a single reviewer marked each citation as either: (1) eligible for review as full-text articles, (2) ineligible for full-text review, or (3) uncertain. Citations marked as uncertain were reviewed by a second reviewer and resolved by consensus opinion, with a third reviewer to be consulted if necessary. Using the final study selection criteria, review of full-text articles was conducted in the same fashion to determine inclusion in the systematic review. Of 1,842 citations, 451 articles were retrieved and 98 selected for inclusion (Figure 2). Records of the reason for exclusion for each paper retrieved in full-text, but excluded from the review, were kept in the ProCite^®^ database (see Appendix B *, Excluded Studies).

Figure 2. QUOROM flow diagram

## Data Extraction and Analysis

### Data Elements

The data elements below were abstracted, or recorded as not reported, from intervention studies. Data elements to be abstracted were defined in consultation with the Technical Expert Panel.

Data elements from intervention studies (RCTs and quasi-experimental studies) include:

- Critical features of the study design (for example, patient inclusion/exclusion criteria, number of participants, allocation method (including concealment), use of blinding)
- Patient characteristics (age, gender, race/ethnicity, body weight, primary or secondary disease. disease duration)
- Measures of disease severity
- Treatment protocols (for example, dose, frequency, duration, extent of arthroscopic surgery, other prior and concurrent treatments)
- Patient monitoring procedures (for example, followup duration and frequency, outcome assessment methods) and
- The specified key outcomes and data analysis methods
- Results
- Funding source.

Data elements from systematic reviews and meta-analyses include:

- Use of a protocol
- The study question (patients, interventions/comparisons, outcomes)
- Literature search strategy
- Study inclusion/exclusion criteria
- Data extraction methods
- Assessment of study quality
- Methods of data synthesis/analysis
- Funding source.

Data elements from case series include:

- Clinical question
- Enrollment of patients (consecutive or otherwise)
- Whether a single-center or multicenter study
- Patient selection criteria and sample characteristics
- Intervention
- Length of followup
- Validated outcome measures and independence or blinding of outcome assessment
- Statistical analyses
- Results.

### Evidence Tables

Templates for evidence tables were created in Microsoft Excel^®^ and Microsoft Word^®^. One reviewer performed primary data abstraction of all data elements into the evidence tables, and a second reviewer reviewed articles and evidence tables for accuracy. Disagreements were resolved by discussion, and if necessary, by consultation with a third reviewer. When small differences occurred in quantitative estimates of data from published figures, the values obtained by the two reviewers were averaged.

## Assessment of Study Quality

### Definition of Ratings Based on Criteria

In consultation with the AHRQ Task Order Officer and Technical Expert Panel, the general approach to grading evidence developed by the U.S. Preventive Services Task Force (Harris, Helfand, Woolf, et al. 2001) were applied to primary studies. The quality of the abstracted studies was assessed by two independent reviewers. Discordant quality assessments were resolved with input from a third reviewer, if necessary.

### Primary RCTs and Quasi-Experimental Studies

The quality of RCTs and quasi-experimental studies were assessed on the basis of the following criteria:

- Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups
- Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders, intention-to-treat analysis.

Definition of Ratings Based on Above Criteria. The rating of intervention studies encompasses the three quality categories described here:

- Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, for RCTs, intention-to-treat analysis is used.
- Fair: Studies were graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: In general, comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is done for RCTs.
- Poor: Studies were graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention-to-treat analysis is lacking.

### Systematic Reviews and Meta-Analyses

Assessment of the quality of systematic reviews and meta-analyses were guided by a quality rating method reported by Oxman and Guyatt (1991; Overview Quality Assessment Questionnaire).^*^ Oxman and Guyatt tool results in a quality score, based on the answers to ten questions that provide information on the content of a review in terms of how it was conducted, as follows:

1 Were the search methods used to find evidence on the primary question(s) stated?
2 Was the search for evidence reasonably comprehensive?
3 Were the criteria used for deciding which studies to include in the overview reported?
4 Was bias in the selection of studies avoided?
5 Were the criteria used for assessing the validity of the included studies reported?
6 Was the validity of all the studies referred to in the text assessed using appropriate criteria?
7 Were the methods used to combine the findings of the relevant (to reach a conclusion) reported?^*^
8 Were the findings of the relevant studies combined appropriately relative to the primary question of the overview?
9 Were the conclusions made by the author(s) supported by the data and/or analysis reported in the overview?
10 What was the overall scientific quality of the overview? Use the following scoring scale:

* Our original protocol included analysis of the quality of meta-analysis reporting according to the QUOROM (Moher, Cook, Eastwood, et al., 1999). However, we have not included this analysis because QUOROM was not generally available or in widespread use when the earlier meta-analyses were published.

The following guidelines are used to apply the Oxman and Guyatt rating:

Question 1: | Literal interpretation.
Question 2: | For a search to be considered comprehensive the methods used to perform the search should include searching for unpublished material as well as multiple medical databases (at least EMBASE and MEDLINE^®^). If only published material was searched for, the search should be marked “partially.” A look through bibliographies, conference proceedings, or trial registries is deemed adequate as a search for unpublished literature. The search must not be limited to the English language.
Question 3: | Should specify defining population, intervention, principal outcomes, and study design to be “yes;” if only 2 or 3 of these are noted, it should be scored “partially” here.
Question 4: | Must be “yes” on 2 and 3 and dual review to be “yes” here; if “no” on 2 or 3 must be “no” here; if “partially” or “can't tell” on 2 and 3 then must be the same here.
Question 5: | Must use some cited validity tool for “yes” here.
Question 6: | Scales used must be appropriately applied to study type for “yes” here.
Question 7: | An appropriate pooling method and test for heterogeneity must be described for “yes” here; were “partially” if a pooling method but no heterogeneity testing method is specified.
Question 8: | If no attempt has been made to combine findings, and no statement is made regarding the inappropriateness of combining findings, check “no.” If a summary (general) estimate is given anywhere in the abstract, the discussion, or the summary section of the paper, and it is not reported how that estimate was derived, mark “no,” even if there is a statement regarding the limitations of combining the findings of the studies reviewed. If in doubt, mark “can't tell.” To determine whether it is appropriate to use random or fixed effects model, the study should address the question of how much heterogeneity would be considered (addressing clinical and statistical aspects of heterogeneity).
Question 9: | If 8 is “no,” 9 must be “no.” If 8 is “can't tell,” 9 must be “can't tell.” For an overview to be scored as “yes” on Question 9, data (not just citations) must be reported that support the main conclusions regarding the primary question(s) that the overview addresses.
Question 10: | The overall scientific quality should be based on the answers to the first 9 questions. The following guidelines can be used to assist with deriving a summary score: if the “can't tell” option is used one or more times on the preceding questions, a review is likely to have minor flaws at best, and it is difficult to rule out major flows (i.e., a score ≥4). If the “no” option is used on Questions 2, 4, 6, or 8, the review is likely to have major flaws (i.e., a score of ≥3, depending on the number and degree of the flaws).

It should be noted that a new quality assessment tool for systematic reviews and meta-analyses was recently developed (Shea, Grimshaw, Wells, et al., 2007). It was based, in part, on the work of Oxman and Guyatt, but differs in significant ways. In particular, the Oxman and Guyatt tool does not adequately address whether quality concerns of the underlying literature were incorporated into conclusions. The tool by Shea, Grimshaw, Wells, et al. (2007) more clearly assesses whether conclusions took appropriate account of the quality of included studies and the potential for publication bias. The recently developed tool was unavailable during the time when ratings of meta-analyses were performed for this evidence report.

### Case Series

The quality of included case series was assessed based on a set of study characteristics proposed by Carey and Boden (2003, Table 2), as follows:

- Clearly defined question
- Well-described study population
- Well-described intervention
- Use of validated outcome measures
- Appropriate statistical analyses
- Well-described results
- Discussion and conclusion supported by data
- Funding source acknowledged.

Table 2 Carey and Boden case series quality assessment tool

Clearly Defined Question | Well-Described Study Population* | Well-Described Intervention | Use of Validated Outcome Measures | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
Question should be appropriate to study design; | Case definition (diagnostic criteria); type of criteria (clinical, radiographic); whether criteria used before (reference); explicit inclusion/exclusion criteria; | Sufficiently clear that another center could replicate study; if not identified in detail, should provide references; | Reference to previous validation; | Statistical tests and power calculations aimed at improvement over time; prepost analysis should take into account paired nature of data; | Utilize only validated outcome measures; | Conclusion should be supported by the data in the article | Funding source should be disclosed in addition to consulting or board relationship with manufacturer
should not be stated in terms of effectiveness; | includes standard information (age; sex; socioeconomic status; stage and duration of disease; comorbidities; n; time to accrual; exclusions and reasons; loss to followup; refusal) | cointerventions should be described in reasonable detail | ideally individual assessing patient's outcome should be masked to specific intervention; alternatively, assessor who is not in direct employ of clinical office; | comparisons with historical controls should take into account differences in cointerventions between time periods; | description of adequacy of followup (number lost to followup, number who switch to another provider or pursue other treatments, number who die from other causes); | where other information is used to buttress conclusions, should be explicitly stated and referenced;
best when focused; | | | standardized length and intervals of observation and of sufficient duration to be clinically meaningful; justification for the duration of followup | attention to nonspecific effects and inability to distinguish procedure's effect from spontaneous improvement; | [adaptation: inclusion of both potentially beneficial outcomes (symptom/function/quality of life) and adverse events] | limitations should be made explicit;
| | | | avoids over-reliance on those variables showing improvement; | | description of specific next research steps (e.g., need for RCT, details of RCT) [adaptation: this element disregarded]
| | | | analysis should address multiple comparisons

* OA criteria noted; minimum set of characteristics: age, sex, disease duration and preop severity described.