# Introduction

This is a systematic review of three treatments for osteoarthritis (OA) of the knee: intra-articular injections of viscosupplements; oral glucosamine, chondroitin or the combination; and, arthroscopic lavage and debridement. The key questions are: (1) effectiveness and harms in primary OA of the knee, (2) in secondary OA of the knee, (3) in subpopulations, and (4) comparison of the three interventions. This section outlines the burden of illness and clinical management of osteoarthritis of the knee, the interventions of interest and uncertainties, and overviews key questions to be addressed.

## Burden of Illness

According to the U.S. Centers for Disease Control and Prevention (CDC), an estimated 22 percent of adults (46 million) in the United States have doctor-diagnosed arthritis (Centers for Disease Control and Prevention, 2006). Earlier figures suggest approximately 11 percent of the population 64 years and older has symptomatic OA of the knee (Manek and Lane, 2000). Symptoms of OA typically begin after age 40 and progress slowly, with radiographic evidence of the disease present in the majority of the population by 65 years of age and in approximately 80 percent of the population age 75 years and older. OA of the knee is more common in women than in men, with risk factors that include obesity, previous knee injury or surgery, and occupational bending and lifting (Felson, 2006; Centers for Disease Control and Prevention, 2005).

Loss of joint function as a result of OA overall is a major cause of work disability and reduced quality of life. The CDC estimates that osteoarthritis and related arthritic conditions cost the U.S. economy nearly $81 billion per year in direct medical care, with indirect expenses of about $47 billion that include lost wages and production (Centers for Disease Control and Prevention, 2004). CDC figures further estimate the total annual direct cost of OA and related conditions per person is approximately $1,752.

## Clinical Management

### Pathophysiology

The term “osteoarthritis” refers to a heterogeneous group of joint disorders, usually signaled by symptoms of pain and stiffness. It involves both destructive and reparative metabolic processes, with a variety of biochemical triggers in addition to mechanical injury of the joint (Mandelbaum and Waddell, 2005). It is thought that inflammation does not play a primary role in osteoarthritis, although it may be present. When inflammation occurs, it is generally mild (Hochberg, Altman, Brandt, et al., 1995b). The pathogenesis of OA is not fully understood, although multiple contributing factors are recognized including genetic, environmental, metabolic, and biomechanical factors (Kraus, 1997).

Although OA eventually involves all joint structures, it begins with damage and progressive degradation of articular hyaline cartilage structure and function (chondropenia), typically in a nonuniform, focal manner (Felson, 2006). As chondropenia progresses in localized areas, stress increases across the entire joint, further damaging and eroding cartilage. In areas with full-thickness cartilage loss, abnormal remodeling and attrition of subarticular bone commences, typically accompanied by growth of osteophytes. Synovitis, ligamentous laxity, and periarticular muscle weakness may also occur, eventually leading to joint tilting and malalignment. Malalignment is a risk factor for joint failure, hastening structural deterioration of the joint by increasing local loading forces.

The symptoms of OA result from abnormal stresses on the weight-bearing joints or normal stresses on weakened joints, becoming progressively worse and more frequent with age. The typical joints involved with osteoarthritis include the large, weight-bearing joints such as the hip and knee, as well as selected smaller joints in the hands, feet, and spine.

### Classification

Osteoarthritis may be broadly categorized as primary (idiopathic) or secondary. According to the American Academy of Orthopaedic Surgeons, primary OA of the knee can be defined as a process in which articular degeneration occurs in the absence of an obvious underlying abnormality (American Academy of Orthopaedic Surgeons, 2004). Secondary OA of the knee is often the result of injury (trauma) or repetitive motion such as found in certain occupations. It can also result from congenital conditions and underlying diseases, including include systemic metabolic diseases, endocrine diseases, bone dysplasias, and calcium crystal deposition diseases. Secondary OA is more likely to manifest itself at an earlier age than primary OA, and may be an initial clue to the presence of a potentially dangerous and treatable systemic disease. While there is rationale for identifying two separate categories of OA, making a distinction between them does not alter clinical practice and therapeutic choices.

### Diagnosis

The diagnosis of osteoarthritis is established using a combination of clinical information derived from history, physical examination, radiologic, and laboratory evaluation. An algorithm of diagnostic criteria for osteoarthritis of the knee has been proposed by the American College of Rheumatology (ACR) (Altman, Asch, Bloch, et al., 1986). A diagnosis of OA of the knee is defined as presenting with pain, and meeting at least five of the following criteria:

- Patient older than 50 years of age
- Less than 30 minutes of morning stiffness
- Crepitus (noisy, grating sound) on active motion
- Bony tenderness
- Bony enlargement
- No palpable warmth of synovium
- Erythrocyte sedimentation rate (ESR) <40 mm/hr
- Rheumatoid factor <1:40
- Noninflammatory synovial fluid.

The presence of clinical symptoms of OA does not always correlate well with the degree of abnormality seen on radiographs. It has been noted that approximately 40 percent of patients who have severe X-ray findings report no symptoms, and conversely, patients with clinical symptoms may show no significant radiological changes (Balint and Szebenyi, 1996; Davis, Ettinger, Neuhaus, et al., 1992; Claessens, Schouten, van den Ouweland, et al., 1990).

### Treatment

Treatment for OA of the knee aims to alleviate pain and improve function in order to mitigate reduction in activity (American College of Rheumatology, 2000; Felson, 2006). However, most treatments do not modify the natural history or progression of OA, and thus are not considered curative. Nonsurgical modalities include education, exercise, weight loss, and various supportive devices; acetaminophen or nonsteroidal anti-inflammatory drugs (NSAIDs) such as ibuprofen; nutritional supplements (glucosamine and chondroitin); and, intra-articular viscosupplements.

Guidelines for the medical management of osteoarthritis emphasize the role of both nonpharmacologic and pharmacologic therapies (American College of Rheumatology, 2000; Jordan, Arden, Doherty, et al., 2003). Initial management involves nonpharmacologic therapies, including education, exercise, various appliances and braces, and weight reduction. Acetaminophen is recommended as first-line pharmacologic therapy. If pain relief is inadequate with acetaminophen, analgesic-dose NSAIDs may be used (e.g., ibuprofen, naproxen). If symptom response to a lower NSAID dosage is inadequate, higher, anti-inflammatory, doses may be used. Intra-articular corticosteroid injection may be considered when relief from NSAIDs is insufficient or the patient is at risk from gastrointestinal adverse effects. Injection of corticosteroids is frequently limited to three to four times per year per joint because of concern about the possibility of progressive cartilage damage through repeated injection in the weight-bearing joints (Neustadt, 1992).

If symptom relief is inadequate with conservative measures, invasive treatments may be considered. Operative treatments for symptomatic OA of the knee include arthroscopic lavage and cartilage debridement, osteotomy, and, ultimately, total joint arthroplasty (Day, 2005). Surgical procedures intended to repair or restore articular cartilage in the knee, including abrasion arthroplasty, microfracture techniques, autologous chondrocyte implantation, and others, are appropriate only for younger patients with focal cartilage defects secondary to injury (Clarke and Scott, 2003).

### Interventions Addressed in This Report

Intra-Articular Injections of Hyaluronic Acid Preparations. As shown in Table 1, five hyaluronan-based products are approved, all as class 3 devices, via U.S. Food and Drug Administration (FDA) premarketing application (PMA) approval. These products vary by molecular weight, with Hyalgan^®^, Supartz^®^, and Orthovisc^®^ on the lower to mid-range end (0.5–0.73 mDa, 0.6–1.2 mDa, and 1–2.9 mDa, respectively) and Synvisc^®^ on the upper end with a much greater molecular weight related to its cross-linked nature. Synvisc^®^ actually comprises two components (thus, the name “hylan gel-fluid 20”): (1) hylan A, which is a viscoelastic fluid with an average molecular weight of 6 mDa, and (2) hylan B, a hydrated gel, for which a molecular weight cannot be measured. For comparison, the molecular weight of hyaluronan in normal synovial fluid is about 0.2–0.5 mDa (Peyron, 1993).

Table 1 U.S. FDA-approved hyaluronan products and product information statements

Product | Regarding Treatment Course | Regarding Minimum # of Injections | Regarding Other Joints | Regarding Repeat Treatments
Hyalgan^®^ (sodium hyaluronate); Fidia Pharmaceutical | “A treatment cycle consists of five injections given at weekly intervals. Some patients may experience benefit with three injections given at weekly intervals.” | “The effectiveness of a single treatment cycle of less than 3 injections has not been established.” | “The safety and effectiveness of the use of Hyalgan^®^ in joints other than the knee have not been established.” | “Adverse experience data from the literature contain no evidence of increased risk relating to retreatment with Hyalgan^®^. The frequency and severity of adverse events occurring during repeat treatment cycles did not increase over that reported for a single treatment cycle....”
Original PMA date: 5/28/97 | | | | Hyalgan^®^ is the only hyaluronan with demonstrated safety in a 30-month, repeat use, open-label trial in which 75 patients received a cycle of 5 weekly injections of Hyalgan^®^ every 6 months.
MW: 0.5–0.73 million Da
Synvisc^®^ (hylan G-F 20); Genzyme Corporation | “Synvisc^®^ is administered by intraarticular injection once a week (one week apart) for a total of three injections.” | “The effectiveness of a single treatment cycle of less than three injections of Synvisc^®^ has not been established.” | “The safety and effectiveness of Synvisc^®^ in locations other than the knee and for conditions other than osteoarthritis have not been established.” | “The reactions seemed to occur more often when Synvisc^®^ was injected into the knee as a repeat set of injections than when Synvisc^®^ was injected as a first set of injections.”
Original PMA date: 8/08/97
MW: 6 million Da (hylan A)
Supartz^®^ (sodium hyaluronate); Seikagaku Corporation | “Supartz^®^ is administered by intraarticular injection once a week (one week apart) for a total of 5 injections.” | “The effectiveness of a single treatment cycle of less than 5 injections has not been established.” | “The safety and effectiveness of the use of Supartz^®^ in joints other than the knee have not been established.” | “The safety and effectiveness of repeat treatment cycles of Supartz^®^ have not been established.”
Original PMA date: 1/24/01
MW: 0.62–1.17 million Da
Orthovisc^®^ (sodium hyaluronate), Anika Therapeutics, Inc. | “Orthovisc^®^ is injected into the knee joint in a series of intraarticular injections one week apart for a total of three or four injections.” | The effectiveness of a single treatment cycle of less than 3 injections has not been established. Pain relief may not be seen until after the third injection. | “The safety and effectiveness of the use of Orthovisc^®^ in joints other than the knee have not been established.” | “The effectiveness has not been established for more than one course of treatment.”
Original PMA date: 2/04/04
MW: 1–2.9 million Da
Euflexxa^®^ (sodium hyaluronate), Ferring Pharmaceuticals | “A dose of 2 ml is injected intraarticularly into the affected knee at weekly intervals for three weeks, for a total of three injections.” | N/R | “Safety and effectiveness of injection in conjunction with other intraarticular injectables, or into joints other than the knee has not been studied.” | “The safety and effectiveness of repeated treatment cycles of EUFLEXXA™ have not been established.”
Original PMA date: (approved under the name Nuflexxa)
MW: 2.4–3.6 million Da

Da: Daltons; MW: molecular weight; PMA: premarket approval

Glucosamine and Chondroitin. Glucosamine is an aminomonosaccharide which is the principal component of O-linked and N-linked glycosaminoglycans, which comprise the matrix of all connective tissues, including cartilage (Biggee and McAlindon, 2004; Matheson and Perry, 2003; Hauselmann, 2001; Deal and Moskowitz, 1999). This compound historically has been derived by extraction of chitin, a component of crustacean shells, although is also is produced through fermentation of a vegetarian source. Chondroitin sulfate is a glycosaminoglycan with a polymerized disaccharide base linked to a sulfate moiety, and is a component of proteoglycans of articular cartilage. It is usually derived from bovine trachea, although other sources such as ovine or porcine trachea and shark cartilage are used. The mechanisms of action of these compounds are unknown, but it is speculated they may promote maintenance and repair of cartilage.

In the United States, glucosamine hydrochloride or sulfate and chondroitin sulfate are considered dietary supplements available in over-the-counter (OTC) products, which may vary substantially in content and purity from what is stated on the label (McAlindon, 2003). In European Union countries, glucosamine sulfate and chondroitin sulfate are regulated as prescription drugs. A number of clinical trials with positive outcomes either used glucosamine sulfate manufactured by an Italian firm, Rotta Research Laboratorium, or were financially supported by Rotta. It has been hypothesized that Rotta glucosamine sulfate has greater efficacy than the hydrochloride salt, and that the formulation is a key factor in trial outcome (Altman, Abramson, Bruyere, et al., 2006; Hochberg, 2006; McAlindon, 2003). Oral administration of glucosamine sulfate can increase serum and synovial fluid sulfate levels, whereas sodium sulfate does not. Absorbed sulfate is then used in the synthesis of proteoglycans and metabolic intermediates like coenzyme A and glutathione that are important for chondrocyte metabolism.

Arthroscopy. The term “arthroscopy” is often used collectively in reference to individual minimally invasive surgical procedures, joint lavage and articular debridement, which are performed using fine needles and an arthroscope (Gidwani and Fairbank, 2004; Gunther, 2001). Arthroscopic lavage is a palliative measure in which intra-articular fluid is aspirated and the joint is washed out, removing inflammatory mediators, debris, or small loose bodies from the osteoarthritic knee. Articular debridement involves removal of cartilage or meniscal fragments, but also can include cartilage abrasion, excision of osteophytes and synovectomy. Debridement is intended to improve symptoms and joint function in patients with mechanical symptoms such as locking or catching of the knee. Because lavage and debridement are often performed at the same time, it is difficult to attribute the success or failure of arthroscopy to a specific procedure.

## Key Questions for This Systematic Review

This systematic review of the literature will address the following questions regarding managing patients with OA of the knee with three interventions: intra-articular injections of viscosupplements; oral glucosamine and chondroitin; and, arthroscopic lavage and debridement.

1 What are the clinical effectiveness and harms of each intervention in patients with primary OA of the knee?
2 What are the clinical effectiveness and harms of each intervention in patients with secondary OA of the knee?
3 How do the short-term and long-term outcomes of each intervention differ by the following subpopulations: age, race/ethnicity, gender, primary or secondary OA, disease severity and duration, weight (body mass index), and prior treatments?
4 How do the short-term and long-term outcomes of each intervention compare for the treatment of primary OA of the knee; and secondary OA of the knee?