# Appendix D. Technical Expert Panel (TEP) and Reviewers

## Technical Expert Panel (TEP)

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

- Mathias P.G. Bostrom, M.D.
- Hospital for Special Surgery
- New York, NY
- (Nominated by the American Academy of Orthopaedic Surgeons)

- Warren Reid Dunn, M.D., M.P.H.
- Assistant Professor, Orthopaedics and Rehabilitation
- Assistant Professor, Medicine & Public Health
- Vanderbilt University Medical Center
- Nashville, TN

- David T. Felson, M.D., M.P.H.
- Chief
- Boston University Clinical Epidemiology Research Training Unit
- Boston, MA

- Marc C. Hochberg, M.D., M.P.H.
- Professor of Medicine
- Head, Division of Rheumatology & Clinical Immunology
- Professor of Epidemiology and Preventive Medicine
- University of Maryland School of Medicine
- Baltimore, MD

- Nancy E. Lane, M.D.
- Director and Distinguished Professor
- Aging Center, Medicine and Rheumatology
- University of California at Davis Medical Center
- Sacramento, CA

- Capt. Ernestine (Tina) Murray, R.N., M.A.S.
- Senior Health Policy Analyst
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Neil A. Segal, M.D.
- Assistant Professor and Staff Physiatrist
- Department of Orthopaedics & Rehabilitation
- University of Iowa
- Iowa City, IA

- Philip Sloane, M.D., M.P.H.
- Department of Family Medicine
- University of North Carolina at Chapel Hill
- Chapel Hill, NC

- Charles M. Turkelson, Ph.D.
- Director, Research and Scientific Affairs Department
- American Academy of Orthopedic Surgeons
- Rosemont, IL

## Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- David Atkins, M.D., M.P.H.
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Rowland W. Chang, M.D., M.P.H.
- Professor of Preventive Medicine
- Medicine, and Physical Medicine and Rehabilitation
- Northwestern University
- Feinberg School of Medicine
- Chicago, IL

- Gregory J. Dennis, M.D.
- Director, Clinical Care and Training
- National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS)
- National Institutes of Health
- Bethesda, MD
- (Nominated by the National Institute of Arthritis and Musculoskeletal and Skin Diseases)

- Kay Dickersin, Ph.D.
- Professor
- Director, Center for Clinical Trials
- Department of Epidemiology
- Johns Hopkins
- Bloomberg School of Public Health
- Baltimore, MD

- Peter Juhn, M.D., M.P.H.
- Executive Medical Director
- Johnson & Johnson
- New Brunswick, NJ

- Jeffrey N. Katz, M.D., M.S.
- Associate Professor of Medicine and Orthopaedic Surgery
- Chief, Section of Clinical Sciences
- Division of Rheumatology, Immunology and Allergy
- Brigham and Women's Hospital
- Boston, MA

- John Kirwan, M.D.
- Professor of Rheumatic Diseases
- Bristol Royal Infirmary Bristol
- UK

- Kathleen Kolsun, M.D.
- Assistant Director, Medical Affairs Orthopedics Division
- Ferring Pharmaceuticals
- Suffern, NY

- Jeffrey L. Kraines, M.D.
- Senior Medical Director
- Genzyme Corporation
- Cambridge, MA

- Stephan Lohmander, M.D., Ph.D.
- Professor and Senior Consultant
- Department of Orthopaedics, Clinical Sciences Lund
- Lund University
- Lund University Hospital
- Lund, Sweden

- Jamal Mikdashi, M.D.
- Assistant Professor of Medicine (Rheumatology)
- University of Maryland Medical Center
- Baltimore, MD

- Roland W. Moskowitz, M.D.
- Co-director
- Arthritis Translational Research Program
- Beachwood, OH
- (Nominated by the Arthritis Foundation)

- Lee S. Simon, M.D., Ph.D.
- Associate Clinical Professor of Medicine
- Harvard Medical School and
- Beth Israel Deaconess Medical Center
- Cambridge, MA