# Appendix C. Evidence Tables

## Part I: Viscosupplementation

Table IA Baseline Characteristics of Placebo-Controlled Randomized Trials of Intraarticular Viscosupplements Injections for Knee OA

Study | HA Derivative (Trade Name) | No. Pts Randomized | | Overall Mean Age (years) | Female Pts (%) | OA Diagnosis (criteria) | | | | OA Stage (%) | Mean Disease Duration (years) | Mean Baseline Pain Score
| | Tx | Plac | | | 1° | 2° | 1° | ? | | | Movement (VAS mm) | | Rest (VAS mm) | | WOMAC Pain Score
| | | | | | | | 2° | | | | Tx | Pl | Tx | Pl | Tx | Pl
Altman and Moskowitz (1998) | Sodium hyaluronate (Hyalgan) | 164 | 168 | 64 | 58 | x^1^ | | | | KL | ≥ 1 yr | 54 | 55 | NR | NR | NR | NR
| | | | | | | | | | 2–3
Altman et al (2004) | Non-animal stabilized hyaluronic acid (Durolane) | 173 | 174 | 62.9 (Tx) | 55 | | | | x^1^ | KL | 5.0 (0–45.5) (Tx) | NR | NR | NR | NR | 9.9 (6–15) | 10.4 (7–15)
| | | | 63.3(Plac) | | | | | | 2 (23) | 6.5 (0–50.5) (Plac)
| | | | | | | | | | 3 (54)
| | | | | | | | | | 4 (24)
Bragantini et al (1987) | Sodium hyaluronate (Hyalgan) | 39 joints | 18 joints | 57 | 75 | | | | x | KL | <1 (16%) | NR | NR | 40 | 40 | NR | NR
| | 55 pts total | | | | | | | | 2–4 | 1–5 (44%)
| | | | | | | | | | | 5–10 (16%)
| | | | | | | | | | | >10 (19%)
| | | | | | | | | | | NR (5%)
Brandt et al (2001) | Sodium hyaluronate (Orthovisc) | 114 | 112 | 66 | 63 | x^1^ | | | | KL | NR | NR | NR | NR | NR | 16 (5–25) | 16 (5–25)
| | | | | | | | | | 2–3
Bunyaratavej et al (2001) | Sodium hyaluronate (Hyalgan) | 24 | 25 | 60 | 78 | | | | x^1^ | KL | HA 2.5 (3.1) | 70 | 70 | NR | NR | NR | NR
| | | | | | | | | | 1–2 (62) | Plac 3 (3.4)
| | | | | | | | | | 3–4 (38)
Carrabba et al (1995) | Sodium hyaluronate (Hyalgan) | 60 | 40 | 60 | 63 | x^1^ | | | | NR | Plac≈2.4 (1.3) | 62(1inj) | 64 | 41 (1inj) | 44 | NR | NR
| | | | | | | | | | | 1inj 2.2 (1.3) | 64 (3inj) | | 45 (3inj)
| | | | | | | | | | | 3inj 2.3 (1.8) | 63 (5inj) | | 44 (5inj)
| | | | | | | | | | | 5inj 2.9 (1.3)
Cohen et al (1994) | Sodium hyaluronate (Hyalgan) | 19 | 20 | NR | NR | | | | x | NR | NR | NR | NR | NR | NR | NR | NR
Corrado et al (1995) | Sodium hyaluronate (Hyalgan) | 21 | 19 | 61 | 78 | | | | x^2^ | NR | ≥ 0.5 | 69 | 62 | 23 | 17 | NR | NR
Creamer et al (1994) | Sodium hyaluronate (Hyalgan) | 12 knees | 12 knees | 72 | 100 | x | | | | KL | 22 | 52 (Figure) | 54 (Figure) | NR | NR | NR | NR
| | | | | | | | | | 2–4^4^
Cubukcu et al (2004) | Hylan G-F 20 (Synvisc) | 20 | 10 | 55 | 80 | | | | x^1^ | Mean KL | HA 2.7 (.81) | 71 | 67 | 47 | 51 | 16 | 18
| | | | | | | | | | 1.9, 1.8 | Plac 1.8 (.63)
Dahlberg et al (1994) | Sodium hyaluronate (Supartz) | 28 | 24 | 45 | NR | | | x^35^ | | NR | NR | NR | NR | 46 | 54 | NR | NR
Day et al (2004) | Sodium hyaluronate (Artz) | 116 | 124 | 62 | 56 | x | | | | NR | >5 | NR | NR | NR | NR | 8 | 9
| | | | | | | | | | | (49%)
Dickson and Hosie (1998/2001) | Hylan G-F 20 (Synvisc) | 53 | 57 | 63 | 53 | | | | x | NR | NR | NR | NR | NR | NR | 59 | 58
Dixon et al (1988) | Sodium hyaluronate (Hyalgan) | 30 | 33 | 69 | 54 | | | | x | NR | NR | NR | NR | NR | NR | NR | NR
Dougados et al (1993) | Sodium hyaluronate (Hyalgan) | 55 | 55 | 68 | 71 | x^1^ | | | | NR | HA 5 | 68 | 62 | 31 | 28 | NR | NR
| | | | | | | | | | | Plac 6.4
Formiguera and Estevel (1995) | Sodium hyaluronate (Hyalgan) | 20 knees | 20 knees | 62 | 73 | x | | | | NR | NR | NR | NR | NR | NR | NR | NR
France (1995) | Sodium hyaluronate (Supartz) | 87 (3 inj) | 80 | 63.9 (3 inj) | 73.6 (3) | | | | x | NR | NR | 57.9 | 59.8 (pl) | NR | NR | NR | NR
| | 87 (5 inj) | | 64.7 (5 inj) | 60.9 (5) | | | | | | | (3 inj)
| | | | 65.2 (Plac) | 68.8 (Plac) | | | | | | | 56.9
| | | | | | | | | | | | (5 inj)
Grecomoro et al (1987) | Sodium hyaluronate (Hyalgan) | 20 knees | 20 knees | 65 | 56 | | | | x | NR | NR | 48 Spontaneous | 43 Spontaneous | NR | NR | NR | NR
Guler et al. (1996) | Sodium hyaluronate (Orthovisc) | 15 | 15 | NR | NR | | | | x | NR | NR | NR | NR | NR | NR | 16.9 | NR
Henderson et al. (1994) | Sodium hyaluronate (Hyalgan) | 45 | 46 | 65 (approx) | 69 | | | | x | KL | NR | 44 (mild OA) | 53 (mild OA) | 21 (mild OA) | 30 (mild OA) | NR | NR
| | | | | | | | | | 1–4 | | 49 (mod OA) | 49 (mod OA) | 25 (mod OA) | 39 (mod OA)
Hizmetli (1999) | Sodium hyaluronate (Orthovisc) | 25 | 25 | 56 | 68 | | | | x | KL | | NR | NR | NR | NR | 17.8 | 17.5
| | | | | | | | | | 1–2 | | | | | | (5–25 scale) | (5–25 scale)
Huskisson and Donnelly (1999) | Sodium hyaluronate (Hyalgan) | 50 | 50 | 65 | 67 | | | | x^2^ | KL | NR | 66 | 62 | NR | NR | NR | NR
| | | | | | | | | | 2–3
Jubb et al (2003) | Sodium hyaluronate (Hyalgan) | 208 | 200 | 64 | 68 | x^1^ | | | | KL | 8 | 57 | 56 | NR | NR | NR | NR
| | | | | | | | | | 2–3
Karlsson et al (2002) | Sodium hyaluronan (Artzal) or Hylan G-F 20 (Synvisc) | 92 (Artzal) | 66 | 71 | 65 | x | | | | Ahl | NR | 64 (Artzal) | 65 | 33 (Artzal) | 33 | 10 (Artzal) | 10
| | 88 (Synvisc) | | | | | | | | 1–2 | | 63 (Synvisc) | | 33 (Synvisc) | | 10 (Synvisc)
Kotevoglu et al 2006) | Sodium hyaluronate (Orthovisc) | 26 | 26 | 58.6 (Orth) | 85 (Orth) | | | | x^1^ | KL | 3.9 (4.6) (Ortho) | NR | NR | NR | NR | 17 (Ortho) | 20
| Hylan G-F 20 (Synvisc) | 26 | | 59.7 (Syn) | 90 (Syn) | | | | | 2–4 | 4.3 (5.2) (Syn) | | | | | 18 (Syn)
| | | | 60.1(Plac) | 89 (Plac) | | | | | | 3.7 (4.0) (Plac)
Lohmander et al (1996) | Sodium hyaluronate (Artzal/Supartz) | 120 | 120 | 58 | 56 | | | | x^1^ | Ahl | NR | 44 | 42 | NR | NR | NR | NR
| | | | | | | | | | 1–2
Moreland et al (1993) | Hylan G-F 20 (Synvisc) | 46 | 48 | NR | 67 | x | | | | KL | NR | 79 (Walking) | 80 (Walking) | NR | NR | NR | NR
| | | | | | | | | | 2–4
Neustadt et al (2005) | Sodium hyaluronate (Orthovisc) | 128 4 inj | 124 | 58.4 (8.9) 4inj | 48 | | | | x^1^ | KL | NR | NR | NR | NR | 287 3inj | 289 3 inj | 294
| | 120 3 inj | | 58.9 (8.9) 3inj | | | | | | 1 (13) | | | | | 289 4inj | 287 4 inj
| | | | 59.1(8.3) Plac | | | | | | 2 (50)
| | | | | | | | | | 3 (38)
Petrella et al (2002) | Sodium hyaluronate (Suplasyn) | 25 | 28 | 66 | 46 | | | | x^2^ | Altman | NR | NR | NR | NR | NR | 3.3 | 3.6
| | | | | | | | | | 1–3
Pham et al (2004) | Sodium hyaluronate (NRD 101) | 131 | 85 | 65 | 67 | x^1^ | | | | KL | NR | 62 | 59 | NR | NR | NR | NR
| | | | | | | | | | 0 (1)
| | | | | | | | | | 1 (3)
| | | | | | | | | | 2 (23)
| | | | | | | | | | 3 (69)
| | | | | | | | | | 4 (3)
Puhl et al (1993) | Sodium hyaluronate (Artz) | 102 | 107 | 62 | 64 | x^4^ | | | | NR | 1–5 | 54 | 51 | NR | NR | NR | NR
| | | | | | | | | | | (50% of pts)
Rolf et al. (2005) | Hylan G-F 20 (Synvisc) | 90 Syn | 91 Plac | 54.5 (9.2) Syn | 44 Syn | | | x^3^ ? | | Ahl | 7.2 (5.9) Syn | NR | NR | NR | NR | NR | NR
| Sodium hyaluronate (Artz) | 91 Artz | | 53.9 (9.0) Artz | 38 Artz | | | | | 0–3 | 8.3 (7.6) Artz
| | | | 53.1 (10) Plac | 38 Plac | | | | | | 7.8 (5.9)
| | | | | 40.4 All | | | | | | Plac
Russell et al (1992) | Sodium hyaluronate (unspecified) | 71 | 71 | 62 | 56 | | | | x | NR | NR | NR | NR | NR | NR | NR | NR
Scale et al (1994) | Hylan G-F 20 (Synvisc) | 25 (2inj) | 40 | 59 | 51 | | | | x^5^ | Larsen | 4–6 | 62 (2inj) | 70 | NR | NR | NR | NR
| | 15 (3inj) | | | | | | | | 2 (44) | | 67(3inj)
| | | | | | | | | | 3 (48)
| | | | | | | | | | 4 (9)
Sezgin et al. (2005) | Sodium hyaluronate (Orthovisc) | 22 | 19 | 59.7 | 75.6 | | | | x^1^ | KL | 41.7 HA | NR | NR | NR | NR | 18.9 | 17.2
| | | | | | | | | | 2–3 | 31.0 Plac
Shichikawa (1983a) | Sodium hyaluronate (Artz) | 114 | 114 | NR | NR | | | | x | KL | NR | NR | NR | NR | NR | NR | NR
| | | | | | | | | | 1–4
Shichikawa (1983b) | Sodium hyaluronate (Artz) | 52 | 55 | 62 | 83 | | | | x | NR | NR | NR | NR | NR | NR | NR | NR
Tamir et al (2001) | Sodium hyaluronate (BioHy/Nuflexxa) | 25 | 24 | 71 | 73 | x^1^ | | | | KL | NR | NR | NR | NR | NR | NR | NR
| | | | | | | | | | 2 (22))
| | | | | | | | | | 3 (55)
| | | | | | | | | | 4 (20)
Tsai et al (2003) | Sodium hyaluronate (Hyalgan) | 100 | 100 | 65 | 76 | x^1^ | | | | KL | 1.2 | 48 | 46 | NR | NR | 46 | 45
| | | | | | | | | | 2–3
UK (1996) | Sodium hyaluronate (Orthovisc) | 116 | 115 | 60.8 (HA) | 60.3(HA) | | | | x | NR | NR | NR | NR | NR | NR | NR | NR
| | | | 61.6(Plac) | 53.9(Plac)
Wobig et al (1998) | Hylan G-F 20 (Synvisc) | 52 | 54 | 62 | 65 | x^5^ | | | | Larsen | 6 | 71 | 75 | 42 | 47 | NR | NR
| | 4 pts both | | | | | | | | 1 (11)
| | | | | | | | | | 2 (46)
| | | | | | | | | | 3 (36)
| | | | | | | | | | 4 (7)
Wu et al (1997) | Sodium hyaluronate (Artz) | 90 total; 116 knees | | 69 | 28 | | | | x | NR | 1.6 | NR | NR | NR | NR | NR | NR
| | Pts per group not reported

KL - Kellgren and Lawrence criteria; Ahl - Ahlbäck; Plac - Placebo; HA - hyaluronan; Syn - Synvisc or hylan G-F 20; Ortho — Orthovisc;

1 ACR criteria;

2 Altman criteria;

3 Outerbridge criteria;

4 Lequesne;

5 Larsen;

4 Presumed Kellgren-Lawrence;

5 65% had prior injury;

6 Ahlbäck

Table IB RCTs of Intra-articular Hyaluronan Injections for OAK: Treatments, Trial Duration, Number Randomized (Hyaluronan and Placebo), and Blinding (bolded studies are unpublished trials in any form; highlighted abstracts not subsequently published)

| Treatment Arms | Injections | Trial Duration (weeks) | Number Randomized | Blinding
Altman & Moskowitz 1998 (HA placebo arms) | HA 20mg | 5 | 26 | 332 | Double
| Placebo
Altman et al. 2004 | HA (NASHA) 60mg | 1 | 26 | 347 | Double
| Placebo
Bragantini et al. 1987 | HA 40mg | 3 | 8.6 | 55 | Single
| HA 20mg
| Placebo
Brandt et al. 2001 | HA 30mg | 3 | 27 | 226 | Double
| Placebo
Bunyaratavej et al. 2001 | HA 20mg | 4 | 26 | 49 | Double
| Placebo
Carrabba et al. 1995 | HA 20mg × 5 | 5 (placebo for HA after 3 or 1 injections) | 26 | 100 | Double
| HA 20mg × 3
| HA 20mg × 1
| Arthrocentesis
| Arthrocentesis/Placebo
Cohen et al. 1994 | HA 20mg | 3 | 8 | 39 | Double
| Placebo
Corrado et al. 1995 | HA 20mg | 5 | 8 | 40 | Double
| Placebo
Creamer et al. 1994 | HA 20mg | 5 | 9 | knees from 12 subjects | Single
| Placebo
Cubukcu et al. 2004 | GF 20 | 3 | 8 | 30 subjects 40 knees | Unblinded
| Placebo
Dahlberg et al. 1994 | HA 25mg | 5 | 52 | 52 | Double
| Placebo
Day et al. 2004 | HA 25mg | 5 | 18 | 240 | Double
| Placebo
Dickson et al. 2001 | GF 20 | 3 | 12 | 110 | Double
| Placebo*
Dixon et al. 1988 | HA 20mg | up to 11 | 48 | 63 | Double
| Placebo
Dougados et al. 1993 | HA 20mg | 4 | 52 | 110 | Single
| Placebo
Formiguera & Esteve 1995 | HA 20mg | 5 | 13 | 36 | Double
| Placebo
France 1995 | HA 25mg 5 inj | 3 or 5 | 13 | 254 | Double
| HA 25mg 3 inj
| Placebo
Grecomoro et al. 1987 | HA 20mg | 3 | 8.6 | 34 pts 40 knees | Double
| Placebo
Guler et al. (1996) | HA 30mg | 3 | 10.0 | 30 | Double
| Placebo
Henderson et al. (1994) | HA 20mg KL 1 | 5 | Main 5 wks Partial to 5 months | 91 | Double
| Placebo KL 1
| HA 20mg KL 3,4
| Placebo KL 3,4
Hizmetli et al. 1999 | HA 20mg | 3and at 6 mo | 52 | 50 | Double
| Placebo
Huskisson & Donnelly 1999 | HA 20mg | 5 | 24 | 100 | Double
| Placebo
Jubb et al. 2003 | HA 20mg | 3 every 4 months | 52 | 408 | Double
| Placebo
Karlsson et al. 2002 | HA 25mg | 3 | 52 | 246 | Double
| GF 20
| Placebo
Kotevoglu et al. 2006 | HA 20mg | 3 | 26 | 78 | Double
| GF 20
| Placebo
Lohmander et al. 1996 | HA 25mg | 5 | 20 | 240 | Double
| Placebo
Moreland et al, 1993 | GF 20 | 3 | 26 | 104 | Double
| Placebo
Neustadt et. al. 2005 | HA 30mg | 4 | 28 | 372 | Double
| HA 30mg | 3,1 placebo
| Placebo | 4
Petrella et al. 2002 4 arm trial with NSAID | HA 20mg/Oral Placebo | 3 | 12 | 53 | Double
| Placebo/Oral Placebo
Pham et al. 2004 3-arm trial; here report only HA Placebo | HA NRD 101 | 3 | 52 | 216 | Double
| Placebo
Puhl et al. 1993 | HA 25 mg | 5 | 14 | 209 | Double
| Placebo
Rolf et al. 2005 | GF 20 | 3 | 52 | 272 | Double
| HA 25mg
| Placebo
Russell et al. 1992 | HA 20mg | 3 | 14 | 210 | Single
| Placebo
Scale et al. 1994 | GF 20 | 3 | 12 | 80 | Double
| GF 20 | 2
| Placebo | 3
| Placebo | 2
Sezgin et al. (2005) | HA 30mg | 3 | 4 | 41 | Single
| Placebo
Shichikawa et al. 1983a | HA 25mg/Oral Plac | 5 | 5 | 228 | Double
| HA 0.25mg/Oral Plac
Shichikawa et al. 1983b | HA 25 mg/Oral Plac | 5 | 5 | 107 | Double
| HA 0.5mg/Oral Plac
Tamir et al. 2001 | HA 20mg | 5 | 20 | 49 | Single
| Placebo
Tsai et al. 2003 | HA 20mg | 5 | 25 | 200 | Double
| Placebo
UK 1996 | HA 25mg | 5 | 25 | 231 | Double
| Placebo
Wobig et al. 1998 | GF 20 | 3 | 26 | 110 pts 117 knees | Double
| Placebo
Wu et al. 1997 | HA 25mg | 5 | 26 | 90 pts 116 knees | Double
| Placebo

Abbreviations:

KL—Kellgren-Lawrence radiographic grade

HA—Hyaluronan

GF—Hylan G-F 20

* Also included a NSAID/arthrocentesis arm; because NSAID given in that arm, the HA and placebo/arthrocentesis arms were given placebo capsules.

Table IC Treatment of Missing Data, Per Patient of Per Knee Analyses, and Multiple Comparison Adjustment in RCTs of Intra-articular Hyaluronan Injections for OA of the Knee (bolded studies are unpublished trials in any form; highlighted abstracts not subsequently published)

| Analyses
| Intention to Treat (ITT) /Per Protocol (PP) | | | | Intention to Treat Analyses
Trial | ITT Analyses | PP Analyses* | Number Randomized | Number PP Analyses | Primary Analyses (e.g., reported in abstract) | Performed and Reported | Performed but not Detailed | Withdrawals Loss to f/u
Altman & Moskorwitz 1998 | Yes | Yes | 332 | 220 | No | Yes | | 33.7%
Altman et al. 2004 | Yes | Yes | 347 | 232 | Yes | Yes | | 21.4%
Bragantini et al. 1987 | No | Yes | 55 | 52 | No | No | | 5.4%
Brandt et al. 2001 | Yes | Yes | 226 | 135 | No | No^†^ | | 22.6%
Bunyaratavej et al. 2001 | Yes | — | 49 | — | Yes | | | NR^‡^
Carrabba et al. 1995 | Yes^†^ | — | 100 | — | Yes^§^ | Yes | | 0.0%**
Cohen et al. 1994 | No | Yes | 39 | 37 | No | No | | 5.1%
Corrado et al. 1995 | No | Yes | 40 | 35 | No | No | | 12.5%
Creamer et al. 1994 | Yes^†^ | — | 24 knees; 12 subjects | — | Yes^†^ | Yes | | 0.0%
Cubukcu et al. 2004 | Yes^†^ | — | 40 knees; 30 subjects | — | Yes^†^ | Yes | | 0.0%
Dahlberg et al. 1994 | Yes | — | 52 | — | Yes | Yes | | 7.5%
Day et al. 2004 | No | Yes | 240 | 223 | No | No | | 7.1%
Dickson et al. 2001 | Yes | Yes | 110 | 92 | Yes | Yes | | 16.4%
Dixon et al. 1988 | Unclear | Probable | 63 | 53 | Unclear | Unclear | | 15.9%
Dougados et al. 1993 | Yes | Yes | 110 | 95 | No | No | Yes | 13.6%
Formiguera & Esteve 1995 | Yes | — | 40 knees; 36 subjects | 40 knees | Yes | Yes | | 0.0%
France 1995 | Yes?^††^ | — | 254 | — | NA | NA | | Unknown
Grecomoro et al. 1987 | Yes | — | 40 knees; 34 subjects | 40 knees | Yes | Yes | | 10.0%
Guler et al. (1996) | Yes | — | 30 | — | Yes | Yes | | NR
Henderson et al. (1994) | Yes | — | 91 | — | Yes | Yes | | 7.7%
Hizmetli et al. 1999 | No | Yes^†^ | 50 | 40 | NA | NA | | 20.0%
Huskisson & Donnelly 1999 | Yes | Yes | 100 | 80/81 | Yes | Yes | | 19.0%
Jubb et al. 2003 | Yes^‡^ | Yes | 408 | 273 | No | Yes | | 33.1%
Karlsson et al. 2002 | No | Yes | 246 | 210 | No | No | Yes | 23.3%^§^
Kotevoglu et al. 2006 | No | Yes | 78 | 59 | No | No | | 24.4%
Lohmander et al. 1996 | Yes | Yes | 240 | 189 | No | Partial | Partial | 21.3%
Moreland et al, 1993 | Unclear | Probable | 104 | 94? | Unclear | | | NR
Neustadt et. al. 2005 | No | Yes | 372 | 336 | No | No | | 9.7%
Petrella et al. 2002 | Yes | No | 120 | — | Yes | | | 10.0%
Pham et al. 2004 | Yes | Yes | 216 | 202 | Yes | Yes | | 6.5%
Puhl et al. 1993 | Yes | Yes | 209 | 195 | No | No | Yes | 6.7%
Rolf et al. 2005 | Yes | Yes | 272 | 268 | Yes | Yes | | 8.4%
Russell et al. 1992 | NR | | 142 | | NR | | | 19.9%
Scale et al. 1994 | No** | | 80 | | Unclear | | | NR
Sezgin et al. (2005) | Yes | — | 41 | | Yes | | | 0.0%
Shichikawa et al. 1983a | No | Yes | 228 | 219 | No | | | 9.2%
Shichikawa et al. 1983b | No | Yes | 107 | 98 | No | | | 8.4%
Tamir et al. 2001 | Unclear | — | 49 | — | No | No | No | 14.3%
Tsai et al. 2003 | Yes | Yes | 200 | | Yes | | | NR
UK 1996 | Unknown | | 131 | | NR | | | NR
Wobig et al. 1998 | Yes | No | 117 knees; 110 subjects | | Yes | Yes | | 0.0%
Wu et al. 1997 | No | Yes | 116 knees; 90 subjects | 58 knees^‡‡‡^ | No | No | No | 50.0%^††^

* —indicates no distinction made and considered intention to treat.

† As reported by Bellamy et al. (2006)

‡ Reported PP values in paper.

§ Through 26 weeks

** Combined 2 control groups post-hoc so not an intention to treat analysis (see also text).

†† At 26 weeks

Table ID Trial Quality for Hyaluronan-Products (bolded studies are unpublished trials in any form; highlighted abstracts not subsequently published)

Trial | Quality | Initial Assembly Comparable Groups | < 80% loss to follow up, Maintain Comparable Groups | Measurements Reliable, Valid, Equal | Intervention Comparable/Clearly Defined | Appropriate Analysis of Results | Allocation concealment
Altman & Moskorwitz 1998 | Fair | Y | N | Y | Y | Y | B
Altman et al. 2004 | Good | Y | Y | Y | Y | Y | A
Bragantini et al. 1987 | Poor | N | Y | Y | Y | N | B
Brandt et al. 2001 | Poor | Y | N | Y | Y | N | A
Bunyaratavej et al. 2001 | Fair | Y | Unclear | Y | Y | Y | B
Carrabba et al. 1995 | Good | Y | Y | Y | Y | Y | B
Cohen et al. 1994 | Poor | Y | Y | Y | Y | N | B
Corrado et al. 1995 | Fair | Y | Y | Y | Y | N | B
Creamer et al. 1994 | Fair | Y | Y | N | Y | Y | B
Cubukcu et al. 2004 | Fair | Y | Y | Y | Y | N | B
Dahlberg et al. 1994 | Good | Y | Y | Y | Y | Y | B
Day et al. 2004 | Good | Y | Y | Y | Y | Unclear | B
Dickson et al.† 2001 | Fair | Y | Y | Y | Y | No | B
Dixon et al. 1988 | Poor | N | Y | Y | N | Unclear | B
Dougados et al. 1993 | Poor | N | Y | Y | Y | Unclear | B
Formiguera & Esteve 1995 | Poor | Unclear | Y | Unclear | Y | Unclear | B
France 1995 | NA | NA | NA | NA | NA | NA | NA
Grecomoro et al. 1987 | Poor | NR | Y | Y | Y | No | B
Guler et al. (1996) | NA | NA | NA | NA | NA | NA | B
Henderson et al. (1994) | Good | Y | Y | Y | Y | Y | B
Hizmetli et al. 1999 | NA | NA | NA | NA | NA | NA | NA
Huskisson & Donnelly 1999 | Good | Y | Y | Y | Y | Y | B
Jubb et al. 2003 | Fair | Y | N | Y | Y | Y | B
Karlsson et al. 2002 | Fair | Y | N | Y | Y | N | B
Kotevoglu et al. 2006 | Poor | Y | N | Y | Y | N | B
Lohmander et al. 1996 | Poor | Y | N | Y | Y | N | B
Moreland et al, 1993 | Poor | NR | NR | NR | Y | NR | B
Neustadt et. al. 2005 | Fair | Y | Y | Y | Y | N | A
Petrella et al. 2002 | Good | Y | Y | Y | Y | Y | A
Pham et al. 2004 | Good | Y | Y | Y | Y | Y | A
Puhl et al. 1993 | Fair | N | Y | Y | Y | N | A
Rolf et al. 2005 | Good | Y | Y | Y | Y | Y | B
Russell et al. 1992 | NA
Scale et al. 1994 | Poor | Y | NR | Y | Y | N | A
Sezgin et al. (2005) | Fair | Y | Y | Y | Y | Unclear | B
Shichikawa et al. 1983a | Fair | Y | Y | Y | Y | N | A
Shichikawa et al. 1983b | Fair | Y | Y | Y | Y | N | A
Tamir et al. 2001 | Fair | Y | Unclear | Y | Y | Y | B
Tsai et al. 2003 | Fair | U | U | Y | Y | U | B
UK 1996 | NA
Wobig et al. 1998 | Poor | N | Y | Y | Y | N | A
Wu et al. 1997 | Fair | Y | N | Y | Y | N | B

Table IE Sample Size Calculations Described in RCTs of Hyaluronan-based Products (bolded studies are unpublished trials in any form; highlighted abstracts not subsequently published)

Trial | Sample Size Calculation
| Performed | Type I Error | Power | Difference Powered to Detect
Altman & Moskorwitz 1998 (HA placebo arms) | Yes | 0.05 | 0.80 | 8mm VAS pain 50 foot walk for 50mm baseline
Altman et al. 2004 | Yes | 0.05 | 0.80 | 35% HA vs. 20% Placebo
Bragantini et al. 1987 | No
Brandt et al. 2001 | Yes | 0.05 | 0.80 | 0.5 unit WOMAC pain 1 to 5 (12.5%)
Bunyaratavej et al. 2001 | No
Carrabba et al. 1995 | No
Cohen et al. 1994 | No
Corrado et al. 1995 | No
Creamer et al. 1994 | No
Cubukcu et al. 2004 | No
Dahlberg et al. 1994 | Yes | 0.05 | 0.80 | 18 mm VAS improvement HA; 9 mm placebo; baseline 45 mm SD 22
Day et al. 2004 | Yes | 0.05 | 0.90 | 10% reduction in WOMAC pain score
Dickson et al. 2001 | Yes | 0.05 | 0.80 | 25% difference in proportion of patients with 25% decrease in WOMAC pain
Dixon et al. 1988 | No
Dougados et al. 1993 | Yes | 0.05 | 0.80 | Disappearance of knee effusion at week 7; 20% placebo; 50% active
Formiguera & Esteve 1995 | No
France 1995 | Unknown
Grecomoro et al. 1987 | No
Guler et al. (1996) | Unknown
Henderson et al. (1994) | Yes | 0.05 | 0.90 | 13.1 mm difference on VAS pain
Hizmetli et al. 1999 | Unknown
Huskisson & Donnelly 1999 | Yes | 0.05 | 0.90 | 15.4 mm difference on VAS pain
Jubb et al. 2003 | Yes | NR | NR | Standardized difference in JSN of 0.32 with dropout rate of 25%
Karlsson et al. 2002 | Yes | 0.05 | 0.80 | Detect a 15mm difference in VAS pain decrease
Kotevoglu et al. 2006 | Yes | 0.05 | 0.80 | No outcome difference specified
Lohmander et al. 1996 | Yes | 0.05 | 0.90 | VAS pain treatment difference of 12 mm
Moreland et al. 1993 | Unknown
Neustadt et. al. 2005 | Yes | 0.05 | 0.80 | 55% placebo and 60% saline response
Petrella et al. 2002 | Yes | NR | 0.80 | “20% pain reduction among groups”
Pham et al. 2004 | Yes | 0.05 | 0.90 | Difference between baseline and year of 15 mm VAS pain SD 35
Puhl et al. 1993 | Yes | 0.05 | 0.90 | SMD in Lequesne of 0.5 between hyaluronan and placebo
Rolf et al. 2005 | Yes | 0.05 | 0.80 | 40% Synvisc; 20% Artzal would be symptom free; placebo rate not specified
Russell et al. 1992 | Unknown
Scale et al. 1994 | No
Sezgin et al. (2005) | No
Shichikawa et al. 1983a | No
Shichikawa et al. 1983b | No
Tamir et al. 2001 | No
Tsai et al. 2003 | Unknown
UK 1996 (not all information available) | Unknown
Wobig et al. 1998 | Yes | 0.05 | 0.80 | 15 mm on VAS with SD of 25
Wu et al. 1997 | No

Table IF Industry Involvement in RCTs of Intra-articular Hyaluronan Injections for OAK (bolded studies are unpublished trials in any form; highlighted abstracts not subsequently published)

| Industry Involvement
Trial | Funding | Analyses | Author
Altman & Moskorwitz 1998 | Fidia | Fidia
Altman et al. 2004 | Q-Med
Bragantini et al. 1987 | NR | | Yes
Brandt et al. 2001 | Anika
Bunyaratavej et al. 2001 | NR
Carrabba et al. 1995 | NR | Fidia
Cohen et al. 1994 | Bioniche
Corrado et al. 1995 | NR
Creamer et al. 1994 | Fidia
Cubukcu et al. 2004 | NR
Dahlberg et al. 1994 | KaroBio
Day et al. 2004 | Seikagaku
Dickson et al. 2001 | Syntex/Roche
Dixon et al. 1988 | Fidia
Dougados et al. 1993 | NR | Fidia
Formiguera & Esteve 1995 | NR
France 1995 | Seikagaku | Seikagaku | Unpublished
Grecomoro 1987 | NR
Guler et al. (1996) | NR
Henderson et al. (1994) | Fidia/Product
Hizmetli et al. 1999 | Anika | Anika | Anika
Huskisson & Donnelly 1999 | NR
Jubb et al. 2003 | Fidia | Fidia | Fidia
Karlsson et al. 2002 | Astra Lakemedel | | Author
Kotevoglu et al. 2006 | NR
Lohmander et al. 1996 | Multiple inc Industry
Moreland et al, 1993 | Biomatrix
Neustadt et. al. 2005 | Anika Therapeutics
Petrella et al. 2002 | Bioniche | ?Bioniche | Bioniche
Pham et al. 2004 | NR | | Author
Puhl et al. 1993 | Luitpold Pharma | Luitpold
Rolf et al. 2005 | Biomatrix/Roche/Genxyme | | 2 Authors
Russell et al. 1992 | NR
Scale et al. 1994 | Biomatrix | ?*
Sezgin et al. (2005) | NR
Shichikawa et al. 1983a | Seikagaku | ?
Shichikawa et al. 1983b | Seikagaku (drug)
Tamir et al. 2001 | NR | | Affiliation
Tsai et al. 2003 | Medpharma | | Fidia
UK 1996 | NR
Wobig et al. 1998 | Biomatrix
Wu et al. 1997 | NR

* Address for correspondence Arnold Goldman, PhD at Biomatrix who was not listed as author.

Table IG Treatment of Missing Data, Per Patient of Per Knee Analyses, and Multiple Comparison Adjustment in RCTs of Intra-articular Hyaluronan Injections for OAK (bolded studies are unpublished trials in any form; highlighted abstracts not subsequently published)

| Analyses
| Per Patient or Per Knee Analysis | Missing Data | Multiple Comparison Adjustment
Altman & Moskorwitz 1998 | Patient | LOCF | No
Altman et al. 2004 | Patient | LOCF | No
Bragantini et al. 1987 | Knee | NR | No
Brandt et al. 2001 | Patient | NR | No
Bunyaratavej et al. 2001 | Patient | NR | No
Carrabba et al. 1995 | Patient | NR | Yes
Cohen et al. 1994 | Patient | NR | NR
Corrado et al. 1995 | Patient | NR | Yes
Creamer et al. 1994 | Knee | NR | No
Cubukcu et al. 2004 | Knee | NR | Yes
Dahlberg et al. 1994 | Patient | NR | No
Day et al. 2004 | Patient | LOCF | Repeated Measures ANCOVA
Dickson et al. 2001 | Patient | NR | Repeated Measures ANOVA
Dixon et al. 1988 | Patient | NR | No
Dougados et al. 1993 | Patient | NR | No
Formiguera & Esteve 1995 | Knee | NR | MANOVA
France 1995 | Patient | NR | Repeated Measures ANCOVA
Grecomoro et al. 1987 | Knee | NR | ANOVA to day 21
Guler et al. (1996) | NR | NR | NR
Henderson et al. (1994) | Patient | Complete case | No
Hizmetli et al. 1999 | Patient | Unknown | Unknown
Huskisson & Donnelly 1999 | Patient | LOCF | No
Jubb et al. 2003 | Patient | LOCF | No
Karlsson et al. 2002 | Patient | LOCF | No
Kotevoglu et al. 2006 | Patient | NR | Yes/Tukey
Lohmander et al. 1996 | Patient | LOCF | No
Moreland et al, 1993 | Knee | NR | NR
Neustadt et. al. 2005 | Patient | GEE (MCAR) | Yes/Hochberg
Petrella et al. 2002 | Patient | NR | Repeated Measures ANCOVA
Pham et al. 2004 | Patient | LOCF | NR
Puhl et al. 1993 | Patient | ?LOCF/MANOVA | Bonferroni-Holm
Rolf et al. 2005 | Patient | NR | No
Russell et al. 1992 | NR | NR | NR
Scale et al. 1994 | Patient | NR | NR
Sezgin et al. (2005) | Patient | None | LSD; Rep meas ANOVA
Shichikawa et al. 1983a | Patient | NR | NA
Shichikawa et al. 1983b | Patient | NR | NA
Tamir et al. 2001 | Patient | NR | NR
Tsai et al. 2003 | Patient | LOCF | NR
UK 1996 | NR | Unknown | Unknown
Wobig et al. 1998 | Knee | Complete Case | NR
Wu et al. 1997 | Knee | NR | NR

Abbreviations

LOCF—Last Observation Carried Forward

NR—Not reported

NA—Not available

GEE—Generalized Estimating Equation regression

MCAR—Missing Completely At Random assumption for missing data

ANOVA—Analysis of Variance

ANCOVA—Analysis of Covariance

Table IH Adverse Events Associated with Hyaluronan Injections for Knee OA in Placebo-Controlled RCTs

Study (year) | HA Derivative (Trade Name) | Injection Site Pain/Infection n (%) | | Local Joint Pain/Swelling n (%) | | Local Skin n (%) | | Headache n (%) | | GI Tract n (%) | | Nervous System n (%) | | Respiratory Tract n (%) | | Urinary Tract n (%) | | General Body n (%)
| | Tx | PL | Tx | PL | Tx | PL | Tx | PL | Tx | PL | Tx | PL | Tx | PL | Tx | PL | Tx | PL
Altman and Moskowitz (1998) | Sodium hyaluronate (Hyalgan) | 38 (23) | 22 (13) | 21 (13) | 22 (13) | 35 (21) | 33 (14) | 30 (18) | 29 (17) | 48 (29) | 59 (36) | NR | NR | NR | NR | NR | NR | NR | NR
Altman et al (2004) | Non animal stabilized hyaluronic acid (Durolane) | NR | NR | 11 (6) | 5 (3) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bragantini et al (1987) | Sodium hyaluronate (Hyalgan) | 4 (10) | NR | 4 (10) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Brandt et al (2001) | Sodium hyaluronate (Orthovisc) | 1.2% | 1.5% | 34 (30) | 30 (27) | 5 (4) | 6 (5) | NR | NR | 11 (10) | 16 (14) | 15 (13) | 16 (14) | 26 (23) | 18 (16) | 6 (5) | 9 (8) | 21 (18) | 23 (21)
Bunyaratavej et al (2001) | Sodium hyaluronate (Hyalgan) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Carrabba et al. (1995) | Sodium hyaluronate (Hyalgan) | NR | NR | 3 (5) | 1 (3) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cohen et al. (1994) | Sodium hyaluronate (Hyalgan) | NR | NR | 3 (16) | 6 (30) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Corrado et al (1995) | Sodium hyaluronate (Hyalgan) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Creamer et al. (1994) | Sodium hyaluronate (Hyalgan) | NR | NR | 3 (25) | 1 (8) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cubukcu et al. (2005) | Hylan G-F 20 (Synvisc) | NR | NR | 1 | | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Dahlberg et al (1994) | Sodium hyaluronate (Supartz) | “a few” | 1(4) | “a few” | “a few” | “a few” | “a few” | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Day et al (2004) | Sodium hyaluronate (Artz) | 16 (14) | 13 (10) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Dickson and Hosie (1998) | Hylan G-F 20 (Synvisc) | 1.8% per injection rate | 0.6% per injection rate | NR | NR | NR | NR | NR | NR | 5 (11) | 4 (9) | NR | NR | NR | NR | NR | NR | NR | NR
Dixon et al (1988) | Sodium hyaluronate (Hyalgan) | NR | NR | 3 (10) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Dougados et al (1993) | Sodium hyaluronate (Hyalgan) | 18 (33) | 18 (33) | NR | NR | NR | NR | 1 (2) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Formiguera Sala et al (1995) | Sodium hyaluronate (Hyalgan) | 3 (15) | 3 (15) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
France (1995) | Sodium hyaluronate (Supartz) | 3 (3.4) | 4 (5.0) | 11 (12.6) | 12 (15) | NR | NR | 3 (3.4) | 4 (5.0) | NR | NR | NR | NR | NR | NR | NR | NR | 10 (12) | 10 (13)
| Only reported for 3 injection arm (not 5 injection) | | | 3 inj 5 not reported | | | | | | | | | | | | | | back pain | back pain
Grecomoro et al (1987) | Sodium hyaluronate (Hyalgan) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Guler et al. (1996) | Sodium hyaluronate (Orthovisc) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Henderson et al (1994) | Sodium hyaluronate (Hyalgan) | NR | NR | 21 (47) | 10 (22) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Huskisson and Donnelly (1999) | Sodium hyaluronate (Hyalgan) | NR | NR | 7 (14) | 7 (14) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 1 (2) | NR
Jubb et al (2003) | Sodium hyaluronate (Hyalgan) | 25 (12) | 20 (10) | 75 (36) | 45 (23) | NR | NR | 26 (13) | 15 (8) | 11 (5) | 10 (5) | 13 (6) | 8 (4) | 18 (9) | 18 (9) | NR | NR | 43 (21) | 35 (18)
| | Infection | Infection
| | 22 (10.6) | 27 (13.5)
Karlsson et al (2002) | Sodium hyaluronan (Artzal) or Hylan G-F 20 (Synvisc) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kotevoglu et al. 2006 | Sodium hyaluronate (Orthovisc) Hylan G-F 20 (Synvisc) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Lohmander et al (1996) | Sodium hyaluronan (Artzal) | NR | NR | Significant difference in favor of PL in maximum severity of injection site swelling (p = 0.041) | | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Moreland et al (1993) | Hylan G-F 20 (Synvisc) | NR | NR | 1% of 400 injections | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Neustdat (2005) | Sodium hyaluronate (Hyalgan) | 49 (20) | 7 (3) | 20 (14) | 2 (2) | 4 (3) | 4 (3) | A "most frequent AE but not numbers not stated | | 21 (9) | 10 (8) | 38 (15) | 26 (21) | 9 (4) | 5 (4) | NR | NR | 21 (9) | 9 (7)
Petrella et al (2002) | Sodium hyaluronate (Suplasyn) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pham et al (2004) | Sodium hyaluronate (NRD 101) | NR | NR | 24 (18) | 19 (22) | 9 (7) | 1 (1) | Included in nervous system tally | | 27 (20) | 25 (29) | 8 (6) | 2 (2) | 17 (13) | 16 (19) | 0 | 0 | 3 (5) | 5 (6)
| | | | (p = .0088 vs PL)
Puhl et al (1993) | Sodium hyaluronate (Supartz) | 3 (3) | 1 (1) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Rolf et al. (2005) | Hylan G-F 20 (Synvisc) | 3 (2) | 0 (0) | NR | NR | NR | NR | 28 (15) | 21 (23) | 6 (3) | 2 (2) | 30 (17) | 21 (23) | 9 (5) | 6 (7) | 3 (2) | 0 (0) | 35(19) | 20 (22)
| Sodium hyaluronate (Artz) | | | | | | | | | | | inc | inc
| | | | | | | | | | | | HA | HA
Russell et al (1992) | Sodium hyaluronate (not specified) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Scale et al (1994) | Hylan G-F 20 (Synvisc) | 1 (group not specified) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Shichikawa (1983a) | Sodium hyaluronate (Artz) | NR | NR | 1 (1) | 5 (4) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Shichikawa (1983b) | Sodium hyaluronate (Artz) | NR | NR | 1 (2) | 1 (2) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 1 (2)
Sezgin (2005) | Sodium hyaluronate (Orthovisc) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Tamir et al (2001) | Sodium hyaluronate (BioHy) | 18 (72) | 11 (46) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wobig et al (1998) | Hylan G-F 20 (Synvisc) | NR | 2 (3) | NR | NR | 1 (2) | NR | NR | NR | 1 (2) | NR | NR | NR | NR | NR | NR | NR | 1 (2) | NR
Wu et al (1997) | Sodium hyaluronate (Artz) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

NR - Not Reported

Table IJ Authors' conclusions from the five study-level meta-analyses

Meta-Analysis | Relevant conclusions
Lo (2003) | “Intra-articular hyaluronic acid has a small effect when compared with an intra-articular placebo. The presence of publication bias suggests even this effect may be overestimated. Compared with lower-molecular-weight hyaluronic acid, the highest-molecular-weight hyaluronic acid may be more efficacious in treating knee OA, but heterogeneity of these studies limits definitive conclusions.”
| “[A]pproximately 80% of the treatment effect of intra-articular hyaluronic acid was accounted for by the placebo effect of an intra-articular injection.”
Wang (2004) | “This meta-analysis confirmed the therapeutic efficacy and safety of intra-articular injection of hyaluronic acid for the treatment of osteoarthritis of the knee. Additional well-designed randomized controlled RCTs with high methodologic quality are needed to resolve the continued uncertainty about the therapeutic effects of different types of hyaluronic acid products on osteoarthritis of the knee in various clinical situations and patient populations.”
Arrich (2005) | “The methodologic quality of most RCTs was poor”
| “According to the currently available evidence, intra-articular hyaluronic acid has not been proven clinically effective and may be associated with a greater risk of adverse events.”
Modawal (2005) | “Intra-articular viscosupplementation was moderately effective in relieving knee pain in patients with osteoarthritis at 5 to 7 and 8 to 10 weeks after the last injection but not at 15 to 22 weeks.”
Bellamy (2006) | “... viscosupplementation is an effective treatment for OA of the knee with beneficial effects: on pain, function and patient global assessment; and at different post injection periods but especially at the 5 to 13 week post injection period.... The clinical effect for some products, against placebo, on some variables at some timepoints is in the moderate to large effect-size range.... Overall, the analyses performed are positive for the HA class and particularly positive for some products with respect to certain variables and timepoints, such as pain on weight bearing at 5 to 13 weeks post injection.”

## Part II: Glucosamine/Chondroitin

Table IIA General Comparison of Glucosamine and Chondroitin Meta-Analyses in Knee Osteoarthritis

Author (year) | Key Question Addressed | | | | Literature Search | Study Inclusion Criteria | Search Results | Overall Patient Demographics | Intervention(s) | Health Outcomes Analyzed
| 1 | 2 | 3 | 4
Bjordal et al (2006) | x | x | | | MEDLINE, EMBASE, PedRo, CCTR | Blinded, randomized, placebo-controlled trials that lasted at least 4 weeks, included patients with knee OA verified by clinical examination according to ACR or X-ray criteria, with minimum symptom duration of 3 months, and primary outcome measure of pain intensity within 4 weeks of treatment start scored on WOMAC pain subscale or a 100 mm VAS | Initial search: number of hits unclear | 401 pts in GS trials | Oral GS 1500 mg daily, duration not specified | 1) Pain intensity within 4 weeks of treatment start scored according to WOMAC pain subscale or on a 100 mm VAS for global or walking pain; 2) Pain intensity, as measured for the primary outcome measure at 8–12 weeks follow-up
| | | | | All databases searched from 1966 to November 2005 using a specified protocol to identify RCTs | | 7 RCTs on GS and 6 on CS included in MA | 362 pts in CS trials | Oral CS 800 mg daily, duration not specified
| | | | | Manual search of reference lists of systematic reviews, conference abstracts, and discussions with clinical experts | | | Mn age 58.6 yrs in GS trials
| | | | | Papers in English, German, and Scandinavian languages were eligible for inclusion | | | Mn age 63.0 yrs in CS trials
| | | | | | | | Sex distribution not provided for individual interventions, overall 63% female
Towheed et al (2006) | x | x | | | MEDLINE, EMBASE, PREMEDLINE, Cochrane Controlled Trials Register (CCTR), Cochrane Database of Systematic Reviews (CDSR), American College of Physicians (ACP) Journal Club, Database of Abstracts of Reviews of Effectiveness (DARE), Allied and Complementary Medicine (AMED) | Single- or double-blinded, placebo- or active-controlled randomized clinical trials (RCTs) that reported usable quantitative data on the efficacy and toxicity of glucosamine sulfate (GS) or glucosamine hydrochloride (GH) [Rotta in 13 trials, 6 used non-Rotta product] administered by any route on at least one of the outcomes of interest in patients age 18 years or older with primary or secondary OA at any site except temporomandibular joint (TMJ) | Initial search: number of hits unclear | 2,596 total pts | 17/20 (85%) RCTs compared GS (16 trials) or GH (1 trial) to placebo | 1) Pain measured by any method; 2) Functional assessment by a validated method (eg, WOMAC); 3) Patient global assessment; 4) Physician global assessment; 5) Range of motion of study joint; 6) Structural benefits, defined as delay of radiological progression of OA; 7) Toxicity of glucosamine measured as adverse events and study subject withdrawals
| | | | | All databases searched from inception to January 2005 using a validated protocol to identify RCTs | | 20 RCTs included in MA | Mn age 61.1 yrs | 4 RCTs compared GS to ibuprofen (3 trials) or piroxicam (1 trial)
| | | | | Manual search of reference lists of primary and review articles | | | 67% female | 16 RCTs used oral glucosamine 1500 mg/day as a single dose (4 trials) or as 500 mg thrice daily (12 trials)
| | | | | No language or age restrictions used in initial searches | | | | 3 RCTs used parenteral (IM, IA, IV) GS 400 mg once daily (2 trials) or twice weekly (1 trial)
| | | | | | | | | 16 RCTs evaluated the knee only, 2 RCTs evaluated OA at multiple sites (knee, hip, other), 2 RCTs did not specify the OA site
| | | | | | | | | 7 RCTs included primary OA, 13 RCTs did not make a clear distinction between primary and secondary OA
Poolsup et al (2005) | x | | | | MEDLINE, EMBASE, BIOSIS, EBM review, Cochrane Library | Double-blind, randomized, controlled trials that lasted at least one year in patients with primary knee OA | Initial search: number of hits unclear | 414 total pts | Oral GS 1500 mg once daily for 3 yrs versus oral placebo | 1) Main efficacy outcome was JSN in the signal joint, reported in terms of relative risk of disease progression, defined as the proportion of patients with JSN > 0.5 mm in the GS group relative to the placebo group; 2) Symptom-modifying effects of GS were assessed by WOMAC pain or physical function subscales; 3) Toxicity of GS measured as proportion of patients who experienced an adverse event
| | | | | All databases searched from inception to August 2004 using MeSH search terms (osteoarthritis, glucosamine, knee, disease progression and clinical trial) followed by a key word search (degenerative joint disease, degenerative arthritis, osteoarthrosis, and gonarthrosis) | | 2/17 RCTs included in MA | Mn age 64.1 yrs
| | | | | Manual search of reference lists of primary and review articles | | | 77% female
| | | | | Language restriction not noted
Richy et al (2003) | x | | | | MEDLINE, PREMEDLINE, EMBASE, BIOSIS Previews, HealthSTAR, EBM reviews, Cochrane Library, Current Contents | Double-blind, randomized, placebo-controlled trials that lasted at least 4 weeks, with sufficient precision in design, methods and results, in patients with knee or hip OA | Initial search: > 500 hits | 1,775 total pts (1,020 given GS, 755 chondroitin sulfate [CS]) | Oral GS 750 or 1500 mg daily for 1–36 mos | 1) JSN; 2) Lequesne Index (LI); 3) WOMAC index; 4) Pain by VAS; 5) Joint mobility by VAS; 6) Responders to treatment and safety
| | | | | All databases searched from January 1980 to March 2002 using a validated protocol to identify RCTs | | 15/36 RCTs included in MA | Mn age 62.1 yrs | Oral CS 200–2000 mg daily for 3–12 mos
| | | | | Manual search of reference lists of primary and review articles, abstracts of scientific meetings, contacts of authors for unpublished data | | | Sex distribution not provided in MA, but no significant differences were noted in the report
| | | | | No language or age restrictions
Leeb et al (2000) | x | x | | | MEDLINE, EMBASE, personal searches | Double-blind, randomized, placebo-controlled trials that contained data on at least half of the efficacy variables proposed by EULAR, in patients with knee or hip OA | Initial search: 16 hits | 703 total pts (372 given CS, 331 controls) | Oral CS 800–1200 mg daily for 3–12 mos | 1) Pain by VAS; 2) Algofunctional LI; 3) Patients and physicians global assessment; 4) Analgesic or NSAID consumption; 4) Toxicity
| | | | | Time period of search not provided, no keywords or protocol specified | | 7/16 RCTs included in MA | Sex and age distributions not provided in MA, but no significant differences were noted in the report
| | | | | Language or age restrictions not noted
McAlindon et al (2000) | x | x | | | MEDLINE, Cochrane Controlled Trials Register | Double-blind, randomized, placebo-controlled trials that lasted at least 4 weeks and included at least one of the outcome measures recommended for OA clinical trials in patients with knee or hip OA | Initial search: 37 hits | 1,710 total pts (911 in glucosamine trials, 799 chondroitin) | Oral or IA glucosamine, dose regimens not provided | 1) Global pain score for index joint (VAS or Likert scale); 2) Pain on walking for index joint (VAS or Likert scale); 3) WOMAC pain subscale (VAS or Likert scale); 4) LI; 5) Pain in index joint during activities other than walking (VAS or Likert scale)
| | | | | All databases searched from 1966 to June 1999 using a validated protocol to identify RCTs | | 15/37 RCTs included in MA | Sex and age distributions not provided in MA | Oral or IM chondroitin, dose regimens not provided
| | | | | Manual search of reference lists of primary and review articles, abstracts of scientific meetings, contacts of authors for unpublished or incomplete data
| | | | | No language or age restrictions

Table Part 1 Design Characteristics of the Glucosamine/Chondroitin Arthritis Intervention Trial (GAIT)*

Purpose | Design** | Patient Eligibility Criteria*** | Patient Exclusion Criteria | Treatment Regimens
To evaluate rigorously the efficacy and safety of glucosamine, chondroitin sulfate, and the two in combination in the treatment of pain due to osteoarthritis of the knee | Double-dummy, double-blind, 5-arm, randomized, placebo- and active-controlled clinical trial, using permuted-block randomization scheme with random block sizes stratified according to the 16 clinical centers and baseline WOMAC pain stratum (miled, defined as a score of 125 to 300, or moderate to severe, defined as a score of 301 to 400) | Age 40 years or more | Concurrent arthritic or medical conditions that could confound evaluation of the index knee | Placebo Group:
| Study conducted under an IND, with agents subjected to pharmaceutical regulation by FDA | Knee pain for at least 6 months and on the majority of days during the preceding month | Predominant patellofemoral disease | Capsules prepared to match nutriceuticals and celecoxib capsules, administered on same schedule as active agents
| | Radiographic evidence of primary knee OA, as exemplified by the presence of tibiofemoral osteophytes of at least 1 mm, signifying Kellgren-Lawrence disease grade 2 or 3 | History of clinically significant trauma or surgery to the index knee | Glucosamine hydrochloride:
| | Summed pain score of 125 to 400 on the index knee according to the WOMAC OA index | Coexisting disease that could preclude successful completion of the trial | 500 mg orally t.i.d.
| | ARA functional class I, II, or III | | Chondroitin sulfate:
| | | | 400 mg orally t.i.d.
| | | | Glucosamine/chondroitin:
| | | | 500 mg glucosamine orally t.i.d. plus 400 mg chondroitin orally t.i.d.
| | | | Active Control Group:
| | | | 200 mg celecoxib (Celebrex, Pfizer) orally once daily

* Clegg DO, Reda DJ, Harris CL, et al. Glucosamine, chondroitin sulfate, and the two in combination for painful knee osteoarthritis. New Engl J Med. 2006;354:795–808.

** IND = investigational new drug; FDA = Food and Drug Administration; WOMAC = Western Ontario and McMaster Universities

*** OA = osteoarthritis; ARA = American Rheumatism Association

Table Part 2 Enrollment and Disposition of Patients in the Glucosamine/Chondroitin Arthritis Intervention Trial (GAIT)*

No. of Patients** | Treatment Group (%)
| Placebo | Glucosamine | Chondroitin | Glucosamine plus Chondroitin | Celecoxib
Assigned | 313 | 317 | 318 | 317 | 318
Completed | 248 (79.2) | 242 (76.3) | 248 (78.0) | 254 (80.1) | 266 (83.6)
Withdrew | 65 (20.8) | 75 (23.7) | 70 (22.0) | 63 (19.9) | 52 (16.4)
| 11 adverse event | 9 adverse event | 20 adverse event | 12 adverse event | 7 adverse event
| 22 lack of efficacy | 27 lack of efficacy | 25 lack of efficacy | 17 lack of efficacy | 11 lack of efficacy
| 17 lost to follow-up | 20 lost to follow-up | 15 lost to follow-up | 16 lost to follow-up | 17 lost to follow-up
| 15 other reasons | 19 other reasons | 10 other reasons | 18 other reasons | 17 other reasons

* Clegg DO, Reda DJ, Harris CL, et al. Glucosamine, chondroitin sulfate, and the two in combination for painful knee osteoarthritis. New Engl J Med. 2006;354:795–808.

** 3,238 screened, 1,655 (51%) excluded, 1,583 (49%) underwent randomization

Table Part 3 Outcome Measures and Analysis of the Glucosamine/Chondroitin Arthritis Intervention Trial (GAIT)*

Outcome Measures | Adverse Events | Statistical Analysis | Study Quality Rating***
Primary Outcome: | At each study visit, safety monitoring included: | Analysis of the primary outcome measure conducted according to the ITT | Criteria:
20% decrease in the summed score for the WOMAC pain subscale from baseline to week 24 | Complete blood counts | All statistical tests were two-sided | Initial assembly and maintenance of comparable groups: Yes
Secondary Outcomes: | Serum aspartate and alanine aminotransferase levels, glucose, glycosylated hemoglobin levels (diabetics only) creatinine, and partial thromboplastin time | An absolute increase in the response rate of 15%, as compared with the rate in the placebo group, was considered to indicate a clinically meaningful treatment effect | Important differential loss to follow-up or overall high loss to follow-up: No (average drop-out rate 20.5%, range 16.4% to 23.7%, NS)
Scores for the stiffness and function subscale of WOMAC | Urinalysis | Pairwise comparisons of the GH, CS and combined-treatment groups with the PL group were made using a two-sided chi-square test at alpha = 0.017 for each comparison (overall alpha = 0.05) | Use of equal, reliable, and valid measurements, including masking of outcome assessment: Yes (described as double-blind design)
Patient's global asssessment of disease status and response to therapy, using 100 mm VAS | At week 24: | Secondary outcomes analyzed according to pairwise comparison scheme outlined above | Clear definition of interventions: Yes (active and PL regimens clear)
Investigator's global asssessment of disease status and response to therapy, using 100 mm VAS | Fecal occult blood (Hemoccult, Bedkman Coulter) | Chi-square test used for categorical data | All important outcomes considered: Yes (primary and secondary well-described)
Presence or absence of soft-tissue swelling, effusion, or both in the index knee | | T-test for independent groups used to compare changes between groups in quantitative data from baseline to end of study | Adjustment for potential confounders and ITT analysis: Yes (stipulated in text)
Scores on the Medical Outcomes Study 36-item Short-Form General Health Survey | | Used last-observation-carried forward method to analyze all outcomes among patients who made at least one follow-up visit but who did not complete follow-up | Overall rating: Good (meets all criteria)
Scores on the Health Assesment Questionnaire | | | Unclear if subgroup analysis by pain stratum was planned or unplanned
Acetaminophen use

* Clegg DO, Reda DJ, Harris CL, et al. Glucosamine, chondroitin sulfate, and the two in combination for painful knee osteoarthritis. New Engl J Med. 2006;354:795–808.

** OA = osteoarthritis; WOMAC = Western Ontario and McMaster Universities; VAS = visual analog scale; GH = glucosamine hydrochloride; CS = chondroitin sulfate; PL = placebo

*** U.S. Preventive Services Task Force approach

Table Part 1 Additional RCT Sample Selection

Study | Inclusion | Exclusion | No. Enrolled | No. Withdrawn (%) | No. with Outcome Evaluated (%)
Herrero-Beaumont et al (2007) | May 2000–December 2002 | Did not meet OARSI criteria* for exclusion from OA clinical trial; enrollment of obese (BMI > 30 kg/m^2^) patients discouraged | 325 | 6 mos: | 6 mos:
| Outpatients (age not specified); clinically symptomatic idiopathic OAK (ACR criteria), with a K-L grade 2–3 | | GS: 106 | GS: 28 (26) | GS: 78 (74)
| | | Acetaminophen: 108 | Acet: 27 (25) | Acet: 80 (74)
| | | Pl: 104 | Pl: 34 (33) | Pl: 70 (67)
Michel et al (2005) | March 1996–May 2001 | Any causes of secondary OAK (calcium pyrophosphate deposition disease, traumatic knee lesions) severe comorbidity; previous joint surgery; intraarticular medications in the previous month; foreseeable major surgery during the 2-years study period | 300 | 24 mos: | 24 mos:
| Age 40–85 years; clinically symptomatic OAK (pain while standing, walking, and/or in motion for at least 25 of the 30 days prior to entry, with no required minimum level of pain); diagnosed according to ACR criteria of OAK; K-L grades 1,2, or 3 | | CS: 150 | CS: 40 (27) | CS: 110 (73)
| | | Pl: 150 | Pl: 41 (27) | Pl: 109 (73)
Uebelhart et al (2004) | February 1996–June 1998 | Other inflammatory joint diseases or systemic conditions affecting or involving the joints; primary or secondary neoplasias; bone metabolic diseases and/or other metabolic or systemic diseases; other treatments such as intraarticular corticosteroids, NSAIDs, symptom-modifying agents or bone-oriented therapies such as fluorides, bisphosphonates, calcitonin or patients under hormonal substitution within 3 mos before beginning the study | 120 | 3–12 mos: | 12 mos:
| Age 40 years and over, clinically symptomatic idiopathic OAK (ACR criteria), with a K-L grade 1–3 and a minimum 25% remaining medial femoro-tibial joint space | | CS: 54 | CS: 11 | CS: 54 (90)
| | | Pl: 56 | Pl: 15 | Pl: 56 (93)
Das and Hammad (2000) | Pts not exhibiting any of the exclusion criteria who had an ISK of at least 7 points; K-L grade ≥ 2; both genders, age 45 – 75 years, ambulatory, willingness to comply with protocol, OA symptom duration ≥ 6 mos; allocated to study groups using randomized block design using computer-based pseudo-random number generator with code concealed to pts and investigators | Pregnancy; severe activity-limiting chronic diseases; non-insulin-dependent diabetes; alcoholism; history of significant hematological disorder, hepatic or renal impairment; active peptic ulcer; associated musculoskeletal disease other than OAK; associated metabolic diseases; injury to or surgery on index knee within 6 mos; intraarticular corticosteroid injection within previous 2 mos; regular use (> 3 times weekly) of NSAID during previous 2 mos | 93 | 6 mos: | 6 mos:
| | | GH/CS: 46 | GH/CS: 1 (2) | GH/CS: 46 (100)
| | | Pl: 47 | Pl: 3 (6) | Pl: 47 (100)
| | | Trial designed to have 80% power to detect difference of 2 points or more between intervention and placebo in the primary outcome (ISK score)

* Altman R, Brandt K, Hochberg M, Moskowitz R. Design and conduct of clinical trials of patients with osteoarthritis: recommendations from a task force of the Osteoarthritis Research Society. Osteoarthirtis Cartilage 1996;4:217–43.

Table Part 2 Additional RCT Baseline Patient Characteristics^a^

Study (Year) | Intervention (Dose) | No. Pts Tx/Pl | Mn Age (yrs) Tx/Pl | Female Pts (%) Tx/Pl | BMI (kg/m^2^) Tx/Pl | OA Diag^b^ (%) | OA Stage (%Tx/%Pl)^c^ | Mn Dis Duration (yrs) Tx/Pl | Mn VAS Rest (mm) Tx/Pl | Mn WOMAC Pain Tx/Pl | Mn WOMAC Function Tx/Pl | Mn WOMAC Stiffness Tx/Pl | Mn WOMAC Total Tx/Pl | Mn LI Tx/Pl
Herrero-Beaumont et al 2007 | GS (1500 mg/day) | 106/108/104 | GS: 63.4 ± 6.9 | 91/93/89 | GS: 27.7 ± 2.3 | 1° (100) | KL 2: 50/56/50 | GS: 7.4 ± 6.0 | | GS: 7.8 ± 3.0 | GS: 27.8 ± 11.4 | NR | GS: 38.3 ± 15.2 | GS: 11.0 ± 3.1
| | | Acet: 63.8 ± 6.9 | | Acet: 27.9 ± 2.3 | | KL 3: 41/31/39 | Acet: 6.5 ± 5.3 | | Acet: 8.0 ± 2.9 | Acet: 29.4 ± 11.0 | | Acet: 40.4 ± 14.8 | Acet: 11.1 ± 2.7
| | | Pl: 64.5 ± 7.2 | | Pl: 27.6 ± 2.4 | | Kl 2/3: 9/12/11 | Pl: 7.2 ± 5.8 | | Pl: 7.9 ± 3.0 | Pl: 27.2 ± 10.9 | | Pl: 37.9 ± 14.3 | Pl: 10.8 ± 2.6
Michel et al (2005) | CS 4&6 (800 mg/day) | 150/150 | T: 62.5 ± 9.1 | 51/52 | Tx: 27.7 ± 5.2 | 1° (100) | KL | NR | | (0–10) 2.5/2.7 | (0–10) 2.1/2.5 | (0–10) 3.0/3.5 | (0–10) 2.3/2.6
| | | Pl: 63.1± 10.7 | | Pl: 28.1 ± 5.5 | | All: 1–3 (100)
Uebelhart et al (2004) | CS 4&6 (800 mg/day) | 54/56 | Tx: 63.2 ± 9.1 | 80/82 | NR | 1° (100) | KL | 4.2/4.4 | 58.8/61.1 | | | | | 9.0/9.1
| | | Pl: 63.7± 8.1 | | | | 1 (7/6)
| | | | | | | 2 (32/33)
| | | | | | | 3 (15/17)
Das and Hammad (2000) | GH (1500 mg/day) plus CS (1600 mg/day) | 46/47 | Tx: 64.5 ± 9.8 | 72/78 | Tx: 30.5 ± 1.0 | 1° | KL 2/3 (72/83) | 5.6/7.4 | | | | | (0–2,400) | KL 2/3: 10.2/10.4
| | | Pl: 66.0 ± 1.5 | | Pl: 30.2 ± 0.9 (SEM) | Tx: 85 | KL 4 (28/17) | | | | | | KL 2/3: 908/944 | KL 4: 11.1/10.7
| | | | | | Pl: 87 | | | | | | | KL 4: 1187/1089

a All values are mean ± SD unless otherwise noted; CS = chondroitin sulfate; OA = osteoarthritis

b ACR = American College of Rheumatology

c KL = Kellgren and Lawrence criteria

d Outcomes are generally those that are denoted in the paper as being the primary study outcomes; WOMAC = Western Ontario and McMaster Universities Osteoarthritis Index; VAS = visual analog scale

Table Part 3 Additional RCT Treatments

Study | Intervention | Dose (mg/day) | Prior Treatments | Concurrent Treatments
Herrero-Beaumont et al (2007) | GS | 1500 | None specified | Rescue analgesia, ibuprofen 400 mg every 8 hr for maximum of 3 consecutive days
Michel et al (2005) | CS 4&6 | 800 | None specified | Rescue analgesia, either acetaminophen maximum 3000 mg/day or NSAID for up to maximum of 5 consecutive days; physical therapy limited to application of warmth and strengthening exercises as needed
Uebelhart et al (2004) | CS 4&6 | 800 | None specified | Rescue analgesia, acetaminophen maximum 4000 mg/day
Das and Hammad (2000) | GH plus CS | GH: 1500 | Occasional use of NSAID | Rescue analgesia, either acetaminophen or NSAID for up to maximum of 3 days per week;
| | CS: 1600

CS = chondroitin sulfate; GH = glucosamine hydrochloride; NSAID = non-steroidal antiinflammatory drug

Table Part 4 Additional RCT Outcome Assessment

Study (Year) | Outcomes Assessed | Response Criteria | Observer | F/U
Herrero-Beaumont et al (2007) | Primary outcome: Lequesne's index (0–24); secondary outcomes 0–4 point Likert scale WOMAC; OARSI-A and -B; proportion of patients reporting at least minimal clinically important improvement (MCII) | OARSI-A responder criteria that define high degree of improvement in pain as either 55% relative change on WOMAC pain subscale and absolute change of at least 30 on a 0–100 standardized scale or moderate improvement in 2 of 3 domains of pain, function and patients global assessment (35%, 15% and 15% relative changes, with 10, 20 and 15 standardized units of absolute change, respectively | Study personnel unaware of group assignment | After 15 days of therapy, then monthly over 6 mos
Michel et al (2005) | WOMAC score (0–10), total (24 questions), pain (5 questions), function (17 questions), stiffness (2 questions); 50-ft walking time; numerical rating scales ranging from 1 to 10 were used; adverse events | Improvement of WOMAC scores based on percentage change from baseline, separate analysis of individual WOMAC subscales, compared using repeated- measures ANOVA and comparison of the 2-year variations using Wilcoxon test | Study personnel unaware of group assignment | Every 3 mos over 24 mos study period
Uebelhart et al (2004) | Primary outcome: Lequesne's algofunctional index at the end of the study; secondary outcomes: spontaneous joint pain assessed by Huskisson's VAS (100 mm); 20-meter walking time on flat track; gobal assessment of efficacy by patient and physician; overall acetaminophen consumption; safety and tolerability | Absolute and percentage change from baseline of mean LI scores, walking time, Huskisson VAS, and AEs compared using repeated-measures ANOVA with Bonferroni's correction for multiple comparisons | Study personnel unaware of group assignment | Every 3 mos over 12 mos study period
Das and Hammad (2000) | Primary outcome: Lequesne's index of severity of OAK; secondary outcomes: VAS version of WOMAC, patient's global assessment, use of pain rescue medication; stratified at randomization by radiographic severity of OAK into mild-to-moderate and severe strata | Positive response defined as improvement of 25% or more in any of the parameters (LI, WOMAC, global assessment) | Study personnel unaware of group assignment | Every 2 mos over 6 mos study period

Table Part 1 Subgroup Analysis of RCTs of Glucosamine Meeting Protocol Study Selection Criteria

Study (Year) | Relevant Subgroup Results Reported | Subgroup report using ITT sample or per protocol | Method for imputing missing data if present (ie no missing or method)
Herrero-Beaumont et al (2007) | N | NA | NA
Clegg et al (2006) | Y | ITT | LOCF method
Usha and Naidu (2004) | N | NA | NA
Hughes and Carr (2002) | N | NA | NA
Pavelka et al (2002) | N | NA | NA
Reginster et al (2001) | N | NA | NA
Ridone et al (2000) | N | NA | NA
Houpt et al (1999) | N | NA | NA
Rovati (1997) | N | NA | NA
Noack et al (1994) | N | NA | NA
Pujalte et al (1980) | N | NA | NA

Table Part 2 Subgroup Analysis of RCTs of Glucosamine Meeting Protocol Study Selection Criteria

Study (Year) | Reporting | | | | | | | | Description
| Subgroup Reported (Y/N) | | | | | | | | Subgroup Reported; Result; subgroup size; total randomized
| Age | Ethnicity/Race | Sex | Primary/Secondary OA | Weight/BMI | Disease Duration | Disease Severity | Previous Treatment | Age | Ethnicity/Race | Sex | Primary/Secondary OA | Weight/BMI | Disease Duration | Disease Severity | Previous Treatment
Herrero-Beaumont et al (2007) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Clegg et al (2006) | N | N | N | N | N | N | Y | N | N | N | N | N | N | N | WOMAC pain: moderate-to-severe (pain score 301–400) n = 70–72; mild (pain score 125–300) n = 243–248; total randomized = 1,583; NSD for any comparison
Usha and Naidu (2004) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Hughes and Carr (2002) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Pavelka et al (2002) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Reginster et al (2001) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Ridone et al (2000) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Houpt et al (1999) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Rovati (1997) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Noack et al (1994) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Pujalte et al (1980) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA

Table Part 3 Subgroup Analysis of RCTs of Glucosamine Meeting Protocol Study Selection Criteria

Study (Year) | Specific Subgroup Methods
| Interaction test performed prior to subgroup analyses Y/N | Interaction reported as qualitative or quantitative qual/quan | Stratified analysis (Mantel-Haenszel) or regression term for interaction | Stratified randomization and prespecified subgroups (number planned) | Prespecified subgroups w/o stratified randomization (number planned) | Post hoc subgroups | Adjustment for multiple testing (type I error) | Probable number of statistical tests conducted | Method for multiple testing adjustment (Bonf, Holm, Hocheberg, Hommel)
Herrero-Beaumont et al (2007) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Clegg et al (2006) | Y | quan | N | Y (3) | N | N | Y | 3 | Bonf
Usha and Naidu (2004) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Hughes and Carr (2002) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Pavelka et al (2002) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Reginster et al (2001) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Ridone et al (2000) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Houpt et al (1999) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Rovati (1997) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Noack et al (1994) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Pujalte et al (1980) | NA | NA | NA | NA | NA | NA | NA | NA | NA

Table Part 1 Subgroup Analysis of RCTs of Chondroitin Meeting Protocol Study Selection Criteria

Study (Year) | Relevant Subgroup Results Reported | Subgroup report using ITT sample or per protocol | Method for imputing missing data if present (ie no missing or method)
Clegg et al (2006) | Y | ITT | LOCF method
Michel et al (2005) | N | NA | NA
Uebelhart et al (2004) | N | NA | NA
Mazieres et al (2001) | N | NA | NA
Bourgeois et al (1998) | N | NA | NA
Bucsi and Poor (1998) | N | NA | NA
Conrozier (1998) | N | NA | NA
Uebelhart et al (1998) | N | NA | NA
L'Hirondel (1992) | N | NA | NA

Table Part 2 Subgroup Analysis of RCTs of Chondroitin Meeting Protocol Study Selection Criteria

Study (Year) | Reporting | | | | | | | | | | | | Description
| Subgroup Reported (Y/N) | | | | | | | | | | | | Subgroup Reported; Result; subgroup size; total randomized
| Age | Ethnicity/Race | Sex | Primary/Secondary OA | Weight/BMI | Disease Duration | Disease Severity | Previous Treatment | Age | Ethnicity/Race | Sex | Primary/Secondary OA | Disease Severity | Previous Treatment
Clegg et al (2006) | N | N | N | N | N | N | Y | N | N | N | N | N | WOMAC pain: moderate-to-severe (pain score 301–400) n = 70–72; mild (pain score 125–300) n = 243–248; total randomized = 1,583; NSD for any comparison | N
Michel et al (2005) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Uebelhart et al (2004) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Mazieres et al (2001) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Bourgeois et al (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Bucsi and Poor (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Conrozier (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Uebelhart et al (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
L'Hirondel (1992) | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA

Table Part 3 Subgroup Analysis of RCTs of Chondroitin Meeting Protocol Study Selection Criteria

Study (Year) | Specific Subgroup Methods
| Interaction test performed prior to subgroup analyses Y/N | Interaction reported as qualitative or quantitative qual/quan | Stratified analysis (Mantel-Haenszel) or regression term for interaction | Stratified randomization & prespecified ubgroups (number planned) | Prespecified subgroups w/o stratified randomization (number planned) | Post hoc subgroups | Adjustment for multiple testing (type I error) | Probable number of statistical tests conducted | Method for multiple testing adjustment (Bonf, Holm, Hocheberg, Hommel)
Clegg et al (2006) | Y | Quant | N | Y | N | N | Y | 3 | Bonf
Michel et al (2005) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Uebelhart et al (2004) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Mazieres et al (2001) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Bourgeois et al (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Bucsi and Poor (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Conrozier (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA
Uebelhart et al (1998) | NA | NA | NA | NA | NA | NA | NA | NA | NA
L'Hirondel (1992) | NA | NA | NA | NA | NA | NA | NA | NA | NA

Table Part 1 Subgroup Analysis of RCTs of Glucosamine plus Chondroitin Meeting Protocol Study Selection Criteria

Study (Year) | Relevant Subgroup Results Reported | Subgroup report using ITT sample or per protocol | Method for imputing missing data if present (ie no missing or method)
Clegg et al (2006) | Y | ITT | LOCF method
Das and Hammad (2000) | Y | ITT | LOCF method

Table Part 2 Subgroup Analysis of RCTs of Glucosamine plus Chondroitin Meeting Protocol Study Selection Criteria

| Reporting | | | | | | | | Description
| Subgroup Reported (Y/N) | | | | | | | | Subgroup Reported; Result; subgroup size; total randomized
Study (Year) | Age | Ethnicity/Race | Sex | Primary/Secondary OA | Weight/BMI | Disease Duration | Disease Severity | Previous Treatment | Age | Ethnicity/Race | Sex | Primary/Secondary OA | Weight/BMI | Disease Duration | Disease Severity | Previous Treatment
Clegg et al (2006) | N | N | N | N | N | N | Y | N | N | N | N | N | N | N | WOMAC pain: moderate-to-severe (pain score 301–400) n = 70–72; mild (pain score 125–300) n = 243–248; total randomized = 1,583; P < 0.002 vs Pl for 20% reduction in WOMAC pain in moderate-severe pain; NSD for pts in mild pain | N
Das and Hammad (2000) | N | N | N | N | N | N | Y | N | N | N | N | N | N | N | LI: mild-moderate: GC = 33/Pl = 39; severe: GC = 13/Pl = 8; total randomized = 93; P = 0.04 vs Pl for pts in mild-moderate pain; NSD vs Pl for pts in severe pain | N

Table Part 3 Subgroup Analysis of RCTs of Glucosamine plus Chondroitin Meeting Protocol Study Selection Criteria

| Specific Subgroup Methods
Study (Year) | Interaction test performed prior to subgroup analyses Y/N | Interaction reported as qualitative or quantitative qual/quan | Stratified analysis (Mantel-Haenszel) or regression term for interaction | Stratified randomization and prespecified subgroups (number planned) | Prespecified subgroups w/o stratified randomization (number planned) | Post hoc subgroups | Adjustment for multiple testing (type I error) | Probable number of statistical tests conducted | Method for multiple testing adjustment (Bonf, Holm, Hocheberg, Hommel)
Clegg et al (2006) | Y | Quant | N | Y (3) | N | N | Y | 3 | Bonf
Das and Hammad (2000) | N | NR | NR | Y (2) | N | N | N | 1 | NR

## Part III. Arthroscopy Tables

Table IIIA Randomized Studies of Arthroscopic Lavage/Debridement

Author (Year) | Patient Inclusion/Exclusion Criteria | Interventions
Gibson et al (1992) | Inclusion: | Arthroscopic Lavage:
| Moderate unilateral osteoarthritis (OA) of the knee | N = 10, 6 M/4 F, mean age 53 ± 10 yrs
| Exclusion: | Arthroscopic Debridement:
| Age > 70 yrs, > 20 degree varus or valgus deformity measured on a weight-bearing radiograph | N = 10, 8 M/2 F, mean age 57 ± 7 yrs
Chang et al (1993) | Inclusion: | Closed-Needle Joint Lavage:
| Persistent knee pain for > 3 mos, despite conservative medical and rehabilitation, which restricted activities, weight-bearing radiographs showing grade 1,2, or 3 changes according to Kellgren and Lawrence (KL), age > 20 yrs, willingness to follow-up at 3 and 12 mos, and give informed consent | N = 14, 4 M/10 F, mean age 65 ± 13 yrs
| Exclusion: | Arthroscopic Surgery
| Knee surgery within 6 mos of study entry, total knee replacement (TKR) concurrent illness that would influence functional assessment of the knee or preclude arthroscopic surgery, KL class 4 changes on radiographs | (debridement/excision of proliferative synovium or loose bodies):
| | N = 18, 5 M/13 F, mean age 61 ± 11 yrs
Edelson et al (1995) | Inclusion: | 23 patients, 20 M/3 F, mean age 58 yrs (rng 39–79)
| Symptomatic knee OA unresponsive to NSAID therapy, grade I –III radiographic OA according to Holden et al (1988) | 29 knees were subjected to arthroscopic washout with hypertonic lactated Ringer's solution
| Exclusion: | Immediately following initial washout, patients were randomly allocated to:
| Clinical signs or symptoms of meniscal tears or obvious mechanical symptoms | Placebo Treatment:
| | 13 knees received a 3 mL intraarticular (IA) injection of placebo (lactated Ringer's solution)
| | IA Hyaluron Treatment:
| | 16 knees received a single 3 mL IA injection of hyaluronic acid (0.5–1.0 mD)
Hubbard (1996) | Inclusion: | Arthroscopic Lavage:
| Symptoms of knee OA > 1 yr, no prior surgery to index knee, no laxity, no deformity, single medial femoral condyle degenerative lesion grade 3 or 4 (Outerbridge), no other IA pathology, normal plain radiograph, modified Lysholm score < 38/70 | N = 36, 20 M/16 F, mean age classified according to success (46 yrs) or failure (59 yrs)
| Exclusion: | Arthroscopic Debridement:
| All knees that showed radiographic loss of joint space, previous operation, previous steroid injection for any reason | N = 40, 28 M/12 F, mean age classified according to success (51 yrs) or failure (45 yrs)
Ravaud et al (1999) | Inclusion: | Placebo Treatment:
| American College of Rheumatology (ACR) criteria for knee OA, pain scored by patient at 40 or greater on a 100-mm visual analog scale (VAS), radiographic evidence of at least KL grade II tibiofemoral OA (within last 6 mos) with osteophytes and minimal joint space narrowing | N = 28, 10 M/18 F, mean age 63 ± 11 yrs
| Exclusion: | IA Corticosteroid Treatment:
| Serious concomitant illness, secondary OA as defined by the Osteoarthritis Research Society, knee surgery scheduled within the following 12 mos, local or systemic contraindication to the use of IA corticosteroids or to joint lavage, any IA injection during the 3 mos prior to study entry, current treatment with systemic corticosteroids or any slow-acting anti-OA drugs | N = 25, 7 M/18 F, mean age 67 ± 12 yrs
| | Arthroscopic Lavage plus Placebo Treatment:
| | N = 21, 7 M/14F, mean age 65 ± 8 yrs
| | Arthroscopic Lavage plus IA Corticosteroid Treatment:
| | N = 24, 8 M/16F, mean age 67 ± 11 yrs
Kalunian et al (2000) | Inclusion: | Control Group - Minimal Arthroscopic Lavage:
| Age > 40 yrs, knee pain for 10 yrs or less, unsatisfactory pain relief despite 6 wks of supervised physical therapy and two or more different NSAIDs and/or analgesics given for 3 or more wks each, willingness to undergo follow-up and give informed consent, normal or minimally abnormal radiographs (KL grade 0–2), fulfill ACR criteria for classification of knee OA using either clinical and radiographic, traditional clinical or clinical and laboratory methods, or classification tree clinical or clinical and laboratory methods | N = 49, 23 M/26 F, mean age 58 yrs (rng 40–85)
| Exclusion: | Treatment Group - Large Volume Arthroscopic Lavage:
| Back/hip or ankle/foot OA of significant severity to confuse the clinical assessment of knee OA, IA corticosteroid injection within 1 mo prior to study, significantly abnormal radiographs (KL grades 3–4), body mass index (BMI) > 35 kg/m2, sensitivity to amide anesthetic agents, serious medical illness that would place patient at risk in the event of surgery, recent history of substance abuse | N = 41, 19 M/22 F, mean age 61 yrs (rng 41–88)
Smith et al (2003) | Inclusion: | Arthroscopic Lavage plus Placebo Injection:
| Symptomatic OA of the knee, fulfilling ACR criteria for knee OA, already receiving NSAID or other analgesic therapy | N = 33, 18 M/15 F, mean age 66 ± 12 yrs
| Exclusion: | Arthroscopic Lavage plus IA Corticosteroid Treatment:
| Mechanical symptoms upon diagnostic arthroscopy, comorbidities preventing arthroscopy, unwillingness to comply with study demands or provide informed consent | N = 38, 26 M/12F, mean age 67 ± 10 yrs
Frias et al (2004) | Inclusion: | Overall 299 knees belonging to 205 patients (45 M/160 F), mean age 67 ± 8 yrs were randomly allocated to:
| Symptomatic OA of the knee for > 3 mos despite conservative medical therapy, fulfilled ACR criteria for knee OA, KL OA radiological grades 2–3, no disability assessment at the time of enrollment, voluntary cooperation and informed consent, age > 18 yrs | Arthroscopic Lavage:
| Exclusion: | N = 62, sex and age not given
| Ankylosis of the index joint, TKA of the index knee, potentially infected injury near puncture site, current anticoagulant therapy, history of coagulation problems, suspected deep venous thrombosis (DVT) or marked venous insufficiency, history of surface thrombosis or DVT | Arthroscopic Lavage Plus IA Corticosteroid Injection:
| | N = 237, sex and age not given

Table IIIB Arthroscopy Case Series Sample Selection

Study | Inclusion | Exclusion | n, Enrolled | n, Withdrawn | n, Outcome Evaluated
Aaron 2006, ALD | Consecutive pts; met ACR OA of tibiofemoral joint; failed oral anti-inflammatory treatment; age 18–70 yo; Kellgren-Lawrence grade ≥ 2 | Previous infection; OA of pattelo-femoral joint; other/confounding diabnoses; | 122 | 12 | 110
Bernard 2004 ALD | 01/91 – 12/93; consecutive patients who underwent knee arthroscopy and washout for OA of the knee (Outerbridge grade 3 or 4); pain not controlled by non-operative treatments; radiographic OA changes; | | 100 knees, 99 pts | | 100 knees, 99 pts
Krystallis 2004 ALD | 02/97 – 06/01; OA of the knee; standard conservative non-operative treatment had failed; local anesthesia (L) in 67 pts (71 operations); general anesthesia (G) in 65 pts; peridual anesthesia (P) in 65 pts; local anesthesia contraindicated for emotionally labile, low tolerance for discomfort | | 201 knees, 197 pts | | 201 knees, 197 pts
Dervin 2003 AD | 03/95 – 11/97; OA of knee; 40–75 yo; referred to orthopaedic outpatient clinic at Ottawa Hospital General Campus; remained symptomatic despite supervised physical therapy and comprehensive medical management | Inflammatory/traumatic forms of OA; | 156 pts | 30 pts | 126 pts
Jackson and Dieterichs 2003 ALD | 01/95 – 06/97; ACR criteria diagnosis of OA of knee; Jackson and Dieterichs stage I–IV; consecutive series | Stage I and IV not suited for arthroscopy; pts treated with marrow stimulation techniques, laser or radio-frequency chondroplasty | 121 pts | | 121 pts
Bohnsack 2002 AD | 05/89 – 11/96; history of knee pain, swelling, radiological signs of severe OA (grade III/IV) | | 104 pts | | 104 pts
Shannon 2001 ALD | Retrospective consecutive series of all pts with mild-moderate OA who had arthroscopic lavage and/or debridement of knee over 4-yr period; symptoms not severe enough for joint replacement; conservative treatment alone had failed or non-specific mechanical symptoms out of proportion to clinical and radiologic findings | Preop clinical/radiologic diagnosis of meniscal tear or loose body | 55 procedures, 54 pts | | 55 procedures, 54 pts
Harwin 1999 ALD | 1980 -1993; of 2,730 knee arthroscopies by author, 248 knees in 220 pts had areas of fibrillated articular cartilage with exposed bone and underwent debridement; Group I - mechanical axis normal at 0^°^ (n=57); Group II - ≤ 5^°^ of varus or valgus (n=102); Group III - > 5^°^ varus or valgus (n=45); unresponsive to all modalities of nonoperative treatment, including lifestyle alterations, NSAIDs, PT, occasional IA steroid injection | | 248 knees, 220 pts | 44 knees, 30 pts | 204 knees, 190 pts
McGinley 1999 AD | 1981-87; of 191 pts > 55 yo who underwent arthroscopic debridement by 1 surgeon; pts with OA symptoms including pain limiting function and Albach radiographic JSN grade 2–3; > 10 yr F/U | | 91 knees, 77 pts | | 91 knees, 77 pts
Linschoten and Johnson 1997 ALD | 07/85 – 01/88; of 169 pts who had arthroscopy of knee; age ≥ 40 yo; preop diagnosis of OA or RA with arthroscopically confirmed degenerative changes; degenerative changes in ≥ 2 of 3 compartments or single compartment Outerbridge III/IV | Arthroscopies for diagnosis or treatment of acute injuries, preliminary diagnosis of degenerative joint disease not confirmed intraoperatively | 68 knees, 67 pts | 12 knees, 12 pts | 56 knees, 55 pts
Yang and Nisonson 1995 ALD | 07/89 – 07/93; did not respond to conservative nonoperative treatment and had persistent evidence of internal derangement of knee; did not show severe signs and symptoms to merit total knee arthroplasty | History of rheumatoid arthritis; gout; ochronosis; ankylosing spondylitis; hemophilia; osteonecrosis; posttraumatic/postinfectious osteoarthritis | 105 procedures, 103 pts | | 105 procedures, 103 pts
Aichroth 1991 ALD | 77 – 88; had arthroscopic debridement and irrigation of a degenerative knee joint; under care of single author | | 280 pts | 26 pts | 276 knees; 254 pts
McLaren 1991 ALD | 07/82 – 07/86; OA confirmed at arthroscopy; nonoperative treatments either did not control symptoms sufficiently to allow normal daily activities or control rest pain | Inflammatory joint disease, malunited fractures and ligamentous instability | 171 pts | | 170 pts
Ogilvie-Harris and Fitsialos 1991 ALD | 1979 - 1987; arthroscopic surgery for degenerative arthritis of the knee; persistent symptoms despite adequate medical management | | 551 pts | 110 pts | 441 pts
Timoney 1990 ALD | 07/81 – 02/86; underwent knee arthroscopy at Naval Hospital, Oakland; age > 40 yo; intraoperative diagnosis of OA | Inflammatory disease (rheumatoid arthritis, acute infection arthritis), acute injury | 125 pts | 17 pts | 111 knees, 108 pts
Bert and Maschka 1989 AD | 09/81 – 12/82; all pts offered arthroscopic debridement plus abrasion arthroplasty (DA) for unicompartmental gonarthrosis, those who refused it were offered arthroscopic debridement alone (D); conservative methods of treatment had failed; available for 5 yr follow-up | | DA 59 pts; D 67 pts | | DA 59 pts; D 67 pts
Sprague 1981 ALD | 08/78 – 11/79; of 331 arthroscopies, 78 were pre- and postoperatively diagnosed as degenerative arthritis of the knee; moderate to extreme degeneration of the articular surfaces of 2–3 compartments; all pts had initially undergone a conservative treatment program with anti-inflammatories, exercise program, physical modalities | | 78 knees, 72 pts | 9 knees, 9 pts | 69 knees, 63 pts

Table IIIC Arthroscopy Case Series Patient Characteristics

Study | Age | Percent Female) | Race (%) | Obesity (%) | Disease Category (%) | Disease Duration | Preop Disease Severity (%) | Arthoscopic Disease Severity (%) | Pain | Function | Other Comorbidities or Prognostic Factors (%)
Aaron 2006 ALD | Mn 61.7 | 67 | | Mn BMI: 31.8 | | | Kellgren-Lawrence (2/3/4) | Noyes-Stabler mn total 21.6 | Knee Society | | Locking or buckling: 56
| | | | | | | 53/29/18 | | mn 11.9
Bernard 2004 ALD | Mn 55, sd 13 | 39
Krystallis 2004 ALD | L: mn 60.8, rng 31–71 | 49 | | | 1°: 94 | | Fairbank | Outerbridge: | | | Mechl sx: 33
| G: mn 59.9, rng 30–67 | | | | 2°: 6 | | 0:12 | I/II: 12 | | | Loading sx: 67
| P: mn 62.2, rng 35–75 | | | | | | I: 36 | III: 28 | | | No. damaged compartments
| | | | | | | II: 40 | IV: 60 | | | 1:52.2
| | | | | | | III: 12 | | | | 2:40.3
| | | | | | | | | | | 3:7.5
| | | | | | | | | | | Limited ROM: 45.8
Dervin 2003 AD | Mn 61.7, sd 8.6 | 53 | | BMI > 27: 67 | | | | Dougados | WOMAC | WOMAC | Giving way: 39
| | | | BMI > 33: 25 | | | | Medial III/IV: 62 | M: mn 22, sd 11.2 | M: mn 72, sd 34.8 | Locking: 22
| | | | | | | | Lateral III/IV: 13 | F: mn 25.5, sd 9.9 | F: mn 87.2, sd 38.9 | Unstable meniscal tear: 63
Jackson and Dieterichs 2003 ALD | I: mn 35.5, rng 22–60 | | | | | | Jackson and Dieterichs
| II: mn 54, rng 26–85 | | | | | | I: 7
| III: mn 56, rng 24–78 | | | | | | II: 26
| IV: mn 64, rng 41–83 | | | | | | III: 32
| | | | | | | IV: 35
Bohnsack 2002 AD | Mn 60, rng 50–83 | 52 | | | | | Jaeger and Wirth III/IV in medial or lateral compartments | Outerbridge: III/IV: 50–80% by surface | | Lysholm and Gillquist
| | | | | | | | | | Mn 40
Shannon 2001 ALD | Mn 60.9, rng 48–83 | 56 | | Mn wt: 76.6 kg, rng 54–100 | | # mo: %
| | | | | | < 3: 20
| | | | | | 3–12: 43
| | | | | | > 12: 39
Harwin 1999 ALD | Mn 62.1, rng 32–88 | 57
McGinley 1999 AD | Mn 62.6, rng 55–82 | | | | | | | Outerbridge: IV: 100
Linschoten and Johnson 1997 ALD | Mn 62.5, rng 41–79 | 51
Yang and Nisonson 1995 ALD | Mn 64.2, sd 4.3 | 19 | | | | # mo: % | Fairbank
| | | | | | < 1: 17 | 0:15
| | | | | | 1–12: 62 | I: 50
| | | | | | > 12: 15 | II: 24
| | | | | | | III: 7
Aichroth 1991 ALD | Mn 49, rng 28–82 | 28 | | | | | | | | | Pain (100%), night pain (15%), swelling (76%), instability (54%), locking (36%)
McLaren 1991 ALD | Mn 54, rng 23–82 | 30 | | | 1°: 81
| | | | | 2°: 19
Ogilvie-Harris and Fitsialos 1991 ALD | Mn 58, rng 28–92 | | | | | ≥ 2 yrs in most pts | | Outerbridge
| | | | | | | | I/II: 32
| | | | | | | | III: 36
| | | | | | | | IV: 32
Timoney 1990 ALD | Mn 58.1, rng 40–81 | 31 | | | | mn 48.9 mo, rng 2–144 | 0–III scale | | HSS
| | | | | | | | | Mn 24.7, sd 9.2, rng 8–44
Bert and Maschka 1989 AD | DA mn 66, rng 46–84 | DA 46 | | % obese: | | | Ahlback | Outerbridge | | | DA pts all had < 15o varus/valgus malalignment
| D mn 61, rng 39–82 | D 42 | | DA 26 | | | II–100 | IV: 100
| | | | D 22
Sprague 1981 ALD | Mn 56, rng 24–78 | 38

Table IIID Arthroscopy Case Series Treatments

Study | Arthroscopic Procedure | Prior Treatments | Concurrent Treatments
Aaron 2006 ALD | One surgeon; 3 portals; Dyonics 4 mm arthroscope; limited surgical debridement of damaged cartilage with chromotome; loose flaps resected; crater edges smooted; loose bodies removed; torn meniscal cartilage, hypertrophic synovial tissue resected; no drilling/abrasion; joint irrigated and evacuated | Mn 2 different NSAIDs; intra-articular | Knee immobilizer, partial weight-bearing for 2–3 days, then ROM exercises/gait as tolerated
| | corticosteroid injections in 20; physical therapy in 12
Bernard 2004 ALD | 2 portal arthroscopy; 1 surgeon; meniscal tears resected (meniscectomy in 40); debridement of loose bodies, unstable chondral flaps; lavage; no synovectomy; punches, scissors and curettes; Outerbridge grading of all 3 compartments
Krystallis 2004 ALD | 2 portal arthroscopy; no tourniquet; 4-mm 30° arthroscope; IM midazolam; local anesthesia with ropivacine, lidocaine, bupivacaine; sterile saline lavage with infusion pump; debris/fragments removed; meniscal lesions given conservative partial meniscectomy without repair; unstable peripheral cartilage flaps removed; mechanical shavers, basket forceps; no abrasion arthroplasty; isolated chondral defects > 1 cm micro-fractured; Outerbridge grading | | Crutches, gradual progress to full weight bearing after 2–3 wks
Dervin 2003 AD | 2 portal arthroscopy; tourniquet optional; diagnosis first; resection of loose chondral flaps and unstable meniscal tears; synovectomy only when needed for visualization; standard hand and shaver instruments; no abrasion arthroplasty or drilling; | 25% had ≥ 1 IA cortisone; 58% regular users of non-narcotic analgesics and/or NSAIDs
Jackson and Dieterichs 2003 ALD | Arthroscopic lavage and debridement; removal of loose bodies; trimming of meniscal fragments; conservative or minimal mechanical removal of any separating or desquamating articular cartilage fragments from the femoral condyles
Bohnsack 2002 AD | Partial, subtotal or total meniscectomy in 73%; one or more loose bodies removed in 11%; shaving of articular surface in 35%; plica mediopatellaris dissected in 1%; diagnostic-only arthroscopy only in 11% | Pain-reducing drugs in 42.3%
Shannon 2001 ALD | General anesthesia; tourniquet; 4-mm 30° arthroscope; 2 portals; IA bupivacaine in 27 knees by surgeon's preference; diagnostic arthroscopy and lavage; removal of loose bodies, debridement of degenerative meniscus and partial meniscectomy in 19 pts | Unresponsive to conservative non-surgical treatments (PT, NSAIDs, weight loss) | Crutches; PT
Harwin 1999 ALD | Lavage and debridement; partial synovectomy; decompression of the anterior chamber by resection of impinging plicae and removal of hypertrophic adipose tissue; partial meniscectomies removed only loose unstable fragments; chondroplasties - removal of only loose, unstable or irregular flaps; osteophytes removed rarely if only directly impinging; general anesthesia in most cases, others had epidural/spinal or local | | Dressing removed in 24–48 hrs; pts encouraged to bear as much weight as tolerable, using cane, crutches, walker; PT as soon as possible; NSAIDs
McGinley 1999 AD | Debridement included meniscus tear resection and nonaggressive shaving of frayed articular cartilage; 5 pts also had drilling of the medial femoral condyle; 3 pts had removal of loose bodies; 1 pt had lateral release
Linschoten and Johnson 1997 ALD | Diagnostic first; individualized according to findings; meniscal tears excised by partial or total meniscectomy; loose bodies removed; synovium and fat interfering with visualization debrided; partial synovectomy when synovial impingement suspected; unstable articular cartilage flaps or fronds debrided; no drilling or abrasion chondroplasty; normal saline lavage | | Robert Jones dressing for 48–72 hrs; weight-bearing with cane/crutches as tolerated
Yang and Nisonson 1995 ALD | 2-portal arthroscopy; general or regional anesthesia; tourniquet used for all pts; 4-mm 30° arthroscope; lavage; intraarticular debris and loose bodies were removed; meniscal disease addressed by partial meniscectomy preserving as much stable meniscal tissue as possible; mechanical shavers, basket forceps to remove unstable cartilage flaps at the periphery; osteochondral fragments or articular cartilage lestion that potentially could detach and become loose bodies were removed; some isolated chondral defects > 1.5 cm drilled with multiple holes; synovectomies using mechanical shavers for significant peripatellar hypertrophic reactive synovitis; meniscal lesions found in 96% | 5 pts had previous surgery: arthroscopy and drilling, arthroscopy and debridement, repair of quadriceps rupture, excision of patella bursa, Maquet procedure | SC pubivacaine; light compressive dressing; partial weightbearing on crutches 4–7 d; progess to full weightbearing with cane 1–2 wk
Aichroth 1991 ALD | Degenerative meniscal tears excised and trimmed; degenerative articular cartilage shaved and loose bodies removed; small osteotome used to remove impinging osteophytes; overgrown synovium cut away; irrigation | | Compression bandage used with early exericies; motion and weight bearing as tolerated
McLaren 1991 ALD | 4 surgeons using similar surgical techniques; normal saline medium; tourniquet used; outpatient setting unless otherwise indicated medially; partial anterior synovectomy often required to aid in visualization; lavage; chondrectomy performed with motorized shaver or curette; removed articular cartilage that was separated from subchondral bone or had gross softening, fibrillation, fissuring; full-thickness chondrectomy often followed by curettage of subchondral bone or abrasion using a burr (except for eburnated subchondral bone in end-stage compartments); meniscal tears were treated with partial meniscectomy; free bodies removed; | Activity modification, anti-inflammatory agents; PT; | Local anesthetic; corticosteroids injected in selected patients with end-stage tricompart-mental disease; crutches followed by progression to full weight-bearing; PT; anti-inflammatory medications as required
Ogilvie-Harris and Fitsialos 1991 ALD | General anesthetic in most case, some had spinal or epidural anesthesia, ~5% had local; lavage and debridement (removal of loose areas of articular cartilage from degenerative area, preserving as much surrounding articular surface as stable) with manual and power instruments for mild and moderate OA; abrasion when erosions involving up to half femoral condyle; minor meniscal degeneration left alone, substantial unstable meniscal flap tears resected, rim contoured; saline lavage alone for extensive degenerative changes without mechanical lesions | NSAIDs in all, IA cortisone in ~25%; previous operation in 61%
Timoney 1990 ALD | Lavage, debridement of degenerative meniscal tears and chondral lesions, partial synovectomy with osteophytecomy as indicated
Bert and Maschka 1989 AD | DA abrasion using Dyonics abrasion instrumentation system; only stage IV lesions abraded; subchondral intracortical bone abraded to depth of ~ 1–2 mm until bleeding bone noted; additional debridement and partial meniscectomy; loose bodies and other joint debris removed; loose or impinging osteophytes removed; D performed with partial meniscectomy by manual and electrocautery instrumentation as above; partial synovectomy if necessary | | DA pts no weight bearing for 6 wks; D pts weight bearing when tolerable
Sprague 1981 ALD | General anesthesia; many outpatient; hospitalization < 36 hrs; 1 surgeon; tourniquet applied, sometimes used; 4 arthroscopes from 4 mm to 6.5 mm; mechanized shaving instruments; 2–3 portals; meniscal tears excised back to intact, stable meniscal tissue; shaggy degenerative tissue of articular surfaces was shaved and debrided; loose bodies, fragments and debris removed; osteophytes trimmed; localized areas of hypertrophic synovium trimmed or excised; synovectomy in 4 pts; normal saline lavage | | Bulky compression dressing for 36 hrs; encouraged to ambulate for limited distances; exercises; anti-inflammatories

Table IIIE Arthroscopy Case Series Outcome Assessment

Study | Outcomes Assessed | Response Criteria | Observer | F/U
Aaron 2006 ALD | Knee Society pain; need for total knee replacement | Post-treatment Knee Society pain success: ≤ 30 | Independent assessor | Mn 34 mo, rng 24–74 mo
Bernard 2004 ALD | Time to further major surgery (Kaplan-Meier) | Osteotomy, unicondylar arthroplasty, total knee replacement
Krystallis 2004 ALD | Baumgaertner (pain, function, patient enthusiasm, 0–9) | Excellent=9; Good=6–8; Fair=4–5; Failure=0–3 | | Mn 32 mo, rng 24–72
| Adverse events
Dervin 2003 AD | WOMAC pain; WOMAC stiffness; WOMAC function; SF-36 | MCIC per item (domain): WOMAC pain - 1.5 cm (7.5 cm); WOMAC stiffness - 1.75 cm (3.5 cm); WOMAC function - 2 cm (34 cm); success also defined as 20% improvement | | 2 yrs
Jackson and Dieterichs 2003 ALD | Patient global assessment | Excellent, good, fair, poor | | ≥ 4 yrs
Bohnsack 2002 AD | Lysholm and Gillquist score; use of pain-reducing drugs | | | Mn 5.4 yr, rng 2–9.8
| Further surgery
Shannon 2001 ALD | Duke arthroscopy score (NRS pain and function); subjective assessment of improvement; further surgery; adverse events | No change=0; fair=1–20, good=21–40; excellent=41–60 | | Mn 29.6 mo, rng 9–51
Harwin 1999 ALD | Patient global assessment | Better, unchanged, worse | | Mn 7.4, yr rng 2–15
McGinley 1999 AD | Further surgery | | | Mn 13.2 yr
Linschoten and Johnson 1997 ALD | Good/poor outcome; further surgery; adverse events | Good=symptomatic improvement, activity better than preop, satisfaction, would do again for other knee | | Mn 49 mo, rng 24–67
Yang and Nisonson 1995 ALD | Investigator-designed pain, function, range of motion (ROM); adverse events, further surgery | All 3 domains rated on 4-point scale, summed | | Mn 11.7 mo, sd 13.14, rng 6–60
| | Excellent=11–12; good=9–10; fair=6–8; poor=3–5
Aichroth 1991 ALD | Investigator-devised grade:symptoms, knee movement, ADLs, sports, analgesics; further surgery | Satisfactory (excellent, good); unsatisfactory (fair, poor) | | Mn 44 mo
McLaren 1991 ALD | Pain, function; satisfaction; further surgery; adverse events | Pain=none, mild, moderate, severe | | Mn 25 mo, rng 12–74
| | Function=ADLs, sports, work
Ogilvie-Harris and Fitsialos 1991 ALD | Pain; pain change; activity limitations activity change; analgesics; analgesics change; satisfaction | All outcomes on 4-point scale except satisfaction (3-point) | | Mn ~ 4 yr, rng 2–9
| | Good result=no or occasional pain and no or occasional limitations of activity
Timoney 1990 ALD | Modified Hospital for Special Surgery rating score (HSS, pain and function); patient subjective assessment of surgical outcome; adverse events; further surgery | HSS (8–52 points) | | Mn 50.6 mo, rng 24–96
| | Patient assessment: good, fair, poor
Bert and Maschka 1989 AD | Hospital for Special Surgery (HSS) system; further surgery | HSS, Excellent= ≥ 85; good=70–84; fair=60–69; poor= < 60 | | 5 yr
Sprague 1981 ALD | Subjective assessment (4 levels, worse to markedly better); functional level (3 levels, reduced to increased); additional surgery performed or contemplated (Y/N) | Good, fair, poor (article describes algorithm for combining subjective assessment, functional level and additional surgery) | | Mn 13.6 mo, rng 6–21

Table IIIF Arthroscopy Case Series Results

Study | Outcomes | | | | | | Outcomes
Aaron et al. 2006 ALD | Knee Society pain | | Pre | F/U | p | | Further surgery: total knee replacement (15%) - related to baseline Kellgren-Lawrence grade.
| Mn | | 11.9 | 30.8 | <0.001
| Success=Knee Society pain ≥ 30 in 72 (65%), failure in 38 (35%)
| Significant predictors of percent success: Kellgren-Lawrence grade, abnormal limb alignment, medial/lateral joint space width; intraoperative lesion severity; mechanical symptoms did not predict success,
Bernard 2004 ALD | 18 knees required further major surgery (osteotomy - 4; unicondylar arthroplasty - 3; total knee replacement - 11)
| 5-yr major surgery-free survival
| all: ~82%
| < 60 yo: 89%
| ≥ 60 yo: 68% (X ^2^, p=0.02)
| prior meniscectomy did not affect outcome
Krystallis 2004 ALD | Excellent results: | | | | | | Adverse events (#): minor intraoperative complications (6.1%); hemarthrosis (24.9%, 6.1% had to be drained)
| All pts: 42.3%
| Mechanical sx: 65.7%
| Loading sx: 30.6%
| No difference between anesthesia groups (ANOVA, p=0.71)
Dervin 2003 AD | MCII WOMAC pain: 44%
| MCII predicted by tenderness at medial joint line, positive Steinman, unstable meniscal tear (logistic regression)
Jackson and Dieterichs 2003 ALD | Group | Excellent/good | Fair | Poor | (%) | | | Repeat Arthroscopy (%) | Arthroplasty (%)
| All | 50 | 27 | 22 | | | I | 0 | 0
| I | 100 | 0 | 0 | | | II | 9 | 0
| II | 91 | 0 | 9 | | | III | 15 | 8
| III | 49 | 28 | 23 | | | IV | 7 | 29
| IV | 12 | 52 | 36
Bohnsack 2002 AD | Lysholm & Gillquist | | Pre | F/U | p | | | | Pre | F/U | p
| Mn | | 40 | 69 | <0.01 | | Use of pain-reducing drugs (%) | | 42 | 19 | 0.0003
| Higher gain in Lysholm & Gillquist score in pts < 60 yo, monolateral | | | | | | Between 5 and 98 mo (mn 33.1), 20% required further surgery: total knee arthroplasty (8%), monocondylar knee arthroplasty (4%), high tibial osteotomy (2%), repeat arthroscopy (4%), unspecified procedure (4%)
| OA; no influence of meniscectomy.
Shannon 2001 ALD | Assessment (%) | | Improved | Unchanged | Worse | | Further surgery: arthroscopy (7.4%); total knee arthroplasty (18.5%)
| All pts | | 67 | 33 | 0 | | Adverse events: none
| Mn duration of symptom relief 25.5 mo, rng 1–51
| No influence on results of sex, age, weight, preop Duke score, duration of symptoms
Harwin 1999 ALD | Assessment (%) | Better | | Unchanged | | Worse | Further surgery: repeat arthroscopy (13.2%), mean time to procedure 3.2 yr, rng 6 mo - 12 yrs; other surgery (15.3%), mean time to osteotomy 3.5 yrs, rng 2–6 yrs, mean time to joint arthroplasty 4.2 yrs, rng 6 mo - 10 yrs
| All pts | 63 | | 21 | | 16 | Adverse events: hemarthroses (2%); deep vein thrombosis (0.5%)
| Group I | 84 | | 12 | | 4
| Group II | 68 | | 24 | | 9
| Group III | 27 | | 27 | | 47
McGinley 1999 AD | Total knee replacement in 33% of knees
Linschoten and Johnson 1997 ALD | Assessment (%) | Good | | Poor | | | Further surgery (12.5%)
| All pts, last F/U | 68 | | 32 | | | Adverse events: prolonged drainage (7.3%); spinal headache (1.9%); effusion requiring aspiration (1.9%); postop nausea requiring admission (1.95)
| 6 mo F/U | 82 | | 18
| 12 mo F/U | 77 | | 23
| 24 mo F/U | 70 | | 30
| 36 mo F/U | 68 | | 32
| 48 mo F/U | 68 | | 32
Yang and Nisonson 1995 ALD | Group | Rating | Excellent | Good | Fair | Poor | Adverse events: deep vein thrombosis (1%); superficial cellulites (2%); repeat arthroscopy (3%); total knee replacement (2%)
| All pts | % | 20 | 45 | 32 | 3
| Sx < 1 mo | | 78
| Sx > 12 mo | | 52
| Mechanical sx | | 96
| No mechanical | | 42
| Fairbank 0/I | | 69
| Fairbank II/III | | 36
| Mild degeneration | | 74
| Severe degeneration | | 39
| Outcome not correlated with age, gender, side or duration of follow-up
Aichroth 1991 ALD | % | Excellent | Good | Fair | Poor | | Further surgery in 14% after mean 46 mo
| All pts | 18 | 57 | 15 | 10
| | Satisfactory | | Unsatisfactory
| All pts | 75 | | | 25
| < 60 yo | 78 | | | 22 | p<0.008
| > 60 yo | 55 | | | 45
| Satisfactory result correlated with Ahlback preop radiographic severity (p<0.001) and with Outerbridge operative severity (p<0.001); no correlation with type or location of meniscal tear or performance of previous surgery
McLaren 1991 ALD | % | Improved | | Same | | Worse | Superficial portal drainage controlled by orally administered antibiotics (1.2%); deep vein thrombosis (0.6%); further surgery: repeat arthroscopy (4.7%), high tibial arthroscopy (4.1%), total knee replacement (3.5%)
| Pain | 78 | | 19 | | 2
| Disability | 22 | | 68 | | 10
| Ambulation limitation | 49 | | 45 | | 6
| Overall assessment | 65 | | 28 | | 7
| Disability (%) | | Pre | Post
| No restriction | | 10 | 32
| Limited recreation & sports | | 48 | 45
| Unable to work | | 25 | 12
| Restricted daily activities | | 17 | 11
Ogilvie-Harris and Fitsialos 1991 ALD | | | | % Good | mn | % | Domain | | %
| Procedure | | n | > 2 yr | F/U | Good | Pain, no/occasional | | 53
| Debridement 1 compartment | | 103 | 82 | 4.3 | 66 | Pain improved | | 86
| Debridement 2 compartments | | 135 | 58 | 3.6 | 41 | Activity limitation, no/occasional | | 59
| Abrasion | | 32 | 56 | 4.1 | 53 | Activity improved | | 83
| Meniscectomy | | 18 | 83 | 4.7 | 72 | Analgesic, no/occasional | | 79
| Meniscectomy+debridement | | 149 | 68 | 4.3 | 53 | Analgesic, improved | | 32
| Lavage only | | 4 | 25 | 3.4 | 25 | Satisfaction | | 90
| All pts | | 441 | 68 | 4.1 | 53 | Results related to disease severity
Timoney 1990 ALD | | Pre | | F/U | | p | Adverse events: postoperative effusions (6.5%); deep vein thrombosis (0.9%); infections (0%)
| Mn HSS score (sd) | 24.7 (9.2) | | 36.1 (16.3) | | <0.001 | Further Surgery: repeat arthroscopy (5.6%); total knee arthroplasty (21.3%)
| Subjective | Good | Fair | Poor
| % | 49 | 20 | 41
| Subjective results deteriorated over time.
| Subjective results significantly worse for those with symptoms > 48 mo, those with severe chondromalacia; not correlated with meniscal pathology, condition of ACL, those undergoing limited lavage and debridement
Bert and Maschka 1989 AD | Group (%) | Good-Excellent | | Fair | Poor | | Further surgery: total knee replacement (DA 25%, D 15%)
| DA | 51 | | 16 | 33
| D | 66 | | 13 | 21
Sprague 1981 ALD | Assessment (%) | Good | | Fair | Poor | | Further surgery: repeat arthroscopy (3.2%); total knee replacement (1.6%)
| All pts | 74 | | 10 | 16