# Appendix B. Listing of Excluded Studies

## Exclusion Codes

AO | arthroscopic procedure other than lavage and debridement
CS | case series
FEW | too few subjects (< 50 for arthroscopy case series)
FLA | foreign language article
FNA | foreign language, no abstract
NDE | not correct study design
NPD | no primary data
NRA | narrative review article
NRD | non-relevant disease
NRQ | non-relevant study question
RCT | randomized controlled trial

## Intervention Codes

ARTH | arthroscopy
GC | glucosamine/chondroitin
VS | viscosupplementation

### References

1 Arthroscopic lavage for osteoarthritis of the knee. Evid.-Based Healthc. Public Health 2005; 9(3):192–6. Notes: ARTH NRA
2 Arthroscopy no benefit for osteoarthritis. OR Manager 2002; 18(9):32. Notes: ARTH NPD
3 Further evidence supports use of glucosamine for knee pain. Pharm. J. 2003; 270 (7234):142. Notes: GC NPD
4 Glucosamine/chondroitin: No clear benefit in knee pain. Pharm. J. 2005; 275 (7377):657. Notes: GC NPD
5 Glucosamine delays progression of osteoarthritis in the knee joint. Pharm. J. 2002; 269(7221):594. Notes: GC NRQ RCT
6 Hyaluronan or hylans for knee osteoarthritis? Drug Ther Bull 1999; 37(9):71–2. Notes: VS NRA
7 Hyaluronic acid minimally effective for knee degenerative joint disease. Cleve Clin J Med 2004; 71(4):272. Notes: VS NPD
8 Adams ME. An analysis of clinical studies of the use of crosslinked hyaluronan, hylan, in the treatment of osteoarthritis. J Rheumatol Suppl. 1993;39:16-8. Notes: VS NRA. [pmid: 8410879].
9 Adams ME, Atkinson MH, Lussier AJ, et al. The role of viscosupplementation with hylan G-F 20 (Synvisc) in the treatment of osteoarthritis of the knee: a Canadian multicenter trial comparing hylan G-F 20 alone, hylan G-F 20 with non-steroidal anti-inflammatory drugs (NSAIDs) and NSAIDs alone. Osteoarthritis Cartilage. 1995;3(4):213-25. Notes: VS NRQ RCT. [pmid: 8689457].
10 Adams ME, Li DK, McConkey JP, et al. Evaluation of cartilage lesions by magnetic resonance imaging at 0.15 T: comparison with anatomy and concordance with arthroscopy. J Rheumatol. 1991;18(10):1573-80. Notes: ARTH AO. [pmid: 1765984].
11 Aderinto J, Cobb AG. Lateral release for patellofemoral arthritis. Arthroscopy. 2002;18(4):399-403. Notes: ARTH AO. [pmid: 11951199].
12 Aggarwal A, Sempowski IP. Hyaluronic acid injections for knee osteoarthritis. Systematic review of the literature. Can Fam Physician. 2004;50:249-56. Notes: VS NRQ. [pmid: 15000336]. [pmcid: 2214549].
13 Aglietti P, Pisaneschi A, Buzzi R, Gaudenzi A, Allegra M. Arthroscopic lateral release for patellar pain or instability. Arthroscopy. 1989;5(3):176-83. Notes: ARTH AO. [pmid: 2775389].
14 Aichroth P. Knee surgery—great strides. Trans Med Soc Lond 1990-1991; 107:61–73. Notes: ARTH NRA
15 Akermark C, Berg P, Bjorkman A, Malm P. Non-animal stabilised hyaluronic acid in the treatment of osteoarthritis of the knee: A tolerability study. Clin Drug Invest. 2002;22(3):157-66. Notes: VS NDE.
16 Akizuki S, Yasukawa Y, Takizawa T. Does arthroscopic abrasion arthroplasty promote cartilage regeneration in osteoarthritic knees with eburnation? A prospective study of high tibial osteotomy with abrasion arthroplasty versus high tibial osteotomy alone. Arthroscopy. 1997;13(1):9-17. Notes: ARTH NA. [pmid: 9043599].
17 Alekseeva LI, Arkhangel'skaia GS, Davydova AF, et al. [Long-term effects of structum administration (according to data from multicenter trial)]. Ter Arkh. 2003;75(9):82-6. Notes: GC NRQ RCT. [pmid: 14582441].
18 Alekseeva LI, Benevolenskaia LI, Nasonov EL, Chichasova NV, Kariakin AN. [Structum (chondroitin sulfate)—a new agent for the treatment of osteoarthrosis]. Ter Arkh. 1999;71(5):51-3. Notes: GC NRQ RCT. [pmid: 10399232].
19 Alekseeva LI, Chichasova NV, Benevolenskaia LI, Nasonov EL, Mendel' OI. [Combined medication ARTRA in the treatment of osteoarthrosis]. Ter Arkh. 2005;77(11):69-75. Notes: GC NRQ RCT. [pmid: 16404866].
20 Alekseeva LI, Mednikov BL, Piiavskii SA, Nasonova VA, Soldatov DG. [Pharmacoeconomic aspects of use of structum in osteoarthrosis]. Ter Arkh. 2001;73(11):90-2. Notes: GC NRQ RCT. [pmid: 11806219].
21 Allhoff P, Graf von der Schulenburg JM. [Cost-effectiveness of conservative therapy of knee joint osteoarthritis]. Z Orthop Ihre Grenzgeb. 1998;136(4):288-92. Notes: VS NRQ. [pmid: 9795428].
22 Alonge TO, Oni OO. An investigation of the frequency of co-existence of osteophytes and circumscribed full thickness articular surface defects in the knee joint. Afr J Med Med Sci. 2000;29(2):151-3. Notes: ARTH NRD. [pmid: 11379448].
23 Altman RD, Abramson S, Bruyere O et al. Commentary: osteoarthritis of the knee and glucosamine. Osteoarthritis Cartilage 2006; Epub. Notes: GC NPD
24 Altman RD, Moskowitz R. A randomized clinical trial of intra-articular sodium hyaluronate in patients with osteoarthritis of the knee: a summary. Am J Orthop. 1999;28(11 Suppl):3-4. Notes: VS NPD. [pmid: 10587244].
25 Anderson JW, Nicolosi RJ, Borzelleca JF. Glucosamine effects in humans: A review of effects on glucose metabolism, side effects, safety considerations and efficacy. Food Chem Toxicol. 2005;43(2):187-201. Notes: GC NRA. [pmid: 15621331].
26 Andersson-Molina H, Karlsson H, Rockborn P. Arthroscopic partial and total meniscectomy: A long-term follow-up study with matched controls. Arthroscopy. 2002;18(2):183-9. Notes: ARTH AO. [pmid: 11830813].
27 Aroen A, Loken S, Heir S, et al. Articular cartilage lesions in 993 consecutive knee arthroscopies. Am J Sports Med. 2004;32(1):211-5. Notes: ARTH AO. [pmid: 14754746].
28 Atamaz F, Kirazli Y, Akkoc Y. A comparative study between intra-articular hylan G-F 20 and Na-hyaluronate and physical therapy in the management of knee osteoarthritis. Annals of Rheumatic Diseases 2004. Notes: VS NRQ RCT
29 Atamaz F, Kirazli Y, Akkoc Y. A comparison of two different intra-articular hyaluronan drugs and physical therapy in the management of knee osteoarthritis.//. Rheumatol Int 2006; Epublication 1–6. Notes: VS NRQ RCT
30 Auerbach B, Melzer C. [Cross-linked hyaluronic acid in the treatment of osteoarthritis of the knee—results of a prospective randomized trial]. Zentralbl Chir. 2002;127(10):895-9. Notes: VS NRQ RCT. [pmid: 12410458].
31 Auerbach B, Melzer C. Cross-linked hyaluronic acid in the treatment of osteoarthritis of the knee - Results of a prospective randomized trial: DIE BEHANDLUNG DER GONARTHROSE MIT HOCHVERNETZTER HYALURONSAURE - ERGEBNISSE EINER PROSPEKTIVEN RANDOMISIERTEN STUDIE. Zentralbl Chir. 2002;127(10):895-9. Notes: VS NRQ RCT. [pmid: 12410458].
32 Ayral X. Arthroscopy and joint lavage. Best Pract Res Clin Rheumatol. 2005;19(3 SPEC. ISS.):401-15. Notes: ARTH NRA. [pmid: 15939366].
33 Ayral X. Arthroscopy and joint lavage. Best Pract Res Clin Rheumatol. 2005;19(3):401-15. Notes: ARTH NRA. [pmid: 15939366].
34 Ayral X, Gicquere C, Duhalde A, Boucheny D, Dougados M. Effects of video information on preoperative anxiety level and tolerability of joint lavage in knee osteoarthritis. Arthritis Rheum. 2002;47(4):380-2. Notes: ARTH NRQ RCT. [pmid: 12209483].
35 Bailey RE. Arthroscopic surgery ineffective for osteoarthritis of the knee. J Fam Pract. 2002;51(10):813. Notes: ARTH NPD. [pmid: 12401143].
36 Barrett GR, Treacy SH, Ruff CG. The effect of partial lateral meniscectomy in patients > or = 60 years. Orthopedics. 1998;21(3):251-7. Notes: ARTH AO. [pmid: 9547809].
37 Barrett JP, Siviero P. Retrospective study of outcomes in Hyalgan(registered trademark)-treated patients with osteoarthritis of the knee. Clin Drug Invest. 2002;22(2):87-97. Notes: VS NDE.
38 Baumgaertner MR, Cannon WD Jr, Vittori JM, Schmidt ES, Maurer RC. Arthroscopic debridement of the arthritic knee. Clin Orthop Relat Res 1990; (253):197–202. Notes: ARTH CS FEW
39 Bayramoglu M, Karatas M, Cetin N, Akman N, Sozay S, Dilek A. Comparison of two different viscosupplements in knee osteoarthritis — a pilot study. Clin Rheumatol. 2003;22(2):118-22. Notes: VS NRQ RCT. [pmid: 12740676].
40 Belickas J, Vitkus L, Fiodorovas M, Pocius G. [Efficiency of arthroscopic treatment in the knee osteoarthritis]. Medicina (Kaunas). 2003;39(11):1082-9. Notes: ARTH FLA CS. [pmid: 14646462].
41 Bellamy N, Bell MJ, Goldsmith CH, et al. The effectiveness of hylan G-F 20 in patients with knee osteoarthritis: an application of two sets of response criteria developed by the OARSI and one set developed by OMERACT-OARSI. Osteoarthritis Cartilage. 2005;13(2):104-10. Notes: VS NRQ RCT. [pmid: 15694571].
42 Bellamy N, Bell MJ, Goldsmith CH, et al. Evaluation of WOMAC 20, 50, 70 response criteria in patients treated with hylan G-F 20 for knee osteoarthritis. Ann Rheum Dis. 2005;64(6):881-5. Notes: VS NRQ RCT. [pmid: 15564311]. [pmcid: 1755531].
43 Benedetto KP, Rangger C. Arthroscopic partial meniscectomy: 5-year follow-up. Knee Surg Sports Traumatol Arthrosc. 1993;1(34):235-8. Notes: ARTH AO. [pmid: 8536038].
44 Bernstein H. A critical review of 100 cases: arthroscopy of the knee. IMJ Ill Med J. 1980;158(6):385-7. Notes: ARTH CS FEW. [pmid: 6108944].
45 Bernstein J, Hou S-M, Wang C-T. Therapeutic effects of hyaluronic acid on osteoarthritis of the knee [1] (multiple letters). J Bone Jt Surg Ser A. 2004;86(11):2567. Notes: VS NPD.
46 Bernstein J, Quach T. A perspective on the study of Moseley et al: questioning the value of arthroscopic knee surgery for osteoarthritis. Cleve Clin J Med 2003; 70(5):401, 405–6, 408–10. Notes: ARTH NPD
47 Bert JM, Gasser SI. Approach to the osteoarthritic knee in the aging athlete: debridement to osteotomy. Arthroscopy. 2002;18(9 Suppl 2):107-10. Notes: ARTH NRA. [pmid: 12426535].
48 Biggee BA, McAlindon T. Glucosamine for osteoarthritis: part I, review of the clinical evidence. Med Health R I. 2004;87(6):176-9. Notes: GC NRA. [pmid: 15344672].
49 Bin SI, Kim JM, Shin SJ. Radial tears of the posterior horn of the medial meniscus. Arthroscopy. 2004;20(4):373-8. Notes: ARTH AO. [pmid: 15067276].
50 Blacher RS. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. author reply 1717–9. Notes: ARTH NPD. [pmid: 12448432].
51 Blackburn WD Jr, Bernreuter WK, Rominger M, Loose LL. Arthroscopic evaluation of knee articular cartilage: a comparison with plain radiographs and magnetic resonance imaging. J Rheumatol. 1994;21(4):675-9. Notes: ARTH AO. [pmid: 8035392].
52 Blohm D, Bojsen B, Sorensen SM, Hansen TB. [Complications of transligamental knee arthroscopy. The frequency of pain and ultrasonographic changes in the inferior patellar tendon]. Ugeskr Laeger. 2001;163(49):6896-9. Notes: ARTH FLA CS. [pmid: 11766501].
53 Bolano LE, Grana WA. Isolated arthroscopic partial meniscectomy. Functional radiographic evaluation at five years. Am J Sports Med. 1993;21(3):432-7. Notes: ARTH AO. [pmid: 8346759].
54 Bonamo JJ, Kessler KJ, Noah J. Arthroscopic meniscectomy in patients over the age of 40. Am J Sports Med. 1992;20(4):422-8. discussion 428–9. Notes: ARTH AO. [pmid: 1415885].
55 Bradley JD, Heilman DK, Katz BP, Gsell P, Wallick JE, Brandt KD. Tidal irrigation as treatment for knee osteoarthritis: a sham-controlled, randomized, double-blinded evaluation. Arthritis Rheum. 2002;46(1):100-8. Notes: ARTH NA. [pmid: 11817581].
56 Braham R, Dawson B, Goodman C. The effect of glucosamine supplementation on people experiencing regular knee pain. Br J Sports Med. 2003;37(1):45-9. discussion 49. Notes: GC NRD. [pmid: 12547742]. [pmcid: 1724589].
57 Brismar BH, Wredmark T, Movin T, Leandersson J, Svensson O. Observer reliability in the arthroscopic classification of osteoarthritis of the knee. J Bone Joint Surg Br. 2002;84(1):42-7. Notes: ARTH AO. [pmid: 11837831].
58 Broderick LS, Turner DA, Renfrew DL, Schnitzer TJ, Huff JP, Harris C. Severity of articular cartilage abnormality in patients with osteoarthritis: evaluation with fast spin-echo MR vs arthroscopy. AJR Am J Roentgenol. 1994;162(1):99-103. Notes: ARTH AO. [pmid: 8273700].
59 Brower RS, Herkowitz HN, Weissman ML. Conus medullaris injury due to herniated disk and intraoperative positioning for arthroscopy. J Spinal Disord. 1995;8(2):163-5. Notes: ARTH AO. [pmid: 7606125].
60 Brown DJ, Beinat L. Safety and efcacy of an hyaluronan of 500–730 KDa and Hylan G-F 20 in clinical practice. Osteoarthritis Cartilage. 2003;11(Suppl A):118. Notes: VS NRQ RCT.
61 Bruun JV. [Placebo effect: arthroscopic lavage and debridement of knee osteoarthritis]. Ugeskr Laeger. 2002;164(50):5957-8. Notes: ARTH NPD. [pmid: 12553123].
62 Bruyere O, Honore A, Ethgen O, et al. Correlation between radiographic severity of knee osteoarthritis and future disease progression. Results from a 3-year prospective, placebo-controlled study evaluating the effect of glucosamine sulfate. Osteoarthritis Cartilage. 2003;11(1):1-5. Notes: GC NRQ RCT. [pmid: 12505481].
63 Bruyere O, Honore A, Rovati LC, et al. Radiologic features poorly predict clinical outcomes in knee osteoarthritis. Scand J Rheumatol. 2002;31(1):13-6. Notes: GC NRQ RCT. [pmid: 11922194].
64 Bruyere O, Pavelka K, Rovati LC, et al. Glucosamine sulfate reduces osteoarthritis progression in postmenopausal women with knee osteoarthritis: evidence from two 3-year studies. Menopause. 2004;11(2):138-43. Notes: GC NRQ RCT. [pmid: 15021442].
65 Burks RT, Metcalf MH, Metcalf RW. Fifteen-year follow-up of arthroscopic partial meniscectomy. Arthroscopy. 1997;13(6):673-9. Notes: ARTH AO. [pmid: 9442319].
66 Caborn D, Rush J, Lanzer W, Parenti D, Murray C. A randomized, single-blind comparison of the efficacy and tolerability of hylan G-F 20 and triamcinolone hexacetonide in patients with osteoarthritis of the knee. J Rheumatol. 2004;31(2):333-43. Notes: VS NRQ RCT. [pmid: 14760806].
67 Caborn DN. EFFICACY AND TOLERABILITY OF HYLAN G-F 20 COMPARED TO INTRA-ARTICULAR TRIAMCINOLONE HEXACETONIDE IN PATIENTS WITH OSTEOARTHRITIS OF THE KNEE IN A RANDOMIZED, EVALUATOR-BLINDED STUDY. Ann Rheum Dis (EULAR Meeting, Lisbon, Portugal, June 18–21, 2003) 2003. Notes: VS NRQ RCT
68 Campbell DG, Angel KR, Dobson PJ, Lewis PL, Tandon S. Experiences of viscosupplementation for knee osteoarthritis. Aust Fam Physician. 2004;33(10):863-4. Notes: VS NDE. [pmid: 15532168].
69 Casscells SW. What, if any, are the indications for arthroscopic debridement of the osteoarthritic knee?. Arthroscopy. 1990;6(3):169-70. Notes: ARTH NPD. [pmid: 2206178].
70 Chambers K, Schulzer M, Sobolev B. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. 2002;18(7):683-7. Notes: ARTH NPD. [pmid: 12240636].
71 Chambers KG, Schulzer M. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. author reply 1717–9. Notes: ARTH NPD. [pmid: 12448431].
72 Chang RW, Falconer J, Stulberg SD, Arnold WJ, Dyer AR. Prerandomization: an alternative to classic randomization. The effects on recruitment in a controlled trial of arthroscopy for osteoarthrosis of the knee. J Bone Joint Surg Am. 1990;72(10):1451-5. Notes: ARTH NPD. [pmid: 2254351].
73 Chang RW, Falconer J, Stulberg SD, Arnold WJ, Manheim LM, Dyer AR. A randomized, controlled trial of arthroscopic surgery versus closed-needle joint lavage for patients with osteoarthritis of the knee. Arthritis Rheum. 1993;36(3):289-96. Notes: ARTH NRQ RCT. [pmid: 8452573].
74 Chapman AB, Feller JA. Therapeutic arthroscopy for knee osteoarthritis: time to reconsider?. Med J Aust. 2003;179(4):179-80. Notes: ARTH NPD. [pmid: 12914503].
75 Chatain F, Adeleine P, Chambat P, Neyret P. A comparative study of medial versus lateral arthroscopic partial meniscectomy on stable knees: 10-year minimum follow-up. Arthroscopy. 2003;19(8):842-9. Notes: ARTH AO. [pmid: 14551546].
76 Chen J, Du L-R, Lu H-S. Metaphase effect of arthroscopic debridement for improving pain and joint function of patients with osteoarthritis. Chin J Clin Rehab. 2004;8(29):6282-3. Notes: ARTH FLA CS.
77 Chou P-H, Chen S-K, Chou Y-L, Lee S-W, Su F-C, Lin T-S. Biomechanical analysis of knee osteoarthritis patients after the treatment of glucosamine. Biomed Eng Appl Basis Commun. 2003;15(1):32-7. Notes: GC NRA.
78 Christgau S, Henrotin Y, Tanko LB, et al. Osteoarthritic patients with high cartilage turnover show increased responsiveness to the cartilage protecting effects of glucosamine sulphate. Clin Exp Rheumatol. 2004;22(1):36-42. Notes: GC NRQ RCT. [pmid: 15005002].
79 Cibere J, Kopec JA, Thorne A, et al. Randomized, double-blind, placebo-controlled glucosamine discontinuation trial in knee osteoarthritis. Arthritis Rheum. 2004;51(5):738-45. Notes: GC NRQ RCT. [pmid: 15478160].
80 Cibere J, Thorne A, Kopec JA, et al. Glucosamine sulfate and cartilage type II collagen degradation in patients with knee osteoarthritis: randomized discontinuation trial results employing biomarkers. J Rheumatol. 2005;32(5):896-902. Notes: GC NRQ RCT. [pmid: 15868627].
81 Cicuttini FM, Forbes A, Yuanyuan W, Rush G, Stuckey SL. Rate of knee cartilage loss after partial meniscectomy. J Rheumatol. 2002;29(9):1954-6. Notes: ARTH AO. [pmid: 12233892].
82 Conrozier T, Mathieu P, Schott AM, et al. Factors predicting long-term efficacy of Hylan GF-20 viscosupplementation in knee osteoarthritis. Joint Bone Spine. 2003;70(2):128-33. Notes: VS NDE. [pmid: 12713857].
83 Conrozier T, Vignon E. Die wirkung von chondroitinsulfat bei der behandlung der huftgelenksarthrose eine doppelblindstudie gegen placebo. Litera Rheumatologica. 1992;14:69-75. Notes: GC Q?.
84 Covall DJ, Wasilewski SA. Roentgenographic changes after arthroscopic meniscectomy: five-year follow-up in patients more than 45 years old. Arthroscopy. 1992;8(2):242-6. Notes: ARTH AO. [pmid: 1637440].
85 Creel AH, Losina E, Mandl LA, et al. An assessment of willingness to participate in a randomized trial of arthroscopic knee surgery in patients with osteoarthritis. Contemp Clin Trials. 2005;26(2):169-78. Notes: ARTH AO. [pmid: 15837439].
86 Crevoisier X, Munzinger U, Drobny T. Arthroscopic partial meniscectomy in patients over 70 years of age. Arthroscopy. 2001;17(7):732-6. Notes: ARTH AO. [pmid: 11536092].
87 Crolle G, D'Este E. Glucosamine sulphate for the management of arthrosis: a controlled clinical investigation. Curr Med Res Opin. 1980;7(2):104-9. Notes: GC NRQ RCT. [pmid: 7002478].
88 D'Ambrosio E, Casa B, Bompani R, Scali G, Scali M. Glucosamine sulphate: a controlled clinical investigation in arthrosis. Pharmatherapeutica. 1981;2(8):504-8. Notes: GC NRQ RCT. [pmid: 7019929].
89 Dai GF, Tang JW, Wang SJ, Liu Q, Shi DP. [Efficacy of intra-articular injection of sodium hyaluronate in post-operation treatment of the knee]. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2002;16(1):16-8. Notes: VS NDE. [pmid: 11826642].
90 Dandy DJ. Abrasion chondroplasty. Arthroscopy. 1986;2(1):51-3. Notes: ARTH NRA. [pmid: 3954839].
91 Dandy DJ. Arthroscopic debridement of the knee for osteoarthritis. J Bone Joint Surg Br. 1991;73(6):877-8. Notes: ARTH NPD. [pmid: 1955427].
92 Dawes PT, Kirlew C, Haslock I. Saline washout for knee osteoarthritis: results of a controlled study. Clin Rheumatol. 1987;6(1):61-3. Notes: ARTH NA. [pmid: 3581699].
93 Day B. The indications for arthroscopic debridement for osteoarthritis of the knee. Orthop Clin North Am. 2005;36(4):413-7. Notes: ARTH NRA. [pmid: 16164946].
94 Deal CL, Moskowitz RW. Nutraceuticals as therapeutic agents in osteoarthritis. The role of glucosamine, chondroitin sulfate, and collagen hydrolysate. Rheum Dis Clin North Am. 1999;25(2):379-95. Notes: GC NPD. [pmid: 10356424].
95 Deblock N, Mazeau P, Ceroni D, Scotto Di Luzio A, Meyer Zu Reckendorf G, Dimeglio A. [Knee arthroscopy in children]. Rev Chir Orthop Reparatrice Appar Mot. 2001;87(4):355-60. Notes: ARTH NRD. [pmid: 11431630].
96 Dervin GF, Feibel RJ, Rody K, Grabowski J. 3-Foot standing AP versus 45 degrees PA radiograph for osteoarthritis of the knee. Clin J Sport Med. 2001;11(1):10-6. Notes: ARTH NDE. [pmid: 11176140].
97 Dervin GF, Stiell IG, Wells GA, Rody K, Grabowski J. Physicians' accuracy and interrator reliability for the diagnosis of unstable meniscal tears in patients having osteoarthritis of the knee. Can J Surg. 2001;44(4):267-74. Notes: ARTH NRQ. [pmid: 11504260].
98 Dick W, Henche HR, Morscher E. [The cartilage-damage after fracture of the patella]. Arch Orthop Unfallchir. 1975;81(1):65-76. Notes: ARTH AO. [pmid: 1119980].
99 Distler J, Anguelouch A. Evidence-based practice: Review of clinical evidence on the efficacy of glucosamine and chondroitin in the treatment of osteoarthritis. J Am Acad Nurse Pract. 2006;18(10):487-93. Notes: GC NRA. [pmid: 16999714].
100 Drovanti A, Bignamini AA, Rovati AL. Therapeutic activity of oral glucosamine sulfate in osteoarthrosis: a placebo-controlled double-blind investigation. Clin Ther. 1980;3(4):260-72. Notes: GC NRD. [pmid: 7023675].
101 Eastwood DM. The failures of arthroscopic partial meniscectomy. Injury. 1985;16(9):587-90. Notes: ARTH AO. [pmid: 4086096].
102 Edelson R, Burks RT, Bloebaum RD. Short-term effects of knee washout for osteoarthritis. Am J Sports Med. 1995;23(3):345-9. Notes: ARTH NRQ RCT. [pmid: 7661265].
103 Espallargues M, Pons JM. Efficacy and safety of viscosupplementation with Hylan G-F 20 for the treatment of knee osteoarthritis: a systematic review. Int J Technol Assess Health Care. 2003;19(1):41-56. Notes: VS NRQ. [pmid: 12701938].
104 Espallargues M, Pons JMV. Efficacy and safety of viscosupplementation with Hylan G-F 20 for the treatment of knee osteoarthritis: A systematic review. Int J Technol Assess Health Care. 2003;19(1):41-56. Notes: VS NRQ. [pmid: 12701938].
105 Ewing W, Ewing JW. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. author reply 1717–9. Notes: ARTH NPD. [pmid: 12448429].
106 Felson DT, Buckwalter J. Debridement and lavage for osteoarthritis of the knee. N Engl J Med. 2002;347(2):132-3. Notes: ARTH NPD. [pmid: 12110742].
107 Felson DT, Glantz L. A surplus of positive trials: Weighing biases and reconsidering equipoise. Arthritis Res Ther. 2004;6(3):117-9. Notes: VS NPD. [pmid: 15142261]. [pmcid: 416455].
108 Felson DT, Zhang Y, Hannan MT, et al. Risk factors for incident radiographic knee osteoarthritis in the elderly: the Framingham Study. Arthritis Rheum. 1997;40(4):728-33. Notes: ARTH NDE. [pmid: 9125257].
109 Fleiss DJ. Arthroscopic treatment of osteoarthritis of the knee: a prospective randomised, placebo controlled trial. Am J Sports Med. 1997;25(5):724. author reply 724–5. Notes: ARTH NPD. [pmid: 9302485].
110 Forssblad M, Weidenhielm L. Knee arthroscopy in local versus general anaesthesia. The incidence of rearthroscopy. Knee Surg Sports Traumatol Arthrosc. 1999;7(5):323-6. Notes: ARTH AO. [pmid: 10525703].
111 Frias G, Caracuel MA, Escudero A, et al. Assessment of the efficacy of joint lavage versus joint lavage plus corticoids in patients with osteoarthritis of the knee. Curr Med Res Opin. 2004;20(6):861-7. Notes: ARTH NRQ RCT. [pmid: 15200744].
112 Friedman MJ, Berasi CC, Fox JM, Del Pizzo W, Snyder SJ, Ferkel RD. Preliminary results with abrasion arthroplasty in the osteoarthritic knee. Clin Orthop Relat Res 1984; ( 182):200–5. Notes: ARTH AO
113 Frizziero L, Govoni E, Bacchini P. Intra-articular hyaluronic acid in the treatment of osteoarthritis of the knee: clinical and morphological study. Clin Exp Rheumatol. 1998;16(4):441-9. Notes: VS NPD. [pmid: 9706425].
114 Frizziero L, Pasquali Ronchetti I. Intra-articular treatment of osteoarthritis of the knee: An arthroscopic and clinical comparison between sodium hyaluronate (500–730 kDa) and methylprednisolone acetate. J Orthop Traumatol. 2002;3(2):89-96. Notes: VS NRQ RCT.
115 Gentelle-Bonnassies S, Le Claire P, Mezieres M, Ayral X, Dougados M. Comparison of the responsiveness of symptomatic outcome measures in knee osteoarthritis. Arthritis Care Res. 2000;13(5):280-5. Notes: ARTH NRQ. [pmid: 14635296].
116 George E. Intra-articular hyaluronan treatment for osteoarthritis. Ann Rheum Dis. 1998;57(11):637-40. Notes: VS NPD. [pmid: 9924202]. [pmcid: 1752501].
117 Gibson JN, White MD, Chapman VM, Strachan RK. Arthroscopic lavage and debridement for osteoarthritis of the knee. J Bone Joint Surg Br. 1992;74(4):534-7. Notes: ARTH NRQ RCT. [pmid: 1624511].
118 Gidwani S, Fairbank A. The orthopaedic approach to managing osteoarthritis of the knee. BMJ. 2004;329(7476):1220-4. Notes: ARTH NRA. [pmid: 15550426]. [pmcid: 529367].
119 Gillespie WJ, O'Connell DL. Arthroscopic lavage of osteoarthritic knees. J Bone Joint Surg Br. 1992;74(5):787-8. author reply 788–9. Notes: ARTH NPD. [pmid: 1527140].
120 Gillquist J, Oretorp N. Arthroscopic partial meniscectomy. Technique and long-term results. Clin Orthop Relat Res 1982; (167):29–33. Notes: ARTH AO
121 Gluckert K, Blank-Schal A, Hofmann G, Kladny B, Willauschus W, Wirtz P. [Possibilities for early detection of arthroses using imaging procedures]. Orthopade. 1990;19(1):50-7. Notes: ARTH AO. [pmid: 2326075].
122 Goerres GW, Hauselmann HJ, Seifert B, Michel BA, Uebelhart D. Patients with knee osteoarthritis have lower total hip bone mineral density in the symptomatic leg than in the contralateral hip. J Clin Densitom. 2005;8(4):484-7. Notes: GC NRQ RCT. [pmid: 16311436].
123 Goldberg VM, Buckwalter JA. Hyaluronans in the treatment of osteoarthritis of the knee: evidence for disease-modifying activity. Osteoarthritis Cartilage. 2005;13(3):216-24. Notes: VS NRA. [pmid: 15727888].
124 Goldberg VM, Coutts RD. Pseudoseptic reactions to hylan viscosupplementation: diagnosis and treatment. Clin Orthop Relat Res 2004; (419):130–7. Notes: VS NRA
125 Goldman RT, Scuderi GR, Kelly MA. Arthroscopic treatment of the degenerative knee in older athletes. Clin Sports Med. 1997;16(1):51-68. Notes: ARTH NRA. [pmid: 9012561].
126 Gondring WH. Arthroscopic surgery of the knee: an early end-result study. Mil Med. 1982;147(8):627-31. Notes: ARTH NRD. [pmid: 6817205].
127 Gotzsche PC. [Placebo surgery: arthroscopic lavage and debridement of knee osteoarthritis]. Ugeskr Laeger. 2002;164(44):5151. Notes: ARTH NPD. [pmid: 12448166].
128 Graf J, Neusel E, Schneider E, Niethard FU. Intra-articular treatment with hyaluronic acid in osteoarthritis of the knee joint: a controlled clinical trial versus mucopolysaccharide polysulfuric acid ester. Clin Exp Rheumatol. 1993;11(4):367-72. Notes: VS NRQ RCT. [pmid: 8403580].
129 Groppa LG, Moshneaga M. Studying of the efficiency of the Synvisk in osteoarthrosis. Ann Rheum Dis. 2001;60(Suppl 1):230. Notes: VS NDE.
130 Gross DE, Brenner SL, Esformes I, Gross ML. Arthroscopic treatment of degenerative joint disease of the knee. Orthopedics. 1991;14(12):1317-21. Notes: ARTH CS FEW. [pmid: 1784548].
131 Guidolin DD, Ronchetti IP, Lini E, Guerra D, Frizziero L. Morphological analysis of articular cartilage biopsies from a randomized, clinical study comparing the effects of 500–730 kDa sodium hyaluronate (Hyalgan) and methylprednisolone acetate on primary osteoarthritis of the knee. Osteoarthritis Cartilage. 2001;9(4):371-81. Notes: VS NRQ RCT. [pmid: 11399102].
132 Gunther KP. Surgical approaches for osteoarthritis. Best Pract Res Clin Rheumatol. 2001;15(4):627-43. Notes: ARTH NRA. [pmid: 11567544].
133 Ha'eri GB, Wiley AM. High tibial osteotomy combined with joint debridement: a long-term study of results. Clin Orthop Relat Res 1980; (151):153–9. Notes: ARTH NA
134 Hamburger MI, Lakhanpal S, Mooar PA, Oster D. Intra-articular hyaluronans: a review of product-specific safety profiles. Semin Arthritis Rheum. 2003;32(5):296-309. Notes: VS NRA. [pmid: 12701040].
135 Hammesfahr JF, Knopf AB, Stitik T. Safety of intra-articular hyaluronates for pain associated with osteoarthritis of the knee. Am J Orthop. 2003;32(6):277-83. Notes: VS NRA. [pmid: 12834190].
136 Harrison MM, Morrell J, Hopman WM. Influence of obesity on outcome after knee arthroscopy. Arthroscopy. 2004;20(7):691-5. Notes: ARTH NRD. [pmid: 15346109].
137 Hart R, Janecek M, Siska V, Kucera B, Stipcak V. [Correlation of long-term clinical and radiological results after meniscectomies]. Acta Chir Orthop Traumatol Cech. 2005;72(5):304-7. Notes: ARTH NRD. [pmid: 16316606].
138 Hartman GP. Arthroscopic treatment of osteoarthritis of the knee: a prospective, randomized, placebo controlled trial. Am J Sports Med. 1997;25(5):724. author reply 724–5. Notes: ARTH NPD. [pmid: 9302486].
139 Hathcock JN, Shao A. Risk assessment for glucosamine and chondroitin sulfate. Regul Toxicol Pharmacol 2006. Notes: GC NRA
140 Hauselmann HJ. Nutripharmaceuticals for osteoarthritis. Best Pract Res Clin Rheumatol. 2001;15(4):595-607. Notes: GC NRQ. [pmid: 11567542].
141 Higuchi H, Kimura M, Shirakura K, Terauchi M, Takagishi K. Factors affecting long-term results after arthroscopic partial meniscectomy. Clin Orthop Relat Res 2000; (377):161–8. Notes: ARTH AO
142 Hilliquin P, Le Devic P, Menkes CJ. Comparison of the efficacy of nonsurgical synovectomy (synoviorthesis) and joint lavage in knee osteoarthritis with effusions. Rev Rhum Engl Ed. 1996;63(2):93-102. Notes: ARTH CS FEW. [pmid: 8689294].
143 Hjelle K, Solheim E, Strand T, Muri R, Brittberg M. Articular cartilage defects in 1,000 knee arthroscopies. Arthroscopy. 2002;18(7):730-4. Notes: ARTH AO. [pmid: 12209430].
144 Hochberg MC. Role of intra-articular hyaluronic acid preparations in medical management of osteoarthritis of the knee. Semin Arthritis Rheum. 2000;30(2 Suppl 1):2-10. Notes: VS NRA. [pmid: 11071576].
145 Hochberg MC, Altman RD, Brandt KD, et al. Guidelines for the medical management of osteoarthritis. Part II. Osteoarthritis of the knee. American College of Rheumatology. Arthritis Rheum. 1995;38(11):1541-6. Notes: ARTH NRA. [pmid: 7488273].
146 Horng S, Miller FG. Is placebo surgery unethical?. N Engl J Med. 2002;347(2):137-9. Notes: ARTH NPD. [pmid: 12110744].
147 Hu D-Y, Xiao P, Fu S-C, Zhong W-J, Feng W, Zhang F-H. Jingusu glucosamine hydrochloride functional food for improving knee joint function in patients with knee osteoarthritis: A human intake trial. Chin J Clin Rehab. 2005;9(18):8-9. Notes: GC NDE.
148 Huang M-H, Yang R-C, Lee C-L, Chen T-W, Wang M-C. Preliminary results of integrated therapy for patients with knee osteoarthritis. Arthritis Care Res. 2005;53(6):812-20. Notes: VS NRQ RCT.
149 Hubbard MJ. Articular debridement versus washout for degeneration of the medial femoral condyle. A five-year study. J Bone Joint Surg Br. 1996;78(2):217-9. Notes: ARTH NRQ RCT. [pmid: 8666628].
150 Hulet C, Schiltz D, Locker B, Beguin J, Vielpeau C. [Lateral meniscal cyst. Retrospective study of 105 cysts treated with arthroscopy with 5 year follow-up]. Rev Chir Orthop Reparatrice Appar Mot. 1998;84(6):531-8. Notes: ARTH AO. [pmid: 9846327].
151 Hulet C, Souquet D, Alexandre P, Locker B, Beguin J, Vielpeau C. Arthroscopic treatment of 105 lateral meniscal cysts with 5-year average follow-up. Arthroscopy. 2004;20(8):831-6. Notes: ARTH AO. [pmid: 15483544].
152 Hulet C, Souquet D, Alexandre P, Locker B, Beguin J, Vielpeau C. Arthroscopic treatment of 105 lateral meniscal cysts with 5-year average follow-up. Arthroscopy J Arthroscopic Relat Surg. 2004;20(8):831-6. Notes: ARTH AO.
153 Ike RW, Arnold WJ. Arthroscopic lavage of osteoarthritic knees. J Bone Joint Surg Br. 1992;74(5):788-9. Notes: ARTH NPD. [pmid: 1527141].
154 Ike RW, Arnold WJ, Rothschild EW, Shaw HL. Tidal irrigation versus conservative medical management in patients with osteoarthritis of the knee: a prospective randomized study. Tidal Irrigation Cooperating Group. J Rheumatol. 1992;19(5):772-9. Notes: ARTH NA. [pmid: 1613709].
155 Insall J. The Pridie debridement operation for osteoarthritis of the knee. Clin Orthop Relat Res 1974; (101):61–7. Notes: ARTH NRQ
156 Israeli A, Liebergal M, Friedman JB, Segal D. Osteoarthritis, the hazard of living longer: arthroscopy vs. conservative treatment. Isr J Med Sci. 1996;32(2):121-2. Notes: ARTH NRA. [pmid: 8631648].
157 Jackson RW. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. author reply 1717–9. Notes: ARTH NPD. [pmid: 12444192].
158 Jackson RW. Debate on the use of arthroscopic surgery for osteoarthritis of the knee. Proc (Bayl Univ Med Cent). 2003;16(1):27. discussion 28–9. Notes: ARTH NPD. [pmid: 16278719]. [pmcid: 1200806].
159 Jackson RW, Gilbert JE, Sharkey PF. Arthroscopic debridement versus arthroplasty in the osteoarthritic knee. J Arthroplasty. 1997;12(4):465-9. discussion 469–70. Notes: ARTH NPD. [pmid: 9195324].
160 Jackson RW, Rouse DW. The results of partial arthroscopic meniscectomy in patients over 40 years of age. J Bone Joint Surg Br. 1982;64(4):481-5. Notes: ARTH AO. [pmid: 6896516].
161 Jackson RW, Silver R, Marans H. Arthroscopic treatment of degenerative joint disease.//. Arthroscopy. 1986;2(2):114. Notes: ARTH CS ABSTR.
162 Jager A, Starker M, Herresthal J. [Can meniscus refixation prevent early development of arthrosis in the knee joint? Long-term results]. Zentralbl Chir. 2000;125(6):532-5. Notes: ARTH NRD. [pmid: 10919247].
163 Janecki CJ, Perry MW, Bonati AO, Bendel M. Safe parameters for laser chondroplasty of the knee. Lasers Surg Med. 1998;23(3):141-50. Notes: ARTH AO. [pmid: 9779648].
164 Jarvela T, Kannus P, Jarvinen M. Anterior cruciate ligament reconstruction in patients with or without accompanying injuries: A re-examination of subjects 5 to 9 years after reconstruction. Arthroscopy. 2001;17(8):818-25. Notes: ARTH NRD. [pmid: 11600978].
165 Jazrawi L, Sherman O, Hunt S. Arthroscopic management of osteoarthritis of the knee. J Am Acad Orthop Surg. 2003;11(4):290. Notes: ARTH NPD. [pmid: 12921088].
166 Jennings JE. Arthroscopic debridement as an alternative to total knee replacement.//. Arthroscopy. 1986;2(2):123-4. Notes: ARTH AO.
167 Jerosch J, Castro WH, Lahm A, Assheuer J. [The value of nuclear magnetic resonance tomography in diseases of the knee joint]. Z Orthop Ihre Grenzgeb. 1989;127(6):661-7. Notes: ARTH AO. [pmid: 2618146].
168 Johnson LL. Arthroscopic abrasion arthroplasty historical and pathologic perspective: present status. Arthroscopy. 1986;2(1):54-69. Notes: ARTH NRA. [pmid: 3954840].
169 Johnson LL. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. 2002;18(7):683-7. Notes: ARTH NPD. [pmid: 12240635].
170 Jones AC, Pattrick M, Doherty S, Doherty M. Intra-articular hyaluronic acid compared to intra-articular triamcinolone hexacetonide in inflammatory knee osteoarthritis. Osteoarthritis Cartilage. 1995;3(4):269-73. Notes: VS NRQ RCT. [pmid: 8689462].
171 Jordan KM, Sawyer S, Coakley P, Smith HE, Cooper C, Arden NK. The use of conventional and complementary treatments for knee osteoarthritis in the community. Rheumatology (Oxford). 2004;43(3):381-4. Notes: GC NDE. [pmid: 14623948].
172 Judet H, Judet J, Ben Hamida H. [Patelloplasty for extensive lesions of the patellar cartilage]. Chirurgie. 1992;118(9):529-32. Notes: ARTH AO. [pmid: 1344787].
173 Kahan A, Guemas E, Lieu PL. Patients with knee osteoarthritis treated by hylan G-F 20 versus usual treatments: a medico-economic, prospective, randomised large scale trial in France, efficacy and safety outcomes. Ann Rheum Dis. 2001;60(Suppl I):232. Notes: VS NRQ.
174 Kahan A, Lleu P-L, Salin L. Prospective randomised study comparing the medico-economic benets of hylan GF-20 versus conventional treatment in knee osteoarthritis [Etude prospective randomisee comparant le benece medico-economique de Synvisc a celui des traitements usuels chez des patients souffrant de gonarthrose]. Revue Du Rhumatisme. 2003;70:588-94. Notes: VS NRQ RCT.
175 Kahan A, Lleu PL, Salin L. Prospective randomized study comparing the medicoeconomic benefits of Hylan GF-20 vs. conventional treatment in knee osteoarthritis. Joint Bone Spine. 2003;70(4):276-81. Notes: VS NRQ RCT. [pmid: 12951310].
176 Kalunian KC, Moreland LW, Klashman DJ, et al. Visually-guided irrigation in patients with early knee osteoarthritis: a multicenter randomized, controlled trial. Osteoarthritis Cartilage. 2000;8(6):412-8. Notes: ARTH NRQ RCT. [pmid: 11069725].
177 Karatay S, Kiziltunc A, Yildirim K, Karanfil RC, Senel K. Effects of different hyaluronic acid products on synovial fluid levels of intercellular adhesion molecule-1 and vascular cell adhesion molecule-1 in knee osteoarthritis. Ann Clin Lab Sci. 2004;34(3):330-5. Notes: VS NRQ RCT. [pmid: 15487709].
178 Karatay S, Kiziltunc A, Yildirim K, Karanfil RC, Senel K. Effects of different hyaluronic acid products on synovial fluid NO levels in knee osteoarthritis. Clin Rheumatol. 2005;24(5):497-501. Notes: VS NRQ RCT. [pmid: 15906109].
179 Karatay S, Kiziltunc A, Yildirim K, Karanfil RC, Senel K. Effects of different hyaluronic acid products on synovial fluid NO levels in knee osteoarthritis.//. Osteoporosis International. 2005;16(3):S71-2. (Abstract #P279). Notes: VS NRQ RCT.
180 Karatay S, Yildirim K, Yildiz L, Karanfil RC, Senel K. The effect of hyaluronic acid on levels of IGF-1 and IGFBP-3 in synovial fluids of patients with knee osteoarthritis.//. Osteoporosis International. 2005;16(3):S72. (Abstract #P281). Notes: VS NRQ RCT.
181 Karatosun V, Unver B, Gocen Z, Sen A. Comparison of two hyaluronan drugs in patients with advanced osteoarthritis of the knee. A prospective, randomized, double-blind study with long term follow-up. Clin Exp Rheumatol. 2005;23(2):213-8. Notes: VS NRQ RCT. [pmid: 15895892].
182 Karatosun V, Unver B, Gocen Z, Sen A, Gunal I. Intra-articular hyaluranic acid compared with progressive knee exercises in osteoarthritis of the knee: A prospective randomized trial with long-term follow-up. Rheumatol Int. 2006;26(4):277-84. Notes: VS NRQ RCT. [pmid: 15776267].
183 Karras D, Basilakos J, Diaourta V, Kedikoglou S, Iliopoulos A. Comparative study of 2 regimens of intraarticular infusion of hyaluronan (Hyalart, Fidia, SPA) in knee osteoarthritis. J Rheumatol Suppl. 2001;28(Suppl 63):6. Notes: VS NRQ RCT.
184 Katz JN, Harris TM, Larson MG, et al. Predictors of functional outcomes after arthroscopic partial meniscectomy. J Rheumatol. 1992;19(12):1938-42. Notes: ARTH AO. [pmid: 1294743].
185 Kawabata M, Igarashi M, Mikami R, et al. Clinical evaluation of SLM-10 (sodium hyaluronate injection) in patients with osteoarthritis of the knee - a mutli-center comparative trial with Artz as control drug. Japanese Pharmacology & Therapeutics. 1993;21(1):257-83. Notes: VS NRQ RCT.
186 Kelly MA. Role of arthroscopic debridement in the arthritic knee. J Arthroplasty. 2006;21(4 Suppl 1):9-10. Notes: ARTH NRA. [pmid: 16781419].
187 Kelly MA, Kurzweil PR, Moskowitz RW. Intra-articular hyaluronans in knee osteoarthritis: rationale and practical considerations. Am J Orthop. 2004;33(2 Suppl):15-22. Notes: VS NRA. [pmid: 15005296].
188 Kemper F, Gebhardt U, Meng T, Murray C. Tolerability and short-term effectiveness of hylan G-F 20 in 4253 patients with osteoarthritis of the knee in clinical practice. Curr Med Res Opin. 2005;21(8):1261-9. Notes: VS NDE. [pmid: 16083536].
189 Kerzberg EM, Roldan EJ, Castelli G, Huberman ED. Combination of glycosaminoglycans and acetylsalicylic acid in knee osteoarthrosis. Scand J Rheumatol. 1987;16(5):377-80. Notes: GC NRQ RCT. [pmid: 3120308].
190 Kesenheimer E, Kolb M, Rosemeyer B. [Late results following meniscectomy]. Sportverletz Sportschaden. 1990;4(2):79-86. Notes: ARTH AO. [pmid: 2382205].
191 Kimura M, Shirakura K, Higuchi H, Kobayashi Y, Takagishi K. Eight- to 14-year followup of arthroscopic meniscal repair. Clin Orthop Relat Res 2004; (421):175–80. Notes: ARTH AO
192 Kirchner M, Marshall D. A double-blind randomized controlled trial comparing alternate forms of high molecular weight hyaluronan for the treatment of osteoarthritis of the knee. Osteoarthritis Cartilage. 2006;14(2):154-62. Notes: VS NRQ RCT. [pmid: 16242361].
193 Kirkley A, Rampersaud R, Griffin S, Amendola A, Litchfield R, Fowler P. Tourniquet versus no tourniquet use in routine knee arthroscopy: a prospective, double-blind, randomized clinical trial. Arthroscopy. 2000;16(2):121-6. Notes: ARTH AO. [pmid: 10705321].
194 Kirwan J. Is there a place for intra-articular hyaluronate in osteoarthritis of the knee?. Knee. 2001;8(2):93-101. Notes: VS NRA. [pmid: 11337235].
195 Kobayashi K, Matsuzaka S, Yoshida Y, Miyauchi S, Wada Y, Moriya H. The effects of intraarticularly injected sodium hyaluronate on levels of intact aggrecan and nitric oxide in the joint fluid of patients with knee osteoarthritis. Osteoarthritis Cartilage. 2004;12(7):536-42. Notes: VS NDE. [pmid: 15219568].
196 Kolarz G, Kotz R, Hochmayer I. Long-term benefits and repeated treatment cycles of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Semin Arthritis Rheum. 2003;32(5):310-9. Notes: VS NDE. [pmid: 12701041].
197 Kotz R, Kolarz G. Intra-articular hyaluronic acid: duration of effect and results of repeated treatment cycles. Am J Orthop. 1999;28(11 Suppl):5-7. Notes: VS NDE. [pmid: 10587245].
198 Kruger-Franke M, Kugler A, Trouillier HH, Reischl A, Rosemeyer B. [Clinical and radiological results after arthroscopic partial medial meniscectomy. Are there risk factors?]. Unfallchirurg. 1999;102(6):434-8. Notes: ARTH FLA CS. [pmid: 10420823].
199 Kruger-Franke M, Siebert CH, Kugler A, Trouillier HH, Rosemeyer B. Late results after arthroscopic partial medial meniscectomy. Knee Surg Sports Traumatol Arthrosc. 1999;7(2):81-4. Notes: ARTH AO. [pmid: 10223528].
200 Kruger T, Wohlrab D, Reichel H, Hein W. [The effect of arthroscopic joint debridement in advanced arthrosis of the knee joint]. Zentralbl Chir. 2000;125(6):490-3. Notes: ARTH FLA CS. [pmid: 10919240].
201 Kuzmanova S, Andreev S, Atanassov A, Batalov A, Solakov P. Arthroscopic synovectomy, debridement and tidal lavage of the knee joint in osteoarthritis - long term results. Rheumatology (Bulgaria). 2004;12(4):42-7. Notes: ARTH FLA CS.
202 Kuzmanova SI. Arthroscopic evaluation of chondropathy in knee osteoarthritis. Folia Med (Plovdiv). 2000;42(4):16-8. Notes: ARTH AO. [pmid: 15359507].
203 Kuzmanova SI. Treatment of knee osteoarthritis by arthroscopic synovectomy and debridement of cartilage lesions—late results. Folia Med (Plovdiv). 2003;45(3):66-72. Notes: ARTH AO. [pmid: 15366669].
204 Kuzmanova SI, Solakov PT, Atanassov AN, Andreev SA. Relevance between arthroscopic pathology and clinical characteristics in knee osteoarthritis. Folia Med (Plovdiv). 2000;42(4):19-22. Notes: ARTH AO. [pmid: 15359508].
205 Laskin RS, Ohnsorge JAK. The role of arthroscopy: Beneficial, placebo, or worse?. Orthopedics. 2005;28(9):975-6. Notes: ARTH NPD. [pmid: 16190075].
206 Leardini G, Franceschini M, Mattara L, Bruno R, Perbellini A. Intra-articular sodium hyaluronate (Hyalgan) in gonarthrosis. A controlled study comparing methylprednisolone acetate. Clin Trials J. 1987;24(4):341-50. Notes: VS NRQ RCT.
207 Leardini G, Mattara L, Franceschini M, Perbellini A. Intra-articular treatment of knee osteoarthritis. A comparative study between hyaluronic acid and 6-methyl prednisolone acetate. Clin Exp Rheumatol. 1991;9(4):375-81. Notes: VS NRQ RCT. [pmid: 1934686].
208 Lee PB, Kim YC, Lim YJ, et al. Comparison between high and low molecular weight hyaluronates in knee osteoarthritis patients: open-label, randomized, multicentre clinical trial. J Int Med Res. 2006;34(1):77-87. Notes: VS NRQ RCT. [pmid: 16604827].
209 Lee PB, Kim YC, Lim YJ, et al. Comparison between high and low molecular weight hyaluronates in knee osteoarthritis patients: open-label, randomized, multicentre clinical trial. J Int Med Res. 2006;34(1):77-87. Notes: VS NRQ RCT. [pmid: 16604827].
210 Leeb BF, Petera P, Neumann K. [Results of a multicenter study of chondroitin sulfate (Condrosulf) use in arthroses of the finger, knee and hip joints]. Wien Med Wochenschr. 1996;146(24):609-14. Notes: GC NDE. [pmid: 9123947].
211 Leffler CT, Philippi AF, Leffler SG, Mosure JC, Kim PD. Glucosamine, chondroitin, and manganese ascorbate for degenerative joint disease of the knee or low back: a randomized, double-blind, placebo-controlled pilot study. Mil Med. 1999;164(2):85-91. Notes: GC NRQ RCT. [pmid: 10050562].
212 Leopold SS, Redd BB, Warme WJ, Wehrle PA, Pettis PD, Shott S. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. A prospective, randomized trial. J Bone Joint Surg Am. 2003;85-A(7):1197-203. Notes: VS NRQ RCT. [pmid: 12851342].
213 Leopold SS, Warme WJ, Pettis PD, Shott S. Increased frequency of acute local reaction to intra-articular hylan GF-20 (synvisc) in patients receiving more than one course of treatment. J Bone Joint Surg Am. 2002;84-A(9):1619-23. Notes: VS NDE. [pmid: 12208919].
214 Lessard LA, Scudds RA, Amendola A, Vaz MD. The efficacy of cryotherapy following arthroscopic knee surgery. J Orthop Sports Phys Ther. 1997;26(1):14-22. Notes: ARTH NRD. [pmid: 9201637].
215 Li B-C, Zhang M, Yang Z-X. Arthroscopic surgery and individual rehabilitation training for the treatment of knee injuries in 101 cases. Chin J Clin Rehab. 2004;8(29):6284-5. Notes: ARTH FLA CS.
216 Lindblad S. Arthroscopic and synovial correlates of pain in osteoarthritis. Semin Arthritis Rheum. 1989;18(4 Suppl 2):91-3. Notes: ARTH CS FEW. [pmid: 2727708].
217 Listrat V, Ayral X, Patarnello F, et al. Arthroscopic evaluation of potential structure modifying activity of hyaluronan (Hyalgan) in osteoarthritis of the knee. Osteoarthritis Cartilage. 1997;5(3):153-60. Notes: VS NRQ RCT. [pmid: 9219678].
218 Livesley PJ. Articular debridement versus washout for degeneration of the medial femoral condyle. J Bone Joint Surg Br. 1996;78(5):854. Notes: ARTH NRA. [pmid: 8836088].
219 Lohmander LS, Dahlberg L, Ryd L, Heinegard D. Increased levels of proteoglycan fragments in knee joint fluid after injury. Arthritis Rheum. 1989;32(11):1434-42. Notes: ARTH NRQ. [pmid: 2554931].
220 Longyhore DS, Seaton TL. Glucosamine and chondroitin effective for knee osteoarthritis. J Fam Pract. 2003;52(12):919-20. Notes: GC NPD. [pmid: 14653970].
221 Lubowitz JH. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. 2002;18(8):950-1. Notes: ARTH NPD. [pmid: 12368798].
222 Lussier A, Cividino AA, McFarlane CA, Olszynski WP, Potashner WJ, De Medicis R. Viscosupplementation with hylan for the treatment of osteoarthritis: findings from clinical practice in Canada. J Rheumatol. 1996;23(9):1579-85. Notes: VS NDE. [pmid: 8877928].
223 Lyu SR, Hsu CC. Medial plicae and degeneration of the medial femoral condyle. Arthroscopy. 2006;22(1):17-26. Notes: ARTH AO. [pmid: 16399456].
224 MacIntosh DL, Welsh RP. Joint debridement—a complement to high tibial osteotomy in the treatment of degenerative arthritis of the knee. J Bone Joint Surg Am. 1977;59(8):1094-7. Notes: ARTH NA. [pmid: 591542].
225 Magee T, Shapiro M, Rodriguez J, Williams D. MR arthrography of postoperative knee: for which patients is it useful?. Radiology. 2003;229(1):159-63. Notes: ARTH AO. [pmid: 12944601].
226 Magilavy D, Polisson R, Parenti D. Re: Karlsson et al. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology (Oxford) 2003; 42(10):1262; author reply 1262–3. Notes: VS NPD
227 Magilavy DB, McPherson JM, Polisson R. Pseudoseptic reactions to Hylan viscosupplementation: diagnosis and treatment. Clin Orthop Relat Res 2004; (429):349–50; author reply 350–1. Notes: VS NPD
228 Maheu E, Ayral X, Dougados M. A hyaluronan preparation (500–730 kDa) in the treatment of osteoarthritis: a review of clinical trials with Hyalgan. Int J Clin Pract. 2002;56(10):804-13. Notes: VS NRA. [pmid: 12510956].
229 Maiotti M, Monteleone G, Tarantino U, Fasciglione GF, Marini S, Coletta M. Correlation between osteoarthritic cartilage damage and levels of proteinases and proteinase inhibitors in synovial fluid from the knee joint. Arthroscopy. 2000;16(5):522-6. Notes: ARTH AO. [pmid: 10882449].
230 Majewski M, Stoll R, Widmer H, Muller W, Friederich NF. Midterm and Long-term Results After Arthroscopic Suture Repair of Isolated, Longitudinal, Vertical Meniscal Tears in Stable Knees. Am J Sports Med 2006. Notes: ARTH AO
231 Maletius W, Messner K. Chondral damage and age depress the long-term prognosis after partial meniscectomy. A 12- to 15-year follow-up study. Knee Surg Sports Traumatol Arthrosc. 1996;3(4):211-4. Notes: ARTH AO. [pmid: 8739715].
232 Maletius W, Messner K. The effect of partial meniscectomy on the long-term prognosis of knees with localized, severe chondral damage. A twelve- to fifteen-year followup. Am J Sports Med. 1996;24(3):258-62. Notes: ARTH AO. [pmid: 8734872].
233 Maravic M, Landais P. Arthroscopy for knee osteoarthritis. Jt Bone Spine. 2003;70(6):404-6. Notes: ARTH NRA.
234 Maravic M, Landais P. Arthroscopy for knee osteoarthritis. Joint Bone Spine. 2003;70(6):404-6. Notes: ARTH NPD. [pmid: 14667547].
235 Matheson AJ, Perry CM. Glucosamine: a review of its use in the management of osteoarthritis. Drugs Aging. 2003;20(14):1041-60. Notes: GC NRA. [pmid: 14651444].
236 Matsui N, Taneda Y, Ohta H, Itoh T, Tsuboguchi S. Arthroscopic versus open synovectomy in the rheumatoid knee. Int Orthop. 1989;13(1):17-20. Notes: ARTH AO. [pmid: 2722313].
237 Matsusue Y, Thomson NL. Arthroscopic partial medial meniscectomy in patients over 40 years old: a 5- to 11-year follow-up study. Arthroscopy. 1996;12(1):39-44. Notes: ARTH AO. [pmid: 8838727].
238 Mazieres B, Loyau G, Menkes CJ, et al. [Chondroitin sulfate in the treatment of gonarthrosis and coxarthrosis. 5-months result of a multicenter double-blind controlled prospective study using placebo]. Rev Rhum Mal Osteoartic. 1992;59(78):466-72. Notes: GC NRD. [pmid: 1485136].
239 McAlindon T. Why are clinical trials of glucosamine no longer uniformly positive?. Rheum Dis Clin North Am. 2003;29(4):789-801. Notes: GC NRA. [pmid: 14603583].
240 McBride GG, Constine RM, Hofmann AA, Carson RW. Arthroscopic partial medial meniscectomy in the older patient. J Bone Joint Surg Am. 1984;66(4):547-51. Notes: ARTH AO. [pmid: 6546758].
241 McDonald C, Hantel S, Strohmeier M. A randomised, controlled study to compare the performance and safety of two sources of sodium hyaluronate given as a viscosupplement by intra-articular injection to patients with osteoarthritis of the knee. Journal of Clinical Research. 2000;3:41-50. Notes: VS NRQ RCT.
242 McGinty JB. Arthroscopic removal of loose bodies. Orthop Clin North Am. 1982;13(2):313-28. Notes: ARTH NRA. [pmid: 7088519].
243 Meredith DS, Losina E, Mahomed NN, Wright J, Katz JN. Factors predicting functional and radiographic outcomes after arthroscopic partial meniscectomy: a review of the literature. Arthroscopy. 2005;21(2):211-23. Notes: ARTH NRA. [pmid: 15689872].
244 Meredith DS, Losina E, Mahomed NN, Wright J, Katz JN. Factors predicting functional and radiographic outcomes after arthroscopic partial meniscectomy: A review of the literature. Arthroscopy J Arthroscopic Relat Surg. 2005;21(2):211-23. Notes: ARTH NRA.
245 Metcalf RW. An arthroscopic method for lateral release of subluxating or dislocating patella. Clin Orthop Relat Res 1982; (167):9–18. Notes: ARTH AO
246 Miller BS, Steadman JR, Briggs KK, Rodrigo JJ, Rodkey WG. Patient satisfaction and outcome after microfracture of the degenerative knee. J Knee Surg. 2004;17(1):13-7. Notes: ARTH AO. [pmid: 14971668].
247 Miller FG. Sham surgery: an ethical analysis. Sci Eng Ethics. 2004;10(1):157-66. Notes: ARTH NRA. [pmid: 14986782].
248 Miltner O, Schneider U, Siebert CH, Niedhart C, Niethard FU. Efficacy of intraarticular hyaluronic acid in patients with osteoarthritis—a prospective clinical trial. Osteoarthritis Cartilage. 2002;10(9):680-6. Notes: VS NRQ RCT. [pmid: 12202120].
249 Mohtadi N. Arthroscopic intervention to reduce pain and improve function in knee osteoarthritis. Clin J Sport Med. 2003;13(5):323-4. Notes: ARTH NPD. [pmid: 14579843].
250 Mohtadi N. Arthroscopic intervention to reduce pain and improve function in knee osteoarthritis. Clin J Sport Med. 2003;13(5):323-4. Notes: ARTH NPD. [pmid: 14579843].
251 Moriya H, Sasho T, Sano S, Wada Y. Arthroscopic posteromedial release for osteoarthritic knees with flexion contracture. Arthroscopy. 2004;20(10):1030-9. Notes: ARTH AO. [pmid: 15592231].
252 Morreale P, Manopulo R, Galati M, Boccanera L, Saponati G, Bocchi L. Comparison of the antiinflammatory efficacy of chondroitin sulfate and diclofenac sodium in patients with knee osteoarthritis. J Rheumatol. 1996;23(8):1385-91. Notes: GC NRQ RCT. [pmid: 8856618].
253 Morse LJ. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. author reply 1717–9. Notes: ARTH NPD. [pmid: 12448433].
254 Nahler G, Metelmann H, Sperber H. Treating osteoarthritis of the knee with a homeopathic preparation. Results of a randomized, controlled, clinical trial in comparison to hyaluronic acid. Biomedical Therapy. 1998;XVI(2):186-91. Notes: VS NRQ RCT.
255 Nahler G (von), Metelmann H, Sperber H. Treatment of gonarthrosis with Zeel comp. - Results of a randomised, controlled, comparative clinical trial with hyaluronic acid [Behandlung der Gonarthrose mit Zeel comp. - Ergebnisse einer randomisierten, kontrollierten klinischen Prufung im Vergleich zu Hyaluronsaure]. Orthopadische Praxis. 1996;32(5):354-9. Notes: VS NRQ RCT.
256 Neustadt D, Caldwell J, Bell M, Wade J, Gimbel J. Clinical effects of intraarticular injection of high molecular weight hyaluronan (Orthovisc) in osteoarthritis of the knee: a randomized, controlled, multicenter trial. J Rheumatol. 2005;32(10):1928-36. Notes: VS NRQ RCT. [pmid: 16206349].
257 Neustadt DH. Long-term efficacy and safety of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Clin Exp Rheumatol. 2003;21(3):307-11. Notes: VS NDE. [pmid: 12846048].
258 Noble J. Articular debridement versus washout for degeneration of the medial femoral condyle. J Bone Joint Surg Br. 1996;78(5):854. Notes: ARTH NRA. [pmid: 8836089].
259 Northmore-Ball MD, Dandy DJ. Long-term results of arthroscopic partial meniscectomy. Clin Orthop Relat Res 1982; (167):34–42. Notes: ARTH AO
260 Northmore-Ball MD, Dandy DJ, Jackson RW. Arthroscopic, open partial, and total meniscectomy. A comparative study. J Bone Joint Surg Br. 1983;65(4):400-4. Notes: ARTH AO. [pmid: 6874710].
261 Novaes AC, Schaiquevich P, Nasswetter G, et al. Multicenter study of hyaluronic acid obtained by biotechnology to evaluate clinical efficacy and safety in knee osteoarthritis. Int J Clin Pharmacol Res. 2005;25(1):1-7. Notes: VS NDE. [pmid: 15864872].
262 O'Hanlon D. Acute local reactions after intraarticular hylan for osteoarthritis of the knee. J Rheumatol. 1996;23(5):945-6. Notes: VS NPD. [pmid: 8724318].
263 Ozturk C, Atamaz F, Hepguler S, Argin M, Arkun R. The safety and efficacy of intraarticular hyaluronan with/without corticosteroid in knee osteoarthritis: 1-Year, single-blind, randomized study. Rheumatol Int. 2006;26(4):314-9. Notes: VS NRQ RCT. [pmid: 15703953].
264 Pagnano M, Westrich G. Successful nonoperative management of chronic osteoarthritis pain of the knee: safety and efficacy of retreatment with intra-articular hyaluronans. Osteoarthritis Cartilage. 2005;13(9):751-61. Notes: VS NRQ. [pmid: 15967686].
265 Pare DM, Schuppers HA, Tetteroo QF, Bots RA. [Partial meniscectomy via arthroscope in patients over 50 years old]. Ned Tijdschr Geneeskd. 1989;133(38):1890-2. Notes: ARTH AO. [pmid: 2797306].
266 Pasquali Ronchetti I, Guerra D, Taparelli F, et al. Morphological analysis of knee synovial membrane biopsies from a randomized controlled clinical study comparing the effects of sodium hyaluronate (Hyalgan) and methylprednisolone acetate (Depomedrol) in osteoarthritis. Rheumatology (Oxford). 2001;40(2):158-69. Notes: VS NRQ RCT. [pmid: 11257152].
267 Pavelka K, Bruyere O, Rovati LC, Olejarova M, Giacovelli G, Reginster JY. Relief in mild-to-moderate pain is not a confounder in joint space narrowing assessment of full extension knee radiographs in recent osteoarthritis structure-modifying drug trials. Osteoarthritis Cartilage. 2003;11(10):730-7. Notes: GC NRQ RCT. [pmid: 13129692].
268 Payne MW, Petrella RJ. Viscosupplementation effect on proprioception in the osteoarthritic knee. Arch Phys Med Rehabil. 2000;81(5):598-603. Notes: VS NDE. [pmid: 10807098].
269 Pearse EO, Craig DM. Partial meniscectomy in the presence of severe osteoarthritis does not hasten the symptomatic progression of osteoarthritis. Arthroscopy. 2003;19(9):963-8. Notes: ARTH AO. [pmid: 14608315].
270 Peckett WR, Butler-Manuel A. Intra-articular steroids after arthroscopy for osteoarthritis of the knee. J Bone Joint Surg Br. 2000;82(5):775-6. Notes: ARTH NPD. [pmid: 10963186].
271 Pedersen MS, Moghaddam AZ, Bak K, Koch JS. The effect of bone drilling on pain in gonarthrosis. Int Orthop. 1995;19(1):12-5. Notes: ARTH AO. [pmid: 7768653].
272 Petersson IF, Sandqvist L, Svensson B, Saxne T. Cartilage markers in synovial fluid in symptomatic knee osteoarthritis. Ann Rheum Dis. 1997;56(1):64-7. Notes: ARTH NA. [pmid: 9059144]. [pmcid: 1752260].
273 Petrella RJ. Hyaluronic acid for the treatment of knee osteoarthritis: long-term outcomes from a naturalistic primary care experience. Am J Phys Med Rehabil. 2005;84(4):278-83. quiz 284, 293. Notes: VS NDE. [pmid: 15785261].
274 Petrella RJ, Petrella M. A prospective, randomized, double-blind, placebo controlled study to evaluate the efficacy of intraarticular hyaluronic acid for osteoarthritis of the knee. J Rheumatol. 2006;33(5):951-6. Notes: VS NRQ RCT. [pmid: 16652426].
275 Pietrogrande V, Melanotte PL, D'Agnolo B, et al. Hyaluronic acid versus methylprednisolone intra-articularly injected for treatment of osteoarthritis of the knee. Curr Ther Res Clin Exp. 1991;50(5):691-701. Notes: VS NRQ RCT.
276 Poehling GG. Degenerative arthritis arthroscopy and research. Arthroscopy. 2002;18(7):683. Notes: ARTH NPD. [pmid: 12209424].
277 Puddu G, Cipolla M, Cerullo G, Scala A. Arthroscopic treatment of the flexed arthritic knee in active middle-aged patients. Knee Surg Sports Traumatol Arthrosc. 1994;2(2):73-5. Notes: ARTH AO. [pmid: 7584187].
278 Puhl W, Scharf P. Intra-articular hyaluronan treatment for osteoarthritis. Ann Rheum Dis. 1997;56(7):441. Notes: VS NRQ. [pmid: 9486013]. [pmcid: 1752402].
279 Puttick MP, Wade JP, Chalmers A, Connell DG, Rangno KK. Acute local reactions after intraarticular hylan for osteoarthritis of the knee. J Rheumatol. 1995;22(7):1311-4. Notes: VS NDE. [pmid: 7562764].
280 Qiu GX, Gao SN, Giacovelli G, Rovati L, Setnikar I. Efficacy and safety of glucosamine sulfate versus ibuprofen in patients with knee osteoarthritis. Arzneimittelforschung. 1998;48(5):469-74. Notes: GC NRQ RCT. [pmid: 9638313].
281 Qiu G-X, Weng X-S, Zhang K, et al. A multi-central randomized, controlled clinical trial of glucosamine hydrochloride / sulfate in the treatment of knee osteoarthritis. Nat Med J China. 2005;85(43):3067-70. Notes: GC NRQ RCT.
282 Rand JA. Role of arthroscopy in osteoarthritis of the knee. Arthroscopy. 1991;7(4):358-63. Notes: ARTH AO. [pmid: 1755883].
283 Rangger C, Klestil T, Gloetzer W, Kemmler G, Benedetto KP. Osteoarthritis after arthroscopic partial meniscectomy. Am J Sports Med. 1995;23(2):240-4. Notes: ARTH AO. [pmid: 7778712].
284 Ravaud P, Moulinier L, Giraudeau B, et al. Effects of joint lavage and steroid injection in patients with osteoarthritis of the knee: results of a multicenter, randomized, controlled trial. Arthritis Rheum. 1999;42(3):475-82. Notes: ARTH NRQ RCT. [pmid: 10088770].
285 Raynauld JP, Goldsmith CH, Bellamy N, et al. Effectiveness and safety of repeat courses of hylan G-F 20 in patients with knee osteoarthritis. Osteoarthritis Cartilage. 2005;13(2):111-9. Notes: VS NRQ RCT. [pmid: 15694572].
286 Raynauld JP, Torrance GW, Band PA, et al. A prospective, randomized, pragmatic, health outcomes trial evaluating the incorporation of hylan G-F 20 into the treatment paradigm for patients with knee osteoarthritis (Part 1 of 2): clinical results. Osteoarthritis Cartilage. 2002;10(7):506-17. Notes: VS NRQ RCT. [pmid: 12127830].
287 Reichelt A, Forster KK, Fischer M, Rovati LC, Setnikar I. Efficacy and safety of intramuscular glucosamine sulfate in osteoarthritis of the knee. A randomised, placebo-controlled, double-blind study. Arzneimittelforschung. 1994;44(1):75-80. Notes: GC NRQ RCT. [pmid: 8135881].
288 Reiter S, Reginster JY, Richy F, Bruyere O. Evidence-based evaluation of study results of symptomatic glucosamine therapy: EVIDENZBASIERTE BEWERTUNG DER SYMPTOMATISCHEN THERAPIE VON GLUCOSAMIN. Z Rheumatol. 2005;64(7):456-66. Notes: GC NRA. [pmid: 16244829].
289 Rejaili WA, Chueire AG, Cordeiro JA, Petean FC, Filho GC. The evaluation of Hilan GF-20 in the postoperative knee arthroscopies for arthrosis. Acta Ortopedica Brasileira. 2005;13(1):20-3. Notes: VS NDE.
290 Richards RJ, Lonergan RP. Arthroscopic surgery for relief of pain in the osteoarthritis knee. Orthopedics. 1984;7(11):1705-7. Notes: ARTH AO.
291 Rodrigo JJ, Steadman JR, Silliman JF, Fulstone HA. Improvement of full-thickness chondral defect healing in the human knee after debridement and microfracture using continuous passive motion. American Journal of Knee Surgery. 1994;7(3):109-16. Notes: ARTH AO.
292 Roman JA, Chismol J, Morales M, Donderis JL. Intra-articular treatment with hyaluronic acid. Comparative study of Hyalgan and Adant. Clin Rheumatol. 2000;19(3):204-6. Notes: VS NRQ RCT. [pmid: 10870655].
293 Roos EM, Ostenberg A, Roos H, Ekdahl C, Lohmander LS. Long-term outcome of meniscectomy: symptoms, function, and performance tests in patients with or without radiographic osteoarthritis compared to matched controls. Osteoarthritis Cartilage. 2001;9(4):316-24. Notes: ARTH AO. [pmid: 11399095].
294 Roos EM, Roos HP, Ryd L, Lohmander LS. Substantial disability 3 months after arthroscopic partial meniscectomy: A prospective study of patient-relevant outcomes. Arthroscopy. 2000;16(6):619-26. Notes: ARTH AO. [pmid: 10976123].
295 Roos H, Adalberth T, Dahlberg L, Lohmander LS. Osteoarthritis of the knee after injury to the anterior cruciate ligament or meniscus: the influence of time and age. Osteoarthritis Cartilage. 1995;3(4):261-7. Notes: ARTH AO. [pmid: 8689461].
296 Roposch A, Brunner G, Schatz KD, Kotz R, Wurnig C. [Arthroscopic menisectomy in older patients: assessing health-related quality of life]. Z Orthop Ihre Grenzgeb. 2003;141(5):563-9. Notes: ARTH FLA CS. [pmid: 14551844].
297 Rovetta G. Galactosaminoglycuronoglycan sulfate (matrix) in therapy of tibiofibular osteoarthritis of the knee. Drugs Exp Clin Res. 1991;17(1):53-7. Notes: GC NRQ RCT. [pmid: 1914837].
298 Rozkydal Z, Kura V, Ondrusek S. The arthroscopic debridement in the management of osteoarthritis of the knee joint by high tibial osteotomy. Bratisl Lek Listy. 2003;104(11):362-6. Notes: ARTH AO. [pmid: 15055722].
299 Ruffin MT 4th, Hunter RE. Arthroscopy in the geriatric patient. Acute injuries and chronic joint diseases. J Am Geriatr Soc. 1989;37(10):977-9. Notes: ARTH AO. [pmid: 2794321].
300 Ruffin MT 4th, Hunter RE. Arthroscopy in the geriatric patient. Acute injuries and chronic joint diseases. J Am Geriatr Soc. 1989;37(10):977-9. Notes: ARTH AO. [pmid: 2794321].
301 Rupp S, Seil R, Jochum P, Kohn D. Popliteal cysts in adults. Prevalence, associated intraarticular lesions, and results after arthroscopic treatment. Am J Sports Med. 2002;30(1):112-5. Notes: ARTH AO. [pmid: 11799006].
302 Salisbury RB, Nottage WM, Gardner V. The effect of alignment on results in arthroscopic debridement of the degenerative knee. Clin Orthop Relat Res 1985; (198):268–72. Notes: ARTH CS FEW
303 Salisbury RB, Nottage WM, Gardner V. The effect of alignment on results in arthroscopic debridement of the degenerative knee. Clin Orthop Relat Res 1985; (198):268–72. Notes: ARTH CS FEW
304 Santavirta S. Arthroscopy for osteoarthrosis of the knee is seldom necessary. Acta Orthop Scand. 2003;74(1):4-5. Notes: ARTH NPD. [pmid: 12635785].
305 Schneider U, Miltner O, Graf J, Thomsen M, Niethard FU. [Mechanism of action of hyaluronic acid in gonarthrosis of both knee joints in a right/left comparison. Study with dynamometry, oxygen partial pressure, temperature and Lequesne score]. Z Orthop Ihre Grenzgeb. 1997;135(4):341-7. Notes: VS NRQ RCT. [pmid: 9381772].
306 Schultz W, Gobel D. Articular cartilage regeneration of the knee joint after proximal tibial valgus osteotomy: a prospective study of different intra- and extra-articular operative techniques. Knee Surg Sports Traumatol Arthrosc. 1999;7(1):29-36. Notes: ARTH NA. [pmid: 10024960].
307 Scott WN, Clarke HD. Early knee arthritis. The role of arthroscopy: beneficial or placebo?. Orthopedics. 2003;26(9):943-4. Notes: ARTH NRA. [pmid: 14503758].
308 Setnikar I. Glucosamine for osteoarthritis. Sound science might have helped avoid confusion. BMJ. 2001;323(7319):1003-4. Notes: GC NPD. [pmid: 11700628].
309 Shichikawa K, Maeda A, Ogawa N. [Clinical evaluation of sodium hyaluronate in the treatment of osteoarthritis of the knee]. Ryumachi. 1983;23(4):280-90. Notes: GC FNA. [pmid: 6364389].
310 Shoor S. Review: Viscosupplementation for knee osteoarthritis reduces pain and improves function. Commentary Evid.-Based Med. 2006;11(1):12. Notes: VS NPD.
311 Singh S, Lee CC, Tay BK. Results of arthroscopic abrasion arthroplasty in osteoarthritis of the knee joint. Singapore Med J. 1991;32(1):34-7. Notes: ARTH AO. [pmid: 2017703].
312 Smith MD, Wetherall M, Darby T, et al. A randomized placebo-controlled trial of arthroscopic lavage versus lavage plus intra-articular corticosteroids in the management of symptomatic osteoarthritis of the knee. Rheumatology (Oxford). 2003;42(12):1477-85. Notes: ARTH AO. [pmid: 12867587].
313 Soballe K, Hansen AJ. Late results after meniscectomy in children. Injury. 1987;18(3):182-4. Notes: ARTH NRD. [pmid: 3508847].
314 Sonnino D. Glucosamine for osteoarthritis. Patients' welfare should be primary concern. BMJ. 2001;323(7319):1003. author reply 1004. Notes: GC NPD. [pmid: 11700629].
315 Spahn G, Wittig R. Short-term effects of different arthroscopic techniques in the treatment of chondral defects (shaving, coblation, and microfracturing). Eur J Trauma. 2002;28(6):349-54. Notes: ARTH AO.
316 Stuart MJ. Arthroscopic management for degenerative arthritis of the knee. Instr Course Lect. 1999;48:135-41. Notes: ARTH NRA. [pmid: 10098036].
317 Su JY, Chang JK, Lu YM, Lin SY. Arthroscopic debridement for osteoarthritis of the knee: a seven years follow-up study. Gaoxiong Yi Xue Ke Xue Za Zhi. 1995;11(12):667-72. Notes: ARTH AO. [pmid: 8551527].
318 Szachnowski P, Wei N, Arnold WJ, Cohen LM. Complications of office based arthroscopy of the knee. J Rheumatol. 1995;22(9):1722-5. Notes: ARTH AO. [pmid: 8523352].
319 Tascioglu F, Oner C. Efficacy of intra-articular sodium hyaluronate in the treatment of knee osteoarthritis. Clin Rheumatol. 2003;22(2):112-7. Notes: VS NRQ RCT. [pmid: 12740675].
320 Tekeoglu I, Adak B, Goksoy T, Tosun N. Effects of intra-articular injections of sodium hyaluronate (Orthovisc) and betamethasone on osteoarthritis of the knee. The Journal of Rheumatology & Medical Rehabilitation. 1998;9(4):220-4. Notes: VS NRQ RCT.
321 Thomas RH, Resnick D, Alazraki NP, Daniel D, Greenfield R. Compartmental evaluation of osteoarthritis of the knee. A comparative study of available diagnostic modalities. Radiology. 1975;116(3):585-94. Notes: ARTH AO. [pmid: 1153764].
322 Thompson JI, Huang YW, Zaibel R. Safety and efcacy of fermentation-derived high molecular weight sodium hyaluronate - a clinical trial in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. 2002;10(Suppl A):70-1. Notes: VS NRQ RCT.
323 Tibrewal SB. The pneumatic tourniquet in arthroscopic surgery of the knee. Int Orthop. 2001;24(6):347-9. Notes: ARTH NRD. [pmid: 11294428].
324 Toda Y. [A comparison of the efficacy of conservative therapies for obese patients with osteoarthritis of the knee]. Ryumachi. 2002;42(5):795-800. Notes: GC NDE. [pmid: 12462019].
325 Torrance GW, Raynauld JP, Walker V, et al. A prospective, randomized, pragmatic, health outcomes trial evaluating the incorporation of hylan G-F 20 into the treatment paradigm for patients with knee osteoarthritis (Part 2 of 2): economic results. Osteoarthritis Cartilage. 2002;10(7):518-27. Notes: VS NRQ RCT. [pmid: 12127831].
326 Towheed TE, Hochberg MC. A systematic review of randomized controlled trials of pharmacological therapy in osteoarthritis of the knee, with an emphasis on trial methodology. Semin Arthritis Rheum. 1997;26(5):755-70. Notes: VS NRQ. [pmid: 9144851].
327 Travers V, Norotte G, Roger B, Apoil A. [Treatment of acute pyogenic arthritis of large joints of the limbs. Apropos of 79 cases]. Rev Rhum Mal Osteoartic. 1988;55(9):655-60. Notes: ARTH NRD. [pmid: 3055244].
328 Tsai L, Wredmark T. Arthroscopic surgery of the knee in local anaesthesia. An analysis of age-related pathology. Arch Orthop Trauma Surg. 1993;112(3):136-8. Notes: ARTH AO. [pmid: 8323843].
329 Tsukamoto Y, Yamamoto M, Motegi M, et al. A double-blind trial of intra-articular higher molecular weight hyaluronic acid (NRD 101) versus lower molecular weight hyaluronic acid (Artz) in knee osteoarthritis. Rheumatology in Europe. 1995;24(Suppl):333. Notes: VS NRQ RCT.
330 Tsumura H, Ikeda S, Torisu T. Debridement and continuous irrigation for the treatment of pyogenic arthritis caused by the use of intra-articular injection in the osteoarthritic knee: indications and outcomes. J Orthop Surg (Hong Kong). 2005;13(1):52-7. Notes: ARTH CS FEW. [pmid: 15872401].
331 Vad VB, Bhat AL, Sculco TP, Wickiewicz TL. Management of knee osteoarthritis: knee lavage combined with hylan versus hylan alone. Arch Phys Med Rehabil. 2003;84(5):634-7. Notes: ARTH AO. [pmid: 12736873].
332 Vajaradul Y. Double-blind clinical evaluation of intra-articular glucosamine in outpatients with gonarthrosis. Clin Ther. 1981;3(5):336-43. Notes: GC NRQ RCT. [pmid: 7008939].
333 Vajranetra P. Clinical trial of glucosamine compounds for osteoarthrosis of knee joints. J Med Assoc Thai. 1984;67(7):409-18. Notes: GC NDE. [pmid: 6392462].
334 Van Der Linden AJ. Debridement in case of gonarthrosis. Acta Orthop Belg. 1976;42(4):367-72. Notes: ARTH NA. [pmid: 1015278].
335 Vaz AL. Double-blind clinical evaluation of the relative efficacy of ibuprofen and glucosamine sulphate in the management of osteoarthrosis of the knee in out-patients. Current Medical Research and Opinion. 1982;8(3):145-9. Notes: GC NRQ RCT. [pmid: 7128187].
336 Villani P, Bouvenot G. [Assessment of the placebo effect of symptomatic slow-acting anti-arthritics]. Presse Med. 1998;27(5):211-4. Notes: GC NRA. [pmid: 9768015].
337 Vojtassak J, Seliga J. High tibial osteotomy and debridement of the knee joint in treatment of varotic gonarthrosis. Bratisl Lek Listy. 2001;102(10):470-2. Notes: ARTH NA. [pmid: 11802295].
338 Wada M, Baba H, Imura S, Morita A, Kusaka Y. Relationship between radiographic classification and arthroscopic findings of articular cartilage lesions in osteoarthritis of the knee. Clin Exp Rheumatol. 1998;16(1):15-20. Notes: ARTH AO. [pmid: 9543556].
339 Waddell D, Rein A, Panarites C, Coleman PM, Weiss C. Cost implications of introducing an alternative treatment for patients with osteoarthritis of the knee in a managed care setting. Am J Manag Care. 2001;7(10):981-91. Notes: VS NDE. [pmid: 11669362].
340 Waddell DD. The tolerability of viscosupplementation: Low incidence and clinical management of local adverse events. Curr Med Res Opin. 2003;19(7):575-80. Notes: VS NPD. [pmid: 14626291].
341 Waddell DD, Bricker DC. Clinical experience with the effectiveness and tolerability of hylan G-F 20 in 1047 patients with osteoarthritis of the knee. J Knee Surg. 2006;19(1):19-27. Notes: VS NDE. [pmid: 16468490].
342 Waddell DD, Bricker DC. Hylan G-F 20 tolerability with repeat treatment in a large orthopedic practice: a retrospective review. J Surg Orthop Adv. 2006;15(1):53-9. Notes: VS NDE. [pmid: 16603113].
343 Waddell DD, Cefalu CA, Bricker DC. An open-label study of a second course of hylan G-F 20 for the treatment of pain associated with knee osteoarthritis. Curr Med Res Opin. 2003;19(6):499-507. Notes: VS NDE. [pmid: 14594522].
344 Waddell DD, Cefalu CA, Bricker DC. A second course of hylan G-F 20 for the treatment of osteoarthritic knee pain: 12-month patient follow-up. J Knee Surg. 2005;18(1):7-15. Notes: VS NDE. [pmid: 15742592].
345 Waddell JP. Arthroscopic debridement of the knee. Can J Surg. 1991;34(6):532. Notes: ARTH NPD. [pmid: 1747824].
346 Wallace DA, Carr AJ, Loach AB, Wilson-MacDonald J. Day case arthroscopy under local anaesthesia. Ann R Coll Surg Engl. 1994;76(5):330-1. Notes: ARTH NRD. [pmid: 7979076]. [pmcid: 2502407].
347 Wallny T, Brackmann HH, Semper H, et al. Intra-articular hyaluronic acid in the treatment of haemophilic arthropathy of the knee. Clinical, radiological and sonographical assessment. Haemophilia. 2000;6(5):566-70. Notes: VS NRD. [pmid: 11012703].
348 Wang DW, Cai X, Liu YJ, Wang ZG, Gao L. [Meniscus injury in osteoarthritis of knee joints: under arthroscopy]. Zhonghua Yi Xue Za Zhi. 2005;85(34):2425-7. Notes: ARTH FLA CS. [pmid: 16321252].
349 Wei N, Delauter SK, Erlichman MS. The holmium YAG laser in office based arthroscopy of the knee: comparison with standard interventional instruments in patients with arthritis. J Rheumatol. 1997;24(9):1806-8. Notes: ARTH AO. [pmid: 9292807].
350 Wein CR, Houpt JB, McMillan R, Russell AHK. Open trial of Glucosamine Hydrochloride (Arthroid) in the Treatment of Pain of Osteoarthritis of the Knee. Unpublished 1998. Notes: GC NDE
351 Weiss C, Tillero W, Balazs L. The treatment of osteoarthritis of the knee with hylan G-F20 in orthopedic practice. Proceedings of the 4th Congress of the OsteoArthritis Research Society International (OARSI), September 16–19, 1999, Vienna, Austria 1999. Notes: VS NDE
352 Wouters E, Bassett FH 3rd, Hardaker WT Jr, Garrett WE Jr. An algorithm for arthroscopy in the over-50 age group. Am J Sports Med. 1992;20(2):141-5. Notes: ARTH NRD. [pmid: 1558240].
353 Wray NP, Moseley JB, O'Malley K. Arthroscopic treatment of osteoarthritis of the knee. J Bone Joint Surg Am. 2003;85-A(2):381. Notes: ARTH NPD. [pmid: 12571321].
354 Wray NR, Moseley JB, O'Malley K. Arthroscopic treatment of osteoarthritis of the knee [1]. J Bone Jt Surg Ser A. 2003;85(2):381. Notes: ARTH NPD.
355 Zenk JL, Helmer TR, Kuskowski MA. The effects of milk protein concentrate on the symptoms of osteoarthritis in adults: an exploratory, randomized, double-blind, placebo-controlled trial. Current Therapeutic Research. 2002;63(7):430-42. Notes: GC NRD.