# Appendix A. Exact Search Strings

- MEDLINE^®^ (through March 29, 2007)
- EMBASE (through March 16, 2006)
- Cochrane Controlled Trials Register (through November 27, 2006)

EMBASE was updated with abbreviated searches through November 27, 2006.

Database Search Strategies:

- “osteoarthritis, knee”[MeSH] OR
- “osteoarthritis”[MeSH] AND (knee(tw) OR knees(tw)) OR
- osteoarthritis*(tw) AND (knee(tw) OR knees(tw)) OR
- “osteoarthritis”[MeSH] AND patellofemoral (tw)

AND

- human (limit/tag)

Results of the above search were limited to citations also identified by the Cochrane Handbook search strategy for controlled trials (Alderson et al. 2004):

- randomized controlled trial [pt] OR
- controlled clinical trial [pt] OR
- randomized controlled trials [mh] OR
- random allocation [mh] OR
- double-blind method [mh] OR
- single-blind method [mh] OR
- clinical trial [pt] OR
- clinical trials [mh] OR
- “clinical trial” [tw] OR
- ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR
- placebos [mh] OR
- placebo* [tw] OR
- random* [tw] OR
- research design [mh:noexp] OR
- comparative study [mh] OR
- evaluation studies [mh] OR
- follow-up studies [mh] OR
- prospective studies [mh] OR
- control* [tw] OR
- prospectiv* [tw] OR
- volunteer* [tw])

For glucosamine and chondroitin, the results of the above search were combined with the results of a search using:

- “Glucosamine”[MeSH] OR “Chondroitin”[MeSH] OR
- glucosamine(tw) OR
- acetylglucosamine(tw) OR
- “n-acetylglucosamine”(tw) OR
- “n-acetyl-d-glucosamine”(tw) OR
- chondroitin(tw)

For hyaluronic acid, the results of the first search above were combined with the results of a search using:

- “Hyaluronic Acid”[MeSH] OR
- “sodium hyaluronate”(tw) OR
- hyaluronan(tw) OR
- hyaluronic(tw) OR
- hylan(tw) OR
- hyalgan(tw) OR
- synvisc(tw) OR
- orthovisc(tw) OR
- euflexxa(tw) OR
- supartz(tw) OR
- nuflexxa(tw) OR
- viscosupplement*

For arthroscopy, the results of the first search above were combined with the results of a search using:

- “Arthroscopy”[MeSH] OR
- arthroscopy(tw) OR
- arthroscopic(tw) OR
- arthroscope(tw)) OR
- lavage(tw) OR
- debridement(tw)