# Appendixes

Appendix A. Exact Search Strings

Appendix B. Listing of Excluded Studies

Appendix C. Evidence Tables

Appendix D. Technical Expert Panel (TEP) and Reviewers