# Figure

Figure 1. Literature Flow.

## Figure 1. Literature Flow

[image]