# References

1 Palella FJ Jr, Delaney KM, Moorman AC, et al. Declining morbidity and mortality among patients with advanced human immunodeficiency virus infection. HIV Outpatient Study Investigators. N Engl J Med. 1998;338(13):853-60. [pmid: 9516219].
2 DHHS Panel on Antiretroviral Guidelines for Adults and Adolescents. Guidelines for the Use of Antiretroviral Agents in HIV-infected adults and adolescents. [Web Page]. Available at http://aidsinfo.nih.gov/ContentFiles/AdultandAdolescentGL.pdf. (Accessed 11 October 2006).
3 Larder BA, Darby G, Richman DD. HIV with reduced sensitivity to zidovudine (AZT) isolated during prolonged therapy. Science. 1989;243(4899):1731-4. [pmid: 2467383].
4 Erice A, Mayers DL, Strike DG, et al. Brief report: primary infection with zidovudine-resistant human immunodeficiency virus type 1. N Engl J Med. 1993;328(16):1163-5. [pmid: 8455683].
5 Johnson VA, Brun-Vezinet F, Clotet B, et al. Update of the drug resistance mutations in HIV-1: Fall 2006. Top HIV Med. 2006;14(3):125-30. [pmid: 16946457].
6 Hirsch MS, Brun-Vezinet F, Clotet B, et al. Antiretroviral drug resistance testing in adults infected with human immunodeficiency virus type 1: 2003 recommendations of an International AIDS Society-USA Panel. Clin Infect Dis. 2003;37(1):113-28. [pmid: 12830416].
7 Clavel F, Hance AJ. HIV drug resistance. N Engl J Med. 2004;350(10):1023-35. [pmid: 14999114].
8 Deeks SG, Barbour JD, Grant RM, Martin JN. Duration and predictors of CD4 T-cell gains in patients who continue combination therapy despite detectable plasma viremia. AIDS. 2002;16(2):201-7. [pmid: 11807304].
9 Tobin NH, Learn GH, Holte SE, et al. Evidence that low-level viremias during effective highly active antiretroviral therapy result from two processes: expression of archival virus and replication of virus. J Virol. 2005;79(15):9625-34. [pmid: 16014925]. [pmcid: 1181593].
10 Hammer SM, Saag MS, Schechter M, et al. Treatment for adult HIV infection: 2006 recommendations of the International AIDS Society—USA panel. Top HIV Med. 2006;14(3):827-43. [pmid: 17016878].
11 Zolopa AR, Lazzeroni LC, Rinehart A, et al. Accuracy, precision, and consistency of expert HIV type 1 genotype interpretation: an international comparison (The GUESS Study). Clin Infect Dis. 2005;41(1):92-9. [pmid: 15937768].
12 Flys T, Nissley DV, Claasen CW, et al. Sensitive drug-resistance assays reveal long-term persistence of HIV-1 variants with the K103N nevirapine (NVP) resistance mutation in some women and infants after the administration of single-dose NVP: HIVNET 012. J Infect Dis. 2005;192(1):24-9. [pmid: 15942890].
13 Johnson JA, Li JF, Morris L, et al. Emergence of drug-resistant HIV-1 after intrapartum administration of single-dose nevirapine is substantially underestimated. J Infect Dis. 2005;192(1):16-23. [pmid: 15942889].
14 Paredes R, Mocroft A, Kirk O, et al. Predictors of virological success and ensuing failure in HIV-positive patients starting highly active antiretroviral therapy in Europe: results from the EuroSIDA study. Arch Intern Med. 2000;160(8):1123-32. [pmid: 10789605].
15 Richman DD, Morton SC, Wrin T, et al. The prevalence of antiretroviral drug resistance in the United States. AIDS. 2004;18:1393-401. [pmid: 15199315].
16 Mocroft A, Ledergerber B, Viard JP, et al. Time to virological failure of 3 classes of antiretrovirals after initiation of highly active antiretroviral therapy: results from the EuroSIDA study group. J Infect Dis. 2004;190(11):1947-56. [pmid: 15529259].
17 Sabin CA, Hill T, Lampe F, et al. Treatment exhaustion of highly active antiretroviral therapy (HAART) among individuals infected with HIV in the United Kingdom: multicentre cohort study. BMJ. 2005;330(7493):695. [pmid: 15749728]. [pmcid: 555628].
18 Vella S, Palmisano L. The global status of resistance to antiretroviral drugs. Clin Infect Dis. 2005;41(Suppl 4):S239-46. [pmid: 16032559].
19 Sachdeva N, Sehgal S, Arora SK. Frequency of Drug-Resistant Variants of HIV-1 Coexistent With Wild-Type in Treatment-Naive Patients of India. MedGenMed. 2005;7(3):68. [pmid: 16369294].
20 Balakrishnan P, Kumarasamy N, Kantor R, et al. HIV type 1 genotypic variation in an antiretroviral treatment-naive population in southern India. AIDS Res Hum Retroviruses. 2005;21(4):301-5. [pmid: 15943572].
21 Deshpande A, Recordon-Pinson P, Deshmukh R, et al. Molecular characterization of HIV type 1 isolates from untreated patients of Mumbai (Bombay), India, and detection of rare resistance mutations. AIDS Res Hum Retroviruses. 2004;20(9):1032-5. [pmid: 15585093].
22 Park SW, Kim HB, Choi YJ, Kim NJ, Oh MD, Choe KW. Genotypic resistance of antiretroviral drugs among drug-naive HIV type 1 patients with the background of long-term access-easy zidovudine therapy. AIDS Res Hum Retroviruses. 2003;19(11):1039-43. [pmid: 14686324].
23 Lan NT, Recordon-Pinson P, Hung PV, et al. HIV type 1 isolates from 200 untreated individuals in Ho Chi Minh City (Vietnam): ANRS 1257 Study. Large predominance of CRF01_AE and presence of major resistance mutations to antiretroviral drugs. AIDS Res Hum Retroviruses. 2003;19(10):925-8. [pmid: 14601592].
24 Ly N, Recordon-Pinson P, Phoung V, et al. Characterization of mutations in HIV type 1 isolates from 144 Cambodian recently infected patients and pregnant women naive to antiretroviral drugs. AIDS Res Hum Retroviruses. 2005;21(11):971-6. [pmid: 16386116].
25 Kijak GH, Pampuro SE, Avila MM, et al. Resistance profiles to antiretroviral drugs in HIV-1 drug-naive patients in Argentina. Antivir Ther. 2001;6(1):71-7. [pmid: 11417764].
26 Brindeiro RM, Diaz RS, Sabino EC, et al. Brazilian Network for HIV Drug Resistance Surveillance (HIV-BResNet): a survey of chronically infected individuals. AIDS. 2003;17(7):1063-9. [pmid: 12700457].
27 Dumans AT, Soares MA, Pieniazek D, et al. Prevalence of protease and reverse transcriptase drug resistance mutations over time in drug-naive human immunodeficiency virus type 1-positive individuals in Rio de Janeiro, Brazil. Antimicrob Agents Chemother. 2002;46(9):3075-9. [pmid: 12183276]. [pmcid: 127402].
28 Pires IL, Soares MA, Speranza FA, et al. Prevalence of human immunodeficiency virus drug resistance mutations and subtypes in drug-naive, infected individuals in the army health service of Rio de Janeiro, Brazil. J Clin Microbiol. 2004;42(1):426-30. [pmid: 14715797]. [pmcid: 321664].
29 Lama JR, Suarez L, Laguna A, et al. A model program linking HIV resistance surveillance and sentinel HIV serosurveillance in Peru. Antivir Ther. 2005;10:S138.
30 Delgado E, Leon-Ponte M, Villahermosa ML, et al. Analysis of HIV type 1 protease and reverse transcriptase sequences from Venezuela for drug resistance-associated mutations and subtype classification: a UNAIDS study. AIDS Res Hum Retroviruses. 2001;17(8):753-8. [pmid: 11429115].
31 Andrade-Villanueva J, Amador-Lara F, Ortiz-Macias X, De La Mora- Jimenez E. Primary HIV drug resistance in a referral HIV unit in Mexico. 42nd Annual Meeting of IDSA. 2004.
32 Fuentes-Romero L, Rodriguez-Diaz RA, Viveros-Rogel M, et al. Genotypic HIV-drug resistance among newly diagnosed, never treated persons in Mexico. 2004:S111.
33 Toni T, Masquelier B, Bonard D, et al. Primary HIV-1 drug resistance in Abidjan (Cote d'Ivoire): a genotypic and phenotypic study. AIDS. 2002;16(3):488-91. [pmid: 11834964].
34 Harrigan PR, Montaner JS, Wegner SA, et al. World-wide variation in HIV-1 phenotypic susceptibility in untreated individuals: biologically relevant values for resistance testing. AIDS. 2001;15(13):1671-7. [pmid: 11546942].
35 Kinomoto M, Appiah-Opong R, Brandful JAM et al. HIV-1 proteases from drug-naive West African patients are differentially less susceptible to protease inhibitors. Clin Infect Dis 2005.
36 Handema R, Terunuma H, Kasolo F, et al. Prevalence of drug-resistance-associated mutations in antiretroviral drug-naive Zambians infected with subtype C HIV-1. AIDS Res Hum Retroviruses. 2003;19(2):151-60. [pmid: 12643279].
37 Pillay C, Bredell H, McIntyre J, Gray G, Morris L. HIV-1 subtype C reverse transcriptase sequences from drug-naive pregnant women in South Africa. AIDS Res Hum Retroviruses. 2002;18(8):605-10. [pmid: 12036490].
38 Bussmann H, Novitsky V, Wester W, et al. HIV-1 subtype C drug-resistance background among ARV-naive adults in Botswana. Antivir Chem Chemother. 2005;16(2):103-15. [pmid: 15889533].
39 Konings FA, Zhong P, Agwara M, et al. Protease mutations in HIV-1 non-B strains infecting drug-naive villagers in Cameroon. AIDS Res Hum Retroviruses. 2004;20(1):105-9. [pmid: 15008125].
40 Vergne L, Peeters M, Mpoudi-Ngole E, et al. Genetic diversity of protease and reverse transcriptase sequences in non-subtype-B human immunodeficiency virus type 1 strains: evidence of many minor drug resistance mutations in treatment-naive patients. J Clin Microbiol. 2000;38(11):3919-25. [pmid: 11060045]. [pmcid: 87518].
41 Petch LA, Hoffman IF, Jere CS, et al. Genotypic analysis of the protease and reverse transcriptase of HIV type 1 subtype C isolates from antiretroviral drug-naive adults in Malawi. AIDS Res Hum Retroviruses. 2005;21(9):799-805. [pmid: 16218804].
42 Laurent C, Diakhate N, Gueye NFN, Toure MA, Sow PS, et al. The Senegalese government's highly active antiretroviral therapy initiative: an 18-month follow-up study. AIDS. 2002;16:1363-70. [pmid: 12131213].
43 Vergne L, Malonga-Mouellet G, Mistoul I, et al. Resistance to antiretroviral treatment in Gabon: need for implementation of guidelines on antiretroviral therapy use and HIV-1 drug resistance monitoring in developing countries. J Acquir Immune Defic Syndr. 2002;29(2):165-8. [pmid: 11832686].
44 Toni TD, Recordon-Pinson P, Minga A, et al. Presence of key drug resistance mutations in isolates from untreated patients of Abidjan, Cote d'Ivoire: ANRS 1257 study. AIDS Res Hum Retroviruses. 2003;19(8):713-7. [pmid: 14506786].
45 Bessong P, Mphahlele J, Obi L, Rekosh D, Hammerskjold ML. Baseline Genetic Drug Resistance Analysis of South African HIV-1 Subtype C Proteases. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
46 Doualla-Bell F, Avalos A, Gaolathe T, et al. Frequency and patterns of specific PR mutations in Botswana subtype C patients who failed a nelfinavir-containing HAART regimen. Antivir Ther. 2005;10:S150.
47 Eshleman SH, Mracna M, Guay LA, et al. Selection and fading of resistance mutations in women and infants receiving nevirapine to prevent HIV-1 vertical transmission (HIVNET 012). AIDS. 2001;15(15):1951-7. [pmid: 11600822].
48 Eshleman SH, Guay LA, Wang J, et al. Distinct patterns of emergence and fading of K103N and Y181C in women with subtype A vs. D after single-dose nevirapine: HIVNET 012. J Acquir Immune Defic Syndr. 2005;40(1):24-9. [pmid: 16123677].
49 Eshleman SH, Hoover DR, Chen S, et al. Nevirapine (NVP) resistance in women with HIV-1 subtype C, compared with subtypes A and D, after the administration of single-dose NVP. J Infect Dis. 2005;192(1):30-6. [pmid: 15942891].
50 McIntyre JA, Martison N, Gray GE, et al. Single dose nevirapine combined with a short course of combivir for prevention of mother to child transmission of HIV-1 can significantly decrease the subsequent development of maternal and infant resistant virus. Antivir Ther. 2005;10:S4.
51 Palmer S, Boltz V, Maldarelli F, et al. Short-course combivir (CBV) single dose nevirapine reduces but does not climinate the selection of nevirapine-resistant HIV-1: improved detection by allele-specific PCR. Antivir Ther. 2005;10:S5.
52 Martinson N, Morris L, Gray G, et al. HIV resistance and transmission following single-dose nevirapine in a PMTCT cohort. 11th Conference on Retroviruses and Opportunistic Infection. Foundation for Retrovirology and Human Health, 2004.
53 Morris L, Martinson N, Pillay C, et al. Persistance of nevirapine resistance mutations 6 months following single dose nevirapine. 15th International AIDS Conference. International AIDS Society, 2004.
54 Loubser S, Sherman G, Chezzi C et al. Characterization of nevirapine resistance mutations using RT-PCR and DNA sequencing methods in a mother-infant cohort following single dose nevirapine. 9. 2004:S145.
55 Kantor R, Lee E, Johnston E, et al. Rapid flux in non-nucleoside reverse transcriptase mutations among subtype C HIV-1-infected women after single dose nevirapine. Antivir Ther. 2003;8:S85.
56 Morris L, Pillay C, Chezzi C, et al. Low frequency of the V106M mutation among HIV-1 subtype C-infected pregnant women exposed to nevirapine. AIDS. 2003;17(11):1698-700. [pmid: 12853755].
57 Gordon M, Graham N, Bland R et al. Surveillance of resistance in KZN South Africa, including mother-infant pairs 6 weeks after single-dose NVP. 9. 2004:S80.
58 Loubser S, Balfe P, Sherman G, Hammer S, Kuhn L, Morris L. Decay of K103N mutants in cellular DNA and plasma RNA after single-dose nevirapine to reduce mother-to-child HIV transmission. AIDS. 2006;20(7):995-1002. [pmid: 16603851].
59 Toni TD, Masquelier B, Lazaro E, et al. Characterization of nevirapine (NVP) resistance mutations and HIV type 1 subtype in women from Abidjan (Cote d'Ivoire) after NVP single-dose prophylaxis of HIV type 1 mother-to-child transmission. AIDS Res Hum Retroviruses. 2005;21(12):1031-4. [pmid: 16379606].
60 Troyer R, Lalonde M, Kyeyune F, et al. High frequency of nevirapine resistant mutations in the HIV quasi species found in NVP-treated participants of an MTCT Ugandan cohort. Antivir Ther. 2005;10:S14.
61 Eshleman SH, Guay LA, Mwatha A, et al. Characterization of nevirapine resistance mutations in women with subtype A vs. D HIV-1 6–8 weeks after single-dose nevirapine (HIVNET 012). J Acquir Immune Defic Syndr. 2004;35(2):126-30. [pmid: 14722443].
62 Martinson NA, Morris L, Gray G et al. Selection and Persistence of Viral Resistance in HIV-Infected Children After Exposure to Single-Dose Nevirapine. J Acquir Immune Defic Syndr 2006.
63 Sutthent R, Arworn D, Kaoriangudom S, et al. HIV-1 drug resistance in Thailand: before and after National Access to Antiretroviral Program. J Clin Virol. 2005;34(4):272-6. [pmid: 16286051].
64 Jourdain G, Ngo-Giang-Huong N, Le Coeur S, et al. Intrapartum exposure to nevirapine and subsequent maternal responses to nevirapine-based antiretroviral therapy. N Engl J Med. 2004;351(3):229-40. [pmid: 15247339].
65 Perez H, Vignoles M, Laufer N et al. Post-partum Interruption of a Triple Drug Regimen Containing Nevirapine for Prevention of Mother-to-child HIV Transmission Does Not Select the K103N Mutation. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
66 Giuliano M, Galluzzo C, Germinario E et al. Selection of Resistance Mutations in Children Receiving Prophylaxis with Lamivudine or Nevirapine for the Prevention of Postnatal Transmission of HIV. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
67 Ekpini RA, Nkengasong JN, Sibailly T, et al. Changes in plasma HIV-1-RNA viral load and CD4 cell counts, and lack of zidovudine resistance among pregnant women receiving short-course zidovudine. AIDS. 2002;16(4):625-30. [pmid: 11873007].
68 Chaix ML, Dabis F, Ekouevi D et al. Addition of 3 Days of ZDV+3TC Postpartum to a Short Course of ZDV+3TC and Single-dose NVP Provides Low Rate of VNP Resistance Mutations and High Efficacy in Preventing Peri-partum HIV-1 Transmission: ANRS DITRAME Plus, Abidjan, Cote d'Ivoire. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
69 Chaix ML, Ekouevi DK, Peytavin G, et al. Persistance of nevirapine-resistant virus and pharmacokinetic analysis in women who received intrapartum NVP associated to a short course of zidovudine (ZDV) to prevent perinatal HIV-1 transmission: the Ditrame Plus ANRS 1201/02 Study, Abidjan, Cote d'Ivoire. 9. 2004:S176.
70 Lyons F, Coughlan S, Byrne C et al. Emergence of Genotypic Resistance in HIV-1-infected Pregnant Women Taking HAART to Reduce Mother-to-child Transmission of HIV-1. 11th Conference on Retroviruses and Opportunistic Infections. 2004.
71 Shapiro RL, Thior I, Gilbert PB, et al. Maternal single-dose nevirapine versus placebo as part of an antiretroviral strategy to prevent mother-to-child HIV transmission in Botswana. AIDS. 2006;20(9):1281-8. [pmid: 16816557].
72 Lockman S, Shapiro RL, Smeaton LM, et al. Response to antiretroviral therapy after a single, peripartum dose of nevirapine. N Engl J Med. 2007;356(2):135-47. [pmid: 17215531].
73 Chi B, Sinkala M, Levy J et al. Maternal immune response and clinical outcomes on NNRTI-based antiretroviral therapy (ART) following exposure to single-dose nevirapine (NVP) for prevention of mother-to-child HIV transmission (PMTCT). International AIDS Conference. Toronto, Cananda: 2006.
74 Johnson JA, Li J-F, Morris L, et al. Resistance mutations arise in the majority of women provided single-dose NVP and appear to differ in emergence and persistence. Antivir Ther. 2005;10:S13.
75 Eshleman SH, Hoover DR, Hudelson SE, et al. Development of nevirapine resistance in infants is reduced by use of infant-only single-dose nevirapine plus zidovudine postexposure prophylaxis for the prevention of mother-to-child transmission of HIV-1. J Infect Dis. 2006;193(4):479-81. [pmid: 16425125].
76 Chaix ML, Msellati P, Rouet F et al. Efficacy of Highly Active Antiviral Therapy and Rate of Genotypic HIV-1 Drug Resistant Strains among HIV-infected Children Receiving Treatment at the Agence Nationale de Recherche sur le SIDA, in Abidjan, Cote d'Ivoire, Africa. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
77 Spacek LA, Shihab HM, Kamya MR, et al. Response to antiretroviral therapy in HIV-infected patients attending a public, urban clinic in Kampala, Uganda. Clin Infect Dis. 2006;42(2):252-9. [pmid: 16355337].
78 Oyugi JH, Byakika-Tusiime J, Ragland K, et al. Treatment interruptions predict resistance in HIV-positive individuals purchasing fixed-dose combination antiretroviral therapy in Kampala, Uganda. AIDS. 2007;21:1-7. [pmid: 17148962].
79 Adje-Toure C, Celestin B, Hanson D, et al. Prevalence of genotypic and phenotypic HIV-1 drug-resistant strains among patients who have rebound in viral load while receiving antiretroviral therapy in the UNAIDS-Drug Access Initiative in Abidjan, Cote d'Ivoire. AIDS. 2003;17(Suppl 3):S23-9. [pmid: 14565606].
80 Mullen J, Leech S, O'Shea S, et al. Antiretroviral drug resistance among HIV-1 infected children failing treatment. J Med Virol. 2002;68(3):299-304. [pmid: 12226814].
81 Coffin JM. HIV population dynamics in vivo: implications for genetic variation, pathogenesis, and therapy. Science. 1995;267(5197):483-9. [pmid: 7824947].
82 Havlir DV, Eastman S, Gamst A, Richman DD. Nevirapine-resistant human immunodeficiency virus: kinetics of replication and estimated prevalence in untreated patients. J Virol. 1996;70(11):7894-9. [pmid: 8892912]. [pmcid: 190861].
83 Bangsberg DR, Acosta EP, Gupta R, et al. Adherence-resistance relationships for protease and non-nucleoside reverse transcriptase inhibitors explained by virological fitness. AIDS. 2006;20(2):223-31. [pmid: 16511415].
84 Deeks SG, Wrin T, Liegler T, et al. Virologic and immunologic consequences of discontinuing combination antiretroviral-drug therapy in HIV-infected patients with detectable viremia. N Engl J Med. 2001;344(7):472-80. [pmid: 11172188].
85 Wong JK, Hezareh M, Gunthard HF, et al. Recovery of replication-competent HIV despite prolonged suppression of plasma viremia. Science. 1997;278(5341):1291-5. [pmid: 9360926].
86 Finzi D, Hermankova M, Pierson T, et al. Identification of a reservoir for HIV-1 in patients on highly active antiretroviral therapy. Science. 1997;278(5341):1295-300. [pmid: 9360927].
87 Benson CA, Vaida F, Havlir DV, et al. A Randomized Trial of Treatment Interruption before Optimized Antiretroviral Therapy for Persons with Drug-Resistant HIV: 48-Week Virologic Results of ACTG A5086. J Infect Dis. 2006;194(9):1309-18. [pmid: 17041858].
88 Hammer SM. Single-dose nevirapine and drug resistance: the more you look, the more you find. J Infect Dis. 2005;192(1):1-3. [pmid: 15942885].
89 Barbour JD, Wrin T, Grant RM, et al. Evolution of phenotypic drug susceptibility and viral replication capacity during long-term virologic failure of protease inhibitor therapy in human immunodeficiency virus-infected adults. J Virol. 2002;76(21):11104-12. [pmid: 12368352]. [pmcid: 136622].
90 De Luca A, Cozzi-Lepri A, Perno CF, et al. Variability in the interpretation of transmitted genotypic HIV-1 drug resistance and prediction of virological outcomes of the initial HAART by distinct systems. Antivir Ther. 2004;9(5):743-52. [pmid: 15535412].
91 Johnson VA. Nucleoside reverse transcriptase inhibitors and resistance of human immunodeficiency virus type 1. J Infect Dis. 1995;171(Suppl 2):S140-9. [pmid: 7861019].
92 Hertogs K, Kemp S, Bloor S, et al. Patterns of cross-resistance among protease inhibitors in over 1500 clinical HIV-1 isolates. Comparison of genotypic and phenotypic resistance profiles. Antiviral Ther. 1998;3(Suppl 1):49-50.
93 Petropoulos CJ, Parkin NT, Limoli KL, et al. A novel phenotypic drug susceptibility assay for human immunodeficiency virus type 1. Antimicrob Agents Chemother. 2000;44(4):920-8. [pmid: 10722492]. [pmcid: 89793].
94 Shafer RW, Schapiro JM. Drug resistance and antiretroviral drug development. J Antimicrob Chemother. 2005;55(6):817-20. [pmid: 15845781]. [pmcid: 2547472].
95 Weinstock H, Respess R, Heneine W, et al. Prevalence of mutations associated with reduced antiretroviral drug susceptibility among human immunodeficiency virus type 1 seroconverters in the United States, 1993-1998. J Infect Dis. 2000;182(1):330-3. [pmid: 10882618].
96 Wensing AM, van de Vijver DA, Angarano G, et al. Prevalence of drug-resistant HIV-1 variants in untreated individuals in Europe: implications for clinical management. J Infect Dis. 2005;192(6):958-66. [pmid: 16107947].
97 Wensing AMJ, Van de Vijver DAMC, Asjo B, et al. Analysis from more than 1600 newly diagnosed patients with HIV from 17 European countries shows that 10% of the patients carry primary drug resistance: the CATCH-Study. in: Program and abstracts. 2nd In ternational AIDS Society Conference on Pathogenesis and Treatment. International AIDS Society.
98 Bowles E, Wensing A, van de Vijver D, Schuurman R, Boucher C, WATCH investigators. WATCH: Worldwide Analysis of Resistance Transmission over Time of Chronically and Acute Infected HIV-1 infected persons. 2006.
99 Pieniazek D, Rayfield M, Hu DJ, et al. HIV-2 protease sequences of subtypes A and B harbor multiple mutations associated with protease inhibitor resistance in HIV-1. AIDS. 2004;18(3):495-502. [pmid: 15090802].
100 Stuyver L, Wyseur A, Rombout A, et al. Line probe assay for rapid detection of drug-selected mutations in the human immunodeficiency virus type 1 reverse transcriptase gene. Antimicrob Agents Chemother. 1997;41(2):284-91. [pmid: 9021181]. [pmcid: 163703].
101 Lehman DA, Chung MH, Richardson BA, John-Stewart GC, Overbaugh J. Patterns of viral load and drug resistance in breast milk and blood from women treated with single-dose nevirapine to reduce mother-to-child transmission of HIV-1. Antivir Ther. 2005;10:S6.
102 Resistant HIV in breast milk. AIDS Patient Care STDS 2003; 17(4):201.
103 Kantor R, DeLong A, Shafer RW, et al. Selection of resistance following first-time andti-retroviral regimens among HIV-1 subtypes. Antivir Ther. 2005;10:S146.
104 Flys TS, Donnell D, Mwatha A, et al. Persistence of K103N-Containing HIV-1 Variants after Single-Dose Nevirapine for Prevention of HIV-1 Mother-to-Child Transmission. J Infect Dis. 2007;195(5):711-5. [pmid: 17262714].
105 Cunningham CK, Chaix ML, Rekacewicz C, et al. Development of resistance mutations in women receiving standard antiretroviral therapy who received intrapartum nevirapine to prevent perinatal human immunodeficiency virus type 1 transmission: a substudy of pediatric AIDS clinical trials group protocol 316. J Infect Dis. 2002;186(2):181-8. [pmid: 12134253].
106 World Health Organization. Antiretroviral drugs for treating pregnant women and preventing HIV infection in infants: towards universal access: recommendations for a public health approach. 2006 editionWHO Press, 2006.
107 Coovadia A, Marais B, Abrams E et al. Virologic Response to NNRTI Treatment among Women Who Took Single-dose Nevirapine 18 to 36 months earlier. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
108 Eure C, Bakai P, McConnell M et al. Effectiveness of repeat single-dose nevirapine in subsequent pregnancies among Ugandan women. 13th Conference on Retroviruses and Opportunistic Infections. Denver, Colorado: 2006.
109 Martinson N, Ekouevi D, Gray G et al. Effectiveness of single-dose nevirapine in consecutive pregnancies in Soweto and Abidjan. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
110 Flys TS, Chen S, Jones D et al. Analysis of K103N-containing HIV-1 Variants in Women with HIV-1 Subtypes A, C, and D after Single-dose Nevirapine Using a Sensitive and Quantitative Point Mutation Assay. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
111 Domingo E, Baranowski E, Ruiz-Jarabo CM, Martin-Hernandez AM, Saiz JC, Escarmis C. Quasispecies structure and persistence of RNA viruses. Emerg Infect Dis. 1998;4(4):521-7. [pmid: 9866728].
112 Bangsberg DR, Kroetz DL, Deeks SG. Adherence-resistance relationships to combination HIV antiretroviral therapy. 2007.
113 Vergne L, Kane CT, Laurent C, et al. Low rate of genotypic HIV-1 drug-resistant strains in the Senegalese government initiative of access to antiretroviral therapy. AIDS. 2003;17(Suppl 3):S31-8. [pmid: 14565607].