# Executive Summary

## Introduction

The clinical management of HIV infection has greatly improved through the use of highly active antiretroviral therapy (HAART),^1^ which comprises the following classes of agents: nucleoside or nucleotide reverse transcriptase inhibitors (NRTIs), non-nucleoside reverse transcriptase inhibitors (NNRTIs), protease inhibitors (PIs), and fusion inhibitors. The clinical effectiveness of these therapies is mediated by treatment-induced reduction of HIV viral replication as demonstrated by measurements of the amount of HIV RNA in the blood (the plasma viral load). However, successful suppression of HIV replication is influenced by the intrinsic potency of the prescribed regimen, patient adherence to treatment, and pre-existing or emerging resistance to antiretroviral (ARV) agents.^2^

Resistance of HIV to ARV agents was first reported within 2 years of the approval of the NRTI zidovudine (ZDV) for the treatment of persons with late-stage HIV infection.^3^ Subsequently, transmission of a ZDV-resistant isolate was first reported in 1992.^4^ The development of ARV resistance has since been reported with all other commercially available ARV agents within all classes.^5^ Because drug resistance mutations often decrease the activity of many ARV agents within an individual class, the emergence of a single major resistance mutation can have important effects on a patient's response to multiple ARV agents.^5^–^7^ Thus, assessment of the proportion of HIV-infected persons who have developed ARV resistance and characterization of the causes and factors associated with resistance development are critical steps in modifying treatment guidelines and regimens to improve their effectiveness.

The emergence of mutations that confer resistance to ARV therapy is an expected consequence of the high rates of viral replication and the inherent error rate of the reverse transcription of single-stranded RNA viruses such as HIV.^7^ Among individuals who are receiving ARV, the likelihood of developing resistance is increased if optimal drug doses (that is, doses that reduce viral load to less than approximately 50 to 200 HIV RNA copies/mL)^8,^ ^9^ are not maintained, either through poor adherence or the prescription of a suboptimal regimen (such as the administration of single-dose neviripine [SD-NVP] to pregnant women infected with HIV for prevention of mother to child transmission [pMTCT] ). A second method of acquiring a resistant strain of the virus is via transmission of a resistant strain to a treatment-naïve person.

The development of ARV resistance can be determined by the use of either genotypic or phenotypic assays.^2,^ ^10^ Genotypic testing assesses the viral genome for mutations in the genes that encode reverse transcriptase or protease; phenotypic testing assesses the ability of the virus to replicate in the presence of the drug in question. Interpretation of genotypic assays depends upon assessment of the probability that a given mutation pattern confers resistance to one or several specific ARV drugs.^6^ Despite agreement regarding the significance of most individual mutations, experts continue to show some disagreement in the interpretation of genotypes.^11^ Although the interpretation of phenotypic HIV resistance tests is straightforward compared with that of genotypic tests, these assays are considerably more expensive, and their clinical utility is less well validated by clinical trials.^6^

Both assays can be applied to virus obtained from any tissue, but for routine clinical purposes, the assays are used to characterize HIV in plasma specimens. Both tests are relatively insensitive for the detection of resistant viral variants (or quasispecies) that account for less than 20 percent of the circulating virus population in plasma, and neither assay detects intracellular, archival virus (virus that remains in a dormant state).^6^ In contrast, by the use of specific genetic probes and allele-specific real-time polymerase chain reaction (PCR, a method used to amplify genetic material for sequencing or assaying), it is possible to detect viral subpopulations that constitute as little as 0.1 to 0.2 percent of circulating virus in plasma.^12,^ ^13^

HIV gene mutations may be classified as primary or secondary. Primary mutations alter the binding of a drug to its target, resulting in increased amounts of medications necessary to inhibit the target enzyme. Secondary mutations increase the level of resistance by improving the fitness of the virus carrying the primary mutations. Often, secondary mutations have little or no effect on the level of resistance in the absence of primary mutations. Other genetic variations, called polymorphisms, are found frequently in untreated HIV positive populations in the developing world. A polymorphism is a form of genetic variation (specifically a discontinuous variation), which occurs in an animal species in which distinct forms exist together in the same population. (The human blood groups are examples of a polymorphism.) The interpretation of these naturally-occurring polymorphisms, usually found in HIV protease, is difficult. Generally, these variations are not primary mutations which confer significant resistance, but may be secondary mutations which could contribute to resistance or improve the fitness of resistant virus.

Virologic treatment failure, and hence the emergence of ARV resistance, was particularly common in persons who received mono- or dual- drug therapy prior to the use of HAART regimens that included NNRTIs and PIs.^14^ As a consequence of prior inadequate therapy, the relatively poor potency of early HAART regimens, and poor adherence related to the complexity of dosing regimens and the frequency of adverse side effects, it was estimated that 50 percent of infected individuals who were receiving care for HIV infection in the United States (U.S.) in 1999 had some evidence of ARV resistance.^15^ More recently, despite the development of new ARV agents with unique profiles of resistance mutations and regimens with less complex dosing and fewer side effects,^2,^ ^10^ ARV resistance remains a serious problem for HIV-infected patients.^16,^ ^17^ Furthermore, up to 10 percent of newly infected, treatment-naive individuals in the developed world are found to be infected by relatively fit, resistant virus that persists in the absence of treatment.^18^

The purpose of this report was to review and synthesize the literature that describes the overall prevalence as well as factors in the development of ARV resistance throughout the developing world, particularly studies that address resistance in non-clade B viral strains (a clade is a group of organisms believed to originate from a single common ancestor; non-clade B viruses are that subtype of virus that is more common outside of North America and Western Europe). According to International AIDS Society recommendations,^6^ evaluating susceptibility patterns among non-clade B persons should be a high priority because these viruses are by far the most prevalent world-wide. The first part of this report focuses on treatment-naïve populations in developing regions. The second focuses on the consequences of pMTCT regimens. Studies of pMTCT are particularly noteworthy, because they represent one of the most common uses of non-suppressive regimens of HAART. The third section focuses on adherence and its association with resistance.

## Methods

This project was suggested by the Fogarty International Center (Fogarty) at the National Institutes of Health (NIH) on behalf of several institutes at NIH, with the aim of guiding the research agenda on the development of ARV resistance in developing countries by identifying critical gaps in the published research. A secondary aim was to identify issues for clinicians rolling out HIV medications in the developing world.

A technical expert panel (TEP) assisted in refining the methodology as well as the following key questions, which guided the review:

1 What is the prevalence of resistance? Does the prevalence of resistance differ between adults and children? Between men and women? Between groups with differing modes of transmission?
2 What are the factors associated with the development of resistance? How do the factors differ among varying population groups?
3 What are effective strategies to prevent or reduce the development of resistance in different population groups (e.g., post pMTCT intervention; people receiving ARV)?
4 What is the likely impact of low-level or partial resistance on subsequent therapy? What is the impact on response to subsequent pMTCT interventions?

The literature search was initiated in November, 2005 with an electronic search of PubMed® and Embase as well as the Cochrane Controlled Clinical Trials Register Database and the Cochrane Database of Reviews of Effectiveness (DARE) for reports on resistance to ARV. Search terms included the generic and trade names of every available NNTRI, NRTI, Protease Inhibitor (PI), and fusion inhibitor (FI), regardless of U.S. Food and Drug Administration (FDA) approval status. Additional sources of evidence included the Stanford University HIV Drug Resistance Database; reports of WATCH: Worldwide Analysis of Resistance Transmission over Time of Chronically and Acute Infected HIV-1 infected persons; a recent presentation on pMTCT by a technical expert; a recent overview;^18^ and various conference proceedings. The Stanford HIV RT and Protease Sequence Database is an on-line relational database that catalogs sequence variation in HIV reverse transcriptase (RT) and protease enzymes, the molecular targets of anti-HIV therapy. One part of the database provides copies of or links to published papers, meeting abstracts, and GenBank entries that have not yet been published as a paper or abstract.

Articles that did not report original research, that reported the results of animal or in vitro studies, that reported on case studies of fewer than 20 individuals, or that reported data already reported in another article were excluded (although we summarized the findings of several recent overviews). Although geographical setting was not initially considered a criterion for exclusion from the review, the TEP - after the first round of screening - recommended including only studies set in developing countries. The TEP also suggested that we focus on key questions one and two.

Results for treatment-naïve populations and pregnant women and their children were examined separately. Because of study heterogeneity, pooling was not possible; thus, the data were summarized qualitatively. Differences by region, population group, and HIV viral clade are described. Resistance studies that reported adherence data are also summarized separately.

## Results

Of 1,122 titles identified by the literature search, only 117 met the inclusion criteria.

### Review of Published Overviews on Incidence and Prevalence

Several overviews on the incidence and prevalence of ARV resistance were identified; however, most provided data only on the developed world. The WATCH study found that the rate of resistance (to any drug) was 5.5 percent in Africa, 7.4 percent in East Asia, 5.7 percent in Southeast Asia, and 6.4 percent in Latin America, lower than in North America (11.4 percent) and Europe (10.6 percent). The patterns of resistance world-wide appear to reflect trends in use of ARV medications: In developed areas, where medications have been more widely available, rates of resistance to NNRTI range from three to four percent, whereas, in developing regions with limited resources, the rates of resistance are much lower.

### Resistance Among Treatment-naïve Persons in Developing Countries

We analyzed resistance prevalence separately for the following areas: India, other developing nations in Asia, Latin America, and the continent of Africa.

Studies of ARV resistance among treatment-naïve patients in India were rare. Published data were found from only three studies;^19^–^21^ these studies varied in their results. A study of 60 persons in Northern India found that at least 80 percent of patients had resistance to ZDV.^19^ A study of 50 persons in South India showed that fourteen percent were resistant to NNRTIs, 6 percent were resistant to NRTIs, and 20 percent were PI resistant although all had mutations that conferred partial resistance.^20^ A study of 128 persons in Mumbai found that only two were resistant to NRTIs.^21^

Only three studies were found that reported on rates of resistance in other developing regions of Asia.^22^–^24^ None reported NNRTI resistance. NRTI resistance ranged from four to seven percent; primary resistance to PIs ranged from two to three percent.

In Latin America, eight studies identified rates of ARV resistance. Resistance to NRTIs ranged from 2 to 14 percent among treatment-naïve groups.^25^–^32^ Reported rates of resistance to NNRTIs were low, ranging from zero to two percent. In a handful of studies that included Brazilian and Argentine populations, rates of secondary PI mutations were high, presumably among persons with HIV clade B. No studies assessed HIV resistance in Central America.

In sub-Saharan Africa, 14 studies identified rates of ARV resistance among the treatment naive. NNRTI resistance rates ranged from 0 percent to 7.7 percent, and were associated with infection with most HIV clades.^33^–^46^ NRTI resistance rates ranged from zero percent to eight percent for all clades. Primary PI mutations were rare (less than three percent) among Africans; however, there were high levels of secondary PI mutations in most studies.

### Resistance among Pregnant Women and Children in Developing Countries

Thirty-one studies were identified that addressed the emergence of ARV resistance in women in developing countries subsequent to the administration of therapy to prevent pMTCT of HIV-1 infection. These studies were highly heterogeneous with respect to study design and outcomes.

Studies of resistance following SD-NVP. Seven studies assessed the effects of SD-NVP on postpartum NNRTI resistance; resistance rates ranged from 9 to 69 percent.^47^–^53^ Seven studies that assessed the effect of SD-NVP among women infected with clade C on resistance reported rates of prevalence that varied from over 70 percent at 2 weeks postpartum to less than nine percent at six weeks postpartum; these findings suggest a decline in resistance over time.^49,^ ^52,^ ^54^–^58^ In studies of women infected with other clades,^48,^ ^49,^ ^59^–^61^ resistance ranged from 16 percent^60^ to 36 percent.^49^

Complex patterns of NNRTI resistance were observed following the receipt of SD-NVP. The most common mutations that resulted in amino acid changes were K103N and Y181C. Y181C was the most commonly detected resistance mutation in plasma collected 2 weeks postpartum from women infected by HIV-1 clade C.^54,^ ^55^ In contrast, the K103N resistance mutation was most common at later time points in persons infected by clade C and at all times in persons infected by other HIV-1 clades. Among clade-C women, from one study in South Africa, V106/A/M was the most common amino acid change.^54^ One report found that the rates of detection of K103N, Y181C, and Y188C were significantly higher in women infected by HIV-1 clade C than by HIV-1 clades A or D.^49^

Several longitudinal analyses support the observation of declines in NNRTI resistance with time and suggest that these declines may differ by clade.^47,^ ^48,^ ^52,^ ^55,^ ^62^

Studies of resistance following other pMTCT regimens. Ten studies from the developing world were identified that studied the emergence of ARV resistance following other pMTCT regimens, including adding ARV therapy before or after SD-NVP. Two studies were done in Thailand,^63,^ ^64^ one was conducted in Argentina,^65^ and the other eight studies were done in Sub-Saharan Africa.^50,^ ^60,^ ^66^–^71^ A randomized comparison of outcomes in women receiving pMTCT with SD-NVP alone with those of women who received SD-NVP followed by a “tail” of 3 or 7 days of ZDV and 3TC found that the prevalence of NNRTI resistance in these three groups was 57 percent, 13 percent, and 9 percent, respectively.^46^

In one study, women who received either intrapartum SD-NVP or placebo following daily ZDV during their third trimester were put on three-drug ARV postpartum. Intrapartum SD- NVP was statistically associated with NRTI and NNRTI mutations at both 3 and 6 months. In another study, in which women were put on three-drug ARV after intrapartum SD-NVP or placebo, resistance was strongly associated with intrapartum SD-NVP among women who started ARV within 6 months postpartum, but not among women who started ARV 6 months or more postpartum,^72^ suggesting development of resistance may be associated with shorter interval between receipt of SD-NVP and initiation of full ARV.

Several trials suggest that when infants receive SD-NVP at birth in the background of ZDV, maternal SD-NVP does not provide any additional protection from HIV transmission.^71,^ ^73^

Effect of test sensitivity. The rates of NNRTI resistance are consistently greater when more-sensitive assays are employed.^51,^ ^58,^ ^65,^ ^74^ For example, the prevalence detected with RT-PCR (real time polymerase chain reaction) of plasma RNA can be up to double that detected with standard testing at six or seven weeks post-partum.

### Resistance in HIV-positive Infants Born To Mothers Receiving pMTCT

Children are often born HIV infected despite pMTCT. Resistant viruses can be transmitted or can emerge independently in either mother or infant. Eight studies^50^ ^54^ ^55^ ^57^ ^60^ ^62^ ^69^ ^75^ evaluated the emergence of ARV resistance in children born to mothers in sub-Saharan Africa who received pMTCT. Most studies examined the impact of SD-NVP. In most studies, infected infants were tested for resistance at 6 or 7 weeks of age. Rates of NNRTI resistance among untreated HIV-positive infants of mothers receiving only SD-NVP ranged from 36 percent to 50 percent. One study found that detectable resistance fades over time in infants exposed to SD-NVP.^62^

Several studies compared the effects of multiple drugs on infant drug resistance. One study compared resistance rates among mother-infant pairs infected with various HIV clades who were treated with ZDV (N = 48) or SD-NVP (N = 61).^60^ The HIV transmission rates were similar in the two groups: 16.4 percent and 16.7 percent respectively. Using the oligonucleotide DNA ligation assay for resistance at 6 weeks postpartum, the researchers found NNRTI mutations in half the infected pairs who received SD-NVP. No ZDV mutations were present in pairs treated with that drug. Resistance data for mothers and infants were not presented separately. In a second study, researchers gave mothers ZDV (300mg) twice daily starting at 36 weeks gestation in addition to oral SD-NVP at onset of labor.^69^ Only 23 percent of their HIV-positive children were resistant to NNRTIs at 4 weeks postpartum. In a third study, researchers compared resistance among infants who received SD-NVP with those who received SD-NVP plus either 4 or 7 days of ZDV + 3TC after birth.^50^ Infected infants who received the additional 7-day ZDV + 3TC showed no resistance at 6 weeks, compared to 78 percent of those who received SD-NVP only. Finally, a fourth study recently compared resistance rates in infants who received various combinations of intrapartum SD-NVP, SD-NVP (2 mg/kg) immediately postpartum, and ZDV (4 mg/kg) twice daily for one week.^75^ At 6 to 8 weeks, the rate of resistance was much lower (27 percent) in the infants who received the postpartum SD-NVP and ZDV without the intrapartum SD-NVP. The study also showed that when infants received ZDV, the transmission rate did not differ between mothers who received SD-NVP and those who did not. When infants received SD-NVP plus one week of ZDV and the mother received SD-NVP, transmission was 17 percent and resistance was observed in 74 percent; when infants received SD-NVP plus 1 week of ZDV and mothers did not receive SD-NVP, transmission was 17 percent but resistance was only 27 percent. Data from the MASHI trial also suggest that when the infant receives SD-NVP at birth in the background of ZDV, maternal SD NVP does not provide any additional protection.^51^ ^65^ ^72^ ^74^

Predictors of Resistance. Several studies evaluated predictors of ARV resistance among persons receiving SD-NVP. A multivariate analysis demonstrated an increased risk of resistance detectable by standard genotyping assays in persons infected with clade C (compared with clade A or clade D) or with increased viral load at delivery, but not with increased age or number of births.^49^ One additional study supports the predictive value of increased viral load.^54^ Plasma HIV RNA level^64^ has also been shown to be predictive of resistance, and increased duration of prepartum use of ZDV+3TC for pMTCT was associated with an increased maternal prevalence of the M184V resistance mutation.^76^

### Adherence and Resistance

Adherence to HIV treatment has long been associated with treatment outcomes. Most studies in the developed world have found evidence that at very low levels of adherence, there is insufficient selective pressure for mutations to evolve. At high levels of adherence, viral replication, and thus, viral evolution, should cease.

Few studies could be identified that were designed to assess the effect of health services delivery factors or medication adherence on the development of resistance in patients in developing countries. Three studies assessed the impact of treatment interruptions on ARV resistance in the developing world: two were conducted in Kampala, Uganda.^77^ ^78^ In the first study, 137 patients received a three-drug regimen; most included NVP (77 percent) or efavirenz (14 percent). At a median of 38 weeks, 91 of the 137 patients had undetectable viral loads. Of the 137 patients, 32 experienced an unplanned treatment interruption of more than 4 days. In multivariate analysis, this treatment interruption was statistically associated with resistance, as was being treatment-naïve at study entry. Of 36 patients for whom genetic data were available, 26 were resistant to NNRTIs; the most common mutation was K103N. NRTI resistance was measured in 23 patients, attributable to the M184V/I mutation. A second study found that among 95 participants, the 33 without treatment interruption had no drug resistance, compared to eight of the 62 participants who did interrupt treatment. A third African study that assessed the relationship between adherence and the presence of resistance in an Ivory Coast AIDS clinic found no association between missed treatments and resistance.^79^ Finally, one additional study from the UK studied black African children with non-clade B virus.^80^ All children whose adherence was classified as good or intermediate had resistance, compared with five of eight children whose adherence was poor. Of critical importance, unlike many studies conducted in the developed world, the latter studies were not initially designed or powered to assess the relationship between adherence and resistance.

## Discussion

This review had several limitations. The primary limitation was the quality and quantity of available studies. Other limitations related specifically to how the studies were conducted, including heterogeneity with respect to study design, the lack of inclusion of participants infected with more unusual viral clades, and failure to stratify treatment-naïve patients.

The paucity of quality research examining and characterizing ARV resistance among populations of developing nations leads us to make the following recommendations:

Given the relatively high prevalence of HIV infection in India, more research on resistance patterns should be a priority for that nation.

Few published studies stratified resistance data by host characteristics such as mode of HIV transmission, risk factors, or gender, although these data were collected in most of the studies. Studies with larger sample sizes would allow meaningful analyses of patterns among groups, for example MSM, heterosexuals, prostitutes, and IDUs.

Data on HIV clades other than A, B, C, D, or the recombinant types were too scarce to permit reliable conclusions. In future studies, rare HIV clades should be over-sampled in order to provide statistically meaningful data.

Evidence provided by longitudinal analyses suggests that the prevalence of NNRTI resistance may vary with the time elapsed since treatment among women taking SD-NVP for pMTCT. In one study, fading of variants with Y181C was reported in women infected with clade A but not clade D; thus, Y181C may have less effect on viral fitness of clade D than on A. This observation warrants further investigation in future studies. The impact of the Y181C mutation should also be studied in clades other than D and A.

Research should be conducted regarding the need for maternal SD-NVP when an infant receives NVP at birth or when the mother receives ZDV regularly before birth.

Further research is needed on the optimum time to begin ongoing postpartum ARV treatment.

Where possible, future research projects on adherence should measure resistance in addition to routinely collected data such as CD4 count and viral load. In addition, observational studies of HIV treatment in developing regions should ask questions about factors that affect patient access to medication.

More studies should use ultrasensitive assays to determine not just the occurrence of resistance but also the quantitative frequency of resistance mutations and types of mutations over time, which may be important in determining response to therapy. Where possible, patients, including mothers and their HIV positive children, should be followed over several years to assess the extent and quantity of archiving of resistance mutations in cells.

Resistance surveillance programs should be established throughout the developing world. Data should be reported and analyzed in a consistent and timely fashion. It is expected that the Global HIV Drug Resistance Surveillance Network (HIV Resnet), recently launched by the World Health Organization, should fulfill this function.