# Results

## Description of the Studies

The literature search identified 1,122 titles. These references were culled from electronic library searches (510), conference proceedings (259), the Stanford University HIV Drug Resistance Database (141), and reference mining from retrieved articles (186). One content expert sent us an overview presentation on pMTCT. Twenty-five articles or abstracts were suggested by reviewers of a draft version of this report.

Of the 1,122 titles identified as possibly relevant to our topics, 63 were excluded at abstract review and two could not be found, leaving 1,057 to be retrieved. Of these 1,057 articles, screening resulted in exclusion of 649 articles: 252 due to study design (background articles, commentary, individual case reports, case series of fewer than 20 persons); 220 focused on basic science or cell lines; 129 were excluded because the topic was not ARV resistance; and 48 reported on obsolete therapies. The remaining 408 were then reviewed with a second screening form.

Of these 408 articles, 291 were excluded from further analysis: 242 either because they were not within developing regions or not on pregnant women or children; 32 had no prevalence or incidence data; 14 reported the same data already reported in other included studies (duplicate data); and three had insufficient statistics. Data were abstracted from the remaining 117 studies (Figure 1 Literature Flow).

## Published Overviews

We found several overviews on the incidence and prevalence of resistance to ARV medications. Most focused on the developed world.

Recent data on treatment naïve persons from ten large cities in the U.S.^95^ showed that resistance was higher in men who have sex with men (MSMs, 12 percent) compared to other risk groups and higher among whites (13 percent) than among other races. Overall, 8.3 percent of treatment-naïve persons were resistant to at least one drug. Regarding treatment-experienced patients in the U.S., 1998 data from the HIV Cost and Services Utilization Study (HCSUS) showed that 76 percent of viremic patients (that is, patients with measurable blood levels of the virus) were resistant to at least one drug. Of the viremic patients, 71.4 percent were resistant to NRTIs, 25.2 percent to NNRTIs, and 40.5 percent to PIs.^15^ In univariate analyses, men had a higher rate of resistance than women; there were no differences by race. Those with heterosexually acquired HIV or unknown mode of transmission had lower levels of resistance than MSMs and injection drug users (IDUs). The patterns likely reflect historical access to medications among population groups, that is, populations with earlier access to medications were more likely to be resistant. However, none of these variables were significant predictors of resistance in a multiple logistic regression that included CD4 count, viral load, and treatment variables.

The CATCH study (Combined Analysis of Resistance Transmission over Time of Chronically and Acutely Infected HIV Patients in Europe) presented an overview of resistance in Europe. Authors analyzed data from 2,208 treatment-naïve individuals. Prevalence of resistance to any medication class was 10.4 percent: 7.6 percent were resistant to NRTIs, 2.9 percent to NNRTIs, 2.5 percent to PIs.^96^ ^97^ Clade B viruses were more likely to carry resistance mutations than non-B clades (12.9 percent vs. 4.8 percent). Baseline resistance in new cases of non-B infection increased over time, from 2.0 percent in 1996-1998 to 8.2 percent in 2000-2001.

The WATCH study (described in the methods section) collected data on resistance from treatment-naïve participants from around the world. In 2006, researchers presented two abstracts{#2102}^98^ on 4,714 patients for whom the viral protease and/or reverse transcriptase sequences had been determined. The patients were primarily male (69 percent) with mean age 35.3 years. Thirty-one percent of the patients identified as MSMs; another 9 percent were IDUs. Data on route of transmission were unavailable for 20 percent. Again, the rates of resistance reflect the patterns of drug availability over the course of the epidemic. The rate of resistance (to any drug) was 5.5 percent in Africa, 7.4 percent in East Asia, 5.7 percent in Southeast Asia, and 6.4 percent in Latin America, lower than in North America (11.4 percent) and Europe (10.6 percent). WATCH data suggest that the use of mono- and dual therapy in the developed world resulted in extensive transmission of NRTI resistance; Western regions had higher levels of resistance to NRTIs than to NNRTIs or PIs, whereas developing regions tended to have a relatively equal distribution of resistance over the three drug classes. Multi-class resistance was very low in both east and Southeast Asia (close to zero) compared to 3.1 percent in North America. The WATCH authors also calculated odds ratios - they were higher for NNRTI resistance in Africa (1.67) and Latin America (1.93) than in Europe, but these results did not meet conventional levels of statistical significance (p= 0.16 and 0.09, respectively).

In 2005, a paper by Vella and Palmisano presented previously published data on the prevalence of resistance in recently infected persons in various countries. The analysis included only one study from the developing world; it showed no drug resistance in 99 patients from Africa's Ivory Coast.

In sum, according to published overviews, the patterns of resistance world-wide appear to reflect trends in use of ARV medications. In developed areas, where medications were available to many HIV patients, rates of resistance to NNRTI ranged from three to four percent. In developing regions with limited resources, the rates of resistance were much lower among treatment naïve persons. Resistance to NRTIs ranged from seven to eight percent in the developed world.

## Treatment-naïve Persons in Developing Regions

Tables 1 through 4 show the prevalence of drug resistance in treatment-naïve persons in developing countries. Because the studies are heterogeneous with respect to sample size, sampling criteria, selection for testing, type of assessment conducted, time from seroconversion, and population characteristics, they report conflicting results. Nevertheless, we believe this overview is an important starting point for discussion.

Table 1 Treatment Naïve Data - India

Reference | Country | Population | Data collected | N | Clade | When assessed | Type of assessment | NNRTI | NRTI | PI | Any
Sachdeva, 2005^19^ | India | Children, women, men | 2000-2002 | 60 | B,C | NR | Genotypic other, Nested PCR | NR | 31.67% at 184, 1.67% at 215, 80% at 70 | NR
Balakrishnan P, 2005^20^ | India | Women, men | 2002-2003 | 50 | C | NR | Genotypic sequence-based mechanism, Nested PCR | 14% | 6% | 100% at minor positions, 20% at major positions
Deshpande A, 2004^21^ | India | Population NR | 2003 | 128 | (96.1%) C, (2.3%) A/C | NR | Genotypic sequence-based mechanism | NR | 1.6% | 0% at major positions

NR = Not reported

Table 2 Treatment-Naïve Data - Other Nations of Asia

Reference | Country | Population | Data collected | N | Clade | When assessed | Type of assessment | NNRTI | NRTI | PI | Any
Park, S W, 2003^22^ | South Korea | IDU, MSM, women, other men | 1998-2002 | 50 | 94% B, 4% A, 2% G | (median) 2 months after HIV infection documented | Genotypic sequence-based mechanism | 0% | 6.40% | 2.60% | 8.0%
Lan N T, 2003^23^ | Viet Nam | IDU, adolescents (12–18 yrs), women, men | 2001-2002 | 200 | 99% CRF01_AE | NR | Genotypic sequence-based mechanism | NR | 4.5% | 2.0% | 6.5%
Ly N, 2005^24^ | Cambodia | Pregnant women, other adults | 2003-2004 | 146 | 99% CRF01_AE | Known date of seroconversion of less than 1 year | Genotypic sequence-based mechanism | NR | 3.4% | 1.4% | 4.9%

NR = Not reported, IDU = Injection Drug User

Table 3 ARV resistance in treatment-naïve patients in Latin America

Reference | Country | Population | Data collected | N | Clade | When assessed | Type of assessment | NNRTI | NRTI | PI | Any
Kijak, 2001^25^ | Argentina | IDU, women, men - with established HIV infection | 1997-2000 | 86 | NR | NR | Genotypic sequence-based mechanism and probe based system | | 1.20% | (1.2%) primary, (83.7%) secondary
| | IDU, women, men - subset of above, with LiPA tests | 1997-2000 | 52 | NR | NR | Genotypic sequence-based mechanism and probe based system | | 11.54%
| | IDU, women, men - with primary HIV infection | 1997-2000 | 13 | NR | NR | Genotypic sequence-based mechanism and probe based system | | 7.69% | 7.69%*
Dumans A T, 2002^27^ | Brazil | Population NR | 1998 | 49 | Mostly B | NR | Genotypic sequence-based mechanism | 0% | 2% | 85% (secondary)
Pires I L, 2004^28^ | Brazil | Women, MSM | 2000-2002 | 50 | Mostly B | NR | Genotypic sequence-based mechanism | | 14% | 0% (primary), 85.7% (secondary)
Brindeiro R M, 2003^26^ | Brazil | Women, IDU, MSM | 2001 | 409 | (Mostly) C and F | NR | Genotypic sequence-based mechanism, Nested PCR | 2.06% | 2.36% | 2.24%
Lama, 2005^29^ | Peru | Tx-naïve - MSM, other adults | 2002-2003 | 359 | NR | NR | Genotypic sequence-based mechanism | | | | 3.3%
| | Tx-experienced - MSM, other adults | 2002-2003 | 16 | NR | NR | Genotypic sequence-based mechanism | | | | 31.3%
Andrade-Villanueva, 2004^31^ | Mexico | Women, men | 2003-2004 | 20 | B | | Genotypic sequence-based mechanism | | | 5%
Delgado E, 2001^30^ | Venezuela | PI naïve; Women, IDU, MSM | NR | 56 | Primarily B | NR | Genotypic sequence-based mechanism, Nested PCR | 1.80% | 1.8% | 1.8%
| Venezuela | PI treated; Women IDU, MSM | NR | 44 | Primarily B | NR | Genotypic sequence-based mechanism, Nested PCR | 0% | 40.9% | 9.1%
Fuentes-Romero, 2004^32^ | Mexico | Population NR | NR | 45 | NR | at enrollment | Genotypic sequence-based mechanism | 0% | 11% | 2%

NR = Not Reported; IDU = Injection Drug Users; MSM = men who have sex with men;

* represents primary PI mutations.

Table 4 ARV Resistance Among Treatment-Naïve Patients in Africa

Reference | Country | Population | Data collected | N | Clade | When assessed | Type of assessment | NNRTI | NRTI | PI | Any
Vergne L, 2000^40^ | Cameroon, Senegal, the Democratic Republic of Congo, France | NR | 1995-1999 | 9 | A | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 13 | B | NR | Genotypic sequence-based mechanism | 0% | 8% (primary) | 0% (primary)
| | NR | 1995-1999 | 2 | C | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 5 | D | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 11 | F | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 4 | G | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 2 | K | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 5 | J | NR | Genotypic sequence-based mechanism | 20% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 67 | CRF02_AG | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 3 | CRF01_AE | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 6 | A/G | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 2 | G/A/G | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 2 | G/K | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 1 | D/G/D | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 4 | ?/K | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 2 | unknown | NR | Genotypic sequence-based mechanism | 0% | 0% (primary) | 0% (primary)
| | NR | 1995-1999 | 4 | O | NR | Genotypic sequence-based mechanism | 100% | 0% (primary) | 0% (primary)
Petch L A, 2005^41^ | Malawi | NR | 1996-2001 | 21 | C | NR | Genotypic sequence-based mechanism | 0% | 0%(major), 100%(minor) | 0% (primary)
Toni T, 2002^33^ | Ivory Coast | Primarily men, heterosexual | 1997-2000 | 99 | 83% CRF02 AG, 9% A, 4% CRF06 | median - 9 mos from seroconversion | Genotypic sequence-based mechanism | 0% | 0% | 0% (primary)
Harrigan, 2001^34^ | South Africa | NR | 1997 | 358 | B and C | NR | Phenotypic VIRCO | < 2% | < 2% | < 2%
Laurent, 2002^42^ | Senegal | Women, men | 1998-2000 | 39 | Mostly CRF02_AG, O, A, B, C, G, G/K | | Genotypic sequence-based mechanism | | 5.1% | 2.6%
Handema R, 2003^36^ | Zambia | Pregnant women | 2000 | 28 | 92.8% C | NR | Genotypic sequence-based mechanism | 0% | 89.3%(secondary), 0% (primary) | 0% (primary)
Konings F A, 2004^39^ | Cameroon | Adolescents (12–18 yrs), women, men | 2000-2002 | 14 | A | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 77 | CRF02-AG | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 3 | C | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 8 | D | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 4 | F2 | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 8 | G | NR | Genotypic sequence-based mechanism, | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 1 | H | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
| | Adolescents (12–18 yrs), women, men | 2000-2002 | 7 | J | NR | Genotypic sequence-based mechanism | | | 100% (secondary)
Vergne L, 2002^43^ | Gabon | Tx naïve adults | 2000 | 13 | CRF02_AG, A, G | NR | Genotypic sequence-based mechanism | 7.7% | 7.7% | 100% (secondary)
| | ARV treated adults | 2000 | 19 | CRF02_AG, A, D | NR | Genotypic sequence-based mechanism | 5.3% | 78.9% | 5.3% (primary), 94.7% (secondary)
Kinomoto M, 2005^35^ | Ghana | Adult males | 2001-2002 | 39 | Most CRF02_AG | | Genotypic sequence-based mechanism, Phenotypic assay | | | No primary mutation observed, secondary commonly observed
Bussman, 2005^38^ | Botswana | Women, men | 2001 | 70 | C | NR | Genotypic sequence-based mechanism | 2.00% | 0% | 100%
Toni T D, 2003^44^ | Ivory Coast | Pregnant women, women, men | 2001-2002 | 107 | (mostly)CRF02_AG, A, K, CRF06_CPX | NR | Genotypic sequence-based mechanism | 4% | 1% | 1% (primary), 94% of CRF02_AG (secondary) | 5.6%
Bessong P, 2005^45^ | South Africa | NR | NR | 40 | C | NR | Genotypic sequence-based mechanism | | | 0% (primary), >90% (secondary)
Doualla-Bell, 2005^46^ | Botswana | Tx-naïve adults | NR | 33 | C | NR | Genotypic sequence-based mechanism | | | >39% (secondary)
| | PI-treated adults | NR | 15 | C | NR | Genotypic sequence-based mechanism | | | >60% (secondary), primary commonly exists
Pillay C, 2002^37^ | South Africa | Pregnant Women | 2000 | 37 | C | Before entering clinical trial | Genotypic sequence-based mechanism; Phenotypic assay | 0% | 0% | NR

NR = Not Reported

Of the 30 studies retrieved, 25 reported clade data, although some of the studies grouped results from different clades together. Three studies included patients in India, three included patients across Asia, nine included patients in Latin America, and fifteen included patients in Africa. Data were collected between 1995 and 2004. The majority conducted genotypic testing only.

### India

In recent years, ARV treatment in India has expanded. However, studies on resistance are quite rare. We found only three studies conducted in India that reported resistance in treatment-naïve HIV positive persons, all published in peer-reviewed journals (Table 1). All studies conducted genotypic testing; none conducted phenotyping. None of the studies stratified data by mode of transmission, and none estimated time from seroconversion to resistance testing. Each study tested consecutive patients entering treatment.

One study^19^ from North India assessed 60 men, women, and children from 2000-2002 using a sensitive nested amplification refractory mutation (ARMS) PCR test as well as a sequence-based mechanism. Of the NRTI mutations, about 32 percent occurred at codon 184, 80 percent at codon 70, and fewer than 2 percent at codon 215. NNRTI and PI mutations were not reported. Most participants showed a mixture of wild-type and mutant virus. CD4 count and gender were not statistically associated with mutations. Frequency of mutations at codon 70 was higher in adults than children.

A second study^20^, collected data on 50 male and female adults in South India in 2002 and 2003. All were infected with HIV clade C. Fourteen percent were resistant to NNRTIs and 6 percent were resistant to NRTIs. The most common PI mutations were naturally occurring polymorphisms, including M36, L63, and I93. Twenty percent had PI mutations at major positions; the most common was V82.

The final study collected data in 2003 from 128 participants in Mumbai (mean age 30.4 years).^21^ Over 96 percent were infected with HIV clade C. Two participants were resistant to NRTIs, as the M184V mutation was present. Polymorphisms such as M36 and L63 were common, but no major PI mutations were reported.

In sum, the populations assessed were very small compared to the number of persons living with HIV in India. We are not sure how well they represent the regional populations. Results varied, and data were not usually stratified by variables of interest. More research on ARV resistance in India is recommended.

### Other Developing Nations in Asia

We found only three studies that reported resistance patterns in treatment-naïve persons in other developing regions of Asia (we excluded Japan, Singapore, and Hong Kong) (Table 2). The first two studies did not stratify results by gender; none of the studies stratified by mode of transmission. All studies conducted genotypic testing; no phenotyping was conducted. All were published in peer-reviewed journals.

The first study^22^ reported data for 50 adults, including MSMs and IDUs, in South Korea. Data were collected between 1998 and 2002. It is unclear how participants were selected for testing. Ninety-four percent of the sample was infected with HIV clade B. Participants were tested for resistance an average of 2 months after testing positive for HIV. None were resistant to NNRTIs, 6.5 percent were resistant to NRTIs, and 2.6 percent were resistant to PIs. The most common NRTI mutations were D67N, K70R, V118I, T215F, and T219Q.

Another study^23^ reported data on 200 adults and adolescents in Vietnam; 42.5 percent were IDUs. Data were collected in 2001 and 2002. HIV clade was primarily CRF01_AE. None of the participants were resistant to NNRTIs; 4.5 percent were resistant to NRTIs, and 2.0 percent were resistant to PIs. The most common NRTI mutations were M41L, K219Q, and M184I. PI mutations found were D30N and L90M.

The last study^24^ collected data on all pregnant women (N = 124) and other adults (N=22) who consecutively entered a treatment program in Cambodia in 2003 and 2004. They were tested for resistance within 1 year of a known date of seroconversion. HIV clade was primarily CRF01_AE. NRTI mutations were found in 3.4 percent; the most common mutations were K70R, V75M, and K101E. Major PI mutations were found in two participants (1.4 percent); one had M46I, the other N88D.

The samples in these studies were very small compared to the numbers of persons living with HIV in the region. Resistance data were not stratified by HIV risk factors, although that information was collected in at least two of the studies. Rates of resistance were fairly low among both clade B and recombinant clade CRF01_AE; rates were similar to those reported in Southeast Asia by the WATCH study.{Bowles, Wensing, et al. August 11–12 #2102}^98^ The specific mutations in the clade B South Korean participants were quite different from those found in the Southeast Asian CRF01_AE participants.

### Latin America

Nine studies reported data on resistance to ARV medications among treatment-naïve populations in Latin America. We found one study from Argentina, three from Brazil, one from Peru, one from Venezuela, and two from Mexico (one study^99^ combined data from several countries-Brazil, Portugal, Ivory Coast, Nigeria, Guinea Bissau, Lebanon, and the U.S. -but did not stratify data by region or HIV clade, so it was excluded). Data were collected between 1997 and 2004. None of the studies reported time from seroconversion to assessment. The Peru and Argentina studies did not report HIV clade, nor did one of the studies from Mexico. None of the studies stratified resistance data by gender or mode of transmission, although one study included only MSM. All studies conducted genotypic assessment; two conducted additional phenotyping. Many studies did not report how participants were selected for resistance testing; statements were often vague as to whether all, or only a sample of patients entering treatment, were tested.

The study from Argentina^25^ assessed resistance among adults, some of whom were IDUs. HIV clade was not reported. The authors compared persons with primary infection (N=13) to those with established infection (N=86). Of those with primary infection, one person was resistant to NRTIs and one was resistant to PIs. Of those with established infection, 1.2 percent had mutations to NRTIs and 1.2 percent had primary PI mutations (83.7 percent had secondary PI mutations). Line probe assays (LiPA), which identify specific mutations by a reverse hybridization strategy, were conducted on 52 of the established infection samples;^100^ 11.5 percent were resistant to NRTIs.

In Brazil, a study of 409 treatment-naïve women (mostly infected with HIV clade C), MSMs, IDUs, and others showed very low resistance levels.^26^ Of the group, 2.06 percent were resistant to NNRTIs, 2.36 percent were resistant to NRTIs, and 2.24 percent were resistant to PIs. Another study of 49 adults, mostly infected with clade B HIV, reported that none were resistant to NNRTIs, 2.0 percent were resistant to NRTIs, and 85 percent had secondary PI mutations.^27^ Another study of 50 adults (mostly infected with clade B), including MSMs, reported that 14 percent were resistant to NRTIs and 85.7 percent had secondary PI mutations.^28^ The secondary mutations in these studies were most likely naturally occurring polymorphisms with no known relationship to resistance.

A study of MSM in Peru^29^ compared resistance in 359 treatment-naïve and 16 treatment-experienced patients. Resistance to drugs was low among the treatment naive - 3.3 percent overall, compared to 31.3 percent overall among the treatment experienced. HIV clade was not reported.

A United Nations (UN) AIDS clinic in Venezuela^30^ reported data on adults including IDUs, MSM, and women. All but two persons had HIV clade B. The authors compared resistance rates of PI-naïve (N=56) and PI-experienced (N=44) patients. Some of the PI-naïve patients had experience with mono- and dual therapy. The rate of resistance was low among the PI naive - only one person was resistant to any drug. Among the PI-experienced patients, 40.9 percent were resistant to NRTIs and 9.1 percent were resistant to PIs.

Finally, studies in Mexico reported that 5.0 percent of 20 adults infected with clade B who enrolled in treatment at a Jalisco clinic were resistant to PIs,^31^ while of 45 patients who enrolled for treatment in Central Mexico, 11.0 percent were resistant to NRTIs and 2.0 percent were resistant to PIs.^32^ Again, stratified data were not reported.

In sum, rates of resistance to NRTIs ranged from 2.0 percent to 14 percent among treatment-naïve groups in Latin America. Rates of resistance to NNRTIs were low, ranging from zero to two percent. Rates of PI polymorphisms were high in Brazil and Argentina, presumably among persons infected with HIV clade B. Resistance data were rarely stratified by mode of transmission or gender, although those data were available in many cases.

The number of persons tested for resistance in these studies is small relative to the number of people taking HIV ARVs in Latin America. Some studies tested all consecutive patients entering clinic^26,^ ^29^, while others did not explicitly state how participants were selected. Therefore, it is difficult to judge how representative the data are. We found no published reports of resistance rates in Central American countries, despite the high HIV prevalence rates in some of those nations.

### Africa

We found 14 studies that reported resistance data on treatment-naïve populations in sub-Saharan Africa. They are displayed in Table 4. Data were collected between 1995 and 2002. Studies were conducted in Cameroon, Senegal, Republic of Congo, Ivory Coast, Zambia, Gabon, Ghana, Malawi, South Africa, Zimbabwe, and Botswana; all reported HIV clade. The most common clades were CRF02 AG, which predominates in west Africa, and C, which is predominant in southern Africa. All studies conducted genotypic testing; three conducted additional phenotypic assessments^33^–^35^. Two studies included only pregnant women^36,^ ^37^; another included only men^35^. The other studies did not stratify results by gender. None of the studies stratified results by mode of transmission; the majority of studies described their participants as heterosexual adults.

Of the studies that described participant selection, two studies^38,^ ^39^ tested random samples of patients, and one study tested all pregnant women entering a clinical trial.^37^ The other studies did not clarify how they selected participants for resistance testing. Many implied that all incoming HIV positive persons were tested; however, none explicitly stated this.

Regarding treatment-naïve pregnant women, one study^36^ performed genotypic testing on 28 women who entered treatment in Zambia in 2000; 92.8 percent of the women were infected with HIV clade C. None had any primary mutations; 89.3 percent had secondary NRTI mutations, and all had secondary PI mutations. Most secondary mutations were polymorphisms. Testing for RT mutations was also performed on samples from 37 pregnant women who entered a clinical trial in South Africa the same year.^37^ No women had resistance to NRTIs or NNRTIs; all were infected with clade C.

The study that included only males^35^ found that although none of the 37 Ghanian men (mostly infected with mostly clade CRF02 AG) had primary PI mutations, secondary mutations were “commonly observed.” Exact figures were not reported. Testing for RT mutations was not performed.

Two studies compared resistance among small samples of people infected with rarer HIV clades. Vergne^40^ reported data collected from 1995 to 1999 in Cameroon, Senegal, the Congo, and France. Regarding NNRTIs, one of five samples from participants infected with type J showed resistance, as did all four type O samples, compared to none of the type A, B, C, D, F, G, K, or recombinant types. Other than one participant infected with clade B, none of the others were resistant to NRTIs. No participants had primary PI mutations; all samples except those from participants infected with clade B and D had secondary PI mutations. Another study^39^ reported on resistance among participants infected with clades A, C, D, F2, G, H, and J in addition to the dominant CRF02-AG clade. Data were collected from adults and adolescents in Cameroon from 2000 to 2002. All samples had secondary PI mutations. Tests for RT mutations were not reported.

Many of the studies conducted among individuals with highly prevalent HIV clades showed a high rate of secondary PI mutations in CFR02-AG. The same was true for HIV clade C. Rates of resistance to NNRTIs ranged from 0 percent to 7.7 percent in clade C-infected individuals and 0 percent to 2 percent in those infected with CRF02-AG. Resistance to NRTIs also ranged from 0 percent to 7.7 percent in clade C and from 0 percent to 5.1 percent in CRF02-AG.

In summary, rates of NNRTI resistance ranged from 0 percent to 7.7 percent in most HIV clades. Prevalence was higher in clades B and O in one study, but samples were too small to allow generalization to the population at large. NRTI resistance rates ranged from 0 percent to 8 percent for all clades. Primary PI mutations were rare (<3 percent) among Africans. There were high levels of secondary PI mutations reported in most studies; there is no evidence that these affect resistance in the absence of primary mutations. It was unclear how some studies selected persons for genetic testing and most studies had small samples. Therefore, the generalizability of the data is limited.

## Pregnant Women and Their Children in Developing Countries

### Overview

We identified 31 studies in developing countries that addressed the emergence of ARV resistance in women subsequent to the administration of ARV therapy to prevent mother to child transmission (pMTCT) of HIV-1 infection. These studies were heterogeneous in terms of the duration of ARV treatment, the selection of the ARV regimen, the timing and frequency with which ARV resistance tests were done, the sensitivity of the assay for ARV resistance, and whether clade-specific data were reported. Many studies were reported only as conference abstracts; these studies tend to include less information than articles in peer-reviewed journals.

In this section, we review the data on the prevalence of resistance in this group according to the prophylactic regimen, the infecting viral clade, the timing of the resistance assay (i.e., how long after the cessation of ARV therapy), and the assay that was used to detect ARV resistance.

### Resistance and pMTCT regimen

Single dose Nevirapine (SD-NVP) alone. The greatest number of evaluable reports studied the impact of SD-NVP alone on the emergence of resistance (N= 14). Several of these reports provided data derived from the HIV-1NET 012 trial, which left three evaluable reports that provided non-overlapping data from the study,^47^–^49^ two reports that provided non-overlapping data from one South African study, ^50^ ^51^ and two reports that provided non-overlapping data from another South African study.^52^ ^53^ All studies were done in sub-Saharan Africa.

The earliest time that resistance was assessed was 7 days postpartum.^47^ Most studies assessed resistance 6 – 8 weeks postpartum (N = 10). Two studies evaluated the prevalence of resistance approximately 6 months postpartum. Eleven of the fourteen reports provided information by viral clade and three did not. The rate of NNRTI resistance 6 to 8 weeks post SD-NVP ranged from 8.5 percent to 69.2 percent.

Table 5 shows the results of standard genotypic resistance assays in the main evaluable studies. Studies that address specific questions in subpopulations of the main study (e.g., data comparing the results of highly sensitive assays for the detection of ARV resistance with standard genotypic resistance assays or studies of resistance over time^13^) are not included in this table.

Table 5 NNRTI Resistance among pregnant women given single-dose nevirapine alone

Reference | Country | When data collected | N | Clade | When assessed (weeks post-partum) | Type of assessment | NNRTI Resistance
Eshleman, 2005^48^ | Uganda | 1997-1999 | 83 | A | 1 | Genotypic sequence-based mechanism | 24.0%
Eshleman, 2005^48^ | Uganda | 1997-1999 | 57 | D | 1 | Genotypic sequence-based mechanism | 19.0%
Loubser, 2004^54^ | South Africa | NR | 35 | C^b^ | 2 | Genotypic sequence-based mechanism | 71.0%
Kantor, 2003^55^ | Zimbabwe | NR | 28 | C | 2 | Genotypic sequence-based mechanism | 75%
Toni, 2005^59^ | Cote d'Ivoire | NR | 29 | CFR02-AG* | 4 | Genotypic sequence-based mechanism | 20.7%
Lehman, 2005^101^ | Kenya | NR | 30 | NR | 4 | Genotypic other, Allele-specific RT-PCR assay | 40.0%
Mcintyre, 2005^50^ | South Africa | NR | 68 | NR | 6 | Genotypic sequence-based mechanism | 57.0%
Loubser, 2006^58^ | South Africa | NR | 66 | C*** | 6 | Genotypic sequence-based mechanism | 54.0%
Morris, 2003^56^ | South Africa | 2002 | 141 | C | 6 | Genotypic sequence-based mechanism | 8.5%
Gordon, 2004^57^ | South Africa | NR | 30 | C^c^ | 6 | Genotypic sequence-based mechanism | 40.0%
Loubser, 2004^54^ | South Africa | NR | 164 | C^b^ | 6 | Genotypic sequence-based mechanism | 48.0%
Troyer, 2005^60^ | Uganda | NR | 71^a^ | A*** | 6 | Genotypic other, Radio labeled oligonuc. DNA ligation (OLA) | 16.0%
Martinson, 2004^52^ | South Africa | NR | 456 | C** | 7 | Genotypic other, NR | 38.8%
Eshleman, 2005^49^ | Uganda | 1997-1999 | 97 | D | 6 to 8 | Genotypic sequence-based mechanism | 36.1%
Eshleman, 2005^49^ | Uganda | 1997-1999 | 144 | A | 6 to 8 | Genotypic sequence-based mechanism | 19.4%
Eshleman, 2005^49^ | Malawi | 1997-1999 | 65 | C | 6 to 8 | Genotypic sequence-based mechanism | 69.2%
Kantor, 2003^55^ | Zimbabwe | NR | 32 | C | 8 | Genotypic sequence-based mechanism | 34%
Eshleman, 2004^61^ | Uganda | 1997-1999 | 28 | Recombinant | 6 to 8 | Genotypic sequence-based mechanism | 17.9%
Author not available, 2003^102^ | Zimbabwe | NR | 33 | NR | 8 | | 24.2%
Kantor, 2003^55^ | Zimbabwe | NR | 8 | C | 24 | Genotypic sequence-based mechanism | 13%
Morris, 2004^53^ | South Africa | NR | 155 | C** | 26 | Genotypic sequence-based mechanism | 35.0%

* 7% of isolates clade A

** 4 participants were not infected by HIV-1 clade C

*** 1 subject infected by HIV-1 clade A

**** 23% of participants were infected by HIV-1 clades D, 3% by clade C and 15% by recombinant clades

a 61 women plus 10 infected infants; duration of NVP usage not clearly stated

b 1% of participants were not infected by HIV-1 clade C

c 2% of isolates were not infected by HIV-1 clade C

Analysis of SD-NVP resistance data by clade. Thirteen studies of SD-NVP contrasted the emergence of ARV resistance in mothers infected by differing clades of HIV-1. Aside from clade C, for which 8 reports provided information regarding the emergence of resistance in seven clinical trials (data from one South African study of persons infected by clade C were provided in two reports^52^ ^53^), no other clade was analyzed in more than two clinical trials.

As shown in Table 6, the reported prevalence of NNRTI-resistance as assessed by standard genotypic resistance tests, is highly variable, ranging from over 70 percent at 2 weeks postpartum^54^ ^103^ to 8.5 percent at 6 weeks postpartum in one study performed in South African women.^56^ Many studies showed a decline in resistance over time; this phenomenon will be discussed in more detail in a separate section.

Table 6 Resistance among pregnant women infected with HIV clade C after single-dose nevirapine

Reference | N | Clade | When assessed (weeks post-partum) | Type of assessment | NNRTI Resistance
Loubser, 2004^54^ | 35 | C* | 2 | Genotypic sequence-based mechanism | 71.0%
Kantor, 2003^55^ | 28 | C | 2 | Genotypic sequence-based mechanism | 75%
Morris, 2003^56^ | 141 | C | 6 | Genotypic sequence-based mechanism | 8.5%
Gordon, 2004^57^ | 30 | C**** | 6 | Genotypic sequence-based mechanism | 40.0%
Loubser, 2004^54^ | 164 | C* | 6 | Genotypic sequence-based mechanism | 48.0%
Loubser, 2006^58^ | 66 | C*** | 6 | Allele-specific real-time PCR assay | 54.0%
Martinson, 2004^52^ | 456 | C** | 7 | Genotypic other, NR | 38.8%
Eshleman, 2005^49^ | 65 | C | 6 to 8 | Genotypic sequence-based mechanism | 69.2%
Kantor, 2003^55^ | 32 | C | 8 | Genotypic sequence-based mechanism | 34%
Kantor, 2003^55^ | 8 | C | 24 | Genotypic sequence-based mechanism | 13%
Morris, 2004^55^ | 155 | C** | 26 | Genotypic sequence-based mechanism | 35%

* 1% of participants were not infected by HIV-1 clade C

** 4 participants were not infected by HIV-1 clade C

*** 1 subject was infected by HIV-1 clade A

**** 2% of participants were not infected by HIV-1 clade C

Following SD-NVP, the prevalence of ARV resistance in women infected by HIV clades other than clade C ranged from 16 percent (6 weeks postpartum, clade A^60^) to 36 percent (6 – 8 weeks postpartum, clade D^47^). A summary of results from studies of ARV resistance following administration of SD-NVP for pMTCT to women infected by other clades of HIV-1 is provided in Table 7.

Table 7 ARV resistance after single-dose nevirapine, among women infected with other HIV clades

Reference | N | Clade | When assessed (weeks post-partum) | Type of assessment | NNRTI Resistance
Eshleman, Sept 2005^48^ | 83 | A | 1 | Genotypic sequence-based mechanism | 24.0%
Eshleman, Sept 2005^48^ | 57 | D | 1 | Genotypic sequence-based mechanism | 19.0%
Toni, 2005^59^ | 29 | CFR02-AG* | 4 | Genotypic sequence-based mechanism | 20.7%
Troyer, 2005^60^ | 71** | A | 6 | Genotypic other, Radio labeled oligonuc. DNA ligation (OLA) | 16.0%
Eshleman, July 2005^49^ | 144 | A | 6 to 8 | Genotypic sequence-based mechanism | 19.4%
Eshleman, July 2005^49^ | 97 | D | 6 to 8 | Genotypic sequence-based mechanism | 36.1%
Eshleman, Feb 2004^61^ | 28 | Recombinant | 6 to 8 | Genotypic sequence-based mechanism | 17.9%

* 93% infected by CFR02-AG, 7% by clade A

** Resistance results are from 61 women plus 10 infected infants; 23% of patients were infected by HIV-1 clades D, 3% by clade C and 15% by recombinants

One formal cross-clade analysis of the prevalence of ARV resistance in female recipients of SD-NVP was identified. Using the results of the HIV-1NET 012 and NVAZ trials, Eshleman demonstrated that the proportion of women with clade C with at least one NVP resistance mutation (69 percent) 6 – 8 weeks postpartum was significantly higher than found in women infected by clade A (19 percent, p < 0.0001) or clade D (36 percent, p < 0.001).^49^ In the HIV-1NET 012 trial, nevirapine resistance was greater in clade A than clade D.

Specific NNRTI amino acid changes associated with resistance in persons receiving SD-NVP. Complex patterns of NNRTI resistance were observed following the receipt of SD-NVP. The most common mutations that resulted in amino acid changes were K103N (lysine to asparagine at position 103) and Y181C (tyrosine to cysteine). Y181C was the most commonly detected resistance mutation in plasma collected 2 weeks postpartum from women infected by HIV-1 clade C.^54,^ ^55^ In contrast, the K103N resistance mutation was most common at later time points in persons infected by clade C and at all times in persons infected by other HIV-1 clades. Among clade-C women from South Africa, V106/A/M (valine to alanine or methionine) was the most common amino acid change.^54^ One report found that the rates of detection of K103N, Y181C, and Y188C were significantly higher in women infected by HIV-1 clade C than by HIV-1 clades A or D.^49^ Still, there has not been enough research to assess whether there are clade-specific differences in the prevalence of resistance.

The findings from studies that provided data on the prevalence of various NNRTI resistance mutations are displayed in Table 8.

Table 8 Specific mutations observed in mothers receiving single-dose nevirapine

Reference | N | Clade | WeekPost- partum | Any | Proportion of women with specific, indicated resistance mutation
| | | | | K103N | Y181C | Y188C | G190A | V106A/M | K101E | V108A/I | L100I | P236L
Loubser, 2004^54^ | 35 | C | 2 | 71% | 29% | 49% | 34% | 23% | 43%
Kantor, 2003^55^ | 28 | C | 2 | 75% | 25% | 57% | 14% | | 19%
Loubser, 2004^54^ | 164 | C | 6 | 48% | 31% | 23% | 20% | 14% | 15%
Gordon, 2004^57^ | 30 | C | 6 | 40% | 33% | 10% | 10% | 3% | 7%
Eshleman, 2005,^49^ | 65 | C | 6 – 8 | 69% | 58% | 32% | 17% | 9% | 3% | 2% | 2%
Kantor, 2003^55^ | 32 | C | 8 | 34% | 28% | 6% | | | 6%
Eshleman, 2005,^49^ | 144 | A | 6 – 8 | 19% | 17% | 6% | 1% | 4% | 1% | 1% | 0%
Eshleman, 2005,^49^ | 98 | D | 6 – 8 | 36% | 29% | 16% | 3% | 6% | 0% | 4% | 1%
Toni, 2005^59^ | 29 | CRF02_AG | 4 | 21% | 10% | | | | 3% | 3% | | 3% | 3%
Eshleman, 2004^61^ | 28 | Recomb | 6 – 8 | 18% | 14% | 7% | | | | 4%
Shapiro, 2006^71^* | 155 | NR | 4 | 45% | 33% | 8% | 1% | 5% | 8%

* mothers also received ZDV for one month. Abbreviations: A=alanine, C=cysteine, E=glutamic acid; G=glycine, I=isoleucine, K=lysine, L=leucine, M=methionine, N=asparagine, P=proline, V=valine, Y=tyrosine.

Effect of single-dose nevirapine on resistance over time. A number of considerations suggest that the prevalence of readily detectable ARV resistance, particularly resistance that results from the use of NNRTIs, may vary after the discontinuation of ARV administration. First, significant serum concentrations of NVP may persist for prolonged periods of time after a single dose, leading to delayed (i.e., beyond 7 days) emergence of resistance. The prolonged presence of subtherapeutic serum concentrations may lead to ongoing selection of mutants for 2 to 3 weeks. Conversely, if resistant virus is less fit than wild type virus, the prevalence of readily detectable resistant virus may gradually decline. Therefore, resistance testing done immediately after the administration of single dose NVP may underestimate the subsequent emergence of NNRTI-resistance due to this treatment strategy, whereas delayed ARV resistance testing may underestimate the prevalence of previously detectable resistance.

Several studies, using a variety of assays including very sensitive ones, assessed the presence of NNRTI resistance over time among women who took SD-NVP to prevent mother-to-child transmission of HIV. Study data are presented in Table 9.

Table 9 Abatement of resistance over time in women taking single-dose nevaripine to prevent mother-to-child transmission

Reference | Country | N | HIV Clade | Type of assessment | NNRTI Resistance Results
Martinson, 2004^52^ | South Africa | 456 | C | Genotypic other, | 4–6 weeks 43% | 6–7 weeks 44% | 7–10 weeks 44% | 10–36 weeks 24%
| | | | NR | (N-unclear) | (N-unclear) | (N-unclear) | (N-unclear)
Eshleman, 2005^48^ | Uganda | 65 | A | Genotypic sequence-based mechanism | 7 days 24% | 6–8 weeks.
| | | | | | 28%
| | | D | Genotypic sequence-based mechanism | 7 days 19% | 6–8 weeks.
| | | | | | 42%
Eshleman, 2001^47^ | Uganda | 311 in NVP arm | A, D | Genotypic sequence-based mechanism | | 6–8 weeks 19% | 12–24 months 0
| | | | | | (21 of 111 tested) | (of 11 of those w/resistance at 6–8 weeks, who were re-tested)
Flys, 2007^104^ | Uganda | 88 | A | Lig Amp assay | 6–8 weeks | 2 years | 3 years | 4 years
| | | | | 34.1% | 3.6% | 1.3% | 0%
| | 56 | D | Lig Amp assay | 6–8 weeks | 2 years | 3 years | 4 years
| | | | | 53.6% | 29.8% | 18.9% | 2.4%
Loubser, 2006^58^ | South Africa | 67 | C | Allele-specific real-time PCR | 6 weeks 87% | 3 months 65% | 7 months 39% | 12 months 11%
| | | | | (27 of 31 RNA tests) | (17 of 26 RNA tests) | (14 of 36 RNA tests) | (6 of 53 RNA tests)
Kantor, 2003^58^ | Zimbabwe | 34 | C | Genotypic sequence-based mechanism | 2 weeks 75% | 8 weeks 34% | 24 weeks 13%
| | | | | (21 of 28 tests) | (11 of 32 tests) | (1 of 8 tests)
Loubser, 2004^54^ | South Africa | 164^a^ | C^b^ | Genotypic sequence-based mechanism | 2 weeks 71% | 6 weeks 48%
| | | | | (25 of 35 tests) | (78 of 164 tests)

a 35 patients were studied 2 weeks after delivery and 164 patients were studied 6 weeks after delivery

b 2 patients were infected by HIV clade A

Eshleman^48^ conducted genotypic testing on participants in randomized trial HIV-1 NET 012 at 7 days postpartum. She found that 24 percent of women infected with HIV clade A had NNRTI resistance, compared to 19 percent of women infected with clade D. The same women were tested at 6 to 8 weeks postpartum. At that point, 28 percent of clade A women had evidence of resistance, compared to 42 percent of clade D women. The authors reported rapid fading of variants with Y181C in clade A but not in clade D. In the developed world, studies in individuals infected with clade B have shown that Y181C confers high-level resistance to NVP and impairs viral fitness. These results suggest that Y181C may have less effect on viral fitness of clade D than on fitness of clade A. Eshleman^47^ also did follow up on 11 women who had resistance at the 6- to 8-week time point. When genotyping was conducted between one and two years postpartum; none of the women had evidence of NNRTI resistance.

Flys^104^ also reported recently on women from HIV-1 NET 012. (It is unclear how her sample overlaps with those in the previous publications.) She reported that 34.1 percent of 88 clade A participants had the K103N mutation at 6 to 8 weeks, compared to 53.6 percent of 56 clade D participants. Using follow-up tests and survival analysis, she estimated that the prevalence of the mutation declined to 3.6 percent in clade A and 29.8 percent in clade D at 2 years. By 4 years, she estimated that no clade A participants and only 2.4 percent of clade D participants had the mutation.

The prevalence and decline of the most common NVP mutant, K103N, were also examined using allele-specific PCR in 65 women infected with HIV clade C in South Africa^58^ after SD-NVP. The rate of resistance, assessed through a highly sensitive assay, declined steadily over 1 year, from 87 percent at 6 weeks post-partum to only 11 percent at 1 year, according to RT-PCR of plasma RNA. PCR was used to detect cellular proviral DNA; these results were used to generate estimated rates of resistance of 52 percent at 6 weeks and only 4.2 percent at 1 year. Of note, the number of women available for testing at each follow-up ranged from 26 to 53 of the original 65. Samples were available at all time points for only 16 women.

We also found two conference abstracts that assessed the association of resistance with time following SD-NVP in a pMTCT cohort. Martinson^52^ followed up on 456 women; all but four were infected with HIV clade C. NNRTI resistance was defined as any of the following mutations: K103N, V106 A/M, Y181C, Y188C, and G190A. It appears that each woman was tested once for resistance within 36 weeks of birth. Compared to women tested within 10 weeks postpartum, far fewer women who were tested between 10 and 36 weeks showed evidence of resistance (44 percent versus 24 percent, respectively). Baseline CD4 cell count, viral load, time from birth to resistance testing, and number of times a mother took NVP during pregnancy were significantly associated with development of resistance. Martinson also measured resistance in infants;^62^ the results of this assessment are discussed below in the section on infants.

Kantor^55^ assessed resistance over time in 34 women in Zimbabwe who received SD-NVP. All were infected with HIV clade C. NNRTI resistance rates dropped from 75 percent at two weeks postpartum to 34 percent at 8 weeks and 13 percent at 24 weeks. (The number of women available for testing dropped from 32 at eight weeks to only eight at 24 weeks, limiting the validity of the findings.) Prevalence of the Y181C mutation dropped from 57 percent at two weeks to six percent at week eight, while the K103N mutation was present in 25 percent of women at 2 weeks and 28 percent at 8 weeks. Similarly, Loubser^54^ studied a group of women in south Africa who had received SD-NVP; all but two were infected by HIV clade C. These investigators found that the prevalence of Y181C decreased from 49 percent at week 2 (N = 35) to 23 percent at week 6 postpartum (N = 164). The prevalence of the K103N mutation was 29 percent at 2 weeks and 31 percent at 6 weeks.

In sum, evidence provided by longitudinal analyses suggests that the prevalence of detectable NNRTI resistance may vary with time since treatment. Fading of variants with Y181C were reported in clade A but not in clade D. Prior studies show that Y181C confers high-level resistance to NVP and impairs viral fitness in persons infected by HIV clade B. Thus it is possible that Y181C may have less effect on viral fitness of clade D than of A. This observation warrants further investigation in future studies.

Other pMTCT regimens, including therapy pre and post SD-NVP. Ten studies from the developing world were identified that studied the emergence of ARV resistance following other pMTCT regimens, including adding ARV therapy before or after SD-NVP. Two studies were done in Thailand,^63,^ ^64^ one was conducted in Argentina,^65^ and the other eight studies were done in Sub-Saharan Africa. The findings are presented in Table 9.

In women using NRTIs alone,^60,^ ^63,^ ^66,^ ^67^ the rates of NRTI resistance ranged from zero to four percent. Rates of HIV transmission to infants varied by regimen. In a study of pregnant women taking ZDV and DDI from 36 weeks gestation, 5.4% of the infants were HIV positive. In two studies of ZDV alone, transmission rates were 16.5% and 16.7%. (In the former study, women were breastfeeding.) Another study of ZDV alone did not report transmission rates.

An RCT conducted in the U.S. and France (not displayed) assessed whether NVP resistance would occur after intrapartum NVP (or placebo) in women receiving standard ARV treatment during pregnancy.^105^ The study included mostly (62 percent) non clade B women, who were of African origin. 15 percent of the women in the NVP group developed a new NVP mutation at 6 weeks postpartum. The development of a new NVP mutation did not correlate with CD4 cell count or viral load at delivery, or with the type of ARV after delivery. Similar trials were conducted in the developing world; rates of 32 percent and 33 percent for NNRTI resistance were observed in two trials using ZDV monotherapy in the pre-partum period followed by SD-NVP during labor.^69^ In another study^70^ 6.3 percent of women who took ARV followed by SD-NVP showed NVP resistance at a mean of 48 days. A very recent study by Shapiro^71^ randomized pregnant women on ZDV-based ARV to either SD-NVP or placebo at birth. 45 percent of the SD-NVP group had NVP resistance at one month post-partum. Importantly, the difference in HIV transmission from mother to child was insignificant between the SD-NVP and placebo groups, suggesting that SD-NVP may be unnecessary in the context of ARV treatment of pregnant women

The World Health Organization (WHO)'s revised guidelines recommend a combination of ZDV and lamivudine (3TC) at the “tail” end (post-partum) be used to reduce the risk of resistance from NVP.^106^ We found two trials that support these new guidelines. One prospective randomized trial compared the prevalence of NVP resistance in persons given SD-NVP followed by 0, 4 or 7 days of ZDV plus 3TC.^46^ The rates of NNRTI resistance in these three groups, as detected by standard genotypic resistance assays, were 57 percent, 13 percent, and 9 percent respectively. Similarly, in a non-controlled trial, Chaix et al. found that the rates of NNRTI resistance were less when SD-NVP was followed by the administration of ZDV plus 3TC for 3 days post-partum than had been observed in previous trials of SD-NVP alone.^68^

Recent reports from sub-Saharan Africa indicate that risk of virologic failure (the failure to achieve measurable decreases in serum viral load after treatment) in women initiating ARV after SD-NVP is associated with the interval between receipt of SD-NVP and initiation of full ARV. Lockman^72^ showed that viral response was similar between women who had SD-NVP and those who received no SD-NVP (placebo) if they started treatment more than 6 months after SD-NVP, while viral failure was more common with SD-NVP if ARV was started less than 6 months after exposure. The CD4 response was the same with or without SD-NVP, regardless of time of initiation. Data from Coovadia,^107^ where women started ARV a median of 2 years after SD-NVP exposure, found no difference in viral response between women with SD-NVP exposure and those without. Chi^73^ also found no difference between SD-NVP and no SD-NVP in viral response or CD4 count response. In this study, median time from SD-NVP to ARV initiation was 503 days; 81% started ARV at least six months post-partum. Additionally, several abstracts have found that SD-NVP is as effective in second pregnancy as in first pregnancy. ^108^ ^109^ None of these abstracts reported resistance rates. We strongly suggest that future studies of this nature include resistance testing.

There are currently two RCTs funded by the NIH that will assess response to NNRTI- and PI-based therapy in persons with and without prior SD-NVP exposure. These trials, one in women and one in infants, will add significantly to our body of knowledge on this issue.

Measuring the presence of resistance using standard vs. more-sensitive techniques. HIV resistance is usually assessed by performing population-based genetic sequencing of HIV RNA collected from virus found in plasma and determining the presence of specific mutations. These assays are insensitive to minor viral sub-populations that account for less than 20 – 30 percent of circulating virus. In contrast, by the use of specific genetic probes, RT-PCR, allele-specific PCR, or multiple single genomes, it is possible to detect viral subpopulations that constitute as little as 0.1 – 0.2 percent of circulating virus in plasma. Other, more sensitive, assays include tests for the presence of HIV proviral DNA in mononuclear cells.

As shown in Table 11, the rates of NNRTI resistance are consistently greater when more-sensitive assays are employed.^51,^ ^58,^ ^65,^ ^74^ For example, Eshleman first reported rates of NNRTI resistance of 69.2 percent, 36.1 percent, and 19.4 percent, respectively for women infected with clade C, D, and A, 6 to 8 weeks after SD-NVP.^49^ According to Flys,^110^ Lig Amp assays on the same participants showed that in reality, 69.8 percent, 54.3 percent, and 41.7 percent of women with clade C, D, and A, respectively, had the K103N resistance mutation.

Table 10 Other pMTCT regimens, including pre- and post-SD-NPV therapy

Reference | Regimen | N | Clade | When assessed (weeks post-partum) | Type of assessment | New NNRTI | New NRTI
Giuliano 2005^b66^ | ZDV+DDI | 22 | NR | 0 | Genotypic other, NR | 0%* | 0%*
Ekpini, 2002^67^ | ZDV | 20 | NR | 0 | Genotypic sequence-based mechanism | NA | 0.0%
Sutthent, 2005^63^ | ZDV | 24^d^ | NR | 0 | Genotypic sequence-based mechanism | 0.0% | 0.0%
Sutthent, 2005^63^ | ZDV+3TC | 21^e^ | NR | 0 | Genotypic sequence-based mechanism | 0.0% | 0.0%
Jourdain, 2004^64^ | ZDV | 47 | CRF01_AE** | 1.5 | Genotypic sequence-based mechanism | NA | 4.0%
Jourdain, 2004^64^ | ZDV + SD-NVP | 209 | CRF01_AE** | 1.5 | Genotypic sequence-based mechanism | 32.0% | 5.0%
Chaix, 2005^68^ | ZDV+3TC+SD-NVP^a^ | 96 | CRF02*** | 4 | Genotypic sequence-based mechanism | 1.1% | 8.3%
Chaix, 2004^69^ | ZDV+SD-NVP | 74 | NR | 4 | Genotypic sequence-based mechanism | 33.0% | NR
McIntyre, 2005^50^ | SD-NVP | 68 | NR | 6 | Genotypic sequence-based mechanism | 57.0% | 0%
McIntyre, 2005^50^ | SD-NVP+ 4 days ZDV & 3TC ^c^ | 67 | NR | 6 | Genotypic sequence-based mechanism | 13.0% | 0%
McIntyre, 2005^50^ | SD-NVP+7 days ZDV & 3TC ^c^ | 68 | NR | 6 | Genotypic sequence-based mechanism | 9.0% | 0%
Troyer, 2005^60^ | ZDV | 56^f^ | A***** | 6 | Genotypic other, Radio labeled oligonuc. DNA ligation | 0.0% | 0%
Lyons, 2005^70^ | ZDV-based HAART | 32 | Non-B (69%) | 7 | Genotypic sequence-based mechanism | 6.3% | 12.5%
Shapiro, 2006^71^ | ZDV + SD-NVP | 155 | NR | 4 | Genotypic sequence-based mechanism | 45% | NR
Perez, 2006^65^ | 3TC+ZDV+NVP | 20 | B/F**** | 12 | Genotypic sequence-based mechanism, Real time PCR | 0.0% | 5.0%

* 14.5% of participants had NNRTI resistance mutations and 4.5% had NRTI resistance mutations prior to administration of pMTCT regimen; no new mutations emerged in any participant

** 3.5% of participants were infected by other HIV-1 clades

*** An unspecified minority of patients were infected by other HIV-1 clades

**** 4 persons were infected by clade B virus

***** 23% of patients were infected by HIV-1 clades D, 3% by clade C and 15% by recombinants

a ZDV and 3TC continued for 3 days post-partum

b All mothers had transmitted HIV-1 to their infants

c ZDV & 3TC initiated during labor

d 24 women plus an unspecified number of infected infants

e 21 (or 28?) women plus an unspecified number of infected infants

f 48 women plus 8 infected infants

Table 11 Standard versus more sensitive tests

Reference | N | Regimen | Clade | When assessed (time post-partum) | NNRTI Resistance | Technique
Loubser, 2006^a58^ | 66 | SD-NVP | C | 6 weeks | 54.0%* | standard genotyping
Loubser, 2006^a58^ | 31 | SD-NVP | C | 6 weeks | 87.0%^g^* | RT-PCR of plasma RNA
Loubser, 2006^a58^ | 26 | SD-NVP | C | 3 months | 67.0%^g^* | RT-PCR of plasma RNA
Loubser, 2006^a58^ | 36 | SD-NVP | C | 7 months | 39.0%^g^* | RT-PCR of plasma RNA
Loubser, 2006^a58^ | 53 | SD-NVP | C | 12 months | 11.0%^g^* | RT-PCR of plasma RNA
Loubser, 2006^a58^ | 44 | SD-NVP | C | 6 weeks | 52.0%^g^* | RT-PCR of mononuclear DNA
Loubser, 2006^a58^ | 48 | SD-NVP | C | 48 weeks | 4.2%^g^* | RT-PCR of mononuclear DNA
Palmer, 2005^51^ | 10 | SD-NVP | NR | 6 weeks | 50%* | standard genotyping
Palmer, 2005^51^ | 10 | SD-NVP | NR | 6 weeks | 75%^i^* | RT-PCR of plasma RNA
Palmer, 2005^51^ | 22 | SD-NVP & ZDV+3TC^b^ | NR | 6 weeks | 0%* | standard genotyping
Palmer, 2005^51^ | 22 | SD-NVP & ZDV+3TC^b^ | NR | 6 weeks | 27%^i^* | RT-PCR of plasma RNA
Troyer, 2005^60^ | 71^c^ | NVP | A^e^ | 6 weeks | 16%* | standard genotyping
Troyer, 2005^60^ | 71^c^ | NVP | A^e^ | 6 weeks | 50%^i^* | Oligonucleotide DNA ligation assay
Troyer, 2005^51^ | 56^d^ | ZDV | A^e^ | 6 weeks | 0%** | standard genotyping
Troyer, 2005^60^ | 56^d^ | ZDV | A^e^ | 6 weeks | 0%^j^** | Oligonucleotide DNA ligation assay
Johnson JA, 2005^f13^ | 50 | SD-NVP | C | 7 weeks | 20%*^g^ | standard genotyping
Johnson JA, 2005^f13^ | 50 | SD-NVP | C | 7 weeks | 52%*^g^ | RT-PCR of plasma RNA
Perez, 2006^65^ | 20 | ZDV/3TC/NVP | B/F^h^ | 3 months | 0%*^g^ | standard genotyping
Perez, 2006^65^ | 20 | ZDV/3TC/NVP | B/F^h^ | 3 months | 15%*^g^ | RT-PCR of plasma RNA
Eshleman, 2005^49^ | 65 | SD-NVP | C | 6 – 8 weeks | 69.2%* | standard genotyping
Eshleman, 2005^49^ | 97 | SD-NVP | D | 6 – 8 weeks | 36.1%* | standard genotyping
Eshleman, 2005^49^ | 144 | SD-NVP | A | 6 – 8 weeks | 19.4%* | standard genotyping
Flys, 2006^110^ | 63 | SD-NVP | C | 6 – 8 weeks | 69.8%* | Lig Amp assay
Flys, 2006^110^ | 94 | SD-NVP | D | 6 – 8 weeks | 54.3%* | Lig Amp assay
Flys, 2006^110^ | 144 | SD-NVP | A | 6 – 8 weeks | 41.7%* | Lig Amp assay

* NNRTI resistance

** NRTI resistance

a Loubser, 2006 (AIDS 2006; 20:995–1002), full publication of data in Loubser, 2005

b Patients received either 4 or 7 days of ZDV plus 3TC postpartum; substudy of McIntyre, 2005

c 61 mothers + 10 infected children

d 48 mothers + 8 infected children

e 23% of patients were infected by HIV-1 clades D, 3% by clade C and 15% by recombinants

f Substudy of Martinson, 2004

g Detection of K103N resistance mutation only

h 4 persons infected by clade B virus

i Detection of K103N or Y181C resistance mutations

j Detection of K70R resistance mutation only

Table 12 Resistance in HIV positive infants born to mothers receiving pMTCT

Reference | Country | Clade | Regimen | Type of assessment | Resistance in HIV+ infants
Loubser, 2004^54^ | South Africa | Mostly C | SD-NVP | Genotypic sequence-based mechanism | 36% NNRTI resistant at 6 weeks
Gordon, 2004^57^ | South Africa | C | SD-NVP | Genotypic sequence-based mechanism | 40% NNRTI resistant at 6 weeks
Martinson, 2004 & Morris, 2004^52^ | South Africa | Mostly C | SD-NVP | Genotypic other; Genotypic sequence-based mechanism | 42% NNRTI resistant at 7 weeks; 65% of a subgroup resistant at 6 months
Troyer, 2005^60^ | Uganda | A, C, D, recombinants | ZDV | Genotypic other, Radio labeled oligonuc. DNA ligation | No resistance at 6 weeks*
| | A, C, D, recombinants | SD-NVP | Genotypic other, Radio labeled oligonuc. DNA ligation | 50% NNRTI resistant at 6 weeks*
Chaix, 2004^69^ | Ivory Coast | NR | ZDV + SD-NVP | Genotypic sequence-based mechanism | 23% NRTI resistant at 4 weeks
McIntyre, 2005^50^ | South Africa | NR | SD-NVP | Genotypic sequence-based mechanism | 78% NRTI resistant at 6 weeks
| | NR | SD-NVP + 4 days ZDV+3TC | Genotypic sequence-based mechanism | 13% NRTI resistant at 6 weeks
| | NR | SD-NVP + 7 days ZDV+3TC | Genotypic sequence-based mechanism | No resistance at 6 weeks
Eshleman, 2006^75^ | Malawi | NR | Infant SD-NVP IP SD-NVP | Genotypic sequence-based mechanism | 87% NNRTI resistance at 6–8 weeks
| | | Infant SD-NVP+ ZDV IP SD-NVP | Genotypic sequence-based mechanism | 57% NNRTI resistance at 6–8 weeks
| | | Infant SD-NVP No IP SD-NVP | Genotypic sequence-based mechanism | 74% NNRTI resistance at 6–8 weeks
| | | Infant SD-NVP+ ZDV No IP SD-NVP | Genotypic sequence-based mechanism | 27% NNRTI resistance at 6–8 weeks
Martinson, 2006^62^ | South Africa | NR | SD-NVP | Genotypic sequence-based mechanism | 45.2% NNRTI resistant at 4–12 weeks, only 4.2% resistant at 18 weeks

SD-NVP = Single dose Nevirapine

ZDV = Zidovudine

IP = Intrapartum

* Resistance rates for mothers and infants combined

Some of the studies also show the quantitative frequency of viruses with resistance as part of the quasispecies (closely related but non-identical mutant and recombinant viral genomes subjected to continuous genetic variation, competition, and selection; thought to be the mechanism by which RNA viruses persist).^111^ Loubser, 2006^58^ showed that the actual frequency of resistant viruses is low and decreases further over time. Twenty seven of 31 women had the K103 N mutation at 6 weeks postpartum, but the median proportion of the virus that contained the K103N variant was 11 percent. At 3 months, in women who still had detectable resistance, the frequency was 6 percent; at 7 months, frequency was 1.2 percent; and at 12 months, the frequency was 0.7 percent. Thus, it is likely that time following SD-NVP exposure is very important in determining response to additional ARV therapy.

Resistance in HIV-positive infants born to mothers receiving pMTCT. Children are often born HIV positive despite pMTCT. Resistant viruses can be transmitted or can emerge independently in either mother or infant. Eight studies^50,^ ^54,^ ^55,^ ^57,^ ^60,^ ^62,^ ^69,^ ^75^ evaluated the emergence of ARV resistance in children born to mothers in sub-Saharan Africa who received pMTCT. Most studies examined the impact of SD-NVP. Three studies reported on participants infected by HIV clade C; one other combined data from those with clades A, D, C, and recombinant types. The other studies did not report clade.

We also found a study conducted in Thailand that reported 12-month postpartum resistance rates in children who, themselves, received ART for unspecified lengths of time.^63^ As the resistance could not be attributed to pMTCT alone, and specific pMTCT regimens were not mentioned, this study will not be discussed.

In most studies, HIV-infected infants were tested for resistance at 6 or 7 weeks of age. Rates of NNRTI resistance among untreated infants of mothers receiving only SD-NVP ranged from 36 percent to 50 percent. The most common mutations were Y181C and K103N.

Martinson^62^ showed that detectable resistance fades over time in infants exposed to SD-NVP. Of the 53 HIV-positive infants studied, 45.3 percent had NNRTI resistance at their first visit (range 4 to 12 weeks). Those with resistance were tested again every 6 months. At 18 months, only one still had the Y181C mutation.

Troyer^60^ compared resistance rates among mother-infant pairs infected with various HIV clades, who were treated with ZDV (N = 48) or SD-NVP (N = 61). The HIV transmission rates were similar in the groups: 16.4 percent and 16.7 percent respectively. Using a sensitive assay for ARV resistance (oligonucleotide DNA ligation assay) at 6 weeks, NNRTI mutations were found in half of the infected pairs who received SD-NVP. ZDV mutations were not present in pairs treated with that drug. Resistance data for mothers and infants were not presented separately.

Chaix^69^ gave mothers ZDV (300mg) twice daily starting at 36 weeks gestation in addition to oral SD-NVP at onset of labor. Only 23 percent of their HIV-positive children were resistant to NRTIs at 4 weeks postpartum. McIntyre^50^ compared resistance among infants who received SD-NVP with those who received SD-NVP plus either 4 or 7 days of ZDV + 3TC after birth. Infected infants who received the additional 7-day ZDV + 3TC showed no resistance at 6 weeks, compared to 78 percent of those who received SD-NVP only.

Finally, Eshleman^75^ recently compared resistance rates in infants who received various combinations of intrapartum SD-NVP, SD-NVP (2 mg/kg) immediately postpartum, and ZDV (4 mg/kg) twice daily for one week. At 6 to 8 weeks, the rate of resistance was much lower (27 percent) in the infants who received the postpartum SD-NVP and ZDVwithout the intrapartum SD-NVP. The Eshleman study also showed that when the infant received ZDV, the transmission rate did not differ between mothers who received SD-NVP and those who did not. When the baby received SD-NVP plus one week of ZDV and the mother got SD-NVP, transmission was 17 percent and resistance was seen in 74 percent; when the baby got SD-NVP plus 1 week of ZDV and the mother did not get SD-NVP, transmission was 17 percent but resistance was only 27 percent. Data from the MASHI trial also suggest that when the infant receives SD-NVP at birth in the background of ZDV, maternal SD NVP does not provide any additional protection.^72^ As mentioned earlier in this report, Shapiro^71^ randomized pregnant women on ZDV-based treatment to either SD-NVP or placebo at birth; the difference in HIV MTCT between the SD-NVP and placebo groups was insignificant at one month.

These findings imply that research should be conducted into the need for maternal SD-NVP when an infant gets NVP at birth, or when the mother receives ZDV regularly before birth.

Predictors of resistance. Several studies evaluated the predictors of ARV resistance among persons receiving SD-NVP. In the most comprehensive analysis, a multivariate analysis performed by Eshleman and colleagues demonstrated an increased risk of resistance detectable by standard genotyping assays in persons infected with clade C vs. clade A or clade D, or increased viral load at delivery, but not with increased age or number of births.^49^ Similarly, Loubser found that an increased viral load was associated with an increased rate of resistance.^54^ Jourdain also showed that plasma HIV RNA level was predictive of likelihood of ARV failure and NPV resistance.^64^

Chaix and colleagues found that increased duration of prepartum use of ZDV+3TC for pMTCT was associated with an increased maternal prevalence of the M184V resistance mutation.^76^ Another study^50^ found a decrease in the rate of NNRTI resistance with longer duration of ZDV+3TC post-partum. In both studies, SD-NVP was given during birth.

The role of adherence in resistance is discussed in the next section.

## Adherence and Health Service Issues

Adherence to HIV treatment has long been associated with treatment outcomes. Most studies in the developed world have found evidence that at very low levels of adherence, there is insufficient selective pressure for mutations to evolve. At high levels of adherence, viral replication, and thus, viral evolution, should be stopped. Recently, Bangsberg^112^ has suggested that the relationship between adherence and resistance differs for the three drug classes (NNRTI, NRTI, and PI). He also suggests that the different half-lives of medications play a significant role (in regard to mutations) when combination therapy is discontinued or interrupted. Thus, health service issues such as unreliable delivery, low stock, and financial constraints are important concerns in the development of ARV resistance in developing regions.

We found three studies that assessed the impact of treatment interruptions on ARV resistance in the developing world; two of these took place in Kampala, Uganda.^77^ ^78^ We also found another African study that assessed the relationship between adherence and the presence of resistance in selected populations.^79^ We found one additional study from the UK that studied black African children with non-clade B virus. Of critical importance, unlike many studies conducted in the developed world, the latter studies were not initially designed or powered to assess the relationship between adherence and resistance.

The first study of treatment interruption included patients attending the HIV clinic at Mulago Hospital, Kampala, from August to December 2003. All patients received a three-drug regimen; most included NVP (77 percent) or efavirenz (14 percent). At a median of 38 weeks, 91 of the 137 patients had undetectable viral loads. Of the 137 patients, 32 experienced an unplanned treatment interruption of more than 4 days. In multivariate analysis, this treatment interruption was statistically associated with virologic failure, as was being treatment-naïve at study entry. The most common reasons for treatment interruption were lack of money to buy medications (63 percent) and toxicity/illness (31 percent). Of the 137 patients, 11 percent reported that, despite having money to buy medications, the medications were sometimes unavailable.

Genotypic and phenotypic data were available from 36 of these patients with detectable viral load. Of these patients, 26 were resistant to NNRTIs; the most common mutation was K103N. NRTI resistance was measured in 23 patients, due to the M184V/I mutation.

The second study in Kampala was a 24-week prospective observational study conducted between September, 2002 and April, 2004. Participants were recruited from pharmacies; they were on a generic fix-dosed combination, including NVP, lamivudine, and stavudine. Adherence was assessed through interviews, electronic medical monitors (EMMs), and unannounced visits to count pills. Treatment interruption was failing to open the EMM for at least 48 hours. Genotypic tests were conducted at 24 weeks. Adherence was good (82 percent – 95 percent) but declined significantly over time. At 24 weeks, 62 (65 percent) of the 95 participants with continuous EMM data had experienced at least one treatment interruption. Of the 33 participants without treatment interruption, none had drug resistance, compared to eight of the 62 participants who did have interruption. The most common mutation was Y181C.

A UNAIDS clinic in the Ivory Coast tested all ARV treatment patients who had a rebound in plasma viral load between August, 1998, and April 1, 2000.^79^ Of these 97 patients, 86 had usable sequences. Thirty eight percent of the patients were female; the majority (89 percent) had A/G recombinant viruses. The rest were clade A, except for one clade G patient. Of the 86 patients, 84 percent had received 2 drug therapies, and 15 percent had received 3 drug therapies that included a PI or NNRTI. Forty percent of the patients had interrupted therapy for at least one day prior to resistance testing; the mean number of days interrupted was 36. Fifteen percent had switched drug regimens. Fifty percent reported missing a least one dose; the mean number of pills missed was six.

Seventy-nine percent of the 86 patients had genotypic resistance to at least one NRTI, NNRTI, or PI. Phenotypic resistance testing was conducted in 80 patients. Of these, 56 percent were resistant to at least one NRTI, 10 percent were resistant to at least one NNRTI, and 1.3 percent were resistant to PIs. The authors conducted a logistic regression analysis of factors associated with drug resistance in patients with rebound in viral load, by comparing the 80 patients with phenotypic and genotypic resistance to the 6 patients without evidence of resistance. The logistic model included variables for age group, gender, and various treatment characteristics. The variable “skipped pills” was not associated with resistance (adjusted OR = 0.7, 95 percent CI 0.1 to 6.2). Likewise, “interrupt therapy ≥ 1 day” was not associated with resistance (adjusted OR = 0.3, 95 percent CI 0.1 to 2.9). The only variables associated with resistance were “use of dual therapy”(adjusted OR = 9.7, 95 percent CI 1.2–81.6) and the patient's maximum initial plasma viral load response, measured at 30 days (adjusted OR = 2.8, 95 percent CI 1.3–5.9). Given the small sample, confidence intervals are very wide, precluding conclusions about the relationship between adherence and resistance.

In another study, researchers tested 80 patients enrolled in an initiative for access to ARV in Senegal^113^ between August, 1988 and February, 2001. The method of selection of these 80 patients (almost equally split by gender) was not reported, except that patients had to have a biological follow-up of at least 6 months. The report also did not describe the degree to which these 80 patients represented the larger population of Senegalese with HIV. Among the patients studied, 68 were treatment-naïve at baseline. HIV clades were primarily recombinant forms. Of the patients, 66 received HAART and 14 received dual therapy. Median length of treatment at resistance testing was 18.4 months for those who were treatment-naïve at baseline and 30.0 months for those who were treatment-experienced. Thirteen of the 80 patients were resistant to at least one NRTI, NNRTI, or PI. In bivariate analyses, the average monthly adherence for previously treatment- naïve patients did not differ significantly between resistant (n=8, 96.5 percent) and non-resistant patients (n=60, 96.0 percent). In patients with prior ARV, adherence was 99.7 percent in both resistant (n=5) and nonresistant patients (n=7). In addition, adverse events that may cause adherence difficulties did not differ. Resistance also did not differ by gender, age, viral load, body mass index, or length of follow-up. Because of the small sample, no strong conclusions can be drawn.

Researchers assessed the association between adherence and drug resistance in 26 children from a clinic in south London who had experienced virological failure between January, 1996, and June, 2000.^80^ These 26 patients were selected from 34 children who experienced one or more virologic failures during this same time and were part of a group of 105 HIV-1 infected children identified in South London. Twenty-four of the children were black African; 23 were infected with a non-B clade virus. Physicians reviewed medical records and estimated adherence for the six-month period prior to the onset of treatment failure. Adherence was categorized as good (>90 percent), intermediate (80–90 percent), or poor (<80 percent).

HIV RNA sequence data were available for 21 of 26 children at treatment failure. Thirty three percent had resistance to PIs; 90 percent had RT mutations. Genotypic resistance was detected in ten of the eleven children who were treated with lamivudine, six of eight treated with NVP, and seven of eleven treated with ZDV. All children whose adherence was classified as good or intermediate had resistance, compared with five of eight children whose adherence was poor.

In summary, we identified few studies originally designed to assess the effect of health services delivery factors or medication adherence on the development of resistance in patients in developing countries. Results were mixed. Where possible, future research projects on adherence should measure resistance in addition to routinely collected data such as CD4 count and viral load.