# Introduction

The clinical management of HIV infection has been greatly improved by the use of highly active antiretroviral (ARV ) therapy (HAART)^1^ HAART comprises the following classes of agents: nucleoside or nucleotide reverse transcriptase inhibitors (NRTIs), non-nucleoside reverse transcriptase inhibitors (NNRTIs), protease inhibitors (PIs), and fusion inhibitors. The clinical effectiveness of these therapies is mediated by treatment-induced reduction of HIV viral replication as demonstrated by measurements of the amount of HIV RNA in the blood (the plasma viral load). In turn, successful suppression of HIV replication is influenced by the intrinsic potency of the prescribed regimen, patient adherence to treatment, and pre-existing or emerging resistance to ARV agents.^2^

Resistance of HIV to ARV agents was first reported within 2 years of the approval of the NRTI zidovudine (ZDV) for the treatment of persons with late-stage HIV infection.^3^ Subsequently, transmission of a ZDV-resistant isolate was first reported 1992.^4^ The development of ARV resistance has since been reported with all other commercially available ARV agents within all classes.^5^ Because drug resistance mutations often decrease the activity of many ARV agents within an individual class, the emergence of a single major resistance mutation, e.g., the NRTI mutations M184V^*^ or T215Y, the NNRTI mutation K103N, or any of a number of major PI mutations, can have important effects on a patient's response to multiple ARV agents.^5^ Thus, assessment of the proportion of HIV-infected persons who have developed ARV resistance and characterization of the causes and factors associated with resistance development are critical steps in modifying treatment guidelines and regimens to improve their effectiveness.

* M184V refers to a mutation that results in the replacement of the amino acid methionine (M) with valine (V) at position 184. The one-letter amino acid abbreviations are as follows: A=alanine, C=cysteine, E=glutamic acid; G=glycine, I=isoleucine, K=lysine, L=leucine, M=methionine, N=asparagine, P=proline, V=valine, Y=tyrosine.

The emergence of mutations that confer resistance to ARV therapy is an expected consequence of the high rates of viral replication and the inherent error rate of the reverse transcription of single-stranded RNA viruses such as HIV.^7^ Because these mutations can decrease the growth rate or replication capacity of HIV,^81^ some drug-resistant viral strains do not compete successfully with wild-type virus in the absence of ARV therapy or the emergence of other compensatory mutations.^7^ However, whereas this phenomenon of decreased replication capacity has been demonstrated with some specific resistance mutations (e.g., K65R and M184V), other mutations such as the K103N mutations produce little if any impact on viral replication.^82^

In contrast, if non-suppressive antiretroviral therapy is administered, emergent resistant viruses are selected as the most replication capable (fit) virus and quickly predominate.^83^ In addition, prolonged non-suppressive ARV therapy may eventually select for the emergence of further compensatory mutations that increase fitness of resistant virus such that they compete successfully with wild-type virus even if ARV therapy is withdrawn. However, if ARV therapy is withdrawn prior to the emergence of compensatory mutations, overgrowth of more rapidly replicating wild-type viruses leads to subsidence of detectable resistant virus in the bloodstream within 4 to 6 weeks.^84^ Even so, resistant virus persists at low levels and/or in latently infected cells^85,^ ^86^ and may later re-emerge, often leading to the failure of subsequent therapeutic regimens.^87^ This phenomenon of re-emergence of drug resistance from cellular reservoirs has been best described in persons who have received prolonged courses of ARV therapy. Whether resistance that emerges after brief exposure (e.g., single-dose (SD) nevirapine (NVP) for preventing mother-to-child transmission (pMTCT) of HIV) has the same implications for the success of subsequent ARV therapy is less certain.^88^

The plasma viral load directly correlates with the amount of viral replication and therefore serves as an indirect measure of the potential mutational rate of HIV and thus of the potential rate of acquisition of ARV resistance mutations. While any residual HIV replication during treatment may allow for continued viral evolution, the emergence of ARV resistance is unusual in persons who have isolated plasma viral loads no higher than 50 – 200 HIV RNA copies/mL.^8,^ ^9^ In contrast, failure to achieve intakes of HAART that are sufficient to maintain a plasma viral load of less than approximately 400 – 1,000 copies/mL is associated with an increased risk for developing ARV resistance.^6,^ ^7^ While patients may derive immunological and clinical benefit from a treatment regimen that does not fully suppress viral replication,^8^ such patients remain at substantial risk for the eventual emergence of drug resistance mutations.^89^

The observation of resistance in treatment-naïve individuals raises the question of when resistance testing should be conducted. This question is informed, at least in part, by the rate at which resistant virus is overgrown by wild-type virus. Because of the frequent, rapid subsidence of resistance when therapy is withdrawn, expert groups recommend that resistance testing should be done while patients are on therapy or shortly after the discontinuation of therapy,^2,^ ^10^ as testing can detect more mutations during this interval. In treatment-naïve patients or persons who have long since discontinued ARV therapy, resistance testing retains specificity but has decreased sensitivity. Nevertheless, the high rate of transmitted resistance has led to recommendations for testing chronically infected treatment-naïve persons.

## Frequency of ARV Resistance

Virological treatment failure, and hence the emergence of ARV resistance, was particularly common in persons who received mono- or dual- drug therapy prior to the use of HAART regimens that included NNRTIs and PIs.^14^ As a consequence of prior inadequate therapy, the relatively poor potency of early HAART regimens, and poor adherence related to the complexity of dosing regimens and the frequency of adverse side effects, it was estimated that 50 percent of infected individuals who were receiving care for HIV infection in the United States (U.S.) in 1999 had some evidence of ARV resistance.^15^ More recently, despite the development of new ARV agents with unique profiles of resistance mutations and regimens with less complex dosing and fewer side effects,^2,^ ^10^ ARV resistance remains a serious problem for HIV-infected patients.^16,^ ^17^ Furthermore, up to 10 percent of newly infected, treatment-naive individuals in the developed world are found to be infected by relatively fit, resistant virus that persists in the absence of treatment.^18^

## Determination of ARV Resistance

The development of ARV resistance can be determined by the use of either genotypic or phenotypic assays.^2,^ ^10^ Genotypic testing assesses the viral genome for mutations in the genes that encode reverse transcriptase or protease; phenotypic testing assesses the ability of the virus to replicate in the presence of the drug in question. Both assays can be applied to virus obtained from any tissue, but for routine clinical purposes, the assays are used to characterize HIV in plasma specimens. Both tests are relatively insensitive for the detection of resistant viral variants (or quasispecies) that account for less than 20 percent of the circulating virus population in plasma, and neither assay detects intracellular, archival virus (virus that remains in a dormant state).^6^ In contrast, by the use of specific genetic probes and allele-specific real time polymerase chain reaction (PCR, a method used to amplify genetic material for sequencing or assaying), it is possible to detect viral subpopulations that constitute as little as 0.1 to 0.2 percent of circulating virus in plasma.^12,^ ^13^

In clinically used genotypic assays, the sequences of the HIV-1 reverse transcriptase and protease genes are reverse-transcribed, and the resultant cloned DNA (cDNA) amplified and sequenced or otherwise assayed for known mutant sequences and compared to a list of mutations that have been associated with ARV resistance. An interpretive algorithm is then used to determine whether the identified mutations are likely to lead to decreased effectiveness of (i.e., resistance to) specific ARV agents. Interpretation of genotypic assays depends upon assessment of the probability that a given mutation pattern confers resistance to one or several specific ARV drugs.^6^ Despite agreement regarding the significance of most individual mutations, experts continue to show some disagreement in the interpretation of genotypes.^11^ Numerous schemes have been developed for interpreting HIV resistance genotypes. Since these schemes differ in how evidence regarding resistance is interpreted, in how interactions between mutations are weighted, and in the frequency with which they are revised in the light of new scientific evidence, it is not surprising that some of these schemes predict the phenotypic response to treatment substantially better than do others.^90^

Although the interpretation of phenotypic HIV resistance tests is straightforward compared with that of genotypic tests, these assays are considerably more expensive, and their clinical utility is less well validated by clinical trials.^6^ Phenotypic susceptibility assays report the drug concentration necessary to inhibit viral replication in vitro by 50 percent, the Inhibitory Concentration(IC)_50_. Traditionally, phenotypic assays for HIV drug susceptibility have required the preparation of a high-titer viral stock in tissue culture, followed by infection of a second culture and determination of the inhibitory effect of the agents in question. Such multistage assays are not only time-consuming and expensive, but the resultant values suffer from relatively poor inter-laboratory reproducibility.^91^ More rapid and reproducible viral phenotypic assays have been developed using recombinant DNA technology. In one such assay, the reverse transcriptase and HIV protease genes of a target virus are cloned and recombined with a laboratory HIV DNA clone from which the the reverse transcriptase and protease genes have been deleted. Another assay uses luciferase indicator genes to track the expression of genes that have conferred resistance.^92,^ ^93^

HIV gene mutations may be classified as primary or secondary. Primary mutations alter the binding of a drug to its target, resulting in increased amounts of medications necessary to inhibit the target enzyme. Secondary mutations increase the level of resistance by improving the fitness of the virus carrying the primary mutations. Often, secondary mutations have little or no effect on the level of resistance in the absence of primary mutations. Other genetic variations, called polymorphisms, are found frequently in untreated HIV positive populations in the developing world. A polymorphism is a form of genetic variation (specifically a discontinuous variation), which occurs in an animal species in which distinct forms exist together in the same population. (The human blood groups are examples of a polymorphism.) The interpretation of these naturally-occurring polymorphisms, usually found in HIV protease, is difficult. Generally, these variations are not primary mutations which confer significant resistance, but may be secondary mutations which could contribute to resistance or improve the fitness of resistant virus.

The purpose of this report is to review and synthesize the literature that describes the overall prevalence of ARV resistance throughout the world. We have emphasized studies conducted since 2000 and have particularly sought out studies in the developing world that address resistance in non-clade B virus (a clade is a group of organisms believed to originate from a single common ancestor; clade B viruses are that subtype of virus that is more common outside of the North America and Western Europe). According to the recommendations of the International AIDS Society,^6^ evaluating susceptibility patterns among non-clade B persons should be a high priority because these viruses are by far the most prevalent worldwide. The first part of our report focuses on treatment-naïve populations in developing regions. The second focuses on the consequences of pMTCT regimens. Studies of pMTCT are particularly noteworthy, because they represent one of the most common uses of non-suppressive regimens of HAART. A third section reviews the few studies that report both adherence and resistance data.

In these analyses, we examine whether the prevalence of resistance differs between adults and children, between men and women, and between groups with differing modes of transmission. We report factors associated with the development of resistance and how these factors differ among varying population groups. Factors of particular concern included viral clades (especially in the context of pMTCT studies in the developing world), region, treatment regimen, adherence, and host factors such as gender and mode of transmission.