# Appendix E. Rejected Titles

## Reject: At Abstract

1 Continuously effective and well tolerated primary HIV therapy: Lopinavir/r - No resistance after 5 years Original>Anhaltend Wirksame Und Vertragliche Hiv-Ersttherapie: Auch Nach Funf Jahren Keine Resistenz. MMW-Fortschr Med. 2003 Dec; 145(50):60-61. Rec #: 1419
2 Drug-resistant HIV increasingly prevalent in US. Infections in Medicine. 2002; 19(2):50. Rec #: 1403
3 HIV cross-resistance to saquinavir is less frequent, slower to develop than other proteinase inhibitors. Formulary. 1995; ISSN: 0098-6909. Rec #: 1508
4 HIV drug resistance is on the increase. Pharmaceutical Journal. 2003 Nov; 271(7273):604. Rec #: 1426
5 HIV resistance to kaletra seen to be very rare. Clin Infect Dis. 2004 Aug; 39(4):iv. Rec #: 1429
6 Justified hope after four years: First antiretroviral therapy still without resistance Original>Berechtigte Hoffnung Nach Vier Jahren: Ersttherapie Immer Noch Ohne Resistenzen. MMW-Fortschr Med. 2003; 145(SUPPL. 1):48-49. Rec #: 1430
7 Zidovudine resistance among HIV infected children: Association with advanced disease. Canadian Journal of Infectious Diseases. 2001; 12(2):113-114. Rec #: 1414
8 Bacheler LT, Anton ED, Kudish P, et al. Impact of baseline NNRTI Resistance on the efficacy of efavirenz combination therapy in NNRTI therapy-naive patients (study DMP 266-006). Antivir Ther. 2000;5(suppl 3):70. Rec #: 1568.
9 Bennett, D. E.; Zaidi, I. F.; Heneine, W., and et al. Prevalence of mutations associated with antiretroviral drug resistance among men and women newly diagnosed with HIV in 10 US cities, 1997-2001. Antivir Ther. 2003; 8(S133). Rec #: 2099
10 Berstein, B. and Kepf, D. Comparison of emergence of resistance in a blinded phase III study with kaletra (lopinavir/ritonavir) or nelfinavir plus d4t/3tc from web 24 through week 96. 41st Interscience Conference on Antimicrobial Agents and Chemotherapy; Chicago. 2001. Rec #: 1537
11 Boucher, C. A. B. Cohen Stuart J. W. T. (C.A.B. Boucher, Eijkman-Winkler Instituut, Academisch Ziekenhuis Utrecht, Heidelberglaan 100, 3584 CX Utrecht. Netherlands). The value of HIV resistance determination for the hospital: Not all resistances are alike: <ORIGINAL> De waarde van HIV-resistentiebepalingen voor de kliniek: de ene resistentie is de andere niet. Pharmaceutisch Weekblad. 1998 Apr 3; ISSN: 0031-6911. Rec #: 1501
12 Boyle BA. A new epidemic: The rising rates of high-risk behavior and transmission of drug-resistant HIV. AIDS Reader. 2001;11(3):114-118. Rec #: 1409.
13 Cabrera C, Clotet B. [Mutations resulting in resistence of antiretroviral drugs in HIV-infected patients]. Med Clin (Barc). Apr 30. 2005;124(16):618-9. Rec #: 1448. [pmid: 15871779].
14 Cain, P. and et al. RT and protease sequences from heavily treated patient s referred to a reference lab in the UK. 1999. Rec #: 1636
15 Calvez V, Delaugerre C, Rohban R, et al. Resistance profile and cross-resistance of HIV-1 among 102 patients failing a non-nucleoside reverse transcriptase inhibitor-containing regimen [abstract 122]. Antivir Ther. 2000;5(suppl 3):97. Rec #: 1570.
16 Clavel F. Resistance to HIV protease inhibitors Original>Resistance Du Vih Aux Inhibiteurs De Protease. Virologie. 2001;5(SPEC. ISS. DEC.):S19-S28. Rec #: 1437.
17 Cohen C, Keisser H, Hunt S, et al. Phenotypic resistance testing significantly improves response to therapy: final analysis of a randomised trial (VIRA3001). Antivir Ther. 2000;5:67-8. Rec #: 1575.
18 Colonno RJ, Friborg J, Rose RE, et al. Identification of amino acid substituions correlated with reduced atazanavir susceptibility in patients treated with atazanavir-containing regimens [abstract 4]. Antivir Ther. 2002;7:S4. Rec #: 1587.
19 Dalmau D, Ochoa de Echaguen A, Martinez E, et al. NEFA simplification trial: patterns of resistance mutations among patients with virological failure. Antivir Ther. 2002;7:S113. Rec #: 1581.
20 De, Clercq E. (E. De Clercq, Rega Institute Medical Research, Katholieke Universiteit, Munderbroedersstraat 10, B-3000 Leuven. Belgium). Development of resistance of human immunodeficiency virus (HIV) to anti-HIV agents: How to prevent the problem? International Journal of Antimicrobial Agents. 1997; ISSN: 0924-8579. Rec #: 1505
21 de Jong JJ, Jurriaans S, Coutinho RA, de Wolf F, Goudsmit J. [Zidovudine-resistant HIV strains in untreated intravenous drug users and homosexual men in Amsterdam infected in 1996]. Ned Tijdschr Geneeskd. Oct 18. 1997;141(42):2030-1. Rec #: 1296. [pmid: 9550757].
22 De Meyer, S. ; Van Marck, H.; Van De Bulcke, T.; Vingerhoets, J.; Azin, H.; Pauwels, R., and et al. Phenotypic and genotypic profiling of TMC 114 a potent next-generation PI, against some 1600 recent PI-resistant clinical isolates. 11th Conference On Retroviruses And Opportunistic Infections; San Francisco. 2004. Rec #: 1566
23 De Meyer, S. ; Van Marck, H.; Veldeman, J.; McKenna, P.; Pauwels, R., and Bethune, M. P. Antiviral Activity of TMC114 , a potent next-genreation PI, against > 4000 recent recombinant clinical isolates exhibiting a wide range of (PI) resitance profiles. 12th International HIV Drug Resistance Workshop; Cabo San Lucas, Mexico. 2003. Rec #: 1567
24 Funk MB, Linde R, Wintergerst U, Schuster T, Notheis G, Sturmer M, Kurowski M, Klingebiel T, Kreuz W. Benefit, resistance and compliance in HIV-infected children on an inital antiretroviral triple therapy for a period of two years Original>Wirksamkeit, Resistenzentwicklung Und Compliance Bei Hiv-Infizierten Kindern Unter Einer 2-Jahrigen, Primaren Antiretroviralen 3fach-Therapie. Monatsschrift Fur Kinderheilkunde. 2002;150(9):1087-1094. Rec #: 1417.
25 Grandadam M, Nicand E, Koeck JL, Caron M, Teyssou R. Resistance of African human immunodeficiency virus to active antiretroviral treatment: Need for virological surveillance Original>Etat De La Resistance Des Souches De Vih-1 En Afrique: Quelle Place Pour Les Reseaux De Surveillance Virologique. Medecine Tropicale. 2002;62(1):89-93. Rec #: 1435. [pmid: 12038188].
26 Harrigan PR, Verbiest W, Larder B, et al. Impact of moderate decreases in baseline NNRTI susceptibility on response to antiretoviral therapy [abstract 86]. Antivir Ther. 2000;5(suppl 3):68-69. Rec #: 1569.
27 Haubrich, R. ; Hellmann, N.; Keiser, P., and et al. The clinical relevance of non-nucleoside reverse transcriptase inhibitor hypersusceptibility: a prospective cohort analysis [abstract ThOrB1388]. XIV International AIDS Conference; Barcelona. Barcelona: Prous Science, S.A.; 2002: 377. Rec #: 1584
28 Haubrich R, Keiser P, Lie YS, Leedom J, Richman D, McCutchan JA, et al. CCTG 575: A randomized, prospective study of phenotype testing versus standard of care for patients failing antiretroviral therapy [Abstract 80]. Antivir Ther. 2001;6(Supl. 1):63-71. Rec #: 1548. [pmid: 11417763].
29 Hofmann-Assmus M. Long-term HIV therapy without resistance development Original>Hiv: Langzeitwirkung Ohne Resistenzbildung. Pharmazeutische Zeitung. Dec. 2004;149(50):40. Rec #: 1431.
30 Howard, A.; Arnsten, J.; Gardner, L., and et al. Lack of multidrug resistance in nonresponders to antiretroviral therapy with poor adherence. 1st International AIDS Society Conference on HIV Pathogenesis and Treatment; Buenos Aires. International AIDS Society, Stockholm, Sweden; 2002. Rec #: 1572
31 Hsu, A.; Kempf, D.; Granneman, R., and et al. Exploring theorical mechanisms for lack of resistance to lopinavir/ritonavir and antiretroviral naive subjects [abstract 436-W]. 9th Conference on Retroviruses and Opportunistic InfectionsAlexandria, VA: Foundation for Retrovirology and Human Health; 2002: 217. Rec #: 1586
32 Kemp SD, Salim M, Stammers D, et al. A mutation in HIV-1 reverse transcriptase at codon 318 (Y-F) confers high-level non-nucleoside reverse transcriptase inhibitor resistance in clinical samples. Antivir Ther. 2001;6(suppl):44. Rec #: 1571.
33 King M, Brun S, Tschampes J, et al. Exploring the effects of adherence on resistance: use of local linear regression to reveal relationships between adherence and resistance in antiretroviral-naive patients treated with lopinavir/ritonavir or nelfinavir. Antivir Ther. 2003;8:S118. Rec #: 1541.
34 Kubisch U. HIV infection: Combined protease inhibitors against resistance development Original>Kombinierte Proteasehemmer Gegen Resistenzentwicklung. Deutsche Apotheker Zeitung. Mar. 2001;141(9):32-35. Rec #: 1427.
35 Kuritzkes, D. R. (D.R. Kuritzkes, UCHSC). HIV resistance to current therapies. Antivir Ther. 1997; ISSN: 1359-6535. Rec #: 1503
36 Labayru C, Hernandez B, Eiros JM, Ortega M, Castrodeza J, Ortiz de Lejarazu R, Rodriguez Torres A. Genotypic resistance of human immunodeficiency virus in patients with virologic failure. Medicina Clinica. Jul. 2002;119(6):201-205. Rec #: 1423. [pmid: 12200006].
37 Leigh, Brown A. J. Richman D. D. (A.J. Leigh Brown, Centre for HIV Research, Inst. Cell, Animal/Pop. Biology, University of Edinburgh ). HIV-1: Gambling on the evolution of drug resistance? Nat Med. 1997; ISSN: 1078-8956. Rec #: 1504
38 Masquelier B, Raffi F, Droz C, et al. Assessment of virological failures in HIV-1 infected patients initiating a first-line PI-containing regimen (APROCO-ANRS EP11 study). Antivir Ther. 2001;6(1):S19-20. Rec #: 1908.
39 Mayers, D. Both antiretroviral drug levels and drug resistance are associated with short-term virologic responses to subsequent drug regimens in Cpcra 046 (Gart Study). 1st International AIDS Society Conference on HIV Pathogenesis and Treatment ; Buenos Aires. 2001. Rec #: 1534
40 McCallister S, Neubacher D, Verbiest W, et al. Susceptibility profile of tipranavir at baseline and subsequent virologic response in a cohort of patients with multiple-PI failure. Antivir Ther. 2002;7:S105. Rec #: 1589.
41 Mellors, J.; Vaida, F.; Bennet, K., and et al. Efavirenz hypersusceptibility improves virologic response to multidrug salvage regimens in ACTG 398 [abstract 45]. 9th conference on Retroviruses and Opportunistic Infections; Seattle. Alexandria, VA: Foundation for Retrovirology and Human Health; 2002: 69. Rec #: 1585
42 Miller, S. Antiretroviral resistance: Highlights from the XV International AIDS Conference, Bangkok, 11-16 July 2004. Southern African Journal of HIV Medicine. 2004; -(16):23-25. Rec #: 1415
43 Miralles, G. ; Lalezari, J.; Bellos, N.; Richmond, G.; Zhang, Y.; Murchison, H., and et al. T-1249 demostrates potent antiviral activity over 10-day dosing in most patients who have failed a regimen containing enfuvirtide: planned interim analysis of T1249-102, a phase I/II study. 10th Conference on Retroviruses and Opportunistic INfections; Boston. 2003. Rec #: 1513
44 Morand-Joubert L. Phenotypic and genotypic resistance patterns in subjects treated with didanosine and stavudine Original>Etude De La Resistance Phenotypique Et Genotypique Au Cours De L'association D4t/Ddl. Virologie. 2000;4(5):427-428. Rec #: 1410.
45 Mugavero MJ, Hicks CB. HIV resistance and the effectiveness of combination antiretroviral treatment. Drug Discovery Today: Therapeutic Strategies. 2004;1(4):529-535. Rec #: 1428.
46 Obry, V.; Race, E.; Bray, M.; Meynard, J. L.; Monrad-Joubett, L.; Descamps, D., and et al. Hypersusceptibility to protease inhibitors associated with mutated proteases at codons and 88 in treated patients. Program and Abstracts of the th Conference on Retrovirus and Opportunistic Infections; Seattle. 2002. Rec #: 1523
47 Oette M, Kaiser R, Haussinger D. The epidemiology of HIV-resistance Original>Hiv-Resistenz: Eher Die Regel Als Die Ausnahme. MMW-Fortschr Med. 2003;145(SUPPL. 1):58-61. Rec #: 1404.
48 Opravil M, Yerly S, Stazewsky S, et al. Prior treatment with mono or dual NRTIs before HAART as predictor of virologic failure in simplified abacavir-based triple NRTI regimen: results from the Simplified Maintenance Trial (SMT) and 30012. Antivir Ther. 2000;5:95-6. Rec #: 1580. [pmid: 10971862].
49 Quigg M, Rebus S, France AJ, McMenamin J, Darby G, Leigh Brown AJ. Mutations associated with zidovudine resistance in HIV-1 among recent seroconvertors. AIDS. May. 1997;11(6):835-6. Rec #: 1301. [pmid: 9143628].
50 Richman DD. Drug resistance and its implications in the management of HIV infection. Antivir Ther. 1997;2(SUPPL. 4):41-58. Rec #: 1420.
51 Roberts NA. Drug-resistance patterns of saquinavir and other HIV proteinase inhibitors. AIDS. Dec. 1995;9(Suppl 2):27-S32. Rec #: 1263.
52 Roman F, Gonzalez D, Boulme R, et al. New mutations at residue positions critical to T-20 resistance inT-20 naive patients infected with clade B HIV-1 isolates [abstract 18]. Antivir Ther. 2002;7:S14. Rec #: 1590.
53 Ross LL, Fisher R, Scarsella A, et al. Patients failing on d4T-based therapies that have developed thymidine analogue mutations; multidrug resistance or V75T mutations have reduced phenotypic susceptibility to stavudine. Antivir Ther. 2000;5:38-9. Rec #: 1578.
54 Schubert C. HIV drug resistance increases. Nat Med. 2002;8(9):941. Rec #: 1407.
55 Scott WA. The enzymatic basis for thymidine analogue resistance in HIV-1. AIDS Reviews. 2001;3:194-200. Rec #: 1511.
56 Sharma R. Antiretroviral resistanvce: Mechanisms, detection and clinical implications. J Pharm Pract. 2000;13(6):442-456. Rec #: 1416.
57 Solomon, A.; Gorry, P.; Wightman, F., and Crowe, S. M. Use of CXCR4 and alternative co-receptors by HIV is strongly associated with immunological failure in individuals infected with drug-resistant virus. In Program and Abstracts Of the 11th Conference On Retroviruses And Opportunistic Infections; San Francisco. 2004. Rec #: 1545
58 Soriano V, Dietrich U, Villalba N, Immelmann A, Gil-Aguado A, Echevarria S, Clotet B, Ocana I, Santamaria JM, Bouza E, Barona V, Gatell JM, Gonzalez-Lahoz J. Lack of emergence of genotypic resistance to stavudine after 2 years of monotherapy. AIDS. Apr. 1997;11(5):696-7. Rec #: 1303. [pmid: 9108961].
59 Tisdale M, Myers R, Randall S, Maguire M, Ait-Khaled M, Elston R, Snowden W. Resistance to the HIV protease inhibitor amprenavir in vitro and in clinical studies: A review. Clin Drug Investig. 2000;20(4):267-285. Rec #: 1438.
60 Venter, W. D. F. A critical evaluation of the South African state antiretroviral programme. South Afr J HIV Med. 2005(20):21-28. Rec #: 1401
61 Vingerhoets, S.; De Baere, I.; Azijn, H.; Van den Bulcke, T.; Mckenna, P.; Pattery, T., and et al. Antiviral activity of TMC 125 against a panel of site-directed mutants encompassing mutations in vitro and in vivo. 11th Conference On Retroviruses And Opportunistic Infections; San Francisco. 2004. Rec #: 1562
62 Weinheimer, S.; Discotto, L.; Friborg, J., and Colonno, R. Recombinant HIV Gag-pool proteins display unique 150L phenotype of selective atazanavir resistance and increased susceptibility to other PI. 11th Conference on Retroviruses And Opportunistic Infections; San Francisco. 2004. Rec #: 1563
63 Wolfe, P.; Hawley, P.; Boccia, N.; Clendennin, N.; Paradiso, L.; Shaw, T., and et al. Safety and efficacy of capravirine versus placebo in HIV-infected patients failing a NNRTI-containing regimen: results of a phase II, double blind, placebo controlled trial. 8th Conference on Retroviruses and Opportunistic Infections; Chicago. 2001. Rec #: 1561

## Rejected: Not Found

1 Flys TS, Chen S, Jones DC, et al. Quantitative analysis of HIV-1 variants with the K103N resistance mutation after single-dose nevirapine in women with HIV-1 subtypes A, C, and D. J Acquir Immune Defic Syndr. Aug 15. 2006;42(5):610-3. Rec #: 2110. [pmid: 16773030].
2 UK Drug Resistance database. HIV drug resistance in the United Kingdom. Commun Dis Rep CDR Wkly. 2003; 13:10-5. Rec #: 2100

## Antiretroviral: Rejected: First Screening - Study Design

1 Highly effective initial therapy without resistance development: Also after 6 years still successful HIV therapy Original>Hochwirksame Initiale Therapie Ohne Resistenzentwicklung: Auch Nach Sechs Jahren Noch Erfolgreiche Hiv-Therapie. MMW-Fortschr Med. 2005 Apr; 147(SUPPL. 1):54-55. Rec #: 1424
2 Resistance with short-course nevirapine. AIDS Patient Care STDS. 2005 Mar; 19(3):202. Rec #: 1012
3 Adje-Toure CA, Cheingsong R, Garcia-Lerma JG, Eholie S, Borget MY, Bouchez JM, Otten RA, Maurice C, Sassan-Morokro M, Ekpini RE, Nolan M, Chorba T, Heneine W, Nkengasong JN. Antiretroviral therapy in HIV-2-infected patients: changes in plasma viral load, CD4+ cell counts, and drug resistance profiles of patients treated in Abidjan, Cote d'Ivoire. AIDS. Jul. 2003;17(Suppl 3):S49-54. Rec #: 1086. [pmid: 14565609].
4 Agwale, S. M. Genotypic and phenotypic analyses of human inmmunodeficiency virus type 1 in antiretroviral drug naive Nigerian patients. 2003. Rec #: 1621
5 Akileswaran, C. Lurie M. N. Flanigan T. P. Mayer K. H. (Dr. M.N. Lurie, Brown University Medical School, International Health Institute). Lessons learned from use of highly active antiretroviral therapy in Africa. Clin Infect Dis. 2005 Aug 1; ISSN: 1058-4838. Rec #: 1486
6 Alberdi Leniz A, Tuset Creus M, Martin Conde M, Del Cacho Del Cacho E, Nigorra Caro M, Codina Jane C, Ribas I, Sala J. Resistance to antiretroviral therapy Original>Resistencias Al Tratamiento Antirretroviral. Farmacia Hospitalaria. 2004;28(6 SUPPL. 1):55-71. Rec #: 1436. [pmid: 15649117].
7 Angarano G, Monno L, Appice A, Giannelli A, Romanelli C, Fico C, Pastore G. Transmission of zidovudine-resistant HIV-1 through heterosexual contacts. AIDS. Jul. 1994;8(7):1013-4. Rec #: 1600. [pmid: 7524541].
8 Arnedo-Valero M, Garcia F, Gil C, Guila T, Fumero E, Castro P, Blanco JL, Miro JM, Pumarola T, Gatell JM. Risk of selecting de novo drug-resistance mutations during structured treatment interruptions in patients with chronic HIV infection. Clin Infect Dis. Sep. 2005;41(6):883-890. Rec #: 1439. [pmid: 16107990].
9 Atkinson B, Isaacson J, Knowles M, Mazabel E, Patick AK. Correlation between human immunodeficiency virus genotypic resistance and virologic response in patients receiving nelfinavir monotherapy or nelfinavir with lamivudine and zidovudine. J Infect Dis. Aug. 2000;182(2):420-7. Rec #: 1214. [pmid: 10915071].
10 Bacheler LT. Resistance to nonnucleoside inhibitors of HIV-I reverse transcriptase. Drug Resist Updat. 1999;2(1):56-67. Rec #: 1412. [pmid: 11504469].
11 Balduin M, Sierra S, Daumer MP, Rockstroh JK, Oette M, Fatkenheuer G, Kupfer B, Beerenwinkel N, Hoffmann D, Selbig J, Pfister HJ, Kaiser R. Evolution of HIV resistance during treatment interruption in experienced patients and after restarting a new therapy. J Clin Virol. 2005;34(4):277-287. Rec #: 1405. [pmid: 16191482].
12 Balotta C, Berlusconi A, Pan A, Violin M, Riva C, Colombo MC, Gori A, Papagno L, Corvasce S, Mazzucchelli R, Facchi G, Velleca R, Saporetti G, Galli M, Rusconi S, Moroni M. Prevalence of transmitted nucleoside analogue-resistant HIV-1 strains and pre-existing mutations in pol reverse transcriptase and protease region: outcome after treatment in recently infected individuals. Antivir Ther. Mar. 2000;5(1):7-14. Rec #: 1218. [pmid: 10846586].
13 Balotta C, Berlusconi A, Pan A, Violin M, Riva C, Gori A, Corvasce S, Mazzucchelli R, Facchi G, Velleca R, Senese D, Deho L, Galli M, Rusconi S, Moroni M. Prevalence of HIV-1 resistant strains in recent seroconverters. J Biol Regul Homeost Agents. Mar 31. 2000 Jan-2000;14(1):51-7. Rec #: 1273.
14 Bangsberg, D. R.; Kroetz, D. L., and Deeks, S. G. Adherence-resistance relationships to combination HIV antiretroviral therapy. 2007. Rec #: 2113
15 Bangsberg DR, Moss AR, Deeks SG. Paradoxes of adherence and drug resistance to HIV antiretroviral therapy. J Antimicrob Chemother. May. 2004;53(5):696-9. Rec #: 1076. [pmid: 15044425].
16 Bassetti D, Cargnel A. Genotypic resistance tests for the management of the HIV-infected pregnant woman. Scand J Infect Dis Suppl. Dec. 2003;35(Suppl 106):70-4. Rec #: 1110. [pmid: 15000589].
17 Belec L, Piketty C, Si-Mohamed A, Goujon C, Hallouin MC, Cotigny S, Weiss L, Kazatchkine MD. High levels of drug-resistant human immunodeficiency virus variants in patients exhibiting increasing CD4+ T cell counts despite virologic failure of protease inhibitor-containing antiretroviral combination therapy. J Infect Dis. May. 2000;181(5):1808-12. Rec #: 1219. [pmid: 10823790].
18 Bessong PO, Larry Obi C, Cilliers T, Choge I, Phoswa M, Pillay C, Papathanasopoulos M, Morris L. Characterization of human immunodeficiency virus type 1 from a previously unexplored region of South Africa with a high HIV prevalence. AIDS Res Hum Retroviruses. Jan. 2005;21(1):103-9. Rec #: 1630. [pmid: 15665650].
19 Bezemer, D.; de Ronde, A.; Prins, M.; Porter, K.; Pillay, D.; Masquelier, B.; Dabis, F.; Back, N.; Jurriaans, S.; van der Hock, L., and CASCADE Collaboration. Trnsmission of HIV-1 with Drug-resistance Mutations that Evolve in the Absence of ART Results in a Mild Initial Decline of CD4 Cell Counts [Interplay among HIV Resistance, Fitness and Outcome]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1768
20 Boucher CA, Lange JM, Miedema FF, Weverling GJ, Koot M, Mulder JW, Goudsmit J, Kellam P, Larder BA, Tersmette M. HIV-1 biological phenotype and the development of zidovudine resistance in relation to disease progression in asymptomatic individuals during treatment. AIDS. Nov. 1992;6(11):1259-64. Rec #: 1339. [pmid: 1282015].
21 Boucher CA, O'Sullivan E, Mulder JW, Ramautarsing C, Kellam P, Darby G, Lange JM, Goudsmit J, Larder BA. Ordered appearance of zidovudine resistance mutations during treatment of 18 human immunodeficiency virus-positive subjects. J Infect Dis. Jan. 1992;165(1):105-10. Rec #: 1604. [pmid: 1370174].
22 Bowles, EC; Wensing, AMJ; van de Vijver, D.; Schuurman, R. ; Boucher, CAB, and WATCH investigators. WATCH: Worldwide Analysis of Resistance Transmission over Time of Chronically and Acute Infected HIV-1 infected persons. 2006 Aug. Rec #: 2103
23 Brandin E, Lindborg L, Gyllensten K, Brostrom C, Hagberg L, Gisslen M, Tuvesson B, Blaxhult A, Albert J. pol gene sequence variation in Swedish HIV-2 patients failing antiretroviral therapy. AIDS Res Hum Retroviruses. Jul. 2003;19(7):543-50. Rec #: 1631. [pmid: 12908931].
24 Brenner BG, Wainberg MA. The role of antiretrovirals and drug resistance in vertical transmission of HIV-1 infection. Ann N Y Acad Sci. Nov. 2000;918:9-15. Rec #: 1250. [pmid: 11131739].
25 Briones C, Perez-Olmeda M, Rodriguez C, del Romero J, Hertogs K, Soriano V. Primary genotypic and phenotypic HIV-1 drug resistance in recent seroconverters in Madrid. J Acquir Immune Defic Syndr. Feb 1. 2001;26(2):145-50. Rec #: 1244. [pmid: 11242181].
26 Cabana M, Clotet B, Martinez MA. Emergence and genetic evolution of HIV-1 variants with mutations conferring resistance to multiple reverse transcriptase and protease inhibitors. J Med Virol. Dec. 1999;59(4):480-90. Rec #: 1635. [pmid: 10534730].
27 Cabrera, C.; Garcia, E.; Marfil, S.; Martinez-Picado, J.; Bonjoch, A.; Grau, E.; Gutierrez, C.; Perez-Elias, M.; Moreno, S.; Clotet, B., and Ruiz, L. Genotypic Evolution of T-20 Resistance-associated Mutations in Heavily Treated HIV-infected Patients on Long-term Treatment with T-20. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1853
28 Calvez V, Costagliola D, Descamps D, Yvon A, Collin G, Cecile A, Delaugerre C, Damond F, Marcelin AG, Matheron S, Simon A, Valantin MA, Katlama C, Brun-Vezinet F. Impact of stavudine phenotype and thymidine analogues mutations on viral response to stavudine plus lamivudine in ALTIS 2 ANRS trial. Antivir Ther. Sep. 2002;7(3):211-8. Rec #: 1171. [pmid: 12487389].
29 Caride E, Brindeiro R, Hertogs K, Larder B, Dehertogh P, Machado E, de Sa CA, Eyer-Silva WA, Sion FS, Passioni LF, Menezes JA, Calazans AR, Tanuri A. Drug-resistant reverse transcriptase genotyping and phenotyping of B and non-B subtypes (F and A) of human immunodeficiency virus type I found in Brazilian patients failing HAART. Virology. Sep 15. 2000;275(1):107-15. Rec #: 1257. [pmid: 11017792].
30 Caride E, Hertogs K, Larder B, Dehertogh P, Brindeiro R, Machado E, de Sa CA, Eyer-Silva WA, Sion FS, Passioni LF, Menezes JA, Calazans AR, Tanuri A. Genotypic and phenotypic evidence of different drug-resistance mutation patterns between B and non-B subtype isolates of human immunodeficiency virus type 1 found in Brazilian patients failing HAART. Virus Genes. 2001;23(2):193-202. Rec #: 1637. [pmid: 11724274].
31 Carr, J. K. ; Lar, P.; Lar, N.; Bemis, K.; Jelpe, J.; Ayuba, L.; Zella, D.; Blattner, W.; Kanki, P., and Abimiku, A. HIV subtype and drug resistance patterns among drug-naive infected persons in Jos, Nigeria. 2005. Rec #: 1638
32 Casado JL, Moreno A, Hertogs K, Dronda F, Moreno S. Extent and importance of cross-resistance to efavirenz after nevirapine failure. AIDS Res Hum Retroviruses. Jul 20. 2002;18(11):771-5. Rec #: 1064. [pmid: 12167268].
33 Chokephaibulkit K, Chaisilwattana P, Vanprapar N, Phongsamart W, Sutthent R. Lack of resistant mutation development after receiving short-course zidovudine plus lamivudine to prevent mother-to-child transmission. AIDS. Jul 22. 2005;19(11):1231-3. Rec #: 1447. [pmid: 15990579].
34 Clarke JR, Braganza R, Mirza A, Stainsby C, Ait-Khaled M, Wright A, Lyall H, Parker D, McClure MO, Weber JN, Taylor GP. Rapid development of genotypic resistance to lamivudine when combined with zidovudine in pregnancy. J Med Virol. Nov. 1999;59(3):364-8. Rec #: 1287. [pmid: 10502270].
35 Clavel, F. Emerging Issues of HIV Drug Resistance. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1835
36 Cleland A, Watson HG, Robertson P, Ludlam CA, Brown AJ. Evolution of zidovudine resistance-associated genotypes in human immunodeficiency virus type 1-infected patients. J Acquir Immune Defic Syndr Hum Retrovirol. May 1. 1996;12(1):6-18. Rec #: 1311. [pmid: 8624762].
37 Clevenbergh P, Kirstetter M, Liotier JY, Dupon M, Philibert P, Jacomet C, Cua E, Montagne N, Schmit JC, Dellamonica P. Long-term virological outcome in patients infected with multi-nucleoside analogue-resistant HIV-1. Antivir Ther. Dec. 2002;7(4):305-8. Rec #: 1639. [pmid: 12553486].
38 Clotet B. Efavirenz: resistance and cross-resistance. Int J Clin Pract Suppl. Jun. 1999;103:21-5. Rec #: 1108. [pmid: 10622039].
39 Clotet B. Strategies for overcoming resistance in HIV-1 infected patients receiving HAART. AIDS Rev. Sep 30. 2004 Jul-2004;6(3):123-30. Rec #: 1038.
40 Clotet B, Ruiz L, Martinez-Picado J, Negredo E, Hill A, Popescu M. Prevalence of HIV protease mutations on failure of nelfinavir-containing HAART: a retrospective analysis of four clinical studies and two observational cohorts. HIV Clin Trials. Aug 31. 2002 Jul-2002;3(4):316-23. Rec #: 1147.
41 Coakley EP, Gillis JM, Hammer SM. Phenotypic and genotypic resistance patterns of HIV-1 isolates derived from individuals treated with didanosine and stavudine. AIDS. Jan 28. 2000;14(2):F9-15. Rec #: 1640. [pmid: 10708277].
42 Cohan D, Feakins C, Wara D, Petru A, McNicholl I, Schillinger D, Lu J, Kuritzkes D, Deeks SG. Perinatal transmission of multidrug-resistant HIV-1 despite viral suppression on an enfuvirtide-based treatment regimen. AIDS. Jun 10. 2005;19(9):989-90. Rec #: 1348. [pmid: 15905684].
43 Colonno R, Rose R, McLaren C, Thiry A, Parkin N, Friborg J. Identification of I50L as the signature atazanavir (ATV)-resistance mutation in treatment-naive HIV-1-infected patients receiving ATV-containing regimens. J Infect Dis. May 15. 2004;189(10):1802-10. Rec #: 1641. [pmid: 15122516].
44 Condra JH, Schleif WA, Blahy OM, Gabryelski LJ, Graham DJ, Quintero JC, Rhodes A, Robbins HL, Roth E, Shivaprakash M, et al. In vivo emergence of HIV-1 variants resistant to multiple protease inhibitors. Nature. Apr 6. 1995;374(6522):569-71. Rec #: 1642. [pmid: 7700387].
45 Conlon CP, Klenerman P, Edwards A, Larder BA, Phillips RE. Heterosexual transmission of human immunodeficiency virus type 1 variants associated with zidovudine resistance. J Infect Dis. Feb. 1994;169(2):411-5. Rec #: 1601. [pmid: 7508970].
46 Conway B, Montessori V, Rouleau D, Montaner JS, O'Shaughnessy MV, Fransen S, Shillington A, Weislow O, Mayers DL. Primary lamivudine resistance in acute/early human immunodeficiency virus infection. Clin Infect Dis. Apr. 1999;28(4):910-1. Rec #: 1270. [pmid: 10825060].
47 Coovadia H. Antiretroviral agents-how best to protect infants from HIV and save their mothers from AIDS. N Engl J Med. Jul 15. 2004;351(3):289-92. Rec #: 1035. [pmid: 15247337].
48 Coovadia H. Top stories of 2004. Perinatal transmission interventions: the benefits come with resistance. AIDS Clin Care. Jan. 2005;17(1):2. Rec #: 1017.
49 Craig C, Moyle G. The development of resistance of HIV-1 to zalcitabine. AIDS. Mar. 1997;11(3):271-9. Rec #: 1305. [pmid: 9147417].
50 Craig C, Race E, Sheldon J, Whittaker L, Gilbert S, Moffatt A, Rose J, Dissanayeke S, Chirn GW, Duncan IB, Cammack N. HIV protease genotype and viral sensitivity to HIV protease inhibitors following saquinavir therapy. AIDS. Sep 10. 1998;12(13):1611-8. Rec #: 1238. [pmid: 9764779].
51 Damond, F.; Collin, G.; Matheron, S.; Taieb, A.; Campa, P.; Benard, A.; Peytavin, G.; Chene, G.; Brun-Vezinet, F.; Descamps, D., and French ANRS HIV-2 Cohort . Phenotypic Susceptibility to Nucleoside Reverse Transcriptase Inhibitors of HIV-2 isolates with the Q151M Mutation in the Reverse Transcriptase Gene [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitor]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1799
52 Damond F, Matheron S, Peytavin G, Campa P, Taieb A, Collin G, Delaunay C, Chene G, Brun-Vezinet F, Descamps D. Selection of K65R mutation in HIV-2-infected patients receiving tenofovir-containing regimen. Antivir Ther. Aug. 2004;9(4):635-6. Rec #: 1482. [pmid: 15456096].
53 Daniel N, Schneider V, Pialoux G, Krivine A, Grabar S, Nguyen TH, Girard PM, Rozenbaum W, Salmon D. Emergence of HIV-1 mutated strains after interruption of highly active antiretroviral therapy in chronically infected patients. AIDS. Sep 26. 2003;17(14):2126-9. Rec #: 1394. [pmid: 14502019].
54 de Mendoza C, Soriano V, Briones C, Gallego O, Barreiro P, Alvarez A, Gonzalez-Lahoz J. Emergence of zidovudine resistance in HIV-infected patients receiving stavudine. J Acquir Immune Defic Syndr. Mar 1. 2000;23(3):279-81. Rec #: 1269. [pmid: 10839665].
55 Deeks, S.; Lu, J.; Hoh, R.; Beatty, G.; Huang, W.; Petropoulos, C., and Kuritzkes, D. Interruption of Enfuvirtide in Patients with Enfuvirtide Resistance. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1844
56 Deeks SG. Nonnucleoside reverse transcriptase inhibitor resistance. J Acquir Immune Defic Syndr. Mar. 2001;26(SUPPL. 1):S25-S33. Rec #: 1432. [pmid: 11264999].
57 Deeks SG, Hellmann NS, Grant RM, Parkin NT, Petropoulos CJ, Becker M, Symonds W, Chesney M, Volberding PA. Novel four-drug salvage treatment regimens after failure of a human immunodeficiency virus type 1 protease inhibitor-containing regimen: antiviral activity and correlation of baseline phenotypic drug susceptibility with virologic outcome. J Infect Dis. Jun. 1999;179(6):1375-81. Rec #: 1645. [pmid: 10228057].
58 DeGruttola V, Dix L, D'Aquila R, Holder D, Phillips A, Ait-Khaled M, Baxter J, Clevenbergh P, Hammer S, Harrigan R, Katzenstein D, Lanier R, Miller M, Para M, Yerly S, Zolopa A, Murray J, Patick A, Miller V, Castillo S, Pedneault L, Mellors J. The relation between baseline HIV drug resistance and response to antiretroviral therapy: re-analysis of retrospective and prospective studies using a standardized data analysis plan. Antivir Ther. Mar. 2000;5(1):41-8. Rec #: 1596. [pmid: 10846592].
59 Demeter LM, Meehan PM, Morse G, Gerondelis P, Dexter A, Berrios L, Cox S, Freimuth W, Reichman RC. HIV-1 drug susceptibilities and reverse transcriptase mutations in patients receiving combination therapy with didanosine and delavirdine. J Acquir Immune Defic Syndr Hum Retrovirol. Feb 1. 1997;14(2):136-44. Rec #: 1122. [pmid: 9052722].
60 Demeter LM, Nawaz T, Morse G, Dolin R, Dexter A, Gerondelis P, Reichman RC. Development of zidovudine resistance mutations in patients receiving prolonged didanosine monotherapy. J Infect Dis. Dec. 1995;172(6):1480-5. Rec #: 1313. [pmid: 7594706].
61 Demeter LM, Shafer RW, Meehan PM, Holden-Wiltse J, Fischl MA, Freimuth WW, Para MF, Reichman RC. Delavirdine susceptibilities and associated reverse transcriptase mutations in human immunodeficiency virus type 1 isolates from patients in a phase I/II trial of delavirdine monotherapy (ACTG 260). Antimicrob Agents Chemother. Mar. 2000;44(3):794-7. Rec #: 1106. [pmid: 10681363]. [pmcid: 89771].
62 Desai N, Mathur M. Selective transmission of multidrug resistant HIV to a newborn related to poor maternal adherence. Sex Transm Infect. Oct. 2003;79(5):419-21. Rec #: 1146. [pmid: 14573842]. [pmcid: 1744738].
63 Descamps D, Joly V, Flandre P, Peytavin G, Meiffredy V, Delarue S, Lastere S, Aboulker JP, Yeni P, Brun-Vezinet F. Genotypic resistance analyses in nucleoside-pretreated patients failing an indinavir containing regimen: results from a randomized comparative trial: (Novavir ANRS 073). J Clin Virol. Jun. 2005;33(2):99-103. Rec #: 1018. [pmid: 15911424].
64 Di Stefano M, Norkrans G, Chiodi F, Hagberg L, Nielsen C, Svennerholm B. Zidovudine-resistant variants of HIV-1 in brain. Lancet. Oct 2. 1993;342(8875):865. Rec #: 1464. [pmid: 8104290].
65 Dietrich U, Ruppach H, Gehring S, Knechten H, Knickmann M, Jager H, Wolf E, Husak R, Orfanos CE, Brede HD, Rubsamen-Waigmann H, von Briesen H. Large proportion of non-B HIV-1 subtypes and presence of zidovudine resistance mutations among German seroconvertors. AIDS. Oct. 1997;11(12):1532-3. Rec #: 1299. [pmid: 9342084].
66 Doerholt, K. ; Gibb, D. M.; Sharland, M., and Walker, A. S. Antiretroviral therapy for HIV-infected children [Protocol]. Cochrane Database of Systematic Reviews 2005;(4). 2005. Rec #: 1360
67 Doualla-Bell F, Avalos A, Gaolathe T, Mine M, Gaseitsiwe S, Ndwapi N, Novitsky VA, Brenner B, Oliveira M, Moisi D, Moffat H, Thior I, Essex M, Wainberg MA. Impact of human immunodeficiency virus type 1 subtype C on drug resistance mutations in patients from Botswana failing a nelfinavir-containing regimen. Antimicrob Agents Chemother. Jun. 2006;50(6):2210-3. Rec #: 2117. [pmid: 16723586]. [pmcid: 1479146].
68 Doualla-Bell F, Gaseitsiwe S, Ndungu T, Modukanele M, Peter T, Novitsky V, Ndwapi N, Tendani G, Avalos A, Wester W, Bussmann H, Cardiello P, Marlink R, Moffat H, Thior I, Wainberg MA, Essex M. Mutations and polymorphisms associated with antiretroviral drugs in HIV-1C-infected African patients. Antivir Chem Chemother. Jul. 2004;15(4):189-200. Rec #: 1029. [pmid: 15457680].
69 Eastman PS, Mittler J, Kelso R, Gee C, Boyer E, Kolberg J, Urdea M, Leonard JM, Norbeck DW, Mo H, Markowitz M. Genotypic changes in human immunodeficiency virus type 1 associated with loss of suppression of plasma viral RNA levels in subjects treated with ritonavir (Norvir) monotherapy. J Virol. Jun. 1998;72(6):5154-64. Rec #: 1248. [pmid: 9573287]. [pmcid: 110088].
70 Elbeik T, Hoo BS, Campodonico ME, Dileanis J, Fay FF, Bortolozzi RL, Benetti MS, Fay OH, Marlowe N, Petrauskene O, Chernoff D, Smith L, Ng VL. In vivo emergence of drug-resistant mutations at less than 50 HIV-1 RNA copies/mL that are maintained at viral rebound in longitudinal plasma samples from human immunodeficiency virus type-1-infected patients on highly active antiretroviral therapy. J Hum Virol. Dec 31. 2001 Nov-2001;4(6):317-28. Rec #: 1574.
71 Erice A, Balfour HH Jr. Resistance of human immunodeficiency virus type 1 to antiretroviral agents: a review. Clin Infect Dis. Feb. 1994;18(2):149-56. Rec #: 1330. [pmid: 7512829].
72 Eshleman, S. ; Nissley, D.; Claasen, C.; Jones, D.; Shi, C.; Guay, L.; Musoke, P.; Mmiro, F.; Strathern, J.; Jackson, J.; Eshleman, J., and Flys, T. Sensitive Drug Resistance Assays Reveal Long-term Persistence of HIV-1 Variants with the K103N Nevirapine-resistance Mutation in Some Women and Infants after Single-dose NVP: HIVNET 012. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1899
73 Eshleman SH, Jackson JB. Nevirapine resistance after single dose prophylaxis. AIDS Rev. Jun 30. 2002 Apr-2002;4(2):59-63. Rec #: 1066.
74 Eshleman, S. H.; Wang, J.; Guay, L. A.; Cunningham, S. P.; Mwatha, A.; Brown, E. R.; Musoke, P.; Mmiro, F., and Jackson, J. B. Distinct patterns of selection and fading of K103N and Y181C are seen in women with subtype A vs D HIV-1 after single dose nevirapine: HIVNET 012. 2004; 9, S59. Rec #: 1916
75 Fidler S, Frater J, Clarke J, Weber J. HIV-1 drug resistance in primary infections in the UK. Br Med J. Sep 15. 2001;323(7313):632-3. Rec #: 1406.
76 Filippini P, Liguori G, Scolastico C, Coppola N, Lucariello A, Marrocco C, Catania MR, Ortega De Luna L, Romano Carratelli C, Marinelli P, Sagnelli E, Rossano F. Prevalence of genotypic resistance to nucleoside analogues and protease inhibitors in antiretroviral-naive HIV patients in Campania, Italy. J Chemother. Dec. 2004;16(6):534-9. Rec #: 1033. [pmid: 15700844].
77 Fitzgibbon JE, DiCola B, Arnold E, Das K, Sha BE, Pottage JC Jr, Nahass R, Gaur S, John JF Jr. HIV-1 reverse transcriptase mutations found in a drug-experienced patient confer reduced susceptibility to multiple nucleoside reverse transcriptase inhibitors. Antivir Ther. Dec. 2001;6(4):231-8. Rec #: 1188. [pmid: 11878404].
78 Fitzgibbon JE, Gaur S, Frenkel LD, Laraque F, Edlin BR, Dubin DT. Transmission from one child to another of human immunodeficiency virus type 1 with a zidovudine-resistance mutation. N Engl J Med. Dec 16. 1993;329(25):1835-41. Rec #: 1602. [pmid: 8247034].
79 Fitzgibbon JE, Gaur S, Walsman SM, Janahi M, Whitley-Williams P, John JF Jr. Emergence of drug resistance mutations in a group of HIV-infected children taking nelfinavir-containing regimens. AIDS Res Hum Retroviruses. Sep 20. 2001;17(14):1321-8. Rec #: 1651. [pmid: 11602042].
80 Fleury HJ, Toni TA, Lan NTH, Hung PV, Deshpande A, Recordon-Pinson P, Cheret A, Lebel-Binay S, Masquelier B. Susceptibility to ARVs of CRF01_AE, CRF02_AG and subtype C viruses from naive patients: comparative genotypical and phenotypical data. Antivir Ther. 2005;10:S148. Rec #: 1993.
81 Flys T, Nissley DV, Claasen CW, Jones D, Shi C, Guay LA, Musoke P, Mmiro F, Strathern JN, Jackson JB, Eshleman JR, Eshleman SH. Sensitive drug-resistance assays reveal long-term persistence of HIV-1 variants with the K103N nevirapine (NVP) resistance mutation in some women and infants after the administration of single-dose NVP: HIVNET 012. J Infect Dis. Jul 1. 2005;192(1):24-9. Rec #: 1006. [pmid: 15942890].
82 Frenkel LM, Wagner LE 2nd, Demeter LM, Dewhurst S, Coombs RW, Murante BL, Reichman RC. Effects of zidovudine use during pregnancy on resistance and vertical transmission of human immunodeficiency virus type 1. Clin Infect Dis. May. 1995;20(5):1321-6. Rec #: 1319. [pmid: 7620018].
83 Friend J, Parkin N, Liegler T, Martin JN, Deeks SG. Isolated lopinavir resistance after virological rebound of a ritonavir/lopinavir-based regimen. AIDS. Sep 24. 2004;18(14):1965-6. Rec #: 1699. [pmid: 15353986].
84 Fumero E, Podzamczer D. New patterns of HIV-1 resistance during HAART. Clin Microbiol Infect. Nov. 2003;9(11):1077-84. Rec #: 1085. [pmid: 14616723].
85 Funk M, Linde R, Braner HJ, Groeschel B, Kornhuber B, Kreuz W. Genotypic and phenotypic resistance under zidovudine and lamivudine therapy in human immunodeficiency virus-infected children. Eur J Pediatr. Jan. 1999;158(1):86-7. Rec #: 1396. [pmid: 9950320].
86 Gallego O, de Mendoza C, Corral A, Barrios A, Soriano V. Estimated extent of cross-resistance to ritonavir-boosted protease inhibitors among protease inhibitors-experienced patients: implications for tipranavir use. AIDS Patient Care STDS. Feb. 2005;19(2):67-9. Rec #: 1032. [pmid: 15716637].
87 Garcia-Lerma G, Soriano V, Gomez-Cano M, Bravo R, Mas A, del Romero J, Martin R, Gonzalez-Lahoz J. Prevalence of zidovudine-resistant HIV-1 among rapid progressors. AIDS. Sep. 1996;10(11):1292-3. Rec #: 1306. [pmid: 8883594].
88 Gatanaga H, Aizawa S, Kikuchi Y, Tachikawa N, Genka I, Yoshizawa S, Yamamoto Y, Yasuoka A, Oka S. Anti-HIV effect of saquinavir combined with ritonavir is limited by previous long-term therapy with protease inhibitors. AIDS Res Hum Retroviruses. Nov 20. 1999;15(17):1493-8. Rec #: 1654. [pmid: 10580399].
89 Gianotti N, Seminari E, Fusetti G, Salpietro S, Boeri E, Galli A, Lazzarin A, Clementi M, Castagna A. Impact of a treatment including tenofovir plus didanosine on the selection of the 65R mutation in highly drug-experienced HIV-infected patients. AIDS. Nov 5. 2004;18(16):2205-8. Rec #: 1054. [pmid: 15577657].
90 Gonzales MJ, Belitskaya I, Dupnik KM, Rhee SY, Shafer RW. Protease and reverse transcriptase mutation patterns in HIV type 1 isolates from heavily treated persons: comparison of isolates from Northern California with isolates from other regions. AIDS Res Hum Retroviruses. Oct. 2003;19(10):909-15. Rec #: 1457. [pmid: 14601580]. [pmcid: 2547469].
91 Gonzalez de Requena D, Gallego O, de Mendoza C, Corral A, Jimenez-Nacher I, Soriano V. Indinavir plasma concentrations and resistance mutations in patients experiencing early virological failure. AIDS Res Hum Retroviruses. Jun. 2003;19(6):457-9. Rec #: 1100. [pmid: 12882654].
92 Grappin M, Piroth L, Kohli E, Buisson M, Duong M, Chavanet P, Portier H. Incomplete genotypic resistance to nonnucleoside reverse transcriptase inhibitors in patients treated with nevirapine: a potential interest in clinical practice. J Acquir Immune Defic Syndr. Dec 15. 2000;25(5):464-5. Rec #: 1091. [pmid: 11141247].
93 Gray, G.; Morris, L., and McIntyre, J. MTCT regimen choice, drug resistance and the treatment of HIV-1-infected children. South Afr J HIV Med. 2002; -(9):5-8. Rec #: 1408
94 Gripshover, B.; Santana, J.; Ribaudo, H.; Gerber, J.; Thomas, C.; Hogg, E.; Jarocki, B.; Hammer, S., and Kuritzkes, D. A Randomized, Placebo-controlled Trial of Amdoxovir vs Placebo with Enfuvirtide plus Optimized Background Therapy for HIV-infected Subjects Failing Current Therapy (AACTG 5118). 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1860
95 Gunthard, H. F. Wong J. K. Ignacio C. C. Guatelli J. C. Riggs N. L. HavlirD. V. Richman D. D. (H.F. Gunthard, University of California San Diego, Division of Infectious Diseases, Department of Pathology/Medicine). Human immunodeficiency virus replication and genotypic resistance in blood and lymph nodes after a year of potent antiretroviral therapy. J Virol. 1998 Mar; 72(3):2422-8; ISSN: 0022-538X. Rec #: 1502
96 Gutierrez F, Molto J, Escolano C, Mora A, Pasquau F, Gregori J, Nogueira E. [Genotypic resistance to antiretroviral drugs in patients with therapeutic failure to highly active antiretroviral therapy]. Med Clin (Barc). Oct 7. 2000;115(11):401-4. Rec #: 1474. [pmid: 11093841].
97 Hachiya A, Gatanaga H, Kodama E, Ikeuchi M, Matsuoka M, Harada S, Mitsuya H, Kimura S, Oka S. Novel patterns of nevirapine resistance-associated mutations of human immunodeficiency virus type 1 in treatment-naive patients. Virology. Oct 1. 2004;327(2):215-24. Rec #: 1030. [pmid: 15351209].
98 Hammer SM. Single-dose nevirapine and drug resistance: the more you look, the more you find. J Infect Dis. Jul 1. 2005;192(1):1-3. Rec #: 1008. [pmid: 15942885].
99 Hasson H, Gianotti N, Danise A, Seminari E, Boeri E, Nozza S, Castagna A, Lazzarin A. Resistance to amprenavir before and after treatment with lopinavir/ritonavir in highly protease inhibitor-experienced HIV patients. AIDS. Jan 2. 2004;18(1):123-7. Rec #: 1072. [pmid: 15090838].
100 Haubrich, R. Demeter L. (R. Haubrich, Division of Infectious Diseases, University of California, San Diego). Clinical utility of resistance testing: Retrospective and prospective data supporting use and current recommendations. J Acquir Immune Defic Syndr. 2001 Mar 1; ISSN: 1525-4135. Rec #: 1497
101 Havlir D, McLaughlin MM, Richman DD. A pilot study to evaluate the development of resistance to nevirapine in asymptomatic human immunodeficiency virus-infected patients with CD4 cell counts of > 500/mm3: AIDS Clinical Trials Group Protocol 208. J Infect Dis. Nov. 1995;172(5):1379-83. Rec #: 1128. [pmid: 7594683].
102 Havlir DV, Hellmann NS, Petropoulos CJ, Whitcomb JM, Collier AC, Hirsch MS, Tebas P, Sommadossi JP, Richman DD. Drug susceptibility in HIV infection after viral rebound in patients receiving indinavir-containing regimens. JAMA. Jan 12. 2000;283(2):229-34. Rec #: 1226. [pmid: 10634339].
103 Herzmann C, Karcher H. Nevirapine plus zidovudine to prevent mother-to-child transmission of HIV. N Engl J Med. Nov 4. 2004;351(19):2013-5. author reply 2013–5. Rec #: 1026.
104 Hirsch MS, Brun-Vezinet F, Clotet B, Conway B, Kuritzkes DR, D'Aquila RT, Demeter LM, Hammer SM, Johnson VA, Loveday C, Mellors JW, Jacobsen DM, Richman DD. Antiretroviral drug resistance testing in adults infected with human immunodeficiency virus type 1: 2003 recommendations of an International AIDS Society-USA Panel. Clin Infect Dis. Jul 1. 2003;37(1):113-28. Rec #: 1552. [pmid: 12830416].
105 Hirsch MS, Brun-Vezinet F, D'Aquila RT, Hammer SM, Johnson VA, Kuritzkes DR, Loveday C, Mellors JW, Clotet B, Conway B, Demeter LM, Vella S, Jacobsen DM, Richman DD. Antiretroviral drug resistance testing in adult HIV-1 infection: recommendations of an International AIDS Society-USA Panel. JAMA. May 10. 2000;283(18):2417-26. Rec #: 1529. [pmid: 10815085].
106 Hirsch MS, Conway B, D'Aquila RT, Johnson VA, Brun-Vezinet F, Clotet B, Demeter LM, Hammer SM, Jacobsen DM, Kuritzkes DR, Loveday C, Mellors JW, Vella S, Richman DD. Antiretroviral drug resistance testing in adults with HIV infection: implications for clinical management. International AIDS Society-USA Panel. JAMA. Jun 24. 1998;279(24):1984-91. Rec #: 1500. [pmid: 9643863].
107 Holguin A, Dietrich U, Immelmann A, Soriano V. Genotypic and phenotypic resistance to stavudine after long-term monotherapy. BMS-020 Spanish Study Group. Antivir Ther. 1998;3(3):183-6. Rec #: 1280. [pmid: 10682136].
108 Holodniy M, Katzenstein D, Winters M, Montoya J, Shafer R, Kozal M, Ragni M, Merigan TC. Measurement of HIV virus load and genotypic resistance by gene amplification in asymptomatic subjects treated with combination therapy. J Acquir Immune Defic Syndr. Apr. 1993;6(4):366-9. Rec #: 1335. [pmid: 8095981].
109 Holodniy M, Mole L, Margolis D, Moss J, Dong H, Boyer E, Urdea M, Kolberg J, Eastman S. Determination of human immunodeficiency virus RNA in plasma and cellular viral DNA genotypic zidovudine resistance and viral load during zidovudine-didanosine combination therapy. J Virol. Jun. 1995;69(6):3510-6. Rec #: 1315. [pmid: 7745698]. [pmcid: 189064].
110 Imrie A, Beveridge A, Genn W, Vizzard J, Cooper DA. Transmission of human immunodeficiency virus type 1 resistant to nevirapine and zidovudine. Sydney Primary HIV Infection Study Group. J Infect Dis. Jun. 1997;175(6):1502-6. Rec #: 1120. [pmid: 9180194].
111 Izopet J, Salama G, Pasquier C, Sandres K, Marchou B, Massip P, Puel J. Decay of HIV-1 DNA in patients receiving suppressive antiretroviral therapy. J Acquir Immune Defic Syndr Hum Retrovirol. Dec 15. 1998;19(5):478-83. Rec #: 1667. [pmid: 9859961].
112 Jackson JB, Becker-Pergola G, Guay LA, Musoke P, Mracna M, Fowler MG, Mofenson LM, Mirochnick M, Mmiro F, Eshleman SH. Identification of the K103N resistance mutation in Ugandan women receiving nevirapine to prevent HIV-1 vertical transmission. AIDS. Jul 28. 2000;14(11):F111-5. Rec #: 1099. [pmid: 10983633].
113 Jacobsen, H. Haenggi M. Ott M. Duncan I. B. Andreoni M. Vella S. MousJ. (PRP/Genetechnology, F. Hoffmann-LaRoche AG, Building 66-709,CH-4002 Basel. Switzerland). Reduced sensitivity of saquinavir: An update on genotyping from phase I/II trials. Antiviral ResearchNetherlands; 1996. Rec #: 1506
114 Johnson VA, Petropoulos CJ, Woods CR, Hazelwood JD, Parkin NT, Hamilton CD, Fiscus SA. Vertical transmission of multidrug-resistant human immunodeficiency virus type 1 (HIV-1) and continued evolution of drug resistance in an HIV-1-infected infant. J Infect Dis. Jun 1. 2001;183(11):1688-93. Rec #: 1192. [pmid: 11343221].
115 Joly V, Descamps D, Peytavin G, Touati F, Mentre F, Duval X, Delarue S, Yeni P, Brun-Vezinet F. Evolution of human immunodeficiency virus type 1 (HIV-1) resistance mutations in nonnucleoside reverse transcriptase inhibitors (NNRTIs) in HIV-1-infected patients switched to antiretroviral therapy without NNRTIs. Antimicrob Agents Chemother. Jan. 2004;48(1):172-5. Rec #: 1044. [pmid: 14693536]. [pmcid: 310183].
116 Jorgensen LB, Katzenstein TL, Gerstoft J, Mathiesen LR, Pedersen C, Nielsen C. Genotypic and phenotypic nevirapine resistance correlates with virological failure during salvage therapy including abacavir and nevirapine. Antivir Ther. Sep. 2000;5(3):187-94. Rec #: 1092. [pmid: 11075938].
117 Jung M, Agut H, Candotti D, Ingrand D, Katlama C, Huraux JM. Susceptibility of HIV-1 isolates to zidovudine: correlation between widely applicable culture test and PCR analysis. J Acquir Immune Defic Syndr. 1992;5(4):359-64. Rec #: 1341. [pmid: 1372352].
118 Kagan RM, Merigan TC, Winters MA, Heseltine PN. Increasing prevalence of HIV-1 reverse transcriptase mutation K65R correlates with tenofovir utilization. Antivir Ther. Oct. 2004;9(5):827-8. Rec #: 1060. [pmid: 15535422].
119 Karmochkine M, Si Mohamed A, Piketty C, Ginsburg C, Raguin G, Schneider-Fauveau V, Gutmann L, Kazatchkine MD, Belec L. The cumulative occurrence of resistance mutations in the HIV-1 protease gene is associated with failure of salvage therapy with ritonavir and saquinavir in protease inhibitor-experienced patients. Antiviral Res. Sep. 2000;47(3):179-88. Rec #: 1208. [pmid: 10974370].
120 Kavlick MF, Wyvill K, Yarchoan R, Mitsuya H. Emergence of multi-dideoxynucleoside-resistant human immunodeficiency virus type 1 variants, viral sequence variation, and disease progression in patients receiving antiretroviral chemotherapy. J Infect Dis. Jun. 1998;177(6):1506-13. Rec #: 1671. [pmid: 9607827].
121 Kellam P, Boucher CA, Tijnagel JM, Larder BA. Zidovudine treatment results in the selection of human immunodeficiency virus type 1 variants whose genotypes confer increasing levels of drug resistance. J Gen Virol. Feb. 1994;75(Pt 2):341-51. Rec #: 1331. [pmid: 7509370].
122 Kitchen, C. ; Suchard, M.; Lu, J.; Hoh, R.; Kuritzkes, D., and Deeks, S. Continued GP41 Evolution after Interruption of Enfuvirtide: Evidence for Ongoing Immunogologic Pressure in Advanced HIV Disease [Mechanisms of Drug Resistance: Entry Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1789
123 Klausner, J.; Bilezikjian, M.; Krone, M.; Gesner, M.; Forte, S.; Donovan, R., and Sheppard, H. CDD38CD8 Expression Prespectively Predicts CD4 Decline Independent of Plasma HIV-1 Viral Load, Use of HAART of HIV-1 Resistance Profile. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1857
124 Kozal MJ, Shafer RW, Winters MA, Katzenstein DA, Merigan TC. A mutation in human immunodeficiency virus reverse transcriptase and decline in CD4 lymphocyte numbers in long-term zidovudine recipients. J Infect Dis. Mar. 1993;167(3):526-32. Rec #: 1336. [pmid: 7680058].
125 Kristiansen TB, Pedersen AG, Eugen-Olsen J, Katzenstein TL, Lundgren JD. Genetic evolution of HIV in patients remaining on a stable HAART regimen despite insufficient viral suppression. Scand J Infect Dis. 2005;37(11-12):890-901. Rec #: 1678. [pmid: 16308226].
126 Kuritzkes, D. R.; Boyle, B. A.; Gallant, J. E.; Squires, K. E., and Zolopa, A. Current management challenges in HIV: antiretroviral resistance. AIDS Read. 2003 Mar; 13(3):133-5, 138-42. Rec #: 1528
127 Kuritzkes DR, Sevin A, Young B, Bakhtiari M, Wu H, St Clair M, Connick E, Landay A, Spritzler J, Kessler H, Lederman MM. Effect of zidovudine resistance mutations on virologic response to treatment with zidovudine-lamivudine-ritonavir: genotypic analysis of human immunodeficiency virus type 1 isolates from AIDS clinical trials group protocol 315.ACTG Protocol 315 Team. J Infect Dis. Feb. 2000;181(2):491-7. Rec #: 1597. [pmid: 10669331].
128 Lafeuillade A, Solas C, Chadapaud S, Hittinger G, Poggi C, Lacarelle B. HIV-1 RNA levels, resistance, and drug diffusion in semen versus blood in patients receiving a lopinavir-containing regimen. J Acquir Immune Defic Syndr. Apr 1. 2003;32(4):462-4. Rec #: 1116. [pmid: 12640207].
129 Landman, R. ; Peytavin, G.; Descamps, D., and Brun-Vezinet, F. Low genetic barrier to resistance is possible cause of early virologic failures in once-daily regimen of Ziagen, Epivir and Viread. 11th Conference on Retroviruses And Opportunistic Infections; San Francisco. 2004. Rec #: 1536
130 Lawrence J, Schapiro J, Winters M, Montoya J, Zolopa A, Pesano R, Efron B, Winslow D, Merigan TC. Clinical resistance patterns and responses to two sequential protease inhibitor regimens in saquinavir and reverse transcriptase inhibitor-experienced persons. J Infect Dis. Jun. 1999;179(6):1356-64. Rec #: 1228. [pmid: 10228055].
131 Lecossier D, Shulman NS, Morand-Joubert L, Shafer RW, Joly V, Zolopa AR, Clavel F, Hance AJ. Detection of minority populations of HIV-1 expressing the K103N resistance mutation in patients failing nevirapine. J Acquir Immune Defic Syndr. Jan 1. 2005;38(1):37-42. Rec #: 1023. [pmid: 15608522].
132 Lin PF, Gonzalez CJ, Griffith B, Friedland G, Calvez V, Ferchal F, Schinazi RF, Shepp DH, Ashraf AB, Wainberg MA, Soriano V, Mellors JW, Colonno RJ. Stavudine resistance: an update on susceptibility following prolonged therapy. Antivir Ther. 1999;4(1):21-8. Rec #: 1283. [pmid: 10682125].
133 Lin PF, Samanta H, Rose RE, Patick AK, Trimble J, Bechtold CM, Revie DR, Khan NC, Federici ME, Li H, et al. Genotypic and phenotypic analysis of human immunodeficiency virus type 1 isolates from patients on prolonged stavudine therapy. J Infect Dis. Nov. 1994;170(5):1157-64. Rec #: 1325. [pmid: 7963708].
134 Lo Cicero M, Bulgheroni E, Soster F, Vigano O, Cicconi P, Galli M, Rusconi S. Absence of new thymidine-associated mutations and evidence of an immune virologic response over a 12-month period in a cohort of antiretroviral-experienced HIV-1-infected subjects treated with tenofovir combination therapy. J Acquir Immune Defic Syndr. Oct 1. 2005;40(2):238-41. Rec #: 1387. [pmid: 16186745].
135 Lorenzi P, Yerly S, Abderrakim K, Fathi M, Rutschmann OT, von Overbeck J, Leduc D, Perrin L, Hirschel B. Toxicity, efficacy, plasma drug concentrations and protease mutations in patients with advanced HIV infection treated with ritonavir plus saquinavir. Swiss HIV Cohort Study. AIDS. Oct. 1997;11(12):F95-9. Rec #: 1253. [pmid: 9110081].
136 Loubser, S. ; Balfe, P.; Sherman, G.; Jones, S.; Cohen, S.; Kuhn, L.; Hammer, S., and Morris, L. Sensitive Real-Time PCR Quantification of 103N Resistance Mutants following Single-dose Treatment with Nevirapine. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1832
137 Loveday C. International perspectives on antiretroviral resistance. Nucleoside reverse transcriptase inhibitor resistance. J Acquir Immune Defic Syndr. Mar 1. 2001;26(Suppl 1):S10-24. Rec #: 1241. [pmid: 11264998].
138 ---. Nucleoside reverse transcriptase inhibitor resistance. J Acquir Immune Defic Syndr. 2001 Mar; 26(SUPPL. 1):S10-S24. Rec #: 1433
139 Loveday C, Kaye S, Tenant-Flowers M, Semple M, Ayliffe U, Weller IV, Tedder RS. HIV-1 RNA serum-load and resistant viral genotypes during early zidovudine therapy. Lancet. Apr 1. 1995;345(8953):820-4. Rec #: 1322. [pmid: 7534858].
140 Luber AD. Genetic barriers to resistance and impact on clinical response. MedGenMed. 2005;7(3):69. Rec #: 1472.
141 Lyons, F.; Coughlan, S.; Byrne, C.; Hopkins, S.; Hall, W.; Bergin, C., and Mulcahy, F. Emergence of Genotypic Resistance in HIV-1-infected Pregnant Women Taking HAART to Reduce Mother-to-child Transmission of HIV-1. 11th Conference on Retroviruses and Opportunistic Infections; San Francisco, CA. 2004. Rec #: 2127
142 Mackie NE, Fidler S, Tamm N, Clarke JR, Back D, Weber JN, Taylor GP. Clinical implications of stopping nevirapine-based antiretroviral therapy: relative pharmacokinetics and avoidance of drug resistance. HIV Med. May. 2004;5(3):180-4. Rec #: 1037. [pmid: 15139985].
143 Magiorkinis E, Paraskevis D, Magiorkinis G, Chryssou S, Chini M, Lazanas M, Paparizos V, Saroglou G, Antoniadou A, Giamarellou E, Karafoulidou A, Hatzakis A. Mutations associated with genotypic resistance to antiretroviral therapy in treatment naive HIV-1 infected patients in Greece. Virus Res. Apr 23. 2002;85(1):109-15. Rec #: 2096. [pmid: 11955643].
144 Marcelin AG, Affolabi D, Lamotte C, Mohand HA, Delaugerre C, Wirden M, Voujon D, Bossi P, Ktorza N, Bricaire F, Costagliola D, Katlama C, Peytavin G, Calvez V. Resistance profiles observed in virological failures after 24 weeks of amprenavir/ritonavir containing regimen in protease inhibitor experienced patients. J Med Virol. Sep. 2004;74(1):16-20. Rec #: 1059. [pmid: 15258963].
145 Martinez-Picado J, Morales-Lopetegi K, Wrin T, Prado JG, Frost SD, Petropoulos CJ, Clotet B, Ruiz L. Selection of drug-resistant HIV-1 mutants in response to repeated structured treatment interruptions. AIDS. Apr 12. 2002;16(6):895-9. Rec #: 1186. [pmid: 11919491].
146 Martinez-Picado, J.; Wrin, T.; Frost, S.; Clotet, B.; Ruiz, L.; Leigh Brown, A.; Petropoulos, C., and Parkin, N. Phenotypic Hypersusceptibility to Multiple Protease Inhibitors and Low Replicative Capacity in Chronically HIV-1-infected Patients. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1888
147 Masquelier B, Descamps D, Carriere I, Ferchal F, Collin G, Denayrolles M, Ruffault A, Chanzy B, Izopet J, Buffet-Janvresse C, Schmitt MP, Race E, Fleury HJ, Aboulker JP, Yeni P, Brun-Vezinet F. Zidovudine resensitization and dual HIV-1 resistance to zidovudine and lamivudine in the delta lamivudine roll-over study. Antivir Ther. 1999;4(2):69-77. Rec #: 1279. [pmid: 10682151].
148 Mayers DL. Drug-resistant HIV-1: the virus strikes back. JAMA. Jun 24. 1998;279(24):2000-2. Rec #: 1538. [pmid: 9643867].
149 Mayers DL. Prevalence and incidence of resistance to zidovudine and other antiretroviral drugs. Am J Med. May 19. 1997;102(5B):70-5. Rec #: 1233. [pmid: 9845501].
150 McClernon DR, Lanier R, Gartner S, Feaser P, Pardo CA, St Clai M, Liao Q, McArthur JC. HIV in the brain: RNA levels and patterns of zidovudine resistance. Neurology. Oct 23. 2001;57(8):1396-401. Rec #: 1203. [pmid: 11673579].
151 McGowan JP, Shah SS. Prevention of perinatal HIV transmission during pregnancy. J Antimicrob Chemother. Nov. 2000;46(5):657-68. Rec #: 1255. [pmid: 11062184].
152 McIntosh K. Antiretroviral resistance and HIV vertical transmission. Acta Paediatr Suppl. Jun. 1997;421:29-32. Rec #: 1300. [pmid: 9240854].
153 McIntyre J. Preventing mother-to-child transmission of HIV: successes and challenges. BJOG. Sep. 2005;112(9):1196-203. Rec #: 1001. [pmid: 16101596].
154 Menzo S, Castagna A, Monachetti A, Hasson H, Danise A, Carini E, Bagnarelli P, Lazzarin A, Clementi M. Genotype and phenotype patterns of human immunodeficiency virus type 1 resistance to enfuvirtide during long-term treatment. Antimicrob Agents Chemother. Sep. 2004;48(9):3253-9. Rec #: 1353. [pmid: 15328081]. [pmcid: 514784].
155 Middleton, T.; Smith, D.; Larder, B.; Law, M., and Birch, C. (Victorian Infectious Diseases Reference Laboratory, North Melbourne, Victoria, Australia. tracey.middleton@mh.org.au). Baseline antiretroviral drug susceptibility influences treatment response in patients receiving saquinavirenhancing therapy. HIV Clinical Trials. 2001; 2(6):445-52. Rec #: 1382
156 Miller MD, Hazuda DJ. HIV resistance to the fusion inhibitor enfuvirtide: mechanisms and clinical implications. Drug Resist Updat. Apr. 2004;7(2):89-95. Rec #: 1476. [pmid: 15158765].
157 Miller V, de Bethune MP, Kober A, Sturmer M, Hertogs K, Pauwels R, Stoffels P, Staszewski S. Patterns of resistance and cross-resistance to human immunodeficiency virus type 1 reverse transcriptase inhibitors in patients treated with the nonnucleoside reverse transcriptase inhibitor loviride. Antimicrob Agents Chemother. Dec. 1998;42(12):3123-9. Rec #: 1114. [pmid: 9835502]. [pmcid: 106010].
158 Miller V, Larder BA. Mutational patterns in the HIV genome and cross-resistance following nucleoside and nucleotide analogue drug exposure. Antivir Ther. 2001;6(Suppl 3):25-44. Rec #: 1201. [pmid: 11678471].
159 Mohri H, Singh MK, Ching WT, Ho DD. Quantitation of zidovudine-resistant human immunodeficiency virus type 1 in the blood of treated and untreated patients. Proc Natl Acad Sci U S A. Jan 1. 1993;90(1):25-9. Rec #: 1337. [pmid: 7678340]. [pmcid: 45592].
160 Morse, C.; Maldarelli, F.; Dewar, R.; Rehm, C., and Kovacs, J. Limited Evolution of Drug Resistane in HIV-1-infected Patients with Persistent Low-level Viremia on a Stable Antiretroviral Regimen for Longer than 1 Year. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1883
161 Mouroux M, Descamps D, Izopet J, Yvon A, Delaugerre C, Matheron S, Coutellier A, Valantin MA, Bonmarchand M, Agut H, Massip P, Costagliola D, Katlama C, Brun-Vezinet F, Calvez V. Low-rate emergence of thymidine analogue mutations and multi-drug resistance mutations in the HIV-1 reverse transcriptase gene in therapy-naive patients receiving stavudine plus lamivudine combination therapy. Antivir Ther. Sep. 2001;6(3):179-83. Rec #: 1190. [pmid: 11808752].
162 Moyle G. Resistance and cross-resistance to abacavir. HIV Med. Jul. 2001;2(3):154-62. Rec #: 1194. [pmid: 11737395].
163 Moyle GJ, Gazzard BG. Differing reverse transcriptase mutation patterns in individuals experiencing viral rebound on first-line regimens with stavudine/didanosine and stavudine/lamivudine. AIDS. Apr 13. 2001;15(6):799-800. Rec #: 1225. [pmid: 11371696].
164 Murphy MD, Marousek GI, Chou S. HIV protease mutations associated with amprenavir resistance during salvage therapy: importance of I54M. J Clin Virol. May. 2004;30(1):62-7. Rec #: 1693. [pmid: 15072756].
165 Nettles, R. E. Kieffer T. L. Simmons R. P. Cofrancesco Jr. J. MooreR. D. Gallant J. E. Persaud D. Siliciano R. F. (Dr. R.F. Siliciano, Dept. of Medicine, Johns Hopkins Univ. Sch. of Medicine, 879 Broadway Research Bldg., 733 N. Broadway, Baltimore, MD 21205. United States). Genotypic resistance in HIV-1-infected patients with persistently detectable low-level viremia while receiving highly active antiretroviral therapy. Clin Infect Dis. 2004 Oct 1; ISSN: 1058-4838. Rec #: 1493
166 Nevins AB, Rhee SY, Fessel WJ, Horberg M, Searsella A, Lee SY, Shafer RW, Zolopa AR. Virological response to antiretroviral therapy in the setting of the K65R mutation. Antivir Ther. 2005;10:S18. Rec #: 1961.
167 Newstein, M.; Martin, T.; Losikoff, P.; Caliendo, A.; Ingersoll, J.; Kurpewski, J.; Hanley, D.; Cerezo, J.; Ramratnam, B., and Cu-Uvin, S. Prevelance and Persistence of NNRTI Mutations In the Female Genital Tract. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1840
168 Nicastri E, Sarmati L, Andreoni M. Stavudine protective function and emergence of Lamivudine resistance. Antimicrob Agents Chemother. Mar. 2003;47(3):1176. author reply 1176. Rec #: 1167. [pmid: 12604569]. [pmcid: 149332].
169 Nicastri E, Sarmati L, d'Ettorre G, Parisi SG, Palmisano L, Galluzzo C, Montano M, Uccella I, Amici R, Gatti F, Vullo V, Concia E, Vella S, Andreoni M. High prevalence of M184 mutation among patients with viroimmunologic discordant responses to highly active antiretroviral therapy and outcomes after change of therapy guided by genotypic analysis. J Clin Microbiol. Jul. 2003;41(7):3007-12. Rec #: 1159. [pmid: 12843034]. [pmcid: 165358].
170 Niehues T, Walter H, Homeff G, Wahn V, Schmidt B. Selective vertical transmission of HIV: lamivudine-resistant maternal clone undetectable by conventional resistance testing. AIDS. Dec 3. 1999;13(17):2482-4. Rec #: 1599. [pmid: 10597795].
171 Nielsen C, Bruun L, Mathiesen LR, Pedersen C, Gerstoft J. Development of resistance of zidovudine (ZDV) and didanosine (ddI) in HIV from patients in ZDV, ddI and alternating ZDV/ddI therapy. AIDS. Jun. 1996;10(6):625-33. Rec #: 1310. [pmid: 8780817].
172 Nolan M, Fowler MG, Mofenson LM. Antiretroviral prophylaxis of perinatal HIV-1 transmission and the potential impact of antiretroviral resistance. J Acquir Immune Defic Syndr. Jun 1. 2002;30(2):216-29. Rec #: 1068. [pmid: 12045685].
173 Nunez M, de Mendoza C, Valer L, Casas E, Lopez-Calvo S, Castro A, Roson B, Podzamczer D, Rubio A, Berenguer J, Soriano V. Resistance mutations in HIV-infected patients experiencing early failure with nelfinavir-containing triple combinations. Med Sci Monit. Sep. 2002;8(9):CR620-3. Rec #: 1142. [pmid: 12218942].
174 Oyugi JH, Byakika-Tusiime J, Ragland K, Laeyendecker O, Mugerwa R, Kityo C, Mugyenyi P, Quinn TC, Bangsberg DR. Treatment interruptions predict resistance in HIV-positive individuals purchasing fixed-dose combination antiretroviral therapy in Kampala, Uganda. AIDS. 2007;21:1-7. Rec #: 2115. [pmid: 17148962].
175 Padzamczer, D.; Ferrer, E.; Gatell, J. M.; Niubo, J.; Dalmau, D.; Leon, A.; Knobel, H.; Iniguez, D., and Ruiz, I. Early virological failure and occurence of resistance in naive patients receiving tenofovir, didanosine and efavirenz. 2004; 9, S172. Rec #: 1947
176 Palmer, S.; Boltz, V.; Maldarelli, F.; Martinson, N.; Gray, G.; McIntyre, J.; Mellors, J.; Morris, L., and Coffin, J. Persistance of NNRTI-r Resistant Variants after Single-dose Nevirapine in HIV-1 Subtype-C-infected Women. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1831
177 Palombi, L. ; Germano, P.; Liotta, G.; Perno, C.; Narciso, P.; da Cruz Gomes, A.; Valls Blazquez, M.; Loureiro, S.; Ceffa, S.; Magnano San Lio, M.; Bartolo, M.; Guidotti, G., and Marazzi, M. HAART in Pregnancy: Safety, Effectiveness, and Protection from Viral Resistance: Results from the Dream Cohort. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1825
178 Paredes, R. ; Marconi, V.; Hoh, R.; Martin, J.; Petropoulos, C.; Deeks, S., and Kuritzkes, D. Prolonged Persistence of M184V Mutation and Phenotypic Resistance to Lamivudine in Adults with Multi-drug-resistant HIV-1 Infection Interrupting Treatment with Reverse Transcriptase Inhibitors [Interplay among HIV Resistance, Fitness and Outcome]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1767
179 Parkin NT, Deeks SG, Wrin MT, Yap J, Grant RM, Lee KH, Heeren D, Hellmanna NS, Petropoulos CJ. Loss of antiretroviral drug susceptibility at low viral load during early virological failure in treatment-experienced patients. AIDS. Dec 22. 2000;14(18):2877-87. Rec #: 1199. [pmid: 11153669].
180 Parkin NT, Schapiro JM. Antiretroviral drug resistance in non-subtype B HIV-1, HIV-2 and SIV. Antivir Ther. Feb. 2004;9(1):3-12. Rec #: 1078. [pmid: 15040531].
181 Paton NI, Aboulhab J. Hydroxychloroquine, hydroxyurea and didanosine as initial therapy for HIV-infected patients with low viral load: safety, efficacy and resistance profile after 144 weeks. HIV Med. Jan. 2005;6(1):13-20. Rec #: 1352. [pmid: 15670247].
182 Pellegrin I, Izopet J, Reynes J, Denayrolles M, Montes B, Pellegrin JL, Massip P, Puel J, Fleury H, Segondy M. Emergence of zidovudine and multidrug-resistance mutations in the HIV-1 reverse transcriptase gene in therapy-naive patients receiving stavudine plus didanosine combination therapy. STADI Group. AIDS. Sep 10. 1999;13(13):1705-9. Rec #: 1286. [pmid: 10509572].
183 Pellegrin I, Segondy M, Garrigue I, Izopet J, Montes B, Pellegrin JL, Reynes J, Massip P, Puel J, Fleury H. Phenotypic resistance pattern of HIV-1 isolates with zidovudine and/or multidrug resistance mutations after didanosine-stavudine combination therapy. J Acquir Immune Defic Syndr. Dec 15. 2000;25(5):465-6. Rec #: 1249. [pmid: 11141248].
184 Perez-Olmeda M, Rubio A, Puig T, Gomez-Cano M, Ruiz L, Leal M, Clotet B, Soriano V. Evolution of genotypic resistance to nucleoside analogues in patients receiving protease inhibitor-containing regimens. Antivir Ther. 1999;4(3):179-81. Rec #: 1163. [pmid: 12731758].
185 Persuad, D. ; Palumbo, P.; Ziemniak, C.; Havens, P.; Chadwick, E., and Pediatric AIDS Clin Trials Group P1030 Team. Acquisition and Archiving of Non-nucleoside Reverse Transcriptase Inhibitor-resistance HIV-1 Variants during Mother-to-Child Transmission in US-born Infants [Selection, Evolution, and Persistence of Drug Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006: Selection. Rec #: 1757
186 Pillay D. The emergence and epidemiology of resistance in the nucleoside-experienced HIV-infected population. Antivir Ther. 2001. 6(Suppl 3):15-24. Rec #: 1202. [pmid: 11678470].
187 Pillay D, Cane PA, Shirley J, Porter K. Detection of drug resistance associated mutations in HIV primary infection within the UK. AIDS. May 5. 2000;14(7):906-8. Rec #: 1391. [pmid: 10839606].
188 Podzamczer D, Ferrer E, Gatell JM, Niubo J, Dalmau D, Leon A, Knobel H, Polo C, Iniguez D, Ruiz I. Early virological failure with a combination of tenofovir, didanosine and efavirenz. Antivir Ther. 2005;10(1):171-7. Rec #: 1708. [pmid: 15751775].
189 Poveda E, Rodes B, Labernardiere JL, Benito JM, Toro C, Gonzalez-Lahoz J, Faudon JL, Clavel F, Schapiro J, Soriano V. Evolution of genotypic and phenotypic resistance to Enfuvirtide in HIV-infected patients experiencing prolonged virologic failure. J Med Virol. Sep. 2004;74(1):21-8. Rec #: 1354. [pmid: 15258964].
190 Poveda E, Rodes B, Lebel-Binay S, Faudon JL, Jimenez V, Soriano V. Dynamics of enfuvirtide resistance in HIV-infected patients during and after long-term enfuvirtide salvage therapy. J Clin Virol. Dec. 2005;34(4):295-301. Rec #: 1469. [pmid: 16286053].
191 Poveda E, Rodes B, Toro C, Martin-Carbonero L, Gonzalez-Lahoz J, Soriano V. Evolution of the gp41 env region in HIV-infected patients receiving T-20, a fusion inhibitor. AIDS. Sep 27. 2002;16(14):1959-61. Rec #: 1560. [pmid: 12351957].
192 Re MC, Monari P, Borderi M, Tadolini M, Verucchi G, Vitone F, Spinosa S, La Placa M. Presence of genotypic resistance to antiretroviral drugs in a cohort of therapy-naive HIV-1-infected Italian patients. J Acquir Immune Defic Syndr. Jul 1. 2001;27(3):315-6. Rec #: 1449. [pmid: 11464154].
193 Reichman RC, Tejani N, Lambert JL, Strussenberg J, Bonnez W, Blumberg B, Epstein L, Dolin R. Didanosine (ddI) and zidovudine (ZDV) susceptibilities of human immunodeficiency virus (HIV) isolates from long-term recipients of ddI. Antiviral Res. Apr. 1993;20(4):267-77. Rec #: 1334. [pmid: 8097906].
194 Rey, D.; Krebs, M.; Partisani, M.; Hess-Kempf, G.; Cheneau, C.; Priester, M.; Bernard-Henry, C.; de Mautort, E., and Lang, J. M. Early Virologic Response at 1-Month and 8-Month Median Follow-up of a New Triple NUC Combination (Zidovudine, Lamivudine, and Tenofovir) in 36 Antiretroviral-naive, HIV-1-infected Patients. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1875
195 Richman DD. AZT resistance in isolates of HIV. Immunodefic Rev. 1991;2(4):315-8. Rec #: 1344. [pmid: 2059436].
196 Richman DD, Meng TC, Spector SA, Fischl MA, Resnick L, Lai S. Resistance to AZT and ddC during long-term combination therapy in patients with advanced infection with human immunodeficiency virus. J Acquir Immune Defic Syndr. Feb. 1994;7(2):135-8. Rec #: 1329. [pmid: 7905522].
197 Richman DD. Resistance, drug failure, and disease progression. AIDS Res Hum Retroviruses. Aug. 1994;10(8):901-5. Rec #: 1136. [pmid: 7811540].
198 Rodes B, de Mendoza C, Rodgers M, Newell A, Jimenez V, Lopez-Brugada RM, Soriano V. Treatment response and drug resistance in patients infected with HIV type 1 group O viruses. AIDS Res Hum Retroviruses. Jul. 2005;21(7):602-7. Rec #: 1003. [pmid: 16060830].
199 Rodes B, Holguin A, Soriano V, Dourana M, Mansinho K, Antunes F, Gonzalez-Lahoz J. Emergence of drug resistance mutations in human immunodeficiency virus type 2-infected subjects undergoing antiretroviral therapy. J Clin Microbiol. Apr. 2000;38(4):1370-4. Rec #: 1527. [pmid: 10747109]. [pmcid: 86447].
200 Rodes B, Poveda E, Soriano V. Rapid assessment of phenotypic resistance to protease inhibitors in human immunodeficiency virus type 1 group O. J Clin Microbiol. Nov. 2002;40(11):4313-6. Rec #: 1129. [pmid: 12409418]. [pmcid: 139640].
201 Roge BT, Katzenstein TL, Nielsen HL, Gerstoft J. Drug resistance mutations and outcome of second-line treatment in patients with first-line protease inhibitor failure on nelfinavir-containing HAART. HIV Med. Jan. 2003;4(1):38-47. Rec #: 1123. [pmid: 12534958].
202 Romano L, Peduzzi C, Venturi G, Di Pietro M, Carli T, Corsi P, Gonnelli A, Valensin PE, Zazzi M. Treatment with lopinavir/ritonavir in heavily pretreated subjects failing multiple antiretroviral regimens in clinical practice. J Acquir Immune Defic Syndr. Aug 15. 2002;30(5):533-5. Rec #: 1714. [pmid: 12154345].
203 Rooke R, Tremblay M, Soudeyns H, DeStephano L, Yao XJ, Fanning M, Montaner JS, O'Shaughnessy M, Gelmon K, Tsoukas C, et al. Isolation of drug-resistant variants of HIV-1 from patients on long-term zidovudine therapy. Canadian Zidovudine Multi-Centre Study Group. AIDS. Jul. 1989;3(7):411-5. Rec #: 1346. [pmid: 2504243].
204 Rousseau MN, Vergne L, Montes B, Peeters M, Reynes J, Delaporte E, Segondy M. Patterns of resistance mutations to antiretroviral drugs in extensively treated HIV-1-infected patients with failure of highly active antiretroviral therapy. J Acquir Immune Defic Syndr. Jan 1. 2001;26(1):36-43. Rec #: 1196. [pmid: 11176267].
205 Ruane PJ, Luber AD. K65R-associated virologic failure in HIV-infected patients receiving tenofovir-containing triple nucleoside/nucleotide reverse transcriptase inhibitor regimens. MedGenMed. Apr 6. 2004;6(2):31. Rec #: 1446.
206 Ruiz L, Nijhuis M, Boucher C, Puig T, Bonjoch A, Martinez-Picado J, Marfil S, de Jong D, Burger D, Arno A, Balague M, Clotet B. Efficacy of adding indinavir to previous reverse transcriptase nucleoside analogues in relation to genotypic and phenotypic resistance development in advanced HIV-1-infected patients. J Acquir Immune Defic Syndr Hum Retrovirol. Sep 1. 1998;19(1):19-28. Rec #: 1715. [pmid: 9732064].
207 Rusconi S, De Pasquale MP, Mainini F, Bulgheroni E, Kurtagic S, Gori A, Violin M, Zanchetta N, Moroni M, Balotta C, Galli M. Viral load, viral phenotype modification, zidovudine susceptibility and reverse transcriptase mutations during the first 6 months of zidovudine monotherapy in HIV-1-infected people. Antivir Ther. Dec. 1996;1(4):211-9. Rec #: 1234. [pmid: 11324823].
208 Rusconi S, De Pasquale MP, Milazzo L, Moscatelli G, Bulgheroni E, Citterio P, d'Arminio-Monforte A, Moroni M, Galli M. Loss of antiviral effect owing to zidovudine and lamivudine double resistance in HIV-1-infected patients in an ongoing open-label trial. Antivir Ther. Jan. 1997;2(1):39-46. Rec #: 1236. [pmid: 11322265].
209 Saah AJ, Haas DW, DiNubile MJ, Chen J, Holder DJ, Rhodes RR, Shivaprakash M, Bakshi KK, Danovich RM, Graham DJ, Condra JH. Treatment with indinavir, efavirenz, and adefovir after failure of nelfinavir therapy. J Infect Dis. Apr 1. 2003;187(7):1157-62. Rec #: 1719. [pmid: 12660932].
210 Salomon H, Montaner JS, Belmonte A, Wainberg MA. Diminished HIV-1 sensitivity to stavudine in patients on prolonged therapy occurs only at low levels and cannot be attributed to any single amino acid substitution in reverse transcriptase. Antivir Ther. 1998;3(3):177-82. Rec #: 1281. [pmid: 10682135].
211 Schapiro JM, Winters MA, Lawrence J, Merigan TC. Clinical cross-resistance between the HIV-1 protease inhibitors saquinavir and indinavir and correlations with genotypic mutations. AIDS. Feb 25. 1999;13(3):359-65. Rec #: 1229. [pmid: 10199226].
212 Schapiro JM, Winters MA, Stewart F, Efron B, Norris J, Kozal MJ, Merigan TC. The effect of high-dose saquinavir on viral load and CD4+ T-cell counts in HIV-infected patients. Ann Intern Med. Jun 15. 1996;124(12):1039-50. Rec #: 1720. [pmid: 8633817].
213 Schapiro JM, Winters MA, Vierra M, Crawford S, Merigan TC. Lymph node human immunodeficiency virus RNA levels and resistance mutations in patients receiving high-dose saquinavir. J Infect Dis. Feb. 1998;177(2):477-80. Rec #: 1252. [pmid: 9466542].
214 Schmidt B, Walter H, Korn K. [Characterization of resistance in HIV. Comparison of geno- and phenotypic resistance to HIV-1 protease inhibitors]. Pharm Unserer Zeit. 2001;30(3):228-32. Rec #: 1466. [pmid: 11400672].
215 Schmit JC, Ruiz L, Clotet B, Raventos A, Tor J, Leonard J, Desmyter J, De Clercq E, Vandamme AM. Resistance-related mutations in the HIV-1 protease gene of patients treated for 1 year with the protease inhibitor ritonavir (ABT-538). AIDS. Aug. 1996;10(9):995-9. Rec #: 1260. [pmid: 8853733].
216 Schuurman R, Nijhuis M, van Leeuwen R, Schipper P, de Jong D, Collis P, Danner SA, Mulder J, Loveday C, Christopherson C, et al. Rapid changes in human immunodeficiency virus type 1 RNA load and appearance of drug-resistant virus populations in persons treated with lamivudine (3TC). J Infect Dis. Jun. 1995;171(6):1411-9. Rec #: 1317. [pmid: 7539472].
217 Schwartz, R.; Kazanjian, P.; Slater, L., and et al. Resistance to tipranavir is uncommon in a randomized trial of tipranavir/ritonavir in multiple PI-failure patients [abstract 562-T]. 9th Conference on Retroviruses and Opportunistic Infections; Seattle. Alexandria, VA: Foundation for Retrovirology and Human Health; 2002: 261. Rec #: 1588
218 Seifert LL. Development of resistance mutations to nevirapine as part of triple-drug therapy in children. Pharmacotherapy. Jan. 2002;22(1):113-7. Rec #: 1075. [pmid: 11794422].
219 Servais J, Plesseria JM, Lambert C, Fontaine E, Robert I, Arendt V, Staub T, Schneider F, Hemmer R, Schmit JC. Longitudinal use of phenotypic resistance testing to HIV-1 protease inhibitors in patients developing HAART failure. J Med Virol. Jul. 2002;67(3):312-9. Rec #: 1153. [pmid: 12116020].
220 Shafer RW, Iversen AK, Winters MA, Aguiniga E, Katzenstein DA, Merigan TC. Drug resistance and heterogeneous long-term virologic responses of human immunodeficiency virus type 1-infected subjects to zidovudine and didanosine combination therapy. The AIDS Clinical Trials Group 143 Virology Team. J Infect Dis. Jul. 1995;172(1):70-8. Rec #: 1314. [pmid: 7541064].
221 Shafer RW, Rhee SY, Pillay D, Miller V, Sandstrom P, Schapiro JM, Kuritzkes DR, Bennett D. HIV-1 protease and reverse transcriptase mutations for drug resistance surveillance. AIDS. Jan 11. 2007;21(2):215-23. Rec #: 2118. [pmid: 17197813]. [pmcid: 2573394].
222 Shafer RW, Schapiro JM. Drug resistance and antiretroviral drug development. J Antimicrob Chemother. Jun. 2005;55(6):817-20. Rec #: 1618. [pmid: 15845781]. [pmcid: 2547472].
223 Shafer RW, Winters MA, Jellinger RM, Merigan TC. Zidovudine resistance reverse transcriptase mutations during didanosine monotherapy. J Infect Dis. Aug. 1996;174(2):448-9. Rec #: 1308. [pmid: 8699089].
224 Shafer RW, Winters MA, Palmer S, Merigan TC. Multiple concurrent reverse transcriptase and protease mutations and multidrug resistance of HIV-1 isolates from heavily treated patients. Ann Intern Med. Jun 1. 1998;128(11):906-11. Rec #: 1245. [pmid: 9634429].
225 Shulman N, Zolopa AR, Passaro D, Shafer RW, Huang W, Katzenstein D, Israelski DM, Hellmann N, Petropoulos C, Whitcomb J. Phenotypic hypersusceptibility to non-nucleoside reverse transcriptase inhibitors in treatment-experienced HIV-infected patients: impact on virological response to efavirenz-based therapy. AIDS. Jun 15. 2001;15(9):1125-32. Rec #: 1573. [pmid: 11416714].
226 Shulman NS, Machekano RA, Shafer RW, Winters MA, Zolopa AR, Liou SH, Hughes M, Katzenstein DA. Genotypic correlates of a virologic response to stavudine after zidovudine monotherapy. J Acquir Immune Defic Syndr. Aug 1. 2001;27(4):377-80. Rec #: 1723. [pmid: 11468426].
227 Siegrist CA, Yerly S, Kaiser L, Wyler CA, Perrin L. Mother to child transmission of zidovudine-resistant HIV-1. Lancet. Dec 31. 1994 Dec 24-1994;344(8939-8940):1771-2. Rec #: 1324.
228 Smith MS, Koerber KL, Pagano JS. Long-term persistence of AZT-resistance mutations in the plasma HIV-1 of patients removed from AZT therapy. Leukemia. Apr. 1994;8(Suppl 1):S179-82. Rec #: 1326. [pmid: 8152287].
229 Sonnerburg A, Johansson B, Ayehunie S, Julander I. Transmission of zidovudine-resistant HIV-1. AIDS. Dec. 1993;7(12):1684-5. Rec #: 1462. [pmid: 8286086].
230 Soriano V, Miro JM, Guerrero A. Primary resistance to antiretroviral agents. Enferm Infecc Microbiol Clin. 2001;19:22-5. Rec #: 1515. [pmid: 11428054].
231 Staszewski, S.; Dauer, B.; Locher, L.; Moesch , M.; Gute, P., and Stuermer, M. Intensification of a Failing Regimen with Zidovudine May Cause Sustained Virologic Suppression in the Presence of the K65R Mutation [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1811
232 Sturmer M, Doerr HW, Staszewski S, Preiser W. Comparison of nine resistance interpretation systems for HIV-1 genotyping. Antivir Ther. Jun. 2003;8(3):239-44. Rec #: 1095. [pmid: 12924541].
233 Tremblay CL, Hicks JL, Sutton L, Giguel F, Flynn T, Johnston M, Sax PE, Walker BD, Hirsch MS, Rosenberg ES, D'Aquila RT. Antiretroviral resistance associated with supervised treatment interruptions in treated acute HIV infection. AIDS. May 2. 2003;17(7):1086-9. Rec #: 1166. [pmid: 12700462].
234 Truong, H. M.; Grant, R. M.; Wong, W.; Louie, B.; McFarland, W., and Klausner, J. D. HIV-1 drug resistance surveillance at San Francisco municipal STD clinic. 42nd Annual Meeting of IDSA; Boston, MS. 2004. Rec #: 2091
235 Turner D, Schapiro JM, Brenner BG, Wainberg MA. The influence of protease inhibitor resistance profiles on selection of HIV therapy in treatment-naive patients. Antivir Ther. Jun. 2004;9(3):301-14. Rec #: 1056. [pmid: 15259893].
236 Vaclavikova J, Weber J, Machala L, Reinis M, Linka M, Bruckova M, Vandasova J, Stankova M, Konvalinka J. Long-term analysis of the resistance development in HIV-1 positive patients treated with protease and reverse transcriptase inhibitors: correlation of the genotype and disease progression. Acta Virol. 2005;49(1):29-36. Rec #: 1015. [pmid: 15929396].
237 Valer L, Gonzalez de Requena D, de Mendoza C, Martin-Carbonero L, Gonzalez-Lahoz J, Soriano V. (Service of Infectious Diseases, Hospital Carlos III, Madrid, Spain.). Impact of drug levels and baseline genotype and phenotype on the virologic response to amprenavir/ritonavir-based salvage regimens. AIDS Patient Care and STDs. Jan. 2004;18(1):1-6. Rec #: 1364. [pmid: 15006188].
238 Vallejo A, Olivera M, Rubio A, Sanchez-Quijano A, Lissen E, Leal M. Genotypic resistance profile in treatment-experienced HIV-infected individuals after abacavir and efavirenz salvage regimen. Antiviral Res. Feb. 2004;61(2):129-32. Rec #: 1045. [pmid: 14670587].
239 Van Laethem, K.; Schrooten, Y.; Lemey, P.; Deforche, K.; Van Ranst, M.; Van Wijngaerden, E., and Vandamme, A. M. Consecutive Transmission of Dual-class Resistant HIV-1 in Untreated Patients [Epidemiology and Transmission of Resistance]. 13th Conference on Retroviruses and Opportunisitic Infections; 2006. Rec #: 1771
240 Vasudevachari MB, Zhang YM, Imamichi H, Imamichi T, Falloon J, Salzman NP. Emergence of protease inhibitor resistance mutations in human immunodeficiency virus type 1 isolates from patients and rapid screening procedure for their detection. Antimicrob Agents Chemother. Nov. 1996;40(11):2535-41. Rec #: 1258. [pmid: 8913459]. [pmcid: 163570].
241 Vella S, Palmisano L. The global status of resistance to antiretroviral drugs. Clin Infect Dis. Aug 15. 2005;41(Suppl 4):S239-46. Rec #: 1398. [pmid: 16032559].
242 Venturi G, Catucci M, Romano L, Corsi P, Leoncini F, Valensin PE, Zazzi M. Antiretroviral resistance mutations in human immunodeficiency virus type 1 reverse transcriptase and protease from paired cerebrospinal fluid and plasma samples. J Infect Dis. Feb. 2000;181(2):740-5. Rec #: 1107. [pmid: 10669367].
243 Vergne L, Paraskevis D, Vandamme AM, Delaporte E, Peeters M. High prevalence of CRF02_AG and many minor resistance-related mutations at the protease gene among HIV-infected treatment-naive immigrants in Madrid. AIDS. May 2. 2003;17(7):1105-7. Rec #: 1904. [pmid: 12700469].
244 Wainberg MA. HIV resistance to nevirapine and other non-nucleoside reverse transcriptase inhibitors. J Acquir Immune Defic Syndr. Sep. 2003;34(Suppl 1):S2-7. Rec #: 1047. [pmid: 14562852].
245 Walter H, Schmidt B, Rascu A, Helm M, Moschik B, Paatz C, Kurowski M, Korn K, Uberla K, Harrer T. Phenotypic HIV-1 resistance correlates with treatment outcome of nelfinavir salvage therapy. Antivir Ther. Dec. 2000;5(4):249-56. Rec #: 1742. [pmid: 11142619].
246 Weidle PJ, Kityo CM, Mugyenyi P, Downing R, Kebba A, Pieniazek D, Respess R, Hertogs K, De Vroey V, Dehertogh P, Bloor S, Larder B, Lackritz E. Resistance to antiretroviral therapy among patients in Uganda. J Acquir Immune Defic Syndr. Apr 15. 2001;26(5):495-500. Rec #: 1223. [pmid: 11391172].
247 Wind-Rotolo, M.; Haggerty, C.; Siliciano, J.; Kwon, P.; Cranmer, L.; Nettles, R., and Silicano, R. Archived NNRTI-resistant HIV-1 in the Resting CD4* T Cell Reservoir of Patients with a Previous History of K103N or Y181C Mutations [Selection, Evolution and Persistence of Drug Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1756
248 Winters MA, Shafer RW, Jellinger RA, Mamtora G, Gingeras T, Merigan TC. Human immunodeficiency virus type 1 reverse transcriptase genotype and drug susceptibility changes in infected individuals receiving dideoxyinosine monotherapy for 1 to 2 years. Antimicrob Agents Chemother. Apr. 1997;41(4):757-62. Rec #: 1304. [pmid: 9087484]. [pmcid: 163789].
249 Winters MA, Weng-Cherng D, Henry K, Tebas P, Valdez H, Wantman M, Katzenstein DA. Emergence of drug resistance mutations during treatment interruption in patients with undetectable viral loads. Antivir Ther. 2005;10:S37. Rec #: 1970.
250 Yang SS, Pattabiraman N, Gussio R, Pallansch L, Buckheit RW Jr, Bader JP. Cross-resistance analysis and molecular modeling of nonnucleoside reverse transcriptase inhibitors targeting drug-resistance mutations in the reverse transcriptase of human immunodeficiency virus. Leukemia. Apr. 1997;11(Suppl 3):89-92. Rec #: 1302. [pmid: 9209308].
251 Young B, Johnson S, Bahktiari M, Shugarts D, Young RK, Allen M, Ramey RR 2nd, Kuritzkes DR. Resistance mutations in protease and reverse transcriptase genes of human immunodeficiency virus type 1 isolates from patients with combination antiretroviral therapy failure. J Infect Dis. Nov. 1998;178(5):1497-501. Rec #: 1751. [pmid: 9780274].
252 Zollner B, Feucht HH, Schroter M, Schafer P, Plettenberg A, Stoehr A, Laufs R. Primary genotypic resistance of HIV-1 to the fusion inhibitor T-20 in long-term infected patients. AIDS. May 4. 2001;15(7):935-6. Rec #: 1358. [pmid: 11399967].

## Reject: First Screening - Basic Science/Cell Lines

1 Abecasis, A. B.; Deforche, K.; Snoeck, J.; Bacheler, L. T.; McKenna, P.; Carvalho, A. P.; Gomes, P. ; Camacho, R. J., and Vandamme, A. M. (A.B. Abecasis, Katholieke Universiteit Leuven, Laboratory for Clinical and Epidemiological Virology, Rega Institute for Medical Research, ). Protease mutation M89I/V is linked to therapy failure in patients infected with the HIV-1 non-B subtypes C, F or G. AIDS. 2005 Nov 4; 19(16):1799-806; ISSN: 0269-9370. Rec #: 1484
2 Adamson, C.; Salzwedel, K.; Castillo, A.; Goila-Gaur, R.; Ablan, S.; Doto, J.; Doto, J.; Li, F.; Martin, D.; Wild, C., and Freed, E. Viral Resistance to PA-457, a Novel Inhibitor of HIV-1 Maturation [HIV Drug Resistance: Mechanisms and Impact on Response to New Agents]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1782
3 Antinori A, Zaccarelli M, Cingolani A, Forbici F, Rizzo MG, Trotta MP, Di Giambenedetto S, Narciso P, Ammassari A, Girardi E, De Luca A, Perno CF. Cross-resistance among nonnucleoside reverse transcriptase inhibitors limits recycling efavirenz after nevirapine failure. AIDS Res Hum Retroviruses. Aug 10. 2002;18(12):835-8. Rec #: 1063. [pmid: 12201905].
4 Aoki, M.; Aoki, H., and Mitsuya, H. TTNTRNS: an Amino Acid Insert near the p17/p24 Gag Cleavage Site Associated with Resistance to Protease Inhibitors [Mechanisms of Resistance: Protease Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1802
5 Babic DZ, Zelnikar M, Seme K, Vandamme AM, Snoeck J, Tomazic J, Vidmar L, Karner P, Poljak M. Prevalence of antiretroviral drug resistance mutations and HIV-1 non-B subtypes in newly diagnosed drug-naive patients in Slovenia, 2000-2004. Virus Res. Jun. 2006;112(1-2):156-63. Rec #: 1624.
6 Balzarini J, Karlsson A, De Clercq E. Human immunodeficiency virus type 1 drug-resistance patterns with different 1-[(2-hydroxyethoxy)methyl]-6-(phenylthio)thymine derivatives. Mol Pharmacol. Oct. 1993;44(4):694-701. Rec #: 1141. [pmid: 7694068].
7 Balzarini J, Karlsson A, Meichsner C, Paessens A, Riess G, De Clercq E, Kleim JP. Resistance pattern of human immunodeficiency virus type 1 reverse transcriptase to quinoxaline S-2720. J Virol. Dec. 1994;68(12):7986-92. Rec #: 1133. [pmid: 7525984]. [pmcid: 237261].
8 Balzarini J, Karlsson A, Perez-Perez MJ, Camarasa MJ, Tarpley WG, De Clercq E. Treatment of human immunodeficiency virus type 1 (HIV-1)-infected cells with combinations of HIV-1-specific inhibitors results in a different resistance pattern than does treatment with single-drug therapy. J Virol. Sep. 1993;67(9):5353-9. Rec #: 1144. [pmid: 7688822]. [pmcid: 237935].
9 Barbour, J. D.; Sinclair, E.; Wrin, T.; Bates, M. S.; Segal, M. R.; Grant, R. M.; Bredt, B. M.; Martin, J. N., and Deeks, S. G. CD8+ T cell activation levels may be predicted by pol replication capacity of drug-resistant and wild-type HIV-1. 2004; 9, S74. Rec #: 1917
10 Bates, M.; Flandre, P.; Ryan, K.; Marcelin, A. G.; Maa, J. F.; Seekins, D.; Chappey, C.; Calvez, V.; Bernard, M. C., and Molina, J. M. Prediction of Early HIV-1 RNA Reduction in the Jaguar Study Using Phenotypic Susceptibility to Didanosine. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1834
11 Becher F, Pruvost AG, Schlemmer DD, Creminon CA, Goujard CM, Delfraissy JF, Benech HC, Grassi JJ. Significant levels of intracellular stavudine triphosphate are found in HIV-infected zidovudine-treated patients. AIDS. Mar 7. 2003;17(4):555-61. Rec #: 1524. [pmid: 12598776].
12 Beck IA, Mahalanabis M, Pepper G, Wright A, Hamilton S, Langston E, Frenkel LM. Rapid and sensitive oligonucleotide ligation assay for detection of mutations in human immunodeficiency virus type 1 associated with high-level resistance to protease inhibitors. J Clin Microbiol. Apr. 2002;40(4):1413-9. Rec #: 1559. [pmid: 11923366]. [pmcid: 140364].
13 Becker-Pergola G, Kataaha P, Johnston-Dow L, Fung S, Jackson JB, Eshleman SH. Analysis of HIV type 1 protease and reverse transcriptase in antiretroviral drug-naive Ugandan adults. AIDS Res Hum Retroviruses. May 20. 2000;16(8):807-13. Rec #: 1628. [pmid: 10826487].
14 Beerenwinkel N, Schmidt B, Walter H, Kaiser R, Lengauer T, Hoffmann D, Korn K, Selbig J. Diversity and complexity of HIV-1 drug resistance: a bioinformatics approach to predicting phenotype from genotype. Proc Natl Acad Sci U S A. Jun 11. 2002;99(12):8271-6. Rec #: 1181. [pmid: 12060770]. [pmcid: 123057].
15 Bennett, D.; Rhee, S. Y.; Pillay, D.; Miller, V.; Sandstrom, P.; Schapiro, J.; Kuritzkes, D., and Shafer, R. HIV-1 Protease and Reverse Transcriptase Mutations for HIV Drug Resistance Epidemiology and Surveillance [Epidemiology and Transmission of Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1821
16 Bennett DE, Winters MA, Shafer RW, Heneine W, McCormick L, Johnson J, Garcia-Lerma JG, Zaidi I, Weinstock H. Concordance of HIV drug resistance genotyping results for paired PBMC and plasma specimens from persons newly diagnosed with HIV. Antivir Ther. 2005;10:S176. Rec #: 2000.
17 Bezemer, D.; de Ronde, A.; Prins, M.; Back, N.; Berkhout, B.; van der Hoek, L., and CASCADE. Evolution of Resistant HIV-1 Strains after Transmission. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1881
18 Biasin, M.; Magri, G.; Trabattoni, D.; Lissoni, F.; Kanari, Y.; Fasano, F.; Bergamaschi, C.; Piacentini, L.; Myazawa, M., and Clerici, M. Genetic Correlates of Resistance to HIV Infection . 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1856
19 Brann, T.; Dewar, R.; Jiang, M. K.; Shah, A.; Metcalf, J.; Falloon, J.; Lane, C., and Imamichi, T. Emergence of Amino Acid INsertion in HIV-1 Protease at Codon 19 and Amino Acid Changes at Codons 21 and 22 Leading to High-level of Resistance to Some but Not All Protease Inhibitors. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1848
20 Brehm, J.; Koontz, D.; Pathak, V.; Sluis-Cremer, N., and Mellors, J. Does 3′-Azidothymidine Select Mutations in the RNase H Domain of HIV-1 Reverse Transcriptase? [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1793
21 Brodard, V. Moret H. Beguinot I. Morcrette L. Bourdaire L. JacquesJ. Rouger C. Strady C. Berger J. L. Andreoletti L. (Dr. V. Brodard, Laboratoire de Virologie, Centre Hospitalier Universitaire, Faculte de Medecine, Reims. France). Prevalence of detection and dynamics of selection and reversion of K65R mutation in nucleoside reverse transcriptase inhibitor-experienced patients failing an antiretroviral regimen [2]. J Acquir Immune Defic Syndr. 2005 Jun; 39(2):250-3; ISSN: 1525-4135. Rec #: 1489
22 Brown AJ, Precious HM, Whitcomb JM, Wong JK, Quigg M, Huang W, Daar ES, D'Aquila RT, Keiser PH, Connick E, Hellmann NS, Petropoulos CJ, Richman DD, Little SJ. Reduced susceptibility of human immunodeficiency virus type 1 (HIV-1) from patients with primary HIV infection to nonnucleoside reverse transcriptase inhibitors is associated with variation at novel amino acid sites. J Virol. Nov. 2000;74(22):10269-73. Rec #: 1093. [pmid: 11044070]. [pmcid: 110900].
23 Brun-Vezinet F, Descamps D, Ruffault A, Masquelier B, Calvez V, Peytavin G, Telles F, Morand-Joubert L, Meynard JL, Vray M, Costagliola D. Clinically relevant interpretation of genotype for resistance to abacavir. AIDS. Aug 15. 2003;17(12):1795-802. Rec #: 1154. [pmid: 12891065].
24 Ceccherini-Silberstein F, Svicher V, Sing T, Santoro M, Beerenwinkel N, Gago F, Bertoli A, Forbici F, Bellocchi MC, Narciso P, d'Arminio Monforte A, Antinori A, Perno CF. Involvement of novel HIV-1 reverse transcriptase mutations in the highly ordered regulation of NRTI resistance. Antivir Ther. 2005;10:S106. Rec #: 1974.
25 Cerqueira DM, Amorim RM, Silva RR, Camara GN, Brigido MM, Martins CR. Antiretroviral resistance and genetic diversity of human immunodeficiency virus type 1 isolates from the Federal District, Central Brazil. Mem Inst Oswaldo Cruz. Dec. 2004;99(8):877-82. Rec #: 1028. [pmid: 15761606].
26 Chen Z, Li Y, Schock HB, Hall D, Chen E, Kuo LC. Three-dimensional structure of a mutant HIV-1 protease displaying cross-resistance to all protease inhibitors in clinical trials. J Biol Chem. Sep 15. 1995;270(37):21433-6. Rec #: 1556. [pmid: 7665551].
27 Cheung P, Woods C, Harrigan PR. Systematic comparison of prevalence of mutation in large database reveals rarely selected mutational pairs. Antivir Ther. 2005;10:S142. Rec #: 1988.
28 Chu, C. K.; Yadav, V.; Rapp, K.; Chong, Y., and Schinazi, R. Dioxolane Thymine Nucleoside Is Active against a Variety of NRTI-resistant Mutants. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1861
29 Collins JA, Thompson MG, Paintsil E, Ricketts M, Gedzior J, Alexander L. Competitive fitness of nevirapine-resistant human immunodeficiency virus type 1 mutants. J Virol. Jan. 2004;78(2):603-11. Rec #: 1043. [pmid: 14694092]. [pmcid: 368761].
30 Condra JH, Holder DJ, Schleif WA, Blahy OM, Danovich RM, Gabryelski LJ, Graham DJ, Laird D, Quintero JC, Rhodes A, Robbins HL, Roth E, Shivaprakash M, Yang T, Chodakewitz JA, Deutsch PJ, Leavitt RY, Massari FE, Mellors JW, Squires KE, Steigbigel RT, Teppler H, Emini EA. Genetic correlates of in vivo viral resistance to indinavir, a human immunodeficiency virus type 1 protease inhibitor. J Virol. Dec. 1996;70(12):8270-6. Rec #: 1643. [pmid: 8970946]. [pmcid: 190914].
31 Condra JH, Petropoulos CJ, Ziermann R, Schleif WA, Shivaprakash M, Emini EA. Drug resistance and predicted virologic responses to human immunodeficiency virus type 1 protease inhibitor therapy. J Infect Dis. Sep. 2000;182(3):758-65. Rec #: 1211. [pmid: 10950769].
32 Cornelissen M, van den Burg R, Zorgdrager F, Lukashov V, Goudsmit J. pol gene diversity of five human immunodeficiency virus type 1 subtypes: evidence for naturally occurring mutations that contribute to drug resistance, limited recombination patterns, and common ancestry for subtypes B and D. J Virol. Sep. 1997;71(9):6348-58. Rec #: 1644. [pmid: 9261352]. [pmcid: 191908].
33 Cozz-Lepri, A.; Ruiz, L.; Ceccherini-Silberstein, F.; Mocroft, A.; Phillips, A.; Gatell, J.; Ledergerber, B.; Reiss, P.; Clotet, B.; Lundgren, J., and EuroSIDA Study Group . Mutation at Reverse Transcriptase Codon 214 is Antagonist to Thymidine Analogue Mutations Type 2 Profiles and Predicts Virological Response to Thymidine Analogue-contanin cART Regimens only if TAM Type 1 Profiles Are Concomitantly Detected [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1798
34 D'Aquila RT, Schapiro JM, Brun-Vezinet F, Clotet B, Conway B, Demeter LM, et al. Drug resistance mutations in HIV-1. Topics in HIV Medicine. 2002;10:21-5. Rec #: 1514. [pmid: 12717052].
35 De Clercq E. HIV resistance to reverse transcriptase inhibitors. Biochem Pharmacol. Jan 20. 1994;47(2):155-69. Rec #: 1138. [pmid: 7508227].
36 de Leal E S, Holmes EC, Zanotto PM. Distinct patterns of natural selection in the reverse transcriptase gene of HIV-1 in the presence and absence of antiretroviral therapy. Virology. Aug 1. 2004;325(2):181-91. Rec #: 1355. [pmid: 15246258].
37 Deeks SG. International perspectives on antiretroviral resistance. Nonnucleoside reverse transcriptase inhibitor resistance. J Acquir Immune Defic Syndr. Mar 1. 2001;26(Suppl 1):S25-33. Rec #: 1090. [pmid: 11264999].
38 Delaunay C, Brun-Vezinet F, Landman R, Collin G, Peytavin G, Trylesinski A, Flandre P, Miller M, Descamps D. Comparative selection of the K65R and M184V/I mutations in human immunodeficiency virus type 1-infected patients enrolled in a trial of first-line triple-nucleoside analog therapy (Tonus IMEA 021). J Virol. Aug. 2005;79(15):9572-8. Rec #: 1010. [pmid: 16014919]. [pmcid: 1181609].
39 Dumans AT, Soares MA, Machado ES, Hue S, Brindeiro RM, Pillay D, Tanuri A. Synonymous genetic polymorphisms within Brazilian human immunodeficiency virus Type 1 subtypes may influence mutational routes to drug resistance. J Infect Dis. Apr 1. 2004;189(7):1232-8. Rec #: 1648. [pmid: 15031792].
40 Dykes, C. and Demeter, L. Development of a Cell Culture Assay to Predict which Non-Nucleoside Reverse Transcriptase Inhibitor-resistant Variants Will Emerge during Clinical Therapy [Selection, Evolution and Persistance of Drug Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1754
41 Dykes C; Najjar J; Bosch RJ; Wantman M; Furtado M; Hart S; Hammer SM, and Demeter LM (University of Rochester School of Medicine and Dentistry, Rochester, New York 14642, USA.). Detection of drug-resistant minority variants of HIV-1 during virologic failure of indinavir, lamivudine, and zidovudine. J Infect Dis. 2004 Mar; 189(6):1091-6. Rec #: 1362
42 Eiros JM, Blanco R, Labayru C, Hernandez B, Mayo A, Ortiz de Lejarazu R. [Genotypic resistence in patients infected with HIV and its correlation with therapy]. Med Clin (Barc). Apr 30. 2005;124(16):601-5. Rec #: 1475. [pmid: 15871775].
43 Emini EA, Byrnes VW, Condra JH, Schleif WA, Sardana VV. The genetic and functional basis of HIV-1 resistance to nonnucleoside reverse transcriptase inhibitors. Arch Virol Suppl. 1994;9:11-7. Rec #: 1140. [pmid: 7518271].
44 Emini EA, Graham DJ, Gotlib L, Condra JH, Byrnes VW, Schleif WA. HIV and multidrug resistance. Nature. Aug 19. 1993;364(6439):679. Rec #: 1333.
45 Flandre P, Descamps D, Joly V, Meiffredy V, Tamalet C, Izopet J, Brun-Vezinet F. A survival method to estimate the time to occurrence of mutations: an application to thymidine analogue mutations in HIV-1-infected patients. J Infect Dis. Mar 1. 2004;189(5):862-70. Rec #: 1112. [pmid: 14976604].
46 Fonjungo PN, Mpoudi EN, Torimiro JN, Alemnji GA, Eno LT, Lyonga EJ, Nkengasong JN, Lal RB, Rayfield M, Kalish ML, Folks TM, Pieniazek D. Human immunodeficiency virus type 1 group m protease in cameroon: genetic diversity and protease inhibitor mutational features. J Clin Microbiol. Mar. 2002;40(3):837-45. Rec #: 1652. [pmid: 11880402]. [pmcid: 120267].
47 Frankel, F.; Turner, D.; Brenner, B.; Quan, Y., and Wainberg, M. The L74V Mutation in HIV-1 RT Diminishes Synthesis of Viral DNA in Real-time PCR and Impairs Rescue of ZDV-terminated DNA Synthesis. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1889
48 Frankel, F.; Turner, D.; Spira, B., and Wainberg, M. Molecular Characterization of HIV-1 Reverse Transcriptase Harboring the K65R and L74V Mutations [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1800
49 Fransen, S.; Whitcomb, J.; Wrin, T.; Toma, J.; Petropoulos, C., and Huang, W. Both HIV-1 gp120 and gp41 Envelope Glycoproteins Contribute to Natural Variability in Enfuvirtide Susceptibility [Mechanisms of Drug Resistance: Entry Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; c2006. Rec #: 1787
50 Freeman GA, Andrews CW Iii 3rd, Hopkins AL, Lowell GS, Schaller LT, Cowan JR, Gonzales SS, Koszalka GW, Hazen RJ, Boone LR, Ferris RG, Creech KL, Roberts GB, Short SA, Weaver K, Reynolds DJ, Milton J, Ren J, Stuart DI, Stammers DK, Chan JH. Design of non-nucleoside inhibitors of HIV-1 reverse transcriptase with improved drug resistance properties. 2. J Med Chem. Nov 18. 2004;47(24):5923-36. Rec #: 1025. [pmid: 15537347].
51 Frost SD, McLean AR. Quasispecies dynamics and the emergence of drug resistance during zidovudine therapy of HIV infection. AIDS. Mar. 1994;8(3):323-32. Rec #: 1327. [pmid: 7913327].
52 Frost SDW, Kosakovsky Pond SL, Smith DM, Richman DD, Leigh Brown AJ. Using mixtures of amino acids to detect individual- and population-level selection of HIV-1 protease. Antivir Ther. 2005;10:S173. Rec #: 1999.
53 Gallego O, Martin-Carbonero L, Aguero J, de Mendoza C, Corral A, Soriano V. Correlation between rules-based interpretation and virtual phenotype interpretation of HIV-1 genotypes for predicting drug resistance in HIV-infected individuals. J Virol Methods. Oct. 2004;121(1):115-8. Rec #: 1081. [pmid: 15350741].
54 Geretti AM, Sabin C, Dunn D, Nebbia G. Mutations at reverse transcriptase (RT) codons G196, Q207, R211 and L214 are associated with drug experience and specific RT mutation patterns. Antivir Ther. 2005;10:S104. Rec #: 1973.
55 Gilbert PB, Hanna GJ, De Gruttola V, Martinez-Picado J, Kuritzkes DR, Johnson VA, Richman DD, D'Aquila RT. Comparative analysis of HIV type 1 genotypic resistance across antiretroviral trial treatment regimens. AIDS Res Hum Retroviruses. Sep 20. 2000;16(14):1325-36. Rec #: 1096. [pmid: 11018852].
56 Gingeras TR, Prodanovich P, Latimer T, Guatelli JC, Richman DD, Barringer KJ. Use of self-sustained sequence replication amplification reaction to analyze and detect mutations in zidovudine-resistant human immunodeficiency virus. J Infect Dis. Dec. 1991;164(6):1066-74. Rec #: 1342. [pmid: 1955709].
57 Giuliano M, Palmisano L, Galluzzo CM, Amici R, Germinario E, Okong P, Kituuka P, Mmirro F, Magoni M, Vella S. Selection of resistance mutations in pregnant women receiving zidovudine and lamivudine to prevent HIV perinatal transmission. AIDS. Jul 4. 2003;17(10):1570-2. Rec #: 2107. [pmid: 12824800].
58 Gomes, P.; Diogo, I., and Goncalves, M. F. Different pathways to nelfinavir in HIV-1 subtypes B and C. 9th Conference on retroviruses and opportunistic infections; Seattle. 2002. Rec #: 1532
59 Gonzales MJ, Johnson E, Dupnik KM, Imamichi T, Shafer RW. Colinearity of reverse transcriptase inhibitor resistance mutations detected by population-based sequencing. J Acquir Immune Defic Syndr. Dec 1. 2003;34(4):398-402. Rec #: 1611. [pmid: 14615657]. [pmcid: 2573396].
60 Gonzales MJ, Machekano RN, Shafer RW. Human immunodeficiency virus type 1 reverse-transcriptase and protease subtypes: classification, amino acid mutation patterns, and prevalence in a northern California clinic-based population. J Infect Dis. Oct 15. 2001;184(8):998-1006. Rec #: 1616. [pmid: 11574914]. [pmcid: 2597357].
61 Gonzales MJ, Wu TD, Taylor J, Belitskaya I, Kantor R, Israelski D, Chou S, Zolopa AR, Fessel WJ, Shafer RW. Extended spectrum of HIV-1 reverse transcriptase mutations in patients receiving multiple nucleoside analog inhibitors. AIDS. Apr 11. 2003;17(6):791-9. Rec #: 1612. [pmid: 12660525]. [pmcid: 2573403].
62 Gotte M, Arion D, Parniak MA, Wainberg MA. The M184V mutation in the reverse transcriptase of human immunodeficiency virus type 1 impairs rescue of chain-terminated DNA synthesis. J Virol. Apr. 2000;74(8):3579-85. Rec #: 1518. [pmid: 10729133]. [pmcid: 111867].
63 Greenberg ML, Cammack N. Resistance to enfuvirtide, the first HIV fusion inhibitor. J Antimicrob Chemother. Aug. 2004;54(2):333-40. Rec #: 1356. [pmid: 15231762].
64 Greenberg, M. L.; Melby, T.; Sista, P.; DeMassi, R.; Cammarck, N.; Salago, M., and et al. Baseline and on-treatment susceptibility to Enfuvirtide seen in TORO1 and TORO2 to 24 weeks. 10th Conference on Retroviruses and Opportunistic Infections; Boston. 2003. Rec #: 1512
65 Grinsztejn, B.; Nguyen, B. Y.; Katlama, C.; Gatell, J.; Lazzarin , A.; Vittecoq, D.; Gonzalez, C.; Chen, J.; Isaacs, R., and Protocol 005 Study Team. Potent Antiretroviral Effect of MK-0518, a Novel HIV-1 Integrase Inhibitor, in Patients with Triple-class Resistant Virus [HIV Drug Resistance: Mechanisms and Impact on Response to New Agents]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1784
66 Grossman Z, Maayan S, Averbuch D, Istomin V, Rudich H, Ram D, Mendelson E, Deforche K, Vandamme AM, Schapiro JM. Substitution of methionine at position 89 of the protease gene by other amino-acids occurs differentially during selection of particular resistance pathways in subtype C-patients. Antivir Ther. 2005;10:S115. Rec #: 1977.
67 Gurusinghe AD, Land SA, Birch C, McGavin C, Hooker DJ, Tachedjian G, Doherty R, Deacon NJ. Reverse transcriptase mutations in sequential HIV-1 isolates in a patient with AIDS. J Med Virol. Jul. 1995;46(3):238-43. Rec #: 1657. [pmid: 7561796].
68 Haas, D. W.; Ribaudo, H.; Kim, R.; Tierney, C.; Wildinson, G.; Gulick, R.; Clifford, D.; Marzolini, C., and Acosta, E. Pharmacogenetics of Efavirenz and Selective Pressure for Drug Resistance after Treatment Discontinuation: NWCS214, an Analysis of ACTG Studies A5095/A5097S. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1839
69 Hackett, J. Natural polymorphisms associated with resistance to protease inhibitors in non-subtype B HIV-1 Strains. 2nd International AIDS Society Conference on HIV pathogenesis and treatment; Paris. 2003. Rec #: 1531
70 Hantson, A.; Witvrouw, M.; Hombrouck, A.; Vercammen, J.; Tetz, V.; Pannecouque, C.; Engelborghs, Y.; De Clercq, E., and Debyser, Z. The V165I and T206S/S230N Mutations in HIV-1 Integrase Confer Resistance to the Pyranodipyrimidine V-165 and Reduce Replication Capacity. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1859
71 Harrigan PR, Salim M, Stammers DK, Wynhoven B, Brumme ZL, McKenna P, Larder B, Kemp SD. A mutation in the 3′ region of the human immunodeficiency virus type 1 reverse transcriptase (Y318F) associated with nonnucleoside reverse transcriptase inhibitor resistance. J Virol. Jul. 2002;76(13):6836-40. Rec #: 1660. [pmid: 12050397]. [pmcid: 136283].
72 Havlir DV, Eastman S, Gamst A, Richman DD. Nevirapine-resistant human immunodeficiency virus: kinetics of replication and estimated prevalence in untreated patients. J Virol. Nov. 1996;70(11):7894-9. Rec #: 1124. [pmid: 8892912]. [pmcid: 190861].
73 Henry M, Tourres C, Colson P, Tamalet C. The coexistence of K65R+L74V on the same HIV genome is rare but possible as evidenced by cloning analysis. Antivir Ther. 2005;10:S107. Rec #: 1975.
74 Henry, M.; Yahi, N.; Fantini, J.; Tourres, C., and Tamalet, C. Structual Analysis of Reverse Transcriptase Mutations at Codon 215 Explains the Predominance of T215Y over T215F in HIV-1 Variants Selected under ART [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1796
75 Hertogs K, de Bethune MP, Miller V, Ivens T, Schel P, Van Cauwenberge A, Van Den Eynde C, Van Gerwen V, Azijn H, Van Houtte M, Peeters F, Staszewski S, Conant M, Bloor S, Kemp S, Larder B, Pauwels R. A rapid method for simultaneous detection of phenotypic resistance to inhibitors of protease and reverse transcriptase in recombinant human immunodeficiency virus type 1 isolates from patients treated with antiretroviral drugs. Antimicrob Agents Chemother. Feb. 1998;42(2):269-76. Rec #: 1530. [pmid: 9527771]. [pmcid: 105399].
76 Ho DD, Toyoshima T, Mo H, Kempf DJ, Norbeck D, Chen CM, Wideburg NE, Burt SK, Erickson JW, Singh MK. Characterization of human immunodeficiency virus type 1 variants with increased resistance to a C2-symmetric protease inhibitor. J Virol. Mar. 1994;68(3):2016-20. Rec #: 1662. [pmid: 8107264]. [pmcid: 236669].
77 Holguin A, Paxinos E, Hertogs K, Womac C, Soriano V. Impact of frequent natural polymorphisms at the protease gene on the in vitro susceptibility to protease inhibitors in HIV-1 non-B subtypes. J Clin Virol. Nov. 2004;31(3):215-20. Rec #: 1663. [pmid: 15465415].
78 Huang W, Gamarnik A, Limoli K, Petropoulos CJ, Whitcomb JM. Amino acid substitutions at position 190 of human immunodeficiency virus type 1 reverse transcriptase increase susceptibility to delavirdine and impair virus replication. J Virol. Jan. 2003;77(2):1512-23. Rec #: 1664. [pmid: 12502865]. [pmcid: 140843].
79 Huigen, M.; Van Ham, P.; De Graaf, L.; Boucher, C., and Nijhuis, M. A Novel and Rare Amino Acid Substitution E40F in HIV-1 Reverse Transcriptase Increases Zidovudine Resistance and Decreases Replication Capacity [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1795
80 Ibanez A, Clotet B, Martinez MA. Human immunodeficiency virus type 1 population bottleneck during indinavir therapy causes a genetic drift in the env quasispecies. J Gen Virol. Jan. 2000;81(Pt 1):85-95. Rec #: 1665. [pmid: 10640545].
81 Imamichi T, Sinha T, Imamichi H, Zhang YM, Metcalf JA, Falloon J, Lane HC. High-level resistance to 3′-azido-3′-deoxythimidine due to a deletion in the reverse transcriptase gene of human immunodeficiency virus type 1. J Virol. Jan. 2000;74(2):1023-8. Rec #: 1666. [pmid: 10623768]. [pmcid: 111626].
82 Iversen AK, Shafer RW, Wehrly K, Winters MA, Mullins JI, Chesebro B, Merigan TC. Multidrug-resistant human immunodeficiency virus type 1 strains resulting from combination antiretroviral therapy. J Virol. Feb. 1996;70(2):1086-90. Rec #: 1312. [pmid: 8551567]. [pmcid: 189915].
83 Jacobsen H, Yasargil K, Winslow DL, Craig JC, Krohn A, Duncan IB, Mous J. Characterization of human immunodeficiency virus type 1 mutants with decreased sensitivity to proteinase inhibitor Ro 31-8959. Virology. Jan 10. 1995;206(1):527-34. Rec #: 1668. [pmid: 7831807].
84 Johnson, J.; Van Rompay, K.; Delwart, E., and Heneine, W. Rapid Emergence of Drug-resistant SIV in Tenofovir-treated Macaques: Implication for Tenofovir Chemoprophylaxis against HIV [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1801
85 Johnston E, Dupnik KM, Gonzales MJ, Winters MA, Rhee SY, Imamichi T, Shafer RW. Panel of prototypical infectious molecular HIV-1 clones containing multiple nucleoside reverse transcriptase inhibitor resistance mutations. AIDS. Apr 29. 2005;19(7):731-3. Rec #: 1669. [pmid: 15821401]. [pmcid: 2573397].
86 Jones D, Parkin N, Hudelson SE, Guay LA, Musoke P, Mmiro F, Jackson JB, Eshleman SH. Genetic linkage of nevirapine resistance mutations in HIV type 1 seven days after single-dose nevirapine. AIDS Res Hum Retroviruses. Apr. 2005;21(4):319-24. Rec #: 1004. [pmid: 15943576].
87 Kagan R, Blick G, Heseltine P, Lewinski M. Prevalence and analysis of a multi-drug resistant HIV-1 PR and RT genotype associated with rapid progression to AIDS in a large clinical database. Antivir Ther. 2005;10:S141. Rec #: 1987.
88 Kaiser, S.; Stahmer, I.; Van Lunzen, J.; Fenner, T.; Eiermann, T.; Mocklinghoff, C., and Stellbrink, H. Effect of NRTI- and NNRTI-resistance Mutations on CTL Recognition [Selection, Evolution and Persistance of Drug Resistance]. 13th Conference on Retroviruses and Oppotunistic Infections; 2006. Rec #: 1759
89 Kantor R, Fessel WJ, Zolopa AR, Israelski D, Shulman N, Montoya JG, Harbour M, Schapiro JM, Shafer RW. Evolution of primary protease inhibitor resistance mutations during protease inhibitor salvage therapy. Antimicrob Agents Chemother. Apr. 2002;46(4):1086-92. Rec #: 1615. [pmid: 11897594]. [pmcid: 127108].
90 Kantor R, Katzenstein DA, Efron B, Carvalho AP, Wynhoven B, Cane P, Clarke J, Sirivichayakul S, Soares MA, Snoeck J, Pillay C, Rudich H, Rodrigues R, Holguin A, Ariyoshi K, Bouzas MB, Cahn P, Sugiura W, Soriano V, Brigido LF, Grossman Z, Morris L, Vandamme AM, Tanuri A, Phanuphak P, Weber JN, Pillay D, Harrigan PR, Camacho R, Schapiro JM, Shafer RW. Impact of HIV-1 subtype and antiretroviral therapy on protease and reverse transcriptase genotype: results of a global collaboration. PLoS Med. Apr. 2005;2(4):e112. Rec #: 1442. [pmid: 15839752].
91 Kellam P, Boucher CA, Larder BA. Fifth mutation in human immunodeficiency virus type 1 reverse transcriptase contributes to the development of high-level resistance to zidovudine. Proc Natl Acad Sci U S A. Mar 1. 1992;89(5):1934-8. Rec #: 1673. [pmid: 1371886]. [pmcid: 48568].
92 Kemp SD, Shi C, Bloor S, Harrigan PR, Mellors JW, Larder BA. A novel polymorphism at codon 333 of human immunodeficiency virus type 1 reverse transcriptase can facilitate dual resistance to zidovudine and L-2′,3′-dideoxy-3′-thiacytidine. J Virol. Jun. 1998;72(6):5093-8. Rec #: 1544. [pmid: 9573280]. [pmcid: 110074].
93 Kempf DJ, Isaacson JD, King MS, Brun SC, Xu Y, Real K, Bernstein BM, Japour AJ, Sun E, Rode RA. Identification of genotypic changes in human immunodeficiency virus protease that correlate with reduced susceptibility to the protease inhibitor lopinavir among viral isolates from protease inhibitor-experienced patients. J Virol. Aug. 2001;75(16):7462-9. Rec #: 1558. [pmid: 11462018]. [pmcid: 114981].
94 Kitchen, C.; Krogstad, P., and Kitchen, S. Decreased Viral Fitness in Resistance-associated Mutations in vivo [Interplay among HIV Resistance, Fitness and Outcome]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1766
95 Kitchen, C.; Shi, B.; Weiser, B.; Philpott, S.; Suchard, M.; Anastos, K.; Meyer, W.; Back, S.; Parker, M., and Burger, H. Evolution and Recombination of Genes Encoding Drug Resistance and Co-receptor Usage during ART [Mechanisms of Drug Resistance: Entry Inhibitors]. 13th Conferenence on Retroviruses and Opportunistic Infections; 2006. Rec #: 1792
96 Koch, S.; Gavegnano, C.; Rose, S.; Pomeroy, S.; Dunn, B.; Sleasman, J., and Goodenow, M. Gag Mutations are Dominant Determinants of Replicative Fitness and Drug Sensitivity in a Protease Inhibitor-resistant HIV-1 Variant [Mechanisms of Resistance: Protease Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1803
97 Kodama, E.; Masuda, N.; Orita, M.; Yamamoto, O.; Fujii, M.; Kageyama, S.; Ohta, M.; Hatta, T.; Inoue, H.; Suzuki, H.; Sudo, K.; Shimizu, Y., and Matsuoka, M. HIV-1 Acquires Resistance to New NNRTI, Thiazol Derivatives, through Steric Hindrance with Multiple Mutations. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1865
98 Koh, Y.; Nakata, H.; Ogata-Aoki, H.; Leschenko, S.; Ghosh, A., and Mitsuya, H. UIC-02031: A Novel Nonpeptidic Protease Inhibitor Containing a Stereochemically Defined Fused Cyclopentanyltetrahydrofuran Potent against Multi-PI-Resistant HIV-1 in Vitro. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1866
99 Konings FA, Nyambi PN. V118I substitution in the reverse transcriptase gene of HIV type 1 CRF02_AG strains infecting drug-naive individuals in Cameroon. AIDS Res Hum Retroviruses. Jun. 2004;20(6):673-8. Rec #: 1677. [pmid: 15242545].
100 Koval, C. and Demeter, L. L74V Compensates for the Fitness Defect of K103N+L 100I. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1849
101 Kozal M. Cross-resistance patterns among HIV protease inhibitors. AIDS Patient Care STDS. Apr. 2004;18(4):199-208. Rec #: 1065. [pmid: 15142350].
102 Kozal MJ, Huppler Hullsick K, Leduc R, et al. Prevalence and impact of protease codon 33 mutations/polymorphisms in treatment-naive and treatment-experienced patients enrolling in clinical trials. Antivir Ther. 2005;10:S28. Rec #: 1966.
103 Lanier ER, Givens N, Stone C, Griffin P, Gibb D, Walker S, Tisdale M, Irlbeck D, Underwood M, St Clair M, Ait-Khaled M. Effect of concurrent zidovudine use on the resistance pathway selected by abacavir-containing regimens. HIV Med. Nov. 2004;5(6):394-9. Rec #: 1680. [pmid: 15544690].
104 Larder BA. 3′-Azido-3′-deoxythymidine resistance suppressed by a mutation conferring human immunodeficiency virus type 1 resistance to nonnucleoside reverse transcriptase inhibitors. Antimicrob Agents Chemother. Dec. 1992;36(12):2664-9. Rec #: 1681. [pmid: 1282792]. [pmcid: 245525].
105 Larder BA, Bloor S, Kemp SD, Hertogs K, Desmet RL, Miller V, Sturmer M, Staszewski S, Ren J, Stammers DK, Stuart DI, Pauwels R. A family of insertion mutations between codons 67 and 70 of human immunodeficiency virus type 1 reverse transcriptase confer multinucleoside analog resistance. Antimicrob Agents Chemother. Aug. 1999;43(8):1961-7. Rec #: 1683. [pmid: 10428920]. [pmcid: 89398].
106 Larder BA, Darby G, Richman DD. HIV with reduced sensitivity to zidovudine (AZT) isolated during prolonged therapy. Science. Mar 31. 1989;243(4899):1731-4. Rec #: 1347. [pmid: 2467383].
107 Larder BA, Kellam P, Kemp SD. Convergent combination therapy can select viable multidrug-resistant HIV-1 in vitro. Nature. Sep 30. 1993;365(6445):451-3. Rec #: 1143. [pmid: 7692302].
108 Larder BA, Kemp SD, Harrigan PR. Potential mechanism for sustained antiretroviral efficacy of AZT-3TC combination therapy. Science. Aug 4. 1995;269(5224):696-9. Rec #: 1682. [pmid: 7542804].
109 Lebel-Binay, S.; Thibaut, L.; Dam, E.; Faudon, J. L.; Cheret, A.; Hill, A., and Clavel, F. Synergistic Activity of Atazanavir and Saquinavir on Viruses with Low Saquinavir and High Atazanavir Resistance. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1893
110 Lee CG, Gottesman MM, Cardarelli CO, Ramachandra M, Jeang KT, Ambudkar SV, Pastan I, Dey S. HIV-1 protease inhibitors are substrates for the MDR1 multidrug transporter. Biochemistry. Mar 17. 1998;37(11):3594-601. Rec #: 1540. [pmid: 9530286].
111 Lee, E.; Kantor, R.; Johnston, E.; Kassaye, S.; Zijenah, L.; Katzenstein, D., and HPTN023. Clonal Analysis of Drug-resistant Mutations in Plasma and Breast Milk following Single-dose Nevirapine. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1900
112 Lennerstrand J, Stammers DK, Larder BA. Biochemical mechanism of human immunodeficiency virus type 1 reverse transcriptase resistance to stavudine. Antimicrob Agents Chemother. Jul. 2001;45(7):2144-6. Rec #: 1684. [pmid: 11408240]. [pmcid: 90617].
113 Loemba H, Brenner B, Parniak MA, Ma'ayan S, Spira B, Moisi D, Oliveira M, Detorio M, Wainberg MA. Genetic divergence of human immunodeficiency virus type 1 Ethiopian clade C reverse transcriptase (RT) and rapid development of resistance against nonnucleoside inhibitors of RT. Antimicrob Agents Chemother. Jul. 2002;46(7):2087-94. Rec #: 1685. [pmid: 12069959]. [pmcid: 127309].
114 Lorenzi P, Opravil M, Hirschel B, Chave JP, Furrer HJ, Sax H, Perneger TV, Perrin L, Kaiser L, Yerly S. Impact of drug resistance mutations on virologic response to salvage therapy. Swiss HIV Cohort Study. AIDS. Feb 4. 1999;13(2):F17-21. Rec #: 1477. [pmid: 10202819].
115 Loveday, C. ; MacRae, E., and Johnson, M. A. The changing prevalence of HIV-1 protease (PR) and reverse transcriptase (RT) polymorphisms in primary HIV infection (PHI), chronic-naive, and following exposure to antiretroviral therapy (ART). 2004; 9, S93. Rec #: 1922
116 Maass G, Immendoerfer U, Koenig B, Leser U, Mueller B, Goody R, Pfaff E. Viral resistance to the thiazolo-iso-indolinones, a new class of nonnucleoside inhibitors of human immunodeficiency virus type 1 reverse transcriptase. Antimicrob Agents Chemother. Dec. 1993;37(12):2612-7. Rec #: 1332. [pmid: 7509144]. [pmcid: 192754].
117 Maldarelli, F.; Kearney, M.; Palmer, S.; Polis, M.; Mican, J.; Stephens, R.; Rock, D.; Mellors, J., and Coffin, J. Recombination is Frequent in HIV-1 Populations in both Drug Naive and Drug-resistant Patients. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1842
118 Malim, M. H. Tenth Annual Bernard Fields Memorial Lecture Natural Resistance to HIV Infection: The Vif - APOBEC Interaction. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1822
119 Mammano F, Petit C, Clavel F. Resistance-associated loss of viral fitness in human immunodeficiency virus type 1: phenotypic analysis of protease and gag coevolution in protease inhibitor-treated patients. J Virol. Sep. 1998;72(9):7632-7. Rec #: 1243. [pmid: 9696866]. [pmcid: 110025].
120 Marcelin, A.; Roquebert, B.; Malet, I.; Wirden, M.; Katlama, C., and Calvez, V. Role of HIV-1 Mminority Populations on Resistance Mutational Patterns Evolution after Nelfinavir Failure and Susceptibility to Protease Inhibitors, 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1846
121 Marcelin AG, Roquebert B, Malet I, Wirden M, Simon A, Katlama C, Calvez V. Relationship between mutations in HIV-1 RNase H domain and nucleoside reverse transcriptase inhibitors resistance mutations in experienced patients. Antivir Ther. 2005;10:S98. Rec #: 1971.
122 Markowitz M, Mo H, Kempf DJ, Norbeck DW, Bhat TN, Erickson JW, Ho DD. Selection and analysis of human immunodeficiency virus type 1 variants with increased resistance to ABT-538, a novel protease inhibitor. J Virol. Feb. 1995;69(2):701-6. Rec #: 1690. [pmid: 7815532]. [pmcid: 188631].
123 Maroldo, L. ; Coakley, E.; Chappey, C.; Fransen, S.; Toma, J.; Whitcomb, J.; Huang, W., and Petropoulos, C. Rapid Selection of High-level Resistance to Enfuvirtide. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1894
124 Martinez-Picado, J.; DePasquale, M. P., and Kartsonis, N. A. Selection of antiretroviral resistance in the latent reservoir of human immunodeficiency virus type 1 during succesful therapy. 7th Conference On Retroviruses And Opportunistic Infections; San Francisco. 2000. Rec #: 1535
125 Mas A, Vazquez-Alvarez BM, Domingo E, Menendez-Arias L. Multidrug-resistant HIV-1 reverse transcriptase: involvement of ribonucleotide-dependent phosphorolysis in cross-resistance to nucleoside analogue inhibitors. J Mol Biol. Oct 18. 2002;323(2):181-97. Rec #: 1174. [pmid: 12381314].
126 McColl DJ, Margot NA, Wulfsohn M, Coakley DF, Cheng AK, Miller MD. Patterns of resistance emerging in HIV-1 from antiretroviral-experienced patients undergoing intensification therapy with tenofovir disoproxil fumarate. J Acquir Immune Defic Syndr. Nov 1. 2004;37(3):1340-50. Rec #: 1069. [pmid: 15483463].
127 Mercelin, A. G.; Flandre, P.; Pavie, J.; Schmidely, N.; Wirden, M.; Lada, O. Ciche D.; Bernard, M. C.; Moina, J. M., and Calvez, V. New genotypic score comprising mutations impacting negatively and positively the virological response to didanosine in treatment-experienced patients from the randomized didanosine add on Jaguar study. 2004; 9, S146. Rec #: 1937
128 Mihailidis, C.; Dunn, D.; Pillay, D., and Pozniak, A. Transmission of HIV-1 containing V118I in reverse transcriptase dose not compromise response to first line therapy. 2004; 9, S117. Rec #: 1935
129 Miller V, Phillips A, Rottmann C, Staszewski S, Pauwels R, Hertogs K, de Bethune MP, Kemp SD, Bloor S, Harrigan PR, Larder BA. Dual resistance to zidovudine and lamivudine in patients treated with zidovudine-lamivudine combination therapy: association with therapy failure. J Infect Dis. Jun. 1998;177(6):1521-32. Rec #: 1294. [pmid: 9607829].
130 Miranda, L. R. and Gotte, M. Differential Effects of L74V and M184V Mutations on ATP-mediated Primer Unblocking in HIV-1 Reverse Transcriptase Carrying Thymidine Analog Resistance Mutations . 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1887
131 Mohri, H.; Jean-Pierre, P.; Berry, L.; Kim, A.; Chung, C.; Manuelli, V.; Boden, D.; Mehandru, S.; Shet, A., and Markowitz, M. Replication Characteristics of Transmitted Multi-drug-resistant HIV-1 Isolates from Recently Infected, ART-naive Patients [Interplay among HIV Resistance, Fitness and Outcome]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1765
132 Molina JM, Cordoba J, Gobernado M. [Resistance of HIV-1 to antiretroviral drugs in Valencia (Spain): mutations and susceptibility]. Rev Esp Quimioter. Sep. 2003;16(3):308-12. Rec #: 1479. [pmid: 14702123].
133 Mosley, M.; Smith-Burchnell, C.; Mori, J.; Lewis, M.; Stockdale, M.; Huang, W.; Whitcomb, J.; Petropoulos, C.; Perros, M., and Westby, M. Resistance to the CCR5 Antagonist Maraviroc Is Characterized by Dose-Response Curves that Display a Reduction in Maximal Inhibition [Mechanisms of Drug Resistance: Entry Inhibitor]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1790
134 Mulato AS, Lamy PD, Miller MD, Li WX, Anton KE, Hellmann NS, Cherrington JM. Genotypic and phenotypic characterization of human immunodeficiency virus type 1 variants isolated from AIDS patients after prolonged adefovir dipivoxil therapy. Antimicrob Agents Chemother. Jul. 1998;42(7):1620-8. Rec #: 1293. [pmid: 9660994]. [pmcid: 105656].
135 Myint, L.; Tomita, Y.; Matsuda, M.; Nishizawa, M.; Miura, H.; Sato, H.; Yamamoto, N., and Sugiura, W. Impaired Intracellular Gag Trafficking and Viral Assembly in Protease Inhibitor Resistant HIV-1: New Mechanism of Viral Fitness Reduction in Drug Resistant Viruses. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1886
136 Myint, L.; Ueda, T.; Nishizawa, M.; Shiino, T.; Matsuda, M., and Sugiura, W. Virological and Statistical Analyses of Interference between Protease Inhibitor-resistant Mutations and Gag Mutations [Mechanisms of Resistance: Protease Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1805
137 Najera I, Richman DD, Olivares I, Rojas JM, Peinado MA, Perucho M, Najera R, Lopez-Galindez C. Natural occurrence of drug resistance mutations in the reverse transcriptase of human immunodeficiency virus type 1 isolates. AIDS Res Hum Retroviruses. Nov. 1994;10(11):1479-88. Rec #: 1134. [pmid: 7534096].
138 Nguyen MH, Schinazi RF, Shi C, Goudgaon NM, McKenna PM, Mellors JW. Resistance of human immunodeficiency virus type 1 to acyclic 6-phenylselenenyl- and 6-phenylthiopyrimidines. Antimicrob Agents Chemother. Oct. 1994;38(10):2409-14. Rec #: 1135. [pmid: 7840579]. [pmcid: 284753].
139 Nicastri E, Sarmati L, Andreoni M, Parisi SG. Human immunodeficiency virus polymorphisms and zidovudine resistance. Antimicrob Agents Chemother. Aug. 2003;47(8):2714. author reply 2714–5. Rec #: 1157. [pmid: 12878551]. [pmcid: 166074].
140 Nijhuis M, Schuurman R, de Jong D, Erickson J, Gustchina E, Albert J, Schipper P, Gulnik S, Boucher CA. Increased fitness of drug resistant HIV-1 protease as a result of acquisition of compensatory mutations during suboptimal therapy. AIDS. Dec 3. 1999;13(17):2349-59. Rec #: 1557. [pmid: 10597776].
141 Nijhuis M, Schuurman R, de Jong D, van Leeuwen R, Lange J, Danner S, Keulen W, de Groot T, Boucher CA. Lamivudine-resistant human immunodeficiency virus type 1 variants (184V) require multiple amino acid changes to become co-resistant to zidovudine in vivo. J Infect Dis. Aug. 1997;176(2):398-405. Rec #: 1553. [pmid: 9237704].
142 Nissley DV, Julias J, Flys T, Hughes S, Mellors J, Jackson JB, Strathern J, Eshleman SH. A sensitive phenotypical assay uncovers low frequency NNRTI-resistant HIV-1 RT variants in subtypes A, B, C and D from clinical samples. Antivir Ther. 2005;10:S149. Rec #: 1994.
143 Ntemgwa, M. ; Wainberg, M.; Spira, B.; Oliveira, M.; Moisi, D., and Brenner, B. Natural Polymorphisms in HIV-1/HIV-2 Protease Can Accelerate Time to Development of Resistance to Protease Inhibitors [Mechanisms of Resistance: Protease Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1804
144 Palmer S, Margot N, Gilbert H, Shaw N, Buckheit R Jr, Miller M. Tenofovir, adefovir, and zidovudine susceptibilities of primary human immunodeficiency virus type 1 isolates with non-B subtypes or nucleoside resistance. AIDS Res Hum Retroviruses. Aug 10. 2001;17(12):1167-73. Rec #: 1697. [pmid: 11522186].
145 Palmer S, Shafer RW, Merigan TC. Highly drug-resistant HIV-1 clinical isolates are cross-resistant to many antiretroviral compounds in current clinical development. AIDS. Apr 16. 1999;13(6):661-7. Rec #: 1696. [pmid: 10397560]. [pmcid: 2566777].
146 Parkin, N. T. and Chappey, C. Protease Mutations Associated with Higher or Lower than Expected Tipranavir Susceptibility Based on the TPV Mutation Score [Impact of Resistant on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1813
147 Parkin NT, Hellmann NS, Whitcomb JM, Kiss L, Chappey C, Petropoulos CJ. Natural variation of drug susceptibility in wild-type human immunodeficiency virus type 1. Antimicrob Agents Chemother. Feb. 2004;48(2):437-43. Rec #: 1083. [pmid: 14742192]. [pmcid: 321508].
148 Patick, A. K. Mo H. Markowitz M. Appelt K. Wu B. Musick L. KalishV. Kaldor S. Reich S. Ho D. Webber S. (Department of Pharmacology, Agouron Pharmaceuticals, Inc.). Antiviral and resistance studies of AG1343, an orally bioavailable inhibitor of human immunodeficiency virus protease. Antimicrob Agents Chemother. 1996 Feb; 40(2):292-7; ISSN: 0066-4804. Rec #: 1507
149 Petropoulos, C.; Huang, W.; Toma, J.; Fransen, S.; Bonhoeffer, S., and Whitcomb, J. Resistance to HIV Chemokine Receptor Antagonists. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1824
150 Phillips, A. N. Projection to 2010 of Trends in Multi-drug-resistant HIV in Infectious Gay Men [Epidemiology and Transmission of Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1776
151 Pierre de Bethune, M.; Andries, K.; Azijn, H.; Guillemont, J.; Heeres, J.; Vingerhoets, J.; Lewi, P.; Lee, E.; Timmerman, P., and Williams, P. TMC278, a New Potent NNRTI, with an Increased Barrier to Resistance and Good Pharmacokinetic Profile. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1863
152 Prado JG, Wrin T, Beauchaine J, Ruiz L, Petropoulos CJ, Frost SD, Clotet B, D'Aquila RT, Martinez-Picado J. Amprenavir-resistant HIV-1 exhibits lopinavir cross-resistance and reduced replication capacity. AIDS. May 3. 2002;16(7):1009-17. Rec #: 1709. [pmid: 11953467].
153 Quinones-Mateu ME, Albright JL, Mas A, Soriano V, Arts EJ. Analysis of pol gene heterogeneity, viral quasispecies, and drug resistance in individuals infected with group O strains of human immunodeficiency virus type 1. J Virol. Nov. 1998;72(11):9002-15. Rec #: 1710. [pmid: 9765445]. [pmcid: 110317].
154 Quiros E, Torti C, Carosi G. HIV and resistance to antiretroviral therapy Original>Virus De La Inmunodeficiencia Humana Y Resistencia a La Terapia Antirretrovirica. Enfermedades Infecciosas y Microbiologia Clinica. 2000;18(5):234-237. Rec #: 1425. [pmid: 10974768].
155 Quiros-Roldan E, Airoldi M, Moretti F, Fausti C, Pan A, Casari S, Torti C, Castelli F, Carosi G. Genotype resistance profiles in patients failing an NNRTI-containing regimen, and modifications after stopping NNRTI therapy. J Clin Lab Anal. 2002;16(2):76-8. Rec #: 1070. [pmid: 11948795].
156 Rayner MM, Cordova B, Jackson DA. Population dynamics studies of wild-type and drug-resistant mutant HIV in mixed infections. Virology. Sep 15. 1997;236(1):85-94. Rec #: 1118. [pmid: 9299620].
157 Reeves, J.; Lee, F. H.; Miamidian J.; Jabara, C.; Juntilla, M., and Doms, R. Enfuvirtide Resistance Mutations: Effect on HIV Envelope Function , Entry Inhibition, and Neutralization. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1847
158 Reeves JD, Lee FH, Miamidian JL, Jabara CB, Juntilla MM, Doms RW. Enfuvirtide resistance mutations: impact on human immunodeficiency virus envelope function, entry inhibitor sensitivity, and virus neutralization. J Virol. Apr. 2005;79(8):4991-9. Rec #: 1349. [pmid: 15795284]. [pmcid: 1069568].
159 Rhee SY, Fessel WJ, Zolopa AR, Hurley L, Liu T, Taylor J, Nguyen DP, Slome S, Klein D, Horberg M, Flamm J, Follansbee S, Schapiro JM, Shafer RW. HIV-1 Protease and reverse-transcriptase mutations: correlations with antiretroviral therapy in subtype B isolates and implications for drug-resistance surveillance. J Infect Dis. Aug 1. 2005;192(3):456-65. Rec #: 1607. [pmid: 15995959]. [pmcid: 2597526].
160 Rhee SY, Gonzales MJ, Kantor R, Betts BJ, Ravela J, Shafer RW. Human immunodeficiency virus reverse transcriptase and protease sequence database. Nucleic Acids Res. Jan 1. 2003;31(1):298-303. Rec #: 1617. [pmid: 12520007]. [pmcid: 165547].
161 Rhee SY, Kantor R, Katzenstein DA, Camacho R, Morris L, Sirivichayakul S, Jorgensen L, Brigido LF, Schapiro JM, Shafer RW. HIV-1 pol mutation frequency by subtype and treatment experience: extension of the HIVseq program to seven non-B subtypes. AIDS. Mar 21. 2006;20(5):643-651. Rec #: 1606. [pmid: 16514293]. [pmcid: 2551321].
162 Rhee SY, Liu T, Ravela J, Gonzales MJ, Shafer RW. Distribution of human immunodeficiency virus type 1 protease and reverse transcriptase mutation patterns in 4,183 persons undergoing genotypic resistance testing. Antimicrob Agents Chemother. Aug. 2004;48(8):3122-6. Rec #: 1609. [pmid: 15273130]. [pmcid: 478552].
163 Richman DD, Guatelli JC, Grimes J, Tsiatis A, Gingeras T. Detection of mutations associated with zidovudine resistance in human immunodeficiency virus by use of the polymerase chain reaction. J Infect Dis. Dec. 1991;164(6):1075-81. Rec #: 1343. [pmid: 1720152].
164 Richman DD, Havlir D, Corbeil J, Looney D, Ignacio C, Spector SA, Sullivan J, Cheeseman S, Barringer K, Pauletti D, et al. Nevirapine resistance mutations of human immunodeficiency virus type 1 selected during therapy. J Virol. Mar. 1994;68(3):1660-6. Rec #: 1137. [pmid: 7509000]. [pmcid: 236624].
165 Romano L, Venturi G, Bloor S, Harrigan R, Larder BA, Major JC, Zazzi M. Broad nucleoside-analogue resistance implications for human immunodeficiency virus type 1 reverse-transcriptase mutations at codons 44 and 118. J Infect Dis. Apr 1. 2002;185(7):898-904. Rec #: 1713. [pmid: 11920313].
166 Ross, L.; Parkin, N.; Underwood, M.; Gerondelis, P.; St Clair, M., and Lanier, E. Comparison of the Phenotypic Effects of NRTI Mutations on Emtricitabine and Lamivudine. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1891
167 Ross, L.; Parkin, N.; Underwood, M.; Gerondelis, P.; St Clair, M., and Lanier, R. In a Paired-sample Comparison, the Presence of Thymidine Analogue Mutations, but not Other Common Nucleoside Reverse Transcriptase Inhibitor Mutations Has a Differential Effect on Emtricitabine and Lamivudine Susceptibility [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1794
168 Rubsamen-Waigmann H, Schroder B, Biesert L, Bauermeister CD, von Briesen H, Suhartono H, Zimmermann F, Brede HD, Regeniter A, Gerte S, et al. Markers for HIV-disease progression in untreated patients and patients receiving AZT: evaluation of viral activity, AZT resistance, serum cholesterol, beta 2-microglobulin, CD4+ cell counts, and HIV antigen. Infection. 1991;19(Suppl 2):S77-82. Rec #: 1345. [pmid: 1673119].
169 Rusconi S, La Seta Catamancio S, Citterio P, Kurtagic S, Violin M, Balotta C, Moroni M, Galli M, d'Arminio-Monforte A. Susceptibility to PNU-140690 (Tipranavir) of human immunodeficiency virus type 1 isolates derived from patients with multidrug resistance to other protease inhibitors. Antimicrob Agents Chemother. May. 2000;44(5):1328-32. Rec #: 1716. [pmid: 10770770]. [pmcid: 89863].
170 Sa-Filho DJ, Costa LJ, de Oliveira CF, Guimaraes AP, Accetturi CA, Tanuri A, Diaz RS. Analysis of the protease sequences of HIV-1 infected individuals after Indinavir monotherapy. J Clin Virol. Oct. 2003;28(2):186-202. Rec #: 1717. [pmid: 12957189].
171 Samri, A.; Marcelin A.G.; Costagliola, D.; Cukierman, L.; Agher, R.; Calvez, V.; Duvivier, C.; Katlama, C., and Autran, B. Cross-reactive CD8 T Cells that Recognize both Wild Type and Mutated HIV-1 RT Sequence Are Detected in HIV-infected Patients Treated by RT Inhibitors with Persistent Low Viral Load. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1836
172 Schmidt B, Walter H, Moschik B, Paatz C, van Vaerenbergh K, Vandamme AM, Schmitt M, Harrer T, Uberla K, Korn K. Simple algorithm derived from a geno-/phenotypic database to predict HIV-1 protease inhibitor resistance. AIDS. Aug 18. 2000;14(12):1731-8. Rec #: 1206. [pmid: 10985309].
173 Schols, D.; Vermeire, K.; Fransen, S.; Huang, W.; Whitcomb, J.; Petropoulos, C.; Calandra, G., and Bridger, G. Multi-drug Resistant HIV-1 is Sensitive to Inhibition by Chemokine Receptor Antagonists. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1837
174 Scudeller L, Torti C, Quiros-Roldan E, Patroni A, Lo Caputo S, Moretti F, Mazzotta F, Donati E, Vivarelli A, Carosi G. HIV susceptibility to amprenavir: phenotype-based versus rules-based interpretations. J Antimicrob Chemother. Nov. 2003;52(5):776-81. Rec #: 1089. [pmid: 14563897].
175 Servais J, Lambert C, Karita E, Vanhove D, Fischer A, Baurith T, Schmit JC, Schneider F, Hemmer R, Arendt V. HIV type 1 pol gene diversity and archived nevirapine resistance mutation in pregnant women in Rwanda. AIDS Res Hum Retroviruses. Mar. 2004;20(3):279-83. Rec #: 1040. [pmid: 15117451].
176 Sevigny, G.; Stranix, B.; Tian, B.; Dubois, A.; Sauve, G.; Petropoulos, C.; Lie, Y.; Hellmann, N.; Conway, B., and Yelle, J. Antiviral activity and cross-resistance profile of P-1946, a novel human immunodeficiency virus type 1 protease inhibitor. Antiviral Res. 2006 Jan 20. Rec #: 1722
177 Sevin AD, DeGruttola V, Nijhuis M, Schapiro JM, Foulkes AS, Para MF, Boucher CA. Methods for investigation of the relationship between drug-susceptibility phenotype and human immunodeficiency virus type 1 genotype with applications to AIDS clinical trials group 333. J Infect Dis. Jul. 2000;182(1):59-67. Rec #: 1217. [pmid: 10882582].
178 Shafer RW. Genotypic testing for human immunodeficiency virus type 1 drug resistance. Clin Microbiol Rev. Apr. 2002;15(2):247-77. Rec #: 1619. [pmid: 11932232]. [pmcid: 118066].
179 Shafer, R. W.; Dupnik, K. M.; Winters, M. A., and Eshleman, S. H. A guide to HIV-1 reverse transcriptase and protease sequencing for drug resistance studies. Human Retroviruses and AIDS, Theoretical Biology and Biophysics. Los Alamos National Laboratories. Rec #: 1620
180 Shulman NS, Delgado J, Bosch RJ, Winters MA, Johnston E, Shafer RW, Katzenstein DA, Merigan TC. Nonnucleoside reverse transcriptase inhibitor phenotypic hypersusceptibility can be demonstrated in different assays. J Acquir Immune Defic Syndr. May 1. 2005;39(1):78-81. Rec #: 1011. [pmid: 15851917].
181 Sluis-Cremer, N.; Argoti Torres, P.; Grzybowski, J.; Parikh, U., and Mellors, J. Molecular Mechanism of Tenofovir, Abacavir, and Lamivudine Resistance by the K70E Mutation in HIV-1 Reverse Transcriptase [HIV Drug Resistance: Mechanisms and Impact on Response to New Agents]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1780
182 Soriano V, de Mendoza C. Genetic mechanisms of resistance to protease inhibitors and entry inhibitors. HIV Clin Trials. Jun 30. 2002 May-2002;3(3):249-57. Rec #: 1156.
183 Tantillo C, Ding J, Jacobo-Molina A, Nanni RG, Boyer PL, Hughes SH, Pauwels R, Andries K, Janssen PA, Arnold E. Locations of anti-AIDS drug binding sites and resistance mutations in the three-dimensional structure of HIV-1 reverse transcriptase. Implications for mechanisms of drug inhibition and resistance. J Mol Biol. Oct 28. 1994;243(3):369-87. Rec #: 1526. [pmid: 7525966].
184 Tee KK, Pon CK, Kamarulzaman A, Ng KP. Emergence of HIV-1 CRF01_AE/B unique recombinant forms in Kuala Lumpur, Malaysia. AIDS. Jan 28. 2005;19(2):119-26. Rec #: 1727. [pmid: 15668536].
185 Thomson MM, Villahermosa ML, Vazquez-de-Parga E, Cuevas MT, Delgado E, Manjon N, Medrano L, Perez-Alvarez L, Contreras G, Carrillo MG, Salomon H, Najera R. Widespread circulation of a B/F intersubtype recombinant form among HIV-1-infected individuals in Buenos Aires, Argentina. AIDS. May 5. 2000;14(7):897-9. Rec #: 1728. [pmid: 10839601].
186 Tirado, G.; Jove, G.; Reyes, E.; Sepulveda, G.; Yamamura, Y., and Kumar, A. Differential Evolution of Cell-free and Cell-associated HIV-1 in Blood and Vaginal Tract. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1882
187 Tisdale M, Myers RE, Maschera B, Parry NR, Oliver NM, Blair ED. Cross-resistance analysis of human immunodeficiency virus type 1 variants individually selected for resistance to five different protease inhibitors. Antimicrob Agents Chemother. Aug. 1995;39(8):1704-10. Rec #: 1732. [pmid: 7486905]. [pmcid: 162812].
188 Torti C, Quiros-Roldan E, Keulen W, Scudeller L, Lo Caputo S, Boucher C, Castelli F, Mazzotta F, Pierotti P, Been-Tiktak AM, Buccoliero G, De Gennaro M, Carosi G, Tinelli C. Comparison between rules-based human immunodeficiency virus type 1 genotype interpretations and real or virtual phenotype: concordance analysis and correlation with clinical outcome in heavily treated patients. J Infect Dis. Jul 15. 2003;188(2):194-201. Rec #: 1104. [pmid: 12854073].
189 Torti C, Quiros-Roldan E, Monno L, Patroni A, Saracino A, Angarano G, Tinelli C, Lo Caputo S, Tirelli V, Mazzotta F, Carosi G. Drug resistance mutations and newly recognized treatment-related substitutions in the HIV-1 protease gene: prevalence and associations with drug exposure and real or virtual phenotypic resistance to protease inhibitors in two clinical cohorts of antiretroviral experienced patients. J Med Virol. Sep. 2004;74(1):29-33. Rec #: 1058. [pmid: 15258965].
190 Torti C, Quiros-Roldan E, Monno L, Patroni A, Saracino A, Angarano G, Tinelli C, Mazzotta F, Lo Caputo S, Pierotti P, Carosi G. HIV-1 resistance to dideoxynucleoside reverse transcriptase inhibitors: genotypic-phenotypic correlations. J Acquir Immune Defic Syndr. Aug 15. 2004;36(5):1104-7. Rec #: 1418. [pmid: 15247566].
191 Turner D, Brenner B, Moisi D, Detorio M, Cesaire R, Kurimura T, Mori H, Essex M, Maayan S, Wainberg MA. Nucleotide and amino acid polymorphisms at drug resistance sites in non-B-subtype variants of human immunodeficiency virus type 1. Antimicrob Agents Chemother. Aug. 2004;48(8):2993-8. Rec #: 1736. [pmid: 15273111]. [pmcid: 478480].
192 Turner, D.; Brenner, B.; Moisi, D.; Detorio, M.; Kurimura, T.; Essex, M., and Wainberg, M. A. Nucleotide and amino acid polymorphisms at drug resistance sites in non-B subtype HIV-1 variants. 2004; 9, S99. Rec #: 1924
193 Underwood, M.; St Clair, M.; Ross, L.; Gerondelis, P.; Parkin, N., and Lanier, R. Cross-resistance of Clinical Samples with K65R, L74V, and M184V Mutations. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1892
194 Vaillancourt M, Irlbeck D, Smith T, Coombs RW, Swanstrom R. The HIV type 1 protease inhibitor saquinavir can select for multiple mutations that confer increasing resistance. AIDS Res Hum Retroviruses. Mar 1. 1999;15(4):355-63. Rec #: 1230. [pmid: 10082119].
195 van de Vijver DA, Wensing AM, Angarano G, Asjo B, Balotta C, Boeri E, Camacho R, Chaix ML, Costagliola D, De Luca A, Derdelinckx I, Grossman Z, Hamouda O, Hatzakis A, Hemmer R, Hoepelman A, Horban A, Korn K, Kucherer C, Leitner T, Loveday C, MacRae E, Maljkovic I, de Mendoza C, Meyer L, Nielsen C, Op de Coul EL, Ormaasen V, Paraskevis D, Perrin L, Puchhammer-Stockl E, Ruiz L, Salminen M, Schmit JC, Schneider F, Schuurman R, Soriano V, Stanczak G, Stanojevic M, Vandamme AM, Van Laethem K, Violin M, Wilbe K, Yerly S, Zazzi M, Boucher CA. The calculated genetic barrier for antiretroviral drug resistance substitutions is largely similar for different HIV-1 subtypes. J Acquir Immune Defic Syndr. Mar. 2006;41(3):352-60. Rec #: 1903. [pmid: 16540937].
196 van de Vijver, D. A. M. C.; Wensing, A. M. J.; Angarano, G., and et al. The calculated genetic barrier for drug resistance mutations in six different non-B subtypes and two CRFs in a large European dataset is largely similar to subtype B. 2004; 9, S98. Rec #: 1923
197 Van Laethem K, Van Vaerenbergh K, Schmit JC, Sprecher S, Hermans P, De Vroey V, Schuurman R, Harrer T, Witvrouw M, Van Wijngaerden E, Stuyver L, Van Ranst M, Desmyter J, De Clercq E, Vandamme AM. Phenotypic assays and sequencing are less sensitive than point mutation assays for detection of resistance in mixed HIV-1 genotypic populations. J Acquir Immune Defic Syndr. Oct 1. 1999;22(2):107-18. Rec #: 1268. [pmid: 10843523].
198 Van Laethem K, Witvrouw M, Balzarini J, Schmit JC, Sprecher S, Hermans P, Leal M, Harrer T, Ruiz L, Clotet B, Van Ranst M, Desmyter J, De Clercq E, Vandamme AM. Patient HIV-1 strains carrying the multiple nucleoside resistance mutations are cross-resistant to abacavir. AIDS. Mar 10. 2000;14(4):469-71. Rec #: 1272. [pmid: 10770556].
199 Vardavas, R. and Blower, S. Stochastic Evolution of Drug-resistant Strains of HIV in Botswana [Selection, Evolution and Persistence of Drug Resistance]. 13th Conference on Retroviruses and Oppotunistic Infections; 2006. Rec #: 1761
200 Vicente AC, Agwale SM, Otsuki K, Njouku OM, Jelpe D, Idoko JA, Caride E, Brindeiro RM, Tanuri A. Genetic variability of HIV-1 protease from Nigeria and correlation with protease inhibitors drug resistance. Virus Genes. Mar. 2001;22(2):181-6. Rec #: 1740. [pmid: 11324755].
201 Vidal N, Koyalta D, Richard V, Lechiche C, Ndinaromtan T, Djimasngar A, Delaporte E, Peeters M. High genetic diversity of HIV-1 strains in Chad, West Central Africa. J Acquir Immune Defic Syndr. Jun 1. 2003;33(2):239-46. Rec #: 1741. [pmid: 12794561].
202 Walter H, Schmidt B, Werwein M, Schwingel E, Korn K. Prediction of abacavir resistance from genotypic data: impact of zidovudine and lamivudine resistance in vitro and in vivo. Antimicrob Agents Chemother. Jan. 2002;46(1):89-94. Rec #: 1743. [pmid: 11751116]. [pmcid: 126991].
203 Wang, J.; Dykes, C.; Domaoal, R.; Koval, C.; Bambara, R., and Demeter, L. The Efavirenz-resistant Reverse Transcriptase Mutants G190S and G190A Demonstrate Reductions in RNase Activity that Correlate with Reductions in HIV-1 Replication Fitness. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1885
204 Watkins, T. Resch W. Irlbeck D. Swanstrom R. (R. Swanstrom, CB7295 Lineberger Bldg., University of North Carolina, Chapel Hill, NC 27599. United States). Selection of high-level resistance to human immunodeficiency virus type 1 protease inhibitors. Antimicrob Agents Chemother. 2003 Feb; 47(2):759-69; ISSN: 0066-4804. Rec #: 1495
205 Wei X, Decker JM, Liu H, Zhang Z, Arani RB, Kilby JM, Saag MS, Wu X, Shaw GM, Kappes JC. Emergence of resistant human immunodeficiency virus type 1 in patients receiving fusion inhibitor (T-20) monotherapy. Antimicrob Agents Chemother. Jun. 2002;46(6):1896-905. Rec #: 1357. [pmid: 12019106]. [pmcid: 127242].
206 Westreich, D.; Van Rie, A.; Behets, F.; Eron, J., and Van Der Horst, C. Nevirapine Resistance and Survival of Women Receiving HAART Subsequent to prevention of Mother-to-Child Transmission: A Population-based Stochastic Model. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1827
207 Whitcomb JM, Parkin NT, Chappey C, Hellmann NS, Petropoulos CJ. Broad nucleoside reverse-transcriptase inhibitor cross-resistance in human immunodeficiency virus type 1 clinical isolates. J Infect Dis. Oct 1. 2003;188(7):992-1000. Rec #: 1149. [pmid: 14513419].
208 Winters, B. ; Rinehart, A.; Montaner, J.; Harrigan, P.; Castor, D.; Hammer, S.; Wasikowski, B.; Miller, M.; Emery, S.; van Leth, F.; Robinson, P.; Baxter, J.; Gazzard, B.; Pozniak, A., and Bacheler, L. Validation of Clinically Relevant Breakpoints for HIV-1 Phenotypic Resistance Data. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1850
209 Winters MA, Rhee SY, Horberg M, Searsella A, Zolopa A, Lee SY, Fessel WJ, Shafer RW. N88D facilitiates the development of multidrug resistance following nelfinvair treatment failure. Antivir Ther. 2005;10:S110. Rec #: 1976.
210 Wolf K, Walter H, Beerenwinkel N, Keulen W, Kaiser R, Hoffmann D, Lengauer T, Selbig J, Vandamme AM, Korn K, Schmidt B. Tenofovir resistance and resensitization. Antimicrob Agents Chemother. Nov. 2003;47(11):3478-84. Rec #: 1145. [pmid: 14576105]. [pmcid: 253768].
211 Wu TD, Schiffer CA, Gonzales MJ, Taylor J, Kantor R, Chou S, Israelski D, Zolopa AR, Fessel WJ, Shafer RW. Mutation patterns and structural correlates in human immunodeficiency virus type 1 protease following different protease inhibitor treatments. J Virol. Apr. 2003;77(8):4836-47. Rec #: 1748. [pmid: 12663790]. [pmcid: 152121].
212 Wyen, C.; Jetter, A.; Aarnoutse, R.; Ford, J.; Klaassen, T.; Lazar, A.; Abdulrazik, F.; Schmeiber, N.; Schomig, E.; Back , D.; Burger, D.; Fuhr, U., and Fatkenheuer, G. Neither MDR1 Genotypes (C3435T, G2677T/A, C1236T) nor Hepatic and Intestinal CYP 3A4 Activity Are Associated with Plasma and Intracellular Concentrations of Lopinavir and Ritonavir. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1877
213 Yeh, F. L.; Miranda, L., and Kuritzkes, D. The Effect of the M184V Substitution in HIV-1 Reverse Transcriptase on DNA 3′-and and RNA 5′-end Directed Ribonuclease H Activity [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1791
214 Yoakim, C.; Bonneau, P.; Deziel, R.; Doyon, L.; Duan, J.; Guse, I.; Landry, S.; Malenfant, E.; Naud, J.; Ogilvie, W.; O'Meara, J.; Thavonekham, B.; Simoneau, B.; Bos, M., and Cordingley, M. Novel 8-Substituted Dipyridodiazepinone Inhibitors with Broad-spectrum of Activity against NNRTI-resistant HIV-1. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1838
215 Yoshimura K, Kato R, Yusa K, Kavlick MF, Maroun V, Nguyen A, Mimoto T, Ueno T, Shintani M, Falloon J, Masur H, Hayashi H, Erickson J, Mitsuya H. JE-2147: a dipeptide protease inhibitor (PI) that potently inhibits multi-PI-resistant HIV-1. Proc Natl Acad Sci U S A. Jul 20. 1999;96(15):8675-80. Rec #: 1750. [pmid: 10411934]. [pmcid: 17575].
216 Zachary KC, Hanna GJ, D'Aquila RT. Human immunodeficiency virus type 1 hypersusceptibility to amprenavir in vitro can be associated with virus load response to treatment in vivo. Clin Infect Dis. Dec 15. 2001;33(12):2075-7. Rec #: 1522. [pmid: 11700580].
217 Zhang J, Rhee SY, Taylor J, Shafer RW. Comparison of the precision and sensitivity of the Antivirogram and PhenoSense HIV drug susceptibility assays. J Acquir Immune Defic Syndr. Apr 1. 2005;38(4):439-44. Rec #: 1608. [pmid: 15764961]. [pmcid: 2547471].
218 Ziermann R, Limoli K, Das K, Arnold E, Petropoulos CJ, Parkin NT. A mutation in human immunodeficiency virus type 1 protease, N88S, that causes in vitro hypersensitivity to amprenavir. J Virol. May. 2000;74(9):4414-9. Rec #: 1521. [pmid: 10756056]. [pmcid: 111958].
219 Zolopa, A.; Becker, S.; Taylor, J.; Bates, M.; Coakley, E., and Parkin, N. Clinical Selection of ARV Regimens is Influenced by the Type of Resistance Test Information Provided. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1896
220 Zolopa AR. Genotype-phenotype discordance: the evolution in our understanding HIV-1 drug resistance. AIDS. May 2. 2003;17(7):1077-8. Rec #: 1113. [pmid: 12700459].

## Reject: First Screening - Topic not ARV Resistance

1 Drug-resistant HIV on rise as medicines misused. AIDS Reader. 2002; 12(1):18. Rec #: 1402
2 Efficacy of three short-course regimens of zidovudine and lamivudine in preventing early and late transmission of HIV-1 from mother to child in Tanzania, South Africa, and Uganda (Petra study): a randomised, double-blind, placebo-controlled trial. Lancet. 2002 Apr 6; 359(9313):1178–86. Rec #: 2106
3 Aceto, L. Karrer U. Grube Ch. Oberholzer R. Hasse B. Presterl E. BoniJ. Kuster H. Trkola A. Weber R. Gunthard H. F. (Dr. H.F. Gunthard, Abteilung Infektionskrankheiten und Spitalhygiene, Universitatsspital Zurich, Ramistrasse 100, 8091 Zurich. Switzerland). Primary HIV-1 infection in Zurich: 2002-2004: <ORIGINAL> Die akute HIV-1-Infektion in Zurich: 2002-2004. Schweizerische Rundschau Fur Medizin - Praxis. 2005 Aug 10; 941199-1205; ISSN: 1013-2058. Rec #: 1485
4 Adeyemi TM, Max B, Badri SM, Baker DE. Impact of resistance testing ordering guidelines on rates of wild-type virus detection among patients for whom highly active antiretroviral therapy fails. J Acquir Immune Defic Syndr. Jan 1. 2004;35(1):98-9. Rec #: 1443. [pmid: 14707801].
5 Albrecht MA, Bosch RJ, Hammer SM, Liou SH, Kessler H, Para MF, Eron J, Valdez H, Dehlinger M, Katzenstein DA. Nelfinavir, efavirenz, or both after the failure of nucleoside treatment of HIV infection. N Engl J Med. Aug 9. 2001;345(6):398-407. Rec #: 1622. [pmid: 11496850].
6 Ananworanich, J.; Cardiello, P.; Srasuebkul, P., and et al. HIV-NAT 001.4: a prospective randomized trial of structured treament interruptions in patients with chronic HIV infection. 10th Conference on Retroviruses and Opportunistic infections; Boston. Foundation for Retrovirology and Human Health; 2003. Rec #: 2039
7 Bannister, W.; Ruiz, L.; Loveday, C.; Vella, S.; Zilmer, K.; Podlekareva, D.; Knysz, B.; Phillips, A.; Lundgren, J.; Mocroft, A., and EuroSIDA study group. HIV-1 Subtypes and Virological Response to HAART in Europe. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1874
8 Bedikou, G.; Viho, I.; Tonwe-Gold, B.; Coffie, J. P.; Amani-Bosse, C.; Allou, G.; Sakarovitch, C.; Toure, S.; Ekouevi, D. K.; Leroy, V.; Abrams, E. J., and Dabis, F. 6-Month Immunological Response with HAART containing Nevirapine in HIV-infected Women Post Exposure to Single Dose of Nevirapine for PMTCT. The MTCT-plus initiative in Abidjan, Cote d'Ivoire (2003-2005). 3rd International AIDS Society Conference on HIV Pathogenesis and Treatment; Rio de Janeiro, Brazil. 2005. Rec #: 2126
9 Bonneau, P.; Robinson, P.; Duan, J.; Doyon, L.; Simoneau, B.; Yoakim, C.; Garneau, M.; Bos, M.; Cordingley, M.; Brenner, B.; Spira, B.; Wainberg, M.; Huang, F.; Drda, K.; Ballow, C., and Mayers, D. Antiviral Characterization and Human Experience with BILR 355 BS, a Novel Next-generation Non-Nucleoside Reverse Transcriptase Inhibitor with a Broad Anti HIV-1 Profile. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1864
10 Bozkaya H, Yurdaydin C, Bozdayi AM, Erkan O, Karayalcin S, Uzunalimoglu O. Oral ganciclovir for treatment of lamivudine-resistant hepatitis B virus infection: a pilot study. Clin Infect Dis. Oct 15. 2002;35(8):960-5. Rec #: 1175. [pmid: 12355383].
11 Brenner, B.; Spira, B.; Moisi, D.; Tuurgel, R.; Roger, M.; Ntemgwa, M.; Doualla-Bell, F.; Turner, D.; Routy, J. P.; Charest, H.; Wainberg, M., and Quebec HIV Drug Resistance/Molecular Epidemiology Group. The Hidden HIV-1 Epidemic in Quebec: Rapid Introduction of Wild-Type and Non-B Viral-Subtype Infections. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1858
12 Brenner BG, Roger M, Moisi D, Matte C, Ntemgwa M, Routy JP, Legault M, Charest H, Wainberg MA. Transmission events within risk groups following primary HIV-1 infection (PHI) in Quebec (1998-2005). Antivir Ther. 2005;10:S125. Rec #: 1978.
13 Brocklehurst, P. and Volmink, J. Antiretrovirals for reducing the risk of mother-to-child transmission of HIV infection [Systematic Review]. Cochrane Database of Systematic Reviews 2005;(4). 2005. Rec #: 1361
14 Cavalcanti, R.; Kain, K.; Shen, S., and Walmsley, S. A Randomized Placebo Controlled Trial of Rosiglitazone for the Treatment of HIV Lipodystrophy. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1901
15 Clevenbergh P, Boulme R, Kirstetter M, Dellamonica P. (Centre Hospitalier Universitaire Lariboisiere, Paris, France. clevenberghph@hotmail.com) Efficacy, safety and predictive factors of virological success of a boosted amprenavir-based salvage regimen in heavily antiretroviral-experienced HIV-1-infected patients. HIV Medicine. Jul. 2004;5(4):284-8. Rec #: 1363. [pmid: 15236618].
16 Coakley, E.; Chappey, C.; Maa, J.; Wang, S.; Bates, M.; Pesano, R.; Thirty, A., and Seekins, D. Evaluation of Phenotypic Clinical Cutoff for Atazanavir/Ritonavir in Patients Who Changed Only the Protease Inhibitor Component of HAART: A Confirmatory Week 2 Analysis of AI 424-045 [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1810
17 Coetzee D, Hildebrand K, Boulle A, Maartens G, Louis F, Labatala V, Reuter H, Ntwana N, Goemaere E. Outcomes after two years of providing antiretroviral treatment in Khayelitsha, South Africa. AIDS. Apr 9. 2004;18(6):887-95. Rec #: 2018. [pmid: 15060436].
18 Connor EM, Sperling RS, Gelber R, Kiselev P, Scott G, O'Sullivan MJ, VanDyke R, Bey M, Shearer W, Jacobson RL, et al. Reduction of maternal-infant transmission of human immunodeficiency virus type 1 with zidovudine treatment. Pediatric AIDS Clinical Trials Group Protocol 076 Study Group. N Engl J Med. Nov 3. 1994;331(18):1173-80. Rec #: 2036. [pmid: 7935654].
19 Coovadia, A.; Marais, B.; Abrams, E.; Sherman, G.; Barry, G.; Hammer, S.; Karstaedt, A.; Walter, J.; Meyers, T., and Kuhn, L. Virologic Response to NNRTI Treatment among Women Who Took Single-dose Nevirapine 18 to 36 Months Earlier [Impact of Resistance on Treatment Response ]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1818
20 ---. Virologic Response to NNRTI Treatment among Women Who Took Single-dose Nevirapine 18 to 36 months earlier. 13th Conference on Retroviruses and Opportunistic Infections; Denver, CO. 2006. Rec #: 2129
21 Cox SW, Aperia K, Albert J, Wahren B. Comparison of the sensitivities of primary isolates of HIV type 2 and HIV type 1 to antiviral drugs and drug combinations. AIDS Res Hum Retroviruses. Dec. 1994;10(12):1725-9. Rec #: 1525. [pmid: 7888232].
22 Cressey TR, Jourdain G, Lallemant MJ, Kunkeaw S, Jackson JB, Musoke P, Capparelli E, Mirochnick M. Persistence of nevirapine exposure during the postpartum period after intrapartum single-dose nevirapine in addition to zidovudine prophylaxis for the prevention of mother-to-child transmission of HIV-1. J Acquir Immune Defic Syndr. Mar 1. 2005;38(3):283-8. Rec #: 1016. [pmid: 15735445].
23 d'Arminio Monforte A, Lepri AC, Rezza G, Pezzotti P, Antinori A, Phillips AN, Angarano G, Colangeli V, De Luca A, Ippolito G, Caggese L, Soscia F, Filice G, Gritti F, Narciso P, Tirelli U, Moroni M. Insights into the reasons for discontinuation of the first highly active antiretroviral therapy (HAART) regimen in a cohort of antiretroviral naive patients. I.CO.N.A. Study Group. Italian Cohort of Antiretroviral-Naive Patients. AIDS. Mar 31. 2000;14(5):499-507. Rec #: 2025. [pmid: 10780712].
24 Dalod M, Dupuis M, Deschemin JC, Goujard C, Deveau C, Meyer L, Ngo N, Rouzioux C, Guillet JG, Delfraissy JF, Sinet M, Venet A. Weak anti-HIV CD8(+) T-cell effector activity in HIV primary infection. J Clin Invest. Nov. 1999;104(10):1431-9. Rec #: 2076. [pmid: 10562305]. [pmcid: 409838].
25 Decosas, J. and Boillot, F. Surveillance of HIV and tuberculosis drug resistance. Lancet. 2005 Aug 6–2005 Aug 12; 366(9484):438–9. Rec #: 1461
26 Dorenbaum A, Cunningham CK, Gelber RD, Culnane M, Mofenson L, Britto P, Rekacewicz C, Newell ML, Delfraissy JF, Cunningham-Schrader B, Mirochnick M, Sullivan JL. Two-dose intrapartum/newborn nevirapine and standard antiretroviral therapy to reduce perinatal HIV transmission: a randomized trial. JAMA. Jul 10. 2002;288(2):189-98. Rec #: 2079. [pmid: 12095383].
27 Ekong, E.; Akinlade, O.; Uwah, A., and Grant-Isibor, I. The Nigerian accelerated antiretroviral drug initaitive-evaluation of combination of nevirapine (NVP), lamivudine (3TC), and stavudine (d4T) in antiretroviral naive patients. 2nd AIS Conference on HIV Pathogenesis and Treament; Paris. 2003. Rec #: 2047
28 Ellenberger DL, Pieniazek D, Nkengasong J, Luo CC, Devare S, Maurice C, Janini M, Ramos A, Fridlund C, Hu DJ, Coulibaly IM, Ekpini E, Wiktor SZ, Greenberg AE, Schochetman G, Rayfield MA. Genetic analysis of human immunodeficiency virus in Abidjan, Ivory Coast reveals predominance of HIV type 1 subtype A and introduction of subtype G. AIDS Res Hum Retroviruses. Jan 1. 1999;15(1):3-9. Rec #: 2074. [pmid: 10024047].
29 Emberti Gialloreti, L.; De Luca, A.; Perno, C. F., and et al. Increase in survival in HIV-1 infected subjects in Matola, Mozambique, after that introduction of combination therapy with generic-manufactured antiretrovirals: preliminary results from the DREAM cohort. 10th Conference on Retroviruses and Opportunistic Infections: Foundation for Retrovirology and Human Health; 2003. Rec #: 2059
30 Emu, B.; Sinclair, E.; Favre, D.; Moretto, W.; Hoh, R.; Martin, J.; Nixon, D.; McCune, J., and Deeks, S. Control of HIV Replication in Long-term Non-progressors and Patients Partially Controlling Drug-resistant HIV Is Associated with High Levels of HIV-specific IL-2-producing CD4+ T Cells and Low Levels of Immune Activiation. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1828
31 Enron, J. J.; Park, J. G.; Haubrich, R.; Gerber, J.; Yu, S.; Wu, H., and Richman, D. The Predictive Value of Pharmacokinetic-adjusted Phenotypic Susceptibility on Antiretroviral Response to Retonavir-enhanced Protease Inhibitors in Subjects Who Failed Previous PI-based Regimens: ACTG A5126 [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1817
32 Epstein BJ. Drug resistance among patients recently infected with HIV. N Engl J Med. Dec 5. 2002;347(23):1889-90. author reply 1889–90. Rec #: 1393. [pmid: 12466517].
33 Eron JJ, Benoit SL, Jemsek J, MacArthur RD, Santana J, Quinn JB, Kuritzkes DR, Fallon MA, Rubin M. Treatment with lamivudine, zidovudine, or both in HIV-positive patients with 200 to 500 CD4+ cells per cubic millimeter. North American HIV Working Party. N Engl J Med. Dec 21. 1995;333(25):1662-9. Rec #: 2035. [pmid: 7477218].
34 Eshleman SH, Gonzales MJ, Becker-Pergola G, Cunningham SC, Guay LA, Jackson JB, Shafer RW. Identification of Ugandan HIV type 1 variants with unique patterns of recombination in pol involving subtypes A and D. AIDS Res Hum Retroviruses. May 1. 2002;18(7):507-11. Rec #: 1614. [pmid: 12015904]. [pmcid: 2573392].
35 Eure, C.; Bakai, P.; McConnell, M.; Mubiru, M.; Thigpen, M.; Musoke, P.; Mmiro, F.; Fowler, M., and MUJHU NVP Resistance Group. Effectiveness of repeat single-dose nevirapine in subsequent pregnancies among Ugandan women. 13th Conference on Retroviruses and Opportunistic InfectionsDenver, Colorado; 2006. Rec #: 2111
36 Gartland M. AVANTI 3: a randomized, double-blind trial to compare the efficacy and safety of lamivudine plus zidovudine versus lamivudine plus zidovudine plus nelfinavir in HIV-1-infected antiretroviral-naive patients. Antivir Ther. Jun. 2001;6(2):127-34. Rec #: 1906. [pmid: 11491417].
37 Guay LA, Musoke P, Fleming T, Bagenda D, Allen M, Nakabiito C, Sherman J, Bakaki P, Ducar C, Deseyve M, Emel L, Mirochnick M, Fowler MG, Mofenson L, Miotti P, Dransfield K, Bray D, Mmiro F, Jackson JB. Intrapartum and neonatal single-dose nevirapine compared with zidovudine for prevention of mother-to-child transmission of HIV-1 in Kampala, Uganda: HIVNET 012 randomised trial. Lancet. Sep 4. 1999;354(9181):795-802. Rec #: 2026. [pmid: 10485720].
38 Guiard-Schmid, J. B.; Montagut, B.; Ribadeau-Dumas, F., and et al. TRICAM: Mmdico-economic pilot study on HAART for HIV-infected patients in a private company of Cameroon. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2053
39 Gulick RM, Ribaudo HJ, Shikuma CM, Lustgarten S, Squires KE, Meyer WA 3rd, Acosta EP, Schackman BR, Pilcher CD, Murphy RL, Maher WE, Witt MD, Reichman RC, Snyder S, Klingman KL, Kuritzkes DR. Triple-nucleoside regimens versus efavirenz-containing regimens for the initial treatment of HIV-1 infection. N Engl J Med. Apr 29. 2004;350(18):1850-61. Rec #: 1656. [pmid: 15115831].
40 Harris, M.; Press, N.; Thorne, A.; Zala, C.; Cahn, P.; Ochoa, C.; Schneider, S.; Hanna, B.; Singer, J.; Montaner, J., and CTN 161 (SPRINT) Study Team. Results of Simplified Protease Inhibitor Trial: Antiviral Effect of Once Daily Saquinavir SGC plus Ritonavir vs Twice Daily Indinavir plus Ritonavir. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1868
41 Haubrich R, Thompson M, Schooley R, Lang W, Stein A, Sereni D, van der Ende ME, Antunes F, Richman D, Pagano G, Kahl L, Fetter A, Brown DJ, Clumeck N. A phase II safety and efficacy study of amprenavir in combination with zidovudine and lamivudine in HIV-infected patients with limited antiretroviral experience. Amprenavir PROAB2002 Study Team. AIDS. Dec 3. 1999;13(17):2411-20. Rec #: 1661. [pmid: 10597783].
42 Hawley, P.; Hammond, J.; Tressler, R.; Ryan, R.; Raber, S., and Hodges, M. Final 48-Week Safety, Tolerability, and Efficacy of Capravirine + Lopinavir/ritonavir and 2 NRTI in Treatment-experienced Patients [New Antiretroviral Agents and Approaches-Clinical Studies]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1786
43 Hoen B, Dumon B, Harzic M, Venet A, Dubeaux B, Lascoux C, Bourezane Y, Ragnaud JM, Bicart-See A, Raffi F, Beauvais L, Fleury H, Sereni D. Highly active antiretroviral treatment initiated early in the course of symptomatic primary HIV-1 infection: results of the ANRS 053 trial. J Infect Dis. Oct. 1999;180(4):1342-6. Rec #: 2075. [pmid: 10479169].
44 Hogg RS, Heath K, Bangsberg D, Yip B, Press N, O'Shaughnessy MV, Montaner JS. Intermittent use of triple-combination therapy is predictive of mortality at baseline and after 1 year of follow-up. AIDS. May 3. 2002;16(7):1051-8. Rec #: 2069. [pmid: 11953472].
45 Hogg RS, Yip B, Chan KJ, Wood E, Craib KJ, O'Shaughnessy MV, Montaner JS. Rates of disease progression by baseline CD4 cell count and viral load after initiating triple-drug therapy. JAMA. Nov 28. 2001;286(20):2568-77. Rec #: 2032. [pmid: 11722271].
46 Hosseinipour, M. C.; Kanyama, C.; Nkhalamba, T., and et al. Safety and efficacy of D4T/3TC/NVP among HIV positive adults in Lilongwe, Malawi. 15th International AIDS Conference; Bangkog. International AIDS Society; 2004. Rec #: 2040
47 Hudspeth, J.; Venter, W.; van Rie, A.; Wing, J., and Feldman, C. Access to and early outcomes of a public Sourth African adult antiretroviral clinic. 12th Conference on Retroviruses and Opportunistic Infections; Boston. Foundation for Retrovirology and Human Health; 2005. Rec #: 2049
48 Ickovics JR, Wilson TE, Royce RA, Minkoff HL, Fernandez MI, Fox-Tierney R, Koenig LJ. Prenatal and postpartum zidovudine adherence among pregnant women with HIV: results of a MEMS substudy from the Perinatal Guidelines Evaluation Project. J Acquir Immune Defic Syndr. Jul 1. 2002;30(3):311-5. Rec #: 1178. [pmid: 12131568].
49 Idoko JA, Akinsete L, Abalaka AD, Keshinro LB, Dutse L, Onyenekwe B, Lhekwaba A, Njoku OS, Kehinde MO, Wambebe CO. (Jos University Teaching Hospital, Nigeria.). A multicentre study to determine the efficacy and tolerability of a combination of nelfinavir (VIRACEPT), zalcitabine (HIVID) and zidovudine in the treatment of HIV infected Nigerian patients. West African Journal of Medicine. 2002;21(2):83-6. Rec #: 1376. [pmid: 12403023].
50 Jackson JB, Musoke P, Fleming T, Guay LA, Bagenda D, Allen M, Nakabiito C, Sherman J, Bakaki P, Owor M, Ducar C, Deseyve M, Mwatha A, Emel L, Duefield C, Mirochnick M, Fowler MG, Mofenson L, Miotti P, Gigliotti M, Bray D, Mmiro F. Intrapartum and neonatal single-dose nevirapine compared with zidovudine for prevention of mother-to-child transmission of HIV-1 in Kampala, Uganda: 18-month follow-up of the HIVNET 012 randomised trial. Lancet. Sep 13. 2003;362(9387):859-68. Rec #: 2037. [pmid: 13678973].
51 Janini LM, Pieniazek D, Peralta JM, Schechter M, Tanuri A, Vicente AC, dela Torre N, Pieniazek NJ, Luo CC, Kalish ML, Schochetman G, Rayfield MA. Identification of single and dual infections with distinct subtypes of human immunodeficiency virus type 1 by using restriction fragment length polymorphism analysis. Virus Genes. 1996;13(1):69-81. Rec #: 2073. [pmid: 8938982].
52 Janini LM, Tanuri A, Schechter M, Peralta JM, Vicente AC, Dela Torre N, Pieniazek NJ, Luo CC, Ramos A, Soriano V, Schochetman G, Rayfield MA, Pieniazek D. Horizontal and vertical transmission of human immunodeficiency virus type 1 dual infections caused by viruses of subtypes B and C. J Infect Dis. Jan. 1998;177(1):227-31. Rec #: 2072. [pmid: 9419195].
53 Johnson, J.; Li, J. F.; Brant, A.; Bennett, D.; Cong, M. E.; Spira, T.; Sandstrom, P., and Heneine, W. Sensitive Drug-resistance Testing Reveals a Greater Prevalence of Transmitted Multi-drug-resistant HIV-1 that Previously Estimated [Epidemiology and Transmission fo Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1770
54 Kabugo, C.; Katureebe, C. N.; Mbidde, M. J., and et al. Antiretroviral therapy in MTCT-Plus program in St. Francis Hospital, Nsambya, Uganda. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2056
55 Kahn JO, Lagakos SW, Richman DD, Cross A, Pettinelli C, Liou SH, Brown M, Volberding PA, Crumpacker CS, Beall G, et al. A controlled trial comparing continued zidovudine with didanosine in human immunodeficiency virus infection. The NIAID AIDS Clinical Trials Group. N Engl J Med. Aug 27. 1992;327(9):581-7. Rec #: 2033. [pmid: 1353607].
56 Kigangou, N.; Tran-Minh, T.; Mankou, M., and et al. Pointe-Noire, Congo-Brazzaville: antiretroviral therapy assessment, an evaluation following 6 months of prescription. 2nd IAS Conference on HIV Pathogenesis and Treament; Paris. 2003. Rec #: 2052
57 Kirk O, Lundgren JD, Pedersen C, Mathiesen LR, Nielsen H, Katzenstein TL, Obel N, Gerstoft J. (Department of Infectious Diseases, Hvidovre University Hospital, Hvidovre, Denmark. oki@cphiv.dk). A randomized trial comparing initial HAART regimens of nelfinavir/nevirapine and ritonavir/saquinavir in combination with two nucleoside reverse transcriptase inhibitors. Antivir Ther. Dec. 2003;8(6):595-602. Rec #: 1370. [pmid: 14760893].
58 Kozal, M.; Amico, K. R.; Chiarella, J.; Fisher, J.; Cornman, D.; Fisher, W., and Friedland, G. HIV drug resistance among HIV+ injection drug users: risk behaviour and patients' beliefs on the transmissibility of HIV. 2004; 9, S100. Rec #: 1926
59 Kuritzkes DR, Marschner I, Johnson VA, Bassett R, Eron JJ, Fischl MA, Murphy RL, Fife K, Maenza J, Rosandich ME, Bell D, Wood K, Sommadossi JP, Pettinelli C. Lamivudine in combination with zidovudine, stavudine, or didanosine in patients with HIV-1 infection. A randomized, double-blind, placebo-controlled trial. National Institute of Allergy and Infectious Disease AIDS Clinical Trials Group Protocol 306 Investigators. AIDS. Apr 16. 1999;13(6):685-94. Rec #: 1554. [pmid: 10397563].
60 Lallemant M, Jourdain G, Le Coeur S, Mary JY, Ngo-Giang-Huong N, Koetsawang S, Kanshana S, McIntosh K, Thaineua V. Single-dose perinatal nevirapine plus standard zidovudine to prevent mother-to-child transmission of HIV-1 in Thailand. N Engl J Med. Jul 15. 2004;351(3):217-28. Rec #: 2082. [pmid: 15247338].
61 Landman R, Schiemann R, Thiam S, Vray M, Canestri A, Mboup S, Kane CT, Delaporte E, Sow PS, Faye MA, Gueye M, Peytavin G, Dalban C, Girard PM, Ndoye I. Once-a-day highly active antiretroviral therapy in treatment-naive HIV-1-infected adults in Senegal. AIDS. May 2. 2003;17(7):1017-22. Rec #: 2014. [pmid: 12700451].
62 Ledergerber B, Egger M, Opravil M, Telenti A, Hirschel B, Battegay M, Vernazza P, Sudre P, Flepp M, Furrer H, Francioli P, Weber R. Clinical progression and virological failure on highly active antiretroviral therapy in HIV-1 patients: a prospective cohort study. Swiss HIV Cohort Study. Lancet. Mar 13. 1999;353(9156):863-8. Rec #: 1510. [pmid: 10093977].
63 Little SJ. Is transmitted drug resistance in HIV on the rise? It seems so. Br Med J. May 5. 2001;322(7294):1074-5. Rec #: 1444. [pmid: 11337420]. [pmcid: 1120220].
64 Lockman S, Shapiro RL, Smeaton LM, Wester C, Thior I, Stevens L, Chand F, Makhema J, Moffat C, Asmelash A, Ndase P, Arimi P, van Widenfelt E, Mazhani L, Novitsky V, Lagakos S, Essex M. Response to antiretroviral therapy after a single, peripartum dose of nevirapine. N Engl J Med. Jan 11. 2007;356(2):135-47. Rec #: 2123. [pmid: 17215531].
65 Lockman, S.; Smeaton, L. M.; Shapiro, R. L., and et al. Maternal and infant response to nevirpine (NVP)-based antiretroviral treament (ART) following peripartum single-dose NVP or placebo (Plc). 43rd Annual Meeting of IDSA; San Francisco. October 6–9, 2005. Rec #: 2002
66 Lohse N, Obel N, Kronborg G, Jorgensen LB, Gerstoft J. Evolution in the population at risk of transmitting resistant HIV during the period 1995-2003. Antivir Ther. 2005;10:S134. Rec #: 1981.
67 Low-Beer S, Yip B, O'Shaughnessy MV, Hogg RS, Montaner JS. Adherence to triple therapy and viral load response. J Acquir Immune Defic Syndr. Apr 1. 2000;23(4):360-1. Rec #: 2068. [pmid: 10836763].
68 Lowenthal, E.; Marape, M.; Mathuba, K.; Calles, N.; Millon, J.; Schwarzwald, H.; Ferris, M.; Kozinetz, C.; Kline, M., and Anabwani, G. A Randomized Compaative Trial of Continuous vs Intermittant HAART in HIV-infected infants and Children in Botswana [Pediatric Antiretroviral Therapy in Resource-Limited Settings]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1806
69 MacArthur RD, Chen L, Mayers DL, Besch CL, Novak R, van den Berg-Wolf M, Yurik T, Peng G, Schmetter B, Brizz B, Abrams D. The rationale and design of the CPCRA (Terry Beirn Community Programs for Clinical Research on AIDS) 058 FIRST (Flexible Initial Retrovirus Suppressive Therapies) trial. Control Clin Trials. Apr. 2001;22(2):176-90. Rec #: 2081. [pmid: 11306155].
70 Macharia DK, Chang LW, Lule G, Owili DM, Tesfaledet G, Patel S, Silverstein DM, Ng'ang'a L, Bush T, De Cock KM, Weidle PJ. Antiretroviral therapy in the private sector of Nairobi, Kenya: a review of the experience of five physicians. AIDS. Apr 11. 2003;17(6):938-40. Rec #: 2016. [pmid: 12660550].
71 Marih, L.; Sodqi, M.; Bensghir, R.; Marhoum, K. E. L., and Himmich, H. Antiretroviral therapy in limited resource countries: example of Morocco. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2057
72 Martinson, N.; Ekouevi, D.; Gray, G.; Tonwe-Gold, B.; Dhlamini, P.; Leroy, V.; Viho, I.; Dabis, F., and McIntyre, J. Effectiveness of single-dose nevirapine in consecutive pregnancies in Soweto and Abidjan. 13th Conference on Retroviruses and Opportunistic Infections; Denver, Colorado. 2006. Rec #: 2112
73 Meynard JL, Vray M, Morand-Joubert L, et al. Impact of treatment guided by phenotypic or genotypic resistance tests on the response to antiretroviral therapy: a randomised trial (NARVAL, ANRS 088). Antivir Ther. 2000;5:67-8. Rec #: 1576.
74 Miller, L.; Mc Cutchan, J. A.; Keiser, P.; Kemper, C.; Witt, M.; Leedon, J., and et al. Accumulation of antiretroviral resistance in treatment-experienced patients: the impact of medication adherence. 2nd International AIDS Society Conference on HIV Pathogenesis And Treatment; Paris, France. 2003. Rec #: 1542
75 Mitty, J.; Mwamburi, D.; Macalino, G.; Caliendo, A.; Bazerman, L., and Flanigan, T. Improved Virologic Outcomes and Less HIV Resistance for HAART-experienced Substance Users Recieving Modified Directly Observed Therapy: Results from a Randomized Controlled Trial [Selection, Evolution and Persistence to Drug Resistance]. 13th Conference on Retroviruses and Oppotunistic Infections; 2006. Rec #: 1762
76 Montano, M.; Sebastiani, P.; Rarick, M.; Thior, I.; Wester, C.; Essex, M., and Navis, A. Gene-expression Patterns Associated with HIV-1 subtype C Infection and Transmission in Botswana [Factors Influencing Mother-to-Child Transmission]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1819
77 Mujugira, A.; Wester, W.; Kim S., and et al. Antiretroviral treatment among ARV naive HIV-1 subtype C infected adults with CD4<50 cells/mm3 at treatment initiation. 15th International AIDS ConferenceBangkok: International AIDS Society; 2004. Rec #: 2054
78 Murphy, R.; Pokrovsky, V.; Rozenbaum, W.; Wood, R.; Percival, L.; Odeshoo, L., and et al. Long-term efficacy and safety of atazanavir (ATV) with stavudine (d4T) and lamivudine (3TC) in patients previously treated with nelfinavir (NFV) or ATV: 108-week results of BMS study 008/044. 10th Conference on Retroviruses and Opportunistic Infections; Boston, Massachusetts. 2003. Rec #: 1564
79 Murphy RL, Sanne I, Cahn P, Phanuphak P, Percival L, Kelleher T, Giordano M. Dose-ranging, randomized, clinical trial of atazanavir with lamivudine and stavudine in antiretroviral-naive subjects: 48-week results. AIDS. Dec 5. 2003;17(18):2603-14. Rec #: 2028. [pmid: 14685054].
80 Mutuluuza, C. K.; Walker, S.; Kaleebu, P., and et al. Short-term virologic response to a triple nucleoside/nucleotide analogue regimen i nadults with HIV infection in Africa within the DART Trial. 12th Conference on Retroviruses and Opportunistic Infections; Boston. Foundation for Retrovirology and Human Health; 2005. Rec #: 2044
81 Ndwapi, N.; Bussman, H.; Gaolathe, T., and et al. Response to the Botswana national antiretroviral therapy program-preliminary analysis of the first 306 treatment-nave adults receiving HAART via the national ARV program. 2nd IAS Conference on HIV Pathogenesis and Treament; Paris. 2003. Rec #: 2058
82 Oette M, Haussinger D. Drug Resistance in Antiretroviral Therapy of HIV Infection Original>Resistenz in Der Antiretroviralen Therapie Der Hiv-Infektion. Medizinische Klinik. Dec. 2003;98(12):692-699. Rec #: 1421. [pmid: 14685670].
83 Oyugi, J. H.; Byakika, J. T.; Ragland, K., and et al. Treament outcomes and adherence to generic Triomune and Maxivir thereapy in Kampala, Uganda. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2041
84 Paediatric European Network for Treatment of AIDS. Comparison of dual nucleoside-analogue reverse-transcriptase inhibitor regimens with and without nelfinavir in children with HIV-1 who have not previously been treated: the PENTA 5 randomised trial. Lancet. 2002 Mar 2; 359(9308):733–40. Rec #: 2077.
85 Palmisano, L.; Giuliano, M.; Pirillo, M. F., and et al. Baseline predictors and virological outcome in subjects developing mutations during intermittent HAART. 2004; 9, S159. Rec #: 1940
86 Pesano, R.; Piraino, S.; Hawley, P.; Hammond, J.; Tressler, R.; Ryan, R.; Nickens, D.; Ruiz, R., and 1002 Study Group. 24 Week Safety, Tolerability, and Efficacy of Capravirine as ADD-on Therapy to Nelfinavir and 2 Nucleoside Reverse Transcriptase Inhibitors in Patients Failing a Non-nucleoside Reverse Transcriptase Inhibitor-based Regimen. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1862
87 Philpott S, Burger H, Charbonneau T, Grimson R, Vermund SH, Visosky A, Nachman S, Kovacs A, Tropper P, Frey H, Weiser B. CCR5 genotype and resistance to vertical transmission of HIV-1. J Acquir Immune Defic Syndr. Jul 1. 1999;21(3):189-93. Rec #: 1288. [pmid: 10421241].
88 Pieniazek, D.; Baggs, J.; Hu, D. J.; Matar, G. M.; Abdelnoor, A. M.; Mokhbat, J. E.; Uwaydah, M.; Bizri, A. R.; Ramos, A.; Janini, L. M.; Tanuri, A.; Fridlund, C.; Schable, C.; Heyndrickx, L.; Rayfield, M. A., and Heneine, W. Introduction of HIV-2 and multiple HIV-1 subtypes to Lebanon. Emerg Infect Dis. 1998 Oct–1998 Dec 31; 4(4):649–56. Rec #: 2022
89 Pieniazek D, Ellenberger D, Janini LM, Ramos AC, Nkengasong J, Sassan-Morokro M, Hu DJ, Coulibally IM, Ekpini E, Bandea C, Tanuri A, Greenberg AE, Wiktor SZ, Rayfield MA. Predominance of human immunodeficiency virus type 2 subtype B in Abidjan, Ivory Coast. AIDS Res Hum Retroviruses. Apr 10. 1999;15(6):603-8. Rec #: 2021. [pmid: 10221538].
90 Pieniazek D, Peralta JM, Ferreira JA, Krebs JW, Owen SM, Sion FS, Filho CF, Sereno AB, de Sa CA, Weniger BG, et al. Identification of mixed HIV-1/HIV-2 infections in Brazil by polymerase chain reaction. AIDS. Nov. 1991;5(11):1293-9. Rec #: 2023. [pmid: 1768377].
91 Ramos, A.; Tanuri, A.; Schechter, M.; Rayfield, M. A.; Hu, D. J.; Cabral, M. C.; Bandea, C. I.; Baggs, J., and Pieniazek, D. Dual and recombinant infections: an integral part of the HIV-1 epidemic in Brazil. Emerg Infect Dis. 1999 Jan–1999 Feb 28; 5(1):65–74. Rec #: 2071
92 Resino S, Bellon JM, Ramos JT, Navarro ML, Martin-Fontelos P, Cabrero E, Munoz-Fernandez MA. (Laboratory of Immuno-Molecular Biology, Department of Pediatrics, Hospital Carlos III, and Abbott Laboratories). Salvage lopinavir-ritonavir therapy in human immunodeficiency virus-infected children. Pediatr Infect Dis J. Oct. 2004;23(10):923-30. Rec #: 1366. [pmid: 15602192].
93 Routy J-P, de B Edwards MD, Rouleau D, Tremblay CL, Boulassel M-R, Brenner B, Thomas R, Trottier B, Cote P, Baril JG, Leblanc R, Tsoukas C, Wainberg MA. Influence of patient caracteristics, year of infection, CD4 cell count and viral load on the presence of primary HIV-1 drug resistance in recently infected patients. Antivir Ther. 2005;10:S133. Rec #: 1980.
94 Ruxrungtham K, Kroon ED, Ungsedhapand C, Teeratakulpisarn S, Ubolyam S, Buranapraditkun S, van Leeuwen R, Weverling GJ, Kunanusont C, Lange JM, Cooper DA, Phanuphak P. A randomized, dose-finding study with didanosine plus stavudine versus didanosine alone in antiviral-naive, HIV-infected Thai patients. AIDS. Jul 7. 2000;14(10):1375-82. Rec #: 2029. [pmid: 10930152].
95 Saag MS, Tebas P, Sension M, Conant M, Myers R, Chapman SK, Anderson R, Clendeninn N. Randomized, double-blind comparison of two nelfinavir doses plus nucleosides in HIV-infected patients (Agouron study 511). AIDS. Oct 19. 2001;15(15):1971-8. Rec #: 1905. [pmid: 11600825].
96 Salamon R, Marimoutou C, Ekra D, Minga A, Nerrienet E, Huet C, Gourvellec G, Bonard D, Coulibaly I, Combe P, Dabis F, Bondurand A, Montagnier L. Clinical and biological evolution of HIV-1 seroconverters in Abidjan, Cote d'Ivoire, 1997-2000. J Acquir Immune Defic Syndr. Feb 1. 2002;29(2):149-57. Rec #: 2078. [pmid: 11832684].
97 Sanne I, Piliero P, Squires K, Thiry A, Schnittman S. Results of a phase 2 clinical trial at 48 weeks (AI424-007): a dose-ranging, safety, and efficacy comparative trial of atazanavir at three doses in combination with didanosine and stavudine in antiretroviral-naive subjects. J Acquir Immune Defic Syndr. Jan 1. 2003;32(1):18-29. Rec #: 2027. [pmid: 12514410].
98 Saracino, A. and Angarano, G. Change of antiretroviral therapy guided by genotypic or phenotypic resistance testing: an open-label, randomized, multicenter study (PhenGen) [abstract 237]. 6th International Congress on Drug Therapy in HIV Infection; Glasgow, Scotland. 2002 Nov 17–2002 Nov 21. Rec #: 2084
99 Sax PE, Islam R, Walensky RP, Losina E, Weinstein MC, Goldie SJ, Sadownik SN, Freedberg KA. Should resistance testing be performed for treatment-naive HIV-infected patients? A cost-effectiveness analysis. Clin Infect Dis. Nov 1. 2005;41(9):1316-23. Rec #: 1483. [pmid: 16206108].
100 Sekar, V.; De Meyer, S.; Vangeneugden, T.; Lefebvre, E.; De Pauw, M.; Van Baelen, B.; De Paepe, E.; De Bethune, M. P.; Hoetelmans, R., and Parys, W. Pharmacokinectic/Pharmacodynamic Analyses of TMC114 in the POWER 1 and POWER 2 Trials in Treatment-experienced HIV-infected Patients [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1816
101 Seyler C, Anglaret X, Dakoury-Dogbo N, Messou E, Toure S, Danel C, Diakite N, Daudie A, Inwoley A, Maurice C, Tonwe-Gold B, Rouet F, N'Dri-Yoman T, Salamon R. Medium-term survival, morbidity and immunovirological evolution in HIV-infected adults receiving antiretroviral therapy, Abidjan, Cote d'Ivoire. Antivir Ther. Oct. 2003;8(5):385-93. Rec #: 2019. [pmid: 14640385].
102 Shulman, N.; Mellors, J.; Clark, S.; Bosch, R., and Parkin, N. Replicative Capacity Effect of Mutations that Are Associated with Efavirenz Hypersusceptibility [Interplay among HIV Resistance, Fitness and Outcome]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1764
103 Simonds RJ, Steketee R, Nesheim S, Matheson P, Palumbo P, Alger L, Abrams EJ, Orloff S, Lindsay M, Bardeguez AD, Vink P, Byers R, Rogers M. Impact of zidovudine use on risk and risk factors for perinatal transmission of HIV. Perinatal AIDS Collaborative Transmission Studies. AIDS. Feb 12. 1998;12(3):301-8. Rec #: 2080. [pmid: 9517993].
104 Sow, P. S.; Schillevoort, I.; Kityo, C., and et al. Implementing antiretroviral treatment in resource-limited settings: clinical results from four African countries. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2045
105 Spacek, L. A.; Mwesigire, D.; Shihab, H., and et al. Treatment outcomes at the Mulago Hospital AIDS in Kampala, Uganda: a resource-limited setting. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2055
106 Stringer, J.; Zulu, I.; Chi, B., and et al. Rapid deployment of ART services is feasible and effective in resource-limited settings in sub-Saharan Africa. 12th Conference on Retroviruses and Opportunistic Infections; Boston. Foundation of Retrovirology and Human Health; 2005. Rec #: 2051
107 Sutthent R, Chokephaibulkit K, Piyasujabul D, Vanprapa N, Roogpisuthipong A, Chaisilwatana P. Effect of perinatal short-course zidovudine on the clinical and virological manifestations of HIV-1 subtype E infection in infants. J Clin Virol. Jul. 2002;25(1):47-56. Rec #: 1725. [pmid: 12126721].
108 Taha TE, Kumwenda NI, Hoover DR, Fiscus SA, Kafulafula G, Nkhoma C, Nour S, Chen S, Liomba G, Miotti PG, Broadhead RL. Nevirapine and zidovudine at birth to reduce perinatal transmission of HIV in an African setting: a randomized controlled trial. JAMA. Jul 14. 2004;292(2):202-9. Rec #: 2060. [pmid: 15249569].
109 Takebe Y, Motomura K, Tatsumi M, Lwin HH, Zaw M, Kusagawa S. High prevalence of diverse forms of HIV-1 intersubtype recombinants in Central Myanmar: geographical hot spot of extensive recombination. AIDS. Sep 26. 2003;17(14):2077-87. Rec #: 1726. [pmid: 14502011].
110 Tanuri A, Swanson P, Devare S, Berro OJ, Savedra A, Costa LJ, Telles JG, Brindeiro R, Schable C, Pieniazek D, Rayfield M. HIV-1 subtypes among blood donors from Rio de Janeiro, Brazil. J Acquir Immune Defic Syndr Hum Retrovirol. Jan 1. 1999;20(1):60-6. Rec #: 2070. [pmid: 9928731].
111 Thomson MM, Delgado E, Manjon N, Ocampo A, Villahermosa ML, Marino A, Herrero I, Cuevas MT, Vazquez-de Parga E, Perez-Alvarez L, Medrano L, Taboada JA, Najera R. HIV-1 genetic diversity in Galicia Spain: BG intersubtype recombinant viruses circulating among injecting drug users. AIDS. Mar 9. 2001;15(4):509-16. Rec #: 1729. [pmid: 11242148].
112 Thomson MM, Sierra M, Tanuri A, May S, Casado G, Manjon N, Najera R. Analysis of near full-length genome sequences of HIV type 1 BF intersubtype recombinant viruses from Brazil reveals their independent origins and their lack of relationship to CRF12_BF. AIDS Res Hum Retroviruses. Oct. 2004;20(10):1126-33. Rec #: 1730. [pmid: 15585105].
113 Torpey, K.; Ampofo, W.; Nyarko, C.; Asare, R.; Antwi, P., and Essah, K. Antiretroviral therapy in Ghana: patients' presentation and response. 15th International AIDS Conference; Bangkok. International AIDS Society; 2004. Rec #: 2048
114 Tovanabutra S, Beyrer C, Sakkhachornphop S, Razak MH, Ramos GL, Vongchak T, Rungruengthanakit K, Saokhieo P, Tejafong K, Kim B, De Souza M, Robb ML, Birx DL, Jittiwutikarn J, Suriyanon V, Celentano DD, McCutchan FE. The changing molecular epidemiology of HIV type 1 among northern Thai drug users, 1999 to 2002. AIDS Res Hum Retroviruses. May. 2004;20(5):465-75. Rec #: 1734. [pmid: 15186520].
115 Tovanabutra S, Brodine SK, Mascola JR, Sankale JL, Sanders-Buell E, Kim B, Birx DL, McCutchan FE. Characterization of complete HIV type 1 genomes from non-B subtype infections in U.S. military personnel. AIDS Res Hum Retroviruses. May. 2005;21(5):424-9. Rec #: 1733. [pmid: 15929707].
116 Triques K, Bourgeois A, Vidal N, Mpoudi-Ngole E, Mulanga-Kabeya C, Nzilambi N, Torimiro N, Saman E, Delaporte E, Peeters M. Near-full-length genome sequencing of divergent African HIV type 1 subtype F viruses leads to the identification of a new HIV type 1 subtype designated K. AIDS Res Hum Retroviruses. Jan 20. 2000;16(2):139-51. Rec #: 1735. [pmid: 10659053].
117 UK Register of HIV Seroconverters Steering Committee. The AIDS incubation period in the UK estimated from a national register of HIV seroconverters. UK Register of HIV Seroconverters Steering Committee. AIDS. Apr 16. 1998;12(6):659-67. Rec #: 2031. [pmid: 9583607].
118 Ungsedhapand C, Kroon ED, Suwanagool S, Ruxrungtham K, Yimsuan N, Sonjai A, Ubolyam S, Buranapraditkun S, Tiengrim S, Pakker N, Kunanusont C, Lange JM, Cooper DA, Phanuphak P. A randomized, open-label, comparative trial of zidovudine plus lamivudine versus zidovudine plus lamivudine plus didanosine in antiretroviral-naive HIV-1-infected Thai patients. J Acquir Immune Defic Syndr. Jun 1. 2001;27(2):116-23. Rec #: 2030. [pmid: 11404532].
119 Wainberg MA. The emergence of HIV resistance and new antiretrovirals: are we winning?. Drug Resist Updat. Jun. 2004;7(3):163-7. Rec #: 1471. [pmid: 15296858].
120 Wegner SA, Wallace MR, Aronson NE, Tasker SA, Blazes DL, Tamminga C, Fraser S, Dolan MJ, Stephan KT, Michael NL, Jagodzinski LL, Vahey MT, Gilcrest JL, Tracy L, Milazzo MJ, Murphy DJ, McKenna P, Hertogs K, Rinehart A, Larder B, Birx DL. Long-term efficacy of routine access to antiretroviral-resistance testing in HIV type 1-infected patients: results of the clinical efficacy of resistance testing trial. Clin Infect Dis. Mar 1. 2004;38(5):723-30. Rec #: 1551. [pmid: 14986258].
121 Weidle PJ, Ganea CE, Irwin KL, Pieniazek D, McGowan JP, Olivo N, Ramos A, Schable C, Lal RB, Holmberg SD, Ernst JA. Presence of human immunodeficiency virus (HIV) type 1, group M, non-B subtypes, Bronx, New York: a sentinel site for monitoring HIV genetic diversity in the United States. J Infect Dis. Feb. 2000;181(2):470-5. Rec #: 1745. [pmid: 10669328].
122 Wiktor SZ, Ekpini E, Karon JM, et al. Short- course oral zidovudine for prevetnion of mother-to-child transmission of HIV-1 in Abidjan, Cote d'Ivoire: a randomised trial. Lancet. 1999;353:781-85. Rec #: 2104. [pmid: 10459958].
123 Williamson C, Morris L, Maughan MF, Ping LH, Dryga SA, Thomas R, Reap EA, Cilliers T, van Harmelen J, Pascual A, Ramjee G, Gray G, Johnston R, Karim SA, Swanstrom R. Characterization and selection of HIV-1 subtype C isolates for use in vaccine development. AIDS Res Hum Retroviruses. Feb. 2003;19(2):133-44. Rec #: 1747. [pmid: 12639249].
124 Wood E, Hogg RS, Yip B, Harrigan PR, O'Shaughnessy MV, Montaner JS. Effect of medication adherence on survival of HIV-infected adults who start highly active antiretroviral therapy when the CD4+ cell count is 0.200 to 0.350 × 10(9) cells/L. Ann Intern Med. Nov 18. 2003;139(10):810-6. Rec #: 2063. [pmid: 14623618].
125 Wood E, Montaner JS, Chan K, Tyndall MW, Schechter MT, Bangsberg D, O'Shaughnessy MV, Hogg RS. Socioeconomic status, access to triple therapy, and survival from HIV-disease since 1996. AIDS. Oct 18. 2002;16(15):2065-72. Rec #: 2065. [pmid: 12370506].
126 Wood E, Montaner JS, Tyndall MW, Schechter MT, O'Shaughnessy MV, Hogg RS. Prevalence and correlates of untreated human immunodeficiency virus type 1 infection among persons who have died in the era of modern antiretroviral therapy. J Infect Dis. Oct 15. 2003;188(8):1164-70. Rec #: 2064. [pmid: 14551887].
127 Yang C, Li M, Shi YP, Winter J, van Eijk AM, Ayisi J, Hu DJ, Steketee R, Nahlen BL, Lal RB. Genetic diversity and high proportion of intersubtype recombinants among HIV type 1-infected pregnant women in Kisumu, western Kenya. AIDS Res Hum Retroviruses. May. 2004;20(5):565-74. Rec #: 1749. [pmid: 15186532].
128 Zhong P, Peeters M, Janssens W, Fransen K, Heyndrickx L, Vanham G, Willems B, Piot P, van der Groen G. Correlation between genetic and biological properties of biologically cloned HIV type 1 viruses representing subtypes A, B, and D. AIDS Res Hum Retroviruses. Feb. 1995;11(2):239-48. Rec #: 1752. [pmid: 7742038].
129 Zijenah, L.; Kadzirange, G.; Tobaiwa, O.; Rusakaniko, S.; Gwanzura, C.; Kufa, T.; Matsikire, E.; Gonah, N.; Lint, J., and Katzenstein, D. A. Immunologic and virologic efficacy of generic nevirapine, zidovudine and lamivudine in the treatment of HIV-1 infected women with pre-exposure to single dose nevirapine or short course zidovudine, in Zimbabwe. 13th Conference on Retroviruses and Opportunistic Infections; Denver, CO. 2006. Rec #: 2128

## Reject: First Screening - Obsolete Therapies

1 Ait-Khaled M, Stone C, Amphlett G, Clotet B, Staszewski S, Katlama C, Tisdale M. M184V is associated with a low incidence of thymidine analogue mutations and low phenotypic resistance to zidovudine and stavudine. AIDS. Aug 16. 2002;16(12):1686-9. Rec #: 1177. [pmid: 12172093].
2 Allen U, Conway B, Lapointe N, Read S, King S, Forbes J, Marshall C, Stephens D, Wells G, Cassol S. High prevalence of genotypic zidovudine resistance among HIV-infected Canadian children. Acta Paediatr. Jul. 2001;90(7):823-4. Rec #: 1400. [pmid: 11519991].
3 Andreoni M, Sarmati L, Nicastri E, Ventura L, Ercoli L, Parisi SG, Giannini G, Galluzzo C, Vella S. Saquinavir delays the emergence of zidovudine resistance in HIV-1 seropositive patients treated with combination therapy. J Med Virol. Dec. 1998;56(4):332-6. Rec #: 1237. [pmid: 9829638].
4 Brun-Vezinet F, Boucher C, Loveday C, Descamps D, Fauveau V, Izopet J, Jeffries D, Kaye S, Krzyanowski C, Nunn A, Schuurman R, Seigneurin JM, Tamalet C, Tedder R, Weber J, Weverling GJ. HIV-1 viral load, phenotype, and resistance in a subset of drug-naive participants from the Delta trial. The National Virology Groups. Delta Virology Working Group and Coordinating Committee. Lancet. Oct 4. 1997;350(9083):983-90. Rec #: 1298. [pmid: 9329513].
5 Calderon EJ, Torres Y, Medrano FJ, Luque F, Larder B, Rey C, Sanchez-Quijano A, Lissen E, Leal M. Emergence and clinical relevance of mutations associated with zidovudine resistance in asymptomatic HIV-1 infected patients. Eur J Clin Microbiol Infect Dis. Jun. 1995;14(6):512-9. Rec #: 1316. [pmid: 7588824].
6 Cho YK, Sung H, Ahn SH, Bae IG, Woo JH, Won YH, Kim DG, Kang MW. Frequency of mutations conferring resistance to nucleoside reverse transcriptase inhibitors in human immunodeficiency virus type 1-infected patients in Korea. J Clin Microbiol. Apr. 2002;40(4):1319-25. Rec #: 1185. [pmid: 11923351]. [pmcid: 140365].
7 D'Aquila RT, Johnson VA, Welles SL, Japour AJ, Kuritzkes DR, DeGruttola V, Reichelderfer PS, Coombs RW, Crumpacker CS, Kahn JO, Richman DD. Zidovudine resistance and HIV-1 disease progression during antiretroviral therapy. AIDS Clinical Trials Group Protocol 116B/117 Team and the Virology Committee Resistance Working Group. Ann Intern Med. Mar 15. 1995;122(6):401-8. Rec #: 1323. [pmid: 7856987].
8 De Antoni A, Foli A, Lisziewicz J, Lori F. Mutations in the pol gene of human immunodeficiency virus type 1 in infected patients receiving didanosine and hydroxyurea combination therapy. J Infect Dis. Oct. 1997;176(4):899-903. Rec #: 1359. [pmid: 9333147].
9 Descamps D, Flandre P, Joly V, Meiffredy V, Peytavin G, Izopet J, Tamalet C, Zeng AF, Harel M, Lastere S, Aboulker JP, Yeni P, Brun-Vezinet F. Effect of zidovudine resistance mutations on virologic response to treatment with zidovudine or stavudine, each in combination with lamivudine and indinavir. J Acquir Immune Defic Syndr. Dec 15. 2002;31(5):464-71. Rec #: 1126. [pmid: 12473833].
10 Drusano GL, Bilello JA, Stein DS, Nessly M, Meibohm A, Emini EA, Deutsch P, Condra J, Chodakewitz J, Holder DJ. Factors influencing the emergence of resistance to indinavir: role of virologic, immunologic, and pharmacologic variables. J Infect Dis. Aug. 1998;178(2):360-7. Rec #: 1242. [pmid: 9697715].
11 Gianotti N, Moretti F, Tambussi G, Racca S, Presi S, Crucianelli R, Carrera P, Ferrari M, Lazzarin A. Study on mutations and antiretroviral therapy (SMART): preliminary results. Antivir Ther. 1999;4(Suppl 3):65-9. Rec #: 1009. [pmid: 16021873].
12 Gianotti N, Setti M, Manconi PE, Leoncini F, Chiodo F, Minoli L, Moroni M, Angarano G, Mazzotta F, Carosi G, Antonelli G, Lazzarin A. Reverse transcriptase mutations in HIV-1 infected patients treated with two nucleoside analogues: the SMART study. Int J Immunopathol Pharmacol. May. 2002;15(2):129-139. Rec #: 1460. [pmid: 12590875].
13 Gilleece Y, Torti C, Mandalia S, Gazzard BG, Pillay D, Pozniak AL. The prevalence of reduced zidovudine susceptibility in zidovudine-naive, antiretroviral-experienced HIV-1-infected patients. HIV Med. Oct. 2003;4(4):305-10. Rec #: 1148. [pmid: 14525540].
14 Gomez-Cano M, Rubio A, Puig T, Perez-Olmeda M, Ruiz L, Soriano V, Pineda JA, Zamora L, Xaus N, Clotet B, Leal M. Prevalence of genotypic resistance to nucleoside analogues in antiretroviral-naive and antiretroviral-experienced HIV-infected patients in Spain. AIDS. Jun 18. 1998;12(9):1015-20. Rec #: 1292. [pmid: 9662197].
15 Hamilton JD, Hartigan PM, Simberkoff MS, Day PL, Diamond GR, Dickinson GM, Drusano GL, Egorin MJ, George WL, Gordin FM, et al. A controlled trial of early versus late treatment with zidovudine in symptomatic human immunodeficiency virus infection. Results of the Veterans Affairs Cooperative Study. N Engl J Med. Feb 13. 1992;326(7):437-43. Rec #: 2020. [pmid: 1346337].
16 Harrigan PR, Stone C, Griffin P, Najera I, Bloor S, Kemp S, Tisdale M, Larder B. Resistance profile of the human immunodeficiency virus type 1 reverse transcriptase inhibitor abacavir (1592U89) after monotherapy and combination therapy. CNA2001 Investigative Group. J Infect Dis. Mar. 2000;181(3):912-20. Rec #: 1274. [pmid: 10720512].
17 Japour AJ, Welles S, D'Aquila RT, Johnson VA, Richman DD, Coombs RW, Reichelderfer PS, Kahn JO, Crumpacker CS, Kuritzkes DR. Prevalence and clinical significance of zidovudine resistance mutations in human immunodeficiency virus isolated from patients after long-term zidovudine treatment. AIDS Clinical Trials Group 116B/117 Study Team and the Virology Committee Resistance Working Group. J Infect Dis. May. 1995;171(5):1172-9. Rec #: 1320. [pmid: 7538548].
18 Joly V, Moroni M, Concia E, Lazzarin A, Hirschel B, Jost J, Chiodo F, Bentwich Z, Love WC, Hawkins DA, Wilkins EG, Gatell AJ, Vetter N, Greenwald C, Freimuth WW, de Cian W. Delavirdine in combination with zidovudine in treatment of human immunodeficiency virus type 1-infected patients: evaluation of efficacy and emergence of viral resistance in a randomized, comparative phase III trial. The M/3331/0013B Study Group. Antimicrob Agents Chemother. Nov. 2000;44(11):3155-7. Rec #: 1094. [pmid: 11036040]. [pmcid: 101620].
19 Katzenstein DA, Bosch RJ, Hellmann N, Wang N, Bacheler L, Albrecht MA. Phenotypic susceptibility and virological outcome in nucleoside-experienced patients receiving three or four antiretroviral drugs. AIDS. Apr 11. 2003;17(6):821-30. Rec #: 1115. [pmid: 12660529].
20 Kuritzkes D, Bassett RL, Young RK, et al. Rate of emergence of thymidine-resistant analogue mutation in HIV-1 selected by stavudine or zidovudine based regimens in treatment naive patients [abstract 36]. Antivir Ther. 2002;7:S31. Rec #: 1579.
21 Kuritzkes DR, Bassett RL, Hazelwood JD, Barrett H, Rhodes RA, Young RK, Johnson VA. Rate of thymidine analogue resistance mutation accumulation with zidovudine- or stavudine-based regimens. J Acquir Immune Defic Syndr. May 1. 2004;36(1):600-3. Rec #: 1098. [pmid: 15097303].
22 Kuritzkes DR, Quinn JB, Benoit SL, Shugarts DL, Griffin A, Bakhtiari M, Poticha D, Eron JJ, Fallon MA, Rubin M. Drug resistance and virologic response in NUCA 3001, a randomized trial of lamivudine (3TC) versus zidovudine (ZDV) versus ZDV plus 3TC in previously untreated patients. AIDS. Aug. 1996;10(9):975-81. Rec #: 1307. [pmid: 8853730].
23 Kuritzkes DR, Shugarts D, Bakhtiari M, Poticha D, Johnson J, Rubin M, Gingeras TR, Kennedy M, Eron JJ. Emergence of dual resistance to zidovudine and lamivudine in HIV-1-infected patients treated with zidovudine plus lamivudine as initial therapy. J Acquir Immune Defic Syndr. Jan 1. 2000;23(1):26-34. Rec #: 1278. [pmid: 10708053].
24 Land S, McGavin C, Lucas R, Birch C. Incidence of zidovudine-resistant human immunodeficiency virus isolated from patients before, during, and after therapy. J Infect Dis. Nov. 1992;166(5):1139-42. Rec #: 1338. [pmid: 1402026].
25 Larder BA, Kohli A, Bloor S, Kemp SD, Harrigan PR, Schooley RT, Lange JM, Pennington KN, St Clair MH. Human immunodeficiency virus type 1 drug susceptibility during zidovudine (AZT) monotherapy compared with AZT plus 2',3'-dideoxyinosine or AZT plus 2',3'-dideoxycytidine combination therapy. The protocol 34,225-02 Collaborative Group. J Virol. Sep. 1996;70(9):5922-9. Rec #: 1441. [pmid: 8709213]. [pmcid: 190611].
26 Leal M, Rey C, Torres Y, Relimpio F, Pino R, Lissen E, Sanchez-Quijano A, Luque F. Rate of development of mutation at codon 215 of HIV-1 reverse transcriptase and its predictive factors at the time of initiation of zidovudine therapy. Eur J Clin Invest. Jun. 1996;26(6):476-80. Rec #: 1309. [pmid: 8817161].
27 Lee, C.-C.; Thoe S.-Y.S.; Leo Y.-S.; Chan K.-P., and Ling A.-E. (C.-C. Lee, Department of Infectious Disease, Communicable Disease Centre, Tan Tock Seng Hospital, Singapore.). Letter To: AIDS. United Kingdom; 2000 May 26. Rec #: 1498
28 Lolekha R, Sirivichayakul S, Siangphoe U, Pancharoen C, Kaewchana S, Apateerapong W, Mahanontharit A, Chotpitayasunondh T, Ruxrungtham K, Phanuphak P, Ananworanich J. Resistance to dual nucleoside reverse-transcriptase inhibitors in children infected with HIV clade A/E. Clin Infect Dis. Jan 15. 2005;40(2):309-12. Rec #: 1459. [pmid: 15655753].
29 Mayers DL, Japour AJ, Arduino JM, Hammer SM, Reichman R, Wagner KF, Chung R, Lane J, Crumpacker CS, McLeod GX, et al. Dideoxynucleoside resistance emerges with prolonged zidovudine monotherapy. The RV43 Study Group. Antimicrob Agents Chemother. Feb. 1994;38(2):307-14. Rec #: 1328. [pmid: 8192457]. [pmcid: 284445].
30 Montaner JS, Singer J, Schechter MT, Raboud JM, Tsoukas C, O'Shaughnessy M, Ruedy J, Nagai K, Salomon H, Spira B, et al. Clinical correlates of in vitro HIV-1 resistance ot zidovudine. Results of the Multicentre Canadian AZT Trial. AIDS. Feb. 1993;7(2):189-96. Rec #: 1389. [pmid: 8466681].
31 Naugler WE, Yong FH, Carey VJ, Dragavon JA, Coombs RW, Frenkel LM. T69D/N pol mutation, human immunodeficiency virus type 1 RNA levels, and syncytium-inducing phenotype are associated with CD4 cell depletion during didanosine therapy. J Infect Dis. Feb 15. 2002;185(4):448-55. Rec #: 1694. [pmid: 11865396].
32 Nielsen C, Gotzsche PC, Nielsen CM, Gerstoft J, Vestergaard BF. Development of resistance to zidovudine in HIV strains isolated from CD4+ lymphocytes and plasma during therapy. Antiviral Res. Jun. 1992;18(34):303-16. Rec #: 1340. [pmid: 1358026].
33 Orlandi P, Cancrini C, Scaccia S, Romiti ML, Livadiotti S, Gattinara GC, Angelini F, Cox S, Rossi P. Analysis of HIV-1 reverse transcriptase gene mutations in infected children treated with zidovudine. J Acquir Immune Defic Syndr Hum Retrovirol. Nov 1. 1998;19(3):230-7. Rec #: 1695. [pmid: 9803964].
34 Perez-Alvarez, L.; Villahermosa, M. L.; Cuevas, M. T.; Delgado, E.; Manjon, N.; Vazquez de Parga, E.; Medrano, L.; Contreras, G.; Thomson, M. M.; Colomo, C.; Taboada, J. A., and Najera, R. Single- and multidrug resistance mutations to reverse transcriptase and protease inhibitors: human immunodeficiency virus type 1-infected patients from two geographical areas in Spain. Spanish Groups for Antiretroviral Resistance Studies. J Hum Virol. 2000 May–2000 Jun 30; 3(3):150–6. Rec #: 1265
35 Pilcher CD, Perkins MD, Fiscus SA, Johnston DM, Dietze R, Duque UH, Zago AM, Assad-Antunes F, Eron JJ. Genotypic resistance and the treatment of HIV-1 infection in Espirito Santo, Brazil. J Infect Dis. May. 1999;179(5):1259-63. Rec #: 1705. [pmid: 10191233].
36 Principi N, Marchisio P, Esposito S, Rossi P, Gattinara GC, Galli L, Gabiano C, Zuccotti GV, Orlandi P. Zidovudine therapy and HIV type 1 mutations in children with symptomatic HIV type 1 infection: effect of switching to didanosine or zidovudine plus didanosine therapy. Italian Multicenter Study Group on HIV Mutations in Children. AIDS Res Hum Retroviruses. Dec 20. 1998;14(18):1653-9. Rec #: 1465. [pmid: 9870319].
37 Quattro Trial. Observations of HIV-1 genotypic drug resistance in a trial of four reverse transcriptase inhibitors (Quattro Trial). Antivir Ther. 2002 Mar; 7(1):11–20.
38 Ross, L.; Henry, K.; Paar, D.; Salvato, P.; Shaefer, M.; Fisher, R.; Liao, Q., and St Clai, M. Thymidine-analog and multi-nucleoside resistance mutations are observed in both zidovudine-naive and zidovudine-experienced subjects with viremia after treatment with stavudine-containing regimens. J Hum Virol. 2001 Jul–2001 Aug 31; 4(4):217–22. Rec #: 1200
39 Rubio A, Gomez-Cano M, Puig T, Leal M, Perez-Olmeda M, Ruiz L, Clotet B, Rey C, Zamora L, Xaus N, Soriano V. Presence of genotypic resistance in nucleoside analogue-treated HIV-1-infected patients with undetectable viral load. Antivir Ther. 1999;4(1):45-9. Rec #: 1282. [pmid: 10682128].
40 Ruibal-Brunet IJ, Cuevas MT, Diaz-Torres H, Villahermosa ML, Noa-Romero E, Vazquez de Parga E, Blanco de Armas M, Perez-Alvarez L. Genotypic resistance mutations to antiretroviral drugs in HIV-1 B and non-B subtypes from Cuba. Rev Panam Salud Publica. Sep. 2001;10(3):174-80. Rec #: 1198. [pmid: 11702373].
41 Sirivichayakul S, Ruxrungtham K, Ungsedhapand C, Techasathit W, Ubolyam S, Chuenyam T, Emery S, Cooper D, Lange J, Phanuphak P. Nucleoside analogue mutations and Q151M in HIV-1 subtype A/E infection treated with nucleoside reverse transcriptase inhibitors. AIDS. Sep 5. 2003;17(13):1889-96. Rec #: 1724. [pmid: 12960821].
42 Tedder RS, Kaye S, Loveday C, Weller IV, Jeffries D, Norman J, Weber J, Bourelly M, Foxall R, Babiker A, Darbyshire JH. Comparison of culture- and non-culture-based methods for quantification of viral load and resistance to antiretroviral drugs in patients given zidovudine monotherapy. J Clin Microbiol. Apr. 1998;36(4):1056-63. Rec #: 1295. [pmid: 9542937]. [pmcid: 104689].
43 Van Vaerenbergh K, Van Laethem K, Albert J, Boucher CA, Clotet B, Floridia M, Gerstoft J, Hejdeman B, Nielsen C, Pannecouque C, Perrin L, Pirillo MF, Ruiz L, Schmit JC, Schneider F, Schoolmeester A, Schuurman R, Stellbrink HJ, Stuyver L, Van Lunzen J, Van Remoortel B, Van Wijngaerden E, Vella S, Witvrouw M, Yerly S, De Clercq E, Destmyer J, Vandamme AM. Prevalence and characteristics of multinucleoside-resistant human immunodeficiency virus type 1 among European patients receiving combinations of nucleoside analogues. Antimicrob Agents Chemother. Aug. 2000;44(8):2109-17. Rec #: 1262. [pmid: 10898683]. [pmcid: 90021].
44 Vella S, Galluzzo C, Giannini G, Pirillo MF, Duncan I, Jacobsen H, Andreoni M, Sarmati L, Ercoli L. Saquinavir/zidovudine combination in patients with advanced HIV infection and no prior antiretroviral therapy: CD4+ lymphocyte/plasma RNA changes, and emergence of HIV strains with reduced phenotypic sensitivity. Antiviral Res. Jan. 1996;29(1):91-3. Rec #: 1261. [pmid: 8721555].
45 Vergne L, Malonga-Mouellet G, Mistoul I, Mavoungou R, Mansaray H, Peeters M, Delaporte E. Resistance to antiretroviral treatment in Gabon: need for implementation of guidelines on antiretroviral therapy use and HIV-1 drug resistance monitoring in developing countries. J Acquir Immune Defic Syndr. Feb 1. 2002;29(2):165-8. Rec #: 1739. [pmid: 11832686].
46 Wainberg MA, Salomon H, Gu Z, Montaner JS, Cooley TP, McCaffrey R, Ruedy J, Hirst HM, Cammack N, Cameron J, et al. Development of HIV-1 resistance to (-)2'-deoxy-3'-thiacytidine in patients with AIDS or advanced AIDS-related complex. AIDS. Apr. 1995;9(4):351-7. Rec #: 1321. [pmid: 7540846].
47 Yarchoan R, Lietzau JA, Nguyen BY, Brawley OW, Pluda JM, Saville MW, Wyvill KM, Steinberg SM, Agbaria R, Mitsuya H, et al. A randomized pilot study of alternating or simultaneous zidovudine and didanosine therapy in patients with symptomatic human immunodeficiency virus infection. J Infect Dis. Jan. 1994;169(1):9-17. Rec #: 2034. [pmid: 7903976].
48 Zolopa AR, Shafer RW, Warford A, Montoya JG, Hsu P, Katzenstein D, Merigan TC, Efron B. HIV-1 genotypic resistance patterns predict response to saquinavir-ritonavir therapy in patients in whom previous protease inhibitor therapy had failed. Ann Intern Med. Dec 7. 1999;131(11):813-21. Rec #: 1753. [pmid: 10610625]. [pmcid: 2606144].

## Rejected: Second screening - TX naive only (incl. pre-2000)

1 Al Dhahry SH, Scrimgeour EM, Al Suwaid AR, Al Lawati MR, El Khatim HS, Al Kobaisi MF, Merigan TC. Human immunodeficiency virus type 1 infection in Oman: antiretroviral therapy and frequencies of drug resistance mutations. AIDS Res Hum Retroviruses. Nov. 2004;20(11):1166-72. Rec #: 1024. [pmid: 15588338].
2 Alexander CS, Dong W, Schechter MT, O'Shaughnessy MV, Strathdee SA, Mo T, Montaner JS, Harrigan PR. Prevalence of primary HIV drug resistance among seroconverters during an explosive outbreak of HIV infection among injecting drug users. AIDS. May 28. 1999;13(8):981-5. Rec #: 2101. [pmid: 10371180].
3 Balotta, C.; Corvasce, S.; Romano, L.; Violin, M.; Razzolini, F.; Vicenti, I.; Marconi, A.; Macciesi, C.; Machetti, S.; Galli, A.; Duca, P., and Zazzi, M. Evidence of differential selection of HIV-1 variants carrying drug-resistant mutations in seroconverters. 2004; 9, S56. Rec #: 1914
4 Bennett, D.; McCormick, L.; Kline, R.; Wheeler, W.; Hemmen, M.; Smith, A.; Zaidi, I.; Dondero, T., and The HIV Drug Resistance ARVDRT/VARHS Surveillance Group. U.S Surveillance of HIV Drug Resistance at Diagnosis Using HIV Diagnostic Sera. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1841
5 Bennett DE, McCormick L, Wheeler W, Kline R. Mutation patterns associated with resistance to tenofovir in drug-naive persons newly diagnosed with HIV. Antivir Ther. 2005;10:S27. Rec #: 1965.
6 Bennett, D. E.; Zaidi, I.; Smith, A. J., and McCormick, L. HIV drug resistance among foreign-born persons newly diagnosed with HIV in the US. 2004; 9, S105. Rec #: 1927
7 Benson, C. A.; Campell, T.; MaWhinney, S.; Connick, E.; Forster, J.; Ray, G.; Thompson, M.; Landay, A.; Badaro, R.; Netto, E.; Judson, F.; Pallela, F., and Schooley, R. A Pilot Open-label Phase II Trial of the Safety and Efficacy of a Compact 3-Drug Antiretroviral Treatment Regimen for Subjects with Acute or Recent Primary HIV-1 Infection. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1867
8 Boden, D.; Hurley, A.; Zhang, L.; Cao, Y.; Guo, Y.; Jones, E.; Tsay, J.; Ip, J.; Farthing, C.; Limoli, K.; Parkin, N., and Markowitz, M. HIV-1 drug resistance in newly infected individuals. JAMA. 1999 Sep 22–1999 Sep 29; 282(12):1135–41. Rec #: 1592
9 Brodine SK, Shaffer RA, Starkey MJ, Tasker SA, Gilcrest JL, Louder MK, Barile A, VanCott TC, Vahey MT, McCutchan FE, Birx DL, Richman DD, Mascola JR. Drug resistance patterns, genetic subtypes, clinical features, and risk factors in military personnel with HIV-1 seroconversion. Ann Intern Med. Oct 5. 1999;131(7):502-6. Rec #: 2098. [pmid: 10507958].
10 Cesaire R, Dos Santos G, Abel S, Bera O, Sobesky G, Cabie A. Drug resistance mutations among HIV-1 strains from antiretroviral-naive patients in Martinique, French West Indies. J Acquir Immune Defic Syndr. Dec 1. 1999;22(4):401-5. Rec #: 1284. [pmid: 10634203].
11 de Mendoza, C.; Rodriguez, C.; Colomina, J.; Tuset, C.; Garcia, F.; Eiros, J.; Corral, A.; del Romero, J.; Aguero, J.; Leiva, P.; Torre-Cisneros, J.; Viciana, I.; Pedreira, J.; Ortiz, R.; Soriano, V., and the Spanish Seroconvertoer Study Group. Transmission of Drug-resistant Viruses in Recent HIV Seroconverters in Spain. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1879
12 Delaugerre C, Mouroux M, Yvon-Groussin A, Simon A, Angleraud F, Huraux JM, Agut H, Katlama C, Calvez V. Prevalence and conditions of selection of E44D/A and V118I human immunodeficiency virus type 1 reverse transcriptase mutations in clinical practice. Antimicrob Agents Chemother. Mar. 2001;45(3):946-8. Rec #: 1246. [pmid: 11181387]. [pmcid: 90400].
13 Dunn, D. T.; Green, H.; Matthias, R., and et al. Prevalence of reduced drug susceptibility in treatment-naive patients in the UK. 2004; 9, S107. Rec #: 1928
14 Duwe S, Brunn M, Altmann D, Hamouda O, Schmidt B, Walter H, Pauli G, Kucherer C. Frequency of genotypic and phenotypic drug-resistant HIV-1 among therapy-naive patients of the German Seroconverter Study. J Acquir Immune Defic Syndr. Mar 1. 2001;26(3):266-73. Rec #: 2094. [pmid: 11242200].
15 Easterbrook, P.; Welz, T., and UK Collaborative Group on HIV Drug Resistance. Effect of HIV-1 Subtype on Genotypic Resistance ot Protease Inhibitors in the United Kingdog [Selection, Evolution and Persistence of Drug Resistance]. 13th Conference on Retroviruses and Oppotunistic Infections; 2006. Rec #: 1760
16 Fontaine, E.; Lambert, C.; Servais, J.; Ninove, D.; Plesseria, J. M.; Staub, T.; Arendt, V.; Kirpach, P.; Robert, I.; Schneider, F.; Hemmer, R., and Schmit, J. C. Fast genotypic detection of drug resistance mutations in the HIV-1 reverse transcriptase gene of treatment-naive patients. J Hum Virol. 1998 Nov–1998 Dec 31; 1(7):451–6. Rec #: 1289
17 Gallego O, Briones C, Corral A, Soriano V. Prevalence of novel lamivudine-resistant genotypes (E44D/A, V118I) in naive and pretreated HIV-infected individuals. J Acquir Immune Defic Syndr. Sep 1. 2000;25(1):95-6. Rec #: 1254. [pmid: 11064512].
18 Garcia F, Romeu J, Grau I, Sambeat MA, Dalmau D, Knobel H, Gomez-Sirvent JL, Arrizabalaga J, Cruceta A, Clotet BG, Podzamczer D, Pumarola T, Gallart T, O'Brien WA, Miro JM, Gatell JM. (Institut d'Investigacions Biomediques August Pi I Sunyer, Faculty of Medicine, University of Barcelona, Spain.). A randomized study comparing triple versus double antiretroviral therapy or no treatment in HIV-1-infected patients in very early stage disease: the Spanish Earth-1 study. AIDS. Dec. 1999;13(17):2377-88. Rec #: 1384. [pmid: 10597779].
19 Garcia-Guerrero J, Herrero A, Bedia M, Araujo R, Castellano JC. [Primary HIV drug resistance in a prison population. REPRICOVA-2 Study]. Enferm Infecc Microbiol Clin. Jan. 2004;22(1):29-31. Rec #: 1456. [pmid: 14757005].
20 Garcia-Guerrero J, Herrero A, Vera E, Almenara JM, Araujo R, Sauri VV, Castellano JC, Fernandez-Clemente L, Bedia M, Llorente MI, Gonzalez-Moran F. [Mutations of resistance of HIV-1 in previously untreated patients at penitentiary centers of the Autonomous Community of Valencia, Spain. REPRICOVA study]. Med Clin (Barc). Mar 2. 2002;118(7):247-50. Rec #: 1478. [pmid: 11882275].
21 Gatanaga, H.; Koike, T.; Asagi, T.; Tsukada, H.; Kondo, M.; Masakane, A.; Kaneda, T.; Mori, H.; Minami, R.; Sugiura, W., and Japanese Drug Resistane HIV-1 Surveillance Network. Multi-center Nationwide Survey of Drug-resistant HIV-1 in Newly Diagnosed HIV/AIDS Patients in Japan from 2003 to 2004 [Epidemiology and Transmission of Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1774
22 Geretti AM, Smith M, Watson C, Mullen J, Osner N, O'Shea S, Chrystie I, Zuckerman M, Easterbrook P. (A.M. Geretti, South London Pub. Health Laboratory, Department of Infection, King's College Hospital, London. United Kingdom). Primary antiretroviral resistance in newly diagnosed patients with established heterosexually acquired HIV-1 [3]. AIDS. Nov 22. 2002;16(17):2358-60. ISSN: 0269-9370. Rec #: 1496. [pmid: 12441818].
23 Gibb DM, Walker AS, Kaye S, De Rossi A, Ait-Khaled M, Pillay D, Munoz-Fernandez MA, Loveday C, Compagnucci A, Dunn DT, Babiker AG. (Medical Research Council Clinical Trials Unit, London, UK. D.Gibb@ctu.mrc.ac.uk). Evolution of antiretroviral phenotypic and genotypic drug resistance in antiretroviral-naive HIV-1-infected children treated with abacavir/lamivudine, zidovudine/lamivudine or abacavir/zidovudine, with or without nelfinavir (the PENTA 5 trial). Antivir Ther. Dec. 2002;7(4):293-303. Rec #: 1373. [pmid: 12553485].
24 Gleeson, T.; Archibald, C. P.; Jayaraman, G. C., and Sandstrom, P. The prevalence of drug resistance in a population of individuals testing positive for HIV infection in Canada from 2000-2003. 2004; 9, S108. Rec #: 1929
25 Grant RM, Hecht FM, Warmerdam M, Liu L, Liegler T, Petropoulos CJ, Hellmann NS, Chesney M, Busch MP, Kahn JO. Time trends in primary HIV-1 drug resistance among recently infected persons. JAMA. Jul 10. 2002;288(2):181-8. Rec #: 1539. [pmid: 12095382].
26 Grant, R. M.; Liegler, T. I., and Hecht, F. M. Clusters and trends in primary resistance in San Francisco, 2001-2003. 2004; 9, S104. Rec #: 1925
27 Grossman Z, Paxinos EE, Averbuch D, Maayan S, Parkin NT, Engelhard D, Lorber M, Istomin V, Shaked Y, Mendelson E, Ram D, Petropoulos CJ, Schapiro JM. Mutation D30N is not preferentially selected by human immunodeficiency virus type 1 subtype C in the development of resistance to nelfinavir. Antimicrob Agents Chemother. Jun. 2004;48(6):2159-65. Rec #: 1655. [pmid: 15155216]. [pmcid: 415604].
28 Hanna GJ, Balaguera HU, Freedberg KA, Werner BG, Steger Craven KA, Craven DE, D'Aquila RT. Drug-selected resistance mutations and non-B subtypes in antiretroviral-naive adults with established human immunodeficiency virus infection. J Infect Dis. Oct 1. 2003;188(7):986-91. Rec #: 1659. [pmid: 14513418].
29 Harrigan PR, Hertogs K, Verbiest W, Larder B, Yip B, Brumme ZL, Alexander C, Tilley J, O'Shaughnessy MV, Montaner JS. Modest decreases in NNRTI susceptibility do not influence virological outcome in patients receiving initial NNRTI-containing triple therapy. Antivir Ther. Oct. 2003;8(5):395-402. Rec #: 1046. [pmid: 14640386].
30 Harrigan, R.; Dong, W.; Alexander, C., and et al. The association between drug resistance and adherence determined by two independent methods in a large cohort of drug naive individuals starting triple therapy. 2nd International Conference on HIV Treatment and Pathogenesis; Paris. IAS International AIDS Society, Stockholm, Sweden; 2003. Rec #: 1555
31 Harzic M, Pellegrin I, Deveau C, Chaix ML, Dubeaux B, Garrigue I, Ngo N, Rouzioux C, Goujard C, Hoen B, Sereni D, Delfraissy JF, Meyer L. Genotypic drug resistance during HIV-1 primary infection in France (1996-1999): frequency and response to treatment. AIDS. Mar 29. 2002;16(5):793-6. Rec #: 1158. [pmid: 11964538].
32 Henderson, H. and Brown, B. HIV drug resistance among untreated chronically HIV-infected person in an infectious diseases (ID) clinic in Jackson, Mississippi. 43rd Annual Meeting of IDSA; San Francisco. 2005 Oct 6–2005 Oct 9. Rec #: 1909
33 Hicks, C.; Eron, J.; Fiscus, S.; Petch, L.; Nguyen, T.; Menezes, P.; Giner, J.; Leone, P.; Cachafeiro, A.; Stalzer, B.; Williams, D.; McPherson, T.; Sebastian, J., and Pilcher, C. Transmitted HIV Resistance among Patients with Acute and Recent HIV Infection in North Carolina: Report of 102 Cases. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1880
34 Holguin A, Alvarez A, Soriano V. High prevalence of HIV-1 subtype G and natural polymorphisms at the protease gene among HIV-infected immigrants in Madrid. AIDS. May 24. 2002;16(8):1163-70. Rec #: 1399. [pmid: 12004275].
35 Horban A, Stanczak JJ, Bakowska E, Tobolewska EJ, Przybylska-Stengiel KJ, Stanczak GP, Burkacka E. High prevalence of genotypic resistance to nucleoside reverse transcriptase inhibitors among therapy-naive individuals from the Warsaw cohort. Infection. Dec. 2002;30(6):356-9. Rec #: 1172. [pmid: 12478325].
36 Ibe S, Hotta N, Takeo U, Tawada Y, Mamiya N, Yamanaka K, Utsumi M, Kaneda T. Prevalence of drug-resistant human immunodeficiency virus type 1 in therapy-naive patients and usefulness of genotype testing. Microbiol Immunol. 2003;47(7):499-505. Rec #: 1051. [pmid: 12953843].
37 Jayaraman GC, Sandstrom P, Archibald CP. Prevalence and determinants of HIV-1 variants with multiple class drug resistance: results from the Canadian HIV strain and drug resistance surveillance program. Antivir Ther. 2005;10:S136. Rec #: 1982.
38 Johnson JA, Li J-F, Wei X, Craig C, Stone C, Horton JH, Lanier ER, Heneine W. Baseline detection of low-frequency drug reseistance-associated mutations is strongly associated with virological failure in previously antiretroviral-naive HIV-1-infected persons. Antivir Ther. 2006;11:S79. Rec #: 2003.
39 Jorgensen LB, Christensen MB, Gerstoft J, Mathiesen LR, Obel N, Pedersen C, Nielsen H, Nielsen C. Prevalence of drug resistance mutations and non-B subtypes in newly diagnosed HIV-1 patients in Denmark. Scand J Infect Dis. 2003;35(1112):800-7. Rec #: 1121. [pmid: 14723353].
40 Kindelan JM, Gimenez-Domenech R, Vidal-Verdu E, Madueno J. [Prevalence of primary mutations in human immunodeficiency virus with resistance to nucleoside analogues in previously untreated patients from Andalusia. Andalusian Group for the Study of Infectious diseases (GAEI)]. Med Clin (Barc). Oct 7. 2000;115(11):423-5. Rec #: 1251. [pmid: 11093845].
41 Le, Moing V. Chene G. Spire B. Raffi F. Leport C. (V. Le Moing, Service des Maladies Infectieuses et Tropicales, CHU). Outcome of HIV-infected patients after 5 years of anti-retroviral therapy including a protease inhibitor: The Aproco/Copilote cohort: <ORIGINAL> Devenir des patients infectes par le vih apres 5 ans de traitment antiretroviral comprenant un inhibiteur de protease: exemple de la cohorte aproco/copilote. Presse Medicale. 2005 Jun 4; 341531–37; ISSN: 0755-4982. Rec #: 1491
42 Little, S. J.; Daar, E. S.; D'Aquila, R. T.; Keiser, P. H.; Connick, E.; Whitcomb, J. M.; Hellmann, N. S.; Petropoulos, C. J.; Sutton, L.; Pitt, J. A.; Rosenberg, E. S.; Koup, R. A.; Walker, B. D., and Richman, D. D. Reduced antiretroviral drug susceptibility among patients with primary HIV infection. JAMA. 1999 Sep 22–1999 Sep 29; 282(12):1142–9. Rec #: 1593
43 Little, S. J.; Grant, R. M.; Daar, E. S.; Markowitz, M.; Hecht, F. M.; Johnson, V.; Allen, T.; Frenkel, L. M.; Benson, C.; Routy, J. P.; Conway, B.; Sun, X.; Richman, D. D., and Frost, S. D. W. Transmitted NNRTI drug resistance is associated with higher steady-state viral load measures in untreated subjects with primary HIV inection. 2004; 9, S58. Rec #: 1915
44 Little SJ, Holte S, Routy JP, Daar ES, Markowitz M, Collier AC, Koup RA, Mellors JW, Connick E, Conway B, Kilby M, Wang L, Whitcomb JM, Hellmann NS, Richman DD. Antiretroviral-drug resistance among patients recently infected with HIV. N Engl J Med. Aug 8. 2002;347(6):385-94. Rec #: 1516. [pmid: 12167680].
45 MacRae E, Loveday C. High prevalence of HIV-1 non-B subtype recombinants and diverse polymorphic profiles in a UK clinical cohort - implications for future resistance analysis. Antivir Ther. 2005;10:S147. Rec #: 1992.
46 Maljkovic I, Wilbe K, Solver E, Alaeus A, Leitner T. Limited transmission of drug-resistant HIV type 1 in 100 Swedish newly detected and drug-naive patients infected with subtypes A, B, C, D, G, U, and CRF01_AE. AIDS Res Hum Retroviruses. Nov. 2003;19(11):989-97. Rec #: 1689. [pmid: 14678606].
47 Martinez-Picado J, Gutierrez C, de Mendoza C, et al. Surveillance of drug resistance and HIV subtypes in newly diagnosed patients in Spain during 2004. Antivir Ther. 2005;10:S137. Rec #: 1983.
48 Masquelier B, Peytavin G, Leport C, Droz C, Duran S, Verdon R, Besnier JM, Chene G, Raffi F, Brun-Vezinet F. Mechanisms of early virologic failure in antiretroviral-naive patients starting protease inhibitor-containing regimens: the APROVIR Study. J Infect Dis. Nov 15. 2002;186(10):1503-7. Rec #: 1691. [pmid: 12404170].
49 Masuhr A, Mueller M, Simon V, Zwingers T, Kurowski M, Jessen H, Lauenroth-Mai E, Moll A, Schranz D, Moecklinghoff C, Arasteh K. (Auguste-Viktoria-Hospital, TH of Free University Berlin, Germany.). Predictors of treatment failure during highly active antiretroviral therapy (racing trial). Eur J Med Res. Aug. 2002;7(8):341-6. Rec #: 1379. [pmid: 12204841].
50 McCormack, O. E.; Barnett, B. J., and Arduino, R. C. Changes in prevalence of genotypic resistance in chronically infected antiretroviral-naive HIV patients in Houston: 1999 and 2003-2004. 42nd Annual Meeting of IDSA; Boston, MS. 2004. Rec #: 2087
51 Middleton, T.; Taqi, R.; Russell, J.; Roth, N.; Medland, N., and Birch, C. Transmission of antiretroviral drug resistant HIV strains between 1996 and 2003 in Victoria, Australia, and their subsequent evolution in untreated individuals. 2004; 9, S110. Rec #: 1931
52 Monno L, Saracino A, Scudeller L, Pastore G, Bonora S, Cargnel A, Carosi G, Angarano G. HIV-1 phenotypic susceptibility to lopinavir (LPV) and genotypic analysis in LPV/r-naive subjects with prior protease inhibitor experience. J Acquir Immune Defic Syndr. Aug 1. 2003;33(4):439-47. Rec #: 1692. [pmid: 12869832].
53 Montes B, Segondy M. Prevalence of the mutational pattern E44D/A and/or V118I in the reverse transcriptase (RT) gene of HIV-1 in relation to treatment with nucleoside analogue RT inhibitors. J Med Virol. Mar. 2002;66(3):299-303. Rec #: 1191. [pmid: 11793380].
54 Nannini EC, Han X, O'Brien WA, Arduino RC. Genotypic HIV-1 drug resistance testing in antiretroviral-naive subjects in Houston, Texas. J Acquir Immune Defic Syndr. Mar 1. 2002;29(3):317-9. Rec #: 1397. [pmid: 11873085].
55 Novak RM, Chen L, MacArthur RD, Baxter JD, Huppler Hullsiek K, Peng G, Xiang Y, Henely C, Schmetter B, Uy J, van den Berg-Wolf M, Kozal M. Prevalence of antiretroviral drug resistance mutations in chronically HIV-infected, treatment-naive patients: implications for routine resistance screening before initiation of antiretroviral therapy. Clin Infect Dis. Feb 1. 2005;40(3):468-74. Rec #: 1451. [pmid: 15668873].
56 Paraskevis D, Magiorkinis E, Katsoulidou A, Hatzitheodorou E, Antoniadou A, Papadopoulos A, Poulakou G, Paparizos V, Botsi C, Stavrianeas N, Lelekis M, Chini M, Gargalianos P, Magafas N, Lazanas M, Chryssos G, Petrikkos G, Panos G, Kordossis T, Theodoridou M, Sypsa V, Hatzakis A. Prevalence of resistance-associated mutations in newly diagnosed HIV-1 patients in Greece. Virus Res. Sep. 2005;112(12):115-22. Rec #: 1698. [pmid: 16022906].
57 Perez-Olmeda M, Del Romero J, Rubio A, Ruiz L, Rodriguez C, Leal M, Clotet B, Soriano V. Primary HIV-1 drug resistance in Spain before and after the introduction of protease inhibitors. J Med Virol. Feb. 2001;63(2):85-7. Rec #: 1247. [pmid: 11170042].
58 Perno CF, Cozzi-Lepri A, Balotta C, Forbici F, Violin M, Bertoli A, Facchi G, Pezzotti P, Angarano G, Arici C, Narciso P, Orani A, Raise E, Scalzini A, Poggio A, Ippolito G, Moroni M, Monforte AD. Impact of mutations conferring reduced susceptibility to lamivudine on the response to antiretroviral therapy. Antivir Ther. Sep. 2001;6(3):195-8. Rec #: 1702. [pmid: 11808755].
59 Perno CF, Cozzi-Lepri A, Balotta C, Forbici F, Violin M, Bertoli A, Facchi G, Pezzotti P, Cadeo G, Tositti G, Pasquinucci S, Pauluzzi S, Scalzini A, Salassa B, Vincenti A, Phillips AN, Dianzani F, Appice A, Angarano G, Monno L, Ippolito G, Moroni M, d' Arminio Monforte A. Secondary mutations in the protease region of human immunodeficiency virus and virologic failure in drug-naive patients treated with protease inhibitor-based therapy. J Infect Dis. Oct 15. 2001;184(8):983-91. Rec #: 1481. [pmid: 11574912].
60 Pillay D, Walker AS, Gibb DM, de Rossi A, Kaye S, Ait-Khaled M, Munoz-Fernandez M, Babiker A. (Public Health Laboratory Service Antiviral Susceptibility Reference Unit, Birmingham Public Health Laboratory, Birmingham, United Kingdom.). Impact of human immunodeficiency virus type 1 subtypes on virologic response and emergence of drug resistance among children in the Paediatric European Network for Treatment of AIDS (PENTA) 5 trial. J Infect Dis. Sep. 2002;186(5):617-25. Rec #: 1374. [pmid: 12195348].
61 Pilon, R.; Brooks, J.; Goedhuis, N.; Jayaraman, G.; Archibald, C., and Sandstrom P. Current Trends in HIV Molecular Epidemiology in Canada Results of the National Surveillance Program [Epidemiology and Transmission of Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1773
62 Puig T, Perez-Olmeda M, Rubio A, Ruiz L, Briones C, Franco JM, Gomez-Cano M, Stuyver L, Zamora L, Alvarez C, Leal M, Clotet B, Soriano V. Prevalence of genotypic resistance to nucleoside analogues and protease inhibitors in Spain. The ERASE-2 Study Group. AIDS. Apr 14. 2000;14(6):727-32. Rec #: 1220. [pmid: 10807196].
63 Salomon H, Wainberg MA, Brenner B, Quan Y, Rouleau D, Cote P, LeBlanc R, Lefebvre E, Spira B, Tsoukas C, Sekaly RP, Conway B, Mayers D, Routy JP. Prevalence of HIV-1 resistant to antiretroviral drugs in 81 individuals newly infected by sexual contact or injecting drug use. Investigators of the Quebec Primary Infection Study. AIDS. Jan 28. 2000;14(2):F17-23. Rec #: 1277. [pmid: 10708278].
64 Shet, A.; Mohri, H.; Berry, L.; Mehandru, S.; Hurley, A.; Simon, V.; Boden, D., and Markowitz, M. Transmission of Drug Resistant HIV-1 in Patients with Acute and Early HIV-1 Infection in 2003 to 2004. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1855
65 Simon V, Vanderhoeven J, Hurley A, Ramratnam B, Louie M, Dawson K, Parkin N, Boden D, Markowitz M. Evolving patterns of HIV-1 resistance to antiretroviral agents in newly infected individuals. AIDS. Jul 26. 2002;16(11):1511-9. Rec #: 1179. [pmid: 12131189].
66 Svarovoskaia ES, Margot NA, Bae AS, Waters JM, Borroto-Esoda K, Miller MD. Allele-specific PCR shows low-level K65R in treatment-experienced patients with L74V in the absence of TMAs. Antivir Ther. 2006;11:S80. Rec #: 2004.
67 Tambussi G, Boeri E, Carrera P, Gianotti N, Lazzarin A. Prevalence of mutation associated to resistance with nucleoside analogues in a cohort of naive HIV-1 positive subjects during the period 1984-1997. J Biol Regul Homeost Agents. 1998;12(12 Suppl):32-4. Rec #: 1291. [pmid: 9689577].
68 Trabaud MA, Leriche-Guerin K, Regis C, Bordes I, Cotte L, Detmer J, Kolberg J, Ritter J, Trepo C. Prevalence of primary resistance to zidovudine and lamivudine in drug-naive human immunodeficiency virus type-1 infected patients: high proportion of reverse transcriptase codon 215 mutant in circulating lymphocytes and free virus. J Med Virol. Jul. 2000;61(3):352-9. Rec #: 1266. [pmid: 10861645].
69 Truong, H. M.; Klausner, J. D.; Louie, B.; McFarland, W., and Grant, R. M. Primary resistance to non-nucleoside reverse transcriptase inhibitors most common pattern detected at San Francisco Municipal STD Clinic. Antivir Ther. 2005. Rec #: 2001
70 Turner D, Brenner B, Routy JP, Moisi D, Rosberger Z, Roger M, Wainberg MA. Diminished representation of HIV-1 variants containing select drug resistance-conferring mutations in primary HIV-1 infection. J Acquir Immune Defic Syndr. Dec 15. 2004;37(5):1627-31. Rec #: 1392. [pmid: 15577421].
71 Valer, L.; Martin-Carbonero, L.; Corral, A.; de Mendoza, C., and Soriano, V. Predictors of selection of K65R: tenofovir use and lack of TAMS. 2004 Oct; 18, (15): 2094–6. Rec #: 1912
72 van de Vijver DAMC, Wensing AMJ, Asjo B, et al. Selective transmission of drug resistance mutations. Antivir Ther. 2005;10:S126. Rec #: 1979.
73 Van Vaerenbergh K, Debaisieux L, De Cabooter N, Declercq C, Desmet K, Fransen K, Maes B, Marissens D, Miller K, Muyldermans G, Sprecher S, Stuyver L, Vaira D, Verhofstede C, Zissis G, Van Ranst M, De Clercq E, Desmyter J, Vandamme AM. Prevalence of genotypic resistance among antiretroviral drug-naive HIV-1-infected patients in Belgium. Antivir Ther. Mar. 2001;6(1):63-70. Rec #: 1222. [pmid: 11417763].
74 Violin M, Cozzi-Lepri A, Velleca R, Vincenti A, D'Elia S, Chiodo F, Ghinelli F, Bertoli A, d'Arminio Monforte A, Perno CF, Moroni M, Balotta C. Risk of failure in patients with 215 HIV-1 revertants starting their first thymidine analog-containing highly active antiretroviral therapy. AIDS. Jan 23. 2004;18(2):227-35. Rec #: 2083. [pmid: 15075540].
75 Violin M, Velleca R, Cozzi-Lepri A, Riva C, Grossi PA, Carnevale G, Rizzardini G, Petrelli E, Perno CF, Monforte A, Balotta C. Prevalence of HIV-1 primary drug resistance in seroconverters of the ICoNA cohort over the period 1996-2001. J Acquir Immune Defic Syndr. Jun 1. 2004;36(2):761-4. Rec #: 1454. [pmid: 15167299].
76 Wegner SA, Brodine SK, Mascola JR, Tasker SA, Shaffer RA, Starkey MJ, Barile A, Martin GJ, Aronson N, Emmons WW, Stephan K, Bloor S, Vingerhoets J, Hertogs K, Larder B. Prevalence of genotypic and phenotypic resistance to anti-retroviral drugs in a cohort of therapy-naive HIV-1 infected US military personnel. AIDS. May 26. 2000;14(8):1009-15. Rec #: 1744. [pmid: 10853983].
77 Weinstock H, Respess R, Heneine W, Petropoulos CJ, Hellmann NS, Luo CC, Pau CP, Woods T, Gwinn M, Kaplan J. Prevalence of mutations associated with reduced antiretroviral drug susceptibility among human immunodeficiency virus type 1 seroconverters in the United States, 1993-1998. J Infect Dis. Jul. 2000;182(1):330-3. Rec #: 1264. [pmid: 10882618].
78 Wensing AM, van de Vijver DA, Angarano G, Asjo B, Balotta C, Boeri E, Camacho R, Chaix ML, Costagliola D, De Luca A, Derdelinckx I, Grossman Z, Hamouda O, Hatzakis A, Hemmer R, Hoepelman A, Horban A, Korn K, Kucherer C, Leitner T, Loveday C, MacRae E, Maljkovic I, de Mendoza C, Meyer L, Nielsen C, Op de Coul EL, Ormaasen V, Paraskevis D, Perrin L, Puchhammer-Stockl E, Ruiz L, Salminen M, Schmit JC, Schneider F, Schuurman R, Soriano V, Stanczak G, Stanojevic M, Vandamme AM, Van Laethem K, Violin M, Wilbe K, Yerly S, Zazzi M, Boucher CA. Prevalence of drug-resistant HIV-1 variants in untreated individuals in Europe: implications for clinical management. J Infect Dis. Sep 15. 2005;192(6):958-66. Rec #: 1517. [pmid: 16107947].
79 Wensing AMJ, Van de Vijver DAMC, Asjo B. Prevalence of transmitted drug resistance in Europe in largely influneced by the presence of non-B sequences: analysis of 1400 patients from 16 countries: the CATCH study. Antivir Ther. 2003;8:S131. Rec #: 2097.
80 Wood E, Hogg RS, Yip B, Dong WW, Wynhoven B, Mo T, Brumme CJ, Montaner JS, Harrigan PR. Rates of antiretroviral resistance among HIV-infected patients with and without a history of injection drug use. AIDS. Jul 22. 2005;19(11):1189-95. Rec #: 1458. [pmid: 15990572].
81 Yerly S, Vora S, Rizzardi P, Chave JP, Vernazza PL, Flepp M, Telenti A, Battegay M, Veuthey AL, Bru JP, Rickenbach M, Hirschel B, Perrin L. Acute HIV infection: impact on the spread of HIV and transmission of drug resistance. AIDS. Nov 23. 2001;15(17):2287-92. Rec #: 2095. [pmid: 11698702].

## Rejected: Second screening - Not developing region, MTCT, children

1 Patients remain resistance-free for up to two years on HIV combination. Pharmaceutical Journal. 2002 Feb 16; 268(7185): 200. Rec #: 1434
2 Ait-Khaled M, Rakik A, Griffin P, Cutrell A, Fischl MA, Clumeck N, Greenberg SB, Rubio R, Peters BS, Pulido F, Gould J, Pearce G, Spreen W, Tisdale M, Lafon S. Mutations in HIV-1 reverse transcriptase during therapy with abacavir, lamivudine and zidovudine in HIV-1-infected adults with no prior antiretroviral therapy. Antivir Ther. Mar. 2002;7(1):43-51. Rec #: 1182. [pmid: 12008787].
3 Antinori, A.; Trotta, M.; Nasta, P.; Bini, T.; Bonora, S.; Castagna, A.; Quirino, T.; Landonio, S.; Merli, S.; Tozzi, V.; Zaccarelli, M.; Di Perri, G.; Andreoni, M.; Perno, C., and Carosi, G. Type-1 Thymidine-associated Mutations but Not K65R mutation Play a Role in Determining Virologic Failure to Combined Rescue Therapy with Tenofovir and Stavudine. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1890
4 Apetrei C, Descamps D, Collin G, Robertson DL, Pandrea I, Groza P, Prisecariu L, Teodorescu I, Luca V, Brun-Vezinet F. HIV type 1 diversity in northeastern Romania in 200-2001 based on phylogenic analysis of pol sequences from patient failing antiretroviral therapy. AIDS Res Hum Retroviruses. Dec. 2003;19(12):1155-1161. Rec #: 1440. [pmid: 14714572].
5 Aquaro, S.; Svicher, V.; D'Arrigo, R.; Visco-Comandini, U.; Antinori, A.; Santoro, M.; Di Perri, G.; Lo Caputo, S.; Narciso, P., and Perno, C. F. Characterization of Gp41 Evolution in a Large Cohort of HIV-1-infected Patients Receiving Long-term T-20 Treatment as a Single Active Drug [Mechanisms of Drug Resistance: Entry Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1788
6 Bacheler L, Jeffrey S, Hanna G, D'Aquila R, Wallace L, Logue K, Cordova B, Hertogs K, Larder B, Buckery R, Baker D, Gallagher K, Scarnati H, Tritch R, Rizzo C. Genotypic correlates of phenotypic resistance to efavirenz in virus isolates from patients failing nonnucleoside reverse transcriptase inhibitor therapy. J Virol. Jun. 2001;75(11):4999-5008. Rec #: 1626. [pmid: 11333879]. [pmcid: 114903].
7 Bacheler LT, Anton ED, Kudish P, Baker D, Bunville J, Krakowski K, Bolling L, Aujay M, Wang XV, Ellis D, Becker MF, Lasut AL, George HJ, Spalding DR, Hollis G, Abremski K. Human immunodeficiency virus type 1 mutations selected in patients failing efavirenz combination therapy. Antimicrob Agents Chemother. Sep. 2000;44(9):2475-84. Rec #: 1209. [pmid: 10952598]. [pmcid: 90088].
8 Baldanti F, Paolucci S, Maga G, Labo N, Hubscher U, Skoblov AY, Victorova L, Spadari S, Minoli L, Gerna G. Nevirapine-selected mutations Y181I/C of HIV-1 reverse transcriptase confer cross-resistance to stavudine. AIDS. Jul 4. 2003;17(10):1568-70. Rec #: 1053. [pmid: 12824799].
9 Balotta C, Violin M, Monno L, Bagnarelli P, Riva C, Facchi G, Berlusconi A, Lippi M, Rusconi S, Clementi M, Galli M, Angarano G, Moroni M. Prevalence of multiple dideoxynucleoside analogue resistance (MddNR) in a multicenter cohort of HIV-1-infected Italian patients with virologic failure. J Acquir Immune Defic Syndr. Jul 1. 2000;24(3):232-40. Rec #: 1259. [pmid: 10969347].
10 Bangsberg, D.; Acosta, E.; Gupta, R.; Guzman, D.; Riley, E.; Harrigan, R.; Parkin, N., and Deeks, S. Viral Replication Capacity under Varying Adherence-adjusted Cmin Drug Levels Explains Differing NNRTI and PI Adherence/Resistance Relationships [Interplay Among HIV Resistance, Fitness and Outcome]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1769
11 Barreiro P, Camino N, de Mendoza C, Valer L, Nunez M, Martin-Carbonero L, Gonzalez-Lahoz J, Soriano V. Comparison of the efficacy, safety and predictive value of HIV genotyping using distinct ritonavir-boosted protease inhibitors. Int J Antimicrob Agents. Dec. 2002;20(6):438-43. Rec #: 1520. [pmid: 12458138].
12 Beatty, G.; Lu, J.; Hunt, P.; Huang, W.; Kuritzkes, D., and Deeks, S. Randomized Pilot Study of Immediate Enfuvirtide-based Therapy vs a Treatment Interruption followed by Enfuvirtide-based Therapy in Highly Treatment-experienced Patients. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1873
13 Bocket L, Yazdanpanah Y, Ajana F, Gerard Y, Viget N, Goffard A, Alcaraz I, Wattre P, Mouton Y. Thymidine analogue mutations in antiretroviral-naive HIV-1 patients on triple therapy including either zidovudine or stavudine. J Antimicrob Chemother. Jan. 2004;53(1):89-94. Rec #: 1130. [pmid: 14645320].
14 Bongiovanni M, Bini T, Adorni F, Meraviglia P, Capetti A, Tordato F, Cicconi P, Chiesa E, Cordier L, Cargnel A, Landonio S, Rusconi S, d'Arminio Monforte A. Virological success of lopinavir/ritonavir salvage regimen is affected by an increasing number of lopinavir/ritonavir-related mutations. Antivir Ther. Jun. 2003;8(3):209-14. Rec #: 1097. [pmid: 12924537].
15 Brenner B, Wainberg MA, Salomon H, Rouleau D, Dascal A, Spira B, Sekaly RP, Conway B, Routy JP. Resistance to antiretroviral drugs in patients with primary HIV-1 infection. Investigators of the Quebec Primary Infection Study. Int J Antimicrob Agents. Dec. 2000;16(4):429-34. Rec #: 1480. [pmid: 11118853].
16 Calza L, Borderi M, Farneti B, Tampellini L, Re MC, Monari P, Bon I, Chiodo F. Prevalence and virologic consequences of HIV-1 genotype mutations detected in a cohort of 161 Italian patients receiving a nelfinavir-based highly active antiretroviral therapy. J Chemother. Apr. 2003;15(2):165-72. Rec #: 1111. [pmid: 12797395].
17 Camacho R, Godinho AR, Gomes P, Abecasis A, Vandamme A-M, Palma C, Carvalho AP, Cabanas J, Goncalves J. Different substitutions under drug pressure at protease codon 82 in HIV-1 subtype G compared to subtype B infected individuals including a novel I82M resistance mutation. Antivir Ther. 2005;10:S151. Rec #: 1996.
18 Cane, P. A.; Osman, H., and Smit, E. Effect of HIV-1 subtype on development of NNRTI resistance mutations in patients failing first line therapy. 2004; 9, S115. Rec #: 1934
19 Carmona R, Perez-Alvarez L, Munoz M, Casado G, Delgado E, Sierra M, Thomson M, Vega Y, Vazquez de Parga E, Contreras G, Medrano L, Najera R. Natural resistance-associated mutations to Enfuvirtide (T20) and polymorphisms in the gp41 region of different HIV-1 genetic forms from T20 naive patients. J Clin Virol. Mar. 2005;32(3):248-53. Rec #: 1350. [pmid: 15722032].
20 Casado JL, Hertogs K, Ruiz L, Dronda F, Van Cauwenberge A, Arno A, Garcia-Arata I, Bloor S, Bonjoch A, Blazquez J, Clotet B, Larder B. Non-nucleoside reverse transcriptase inhibitor resistance among patients failing a nevirapine plus protease inhibitor-containing regimen. AIDS. Jan 28. 2000;14(2):F1-7. Rec #: 1105. [pmid: 10714562].
21 Casado JL, Moreno S, Hertogs K, Dronda F, Antela A, Dehertogh P, Perez-Elias MJ, Moreno A. Plasma drug levels, genotypic resistance, and virological response to a nelfinavir plus saquinavir-containing regimen. AIDS. Jan 4. 2002;16(1):47-52. Rec #: 1164. [pmid: 11741162].
22 Ceccherini-Silberstein, F.; Gori, C.; Santoro, M.; Forbici, F.; D'Arrigo, R.; Bellocchi, M.; Esposito, N.; Zaccarelli, M.; Bertoli, A.; Cenci, A.; Trotta, M.; Tozzi, V.; Antinori, A., and Perno, C. F. Dynamics of Protease Inhibitor-resistance Mutations during Treatment Interruptions. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1845
23 Chix, M.; Harzic, M.; Masquelier, B., and et al. Prevalence of genotypic drug resistance among French patients infected during the year 1999 [abstract 755]. 8th Conference on Retroviruses and Opportunistic Infections; Chicago. 2001. Rec #: 1594
24 Collier, A.; Tierney, C.; Downey, G.; Eshleman, S.; Kashuba, A.; Klingman, K.; Vergis, E.; Pakes, G.; Rooney, J.; Rinehart, A.; Mellors, J., and Adult AIDS Clinical Trials Group Protocol 5143 Team. Randomized Study of Twice-daily Lopinavir/ritonavir or Fosamprenavir + Ritonavir vs Lopinavir/ritonavir +Fosamprenavir (with Tenofovir DF and Nucleosides) as Resuce Therapy. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1870
25 Conway B, Wainberg MA, Hall D, Harris M, Reiss P, Cooper D, Vella S, Curry R, Robinson P, Lange JM, Montaner JS. Development of drug resistance in patients receiving combinations of zidovudine, didanosine and nevirapine. AIDS. Jul 6. 2001;15(10):1269-74. Rec #: 1082. [pmid: 11426071].
26 Cozzi Lepri A, Sabin CA, Staszewski S, Hertogs K, Muller A, Rabenau H, Phillips AN, Miller V. Resistance profiles in patients with viral rebound on potent antiretroviral therapy. J Infect Dis. Mar. 2000;181(3):1143-7. Rec #: 1102. [pmid: 10720543].
27 Darwich L, Martinez-Picado J, Bellido R, Blanco A, Bofill M, Clotet B, Ruiz L. Selection of drug-resistance mutations during guided treatment interruptions is associated with suboptimal antiretroviral treatments prior to HAART. Antivir Ther. 2006;11:S90. Rec #: 2011.
28 De Meyer, S.; Hill, A.; De Baere, I.; Rimsky, L.; Azijn, H.; Van Baelen, B.; De Paepe, E.; Vangeneugden, T.; Lefebvre, E., and De Bethune, M. P. Effect of Baseline Susceptibility and On-treatment Mutations on TMC114 and Control PI Efficacy: Preliminary Analysis of Data from PI-experienced Patients from POWER 1 and POWER 2 [HIV Drug Resistance: Mechanisms and Impact on Response to New Agents]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1783
29 Delaugerre C, Rohban R, Simon A, Mouroux M, Tricot C, Agher R, Huraux JM, Katlama C, Calvez V. Resistance profile and cross-resistance of HIV-1 among patients failing a non-nucleoside reverse transcriptase inhibitor-containing regimen. J Med Virol. Nov. 2001;65(3):445-8. Rec #: 1080. [pmid: 11596076].
30 Demeter LM, Ribaudo HJ, Erice A, Eshleman SH, Hammer SM, Hellmann NS, Fischl MA. HIV-1 drug resistance in subjects with advanced HIV-1 infection in whom antiretroviral combination therapy is failing: a substudy of AIDS Clinical Trials Group Protocol 388. Clin Infect Dis. Aug 15. 2004;39(4):552-8. Rec #: 1050. [pmid: 15356820].
31 Di Giambenedetto S, Colafigli M, Pinnetti C, Bacarelli A, Cingolani A, Tamburrini E, Cauda R, De Luca A. HIV drug resistance predictors of clinical disease progression in patients undergoing resistance testing in clinical practice. Antivir Ther. 2005;10:S34. Rec #: 1967.
32 Dronda F, Casado JL, Moreno S, Hertogs K, Garcia-Arata I, Antela A, Perez-Elias MJ, Ruiz L, Larder B. Phenotypic cross-resistance to nelfinavir: the role of prior antiretroviral therapy and the number of mutations in the protease gene. AIDS Res Hum Retroviruses. Feb 10. 2001;17(3):211-5. Rec #: 1195. [pmid: 11177403].
33 Dunn, D. (D. Dunn, HIV Division, Med. Res. Cncl. Clinical Trials Unit, 222 Euston Road, London NW1 2DA. United Kingdom). A randomized controlled trial of the value of phenotypic testing in addition to genotypic testing for HIV drug resistance. J Acquir Immune Defic Syndr. 2005 Apr 15; ISSN: 1525–4135. Rec #: 1492
34 Erickson-Viitanen, S.; Hou, K.; Lloyd Jr., R.; Mathis, R.; Burns, D.; Goyvaerts, R., and Levy, R. Baseline Genotype/Phenotype, Virological Response, and Lack of de novo Resistance Mutation Generation during Therapy with Dexelvucitabine (Formerly Reverset) in Study RVT-203 [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1808
35 Eshleman SH, Krogstad P, Jackson JB, Wang YG, Lee S, Wei LJ, Cunningham S, Wantman M, Wiznia A, Johnson G, Nachman S, Palumbo P. Analysis of human immunodeficiency virus type 1 drug resistance in children receiving nucleoside analogue reverse-transcriptase inhibitors plus nevirapine, nelfinavir, or ritonavir (Pediatric AIDS Clinical Trials Group 377). J Infect Dis. Jun. 2001;183(12):1732-8. Rec #: 1381. [pmid: 11372025].
36 Ferrer E, Podzamczer D, Arnedo M, Fumero E, McKenna P, Rinehart A, Perez JL, Barbera MJ, Pumarola T, Gatell JM, Gudiol F. Genotype and phenotype at baseline and at failure in human immunodeficiency virus-infected antiretroviral-naive patients in a randomized trial comparing zidovudine and lamivudine plus nelfinavir or nevirapine. J Infect Dis. Feb 15. 2003;187(4):687-90. Rec #: 1119. [pmid: 12599088].
37 Foli A, Maserati R, Barasolo G, Castelli F, Tomasoni L, Migliorino M, Maggiolo F, Pan A, Paolucci S, Scudeller L, Tinelli C, D'Aquila R, Lisziewicz J, Lori F. Strategies to decrease viral load rebound, and prevent loss of CD4 and onset of resistance during structured treatment interruptions. Antivir Ther. Feb. 2004;9(1):123-32. Rec #: 1077. [pmid: 15040544].
38 Gallego O, Corral A, de Mendoza C, Rodes B, Soriano V. Prevalence of G333D/E in naive and pretreated HIV-infected patients. AIDS Res Hum Retroviruses. Aug 10. 2002;18(12):857-60. Rec #: 1176. [pmid: 12201908].
39 Gallego O, de Mendoza C, Perez-Elias MJ, Guardiola JM, Pedreira J, Dalmau D, Gonzalez J, Moreno A, Arribas JR, Rubio A, Garcia-Arata I, Leal M, Domingo P, Soriano V. Drug resistance in patients experiencing early virological failure under a triple combination including indinavir. AIDS. Sep 7. 2001;15(13):1701-6. Rec #: 1168. [pmid: 11546946].
40 Gianotti, N.; Tambussi, G.; Boeri, E., and Lazzarin, A. Comparison of protease genotype and phenotype in HIV-1 infected patients exposed to more than one protease inhibitor. J Biol Regul Homeost Agents. 2001 Apr–2001 Jun 30; 15(2):166–9. Rec #: 1169
41 Gifford R, Pillay D. Utilisation of HIV-1 subtype specific consensus sequences to explore treatment related mutational patterns within and between subtypes. Antivir Ther. 2005;10:S153. Rec #: 1998.
42 Gil, P.; Barrios, A.; Garcia-Benayas, T.; Valer, L.; Martin-Carbonero, L.; Maida, I., and Soriano, V. Rate of virological failure and resistance profiles in patients treated with triple nucleoside regimens. 2004; 9, S182. Rec #: 1952
43 Greaves, W.; Landovits, R.; Fatkenheuer, G.; Hoffman, C.; Antunes, F.; Angel, J.; Boparai, N.; Knepp, D.; Keung, A., and Dunkle, L. Late Virologic Breakthrough in Treatment-naive Patients on a Regimen of Combivir + Vicriviroc [HIV Drug Resistance: Mechanisms and Impact on Response to New Agents]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1785
44 Grebely, J.; Raffa, J., and Conway, B. Development of resistance mutations in patients receiving salvage therapy with tenofovir. 2004; 9, S170. Rec #: 1946
45 Grossman Z, Istomin V, Averbuch D, Lorber M, Risenberg K, Levi I, Chowers M, Burke M, Bar Yaacov N, Schapiro JM. Genetic variation at NNRTI resistance-associated positions in patients infected with HIV-1 subtype C. AIDS. Apr 9. 2004;18(6):909-15. Rec #: 1041. [pmid: 15060438].
46 Grossman, Z.; Lorber, M.; Thibaut, L; Shahar, E.; Torten, D.; Levy, I.; Riesenberg, K.; Chowers, M.; Istomin, V.; Averbuch, D.; Kra-Oz, Z.; Pollack, S.; Maayan, S.; Faudon, J.; Schapiro, J., and The Israeli Multi Center AIDS Study Group. Virological Response and Resistance to Lopinavir/Ritonavir in Subtype-C Patients. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1854
47 Gulick RM, Mellors JW, Havlir D, Eron JJ, Gonzalez C, McMahon D, Jonas L, Meibohm A, Holder D, Schleif WA, Condra JH, Emini EA, Isaacs R, Chodakewitz JA, Richman DD. (Department of Medicine, New York University School of Medicine, New York, USA. rgulick@mail.med.cornell.edu). Simultaneous vs sequential initiation of therapy with indinavir, zidovudine, and lamivudine for HIV-1 infection: 100-week follow-up. JAMA. Jul. 1998;280(1):35-41. Rec #: 1386. [pmid: 9660361].
48 Gupta RK, Chrystie IL, O'Shea S, Mullen JE, Kulasegaram R, Tong CY. K65R and Y181C are less prevalent in HAART-experienced HIV-1 subtype A patients. AIDS. Nov 4. 2005;19(16):1916-9. Rec #: 1445. [pmid: 16227803].
49 Hackett JR Jr, Holzmayer V, Marlowe N, DeHaan MP, Robinson KY, Wikstrom KJ, Niemi KR, King MS, da Silva BA, Hanna GJ. Selection of protease inhibitor (PI) resistance mutations during virological failure of lopinavir/ritonavir (LPV/r) monotherapy in an induction-maintenance study. Antivir Ther. 2006;11:S85. Rec #: 2007.
50 Hall, D. B.; van Leth, F.; Robinson, P.; McKenna, P.; Wit, FWMN, and Lange, JMA. The V106M mutation in treatment failures from a randomized controlled trial of lamivudine and stavudine, with nevirapine and/or efavirenz. 2004; 9, S177. Rec #: 1951
51 Hanna GJ, Johnson VA, Kuritzkes DR, Richman DD, Brown AJ, Savara AV, Hazelwood JD, D'Aquila RT. Patterns of resistance mutations selected by treatment of human immunodeficiency virus type 1 infection with zidovudine, didanosine, and nevirapine. J Infect Dis. Mar. 2000;181(3):904-11. Rec #: 1103. [pmid: 10720511].
52 Harrigan PR, Brumme C, Sattha B, Bangsberg D, Montaner J, Hogg RS. The relationship between resistance and adherence and the accumulation of mutations in drug naive individuals starting HAART is specific to individual drug classes. Antivir Ther. 2005;10:S139. Rec #: 1985.
53 Harrigan PR, Larder BA. Extent of cross-resistance between agents used to treat human immunodeficiency virus type 1 infection in clinically derived isolates. Antimicrob Agents Chemother. Mar. 2002;46(3):909-12. Rec #: 2066. [pmid: 11850286]. [pmcid: 127474].
54 Hatano, H.; Hunt, P.; Weidler, J.; Coakely, E.; Hoh, R.; Liegler, T.; Martin, J., and Deeks, S. Rate of Viral Evolution and Risk of Losing Future Drug Options in Heavily Pretreated Patients Remaining on a Stable Partially Suppressive Regimen [Selection, Evolution and Persistence of Drug Resistance]. 13th Conference on Retroviruses and Opprotunisitic Infections; 2006. Rec #: 1755
55 Havlir DV, Marschner IC, Hirsch MS, Collier AC, Tebas P, Bassett RL, Ioannidis JP, Holohan MK, Leavitt R, Boone G, Richman DD. (University of California, San Diego, and the San Diego Veterans Affairs Medical Center, 92103, USA.). Maintenance antiretroviral therapies in HIV infected patients with undetectable plasma HIV RNA after triple-drug therapy. AIDS Clinical Trials Group Study 343 Team. N Eng J Med. Oct. 1998;339(18):1261-8. Rec #: 1385.
56 Hogg, R.; Bangsberg, D.; Alexander, C.; Bonner, S.; Yip, B.; Wood, E.; Dong, W.; Wynhoven, B.; Montaner, J., and Harrigan, P. Drug Resistance is Associated with an Increased Risk of Death in Patients First Starting HAART. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1852
57 Isaacson, J.; Kempf, D.; Calvez, V., and et al. Quantitiative estimate of the effect of the individual baseline mutations in HIV protease on the virologic response to lopinavir/ritonavir therapy in heavily experienced patients [abstract 559-T]. 9th Conference on Retroviruses and Opportunistic Infections; Seattle. Alexandria, VA: Foundation for Retrovirology and Human Health; 2002: 260. Rec #: 1583
58 Joly V, Flandre P, Meiffredy V, Brun-Vezinet F, Gastaut JA, Goujard C, Remy G, Descamps D, Ruffault A, Certain A, Aboulker JP, Yeni P. Novavir Study Group. (Agence Francaise de Recherche sur le SIDA, Paris, France. veronique.joly@bch.ap-hop-paris.fr). Efficacy of zidovudine compared to stavudine, both in combination with lamivudine and indinavir, in human immunodeficiency virus-infected nucleoside-experienced patients with no prior exposure to lamivudine, stavudine, or protease inhibitors (novavir trial). Antimicrob Agents Chemother. Jun. 2002;46(6):1906-13. Rec #: 1371. [pmid: 12019107]. [pmcid: 127263].
59 Kantor R, Shafer RW, Follansbee S, Taylor J, Shilane D, Hurley L, Nguyen DP, Katzenstein D, Fessel WJ. Evolution of resistance to drugs in HIV-1-infected patients failing antiretroviral therapy. AIDS. Jul 23. 2004;18(11):1503-11. Rec #: 1610. [pmid: 15238768]. [pmcid: 2547474].
60 Katzenstein, D.; Winters, M.; Fiscus, S.; Bettendorf, D.; Kantor, R.; Wantman, M.; Cu-Uvin, S.; D'aquila, R.; Frenkel, L.; Coombs, R., and AIDS Clin Trials Group 5077. Drug Resistance in Plasma and Genital Compartments among Viremic, Multidrug-experienced Men and Women [Selection, Evolution, and Persistance of Drug Resistance]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1758
61 Katzenstein, D.; Winters, M.; Fiscus, S.; Petch, L.; Bettendorf, D.; Bosch, R.; Cooper, M.; Cu-Uvin, S.; D'Aquila, R.; Mowry, E.; Luque, A.; Frenkel, L.; Ellis, N.; Cavert, W.; Coombs, R., and ACTG A5077 Study Team. NIH, NIAID DAIDS Bethesda MD. Setting the Stage for Transmission of Drug Resistance: Genital HIV Shedding and Drug Resistance in Men and Women. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1878
62 Kemper CA, Witt MD, Keiser PH, Dube MP, Forthal DN, Leibowitz M, Smith DS, Rigby A, Hellmann NS, Lie YS, Leedom J, Richman D, McCutchan JA, Haubrich R. Sequencing of protease inhibitor therapy: insights from an analysis of HIV phenotypic resistance in patients failing protease inhibitors. AIDS. Mar 30. 2001;15(5):609-15. Rec #: 1193. [pmid: 11316998].
63 Kempf, D.; Bernstein, B.; King, M., and et al. Comparison of the emergence of genotypic resistance over 60 weeks of therapy with lopinavir/ritonavir (Kaletra (TM)) or nelfinavir plus d4R/3TC. Program and abstracts of the First IAS Conference on HIV Pathogenesis and Treatment; Buenos Aires, Argentina. Abstract 129. Rec #: 1907
64 Kempf DJ, King MS, Bernstein B, Cernohous P, Bauer E, Moseley J, Gu K, Hsu A, Brun S, Sun E. Incidence of resistance in a double-blind study comparing lopinavir/ritonavir plus stavudine and lamivudine to nelfinavir plus stavudine and lamivudine. J Infect Dis. Jan 1. 2004;189(1):51-60. Rec #: 1084. [pmid: 14702153].
65 Kempf DJ, King MS, Bernstein B, Cernohous P, Bauer E, Moseley J, Gu K, Hsu A, Brun S, Sun E. (Global Pharmaceutical Research and Development, Abbott Laboratories, Abbott Park, Illinois, USA. dale. kempf@abbott.com). Incidence of resistance in a double-blind study comparing lopinavir/ritonavir plus stavudine and lamivudine to nelfinavir plus stavudine and lamivudine. J Infect Dis. Jan. 2004;189(1):51-60. Rec #: 1365. [pmid: 14702153].
66 King M, Palmer S, Wiegand A, Maldarelli F, Brun S, Kempf D, Hanna G, Coffin J, Mellors J. The level of persistant viraemia below 50 copies/mL is associated with subsequent rebound to above 50 HIV RNA copies/mL for nelfinavir-treated subjects but not lopinavir/ritonavir-treated subjects. Antivir Ther. 2005;10:S36. Rec #: 1969.
67 King MS, Brun SC, Kempf DJ. Relationship between adherence and the development of resistance in antiretroviral-naive, HIV-1-infected patients receiving lopinavir/ritonavir or nelfinavir. J Infect Dis. Jun 15. 2005;191(12):2046-52. Rec #: 1019. [pmid: 15897990].
68 Kojima E, Shirasaka T, Anderson BD, Chokekijchai S, Steinberg SM, Broder S, Yarchoan R, Mitsuya H. Human immunodeficiency virus type 1 (HIV-1) viremia changes and development of drug-related mutations in patients with symptomatic HIV-1 infection receiving alternating or simultaneous zidovudine and didanosine therapy. J Infect Dis. May. 1995;171(5):1152-8. Rec #: 1318. [pmid: 7751690].
69 Kozal M, Amico R, Chiarella J, Cornman D, Fisher W, Fisher J, Friedland G. HIV sexual transmissio risk behaviour and multidrug resistant (MDR) HIV. Antivir Ther. 2005;10:S140. Rec #: 1986.
70 Kozal MJ, Huppler Jullsick K, MacArthur RD, Peng G, Xiang Y, Baxter JD, Van den Berg-Wolf M, Uy J, Telzak EE, Novak RM. Initial virological failure with HIV drug resistance and impact of resistance on disease progression and death for patients beginning PI, NNRTI or PI+NNRTI based strategies: the FIRST Study. Antivir Ther. 2006;11:S89. Rec #: 2010.
71 Launay O, Gerard L, Morand-Joubert L, Flandre P, Guiramand-Hugon S, Joly V, Peytavin G, Certain A, Levy C, Rivet S, Jacomet C, Aboulker JP, Yeni P. Agence Nationale de Recherches sur le SIDA (ANRS) 081 Study Group. (Service de Maladies Infectieuses et Tropicales, Hopital Bichat-Claude Bernard). Nevirapine or lamivudine plus stavudine and indinavir: examples of 2-class versus 3-class regimens for the treatment of human immunodeficiency virus type 1. Clin Infect Dis. Nov. 2002;35(9):1096-105. Rec #: 1377. [pmid: 12384844].
72 Lawrence, J.; Huppler Hullsiek, K.; Thackeray, L.; Abrams, D.; Mayers, D.; Crane, L.; Jones, M.; Saldanha, J.; Schmetter, B.; Dionne, T.; Pettinelli, C.; Baxter, J., and 064 Study Team of the Terry Beirn Communicty Programs for Clinical Research on AIDS. Final Results of CPCRA 064: A Randomized Trial Examining Structured Treatment Interruption for Patients Failing Therapy with Multi-drug Resistant HIV. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1872
73 Loveday, C.; Grant, P.; Goodall, R.; Pillay, D.; Macrae, E.; Asboe, D.; Williams, I.; Stoehr, W.; Babiker, A., and Forte Virology Group and Trial Steering Comm. Adding a PI for 6 Months to a Standard NNRTI-based Regimen Reduces the Risk of Virological Failure without Inducing Resistance to the PI: A FORTE Virology Analysis. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1869
74 Machouf, N.; Trottier, B.; Thomas, R.; Routy, J. P., and Wainberg, M. A. Viral load in patients failing therapy: is it the type of mutation or the total number of mutations that matter? 2004; 9, S157. Rec #: 1939
75 MacManus S, Yates PJ, Elston RC, White S, Richards N, Snowden W. GW433908/ritonavir once daily in antiretroviral therapy-naive HIV-infected patients: absence of protease resistance at 48 weeks. AIDS. Mar 5. 2004;18(4):651-5. Rec #: 1073. [pmid: 15090770].
76 Maguire M, Gartland M, Moore S, Hill A, Tisdale M, Harrigan R, Kleim JP. Absence of zidovudine resistance in antiretroviral-naive patients following zidovudine/lamivudine/protease inhibitor combination therapy: virological evaluation of the AVANTI 2 and AVANTI 3 studies. AIDS. Jun 16. 2000;14(9):1195-201. Rec #: 1216. [pmid: 10894284].
77 Maguire M, Shortino D, Klein A, Harris W, Manohitharajah V, Tisdale M, Elston R, Yeo J, Randall S, Xu F, Parker H, May J, Snowden W. (GlaxoSmithKline Research and Development, International Clinical Virology). Emergence of resistance to protease inhibitor amprenavir in human immunodeficiency virus type 1-infected patients: selection of four alternative viral protease genotypes and influence of viral susceptibility to coadministered reverse transcriptase nucleoside inhibitors. Antimicrob Agents Chemother. Mar. 2002;46(3):731-8. Rec #: 1372. [pmid: 11850255]. [pmcid: 127503].
78 Manfredi R. A cross-sectional survey of HIV genotype mutations conferring resistance to all nonnucleoside reverse transcriptase inhibitors and related features, at the time of failure of antiretroviral therapy in the real world. J Acquir Immune Defic Syndr. Sep 1. 2001;28(1):97-9. Rec #: 1390. [pmid: 11579284].
79 Manfredi R, Calza L. HIV genotype mutations evoked by nelfinavir-based regimens: frequency, background, and consequences on subsequent treatment options. J Acquir Immune Defic Syndr. Jun 1. 2002;30(2):258-60. Rec #: 1155. [pmid: 12045690].
80 Marcelin AG, Flandre P, Pavie J, Schmidely N, Wirden M, Bernard MC, Molina JM, Calvez V. Influence of new reverse transcriptase mutations on virological response to didanosine in the didanosine add on Jaguar study. Antivir Ther. 2005;10:S25. Rec #: 1964.
81 Margot NA, Isaacson E, McGowan I, Cheng A, Miller MD. Extended treatment with tenofovir disoproxil fumarate in treatment-experienced HIV-1-infected patients: genotypic, phenotypic, and rebound analyses. J Acquir Immune Defic Syndr. May 1. 2003;33(1):15-21. Rec #: 1160. [pmid: 12792350].
82 Margot NA, Isaacson E, McGowan I, Cheng AK, Schooley RT, Miller MD. Genotypic and phenotypic analyses of HIV-1 in antiretroviral-experienced patients treated with tenofovir DF. AIDS. Jun 14. 2002;16(9):1227-35. Rec #: 1519. [pmid: 12045487].
83 Masquelier B, Costagliola D, Schmuck A, Cottalorda J, Schneider V, Izopet J, Calvez V, Descamps D, Poggi C, Brun-Vezinet F. Prevalence of complete resistance to at least two classes of antiretroviral drugs in treated HIV-1-infected patients: a French nationwide study. J Med Virol. Aug. 2005;76(4):441-6. Rec #: 1013. [pmid: 15977249].
84 Masquelier, B.; Costagliola, D.; Schmuck, A.; Cottalorda, J.; Schneider, V.; Izopet, J.; Descamps, D.; Poggi, C.; Brun-Vezinet, F., and ANRS Resistance Study Group. Prevalence of multiple-class antiretroviral drug resistance in HIV-1 -treated patients. 2004; 9, S89. Rec #: 1921
85 Mayers, D. L.; Leith, J.; Valdez, H., and et al. Impact of three or four protease mutations at codons 33, 82, 84 and 90 on 2 week virological responses to tipranavir, lopinavir, amprenavir and saquinavir all boosted by ritonavir in Phase 2B trial BI 1182.51. 2004; 9, S163. Rec #: 1942
86 McGrath D, Hammond J, Frederick D, Mathew M, Kastango K, McLaren C. Evaluation of resistance patterns in treatment-naive subjects with virological failure on atazanavir- or antazanavir/ritonavir-containing regimens. Antivir Ther. 2006;11:S97. Rec #: 2013.
87 Meynard J-L, Vray M, Morand-Joubert L, Race E, Descamps D, Peytavin G, Matheron S, Lamotte C, Guiramand S, Costagliola D, Brun-Vezinet F, Clavel F, Girard P-M. Phenotypic or genotypic resistance testing for choosing antiretroviral therapy after treatment failure: A randomized trial. AIDS. 2002;16(5):727-736. Rec #: 1378. [pmid: 11964529].
88 Milazzo L, Rusconi S, Testa L, La Seta-Catamancio S, Galazzi M, Kurtagic S, Citterio P, Gianotto M, Grassini A, Adorni F, d'Arminio-Monforte A, Galli M, Moroni M. Evidence of stavudine-related phenotypic resistance among zidovudine-pretreated HIV-1-infected subjects receiving a therapeutic regimen of stavudine plus lamivudine. J Acquir Immune Defic Syndr. Sep 1. 1999;22(1):101-3. Rec #: 1285. [pmid: 10534153].
89 Miller MD, Margot NA, Lamy PD, Fuller MD, Anton KE, Mulato AS, Cherrington JM. Adefovir and tenofovir susceptibilities of HIV-1 after 24 to 48 weeks of adefovir dipivoxil therapy: genotypic and phenotypic analyses of study GS-96-408. J Acquir Immune Defic Syndr. Aug 15. 2001;27(5):450-8. Rec #: 1212. [pmid: 11511821].
90 Miller V, Ait-Khaled M, Stone C, Griffin P, Mesogiti D, Cutrell A, Harrigan R, Staszewski S, Katlama C, Pearce G, Tisdale M. HIV-1 reverse transcriptase (RT) genotype and susceptibility to RT inhibitors during abacavir monotherapy and combination therapy. AIDS. Jan 28. 2000;14(2):163-71. Rec #: 1276. [pmid: 10708287].
91 Mo H, King MS, King K, Molla A, Brun S, Kempf DJ. Selection of resistance in protease inhibitor-experienced, human immunodeficiency virus type 1-infected subjects failing lopinavir- and ritonavir-based therapy: mutation patterns and baseline correlates. J Virol. Mar. 2005;79(6):3329-38. Rec #: 1031. [pmid: 15731227]. [pmcid: 1075714].
92 Molina JM, Marcelin AG, Pavie J, Heripret L, De Boever CM, Troccaz M, Leleu G, Calvez V. Didanosine in HIV-1-infected patients experiencing failure of antiretroviral therapy: a randomized placebo-controlled trial. J Infect Dis. Mar 15. 2005;191(6):840-7. Rec #: 1351. [pmid: 15717257].
93 Montes B, Vergne L, Peeters M, Reynes J, Delaporte E, Segondy M. Comparison of drug resistance mutations and their interpretation in patients infected with non-B HIV-1 variants and matched patients infected with HIV-1 subtype B. J Acquir Immune Defic Syndr. Apr 1. 2004;35(4):329-36. Rec #: 1071. [pmid: 15097148].
94 Naeger, L.; Zheng, J., and Struble, K. Virologic Response to Tepranavir Based on Plasma Concentration and Baseline Resistance Parameters [Impact of Resistance on Treatment Response ]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1815
95 Napravnik S, Keys J, Quinlivan EB, Wohl DA, Myers AM, Eron JJ Jr. Prevalence and predictors of triple-class antiretroviral drug resistance in routine HIV primary care. Antivir Ther. 2006;11:S88. Rec #: 2009.
96 Nasta, P.; Castelnuovo, F.; Paraninfo, G.; Bella, D.; Matti, A.; Cocca, G.; Rizzardini, G.; Zoboli, G.; Magnani, G.; Nigo, M.; Colombo, M.; Calzetti, C.; Barchiesi, G.; Celesia, M.; Carosi, G., and Master-IM.P.R.O.V.E. study group. To Maintain or to Switch HAART in Heavily Pre-treated Patients with Low-level Viremia. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1876
97 Norton M, Delaugere C, Batot G, Delfraissy JF, Rouzioux C. Drug resistance outcomes in a trial comparing lopinavir/ritonavir (LPV/r) monotherapy to LPV/r + zidovudine/lamivudine (MONARK Trial). Antivir Ther. 2006;11:S84. Rec #: 2006.
98 Palacios R, Viciana I, Lopez-Ruz MA, Rivero A, Rios MJ, Garcia F, Lozano AB, Nogales MC, Lozano F, Santos J. A case-control study of HIV patients with the K65R mutation in the reverse transcriptase gene with virological failure. AIDS. Nov 4. 2005;19(16):1928-30. Rec #: 1388. [pmid: 16227808].
99 Parienti JJ, Massari V, Descamps D, Vabret A, Bouvet E, Larouze B, Verdon R. Predictors of virologic failure and resistance in HIV-infected patients treated with nevirapine- or efavirenz-based antiretroviral therapy. Clin Infect Dis. May 1. 2004;38(9):1311-6. Rec #: 1039. [pmid: 15127346].
100 Patick AK, Duran M, Cao Y, Shugarts D, Keller MR, Mazabel E, Knowles M, Chapman S, Kuritzkes DR, Markowitz M. Genotypic and phenotypic characterization of human immunodeficiency virus type 1 variants isolated from patients treated with the protease inhibitor nelfinavir. Antimicrob Agents Chemother. Oct. 1998;42(10):2637-44. Rec #: 1239. [pmid: 9756769]. [pmcid: 105911].
101 Paulsen D, Liao Q, Fusco G, St Clai M, Shaefer M, Ross L. Genotypic and phenotypic cross-resistance patterns to lopinavir and amprenavir in protease inhibitor-experienced patients with HIV viremia. AIDS Res Hum Retroviruses. Sep 20. 2002;18(14):1011-9. Rec #: 1132. [pmid: 12396453].
102 Pellegrin I, Breilh D, Montestruc F, Caumont A, Garrigue I, Morlat P, Le Camus C, Saux MC, Fleury HJ, Pellegrin JL. Virologic response to nelfinavir-based regimens: pharmacokinetics and drug resistance mutations (VIRAPHAR study). AIDS. Jul 5. 2002;16(10):1331-40. Rec #: 1151. [pmid: 12131209].
103 Pellegrin, I.; Coureau, G.; Dupon, M.; Morlat, P.; Lazaro, E.; Fleury, H.; Boucher, S.; Thiebaut, R.; Pellegrin, J. L; Breilh, D., and ANRS CO3 Aquitaine Cohort. Clinically Relevant Interpretation of Genotype and Pharmacokinectics Parameters for Resistance to Fosamprenavir/ritonavir-based Regimens in ART-experienced Patients: Zephir Study [Impact of Resistant on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1814
104 Perez-Alvarez L, Thomson MM, Villahermosa ML, de Parga EV, Rodriguez A, Cuevas MT, Delgado E, Manjon N, Miralles C, Medrano L, Taboada JA, Najera R. HIV-1 subtype G and BG recombinant viruses in Spanish natives: evidence of characteristic mutations in reverse transcriptase and protease. AIDS. Sep 28. 2001;15(14):1907-10. Rec #: 1701. [pmid: 11579264].
105 Phillips AN, Dunn D, Sabin C, Pozniak A, Matthias R, Geretti AM, Clarke J, Churchill D, Williams I, Hill T, Green H, Porter K, Scullard G, Johnson M, Easterbrook P, Gilson R, Fisher M, Loveday C, Gazzard B, Pillay D. Long term probability of detection of HIV-1 drug resistance after starting antiretroviral therapy in routine clinical practice. AIDS. Mar 25. 2005;19(5):487-94. Rec #: 1027. [pmid: 15764854].
106 PIllay, D.; Green, H.; Gazzard, B.; Pozniak, A.; Matthias, R.; Johnson, M.; Churchill, D.; Fisher, M.; Hill, T.; Geretti, A. M.; Clarke, J.; Cane, P.; Loveday, C.; Scullard, G.; Easterbrook, P.; Porter, K.; Williams, I.; Gilson, R.; Sabin, C.; Phillips, A., and Dunn, D. Estimating resistance in drug experienced patients in the UK. 2004; 9, S88. Rec #: 1920
107 Pozniak AL, Gilleece Y, Nelson M, et al. Zidovudine genotypic and phenotypic resistance arising in patients never exposed to zidovudine. Antivir Ther. 2000;5:42. Rec #: 1577.
108 Quiros-Roldan E, Bertelli D, Signorini S, Airoldi M, Torti C, Moretti F, Carosi G. HIV-1 multi-dideoxynucleoside resistance mutation (Q151M): prevalence, associated resistance mutations and response to antiretroviral salvage treatment. Microbios. 2001;106(414):137-45. Rec #: 1213. [pmid: 11506064].
109 Race E, Gilbert SM, Sheldon JG, Rose JS, Moffatt AR, Sitbon G, Dissanayeke SR, Cammack N, Duncan IB. Correlation of response to treatment and HIV genotypic changes during phase III trials with saquinavir and reverse transcriptase inhibitor combination therapy. AIDS. Aug 20. 1998;12(12):1465-74. Rec #: 1240. [pmid: 9727567].
110 Re MC, Bon I, Monari P, Borderi M, Gibellini D, Schiavone P, Vitone F, Chiodo F, La Placa M. Mutation patterns of the reverse transcriptase genes in HIV-1 infected patients receiving combinations of nucleoside and non nucleoside inhibitors. Int J Antimicrob Agents. Oct. 2003;22(4):388-94. Rec #: 1048. [pmid: 14522102].
111 Re MC, Monari P, Bon I, Borderi M, Gibellini D, Schiavone P, Vitone F, Furlini G, La Placa M. Development of drug resistance in HIV-1 patients receiving a combination of stavudine, lamivudine and efavirenz. Int J Antimicrob Agents. Sep. 2002;20(3):223-6. Rec #: 1061. [pmid: 12385703].
112 Richman DD, Morton SC, Wrin T, Hellman N, Berry S, Shapiro MF, Bozzette SA. The prevalence of antiretroviral drug resistance in the United States. AIDS. 2004;18:1393-401. Rec #: 2093. [pmid: 15199315].
113 Rinehart, A.; Lecocq, P.; Pattery, T.; Wasikowsi, B., and Bacheler, L. Evolution in the Diversity of HIV-1-resistance Mutation Patterns in >128,000 Clinical Samples Received for Resistance Analysis form 1998 to 2004. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1884
114 Rodriguez, Martinez J. M. Palomares Folia J. C. (Dr. J.M. Rodriguez Martinez, Departamento de Microbiologia, Facultad de Medicina, Universidad de Sevilla). Genotypic resistance of human immunodeficiency virus type 1 in patients with therapeutic failure: <ORIGINAL> Resistencia genotipica del virus de la inmunodeficiencia humana tipo 1 en pacientes con fracaso terapeutico. Med Clin (Barc). 2004 Feb 14; 122(5):161–4; ISSN: 0025-7753. Rec #: 1494
115 Roge BT, Barfod TS, Kirk O, Katzenstein TL, Obel N, Nielsen H, Pedersen C, Mathiesen LR, Lundgren JD, Gerstoft J. Resistance profiles and adherence at primary virological failure in three different highly active antiretroviral therapy regimens: analysis of failure rates in a randomized study. HIV Med. Sep. 2004;5(5):344-51. Rec #: 1049. [pmid: 15369509].
116 Roge BT, Katzenstein TL, Obel N, Nielsen H, Kirk O, Pedersen C, Mathiesen L, Lundgren J, Gerstoft J. K65R with and without S68: a new resistance profile in vivo detected in most patients failing abacavir, didanosine and stavudine. Antivir Ther. Apr. 2003;8(2):173-82. Rec #: 1712. [pmid: 12741630].
117 Romano L, Venturi G, Giomi S, Pippi L, Valensin PE, Zazzi M. Development and significance of resistance to protease inhibitors in HIV-1-infected adults under triple-drug therapy in clinical practice. J Med Virol. Feb. 2002;66(2):143-50. Rec #: 1162. [pmid: 11782921].
118 Roquebert B, Dalban C, Wirden M, et al. Association between nucleoside reverse transcriptase inhibitors resistance mutations and elvel of residual HIV-1 viraemia under antiretroviral treatment in patients experiencing virological failure. Antivir Ther. 2005;10:S24. Rec #: 1963.
119 Ross L, Boulme R, Fusco G, Scarsella A, Florance A. Comparison of HIV type 1 protease inhibitor susceptibility results in viral samples analyzed by phenotypic drug resistance assays and by six resistance algorithms: an analysis of a subpopulation of the CHORUS cohort. AIDS Res Hum Retroviruses. Aug. 2005;21(8):696-701. Rec #: 1002. [pmid: 16131308].
120 Ross L, Gerondelis P, Liao Q, Wine B, Lim M, Shaefer M, Rodriguez A, Limoli K, Huang W, Parkin NT, Gallant J, Lanier R. Selection of the HIV-1 reverse transcriptase mutation K70E in antiretroviral -naive subjects treated with tenfovir/abacavir/lamivudine therapy. Antivir Ther. 2005;10:S102. Rec #: 1972.
121 Ross L, Scarsella A, Raffanti S, Henry K, Becker S, Fisher R, Liao Q, Hirani A, Graham N, St Clai M, Hernandez J. Thymidine analog and multinucleoside resistance mutations are associated with decreased phenotypic susceptibility to stavudine in HIV type 1 isolated from zidovudine-naive patients experiencing viremia on stavudine-containing regimens. AIDS Res Hum Retroviruses. Aug 10. 2001;17(12):1107-15. Rec #: 1210. [pmid: 11522180].
122 Ross, L. L.; Gerondelis, P.; Rouse, E. G., and et al. Impact of HIV resistance mutations, drug resistance and viral fitness on antiviral activity of tenofovir/abacavir/lamivudine in the ESS30009 study. 2004; 9, S175. Rec #: 1949
123 Ruiz, L.; Romeu, J.; Martinez-Picado, J.; Bellido, R.; Llibre, J.; Domingo, P.; Tambussi, G.; Clotet, B., and On Behalf of the Tibet Study Group. Selection of Drug-resistance Mutations in Chronic HIV-infected Patients during Therapy Interruptions Guided by CD4+ T-cell Counts and Viral Load Levels: The Tibet Study. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1843
124 Salebongo P, Levan Thoi J, Bantsimba J, Chater A, Dublanchet A, Patey O. Genotypic antiretroviral resistance testing in multi-treated HIV-1 adult patients Original>Les Tests De Resistance Genotypiques Aux Antire Troviraux Chez Les Patients Adultes Vih-1 Multitraites. Louvain Medical. 2002;121(7):265-274. Rec #: 1422.
125 Saracino A, Monno L, Locaputo S, Torti C, Scudeller L, Ladisa N, Antinori A, Sighinolfi L, Chirianni A, Mazzotta F, Carosi G, Angarano G. Selection of antiretroviral therapy guided by genotypic or phenotypic resistance testing: an open-label, randomized, multicenter study (PhenGen). J Acquir Immune Defic Syndr. 2004;37(5):1587-98. Rec #: 1367. [pmid: 15577415].
126 Schapiro JM, Lawrence J, Speck R, Winters MA, Efron B, Coombs RW, Collier AC, Merigan TC. Resistance mutations to zidovudine and saquinavir in patients receiving zidovudine plus saquinavir or zidovudine and zalcitabine plus saquinavir in AIDS clinical trials group 229. J Infect Dis. Jan. 1999;179(1):249-53. Rec #: 1235. [pmid: 9841849].
127 Schmit JC, Van Laethem K, Ruiz L, Hermans P, Sprecher S, Sonnerborg A, Leal M, Harrer T, Clotet B, Arendt V, Lissen E, Witvrouw M, Desmyter J, De Clercq E, Vandamme AM. Multiple dideoxynucleoside analogue-resistant (MddNR) HIV-1 strains isolated from patients from different European countries. AIDS. Oct 22. 1998;12(15):2007-15. Rec #: 1721. [pmid: 9814869].
128 Schooley RT, Ruane P, Myers RA, Beall G, Lampiris H, Berger D, Chen SS, Miller MD, Isaacson E, Cheng AK. Tenofovir DF in antiretroviral-experienced patients: results from a 48-week, randomized, double-blind study. AIDS. Jun 14. 2002;16(9):1257-63. Rec #: 2024. [pmid: 12045491].
129 Segondy M, Montes B. Prevalence and conditions of selection of the K65R mutation in the reverse transcriptase gene of HIV-1. J Acquir Immune Defic Syndr. Jan 1. 2005;38(1):110-1. Rec #: 1450. [pmid: 15608534].
130 Sethi AK, Celentano DD, Gange SJ, Moore RD, Gallant JE. Association between adherence to antiretroviral therapy and human immunodeficiency virus drug resistance. Clin Infect Dis. Oct 15. 2003;37(8):1112-8. Rec #: 1543. [pmid: 14523777].
131 Shafer RW, Smeaton LM, Robbins GK, De Gruttola V, Snyder SW, D'Aquila RT, Johnson VA, Morse GD, Nokta MA, Martinez AI, Gripshover BM, Kaul P, Haubrich R, Swingle M, McCarty SD, Vella S, Hirsch MS, Merigan TC. AIDS Clinical Trials Group 384 Team. (Stanford University Medical Center). Comparison of four-drug regimens and pairs of sequential three-drug regimens as initial therapy for HIV-1 infection. N Eng J Med. Dec. 2003;349(24):2304-15. Rec #: 1368.
132 Squires, K.; Mccallister, S.; Lazzarin, A.; Kumar, P.; De Jesus, E.; Nadler, J., and et al. Tipranavir /ritonavir (TPV/r) demonstrates a robust resistance profile in multiple protease inhibitor-experienced patients: correlation of baseline genotype and antiviral activity in bi 1182.52. The 2nd LAS Conference on HIV Patogenesis and Treatment; Paris. 2003. Rec #: 1565
133 Squires, K. E.; Thiry, A., and Giordano, M. Atazanavir (ATV) QD and efavirenz (EFV) QD with fixed-dose ZDV+3TC: combination of antiviral effiacy and safety through week 24 (AI424-034). 42nd Interscience Conference on Antimicrobial Agents and Chemotherapy; San Diego. American Society for Microbiology; 2002. Rec #: 2038
134 St Clair MH, Hartigan PM, Andrews JC, Vavro CL, Simberkoff MS, Hamilton JD. Zidovudine resistance, syncytium-inducing phenotype, and HIV disease progression in a case-control study. The VA Cooperative Study Group. J Acquir Immune Defic Syndr. Aug. 1993;6(8):891-7. Rec #: 1463. [pmid: 8315574].
135 Staszewski S, Keiser P, Montaner J, Raffi F, Gathe J, Brotas V, Hicks C, Hammer SM, Cooper D, Johnson M, Tortell S, Cutrell A, Thorborn D, Isaacs R, Hetherington S, Steel H, Spreen W. CNAAB3005 International Study Team. (Klinikum der Johann Wolfgang Goethe-Universitat, Zentrum der Inneren Medizin). Abacavir-lamivudine-zidovudine vs indinavir-lamivudine-zidovudine in antiretroviral-naive HIV-infected adults: A randomized equivalence trial. JAMA. Mar. 2001;285(9):1155-63. Rec #: 1380. [pmid: 11231744].
136 Svedhem V, Lindkvist A, Bergroth T, Knut L, Sonnerborg A. Diverse pattern of protease inhibitor resistance mutations in HIV-1 infected patients failing nelfinavir. J Med Virol. Aug. 2005;76(4):447-51. Rec #: 1014. [pmid: 15977242].
137 Tamalet C, Yahi N, Tourres C, Colson P, Quinson AM, Poizot-Martin I, Dhiver C, Fantini J. Multidrug resistance genotypes (insertions in the beta3-beta4 finger subdomain and MDR mutations) of HIV-1 reverse transcriptase from extensively treated patients: incidence and association with other resistance mutations. Virology. May 10. 2000;270(2):310-6. Rec #: 1271. [pmid: 10792990].
138 Thorne A, Harrigan PR, LaPierre N, Walmsley S. Evolution of resistance to salvage therapy with or without a preceding structured treatment interruption: impact on virological response. Antivir Ther. 2006;11:S91. Rec #: 2012.
139 Trotta, M. P.; Bonfigli, S.; Ceccherini Silberstein, F.; Zinzi, D.; D'Arrigo, R.; Soldani, F.; Zaccarelli, M.; Marconi, P.; Visco Comandini, U.; Boumis, E.; Forbici, F.; Tozzi, V.; Narciso, P.; Perno, C. F., and Antinori, A. Clinical and genotypic correlates of K65R mutation in an unselected cohort of HIV-infected persons naive for tenofovir. 2004; 9, S168. Rec #: 1945
140 Tsuchiya K, Matsuoka-Aizawa S, Yasuoka A, Kikuchi Y, Tachikawa N, Genka I, Teruya K, Kimura S, Oka S. Primary nelfinavir (NFV)-associated resistance mutations during a follow-up period of 108 weeks in protease inhibitor naive patients treated with NFV-containing regimens in an HIV clinic cohort. J Clin Virol. Aug. 2003;27(3):252-62. Rec #: 1101. [pmid: 12878089].
141 Tsuchiya K, Matsuoka S, Hachiya A, Yasuoka A, Tachikawa N, Kikuchi Y, Genka I, Teruya K, Kimura S, Oka S. Accumulation of lopinavir resistance-associated mutations over 3 years follow-up of patients on highly active antiretroviral therapy: implication in salvage therapy. AIDS. Jun 15. 2001;15(9):1183-4. Rec #: 1170. [pmid: 11416723].
142 UK Collaborative group on monitoring the transmission of HIV drug resis tance. Analysis of prevalence of HIV-1 drug resistance in primary infections in the United Kingdom. Br Med J. 2001;322:1087-88. Rec #: 1595. [pmid: 11337435]. [pmcid: 31258].
143 Valer L, Varrios A, Domingo P, et al. Rate of virological failure and resistance mutations in antiretroviral-experienced patients shift to a QD simplification regimen with didanosine, tenofovir and efavirenz (EFADITE Trial). Antivir Ther. 2005;10:S23. Rec #: 1962.
144 van de Vijver DAMC, Wensing AMJ, Angarano G, et al. Differences in the frequency of minor substitutions between HIV-1 subtypes and their potential impact on the genetic barrier for resistance to protesase inhibitors. Antivir Ther. 2005;10:S145. Rec #: 1990.
145 Vandamme A-M, Deforche K, Van Laethem K, Comacho R. HIV-1 subtype A1, C, F and G strains hvae a higher tipranavir mutation score than subtype B strains. Antivir Ther. 2005;10:S152. Rec #: 1997.
146 Venturi G, Romano L, Carli T, Corsi P, Pippi L, Valensin PE, Zazzi M. Divergent distribution of HIV-1 drug-resistant variants on and off antiretroviral therapy. Antivir Ther. Dec. 2002;7(4):245-50. Rec #: 1737. [pmid: 12553478].
147 Vidal C, Arnedo M, Garcia F, Mestre G, Plana M, Cruceta A, Capon A, Gallart T, Miro JM, Pumarola T, Gatell JM. Genotypic and phenotypic resistance patterns in early-stage HIV-1-infected patients failing initial therapy with stavudine, didanosine and nevirapine. Antivir Ther. Dec. 2002;7(4):283-7. Rec #: 1057. [pmid: 12553483].
148 Vingerhoets, J.; Peeters, M.; Corbett, C.; Iveson, K.; Vandermeulen, K.; Keen, R.; Woodfall, B., and De Bethune, M. P. Effect of Baseline Resistance on the Virologic Response to a Novel NNRTI, TMC125, in Patients with Extensive NNRTI and PI Resistance: Analysis of Study TMC125-C223 [HIV Drug Resistance: Mechanisms and Impact on Response to New Agents]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1781
149 Violin, M.; Forbici, F.; Cozzi-Lepri, A.; Velleca, R.; Bertoli, A.; Riva, C.; Giannella, S.; Manconi, P. E.; Lazzarin, A.; Pasquinucci, S.; Tacconi, L.; Carnevale, G.; Mazzotta, F.; Bonazzi, L.; Montroni, M.; Chirianni, A.; Capobianchi, M.; Ippolito, G.; Moroni, M.; Perno, C. F., and D'Arminio-Monforte, A. Primary HIV-1 resistance in recently and chronically infected individuals of the Italian Cohort Naive for Antiretrovirals. J Biol Regul Homeost Agents. 2002 Jan–2002 Mar 31; 16(1):37–43. Rec #: 1184
150 Walsh JC, Pozniak AL, Nelson MR, Mandalia S, Gazzard BG. Virologic rebound on HAART in the context of low treatment adherence is associated with a low prevalence of antiretroviral drug resistance. J Acquir Immune Defic Syndr. Jul 1. 2002;30(3):278-87. Rec #: 1150. [pmid: 12131564].
151 Waters, J.; Margot, N.; McColl, D.; Zhong, L., and Miller, M. K65R, L74V and Thymidine Analog Mutations in HIV-1 RT Associated with Reduced Response to Tenofovir DF in ART-experienced Patients [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1809
152 Whitcomb JM, Huang W, Limoli K, Paxinos E, Wrin T, Skowron G, Deeks SG, Bates M, Hellmann NS, Petropoulos CJ. Hypersusceptibility to non-nucleoside reverse transcriptase inhibitors in HIV-1: clinical, phenotypic and genotypic correlates. AIDS. Oct 18. 2002;16(15):F41-7. Rec #: 1746. [pmid: 12370521].
153 Winters MA, Baxter JD, Mayers DL, Wentworth DN, Hoover ML, Neaton JD, Merigan TC. Frequency of antiretroviral drug resistance mutations in HIV-1 strains from patients failing triple drug regimens. The Terry Beirn Community Programs for Clinical Research on AIDS. Antivir Ther. Mar. 2000;5(1):57-63. Rec #: 1267. [pmid: 10846594].
154 Wirden, M.; Marcelin, A. G.; Ghosn, J.; Dominguez, S.; Roquebert, B.; Simon, A.; Katlama, C., and Calvez, V. T215F Mutation and Abacavir or Efavirenz Use Are Linked to the L74I Mutation Selection [Mechanisms of Drug Resistance: Reverse Transcriptase Inhibitors]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1797
155 Wirden M, Marcelin AG, Simon A, Kirstetter M, Tubiana R, Valantin MA, Paris L, Bonmarchand M, Conan F, Kalkias L, Katlama C, Calvez V. Resistance mutations before and after tenofovir regimen failure in HIV-1 infected patients. J Med Virol. Jul. 2005;76(3):297-301. Rec #: 1021. [pmid: 15902696].
156 Yerly S, Fagard C, Gunthard HF, Hirschel B, Perrin L. Drug resistance mutations during structured treatment interruptions. Antivir Ther. Oct. 2003;8(5):411-5. Rec #: 1131. [pmid: 14640388].
157 Yerly, S.; Race, E.; Vora, S., and et al. HIV drug resistance and molecular epidemiology in patients with primary HIV infection [abstract 754]. 8th Conference on Retroviruses and Opportunistic Infections; Chicago. 2001. Rec #: 1591
158 Yerly S, Rakik A, Kinloch-de-Loes S, Erb P, Vernazza P, Hirschel B, Perrin L. [Prevalence of transmission of zidovudine-resistant viruses in Switzerland. l'Etude suisse de cohorte VIH]. Schweiz Med Wochenschr. Oct 26. 1996;126(43):1845-8. Rec #: 1455. [pmid: 9005525].
159 Yerly S, Rickenbach M, Popescu M, Taffe P, Craig C, Perrin L. Drug resistance mutations in HIV-1-infected subjects during protease inhibitor-containing highly active antiretroviral therapy with nelfinavir or indinavir. Antivir Ther. Sep. 2001;6(3):185-9. Rec #: 1161. [pmid: 11808753].
160 Zaccarelli M, Perno CF, Forbici F, Cingolani A, Liuzzi G, Bertoli A, Trotta MP, Bellocchi MC, Di Giambenedetto S, Tozzi V, Gori C, D'Arrigo R, De Longis P, Noto P, Girardi E, De Luca A, Antinori A. Using a database of HIV patients undergoing genotypic resistance test after HAART failure to understand the dynamics of M184V mutation. Antivir Ther. Feb. 2003;8(1):51-6. Rec #: 1165. [pmid: 12713064].
161 Zaccarelli M, Perno CF, Forbici F, Soldani F, Bonfigli S, Gori C, Trotta MP, Bellocchi MC, Liuzzi G, D'Arrigo R, De Longis P, Boumis E, Bellagamba R, Tozzi V, Narciso P, Antinori A. Q151M-mediated multinucleoside resistance: prevalence, risk factors, and response to salvage therapy. Clin Infect Dis. Feb 1. 2004;38(3):433-7. Rec #: 1117. [pmid: 14727218].

## Rejected: Second screening - No prevalence or incidence data

1 Antinori, A.; Trotta, M.; Lorenzini, P.; Carosi, G.; Gianotti, N.; Maggiolo, F.; Torti, C.; Castagna, A.; Andreoni, M., and Perno, C. F. Virological Response to ART in the Presence of K65R Mutation [Impact of Resistance on Treatment Response]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1812
2 Baxter, J. D.; Leduc, R. E.; DuChene, A.; Leong, H.; Furtado, M. R., and Petrauskene, O. V. Prevalence of HIV-1 GAG cleavage site mutations in patients failing protease inhiitors in the GART Study (CPCRA 046). 2004; 9, S48. Rec #: 1913
3 Baxter JD, Mayers DL, Wentworth DN, Neaton JD, Hoover ML, Winters MA, Mannheimer SB, Thompson MA, Abrams DI, Brizz BJ, Ioannidis JP, Merigan TC. (Cooper Hospital/UMDNJ-Robert Wood Johnson Medical School, Camden, NJ, USA.). A randomized study of antiretroviral management based on plasma genotypic antiretroviral resistance testing in patients failing therapy. CPCRA 046 Study Team for the Terry Beirn Community Programs for Clinical Research on AIDS. AIDS. Jun. 2000;14(9):F83-93. Rec #: 1383. [pmid: 10894268].
4 Cingolani A, Antinori A, Rizzo MG, Murri R, Ammassari A, Baldini F, Di Giambenedetto S, Cauda R, De Luca A. Usefulness of monitoring HIV drug resistance and adherence in individuals failing highly active antiretroviral therapy: a randomized study (ARGENTA). AIDS. Feb 15. 2002;16(3):369-79. Rec #: 1549. [pmid: 11834948].
5 Cohen CJ, Hunt S, Sension M, Farthing C, Conant M, Jacobson S, Nadler J, Verbiest W, Hertogs K, Ames M, Rinehart AR, Graham NM. A randomized trial assessing the impact of phenotypic resistance testing on antiretroviral therapy. AIDS. Mar 8. 2002;16(4):579-88. Rec #: 1547. [pmid: 11873001].
6 Costagliola, D.; Morand-Joubert, L.; Assoumou, L.; Brodard, V.; Plantier, J. C.; Delaugerre, C.; Mackiewicz, V.; Saidi, S.; Brun-Vezinet, F.; Masquelier, B., and ANRS AC11 Resistance Study Group. Prevalence of Resistance to at Least 1 Drug in Treated-HIV-infected Patients with Viral Load >1000 Copies/mL in 2004: A French Nationwide Study [Epidemiology and Transmission of Resistance]. 13th Conference on Retroviruses and Opportunisitic Infections; 2006. Rec #: 1775
7 Durant J, Clevenbergh P, Halfon P, Delgiudice P, Porsin S, Simonet P, Montagne N, Boucher CA, Schapiro JM, Dellamonica P. Drug-resistance genotyping in HIV-1 therapy: the VIRADAPT randomised controlled trial. Lancet. Jun 26. 1999;353(9171):2195-9. Rec #: 1546. [pmid: 10392984].
8 Duvivier, C.; Ghosn, J.; Wirden, M.; Ouagari, Z.; Dominguez, S.; Marcelin A.G.; Peytavin, G., and Katlama, C. Efficacy and Safety of Dual Boosted PI Regimen without RT Inhibitors in HIV-1-infected Patients. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1871
9 El-Far F, Medeiros EAS, Gasparoto CT, Diaz RS. (Dr. R.S. Diaz, Laboratorio de Retrovirologia, Infectious Disease Division, Federal University of Sao Paulo). Antiretroviral drug resistance among patients with human immunodeficiency virus who act as sources or potential sources in occupational accidents involving healthcare workers. Infect Control Hosp Epidemiol. Sep. 2005;26(9):782-8. ISSN: 0899-823X. Rec #: 1499. [pmid: 16209385].
10 Gunthard H, von Wyl V, Yerly S, Boni J, Schupbach J, Burgisser P, Klimkait T, Battegay M, Furrer H, Telenti A, Hirschel B, Vernazza P, Bernasconi E, Rickenbach M, Perrin L, Ledergerber B. Virologicdal failure and emergence of treatment-specific HIV-1 drug resistance patterns on first-line HAART in previously untreated patients from the Swiss HIV Cohort Study (SHCS). Antivir Ther. 2006;11:S82. Rec #: 2005.
11 Haubrich, R.; Hernandez, J.; Bates, M.; Thompson, M.; Margolis, D.; Pappa, K.; Yau, L., and Schooley, R. Determinants of replication capacity (RC) in HIV-1 isolates from antiretroviral (ART)-experienced adults failing a PI-based regimen, and relationship of RC with HIV-1 RNA and CD4 counts. 2004; 9, S162. Rec #: 1941
12 Hertogs K, Bloor S, Kemp SD, Van den Eynde C, Alcorn TM, Pauwels R, Van Houtte M, Staszewski S, Miller V, Larder BA. Phenotypic and genotypic analysis of clinical HIV-1 isolates reveals extensive protease inhibitor cross-resistance: a survey of over 6000 samples. AIDS. Jun 16. 2000;14(9):1203-10. Rec #: 1215. [pmid: 10894285].
13 Marcelin, A. G.; Roquebert, B.; Malet, I.; Wirden, M.; Katlama, C., and Calvez, V. Minor protease inhibitor resistant variants, even at very low level, can drive the failure resistance mutations profiles of subsequent protease inhibitor-based regimen. 2004; 9, S164. Rec #: 1943
14 Masquelier B, Race E, Tamalet C, Descamps D, Izopet J, Buffet-Janvresse C, Ruffault A, Mohammed AS, Cottalorda J, Schmuck A, Calvez V, Dam E, Fleury H, Brun-Vezinet F. Genotypic and phenotypic resistance patterns of human immunodeficiency virus type 1 variants with insertions or deletions in the reverse transcriptase (RT): multicenter study of patients treated with RT inhibitors. Antimicrob Agents Chemother. Jun. 2001;45(6):1836-42. Rec #: 1232. [pmid: 11353634]. [pmcid: 90554].
15 Mougnutou, R.; Bourgeois, A.; Nkoue, N.; Laurent, C.; Lactouock, B.; Liegeois, F., and et al. Evaluation of a AART pilot study in Yaounde, Cameroon: 24 months follow-up. 2nd AIS Conference on HIV Pathogenesis and Treament; Paris. 2003. Rec #: 2046
16 Phillips, A. N.; Dunn, D.; Sabin, C., and et al. Risk of development of drug resistance in patients starting antiretroviral therapy with three or more drugs in routine clinical practice. 2004; 9, S151. Rec #: 1938
17 Quiros-Roldan E, Signorini S, Castelli F, Torti C, Patroni A, Airoldi M, Carosi G. Analysis of HIV-1 mutation patterns in patients failing antiretroviral therapy. J Clin Lab Anal. 2001;15(1):43-6. Rec #: 1197. [pmid: 11170234].
18 Race E, Dam E, Obry V, Paulous S, Clavel F. Analysis of HIV cross-resistance to protease inhibitors using a rapid single-cycle recombinant virus assay for patients failing on combination therapies. AIDS. Oct 22. 1999;13(15):2061-8. Rec #: 1227. [pmid: 10546858].
19 Riddler, S.; Jiang, H.; Deeks, S.; Tenorio, A.; Huang, H.; Kuritzkes, D.; Acosta, E.; Landay, A.; Bartlett, J., and Aids Clin Trials Group. A Randomized Pilot Study of Delayed ART Switch in Subjects with Detectable Viremia on HAART [Antiretroviral Therapy: Randomized Trials, Strategies and Long-Term Outcomes]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1807
20 Rodrigues R, Custodio RM, Bueno SM, Eira M, Ferreira JL, Jamal L, Duarte AJ, Brigido LF. Prevalence of ARV resistance mutations and impact of genotyping test in HIV patients with advance disease in Sao Paulo, Brazil. J Clin Virol. Apr. 2005;32(4):336-7. Rec #: 1452. [pmid: 15780815].
21 Schmidt B, Korn K, Moschik B, Paatz C, Uberla K, Walter H. Low level of cross-resistance to amprenavir (141W94) in samples from patients pretreated with other protease inhibitors. Antimicrob Agents Chemother. Nov. 2000;44(11):3213-6. Rec #: 1205. [pmid: 11036057]. [pmcid: 101637].
22 Schnell T, Schmidt B, Moschik G, Thein C, Paatz C, Korn K, Walter H. Distinct cross-resistance profiles of the new protease inhibitors amprenavir, lopinavir, and atazanavir in a panel of clinical samples. AIDS. May 23. 2003;17(8):1258-61. Rec #: 1109. [pmid: 12819531].
23 Shulman, N. S.; Bosch, R. J.; Albrecht, M.; Hellmann, N.; Katzenstein, D. A., and ACTG 365 team. Impact of the M184V/I on protease inhibitor susceptibilities in protease inhibitor-naive patients. 2004; 9, S84. Rec #: 1919
24 Smith, A. J.; Wang, H.; Bennett, D.; Teshale, E.; Buskin, S.; Morse, A.; Wohl, A.; Swerdlow, D.; Sullivan, P., and Wolfe, M. Prevalence of mutations associated with antiretroviral drug resistance (ARVDR) in a cohort of treated individuals in four US cities. 2004; 9, S112. Rec #: 1933
25 Spacek, L. A.; Shihab, H. M.; Mwesigire, D.; Ronald, A.; Kamya, M.; Mayanja, H.; Moore, R. D., and Quinn, T. C. Drug resistance in patients iwth HIV-1 non-B subypes in Kampala, Uganda. 42nd Annual Meeting of IDSA; Boston, MS. 2004. Rec #: 2090
26 Sugiura, W.; Matsuda, M.; Chiba, T., and et al. Changes in prevalence and patterns of drug resistant mutations in Japan - summary of nationwide HIV-1 drug resistance surveillance study (1996 to 2003) in Japan. 2004; 9, S109. Rec #: 1930
27 Swartz, E. C.; Defore, K. T.; Horvath, J. A.; Postic, B., and Talwani, R. Differences in virologic, immunologic, and genotypic responses according to regimen class during time on first HAART regimen started in treatment naive HIV-infected patients (pts) treated at a publicly funded clinic. 42nd Annual Meeting of IDSA; Boston, MS. 2004. Rec #: 2086
28 Torti C, Quiros-Roldan E, Regazzi M, De Luca A, Mazzotta F, Antinori A, Ladisa N, Micheli V, Orani A, Patroni A, Villani P, Lo Caputo S, Moretti F, Di Giambenedetto S, Castelnuovo F, Maggi P, Tinelli C, Carosi G. (Dr. C. Torti, Institute for Infectious and Tropical Diseases). A randomized controlled trial to evaluate antiretroviral salvage therapy guided by rules-based or phenotype-driven HIV-1 genotypic drug-resistance interpretation with or without concentration-controlled intervention: The resistance and dosage adapted regimens (RADAR) study. Clin Infect Dis. 2005 Jun;40(12):1828-36. ISSN: 1058-4838. Rec #: 1488. [pmid: 15909273].
29 Tural C, Ruiz L, Holtzer C, Schapiro J, Viciana P, Gonzalez J, Domingo P, Boucher C, Rey-Joly C, Clotet B. Clinical utility of HIV-1 genotyping and expert advice: the Havana trial. AIDS. Jan 25. 2002;16(2):209-18. Rec #: 1550. [pmid: 11807305].
30 Vray M; Meynard JL; Dalban C; Morand-Joubert L; Clavel F; Brun-Vezinet F; Peytavin G; Costagliola D; Girard PM, and Narval Trial Group (INSERM EMI 0214, Universite Pierre et Marie Curie, Paris, France. murielvray@hotmail.com). Predictors of the virological response to a change in the antiretroviral treatment regimen in HIV-1-infected patients enrolled in a randomized trial comparing genotyping, phenotyping and standard of care (Narval trial, ANRS 088). 2003 Oct;8(5):427–34. Rec #: 1369
31 Weidle, P.; Sozi, C.; Mwebaze, R., and et al. Resistance to antiretroviral therapy in the UNAIDS HIV drug access initiative-Uganda [abtract 527]. 8th Conference on Retroviruses and Opportunistic Infections; Chicago. 2001. Rec #: 1598
32 Yahi, N.; Tamalet, C.; Tourres, C.; Tivoli, N., and Fantini, J. Mutation L210W of HIV-1 reverse transcriptase in patients receiving combination therapy. Incidence, association with other mutations, and effects on the structure of mutated reverse transcriptase. J Biomed Sci. 2000 Nov–2000 Dec 31; 7(6):507–13. Rec #: 1256

## Antiretroviral: Rejected: Second screening - Duplicate data

1 Adje-Toure C, Celestin B, Hanson D, Roels TH, Hertogs K, Larder B, Diomande F, Peeters M, Eholie S, Lackritz E, Chorba T, Nkengasong JN. Prevalence of genotypic and phenotypic HIV-1 drug-resistant strains among patients who have rebound in viral load while receiving antiretroviral therapy in the UNAIDS-Drug Access Initiative in Abidjan, Cote d'Ivoire. AIDS. Jul. 2003;17(Suppl 3):S23-9. Rec #: 1088. [pmid: 14565606].
2 Bauer GR, Welles SL, Colgrove RR, Pitt J. Zidovudine resistance phenotype and risk of perinatal HIV-1 transmission in zidovudine monotherapy-treated mothers with moderately advanced disease. J Acquir Immune Defic Syndr. Nov 1. 2003;34(3):312-9. Rec #: 1139. [pmid: 14600578].
3 Eshleman SH, Becker-Pergola G, Deseyve M, Guay LA, Mracna M, Fleming T, Cunningham S, Musoke P, Mmiro F, Jackson JB. Impact of human immunodeficiency virus type 1 (hiv-1) subtype on women receiving single-dose nevirapine prophylaxis to prevent hiv-1 vertical transmission (hiv network for prevention trials 012 study). J Infect Dis. Oct 1. 2001;184(7):914-7. Rec #: 1650. [pmid: 11509999].
4 Eshleman SH, Guay LA, Mwatha A, Cunningham SP, Brown ER, Musoke P, Mmiro F, Jackson JB. Comparison of nevirapine (NVP) resistance in Ugandan women 7 days vs. 6–8 weeks after single-dose nvp prophylaxis: HIVNET 012. AIDS Res Hum Retroviruses. Jun. 2004;20(6):595-9. Rec #: 1036. [pmid: 15242535].
5 Eshleman, S. H.; Hoover, D.; Chen, S.; Hudelson, S.; Guay, L.; Mwatha, A.; Brown, E.; Mmiro, F.; Musoke, P.; Jackson, J.; Kumwenda, N., and Taha, T. Comparison of Nevirapine Resistance in Women with Subtype C Compared with Subtypes A and D after Single-dose NVP. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1898
6 Eshleman SH, Hoover DR, Hudelson SE, Chen S, Guay LA, Mwatha A, Fiscus SA, Mmiro F, Musoke P, Jackson JB, Kumwenda NI, Taha T. Resistance after single dose nevirapine prophylaxis varies by viral subtyle in infants from sub-Saharan Africa. Antivir Ther. 2005;10:S12. Rec #: 1954.
7 Eshleman SH, Hoover DR, Hudelson SE, Chen S, Mwatha A, Ficus SA, Jackson JB, Kumwenda NI, Taha T. Infant nevirapine resistance can be substantially reduced after single dose nevirapine by avoiding maternal nevirapine dosing and providing infants with zidovudine in addition to single dose nevirapine after birth. Antivir Ther. 2005;10:S3. Rec #: 1953. [pmid: 16163812].
8 Eshleman SH, Mracna M, Guay LA, Deseyve M, Cunningham S, Mirochnick M, Musoke P, Fleming T, Glenn Fowler M, Mofenson LM, Mmiro F, Jackson JB. Selection and fading of resistance mutations in women and infants receiving nevirapine to prevent HIV-1 vertical transmission (HIVNET 012). AIDS. Oct 19. 2001;15(15):1951-7. Rec #: 1079. [pmid: 11600822].
9 Flys, T. S.; Chen, S.; Jones, D.; Hoover, D.; Guay, L.; Jackson, J.; Fiscus, S.; Kumwenda, N.; Taha, T., and Eshleman, S. Analysis of K103N-containing HIV-1 Variants in Women with HIV-1 Subtypes A, C, and D after Single-dose Nevirapine Using a Sensitive and Quantitative Point Mutation Assay [Antiretroviral Resistance in Mother-to-child Transmission]. 13th Conference on Retroviruses and Opportunistic Infections; 2006. Rec #: 1779
10 Johnson, J.; Li, J. F.; Morris, L.; Martinson, N.; Gray, G.; McIntyre, J., and Heneine, W. Resistance Emerges in the Majority of Women Provided Intrapartum Single-dose Nevirapine. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1830
11 Johnson JA, Li J-F, Morris L, Martinson N, Gray G, McIntyre J, Heneine W. Resistance mutations arise in the majority of women provided single-dose NVP and appear to differ in emergence and persistence. Antivir Ther. 2005;10:S13. Rec #: 1958.
12 Nuesch R, Ananworanich J, Sirivichayakul S, Ubolyam S, Siangphoe U, Hill A, Cooper D, Lange J, Phanuphak P, Ruxrungtham K. Development of HIV with drug resistance after CD4 cell count-guided structured treatment interruptions in patients treated with highly active antiretroviral therapy after dual-nucleoside analogue treatment. Clin Infect Dis. Mar 1. 2005;40(5):728-34. Rec #: 1467. [pmid: 15714420].
13 Palumbo, P.; Dobbs, T.; Holland, B., and et al. Antiretroviral resistance mutations among pregnant HIV-infected women and their newborns in the US: Vertical transmission and clades [abstract TuPpB1230]. XIII International AIDS Conference; Durban, South Africa. 2000. Rec #: 1603
14 Pieniazek D, Rayfield M, Hu DJ, Nkengasong J, Wiktor SZ, Downing R, Biryahwaho B, Mastro T, Tanuri A, Soriano V, Lal R, Dondero T. Protease sequences from HIV-1 group M subtypes A-H reveal distinct amino acid mutation patterns associated with protease resistance in protease inhibitor-naive individuals worldwide. HIV Variant Working Group. AIDS. Jul 28. 2000;14(11):1489-95. Rec #: 1207. [pmid: 10983635].

## Antiretroviral: Rejected: Second screening - Insufficient statistics

1 Easterbrook PJ, Hertogs K, Waters A, Wills B, Gazzard BG, Larder B. Low prevalence of antiretroviral drug resistance among HIV-1 seroconverters in London, 1984-1991. J Infect. Feb. 2002;44(2):88-91. Rec #: 1180. [pmid: 12076067].
2 Harrigan PR, Montaner JS, Wegner SA, Verbiest W, Miller V, Wood R, Larder BA. World-wide variation in HIV-1 phenotypic susceptibility in untreated individuals: biologically relevant values for resistance testing. AIDS. Sep 7. 2001;15(13):1671-7. Rec #: 2067. [pmid: 11546942].
3 Johnson, M.; DeJesus, E.; Rodriguez, C.; Nieto-Cisneros, L.; Rightmire, A.; McLaren, C., and Odeshoo, L. The Influence of Baseline Protease Inhibitor Mutations on the Efficacy of Ritonavir-Boosted Atazanavir, Atazanavir plus Saquinavir, and Lopinavir/Ritonavir in Patients Who Have Experienced Virologic Failure on Multiple HAART Regimens. 12th Conference on Retroviruses and Opportunistic Infections; 2005. Rec #: 1851