# Appendix D. Evidence Table, Resistance to Antiretroviral Drugs in Developing Regions

First author | Study Design | Population | Medication Class | Selection Method
Year | Sample Size | Age/Age Range | Inclusion Criteria | Resistance Testing Method
Reference # | Year/Range Data Collected | Region
ADJE | Design: Consecutive patients | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2001^1^ | Sample Size: 81 | Age/Range: NR / NR | Inclusions: ARV experienced | Testing: Genotypic sequence-based mechanism, Phenotypic VIRCO
| Year/Range: 1998-1999 | Region: Africa
ANAWORANCIH | Design: Clinical trial | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Treatment failure, ≥ 2 STI-Tx cycles
2006^2^ | Sample Size: 125 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002-2003 | Region: Western Europe, Australia/NZ, Other Asia
ANAWORANICH | Design: Clinical trial | Population: Population NR, Not Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Treatment failure
2005^3^ | Sample Size: 348 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve or Prior exposure to unboosted SQV regimen | Testing: Genotypic other, NR
| Year/Range: NR | Region: Western Europe, Australia/NZ, Other Asia
ANDRADE-VILLANUEVA | Design: Case series, sample assembly NR | Population: Adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^4^ | Sample Size: 20 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 2003-2004 | Region: Latin America
ANDRADE-VILLANUEVA | Design: Case series, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^5^ | Sample Size: 50 | Age/Range: NR / NR | Inclusions: Virological failure | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002-2004 | Region: Latin America
AUTHOR NOT AVAILABLE | Design: Case series, sample assembly NR | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2003^6^ | Sample Size: 33 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, NR
| Year/Range: NR | Region: Africa
AVERBUCH | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^7^ | Sample Size: 59 | Age/Range: NR / 1–18 | Inclusions: Available information on ARV regimens, Viral load > 1000 copies/ml | Testing: Genotypic other, NR
| Year/Range: NR | Region: Western Europe
BALAKRISHNAN | Design: Case series, sample assembly NR | Population: Adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^8^ | Sample Size: 50 | Age/Range: 34 / 20–61 | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism, Nested PCR
| Year/Range: 2002-2003 | Region: India
BAUER | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
2001^9^ | Sample Size: 81 | Age/Range: NR / NR | Inclusions: ZDV resistance or Wild-type virus | Testing: Phenotypic assay
| Year/Range: 1994 | Region: US/Canada
BESSONG | Design: Case series, sample assembly NR | Population: Population NR, Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2005^10^ | Sample Size: 40 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic other, Nested PCR
| Year/Range: NR | Region: Africa
BOWLES | Design: Other | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2006^11^ | Sample Size: 4714 | Age/Range: NR / NR | Inclusions: Tx naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: US/Canada, Western Europe, Latin America, Africa, Asia
BRENNER | Design: Cohort, sample assembly NR | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2003^12^ | Sample Size: 532 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism, Phenotypic VIRCO
| Year/Range: NR | Region: US/Canada, Africa
BRINDEIRO | Design: Cohort, sample assembly NR | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2002^13^ | Sample Size: 52 | Age/Range: NR / 2–14 | Inclusions: Virological failure | Testing: Genotypic sequence-based mechanism, Phenotypic VIRCO, Nested PCR
| Year/Range: NR/1999-2000 | Region: Latin America
BRINDEIRO | Design: Consecutive patients | Population: IV drug users and men who have sex with men, and women, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2003^14^ | Sample Size: 535 | Age/Range: 31 / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism, Nested PCR
| Year/Range: 2001/NR-NR | Region: Latin America
BUSSMANN | Design: Random sample of larger database | Population: Adults (NOS), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2005^15^ | Sample Size: 71 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001/NR-NR | Region: Africa
CAROBENE | Design: Cohort, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^16^ | Sample Size: 583 | Age/Range: NR / NR | Inclusions: Virological failure | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Latin America
CHAIX | Design: Clinical trial and random sample of larger database | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^17^ | Sample Size: 112 | Age/Range: NR / NR | Inclusions: Infected during birth, Transmitted HIV to child | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002-2003 | Region: Africa
CHAIX | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Treatment failure
2005^18^ | Sample Size: 115 | Age/Range: NR / 1–15 | Inclusions: ARV treatment ≥ 6 mo | Testing: Genotypic other, NR
| Year/Range: 2000-2003 | Region: Africa
CHAIX | Design: Clinical trial | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2004^19^ | Sample Size: 74 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
CHANTRATITA | Design: Case series, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: NNRTI, Protease inhibitor | Selection: Entire population
2002^20^ | Sample Size: 83 | Age/Range: NR / NR | Inclusions: ARV Tx with nucleosides, non-nucleosides, PIs, Acceptable compliance | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Other Asia
COHEN | Design: Clinical trial | Population: IV drug users, and Adults (NOS), Not Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
2005^21^ | Sample Size: 300 | Age/Range: NR / NR | Inclusions: Age ≥ 16 years, and Viral load > 1000 copies/ml, and Virologic response to at least1 HAART regimen, and Failure to prior regimen including at least 1 PI, and CD4 cell count > 50 cell/ mm3 | Testing: Phenotypic Virologic
| Year/Range: 2001-2002 | Region: US/Canada, Western Europe, Eastern Europe, Latin America
COLGROVE | Design: Convenience sample | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
1998^22^ | Sample Size: 48 | Age/Range: NR / NR | Inclusions: Received ZDV Tx during pregnancy | Testing: Genotypic sequence-based mechanism
| Year/Range: 1989-1994 | Region: US/Canada, Latin America
CUNNINGHAM | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2002^23^ | Sample Size: 217 | Age/Range: NR / NR | Inclusions: Age ≥ 13 years, and > 20 weeks gestation, and Plasma RNA > 400 copies/ml | Testing: Genotypic sequence-based mechanism
| Year/Range: 1997-2000 | Region: US/Canada, Western Europe, Latin America
DEFORCHE | Design: Other | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^24^ | Sample Size: 940 | Age/Range: NR / NR | Inclusions: Received NVP-based ART | Testing: Genotypic other, NR
| Year/Range: NR | Region: US/Canada, Western Europe, Latin America, Africa, Japan, Other Asia
DELAUGERRE | Design: Consecutive patients | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2006^25^ | Sample Size: 53 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, NR
| Year/Range: 1997-2004 | Region: Western Europe
DELGADO | Design: Cohort, sample assembly NR | Population: IV drug users, men who have sex with men, women, Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2001^26^ | Sample Size: 100 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, Nested PCR
| Year/Range: NR | Region: Latin America
DESHPANDE | Design: Consecutive patients | Population: Population NR, T Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2004^27^ | Sample Size: 128 | Age/Range: 30 / NR | Inclusions: Antiretroviral naïve, CD4 > 400 | Testing: Genotypic sequence-based mechanism
| Year/Range: 2003 | Region: India
DOUALLA-BELL | Design: Case series, sample assembly NR | Population: Adults (NOS), Not TX naive | Med Class: Non-NRTI, NRTI | Selection: Treatment failure
2006^28^ | Sample Size: 23 | Age/Range: NR / NR | Inclusions: Initiated NNRTI based-regimen, Claude C | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002/NR-NR | Region: Africa
DOUALLA-BELL | Design: Cohort, sample assembly NR | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^29^ | Sample Size: 48 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
DUMANS | Design: Other | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2002^30^ | Sample Size: 49 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism, Phenotypic VIRCO
| Year/Range: 1998 | Region: Latin America
EASTMAN | Design: Clinical trial and random sample of larger database | Population: Pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
1998^31^ | Sample Size: 96 | Age/Range: NR / NR | Inclusions: CD4 cell count > 200/μL, No indications for ARV Tx | Testing: Probe-based system
| Year/Range: 1993-1994 | Region: US/Canada
EKPINI | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
2002^32^ | Sample Size: 84 | Age/Range: NR / 17–37 | Inclusions: Received ZDV Tx during pregnancy, and Transmitted HIV to child, and Haemoglobin ≥70 g/L, and Absolute neutrophil count ≥1.0 X 109/L, and ≥ 36 weeks gestation, and Platelet count >100 X 109/L, and Serum alanine aminotransferase concentration ≤ 2.5 times the upper limit of normal, and Serum creatinine concentration ≤150 g/L | Testing: Genotypic sequence-based mechanism
| Year/Range: 1996-1998 | Region: Africa
ESHLEMAN | Design: Clinical trial | Population: Children (under 12 yrs), pregnant women, Not TX naive | Med Class: Non-NRTI, NRTI | Selection: Entire population
2006^33^ | Sample Size: 329 | Age/Range: NR / NR | Inclusions: Infant with known HIV status | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
ESHLEMAN | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2005^34^ | Sample Size: 140 | Age/Range: NR / NR | Inclusions: Age ≥ 18 years, > 32 weeks gestation | Testing: Genotypic sequence-based mechanism
| Year/Range: 1997-1999 | Region: Africa
ESHLEMAN | Design: Clinical trial and consecutive patients | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2005^35^ | Sample Size: 306 | Age/Range: 25 / NR | Inclusions: Expected delivery ≥ 4 hrs after enrollment | Testing: Genotypic sequence-based mechanism
| Year/Range: 2000-2003 | Region: Africa
ESHLEMAN | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2004^36^ | Sample Size: 279 | Age/Range: 21–27 | Inclusions: Age ≥ 18 years, > 30 weeks gestation | Testing: Genotypic sequence-based mechanism
| Year/Range: 1997-1999 | Region: Africa
FLYS | Design: Clinical trial | Population: Pregnant women, Not TX naive | Med Class: Non-NRTI | Selection: Entire population
2007^37^ | Sample Size: 144 | Age/Range: NR / NR | Inclusions: K103N mutation present at 6–8 weeks | Testing: Genotypic other, LigAmp assay
| Year/Range: NR/1998-2003 | Region: Africa
FUENTES-ROMERO | Design: Case series, sample assembly NR | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^38^ | Sample Size: 45 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve, Age > 14 years | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Latin America
GALLANT | Design: Clinical trial | Population: Pregnant women, and adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Treatment failure
2004^39^ | Sample Size: 602 | Age/Range: 38 / 18–64 | Inclusions: Viral load > 5,000 copies RNA/ml, Antiretroviral naïve | Testing: Genotypic sequence-based mechanism, Phenotypic Virologic
| Year/Range: 2000-2004 | Region: US/Canada, Western Europe, Latin America
GIULIANO | Design: Clinical trial | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^40^ | Sample Size: 47 | Age/Range: NR / NR | Inclusions: Infected during birth, Transmitted HIV to child | Testing: Genotypic other, NR
| Year/Range: NR | Region: Africa
GORDON | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^41^ | Sample Size: 60 | Age/Range: NR / NR | Inclusions: Received PMTCT | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
HAN | Design: Cohort, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^42^ | Sample Size: NR | Age/Range: NR / 23–54 | Inclusions: CD4 < 350 | Testing: Genotypic sequence-based mechanism
| Year/Range: 2003 | Region: Other Asia
HANDEMA | Design: Case series, sample assembly NR | Population: Pregnant woment, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2003^43^ | Sample Size: 28 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 2000 | Region: Africa
HANLON | Design: Cohort, sample assembly NR | Population: Pregnant women, Not Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2006^44^ | Sample Size: 65 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, NR
| Year/Range: NR | Region: Western Europe
HARRIGAN | Design: Consecutive patients | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2002^45^ | Sample Size: 6275 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve, Available information on ARV regimens | Testing: Genotypic sequence-based mechanism, Phenotypic VIRCO, Nested PCR
| Year/Range: NR | Region: US/Canada, Western Europe, Africa
JACK | Design: Consecutive patients | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population, Treatment failure
2004^46^ | Sample Size: 20 | Age/Range: 31 / 18–53 | Inclusions: Age ≥ 18 years, and Pulmonary TB | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002 | Region: Africa
JEANNIN | Design: Case series, sample assembly NR | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Random sample, Treatment failure
2004^47^ | Sample Size: 398 | Age/Range: NR / NR | Inclusions: ARV treatment ≥ 6 mo | Testing: Genotypic other, NR
| Year/Range: 2004 | Region: Africa
JENWITHEESUK | Design: Case series, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2003^48^ | Sample Size: 171 | Age/Range: NR / NR | Inclusions: Viral load > 500 HIV RNA copies/ml, ARV experienced | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001-2002 | Region: Other Asia
JOHANN-LIANG | Design: Consecutive patients | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2000^49^ | Sample Size: 40 | Age/Range: NR / 1–14 | Inclusions: Viral load > 1000 copies/ml and Currently on ARV Tx | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: US/Canada
JOHNSON | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: NR
2005^50^ | Sample Size: 50 | Age/Range: NR / NR | Inclusions: 32 – 38 weeks gestation | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
JOURDAIN | Design: Clinical trial and other method | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2004^51^ | Sample Size: 269 | Age/Range: NR / NR | Inclusions: > 28 weeks gestation and CD4 cell count < 250/ml2 | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001-2003 | Region: Other Asia
JOURDAIN | Design: Clinical trial | Population: Pregnant women, Not TX naive | Med Class: Non-NRTI | Selection: Random sample
2004^52^ | Sample Size: 219 | Age/Range: NR / NR | Inclusions: Received pMTCT, Initiated NNRTI based-regimen | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Other Asia
KAMKAMIDZE | Design: Random sample of larger database | Population: Children (under 12 yrs), Tx naïve | Med Class: NRTI | Selection: Entire population
2001^53^ | Sample Size: 49 | Age/Range: NR / 0–16 | Inclusions: NR | Testing: Genotypic other, Nested PCR
| Year/Range: 1992-1999 | Region: US/Canada
KANTOR | Design: Case series, sample assembly NR | Population: Adults (NOS), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Treatment failure
2002^54^ | Sample Size: 21 | Age/Range: NR / 31–61 | Inclusions: On current ARV for ≥ 2 months | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001 | Region: Africa
KANTOR | Design: Case series, sample assembly NR | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2003^55^ | Sample Size: 34 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
KANTOR | Design: Cohort, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^56^ | Sample Size: 379 | Age/Range: NR / NR | Inclusions: Failing first line regimen | Testing: Genotypic other, NR
| Year/Range: NR | Region: US/Canada, Western Europe, Latin America, Africa, Japan, Other Asia
KARCHAVA | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2006^57^ | Sample Size: 42 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism, Nested PCR
| Year/Range: 2001-2002 | Region: US/Canada
KARCHER | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), pregnant women, adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Treatment failure
2004^58^ | Sample Size: 76 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, NR
| Year/Range: NR | Region: Africa
KIJAK | Design: Clinical trial and random sample of larger database | Population: IV drug users, and adults (NOS), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2001^59^ | Sample Size: 107 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism and probe-based system, Nested PCR
| Year/Range: 1997-2000 | Region: Latin America
KINOMOTO | Design: Case series, sample assembly NR | Population: Adults (NOS), Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
2005^60^ | Sample Size: 39 | Age/Range: NR / 30–40 | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism, Phenotypic assay
| Year/Range: 2001-2002 | Region: Africa
KONINGS | Design: Random sample of larger database | Population: Adolescents (12–18 yrs), women, Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
2004^61^ | Sample Size: 128 | Age/Range: 35 / 17–70 | Inclusions: Tx naïve | Testing: Genotypic sequence-based mechanism, Nested PCR
| Year/Range: 2000-2002 | Region: Africa
LAMA | Design: Consecutive patients | Population: Men who have sex with men, and adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^62^ | Sample Size: 375 | Age/Range: NR / NR | Inclusions: Male who had sex with a man in past year | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002-2003 | Region: Latin America
LAN | Design: Case series, sample assembly NR | Population: IV drug users, adolescents (12–18 yrs), and adults (NOS), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2003^63^ | Sample Size: 200 | Age/Range: NR / 15–52 | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001-2002 | Region: Other Asia
LARBALESTIER | Design: Cohort, sample assembly NR | Population: Pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
2003^64^ | Sample Size: 91 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism and probe-based system
| Year/Range: 1996-2001 | Region: Western Europe
LAURENT | Design: Case series, sample assembly NR | Population: Adults (NOS), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population, Treatment failure
2002^65^ | Sample Size: 58 | Age/Range: NR / NR | Inclusions: Tx naïve, High risk of AIDS progression | Testing: Genotypic sequence-based mechanism
| Year/Range: 1998-2000 | Region: Africa
LAURENT | Design: Clinical trial | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Treatment failure
2004^66^ | Sample Size: 60 | Age/Range: 35 / 29–41 | Inclusions: HIV-1 group M infection, and Age ≥ 18 years, and AIDS diagnosis, and Hemoglobin ≥ 8 g/dL, and Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 2002-2003 | Region: Africa
LAURENT | Design: Consecutive patients | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population, Treatment failure
2005^67^ | Sample Size: 176 | Age/Range: NR / NR | Inclusions: Age > 15 | Testing: Genotypic sequence-based mechanism
| Year/Range: 1998-2001 | Region: Africa
LEE | Design: Clinical trial | Population: Pregnant women, Not TX naive | Med Class: Non-NRTI | Selection: Entire population
2005^68^ | Sample Size: 32 | Age/Range: NR / NR | Inclusions: Received pMTCT | Testing: Genotypic sequence-based mechanism
| Year/Range: NR/2000-2001 | Region: Africa
LEHMAN | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2005^69^ | Sample Size: 30 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, Allele-specific RT-PCR assay
| Year/Range: NR | Region: Africa
LOUBSER | Design: Consecutive patients | Population: Pregnant women, Not TX naive | Med Class: Non-NRTI | Selection: Entire population
2006^70^ | Sample Size: 67 | Age/Range: NR / NR | Inclusions: Received pMTCT, ARV naïve prior to pregnancy | Testing: Genotypic other, Allele-specific RT-PCR assay
| Year/Range: NR | Region: Africa
LOUBSER | Design: Case series, sample assembly NR | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2005^71^ | Sample Size: NR | Age/Range: NR / NR | Inclusions: Received pMTCT | Testing: Genotypic other, Real time PCR
| Year/Range: NR | Region: Africa
LOUBSER | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2004^72^ | Sample Size: NR | Age/Range: NR / NR | Inclusions: Received pMTCT | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
LY | Design: Consecutive patients | Population: Pregnant women, and adults (NOS), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2005^73^ | Sample Size: 146 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve, Tested HIV+ in the last year | Testing: Genotypic sequence-based mechanism
| Year/Range: 2003-2004 | Region: Asia
LYONS | Design: Cohort, sample assembly NR | Population: Pregnant women, and adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^74^ | Sample Size: 39 | Age/Range: NR / 16–32 | Inclusions: > 28 weeks gestation, CD4 cell count > 300 × 106/l | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Western Europe
MACHADO | Design: Consecutive patients | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2004^75^ | Sample Size: 75 | Age/Range: 7 / 1–14 | Inclusions: Age ≤ 14 years, ARV Tx for at least 3 months | Testing: Genotypic sequence-based mechanism, Nested PCR
| Year/Range: 1999-2002 | Region: Latin America
MARCELIN | Design: Case series, sample assembly NR | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Treatment failure
2006^76^ | Sample Size: 109 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, NR
| Year/Range: 2004-2005 | Region: Africa
MARTINSON | Design: Consecutive patients | Population: Children (under 12 yrs), Not TX naive | Med Class: Non-NRTI | Selection: Entire population
2006^77^ | Sample Size: 53 | Age/Range: 1 / NR | Inclusions: > 32 weeks gestation | Testing: Genotypic sequence-based mechanism
| Year/Range: NR/2002-2003 | Region: Africa
MARTINSON | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), pregnant women, Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2004^78^ | Sample Size: NR | Age/Range: NR / NR | Inclusions: Infected during birth, Received pMTCT | Testing: Genotypic other, NR
| Year/Range: NR | Region: Africa
MATHUR | Design: Consecutive patients | Population: Children (under 12 yrs), Not Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
2005^79^ | Sample Size: 49 | Age/Range: NR / NR | Inclusions: NR | Testing: MISSING
| Year/Range: 2000 | Region: US/Canada
MCINTYRE | Design: Clinical trial | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population, Infected children
2005^80^ | Sample Size: 454 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
MILLER | Design: Clinical trial | Population: Population NR, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population, Treatment failure
2004^81^ | Sample Size: 600 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic other, NR
| Year/Range: NR | Region: US/Canada, Western Europe, Latin America
MOFENSON | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2000^82^ | Sample Size: 74 | Age/Range: NR / NR | Inclusions: Received ZDV Tx during pregnancy, CD4 < 350 | Testing: Genotypic sequence-based mechanism
| Year/Range: 1993-1997 | Region: US/Canada
MORRIS | Design: Case series, sample assembly NR | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population, Treatment failure
2003^83^ | Sample Size: 163 | Age/Range: NR / NR | Inclusions: Clade C | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
MORRIS | Design: Cohort, sample assembly NR | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2004^84^ | Sample Size: 175 | Age/Range: NR / NR | Inclusions: Infected during birth, Received pMTCT | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
MULLEN | Design: Case series, sample assembly NR | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Treatment failure
2002^85^ | Sample Size: 26 | Age/Range: NR / 0–15 | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: 1996-2000 | Region: Western Europe
NGO-GIANG-HUONG | Design: Clinical trial | Population: Children (under 12 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^86^ | Sample Size: 50 | Age/Range: NR / NR | Inclusions: Received pMTCT | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Asia
NURUTDINOVA | Design: Cohort, sample assembly NR | Population: Pregnant women, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^87^ | Sample Size: 80 | Age/Range: 37 / NR | Inclusions: NR | Testing: Genotypic other, NR
| Year/Range: 1999-2004 | Region: US/Canada
PALMER | Design: Consecutive patients | Population: Pregnant women, Not TX naive | Med Class: Non-NRTI | Selection: Entire population
2006^88^ | Sample Size: 22 | Age/Range: NR / NR | Inclusions: Received pMTCT | Testing: Genotypic sequence-based mechanism, Allele-specific RT-PCR assay
| Year/Range: NR | Region: Africa
PALMER | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2005^89^ | Sample Size: 32 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic other, Allele-specific RT-PCR assay
| Year/Range: NR | Region: Africa
PALUMBO | Design: Clinical trial | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2001^90^ | Sample Size: 244 | Age/Range: NR / NR | Inclusions: Viral load > 1000 copies/ml and Recorded AZT duration during pregnancy | Testing: Genotypic sequence-based mechanism, Nested PCR
| Year/Range: 1991-1997 | Region: US/Canada
PARK | Design: Case series, sample assembly NR | Population: IV drug users, and men who have sex with men, and adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2003^91^ | Sample Size: 50 | Age/Range: 40 / 22–71 | Inclusions: Antiretroviral naïve, Virus level > 3.0 log10 copies/ml | Testing: Genotypic sequence-based mechanism
| Year/Range: 1998-2002 | Region: Other Asia
PEREZ | Design: Clinical trial | Population: Children (under 12 yrs), adolescents (12–18 yrs), Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2001^92^ | Sample Size: 26 | Age/Range: NR / 1–17 | Inclusions: Protease Inhibitor naïve, and Viral load > log10 copies/mL | Testing: Genotypic sequence-based mechanism
| Year/Range: 1996-1999 | Region: US/Canada
PEREZ | Design: Clinical trial | Population: Pregnant women, Not Tx naïve | Med Class: Non-NRTI | Selection: Entire population
2006^93^ | Sample Size: 20 | Age/Range: NR / NR | Inclusions: Started ZDV/3TC/NVP in 2nd or 3rd trimester, ARV naïve prior to pregnancy | Testing: Genotypic sequence-based mechanism, Real time PCR
| Year/Range: NR | Region: Latin America
PETCH | Design: Case series, sample assembly NR | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^94^ | Sample Size: 21 | Age/Range: NR / NR | Inclusions: Tx naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 1996-2001 | Region: Africa
PIENIAZEK | Design: Case series, sample assembly NR | Population: Population NR, Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
2004^95^ | Sample Size: 76 | Age/Range: NR / NR | Inclusions: Tx naïve, HIV-2 infection | Testing: Genotypic other, Nested PCR
| Year/Range: 1986-1999 | Region: US/Canada, Western Europe, Latin America, Africa
PILLAY | Design: Clinical trial | Population: Pregnant women, Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2002^96^ | Sample Size: 37 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic other, Nested PCR
| Year/Range: 2000 | Region: Africa
PIRES | Design: Case series, sample assembly NR | Population: Men who have sex with men, women, Tx naïve | Med Class: NRTI, Protease inhibitor | Selection: Entire population
2004^97^ | Sample Size: 56 | Age/Range: 28 / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 2000-2002 | Region: Latin America
PUTHANAKIT | Design: Cohort, sample assembly NR | Population: Children (under 12 yrs), adolescents (12–18 yrs), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^98^ | Sample Size: 96 | Age/Range: 8 / 2–14 | Inclusions: Antiretroviral naïve, CD4 % < 15% | Testing: Genotypic other, NR
| Year/Range: 2000-2003 | Region: Asia
RICHARD | Design: Cohort, sample assembly NR | Population: Adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^99^ | Sample Size: 86 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism, Phenotypic Virologic, Nested PCR
| Year/Range: 1996-2002 | Region: Africa
RODRIGUES | Design: Consecutive patients | Population: Children (under 12 yrs), adolescents (12–18 yrs), and pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2005^100^ | Sample Size: 306 | Age/Range: NR / NR | Inclusions: Available information on ARV regimens, Clinical indication for genotype testing | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001-2003 | Region: Latin America
SAAG | Design: Clinical trial | Population: Adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Treatment failure
2004^101^ | Sample Size: 580 | Age/Range: 36 / 18–69 | Inclusions: Age ≥ 18 years, Viral load > 5,000 copies RNA/ml | Testing: Genotypic other, Nested PCR
| Year/Range: 2000-2002 | Region: US/Canada, Western Europe, Latin America and
SACHDEVA | Design: Consecutive patients | Population: Children and adults (NOS), Tx naïve | Med Class: NRTI | Selection: Entire population
2005^102^ | Sample Size: 60 | Age/Range: 31 / 1–67 | Inclusions: Antiretroviral naïve | Testing: Genotypic other, Nested PCR
| Year/Range: 2000-2002 | Region: India
SCHAPIRO | Design: Clinical trial | Population: Population NR, Not Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
2005^103^ | Sample Size: 1483 | Age/Range: NR / NR | Inclusions: ARV Tx with nucleosides, or non-nucleosides, or PIs, or Prior exposure to unboosted SQV regimen | Testing: Genotypic sequence-based mechanism, Virtual phenotype
| Year/Range: NR | Region: US/Canada, Western Europe, Australia/NZ, Latin America
SHAPIRO | Design: Clinical trial | Population: Pregnant women, Not TX naive | Med Class: Non-NRTI, NRTI | Selection: Entire population
2006^104^ | Sample Size: 709 | Age/Range: NR / 18–99 | Inclusions: Age >= 18 years, Hemoglobin >= 8 g/dL, 32 – 35 weeks gestation, Absolute neutrophil count >=1.0 X 109/L, Infant with known HIV status | Testing: Genotypic sequence-based mechanism
| Year/Range: NR/2002-2003 | Region: Africa
SITNITSKAYA | Design: Cohort, sample assembly NR | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
2001^105^ | Sample Size: 64 | Age/Range: NR / NR | Inclusions: Viral load > 1000 copies/ml, Infant with known HIV status | Testing: Genotypic sequence-based mechanism and probe-based system
| Year/Range: 1995-1999 | Region: US/Canada
SPACEK | Design: Consecutive patients | Population: Women, Not TX naive | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population, Viral load level
2006^106^ | Sample Size: 137 | Age/Range: 39 / NR | Inclusions: Continuous ARV >= 12 weeks | Testing: Genotypic sequence-based mechanism, Phenotypic assay
| Year/Range: 2003/NR-NR | Region: Africa
SUTTHENT | Design: Cohort, sample assembly NR | Population: Children (under 12 yrs), pregnant women, and adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^107^ | Sample Size: 542 | Age/Range: NR / NR | Inclusions: NR | Testing: Genotypic sequence-based mechanism
| Year/Range: 1998-2003 | Region: Asia
TANURI | Design: Convenience sample | Population: Population NR, Tx naïve | Med Class: Protease inhibitor | Selection: Entire population
1999^108^ | Sample Size: 76 | Age/Range: NR / NR | Inclusions: PI naïve | Testing: Genotypic sequence-based mechanism, Phenotypic assay
| Year/Range: 1993-1997 | Region: Latin America
TONI | Design: Case series, sample assembly NR | Population:Pregnant women, Not TX naive | Med Class: Non-NRTI | Selection: Entire population
2005^109^ | Sample Size: 29 | Age/Range: 30 / NR | Inclusions: Received pMTCT | Testing: Genotypic sequence-based mechanism
| Year/Range: NR | Region: Africa
TONI | Design: Case series, sample assembly NR | Population: Pregnant women and adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2003^110^ | Sample Size: 107 | Age/Range: 28 / NR | Inclusions: Antiretroviral naïve, and Seroconversion within 3 years | Testing: Genotypic sequence-based mechanism
| Year/Range: 2001-2002 | Region: Africa
TONI | Design: Consecutive patients | Population: Adults (NOS), Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2002^111^ | Sample Size: 99 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve, and Seroconversion within 3 years | Testing: Genotypic sequence-based mechanism, Phenotypic assay
| Year/Range: 1997-2000 | Region: Africa
TROYER | Design: Cohort, sample assembly NR | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: Non-NRTI, NRTI | Selection: Entire population
2005^112^ | Sample Size: 398 | Age/Range: NR / NR | Inclusions: Received pMTCT | Testing: Genotypic other, Radio labeled oligonuc. DNA ligation (OLA)
| Year/Range: NR | Region: Africa
VERGNE | Design: Case series, sample assembly NR | Population: Population NR, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2000^113^ | Sample Size: 142 | Age/Range: NR / NR | Inclusions: Antiretroviral naïve | Testing: Genotypic sequence-based mechanism
| Year/Range: 1995-1999 | Region: Western Europe, Africa
VERGNE | Design: Case series, sample assembly NR | Population: Adults (NOS), Not Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Random sample, Treatment failure
2003^114^ | Sample Size: 80 | Age/Range: NR / NR | Inclusions: AIDS diagnosis, and High risk of AIDS progression | Testing: Genotypic sequence-based mechanism
| Year/Range:1998-2001 | Region: Africa
WALMSLEY | Design: Clinical trial | Population: Adolescents (12–18 yrs), and adults (NOS), Not Tx naïve | Med Class: Protease inhibitor | Selection: Treatment failure, Nelfinavir treated patients with D30N and L90M mutations
2002^115^ | Sample Size: 686 | Age/Range: 38 / 19–84 | Inclusions: Plasma RNA > 400 copies/ml | Testing: Genotypic sequence-based mechanism, Phenotypic Virologic
| Year/Range: 1999 | Region: US/Canada, Western Europe, Australia/NZ, Latin America, Africa
WELLES | Design: Convenience sample | Population: Children (under 12 yrs), pregnant women, Not Tx naïve | Med Class: NRTI | Selection: Entire population
2000^116^ | Sample Size: 142 | Age/Range: NR / 24–32 | Inclusions: Received ZDV Tx during pregnancy | Testing: Genotypic sequence-based mechanism
| Year/Range: 1989-1994 | Region: US/Canada, Latin America
ZHANG | Design: Case series, sample assembly NR | Population: IV drug users, Tx naïve | Med Class: Non-NRTI, NRTI, Protease inhibitor | Selection: Entire population
2004^117^ | Sample Size: 53 | Age/Range: 40 / 14–60 | Inclusions: Antiretroviral naïve, AIDS diagnosis | Testing: Genotypic other, Nested PCR, Real time PCR
| Year/Range: NR | Region: Asia

## Reference List for Appendix D

1 Adje C, Cheingsong R, Roels TH, et al. High prevalence of genotypic and phenotypic HIV-1 drug-resistant strains among patients receiving antiretroviral therapy in Abidjan, Cote d'Ivoire. J Acquir Immune Defic Syndr. 2001;26(5):501-6. [pmid: 11391173].
2 Anaworancih J, Hirschel B, Furrer H et al. CD4-guided Scheduled Treatment Interruptions: Low Incidence of Resistance Mutations in the Staccato Trial. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
3 Ananworanich J, Sirivichayakul S, Ubolyam S, et al. Different incidence of protease resistance in patients failing treatment on an initial ritonavir-boosted saquinavir (saquinavir/r) regimen versus those with prior exposure to dual-nucleosides and unboosted saquinavir. Antivir Ther. 2005;10:S35.
4 Andrade-Villanueva J, Amador-Lara F, Ortiz-Macias X, De La Mora- Jimenez E. Primary HIV drug resistance in a referral HIV unit in Mexico. 42nd Annual Meeting of IDSA. 2004.
5 Andrade-Villanueva J, Amador-Lara F, Ortiz-Macias X, Martinez-Ortiz M, Anguiano-Torres G. Resistance mutation in treatment-experienced patients in a Mexican HIV population. 42nd Annual Meeting of IDSA. 2004.
6 Resistant HIV in breast milk. AIDS Patient Care STDS 2003; 17(4):201.
7 Averbuch D, Schapiro JM, Engelhard D, et al. Reverse transcriptase mutation M184V delays the selection of thymidine-analogue mutations in children infected with subtype-C HIV-1. Antivir Ther. 2004;9:S166.
8 Balakrishnan P, Kumarasamy N, Kantor R, et al. HIV type 1 genotypic variation in an antiretroviral treatment-naive population in southern India. AIDS Res Hum Retroviruses. 2005;21(4):301-5. [pmid: 15943572].
9 Bauer G, Pitt J, Colgrove R, et al. Phenotypic zidovudine resistance and perinatal HIV-1 transmission [abstract 711]. 8th Conference on Retroviruses and Opportunistic Infections. 2001.
10 Bessong P, Mphahlele J, Obi L, Rekosh D, Hammerskjold ML. Baseline Genetic Drug Resistance Analysis of South African HIV-1 Subtype C Proteases. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
11 Bowles E, Wensing A, van de Vijver D, Boucher C, WATCH. Global transmission of resistant HIV-1: geographical patterns may reflect differences in introduction and use of antiretroviral drugs. 16^th^ International AIDS Conference. August 11–12, 2006.
12 Brenner B, Turner D, Oliveira M, et al. A V106M mutation in HIV-1 clade C viruses exposed to efavirenz confers cross-resistance to non-nucleoside reverse transcriptase inhibitors. AIDS. 2003;17(1):F1-5. [pmid: 12478064].
13 Brindeiro PA, Brindeiro RM, Mortensen C, et al. Testing genotypic and phenotypic resistance in human immunodeficiency virus type 1 isolates of clade B and other clades from children failing antiretroviral therapy. J Clin Microbiol. 2002;40(12):4512-9. [pmid: 12454144]. [pmcid: 154623].
14 Brindeiro RM, Diaz RS, Sabino EC, et al. Brazilian Network for HIV Drug Resistance Surveillance (HIV-BResNet): a survey of chronically infected individuals. AIDS. 2003;17(7):1063-9. [pmid: 12700457].
15 Bussmann H, Novitsky V, Wester W, et al. HIV-1 subtype C drug-resistance background among ARV-naive adults in Botswana. Antivir Chem Chemother. 2005;16(2):103-15. [pmid: 15889533].
16 Carobene MG, Rubio AE, Carrillo MG, et al. Differences in frequencies of drug resistance-associated mutations in the HIV-1 pol gene of B subtype and BF intersubtype recombinant samples. J Acquir Immune Defic Syndr. 2004;35(2):207-9. [pmid: 14722457].
17 Chaix ML, Dabis F, Ekouevi D et al. Addition of 3 Days of ZDV+3TC Postpartum to a Short Course of ZDV+3TC and Single-dose NVP Provides Low Rate of VNP Resistance Mutations and High Efficacy in Preventing Peri-partum HIV-1 Transmission: ANRS DITRAME Plus, Abidjan, Cote d'Ivoire. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
18 Chaix ML, Msellati P, Rouet F et al. Efficacy of Highly Active Antiviral Therapy and Rate of Genotypic HIV-1 Drug Resistant Strains among HIV-infected Children Receiving Treatment at the Agence Nationale de Recherche sur le SIDA, in Abidjan, Cote d'Ivoire, Africa. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
19 Chaix ML, Ekouevi DK, Peytavin G, et al. Persistance of nevirapine-resistant virus and pharmacokinetic analysis in women who received intrapartum NVP associated to a short course of zidovudine (ZDV) to prevent perinatal HIV-1 transmission: the Ditrame Plus ANRS 1201/02 Study, Abidjan, Cote d'Ivoire. Antivir Ther. 2004;9:S176.
20 Chantratita W, Jenwitheesuk E, Watitpun C, et al. Prevalence of HIV-1 polymerase gene mutations in pre-treated patients in Thailand. Southeast Asian J Trop Med Public Health. 2002;33(1):80-4. [pmid: 12118466].
21 Cohen C, Nieto-Cisneros L, Zala C, et al. Comparison of atazanavir with lopinavir/ritonavir in patients with prior protease inhibitor failure: A randomized multinational trial. Curr Med Res Opin. 2005;21(10):1683-92. [pmid: 16238909].
22 Colgrove RC, Pitt J, Chung PH, Welles SL, Japour AJ. Selective vertical transmission of HIV-1 antiretroviral resistance mutations. AIDS. 1998;12(17):2281-8. [pmid: 9863870].
23 Cunningham CK, Chaix ML, Rekacewicz C, et al. Development of resistance mutations in women receiving standard antiretroviral therapy who received intrapartum nevirapine to prevent perinatal human immunodeficiency virus type 1 transmission: a substudy of pediatric AIDS clinical trials group protocol 316. J Infect Dis. 2002;186(2):181-8. [pmid: 12134253].
24 Deforche K, Camacho R, Grossman Z, et al. Interactions between nevirapine resistance mutations and NRTI resistance mutations. Antivir Ther. 2005;10:S144.
25 Delaugerre C, Cornet D, Chaix ML et al. Mechanisms of Acquisition of ART Drug-resistant Virus in HIV-1-infected Newborns in the French Perinatal Cohort (EPF-ANRS). 13th Conference on Retroviruses and Opportunisitic Infections. 2006.
26 Delgado E, Leon-Ponte M, Villahermosa ML, et al. Analysis of HIV type 1 protease and reverse transcriptase sequences from Venezuela for drug resistance-associated mutations and subtype classification: a UNAIDS study. AIDS Res Hum Retroviruses. 2001;17(8):753-8. [pmid: 11429115].
27 Deshpande A, Recordon-Pinson P, Deshmukh R, et al. Molecular characterization of HIV type 1 isolates from untreated patients of Mumbai (Bombay), India, and detection of rare resistance mutations. AIDS Res Hum Retroviruses. 2004;20(9):1032-5. [pmid: 15585093].
28 Doualla-Bell F, Avalos A, Brenner B, et al. High prevalence of the K65R mutation in human immunodeficiency virus type 1 subtype C isolates from infected patients in Botswana treated with didanosine-based regimens. Antimicrob Agents Chemother. 2006;50(12):4182-5. [pmid: 17015626]. [pmcid: 1693987].
29 Doualla-Bell F, Avalos A, Gaolathe T, et al. Frequency and patterns of specific PR mutations in Batswana subtype C patients who failed a nelfinavir-containing HAART regimen. Antivir Ther. 2005;10:S150.
30 Dumans AT, Soares MA, Pieniazek D, et al. Prevalence of protease and reverse transcriptase drug resistance mutations over time in drug-naive human immunodeficiency virus type 1-positive individuals in Rio de Janeiro, Brazil. Antimicrob Agents Chemother. 2002;46(9):3075-9. [pmid: 12183276]. [pmcid: 127402].
31 Eastman PS, Shapiro DE, Coombs RW, et al. Maternal viral genotypic zidovudine resistance and infrequent failure of zidovudine therapy to prevent perinatal transmission of human immunodeficiency virus type 1 in pediatric AIDS Clinical Trials Group Protocol 076. J Infect Dis. 1998;177(3):557-64. [pmid: 9498432].
32 Ekpini RA, Nkengasong JN, Sibailly T, et al. Changes in plasma HIV-1-RNA viral load and CD4 cell counts, and lack of zidovudine resistance among pregnant women receiving short-course zidovudine. AIDS. 2002;16(4):625-30. [pmid: 11873007].
33 Eshleman SH, Hoover DR, Hudelson SE, et al. Development of nevirapine resistance in infants is reduced by use of infant-only single-dose nevirapine plus zidovudine postexposure prophylaxis for the prevention of mother-to-child transmission of HIV-1. J Infect Dis. 2006;193(4):479-81. [pmid: 16425125].
34 Eshleman SH, Guay LA, Wang J, et al. Distinct patterns of emergence and fading of K103N and Y181C in women with subtype A vs. D after single-dose nevirapine: HIVNET 012. J Acquir Immune Defic Syndr. 2005;40(1):24-9. [pmid: 16123677].
35 Eshleman SH, Hoover DR, Chen S, et al. Nevirapine (NVP) resistance in women with HIV-1 subtype C, compared with subtypes A and D, after the administration of single-dose NVP. J Infect Dis. 2005;192(1):30-6. [pmid: 15942891].
36 Eshleman SH, Guay LA, Mwatha A, et al. Characterization of nevirapine resistance mutations in women with subtype A vs. D HIV-1 6–8 weeks after single-dose nevirapine (HIVNET 012). J Acquir Immune Defic Syndr. 2004;35(2):126-30. [pmid: 14722443].
37 Flys TS, Donnell D, Mwatha A, et al. Persistence of K103N-Containing HIV-1 Variants after Single-Dose Nevirapine for Prevention of HIV-1 Mother-to-Child Transmission. J Infect Dis. 2007;195(5):711-5. [pmid: 17262714].
38 Fuentes-Romero L, Rodriguez-Diaz RA, Viveros-Rogel M, et al. Genotypic HIV-drug resistance among newly diagnosed, never treated persons in Mexico. Antivir Ther. 2004;9:S111.
39 Gallant JE, Staszewski S, Pozniak AL, et al. Efficacy and safety of tenofovir DF vs stavudine in combination therapy in antiretroviral-naive patients: a 3-year randomized trial. JAMA. 2004;292(2):191-201. [pmid: 15249568].
40 Giuliano M, Galluzzo C, Germinario E et al. Selection of Resistance Mutations in Children Receiving Prophylaxis with Lamivudine or Nevirapine for the Prevention of Postnatal Transmission of HIV. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
41 Gordon M, Graham N, Bland R, et al. Surveillance of resistance in KZN South Africa, including mother-infant pairs 6 weeks after single-dose NVP. Antivir Ther. 2004;9:S80.
42 Han XX, Zhang M, Cui WG, et al. [Efficacy of anti-HIV treatment and drug-resistance mutations in some parts of China]. Zhonghua Yi Xue Za Zhi. 2005;85(11):760-4. [pmid: 15949383].
43 Handema R, Terunuma H, Kasolo F, et al. Prevalence of drug-resistance-associated mutations in antiretroviral drug-naive Zambians infected with subtype C HIV-1. AIDS Res Hum Retroviruses. 2003;19(2):151-60. [pmid: 12643279].
44 Hanlon M, O'Dea S, McDermott H, Woods S, Coughlan S, Mulcahy F. Evaluation of Ritonavir/Saquinavir-based Regimens in the Prevention of MTCT of HIV. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
45 Harrigan PR, Miller MD, McKenna P, Brumme ZL, Larder BA. Phenotypic susceptibilities to tenofovir in a large panel of clinically derived human immunodeficiency virus type 1 isolates. Antimicrob Agents Chemother. 2002;46(4):1067-72. [pmid: 11897591]. [pmcid: 127100].
46 Jack C, Lalloo U, Karim QA, et al. A pilot study of once-daily antiretroviral therapy integrated with tuberculosis directly observed therapy in a resource-limited setting. J Acquir Immune Defic Syndr. 2004;36(4):929-34. [pmid: 15220699].
47 Jeannin A, Pinoges L, Calmy A, et al. Clinical and virological outcomes of patients on HAART in a large-scale simplified treatment program in a rural district of Malawi. 2nd IAS Conference on HIV Pathogenesis and Treatment. 2004.
48 Jenwitheesuk E, Watitpun C, Vibhagool A, Chantratita W. Prevalence of genotypic HIV-1 drug resistance in Thailand, 2002. Ann Clin Microbiol Antimicrob. 2003;2:4. [pmid: 12657161]. [pmcid: 153426].
49 Johann-Liang R, Lee SE, Fernandez A, Cervia J, Noel GJ. Genotypic characterization of human immunodeficiency virus type 1 isolated from vertically infected children with antiretroviral therapy experience. Pediatr Infect Dis J. 2000;19(4):363-4. [pmid: 10783035].
50 Johnson JA, Li JF, Morris L, et al. Emergence of drug-resistant HIV-1 after intrapartum administration of single-dose nevirapine is substantially underestimated. J Infect Dis. 2005;192(1):16-23. [pmid: 15942889].
51 Jourdain G, Ngo-Giang-Huong N, Le Coeur S, et al. Intrapartum exposure to nevirapine and subsequent maternal responses to nevirapine-based antiretroviral therapy. N Engl J Med. 2004;351(3):229-40. [pmid: 15247339].
52 Jourdain G, Ngo-Giang-Huong N, Tungyai P et al. Exposure to Intrapartum Single-dose Nevirapine and Subsequent Maternal 6-Month Response to NNRTI-based Regimens. 11th Conference on Retroviruses and Opportunistic Infections. 2004.
53 Kamkamidze G, Sullivan T, Charbonneau T. Occurrence of HIV-1 reverse transcriptase gene mutation at codon 215 in HIV-infected infants. J Clin Virol. 2001;22(1):143-8. [pmid: 11418362].
54 Kantor R, Zijenah LS, Shafer RW, et al. HIV-1 subtype C reverse transcriptase and protease genotypes in Zimbabwean patients failing antiretroviral therapy. AIDS Res Hum Retroviruses. 2002;18(18):1407-13. [pmid: 12512512]. [pmcid: 2573400].
55 Kantor R, Lee E, Johnston E, et al. Rapid flux in non-nucleoside reverse transcriptase mutations among subtype C HIV-1-infected women after single dose nevirapine. Antivir Ther. 2003;8:S85.
56 Kantor R, DeLong A, Shafer RW, et al. Selection of resistance following first-time andti-retroviral regimens among HIV-1 subtypes. Antivir Ther. 2005;10:S146.
57 Karchava M, Pulver W, Smith L et al. Prevalence of ART Resistance Mutations in HIV Proviral DNA from Infected Infants Diagnosed in New York State, 2001-2002. 13th Conference on Retroviruses adn Opportunistic Infections. 2006.
58 Karcher H, MOses A, Weide AlL, Stelzenmueller J, Mayer A, Harms G. Evaluation of antiretroviral treatment in Fort Portal, western Uganda. 15th International AIDS Conference. International AIDS Society, 2004.
59 Kijak GH, Pampuro SE, Avila MM, et al. Resistance profiles to antiretroviral drugs in HIV-1 drug-naive patients in Argentina. Antivir Ther. 2001;6(1):71-7. [pmid: 11417764].
60 Kinomoto M, Appiah-Opong R, Brandful JA, et al. HIV-1 proteases from drug-naive West African patients are differentially less susceptible to protease inhibitors. Clin Infect Dis. 2005;41(2):252-254. [pmid: 15983924].
61 Konings FA, Zhong P, Agwara M, et al. Protease mutations in HIV-1 non-B strains infecting drug-naive villagers in Cameroon. AIDS Res Hum Retroviruses. 2004;20(1):105-9. [pmid: 15008125].
62 Lama JR, Suarez L, Laguna A, et al. A model program linking HIV resistance surveillance and sentinel HIV serosurveillance in Peru. Antivir Ther. 2005;10:S138.
63 Lan NT, Recordon-Pinson P, Hung PV, et al. HIV type 1 isolates from 200 untreated individuals in Ho Chi Minh City (Vietnam): ANRS 1257 Study. Large predominance of CRF01_AE and presence of major resistance mutations to antiretroviral drugs. AIDS Res Hum Retroviruses. 2003;19(10):925-8. [pmid: 14601592].
64 Larbalestier N, Mullen J, O'Shea S, et al. Drug resistance is uncommon in pregnant women with low viral loads taking zidovudine monotherapy to prevent perinatal HIV transmission. AIDS. 2003;17(18):2665-7. [pmid: 14685064].
65 Laurent C, Diakhate N, Gueye NFN, Toure MA, Sow PS, et al. The Senegalese government's highly active antiretroviral therapy initiative: an 18-month follow-up study. AIDS. 2002;16:1363-70. [pmid: 12131213].
66 Laurent C, Kouanfack C, Koulla-Shiro S, et al. Effectiveness and safety of a generic fixed-dose combination of nevirapine, stavudine, and lamivudine in HIV-1-infected adults in Cameroon: open-label multicentre trial. Lancet. 2004;364(9428):29-34. [pmid: 15234853].
67 Laurent C, Ngom Gueye NF, Ndour CT, et al. Long-term benefits of highly active antiretroviral therapy in Senegalese HIV-1-infected adults. J Acquir Immune Defic Syndr. 2005;38(1):14-7. [pmid: 15608518].
68 Lee EJ, Kantor R, Zijenah L, et al. Breast-milk shedding of drug-resistant HIV-1 subtype C in women exposed to single-dose nevirapine. J Infect Dis. 2005;192(7):1260-4. [pmid: 16136470].
69 Lehman DA, Chung MH, Richardson BA, John-Stewart GC, Overbaugh J. Patterns of viral load and drug resistance in breast milk and blood from women treated with single-dose nevirapine to reduce mother-to-child transmission of HIV-1. Antiviral Therapy. 2005;10:S6.
70 Loubser S, Balfe P, Sherman G, Hammer S, Kuhn L, Morris L. Decay of K103N mutants in cellular DNA and plasma RNA after single-dose nevirapine to reduce mother-to-child HIV transmission. AIDS. 2006;20(7):995-1002. [pmid: 16603851].
71 Loubser S, Balfe P, Sherman G, Hammer S, Kuhn L, Morris L. Increased sensitivity of detection of K103N resistance variants by real-time PCR in RNA and DNA after single-dose nevirapine. Antivir Ther. 2005;10:S15.
72 Loubser S, Sherman G, Chezzi C, et al. Characterization of nevirapine resistance mutations using RT-PCR and DNA sequencing methods in a mother-infant cohort following single dose nevirapine. Antivir Ther. 2004;9:S145.
73 Ly N, Recordon-Pinson P, Phoung V, et al. Characterization of mutations in HIV type 1 isolates from 144 Cambodian recently infected patients and pregnant women naive to antiretroviral drugs. AIDS Res Hum Retroviruses. 2005;21(11):971-6. [pmid: 16386116].
74 Lyons FE, Coughlan S, Byrne CM, Hopkins SM, Hall WW, Mulcahy FM. Emergence of antiretroviral resistance in HIV-positive women receiving combination antiretroviral therapy in pregnancy. AIDS. 2005;19(1):63-7. [pmid: 15627034].
75 Machado ES, Lambert JS, Watson DC, et al. Genotypic resistance and HIV-1 subtype in Brazilian children on dual and triple combination therapy. J Clin Virol. 2004;30(1):24-31. [pmid: 15072750].
76 Marcelin AG, Jarrousse B, Derache A, et al. Development of drug resistance in a sub-Saharan cohort of HIV-1-infected adult patients receiving fixed-dose combination of stavudine 30 mg/lamivudine/nevirapine as standard first-line regimen. Antivir Ther. 2006;11:S87.
77 Martinson NA, Morris L, Gray G et al. Selection and Persistence of Viral Resistance in HIV-Infected Children After Exposure to Single-Dose Nevirapine. J Acquir Immune Defic Syndr 2006.
78 Martinson N, Morris L, Gray G, et al. HIV resistance and transmission following single-dose nevirapine in a PMTCT cohort. 11th Conference on Retroviruses and Opportunistic Infection. Foundation for Retrovirology and Human Health, 2004.
79 Mathur M, Desai N, Calmus M, Gesner M, Godfrey J. Durability of lopinavir/ritonavir (LPV/RTV) based HAART as salvage therapy in a closely followed cohort of children with perinatal HIV infection. 43rd Annual Meeting of IDSA. 2005.
80 McIntyre JA, Martison N, Gray GE, et al. Single dose nevirapine combined with a short course of combivir for prevention of mother to child transmission of HIV-1 can significantly decrease the subsequent development of maternal and infant resistant virus. Antivir Ther. 2005;10:S4.
81 Miller MD, Margot NA, Waters JM, Harris J, Lu B, Cheng AK. Baseline gentypic analysis of treatment-naive patients taking tenofovir DF (TDF) or stavudine (d4T) in combination with lamivudine (3TC) and efavirenz (EFV). Antivir Ther. 2004;9:S173.
82 Mofenson L, Lambert J, Stiehm., et al. Association of ZDV genotypic resistance with perinatal HIV transmission in women receiving ZDV in pediatric AIDS Clinical Trials Group (PACTG) Protocol 185 [abstract TupPB1229]. XIII International AIDS Conference. 2000.
83 Morris L, Pillay C, Chezzi C, et al. Low frequency of the V106M mutation among HIV-1 subtype C-infected pregnant women exposed to nevirapine. AIDS. 2003;17(11):1698-700. [pmid: 12853755].
84 Morris L, Martinson N, Pillay C, et al. Persistance of nevirapine resistance mutations 6 months following single dose nevirapine. 15th International AIDS Conference. International AIDS Society, 2004.
85 Mullen J, Leech S, O'Shea S, et al. Antiretroviral drug resistance among HIV-1 infected children failing treatment. J Med Virol. 2002;68(3):299-304. [pmid: 12226814].
86 Ngo-Giang-Huong N, Jourdain G, Tungyai P et al. Infant Zidovudine Prophylaxis and Emergence of Nevirapine Resistance at 6 Weeks in Perinatally HIV-infected Infants Exposed to Intra-partum or Newborn Nevirapine. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
87 Nurutdinova D, Sungkanuparph S, Overton ET, Powderly WG. Trends in antiretroviral resistance among HIV-positive pregnant women, 1999-2004. 43rd Annual Meeting of IDSA. 2005.
88 Palmer S, Boltz V, Martinson N, et al. Persistence of nevirapine-resistant HIV-1 in women after single-dose nevirapine therapy for prevention of maternal-to-fetal HIV-1 transmission. Proc Natl Acad Sci U S A. 2006;103(18):7094-9. [pmid: 16641095]. [pmcid: 1459023].
89 Palmer S, Boltz V, Maldarelli F, et al. Short-course combivir (CBV) single dose nevirapine reduces but does not eliminate the selection of nevirapine-resistant HIV-1: improved detection by allele-specific PCR. Antivir Ther. 2005;10:S5.
90 Palumbo P, Holland B, Dobbs T, et al. Antiretroviral resistance mutations among pregnant human immunodeficiency virus type 1-infected women and their newborns in the United States: vertical transmission and clades. J Infect Dis. 2001;184(9):1120-6. [pmid: 11598834].
91 Park SW, Kim HB, Choi YJ, Kim NJ, Oh MD, Choe KW. Genotypic resistance of antiretroviral drugs among drug-naive HIV type 1 patients with the background of long-term access-easy zidovudine therapy. AIDS Res Hum Retroviruses. 2003;19(11):1039-43. [pmid: 14686324].
92 Perez EE, Rose SL, Peyser B, et al. Human immunodeficiency virus type 1 protease genotype predicts immune and viral responses to combination therapy with protease inhibitors (PIs) in PI-naive patients. J Infect Dis. 2001;183(4):579-88. [pmid: 11170983].
93 Perez H, Vignoles M, Laufer N et al. Post-partum interruption of a triple drug regimen containing Nevirapine for prevention of mother-to-child HIV transmission does not select the K103N mutation. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
94 Petch LA, Hoffman IF, Jere CS, et al. Genotypic analysis of the protease and reverse transcriptase of HIV type 1 subtype C isolates from antiretroviral drug-naive adults in Malawi. AIDS Res Hum Retroviruses. 2005;21(9):799-805. [pmid: 16218804].
95 Pieniazek D, Rayfield M, Hu DJ, et al. HIV-2 protease sequences of subtypes A and B harbor multiple mutations associated with protease inhibitor resistance in HIV-1. AIDS. 2004;18(3):495-502. [pmid: 15090802].
96 Pillay C, Bredell H, McIntyre J, Gray G, Morris L. HIV-1 subtype C reverse transcriptase sequences from drug-naive pregnant women in South Africa. AIDS Res Hum Retroviruses. 2002;18(8):605-10. [pmid: 12036490].
97 Pires IL, Soares MA, Speranza FA, et al. Prevalence of human immunodeficiency virus drug resistance mutations and subtypes in drug-naive, infected individuals in the army health service of Rio de Janeiro, Brazil. J Clin Microbiol. 2004;42(1):426-30. [pmid: 14715797]. [pmcid: 321664].
98 Puthanakit T, Oberdorfer A, Akarathum N et al. Effectiveness of NNRTI-based HAART in ART-naive HIV-infected Children Participating in Thailand's National Access Program: 72-week Result. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
99 Richard N, Juntilla M, Abraha A, et al. High prevalence of antiretroviral resistance in treated Ugandans infected with non-subtype B human immunodeficiency virus type 1. AIDS Res Hum Retroviruses. 2004;20(4):355-64. [pmid: 15157354].
100 Rodrigues R, Vazquez CM, Colares JK, et al. Antiretroviral resistance mutations in human immunodeficiency virus type 1 infected patients enrolled in genotype testing at the Central Public Health Laboratory, Sao Paulo, Brazil: preliminary results. Mem Inst Oswaldo Cruz. 2005;100(1):97-102.
101 Saag MS, Cahn P, Raffi F, et al. Efficacy and safety of emtricitabine vs stavudine in combination therapy in antiretroviral-naive patients: a randomized trial. JAMA. 2004;292(2):180-9. [pmid: 15249567].
102 Sachdeva N, Sehgal S, Arora SK. Frequency of Drug-Resistant Variants of HIV-1 Coexistent With Wild-Type in Treatment-Naive Patients of India. MedGenMed. 2005;7(3):68. [pmid: 16369294].
103 Schapiro J, Cahn P, Trottier B et al. Effect of Baseline Genotype on Response to Tipranavir/ritonavir (TPV/r) Compared with Standard-of-care Comparator (CPI/r) in Treatment-experienced Patients: The Phase 3 RESIST-1 and -2 Trials. 12th Conference on Retroviruses and Opportunistic Infections. 2005.
104 Shapiro RL, Thior I, Gilbert PB, et al. Maternal single-dose nevirapine versus placebo as part of an antiretroviral strategy to prevent mother-to-child HIV transmission in Botswana. AIDS. 2006;20(9):1281-8. [pmid: 16816557].
105 Sitnitskaya Y, Rochford G, Rigaud M, et al. Prevalence of the T215Y mutation in human immunodeficiency virus type 1-infected pregnant women in a New York cohort, 1995--1999. Clin Infect Dis. 2001;33(1):e3-7. [pmid: 11389511].
106 Spacek LA, Shihab HM, Kamya MR, et al. Response to antiretroviral therapy in HIV-infected patients attending a public, urban clinic in Kampala, Uganda. Clin Infect Dis. 2006;42(2):252-9. [pmid: 16355337].
107 Sutthent R, Arworn D, Kaoriangudom S, et al. HIV-1 drug resistance in Thailand: before and after National Access to Antiretroviral Program. J Clin Virol. 2005;34(4):272-6. [pmid: 16286051].
108 Tanuri A, Vicente AC, Otsuki K, et al. Genetic variation and susceptibilities to protease inhibitors among subtype B and F isolates in Brazil. Antimicrob Agents Chemother. 1999;43(2):253-8. [pmid: 9925514]. [pmcid: 89059].
109 Toni TD, Masquelier B, Lazaro E, et al. Characterization of nevirapine (NVP) resistance mutations and HIV type 1 subtype in women from Abidjan (Cote d'Ivoire) after NVP single-dose prophylaxis of HIV type 1 mother-to-child transmission. AIDS Res Hum Retroviruses. 2005;21(12):1031-4. [pmid: 16379606].
110 Toni TD, Recordon-Pinson P, Minga A, et al. Presence of key drug resistance mutations in isolates from untreated patients of Abidjan, Cote d'Ivoire: ANRS 1257 study. AIDS Res Hum Retroviruses. 2003;19(8):713-7. [pmid: 14506786].
111 Toni T, Masquelier B, Bonard D, et al. Primary HIV-1 drug resistance in Abidjan (Cote d'Ivoire): a genotypic and phenotypic study. AIDS. 2002;16(3):488-91. [pmid: 11834964].
112 Troyer R, Lalonde M, Kyeyune F, et al. High frequency of nevirapine resistant mutations in the HIV quasi species found in NVP-treated participants of an MTCT Ugandan cohort. Antivir Ther. 2005;10:S14.
113 Vergne L, Peeters M, Mpoudi-Ngole E, et al. Genetic diversity of protease and reverse transcriptase sequences in non-subtype-B human immunodeficiency virus type 1 strains: evidence of many minor drug resistance mutations in treatment-naive patients. J Clin Microbiol. 2000;38(11):3919-25. [pmid: 11060045]. [pmcid: 87518].
114 Vergne L, Kane CT, Laurent C, et al. Low rate of genotypic HIV-1 drug-resistant strains in the Senegalese government initiative of access to antiretroviral therapy. AIDS. 2003;17(Suppl 3):S31-8. [pmid: 14565607].
115 Walmsley S, Bernstein B, King M, et al. Lopinavir-ritonavir versus nelfinavir for the initial treatment of HIV infection. N Engl J Med. Jun. 2002;346(26):2039-46. [pmid: 12087139].
116 Welles SL, Pitt J, Colgrove R, et al. HIV-1 genotypic zidovudine drug resistance and the risk of maternal—infant transmission in the women and infants transmission study. The Women and Infants Transmission Study Group. AIDS. 2000;14(3):263-71. [pmid: 10716502].
117 Zhang M, Shang H, Han XX, et al. Study of genotypic resistance mutation to antiretroviral drugs of HIV strains of treatment-naive HIV/AIDS patients in the northeast of China. Chinese Journal of Microbiology and Immunology. 2004;24(11):850-4.