# Appendix C. Data Collection Forms

To see the Data Collection Forms, please select the link below. This link will take you to a PDF version of the forms.

Data Collection Forms