# Appendix B. Antiretroviral Drug Resistance - Search Methodology

DATABASE SEARCHED& TIME PERIOD COVERED:

PubMed - 1966-2005

OTHER LIMITERS:

HUMAN

SEARCH STRATEGIES:

SEARCH #1a (Protease Inhibitors)

amprenavir OR tipranavir OR indinavir OR saquinavir OR lopinavir OR ritonavir OR fosamprenavir OR atazanavir OR nelfinavir)

AND

resistan* OR drug resistance, viral

TOTAL OF ABOVE SEARCHES: 974

SEARCH #1B (NNRTI's)

delavirdine OR efavirenz OR nevirapine

AND

resistan* OR drug resistance, viral

NOT

Results of Search #1A

TOTAL OF ABOVE SEARCHES: 374

SEARCH #1C (NRTI's)

zidovudine OR lamivudine OR emtricitabine OR abacavir OR zalcitabine OR tenofovir OR stavudine

AND

resistan* OR drug resistance, viral

NOT

Results of previous searches

TOTAL OF ABOVE SEARCHES: 1816

SEARCH #1D (Additional Drugs)

didanosine OR enfuvirtide

AND

resistan* OR drug resistance, viral

NOT

Results of previous searches

TOTAL OF ABOVE SEARCHES: 507