# Appendix A. Technical Expert Panel Members and Peer Reviewers

## Technical Expert Panel Members

Name | Institution
David Bangsberg, MD | University of California, San Francisco
John Baxter, MD | University of Medicine & Dentistry of New Jersey
Lisa Frenkel, MD | University Washington, Seattle
David Katzenstein, MD | Stanford University
Shahin Lockman, MD | Harvard School of Public Health AIDS Initiative
Douglas Richman, MD | University of California, San Diego
Robert Shafer, MD | Stanford Medical Center
Steve Spector, MD | University of California, San Diego
Jonathan Uy, MD | University of Illinois at Chicago

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

## Peer Reviewers

Name | Institution
Eric Daar, MD | Harbor-UCLA Medical Center
Dan Kuritzkes, MD | Brigham and Women's Hospital, Harvard Medical School
Kenneth H. Mayer, MD | Brown University
William O'Brien, MD | University of Texas Medical Branch

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.