# Appendixes

Appendix A. Technical Expert Panel Members and Peer Reviewers

Appendix B. Antiretroviral Drug Resistance - Search Methodology

Appendix C. Data Collection Forms

Appendix D. Evidence Table, Resistance to Antiretroviral Drugs in Developing Regions

Appendix E. Rejected Titles