# Abbreviations

Abbreviation | Description
AA | Alcoholics Anonymous
ACF | adrenocortical functioning
Ach | acetylcholine
AEI | artery elasticity index
AHM | antihypertensive medication
AHRQ | Agency for Healthcare Research and Quality
AI | alpha index
AMI | acute myocardial infarction
APO-A1 | apolipoprotein A1
AT | autogenic training
ATN | attention
BC | blood composition
BDT | bone density test
BE | breathing exercises
BF | biofeedback
BGM | blood gass measurement
BHT | borderline hypertension
BHt | breath holding time
BL | blood lactate
BM | blood measurement
BMI | body mass index
BNP | B-type natriuretic peptide
BP | blood pressure
BR | breathing rate
bpm | beats per minute
BS | blood sugar
Ca | calcium
CABS | coronary artery bypass surgery
cAMP | cyclic adenosine monophosphate
CF | cognitive function
CHD | chronic heart disease
ChE | cholinesterase
cIMT | carotid intima media thickness
CM | carbohydrate metabolism
CMBT | contemplative meditation with breathing techniques
CNS-H | central nervous system hormone
CO | cardiac output
COG/N | cognitive/neuropsychological
COPD | chronic obstructive pulmonary disease
CPR | cold pressor response
Cr | creatinine
CRT | cognitive restructuring training
CSM | Clinically Standardized Meditation
CTY | creativity
CV | cardiovascular
CVF | cardiovascular functioning
d | day(s)
DBH | dopamine beta hydroxylase
DBP | diastolic blood pressure
DHEAS | dehydroepiandrosterone
DIG | digestive
DM | diabetes mellitus
DPV | digital pulse volume
E/A ratio | early filling divided by atrial constriction
ECG | electrocardiography
EEG | electroencephalogram
EMG | electromyography
EPC | Evidence-based Practice Center
EPI | epinephrine
ESR | erythrocyte sedimentation rate
FBS | fasting blood sugar
FEV1 | forced expiratory volume in one second
FPA | finger plethysmogram amplitude
FVC | forced vital capacity
GH | growth hormone
Glc | glucose
GLH | glycosylated hemoglobine
GSH | glutathione
GSR | galvanic skin response
Hb | hemoglobin
Hb-A1c | hemoglobin A1c
HDL-C | high-density lipoprotein cholesterol
HE | health education
HI | humoral immunity
HIV | human immunodeficiency virus
HR | heart rate
HRQL | health-related quality of life
HRV | heart rate variability
HT | hypertension
HVA | homovanillic acid
IQR | interquartile range
ITT | intention-to-treat
IVST | intraventricular septal thickness
JNC 7 | Joint National Committee 7
K | potassium
LDL-C | low-density lipoprotein cholesterol
LDH | lactate dehydrogenase
LFPMF | low frequency pulsed magnetic field
LIP | lipoproteins
LLM | lowering lipid medication
LSD | lysergic acid diethylamide
Lt | left
LVDIS | left ventricular internal dimension at systole
LVDDi | left ventricular end diastolic volume index
LVEF | left ventricular ejection fraction
LVIDD | left ventricular internal dimension at diastole
LVMI | left ventricular mass index
MBCT | mindfulness-based cognitive therapy
MBSR | mindfulness-based stress reduction
MEM | memory
MEP | maximum expiratory volume
Mg | magnesium
MHPG | 3-methoxy-4-hydroxyphenylglycol
MI | myocardial infarction
MIP | maximum inspiratory pressure
MM | mindfulness meditation
mo. | month(s)
MSK | musculoskeletal
MVV | maximal voluntary ventilation
Na | sodium
NA | not applicable
NCCAM | National Center for Complementary and Alternative Medicine
ND | not described
NE | norepinephrine
NER | nervous
NHS | National Health System
NIDDM | noninsulin dependent diabetes mellitus
N/M | nutrition/metabolism
NOS | Newcastle-Ottawa Scales
NR | not reported
NRCT | nonrandomized controlled clinical trial
NS | not specified
NT | no treatment
NYHA | New York Heart Association
OGTT | oral glucose tolerance test
OH-DOC | hydroxydeoxycorticosterone
OR | odds ratio
PAA | peak aortic acceleration
PaO_2_ | pressure of oxygen
PBI | protein bound iodine
PEF (25–75) | peak expiratory flow at piddle portion of expiration
PEFR | peak expiratory flow rate
PER | perception
PFT | pulmonary function test
PIFR | peak inspiratory flow rate
PLB | placebo
P-MDA | plasma malondialdehyde
PMR | progressive muscle relaxation
PO_2_ | pressure of oxygen
PP | pulse pressure
PPT | physical performance test
PRA | plasma renin activity
PR | pulse rate
PWT | posterior wall thickness
RA | renin activity
RCT | randomized controlled clinical trial
RER | respiratory exchange ratio
RES | respiratory
Res-v | respiratory variability
RFT | renal function test
RPP | rate pressure product
RR | relaxation Response
RSG | reasoning
RT | reaction time
Rt | right
SA | spatial ability
SAO_2_ | saturated oxygen
SBP | systolic blood pressure
S-Ca | serum calcium
SCL | skin conductance level
SD | standard deviation
se | session
SEN | sensory
SI | serum insulin
SMD | standardized mean difference
S-Mg | serum magnesium
SMF | sensory motor function
SPSS | Statistical Package for the Social Sciences
SRL | skin resistance level
SRS | Systematic Review Software
SVR | systemic vascular resistance
TC | total cholesterol
TEE | total energy expenditure
TG | triglycerides
TEP | technical expert panel
THR | thermoregulatory
TM^®^ | Transcendental Meditation^®^
TOO | Task Order Officer
TSH | thyroid stimulating hormone
TV | tidal volume
UAEPC | University of Alberta Evidence-based Practice Center
UC | usual care
UE | urinary/excretory
UFNB | unilateral forced nostril breathing
UL | urine lactate
ULNB | unilateral left nostril breathing
UNB | unilateral nostril breathing
URNB | unilateral right nostril breathing
VA | verbal ability
VCO_2_ | carbon dioxide production
Ve | minute ventilation
VE/VCO_2_ | rate of increase of ventilation per unit of increase of carbon dioxide production
VLDL-C | very low density lipoprotein cholesterol
VMA | vanillylmandelic acid
VO_2_ | oxygen consumption
VO_2_ max | maximum oxygen consumption
WBC | white blood cell
wk | week(s)
WL | waiting list
WR | work rate
WMD | weighted mean difference
yr | year(s)
Zn | zinc
5-HIAA | 5-hydroxyindole acetic acid
17-KS | 17-ketosteroids
95% CI | 95% confidence interval