# References and Included Studies

1 Walters JD. The art and science of Raja yoga: fourteen steps to higher awareness. Delhi: Motilal Banarsidass Publishers; 2002.
2 West MA. The psychosomatics of meditation. J Psychosom Res. 1980;24(5):265-73. [pmid: 7009847].
3 Perez de Albeniz A, Holmes J. Meditation: concepts, effects and uses in therapy. Int J Psychother. 2000;5(1):49-58.
4 Pollard I. Meditation and brain function: a review. Eubios J Asian Int Bioethics. 2004;14:28-34.
5 Deurr M. A powerful silence: the role of meditation and other contemplative practices in American life and work. Northampton, MA: Center for Contemplative Mind in Society; 2004.
6 Salmon PG, Santorelli SF, Kabat-Zinn J. Intervention elements promoting adherence to mindfulness-based stress reduction programs in the clinical behavioral medicine setting. In: Shumaker SA, Schron EB, Ockene JK, et al., eds. The handbook of health behavior change. 2nd ed. New York: Springer Publishing Co.; 1998. p. 239–68.
7 Baer RA. Mindfulness training as a clinical intervention: a conceptual and empirical review. Clin Psychol: Sci Pract. 2003;10(2):125-43.
8 Andresen J. Meditation meets behavioural medicine: the story of experimental research on meditation. J Consciousness Stud. 2000;7(1112):17-73.
9 Cardoso R, De Souza E, Camano L, et al. Meditation in health: an operational definition. Brain Res Brain Res Protoc. 2004;14(1):58-60. [pmid: 15519952].
10 Walsh R, Shapiro SL. The meeting of meditative disciplines and Western psychology: a mutually enriching dialogue. Am Psychol. 2006;61(3):227-39. [pmid: 16594839].
11 Craven JL. Meditation and psychotherapy. Can J Psychiatry. 1989;34(7):648-53. [pmid: 2680046].
12 Manocha R. Why meditation?. Aust Fam Physician. 2000;29(12):1135-8. [pmid: 11140217].
13 Kokoszka A. Axiological aspects of comparing psychotherapy and meditation. Int J Psychosom. 1990;37(14):78-81. [pmid: 2246110].
14 Delmonte MM. Meditation and anxiety reduction: a literature review. Clin Psychol Rev. 1985;5(2):91-102.
15 Rutschman JR. Effects of techniques of receptive meditation and relaxation on attentional processing. Can Undergraduate J Cogn Sci. 2004;7:6-16.
16 Bonadonna R. Meditation's impact on chronic illness. Holist Nurs Pract. 2003;17(6):309-19. [pmid: 14650573].
17 Caspi O, Burleson KO. Methodological challenges in meditation research. Adv Mind Body Med. 2005;21(1):4-11. [pmid: 15973854].
18 Grossman P, Niemann L, Schmidt S, et al. Mindfulness-based stress reduction and health benefits: a meta-analysis. J Psychosom Res. 2004;57(1):35-43. [pmid: 15256293].
19 Krisanaprakornkit T, Piyavhatkul N, Krisanaprakornkit W, et al. Meditation therapy for anxiety disorders. Cochrane Database Syst Rev 2004;(4).
20 Bishop SR. What do we really know about mindfulness-based stress reduction?. Psychosom Med. 2002;64(1):71-83. [pmid: 11818588].
21 Swinyard CA, Chaube S, Sutton DB. Neurological and behavioral aspects of Transcendental Meditation relevant to alcoholism: a review. Ann N Y Acad Sci. 1974;233:162-73. [pmid: 4596657].
22 Gelderloos P, Walton KG, Orme-Johnson DW, et al. Effectiveness of the Transcendental Meditation program in preventing and treating substance misuse: a review. Int J Addict. 1991;26(3):293-325. [pmid: 1889927].
23 Canter PH, Ernst E. The cumulative effects of Transcendental Meditation on cognitive function - a systematic review of randomised controlled trials. Wien Klin Wochenschr. 2003;115(2122):758-66. [pmid: 14743579].
24 Barnes VA, Schneider RH, Alexander CN, et al. Stress, stress reduction, and hypertension in African Americans: an updated review. J Natl Med Assoc. 1997;89(7):464-76. [pmid: 9220696]. [pmcid: 2568086].
25 Canter PH, Ernst E. Insufficient evidence to conclude whether or not Transcendental Meditation decreases blood pressure: results of a systematic review of randomized clinical trials. J Hypertens. 2004;22(11):2049-54. [pmid: 15480084].
26 King MS, Carr T, D'Cruz C. Transcendental Meditation, hypertension and heart disease. Aust Fam Physician. 2002;31(2):164-8. [pmid: 11917830].
27 Astin JA, Shapiro SL, Eisenberg DM, et al. Mind-body medicine: state of the science, implications for practice. J Am Board Fam Med. 2003;16(2):131-47.
28 Astin JA. Mind-body therapies for the management of pain. Clin J Pain. 2004;20(1):27-32. [pmid: 14668653].
29 Wang C, Collet JP, Lau J. The effect of tai chi on health outcomes in patients with chronic conditions: a systematic review. Arch Intern Med. 2004;164(5):493-501. [pmid: 15006825].
30 Bilkis MR, Mark KA. Mind-body medicine. Practical applications in dermatology. Arch Dermatol. 1998;134(11):1437-41. [pmid: 9828881].
31 Coker KH. Meditation and prostate cancer: integrating a mind/body intervention with traditional therapies. Semin Urol Oncol. 1999;17(2):111-8. [pmid: 10332925].
32 Woolfolk RL. Psychophysiological correlates of meditation. Arch Gen Psychiatry. 1975;32(10):1326-33. [pmid: 1180661].
33 Delmonte MM. Physiological concomitants of meditation practice. Int J Psychosom. 1984;31(4):23-36.
34 West MA, ed. The psychology of meditation. New York: Oxford University Press; 1987.
35 Bogart G. The use of meditation in psychotherapy: a review of the literature. Am J Psychiatry. 1991;45(3):383-412.
36 Hasson F, Keeney S, McKenna H. Research guidelines for the Delphi survey technique. Adv Nurs. 2000;32:1008-15.
37 Crisp J, Pelletier D, Duffield C, et al. The Delphi method?. Nurs Res. 1997;46:116-8. [pmid: 9105336].
38 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33:159-74. [pmid: 843571].
39 Seigel DG, Podgor MJ, Remaley NA. Acceptable values of kappa for comparison of two groups. Am J Epidemiol. 1992;135:571-8. [pmid: 1570823].
40 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias: dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
41 Altman D, Schulz K. Concealing treatment allocation in randomised trials. BMJ. 2001;326:446-47.
42 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
43 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
44 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses [web page]. Available at: Ottawa Health Research Institute. Research Programs. http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm. Accessed Aug 15, 2005.
45 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282:1054-60. [pmid: 10493204].
46 Cho MK, Bero LA. The quality of drug studies published in symposium proceedings. Ann Intern Med. 1996;124:485-9. [pmid: 8602706].
47 Gunaratana H. Mindfulness in plain English. Boston: Wisdom Publications; 1993.
48 Kabat-Zinn J. Full catastrophe living: using the wisdom of your body and mind to face stress, pain, and illness. New York: Dell Publishing; 1990.
49 Thomson RF. Zazen and psychotherapeutic presence. Am J Psychiatry. 2000;54(4):531-48.
50 Higgins JPT, Green S, eds. Cochrane handbook for systematic reviews of interventions 4.2.6 [updated September 2006]. In: The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2006.
51 Deeks JJ, Altman DG, Bradburn MJ. Statistical methods for examining heterogeneity and combining results from several studies in meta-analysis. In: Egger M, Smith GD, Altman DG, eds. Systematic reviews in health care: meta-analysis in context. 3rd ed. London: BMJ Publishing Group; 2001. p. 285–312.
52 Deeks J. Systematic reviews of evaluations of diagnostic and screening tests studies. In: Egger M, Smith GD, Altman D, eds. Systematic reviews in health care: meta-analysis in context. London: BMJ Books; 2001. p. 264–9.
53 Sutton AJ, Abrams KR, Jones DR, et al. Methods for meta-analysis in medical research. London: John Wiley & Sons, Ltd.; 2000.
54 Hedges LV, Olkin I. Statistical methods for meta-analysis. London: Academic Press; 1985.
55 Song F, Altman DG, Glenny AM, et al. Validity of indirect comparison for estimating efficacy of competing interventions: empirical evidence from published meta-analyses. BMJ. 2003;326(7387):472-76. [pmid: 12609941]. [pmcid: 150178].
56 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. 2004;23(2020):3105-24. [pmid: 15449338].
57 Gilks WR, Richardson S, Spiegelhalter DJ. Markov chain Monte Carlo in practice. London: Chapman & Hall; 1996.
58 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
59 Greenland S. A critical look at some popular meta-analysis methods. Am J Epidemiol. 1994;140:290-6. [pmid: 8030632].
60 Dwyer T, Couper D, Walter SD. Sources of heterogeneity in the meta-analysis of observational studies: the example of SUDS and sleeping position. J Clin Epidemiol. 2001;54:440-7. [pmid: 11337206].
61 Clarke M, Oxman AD. Cochrane reviewers' handbook 4.1 [web page]. Jun 2000; Available at: Cochrane Collaboration. http://www.cochrane.dk/cochrane/handbook/handbook.htm. Accessed May 5, 2005.
62 Shannahoff-Khalsa DS. Kundalini yoga meditation: techniques specific for psychiatric disorders, couples therapy, and personal growth. New York: W.W. Norton & Co.; 2007.
63 Duval S, Tweedie R. A non-parametric “trim and fill” method of accounting for publication bias in meta-analysis. JAMA. 2000;95:89-98.
64 Carrington P. Freedom in meditation. Garden City, NY: Anchor Press/Doubleday; 1977.
65 Kaplan S. Meditation, restoration, and the management of mental fatigue. Environ Behav. 2001;33(4):480-506.
66 Chang JC, Chiung W. Effect of meditation on music performance anxiety [dissertation]. New York: Columbia University; 2001.
67 Wang HM. Length and frequency of practice of Zen meditation and personality for meditators in Taiwan (China) [dissertation]. College Station, TX: Texas A & M University; 2000.
68 Benson H. The relaxation response. New York: William Morrow and Company, Inc.; 1975.
69 Holmes DS. Meditation and somatic arousal reduction: a review of the experimental evidence. Am Psychol. 1984;39(1):1-10. [pmid: 6142668].
70 Tloczynski J, Tantriella M. A comparison of the effects of Zen breath meditation or relaxation on college adjustment. Psychologia: Int J Psychol Orient. 1998;41(1):32-43.
71 Sri Swami Sivinanda. Concentration and meditation. 5th ed. Himalayas: The Divine Life Society; 1975.
72 Sagula DA. Varying treatment duration in a mindfulness meditation stress reduction program for chronic pain patients [dissertation]. East Lansing, MI: Michigan State University; 2000.
73 Graves LA. A theoretical framework for the use of mindfulness meditation in the practice of pastoral counseling from the perspectives of transpersonal psychology and process theology [dissertation]. Claremont, CA: Claremont School of Theology; 1999.
74 Kuna DJ. Meditation and work. Vocational Guidance Q. 1975;23(4):342-6.
75 Rios RJ. The effect of hypnosis and meditation on state and trait anxiety and locus of control [dissertation]. College Station, TX: Texas A & M University; 1979.
76 Alexander CN. Transcendental Meditation. In: Corsini RJ, ed. Encyclopedia of psychology. 2nd ed. Vol. 3. New York: John Wiley and Sons; 1994. p. 545–6.
77 Delmonte MM. Personality characteristics and regularity of meditation. Psychol Rep. 1980;46(3 Pt 1):703-12.
78 Yucel HG. The effects of the practice of the Transcendental Meditation technique and exercise on cognitive and psychophysiological measures in the elderly [dissertation]. Fairfield, IA: Maharishi International University; 2001.
79 Schneider RH, Castillo-Richmond A, Alexander CN. Behavioral treatment of hypertensive heart disease in African Americans: rationale and design of a randomized controlled trial. Behav Med. 2001;27(2):83-95. [pmid: 11763829].
80 Farrow JT, Hebert JR. Breath suspension during the Transcendental Meditation technique. Psychosom Med. 1982;44(2):133-53. [pmid: 7045911].
81 Maharishi Mahesh Yogi. Transcendental Meditation (originally titled: The science of being and art of living). New York: Penguin; 2001.
82 Maharishi Mahesh Yogi. On the Bhagavad-Gita. A new translation and commentary: chapters 1–6. Baltimore: Penguin; 1967.
83 Telles S, Desiraju T. Autonomic changes in brahmakumaris raja yoga meditation. Int J Psychophysiol. 1993;15(2):147-52. [pmid: 8244842].
84 Ferguson PC. The psychobiology of Transcendental Meditation: a review. J Altered States Consciousness. 1975;2(1):15-36.
85 Schneider RH, Alexander CN, Salerno JW, et al. Disease prevention and health promotion in the aging with a traditional system of natural medicine: Maharishi vedic medicine. J Aging Health. 2002;14(1):57-78. [pmid: 11892761]. [pmcid: 2211377].
86 Broome JRN. Stress management and organisation development: effects of Transcendental Meditation on psychological, physiological, and organisational variables at the worksite [dissertation]. Cape Town, South Africa: University of Cape Town; 1995.
87 Jedrczak A, Miller D, Antoniou M. Transcendental Meditation and health: an overview of experimental research and clinical experience. Health Promot. 1987;2(4):369-76.
88 Morse DR. An exploratory study of the use of meditation alone and in combination with hypnosis in clinical dentistry. J Am Soc Psychosom Dent Med. 1977;24(4):113-20. [pmid: 338563].
89 Benson H. The relaxation response: its subjective and objective historical precedents and physiology. Trends Neurosci. 1983;6(7):281-4.
90 Keable D. Relaxation training techniques: a review: I what is relaxation?. Br J Occup Ther. 1985;48(4):99-102.
91 Mandle CL. The use of the relaxation response with patients during femoral arteriograms [dissertation]. Newton Centre, MA: Boston College; 1988.
92 Lutz SJ. The effect of relaxation training on sleep, state anxiety, and sick call in a jail population. J Prison Jail Health. 1990;9(1):55-71.
93 Zastrow C. Using relaxation techniques with individuals and with groups. J Independent Soc Work. 1987;2(1):83-95.
94 Dusek JA, Chang BH, Zaki J. Increased nitric oxide (NO) production during the relaxation response. In: Neuroscience 2005: Society for Neuroscience 35th Annual Meeting; Washington, DC.; 2005. Program No. 57.10.
95 Bench SA. The therapeutic impact of therapist enthusiasm and scientific credibility on the relaxation response [dissertation]. Hempstead, NY: Hofstra University; 2000.
96 Greene PB. Stress reactivity, health, and meditation: a path analytic approach [dissertation]. Boston: Boston University; 2004.
97 Norton GR, Rhodes L, Hauch J. Characteristics of subjects experiencing relaxation and relaxation-induced anxiety. J Behav Ther Exp Psychiatry. 1985;16(3):211-6. [pmid: 3905864].
98 Bishop SR, Lau M, Shapiro S, et al. Mindfulness: a proposed operational definition. Clin Psychol: Sci Pract. 2004;11(3):230-41.
99 Salmon PG, Sephton SE, Weissbecker I, et al. Mindfulness meditation in clinical practice. Cogn Behav Pract. 2004;11(4):434-46.
100 Ahir DC, ed. Vipassana: a universal Buddhist meditation technique. New Delhi: Sri Satguru Publications; 1999.
101 Thera N. The heart of Buddhist meditation (satipa.t.thana). 3rd ed. London: Rider & Co.; 1962.
102 Glickman M. Beyond the breath: extraordinary mindfulness through whole-body Vipassana meditation. 1st ed. Boston: Journey Editions; 2002.
103 Kit WK. The complete book of Zen. Boston: Tuttle Publishing; 2001.
104 Omori Sogen. An introduction to Zen training: a translation of Sanzen Nyumon. Boston: Tuttle Publishing; 2001.
105 Lesko TM. The long-term effects of Zen meditation (zazen): living in the present moment and having an inner sense of direction [dissertation]. San Francisco: California School of Professional Psychology; 1999.
106 Sudsuang R, Chentanez V, Veluvan K. Effect of Buddhist meditation on serum cortisol and total protein levels, blood pressure, pulse rate, lung volume and reaction time. Physiol Behav. 1991;50(3):543-8. [pmid: 1801007].
107 Kabat-Zinn J. Mindfulness-based stress reduction (MBSR). Constructivism Hum Sci. 2003;8(2):73-107.
108 Segal ZJ, Williams MG, Teasdale JD. Mindfulness-based cognitive therapy for depression: a new approach to preventing relapse. New York: Guilford Press; 2002.
109 Feuerstein G. The yoga tradition: its history, literature, philosophy, and practice. New Delhi: Bhavana Books; 2002.
110 Brown RP, Gerbarg PL. Sudarshan kriya yogic breathing in the treatment of stress, anxiety, and depression: part I-neurophysiologic model. J Altern Complement Med. 2005;11(1):189-201. [pmid: 15750381].
111 Baker MA. The effects of hatha yoga and self-recording on trait anxiety and locus of control [dissertation]. San Diego, CA: United States International University; 1979.
112 Lohman R. Yoga techniques applicable within drug and alcohol rehabilitation programmes. Therap Communities: Int J Therap Support Organ. 1999;20(1):61-72.
113 Arias AJ, Steinberg K, Banga A, et al. Systematic review of the efficacy of meditation techniques as treatments for medical illness. J Altern Complement Med. 2006;12(8):817-32. [pmid: 17034289].
114 Collins C. Yoga: intuition, preventive medicine, and treatment. JOGN Nurs. 1998;27(5):563-8.
115 Bhagavatheeswaran R, Divarakan J, Govindan M, et al. A pilot study of a yoga meditation protocol for patients with medically refractory epilepsy. J Altern Complement Med. 2006;12(4):367-71. [pmid: 16722786].
116 Shannahoff-Khalsa DS. Patient perspectives: kundalini yoga meditation techniques for psycho-oncology and as potential therapies for cancer. Integr Cancer Ther. 2005;4(1):87-100. [pmid: 15695478].
117 Shannahoff-Khalsa DS. Kundalini yoga meditation: techniques specific for psychiatric disorders, couples therapy, and personal growth. New York: W. W. Norton & Company; 2006.
118 Williams KA, Petronis J, Smith D, et al. Effect of iyengar yoga therapy for chronic low back pain. Pain. 2005;115(12):107-17. [pmid: 15836974].
119 Iyengar BKS. Light on pranayama: the yogic art of breathing. New York: Crossroad Publishing Company; 1981.
120 Cohen L, Warneke C, Fouladi RT, et al. Psychological adjustment and sleep quality in a randomized trial of the effects of a Tibetan yoga intervention in patients with lymphoma. Cancer. 2004;100(10):2253-60. [pmid: 15139072].
121 Swami Vishnudevananda. The complete illustrated book of Yoga. New York: Bell Publishing, Inc.; 1960.
122 Wood CJ. Mood change and perceptions of vitality: a comparison of the effects of relaxation, visualization and yoga. J R Coll Gen Pract. 1993;86(5):254-8.
123 Krishna-Rao PV. Yoga: its scientific and applied aspects. Indian J Psychol. 1995;13(2):1-12.
124 Bower JE, Woolery A, Sternlieb B, et al. Yoga for cancer patients and survivors. Cancer Control. 2005;12(3):165-71. [pmid: 16062164].
125 Swami Vishnu Devananda. Meditation and mantras. New York: OM Lotus Publishing; 1981.
126 Baldwin MC. Psychological and physiological influences of hatha yoga training on healthy, exercising adults (yoga, stress, wellness) [dissertation]. Boston: Boston University; 1999.
127 Cowen VS, Adams TB. Physical and perceptual benefits of yoga asana practice: results of a pilot study. J Bodywork Movement Ther. 2005;9:211-9.
128 Shannahoff-Khalsa DS. An introduction to kundalini yoga meditation techniques that are specific for the treatment of psychiatric disorders. J Altern Complement Med. 2004;10(1):91-101. [pmid: 15025884].
129 Shannahoff-Khalsa DS. Unilateral forced nostril breathing: basic science, clinical trials, and selected advanced techniques. Subtle Energies & Energy Med J. 2001;12(2):79-106.
130 Lee GW. The subjective well-being of beginning vs advanced hatha yoga practitioners [dissertation]. Honolulu, HI: University of Hawaii; 2004.
131 Ramaratnam S, Sridharan K. Yoga for epilepsy. Cochrane Database Syst Rev 2000;(3):CD001524.
132 Shannahoff-Khalsa DS. Stress technology medicine: a new paradigm for stress and considerations for self-regulation. In: Brown M, Rivier C, Koob G, eds. Stress: neurobiology and neuroendocrinology. New York: Marcel Dekker, Inc.; 1991. p. 647–86.
133 Telles S, Joseph C, Venkatesh S. Alterations of auditory middle latency evoked potentials during yogic consciously regulated breathing and attentive state of mind. Int J Psychophysiol. 1993;14(3):189-98. [pmid: 8340237].
134 Fieldstone A. Respiration as a mediator of body temperature [dissertation]. Columbus, OH: Ohio State University; 2000.
135 Singh V, Wisniewski A, Britton J, et al. Effect of yoga breathing exercises (pranayama) on airway reactivity in subjects with asthma. Lancet. 1990;335(8702):1381-3. [pmid: 1971670].
136 Feuerstein GA. The essence of yoga: a contribution to the psychohistory of Indian civilisation. London: Rider and Company; 1974.
137 Sharma H, Sen S, Singh A. Sudarshan kriya practitioners exhibit better antioxidant status and lower blood lactate levels. Biol Psychol. 2003;63(3):281-91. [pmid: 12853172].
138 Janakiramaiah N, Gangadhar BN, Naga Venkatesha Murthy PJ. Antidepressant efficacy of sudarshan kriya yoga (SKY) in melancholia: a randomized comparison with electroconvulsive therapy (ECT) and imipramine. J Affect Disord. 2000;57(13):255-9. [pmid: 10708840].
139 Iyengar BKS. Light on yoga. London: George Allen & Unwin, Ltd.; 1966.
140 Telles S, Nagarathna R, Nagendra HR. Breathing through a particular nostril can alter metabolism and autonomic activities. Indian J Physiol Pharmacol. 1994;38(2):133-7. [pmid: 8063359].
141 Moy M. An investigation of the effectiveness of yoga and meditation upon anxiety and its implications for education [dissertation]. South Orange, NJ: Seton Hall University; 1996.
142 Sridevi K, Sitamma M, Krishna-Rao PV. Perceptual organisation and yoga training. Indian J Psychol. 1995;13(2):21-7.
143 Watts FN. Psychological research questions about yoga. Ment Health Religion Cult. 2000;3(1):71-83.
144 Werner K. Yoga and Indian philosophy. New Delhi: Motilal Banarsidass; 1977.
145 Pilkington K, Kirkwood G, Rampes H, et al. Yoga for depression: the research evidence. J Affect Disord. 2005;89(13):13-24. [pmid: 16185770].
146 Aftanas LI, Golosheykin S. Impact of regular meditation practice on EEG activity at rest and during evoked negative emotions. Int J Neurosci. 2005;115(6):893-909. [pmid: 16019582].
147 Fasko D Jr,, Grueninger RW. T'ai chi ch'uan and physical and psychological health: a review. Clin Kinesiology: J Am Kinesiotherapy Assoc. 2001;55(1):4-12.
148 Li F, Fisher KJ, Harmer P, et al. A simpler eight-form easy tai chi for elderly adults. J Aging Phys Act. 2003;11(2):206-18.
149 Yalden J, Chung L. Tai chi: towards an exercise program for the older person. Aust J Holist Nurs. 2001;8(1):4-13.
150 Hendlin SJ. T'ai chi chaun and gestalt therapy. J Contemp Psychother. 1978;10(1):25-31.
151 Lee YH. Discovering the essential power of t'ai chi ch'uan: the yin and yang of leadership [dissertation]. San Antonia TX: University of the Incarnate Word; 2002.
152 Barker L. The perceived efficacy of the mind/body fitness therapy taijiquan in improving the level of transitory feelings of anxiety [dissertation]. Columbia, SC: University of South Carolina; 2000.
153 Koh TC. Tai chi chuan. Am J Chin Med. 1981;9(1):15-22. [pmid: 7030051].
154 Lan C, Lai JS, Chen SY. Tai chi chuan - an ancient wisdom on exercise and health promotion. Sports Med. 2002;32(4):217-24. [pmid: 11929351].
155 Bonifonte P. T'ai Chi for seniors: how to gain flexibility, strength, and inner peace. Franklin Lakes, NJ: The Career Press, Inc.; 2004.
156 Ai AL, Peterson C, Gillespie B, et al. Designing clinical trials on energy healing: ancient art encounters medical science. Altern Ther Health Med. 2001;7(4):83-90. [pmid: 11452571].
157 Sancier KM. Therapeutic benefits of qigong exercises in combination with drugs. J Altern Complement Med. 1999;5(4):383-9. [pmid: 10471019].
158 Sancier KM. Medical applications of qigong. Altern Ther Health Med. 1996;2(1):40-6.
159 Ng BY. Qigong-induced mental disorders: a review. Aust N Z J Psychiatry. 1999;33(2):197-206. [pmid: 10336217].
160 Aung SKH. A brief introduction to the theory and practice of qigong. Am J Acupunct. 1994;22(4):335-48.
161 Pan W, Zhang L, Xia Y. The difference in EEG theta waves between concentrative and non-concentrative qigong states—a power spectrum and topographic mapping study. J Tradit Chin Med. 1994;14(3):212-8. [pmid: 7799657].
162 Chen KW. An analytic review of studies on measuring effects of external QI in China. Altern Ther Health Med. 2004;10(4):38-50.
163 Ai AL. Assessing mental health in clinical study on qigong: between scientific investigation and holistic perspectives. Semin Integrative Med. 2003;1(2):112-21.
164 Wang C, Yuan XY, Xu DD, et al. Brief introduction to the keep-fit qigong exercise. J Tradit Chin Med. 1986;6(4):239-42. [pmid: 3600016].
165 The problem of multiple publication. Bandolier 2001;91:91–6.
166 Tramer MR, Reynolds DJM, Moore RA, et al. Impact of covert duplicate publication on meta-analysis: a case study. BMJ. 1997;315:635-40. [pmid: 9310564]. [pmcid: 2127450].
167 Jackson K. A randomised controlled trial to evaluate the effectiveness of a mindfulness based stress reduction (MBSR) intervention as an adjunct therapy in moderate to severe psoriasis (pilot study) [unpublished data]. United Kingdom; 2004.
168 Sabina AB, Williams AL, Wall HK. Yoga intervention for adults with mild-to-moderate asthma: a pilot study. Ann Allergy Asthma Immunol. 2005;94(5):543-8. [pmid: 15945557].
169 Manocha R, Zollo M, Malhi GS. A randomized, double-blind controlled trial of meditation for work stress [unpublished data]. Randwick, UK; 2005.
170 Vahia NS, Doongaji DR, Jeste DV, et al. Psychophysiologic therapy based on the concepts of Patanjali. Am J Psychother. 1973;27:557-65. [pmid: 4761011].
171 Curtin TG. The relationship between Transcendental Meditation and adaptive regression. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1022–9.
172 Rani NJ, Rao PVK. Body awareness and yoga training. Percept Mot Skills. 1994;79(3 Pt 1):1103-6.
173 U.S. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research (CDER), et al. Guidance for industry: E 10 choice of control group and related issues in clinical trials. Rockville, MD: ICH, 2001.
174 Shannahoff-Khalsa DS, Ray LE, Levine S. Randomized controlled trial of yogic meditation techniques for patients with obsessive-compulsive disorder. CNS Spectr. 1999;4(12):34-47. [pmid: 18311106].
175 Bunk BE. Effects of hatha yoga and mantra meditation on the psychological health and behavior of incarcerated males [dissertation]. Dallas, TX: University of Texas Health Science Center; 1979.
176 Backon J, Matamoros N, Ticho U. Changes in intraocular pressure induced by differential forced unilateral nostril breathing, a technique that affects both brain hemisphericity and autonomic activity: a pilot study. Graefes Arch Clin Exp Ophtalmol. 1989;227(6):575-7.
177 Block RA, Arnott DP, Quigley B, et al. Unilateral nostril breathing influences lateralized cognitive performance. Brain Cogn. 1989;9(2):181-90. [pmid: 2923709].
178 Jella SA, Shannahoff-Khalsa DS. The effects of unilateral forced nostril breathing on cognitive performance. Int J Neurosci. 1993;73(12):61-8. [pmid: 8132419].
179 Mohan SM, Reddy S, Wei LY. Modulation of intraocular pressure by unilateral and forced unilateral nostril breathing in young healthy subjects. Int Ophthalmol. 2001;24:305-11. [pmid: 14750567].
180 Mohan SM, Wei LY. Modulation of pulse rate by unilateral nostril breathing. Indian J Psychol. 2002;20(1):32-7.
181 Sanders B, Lattimore C, Smith K. Forced single-nostril breathing and cognition. Percept Mot Skills. 1994;79(3 Pt 2):1499-506. [pmid: 7870536].
182 Saucier DM, Tessem FK, Sheerin AH. Unilateral forced nostril breathing affects dichotic listening for emotional tones. Brain Cogn. 2004;55(2):403-5. [pmid: 15177823].
183 Stancak A Jr,, Honig J, Wackermann J. Effects of unilateral nostril breathing on respiration, hearth rhythm and brain electrical activity. Neurosciences. 1991;17:409-17.
184 Rohini-Vangala-Pandey-Ravi S, Janakiramaiah N. A comparative study of full and partial sudarshan kriya yoga (SKY) in major depressive disorder. NIMHANS Journal. 2000;18(12):53-7.
185 Hafner RJ. Psychological treatment of essential hypertension: a controlled comparison of meditation and meditation plus biofeedback. Biofeedback Self Regul. 1982;7(3):305-16. [pmid: 6756484].
186 Dick LD. A study of meditation in the service of counseling [abstract]. Diss Abstr Int. 1974;34(8B):4037.
187 Ferguson PC, Gowan J. TM: some preliminary findings. J Hum Psychol. 1976;16(3):51-60.
188 Orme-Johnson DW, Moore RM. Section II: Original research on rehabilitation first prison study using the Transcendental Meditation program: La Tuna Federal Penitentiary, 1971. J Offender Rehabil. 2003;36(14):89-95.
189 Busby K, de Koninck J. Short-term effects of strategies for self-regulation on personality dimensions and dream content. Percept Mot Skills. 1980;50(3 Pt 1):751-65.
190 Puente AE. Psychophysiological investigations on Transcendental Meditation. Biofeedback Self Regul. 1981;6(3):327-42. [pmid: 7034788].
191 Zaichkowsky LD, Kamen R. Biofeedback and meditation: effects on muscle tension and locus of control. Percept Mot Skills. 1978;46(3 Pt 1):955-8. [pmid: 353698].
192 Daltroy LH, Morlino CI, Eaton HM, et al. Preoperative education for total hip and knee replacement patients. Arthritis Care Res. 1998;11(6):469-78. [pmid: 10030179].
193 Carrington P, Collings GH Jr,, Benson H, et al. The use of meditation—relaxation techniques for the management of stress in a working population. J Occup Med. 1980;22(4):221-31. [pmid: 6988553].
194 Couture RT, Singh M, Lee W, et al. The effect of mental training on the performance of military endurance tasks in the Canadian infantry. Int J Sport Psychol. 1994;25(2):144-57.
195 Kabat-Zinn J, Wheeler E, Light T, et al. Part II: Influence of a mindfulness meditation-based stress reduction intervention on rates of skin clearing in patients with moderate to severe psoriasis undergoing phototherapy (UVB) and photochemo-therapy (PUVA). Constructivism Hum Sci. 2003;8(2):85-106.
196 Wilson HB. The specific effects model: relaxation and meditation effects on cognitive and somatic anxiety [dissertation]. Columbus, OH: Ohio State University; 2000.
197 Cort DA. A comparison of compliance to group meditation, individual meditation and didactic group training in a program to help lower blood pressure in black adults [dissertation]. Tallahassee, FL: Florida State University; 1988.
198 Morse DR, Schacterle GR, Furst ML. Stress, relaxation, and saliva: a pilot study involving endodontic patients. Oral Surg Oral Med Oral Pathol. 1981;52(3):308-13. [pmid: 7027112].
199 Zeier H. Arousal reduction with biofeedback-supported respiratory meditation. Biofeedback Self Regul. 1984;9(4):497-508. [pmid: 6399464].
200 Lee MS, Huh HJ, Kim BG. Effects of qi-training on heart rate variability. Am J Chin Med. 2002;30(4):463-70. [pmid: 12568274].
201 Ryu H, Lee MS, Jeong SM. Modulation of neuroendocrinological function by psychosomatic training: acute effect of chundosunbup qi-training on growth hormone, insulin-like growth factor (Igf)-I, and insulin-like growth factor binding protein (Igfbp)-3 in men. Psychoneuroendocrinology. 2000;25(5):439-51. [pmid: 10818279].
202 Peng CK, Mietus JE, Liu Y. Exaggerated heart rate oscillations during two meditation techniques. Int J Cardiol. 1999;70(2):101-7. [pmid: 10454297].
203 Aivazyan TA, Zaitsev VP, Salenko BB, et al. Efficacy of relaxation techniques in hypertensive patients. Health Psychol. 1988;7(Suppl):193-200. [pmid: 3072179].
204 Broota A, Varma R, Singh A. Role of relaxation in hypertension. J Indian Acad Appl Psychol. 1995;21(1):29-36.
205 Calderon R Jr. Effects of nonpharmacological approaches on cholesterol levels in mild hypertensive African Americans: a pilot study of the Transcendental Meditation program and a health education program [dissertation]. Fairfield, IA: Maharishi International University; 2000.
206 Castillo-Richmond A, Schneider RH, Alexander CN, et al. Effects of stress reduction on carotid atherosclerosis in hypertensive African Americans. Stroke. 2000;31(3):568-73. [pmid: 10700487].
207 Cheung BMY, Lo JLF, Fong DYT, et al. Randomised controlled trial of qigong in the treatment of mild essential hypertension. J Hum Hypertens. 2005;19(9):697-704. [pmid: 15905884].
208 Cohen J, Sedlacek K. Attention and autonomic self-regulation. Psychosom Med. 1983;45(3):243-57. [pmid: 6351148].
209 Hager JL, Surwit RS. Hypertension self-control with a portable feedback unit or meditation-relaxation. Biofeedback Self Regul. 1978;3(3):269-76. [pmid: 365249].
210 Kondwani KA. Nonpharmacologic treatment of hypertensive heart disease in African Americans: a trial of the Transcendental Meditation program and a health education program [dissertation]. Fairfield, IA: Maharishi University of Management; 1998.
211 Kuang AK, Wang CX, Li G. Effect of qigong therapy on plasma 18-OH-DOC level in hypertensives. J Tradit Chin Med 1987;(7):169–70.
212 Latha DR, Kaliappan KV. Yoga, pranayama, thermal biofeedback techniques in the management of stress and high blood pressure. Indian J Psychol. 1991;9(12):36-46.
213 Lee MS, Lee MS, Kim HJ. Effects of qigong on blood pressure, high-density lipoprotein cholesterol and other lipid levels in essential hypertension patients. Int J Neurosci. 2004;114(7):777-86. [pmid: 15204043].
214 Lee MS, Lee MS, Kim HJ. Qigong reduced blood pressure and catecholamine levels of patients with essential hypertension. Int J Neurosci. 2003;113(12):1691-701. [pmid: 14602541].
215 Manikonda P, Stoerk S, Toegel S. Influence of non-pharmacological treatment (contemplative meditation and breathing technique) on stress induced hypertension—a randomized controlled study. Am J Hypertens. 2005;18(5):89A-90A.
216 McCaffrey R, Ruknui P, Hatthakit U. The effects of yoga on hypertensive persons in Thailand. Holist Nurs Pract. 2005;19(4):173-80. [pmid: 16006832].
217 Murugesan R, Govindarajulu N, Bera TK. Effect of selected yogic practices on the management of hypertension. Indian J Physiol Pharmacol. 2000;44(2):207-10. [pmid: 10846637].
218 Patel CH, Marmot MG, Terry DJ. Trial of relaxation in reducing coronary risk: four year follow up. BMJ (Clin Res Ed). 1985;290(6475):1103-6.
219 Patel CH, North WR. Randomised controlled trial of yoga and bio-feedback in management of hypertension. Lancet. 1975;2(7925):93-5. [pmid: 49737].
220 Schneider RH, Alexander CN, Staggers F. A randomized controlled trial of stress reduction in African Americans treated for hypertension for over one year. Am J Hypertens. 2005;18(1):88-98. [pmid: 15691622]. [pmcid: 2224896].
221 Schneider RH, Staggers F, Alexander CN. A randomised controlled trial of stress reduction for hypertension in older African Americans. Hypertension. 1995;26(5):820-7. [pmid: 7591024].
222 Seer P, Raeburn JM. Meditation training and essential hypertension: a methodological study. J Behav Med. 1980;3(1):59-71. [pmid: 6995617].
223 Tsai JC, Wang WH, Chan P, et al. The beneficial effects of tai chi chuan on blood pressure and lipid profile and anxiety status in a randomized controlled trial. J Altern Complement Med. 2003;9(5):747-54. [pmid: 14629852].
224 Van Montfrans GA, Karemaker JM, Wieling W, et al. Relaxation therapy and continuous ambulatory blood pressure in mild hypertension: a controlled study. BMJ. 1990;300(6736):1368-72. [pmid: 2196946]. [pmcid: 1662994].
225 Yen LL, Patrick WK, Chie WC. Comparison of relaxation techniques, routine blood pressure measurements, and self-learning packages in hypertension control. Prev Med. 1996;25(3):339-45. [pmid: 8781012].
226 Selvamurthy W, Sridharan K, Ray US. A new physiological approach to control essential hypertension. Indian J Physiol Pharmacol. 1998;42(2):205-13. [pmid: 10225047].
227 Stone RA, DeLeo J. Psychotherapeutic control of hypertension. N Engl J Med. 1976;294(2):80-4. [pmid: 1244504].
228 Surwit RS, Shapiro D, Good MI. Comparison of cardiovascular biofeedback, neuromuscular biofeedback, and meditation in the treatment of borderline essential hypertension. J Consult Clin Psychol. 1978;46(2):252-63. [pmid: 348731].
229 Kondwani K, Schneider RH, Alexander CN, et al. Left ventricular mass regression with the Transcendental Meditation technique and a health education program in hypertensive African Americans. J Soc Behav Pers. 2005;17(1):181-200.
230 Lee MS, Lee MS, Choi ES. Effects of qigong on blood pressure, blood pressure determinants and ventilatory function in middle-aged patients with essential hypertension. Am J Chin Med. 2003;31(3):489-97. [pmid: 12943180].
231 Lee MS, Lim HJ, Lee MS. Impact of qigong exercise on self-efficacy and other cognitive perceptual variables in patients with essential hypertension. J Altern Complement Med. 2004;10(4):675-80. [pmid: 15353025].
232 Alexander CN, Schneider RH, Staggers F, et al. Trial of stress reduction for hypertension in older African Americans II: sex and risk subgroup analysis. Hypertension. 1996;28(2):228-37. [pmid: 8707387].
233 Ades PA, Savage PD, Brochu M, et al. Resistance training increases total daily energy expenditure in disabled older women with coronary heart disease. J Appl Physiol. 2005;98(4):1280-5. [pmid: 15772059].
234 Chang BH, Hendricks A, Zhao Y, et al. A relaxation response randomized trial on patients with chronic heart failure. J Cardiopulm Rehabil. 2005;25(3):149-57. [pmid: 15931018].
235 Channer KS, Barrow D, Barrow R, et al. Changes in haemodynamic parameters following tai chi chuan and aerobic exercise in patients recovering from acute myocardial infarction. Postgrad Med J. 1996;72(848):349-51. [pmid: 8758013]. [pmcid: 2398496].
236 Curiati JA, Bocchi E, Freire JO, et al. Meditation reduces sympathetic activation and improves the quality of life in elderly patients with optimally treated heart failure: a prospective randomized study. J Altern Complement Med. 2005;11(3):465-72. [pmid: 15992231].
237 Friedman NL. Zen breath meditation awareness improves heart rate variability in patients with coronary artery disease [dissertation]. San Diego, CA: California School of Professional Psychology; 2002.
238 Jatuporn S, Sangwatanaroj S, Saengsiri AO, et al. Short-term effects of an intensive lifestyle modification program on lipid peroxidation and antioxidant systems in patients with coronary artery disease. Clin Hemorheol Microcirc. 2003;29(34):429-36. [pmid: 14724371].
239 Mahajan AS, Reddy KS, Sachdeva U. Lipid profile of coronary risk subjects following yogic lifestyle intervention. Indian Heart J. 1999;51(1):37-40. [pmid: 10327777].
240 Manchanda SC, Narang R, Reddy KS. Retardation of coronary atherosclerosis with yoga lifestyle intervention. J Assoc Physicians India. 2000;48(7):687-94. [pmid: 11273502].
241 Pool JI. Cognitive restructuring and meditation training as stress management intervention in post-cardiac adjustment [dissertation]. Bethlehem, PA: Lehigh University; 1995.
242 Quillian-Wolever RE, Gaudet T, Liebowitz R. Use of mindfulness in an integrative model of health: RCT for coronary risk prevention [abstract]. In: Society of Behavioral Medicine Annual Meeting; Boston.; 2005. p. S108.
243 Stenlund T, Lindstrom B, Granlund M. Cardiac rehabilitation for the elderly: qi gong and group discussions. Eur J Cardiovasc Prev Rehabil. 2005;12(1):5-11. [pmid: 15703500].
244 Tacon AM, McComb JJR, Caldera YM. Mindfulness meditation, anxiety reduction, and heart disease: a pilot study. Fam Community Health. 2003;26(1):25-33. [pmid: 12802125].
245 Williams KA, Kolar MM, Larkin KT, et al. Predictors of improvement in psychosocial factors in patients with coronary artery disease after participation in the mindfulness-based stress reduction program. Psychosom Med. 2001;63(1):179-80.
246 Yeh GY, Wood MJ, Lorell BH, et al. Effects of tai chi mind-body movement therapy on functional status and exercise capacity in patients with chronic heart failure: a randomized controlled trial. Am J Med. 2004;117(8):541-8. [pmid: 15465501].
247 Hipp A, Heitkamp HC, Rocker K, et al. Effects of yoga on lipid metabolism in patients with coronary artery disease. Int J Sports Med. 1998;19:S7.
248 Lan C, Chen SY, Lai JS. The effect of tai chi on cardiorespiratory function in patients with coronary artery bypass surgery. Med Sci Sports. 1999;31(5):634-8.
249 Tsai SL. Audio-visual relaxation training for anxiety, sleep, and relaxation among Chinese adults with cardiac disease. Res Nurs Health. 2004;27(6):458-68. [pmid: 15514963].
250 Yogendra J, Yogendra HJ, Ambardekar S, et al. Beneficial effects of yoga lifestyle on reversibility of ischaemic heart disease: caring heart project of International Board of Yoga. J Assoc Physicians India. 2004;52:283-9. [pmid: 15636328].
251 Young JW. Effects of a yoga intervention on symptoms of stress in individuals recovering from heart disease. Ann Ther Recreation 2001;10:13–22, 84–5, 88.
252 Zamarra JW, Schneider RH, Besseghini I, et al. Usefulness of the Transcendental Meditation program in the treatment of patients with coronary artery disease. Am J Cardiol. 1996;77(10):867-70. [pmid: 8623742].
253 Ades PA, Savage PD, Cress ME, et al. Resistance training on physical performance in disabled older female cardiac patients. Med Sci Sports. 2003;35(8):1265-70.
254 Mandle CL, Domar AD, Harrington DP. Relaxation response in femoral angiography. Radiology. 1990;174(3 Pt 1):737-9. [pmid: 2406782].
255 McComb JJR, Tacon AM, Randolph PD. A pilot study to examine the effects of a mindfulness-based stress-reduction and relaxation program on levels of stress hormones, physical functioning, and submaximal exercise responses. J Altern Complement Med. 2004;10(5):819-27. [pmid: 15650471].
256 Yeh GY, Eisenberg DM, Wood MJ, et al. Tai chi as an adjunctive intervention for patients with heart failure: a pilot study. J Gen Intern Med. 2003;18(1 Suppl):161.
257 Zamarra JW, Besseghini I, Wittenberg S. The effects of the Transcendental Meditation program on the exercise performance of patients with angina pectoris. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 270–8.
258 Alterman AI, Koppenhaver JM, Mulholland E, et al. Pilot trial of effectiveness of mindfulness meditation for substance abuse patients. J Subst Use. 2004;9(6):259-68.
259 Ballou D. The Transcendental Meditation program at Still Water prison. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 569–76.
260 Barton MJ. The effects of meditation on relaxation and spirituality on recovering alcoholics [dissertation]. Sarasota, FL: Argosy University; 2004.
261 Brautigam E. Effects of the Transcendental Meditation program on drug abusers: a prospective study. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 506–14.
262 Li M, Chen K, Mo Z. Use of qigong therapy in the detoxification of heroin addicts. Altern Ther Health Med. 1956;8(1):50-4.
263 Murphy R. The effects of mindfulness meditation vs progressive relaxation training on stress egocentrism anger and impulsiveness among inmates [dissertation]. Hempstead, NY: Hofstra University; 1995.
264 Murphy TJ, Pagano RR, Marlatt GA. Lifestyle modification with heavy alcohol drinkers: effects of aerobic exercise and meditation. Addict Behav. 1986;11(2):175-86. [pmid: 3526824].
265 Parker JC, Gilbert GS. Anxiety management in alcoholics: a study of generalized effects of relaxation techniques. Addict Behav. 1978;3(2):123-7. [pmid: 362837].
266 Raina N, Chakraborty PK, Basit MA. Evaluation of yoga therapy in alcohol dependence syndrome. Indian J Psychiatr. 2001;43(2):171-4.
267 Ramirez J. The Transcendental Meditation program as a possible treatment modality for drug offenders: evaluation of a pilot project at Milan Federal Correctional Institution. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1118–34.
268 Rohsenow DJ, Smith RE, Johnson S. Stress management training as a prevention program for heavy social drinkers: cognitions, affect, drinking, and individual differences. Addict Behav. 1985;10(1):45-54. [pmid: 3890473].
269 Shaffer HJ, LaSalvia TA, Stein JP. Comparing hatha yoga with dynamic group psychotherapy for enhancing methadone maintenance treatment: a randomized clinical trial. Altern Ther Health Med. 1997;3(4):57-66.
270 Taub E, Steiner SS, Weingarten E. Effectiveness of broad spectrum approaches to relapse prevention in severe alcoholism: a long-term, randomized, controlled trial of Transcendental Meditation, EMG biofeedback and electronic neurotherapy. Alcohol Treat Q. 1994;11(12):187-220.
271 Kline KS, Docherty EM, Farley FH. Transcendental Meditation, self/actualization, and global personality. J Gen Psychol. 1982;106(1):3-8.
272 Marcus MT, Fine PM, Kouzekanani K. Mindfulness-based meditation in a therapeutic community. J Subst Use. 2001;5(4):305-11.
273 Subrahmanyam S, Satyanarayana M, Rajeswari KR. Alcoholism: newer methods of management. Indian J Physiol Pharmacol. 1986;30(1):43-54. [pmid: 3818032].
274 Wong MR, Brochin NB, Gendron KL. Effects of meditation on anxiety and chemical dependency. J Drug Educ. 1981;11(2):91-105.
275 Marcus MT, Fine PM, Moeller FG. Change in stress levels following mindfulness-based stress reduction in a therapeutic community. Addict Disord Their Treat. 2003;2(3):63-8.
276 Gilbert GS, Parker JC, Claiborn CD. Differential mood changes in alcoholics as a function of anxiety management strategies. J Clin Psychol. 1978;34(1):229-32. [pmid: 346607].
277 Parker JC, Gilbert GS, Thoreson RW. Reduction of autonomic arousal in alcoholics: a comparison of relaxation and meditation techniques. J Consult Clin Psychol. 1978;46(5):879-86. [pmid: 359608].
278 Agrawal RP, Aradhana HS, Beniwal R, et al. Influence of yogic treatment on quality life outcomes, glycemic control and risk factors in diabetes mellitus. Int J Diab Dev Countries. 2003;23:130-4.
279 Alexander CN, Davies JL, Newman RI, et al. The effects of Transcendental Meditation on cognitive and behavioral flexibility, health and longevity in the elderly: an experimental comparison of the Transcendental Meditation program, mindfulness training, and relaxation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2295–312.
280 Blumenthal JA, Emery CF, Madden DJ, et al. Long-term effects of exercise on psychological functioning in older men and women. J Gerontol. 1991;46(6):352-61.
281 Bowman AJ, Clayton RH, Murray A, et al. Effects of aerobic exercise training and yoga on the baroreflex in healthy elderly persons. Eur J Clin Invest. 1997;27(5):443-9. [pmid: 9179553].
282 Fields JZ, Walton KG, Schneider RH, et al. Effect of a multimodality natural medicine program on carotid atherosclerosis in older subjects: a pilot trial of Maharishi vedic medicine. Am J Cardiol. 2002;89(8):952-8. [pmid: 11950434].
283 Hoffman JW, Benson H, Arns PA, et al. Reduced sympathetic nervous system responsivity associated with the relaxation response. Science. 1982;215(4529):190-2. [pmid: 7031901].
284 Peters RK, Benson H, Porter D. Daily relaxation response breaks in a working population: I effects on self-reported measures of health, performance, and well-being. Am J Pub Health. 1977;67(10):946-53. [pmid: 333957]. [pmcid: 1653745].
285 Sun WY, Dosch M, Gilmore GD. Effects of a tai chi chuan program on Hmong American older adults. Educ Gerontol. 1996;22(2):161-7.
286 Thornton EW, Sykes KS, Tang WK. Health benefits of tai chi exercise: improved balance and blood pressure in middle-aged women. Health Promot Int. 2004;19(1):33-8. [pmid: 14976170].
287 Young DR, Appel LJ, Jee S, et al. The effects of aerobic exercise and t'ai chi on blood pressure in older people: results of a randomized trial. J Am Geriatr Soc. 1999;47(3):277-84. [pmid: 10078888].
288 Pollak MH, Zeiner AR. Physiological correlates of an experimental relaxation procedure with comparisons to uninstructed relaxation and sitting. Biol Psychol Bull. 1979;5(4):161-70.
289 Abrams AI, Siegel LM. The Transcendental Meditation program and rehabilitation at Folsom State Prison: a cross-validation study. Crim Justice Behav. 1978;5(1):3-20.
290 Chen WW, Sun WY. Tai chi chuan, an alternative form of exercise for health promotion and disease prevention for older adults in the community. Int Q Community Health Educ. 1997;16(4):333-9.
291 Cooper MJ, Aygen MM. Effect of Transcendental Meditation on serum cholesterol and blood pressure. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1787–91.
292 De Armond DL. Effects of the Transcendental Meditation program on psychological, physiological, behavioral and organizational consequences of stress in managers and executives [dissertation]. Fairfield, IA: Maharishi International University; 1996.
293 Travis FT. Creative thinking and the Transcendental Meditation technique. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1972–7.
294 Damodaran A, Malathi A, Patil N, et al. Therapeutic potential of yoga practices in modifying cardiovascular risk profile in middle aged men and women. J Assoc Physicians India. 2002;50(5):633-40. [pmid: 12186115].
295 Agarwal BL, Kharbanda A. Effect of Transcendental Meditation on mild and moderate hypertension. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM- Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1815–9.
296 Jones AY, Dean E, Scudds RJ. Effectiveness of a community-based tai chi program and implications for public health initiatives. Arch Phys Med Rehabil. 2005;86(4):619-25. [pmid: 15827909].
297 Chen JC, Brown B, Schmid KL. Effect of unilateral forced nostril breathing on tonic accommodation and intraocular pressure. Clin Auton Res. 2004;14(6):396-400. [pmid: 15666068].
298 Jain SC, Uppal A, Bhatnagar SO. A study of response pattern of non-insulin dependent diabetics to yoga therapy. Diabetes Res Clin Pract. 1993;19(1):69-74. [pmid: 8472621].
299 Jones BM. Changes in cytokine production in healthy subjects practicing guolin qigong: a pilot study. BMC Complement Altern Med. 2001;1(1):8. [pmid: 11696251]. [pmcid: 59661].
300 Madanmohan, Thombre DP, Balakumar B. Effect of yoga training on reaction time, respiratory endurance and muscle strength. Indian J Physiol Pharmacol. 1992;36(4):229-33. [pmid: 1291472].
301 Manjunatha S, Vempati RP, Ghosh D. An investigation into the acute and long-term effects of selected yogic postures on fasting and postprandial glycemia and insulinemia in healthy young subjects. Indian J Physiol Pharmacol. 2005;49(3):319-24. [pmid: 16440850].
302 Schmidt TFH, Wijga AH, Robra BP, et al. Yoga training and vegetarian nutrition reduce cardiovascular risk factors in healthy Europeans. Homeost Health Dis. 1994;35(45):209-25.
303 Vijayalakshmi P, Madanmohan, Bhavanani AB, et al. Modulation of stress induced by isometric handgrip test in hypertensive patients following yogic relaxation training. Indian J Physiol Pharmacol. 2004;48(1):59-64. [pmid: 15270370].
304 Bahrke MS, Morgan WP. Anxiety reduction following exercise and meditation. Cognit Ther Res. 1978;2(4):323-33.
305 Bose S, Etta KM, Balagangadharan S. The effect of relaxing exercise ‘shavasan’. J Assoc Physicians India. 1987;35(5):365-6. [pmid: 3693289].
306 Cuthbert B, Kristeller JL, Simons R, et al. Strategies of arousal control: biofeedback, meditation, and motivation. J Exp Psychol Gen. 1981;110(4):518-46. [pmid: 6459406].
307 Jin P. Efficacy of tai chi, brisk walking, meditation, and reading in reducing mental and emotional stress. J Psychosom Res. 1992;36(4):361-70. [pmid: 1593511].
308 Monro R, Power J, Coumar A. Yoga therapy for NIDDM: a controlled trial. Complement Med Res 1992;(6):66–8.
309 Reddy KM. The role of the Transcendental Meditation programme in the promotion of athletic excellence: long- and short-term effects and their relation to activation theory. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 907–49.
310 Anantharaman RN, Kabir R. A study of yoga. J Psychol Res. 1984;28(2):97-101.
311 Benson H, Rosner BA, Marzetta BR, et al. Decreased blood pressure in borderline hypertensive subjects who practiced meditation. J Chronic Dis. 1974;27(3):163-9. [pmid: 4830843].
312 Bhargava R, Gogate MG, Mascarenhas JF. Autonomic responses to breath holding and its variations following pranayama. Indian J Physiol Pharmacol. 1988;32(4):257-64. [pmid: 3215678].
313 Joseph S, Sridharan K, Patil SK, et al. Study of some physiological and biochemical parameters in subjects undergoing yogic training. Indian J Med Res. 1981;74:120-4. [pmid: 7309176].
314 Joshi LN, Joshi VD, Gokhale LV. Effect of short term ‘pranayam’ practice on breathing rate and ventilatory functions of lung. Indian J Physiol Pharmacol. 1992;36(2):105-8. [pmid: 1506070].
315 Kocer I, Dane S, Demirel S. Unilateral nostril breathing in intraocular pressure of right-handed healthy subjects. Percept Mot Skills. 2002;95:491-6. [pmid: 12434841].
316 Lim YA, Boone T, Flarity JR. Effects of qigong on cardiorespiratory changes: a preliminary study. Am J Chin Med. 1993;21(1):1-6. [pmid: 8328418].
317 Liu S. The effects of taijiquan training on cardiorespiratory fitness, blood cholesterol, glucose and stress control in college men and women [abstract ]. Diss Abstr Int. 1996;56(9B):4764.
318 Malathi A, Parulkar VG. Effect of yogasanas on the visual and auditory reaction time. Indian J Physiol Pharmacol. 1989;33(2):110-2. [pmid: 2777359].
319 Pollack AA, Case DB, Weber MA. Limitations of Transcendental Meditation in the treatment of essential hypertension. Lancet. 1977;1(8002):71-3. [pmid: 63713].
320 Raju PS, Kumar KA, Reddy SS. Effect of yoga on exercise tolerance in normal healthy volunteers. Indian J Physiol Pharmacol. 1986;30(2):121-32. [pmid: 3818038].
321 Singh S, Malhotra V, Singh KP. Role of yoga in modifying certain cardiovascular functions in type 2 diabetic patients. J Assoc Physicians India. 2004;52:203-6. [pmid: 15636309].
322 Sung BH, Nagubandi MK, Wilson MF. Yoga breathing improves large and small artery compliance [abstract]. In: 60th Annual Scientific Conference of the American Psychosomatic Society; Barcelona, Spain.; 2002. No. 1176.
323 Telles S, Nagarathna R, Nagendra HR. Physiological changes in sports teachers following 3 months of training in yoga. Indian J Med Sci. 1993;47(10):235-8. [pmid: 8112782].
324 Fuson JW. The effect of the Transcendental Meditation program on sleeping and dreaming patterns. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 880–96.
325 Vedanthan PK, Kesavalu LN, Murthy KC, et al. Clinical study of yoga techniques in university students with asthma: a controlled study. Allergy Asthma Proc. 1998;19(1):3-9. [pmid: 9532318].
326 Lan C, Lai JS, Chen SY. 12-month tai chi training in the elderly: its effect on health fitness. Med Sci Sports. 1998;30(3):345-51.
327 Ross PA. Sorting out the concept disorder. Theoret Med Bioeth. 2005;26:115-40. [pmid: 15971894].
328 Orenstein RE. The techniques of meditation and their implications for modern psychology. In: Naranjo C, Orenstein RE, eds. On the psychology of meditation. New York: Viking Press; 1971.
329 Wittgenstein L. Philosophical investigations. Oxford: Basil Blackwell; 1968.
330 Rosch EH. Natural categories. Cognit Psychol. 1973;4:328-50.
331 Boyd R. How to be a moral realist. In: Sayre-McCord G, ed. Essays on moral realism. Ithaca, NY: Cornell University Press; 1988. p. 180–228.
332 Boyd R. Homeostasis, species, and higher taxa. In: Wilson RA, ed. Species: new interdisciplinary essays. Cambridge, MA: MIT Press; 1999. p. 141–85.
333 Wilson RA. Realism, essence, and kind: resuscitating species essentialism? In: Wilson RA, ed. Species: new interdisciplinary essays. Cambridge, MA: MIT Press; 1999. p. 187–207.
334 Koshikawa F, Ichii M. An experiment on classification methods of meditation methods: on procedures, goals and effects. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Delft, Netherlands: Eburon; 1996. p. 213–24.
335 Naranjo C. Meditation: its spirit and techniques. In: Naranjo C, Orenstein RE, ed. On the psychology of meditation. New York: Viking Press; 1971. p. 2–132.
336 Haruki Y, Ishii I, Suzuli M, eds. Comparative and psychological study on meditation; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996.
337 Khalsa SB. Yoga as a therapeutic intervention: a bibliometric analysis of published research studies. Indian J Physiol Pharmacol. 2004;48(3):269-85. [pmid: 15648399].
338 Gotzsche P. Multiple publication of reports of drug trials. Eur J Clin Pharmacol. 1989;36:429-32. [pmid: 2666138].
339 Kassirer JP, Angell M. Redundant publication: a reminder. NEJM. 1995;333(7):449-50. [pmid: 7616995].
340 Committee on publication ethics (COPE). Guidelines on good publication practice: the COPE report 2003. Indian J Pharmacol 2005;37(3):199–203.
341 Linde K, Jonas WB, Melchart D, et al. The methodological quality of randomised controlled trials of homeopathy, herbal medicine and acupuncture. Int J Epidemiol. 2001;30:526-31. [pmid: 11416076].
342 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials: the CONSORT statement. JAMA. 1996;276(8):637-9. [pmid: 8773637].
343 Nahin R, Strauss SE. Research into complementary and alternative medicine: problems and potential. BMJ. 2001;322(7279):161-4. [pmid: 11159578]. [pmcid: 1119420].
344 Brown MB. Control groups appropriate for surgical interventions: ethical and practical issues. Gastroenterology. 2004;126(1):S164-8. [pmid: 14978655].
345 Whitehead WE. Control groups appropriate for behavioral interventions. Gastroenterology. 2004;126(1):S159-63. [pmid: 14978654].
346 Walach H. The efficacy paradox in randomized controlled trials of CAM and elsewhere: beware of the placebo trap. J Altern Complement Med. 2001;7(3):213-18. [pmid: 11439833].
347 Thorne S, Best A, Balon J, et al. Ethical dimensions in the borderland between conventional and complementary/alternative medicine. J Altern Complement Med. 2002;8(6):907-15. [pmid: 12614541].
348 Fabrega H. Medical validity in eastern and western traditions. Perspect BioI Med. 2002;45(3):395-415.
349 Moerman DE, Jonas WB. Deconstructing the placebo effect and finding the meaning response. Ann Intern Med. 2002;136(6):471-6. [pmid: 11900500].
350 Juni P, Altman DG, Egger M. Assessing the quality of randomized controlled trials. Egger M, Smith GD, Altman DG, ed. Systematic reviews in health care. Meta-analysis in context. London: BMJ Publishing Group; 2001. p. 87–109.
351 Juni P, Altman DG, Egger M. Systematic reviews in health care: Assessing the quality of controlled clinical trials. BMJ. 2001;323(7303):42-6. [pmid: 11440947]. [pmcid: 1120670].
352 Ernst E. The role of complementary and alternative medicine. BMJ. 2000;321(7269):1133-5. [pmid: 11061738]. [pmcid: 1118903].
353 Miller FG, Emanuel EJ, Rosenstein DL, et al. Ethical issues concerning research in complementary and alternative medicine. JAMA. 2004;291(5):599-604. [pmid: 14762039].
354 Walsh RN. Meditation research: an introduction and review. J Transpersonal Psychol. 1979;11(2):161-74.
355 Murray CJL, Lopez A. The Global Burden of Disease: a comprehensive assessment of mortality and disability from diseases, injuries, and risk factors in 1990 and projected to 2020. Cambridge, MA: Harvard University Press; 1996.
356 Michaud CC, McKeena MT, Begg S, et al. The burden of disease and injury in the United States. Popul Health Metr. 2004;4:11.
357 Walton KG, Schneider RH, Nidich SI, et al. Psychosocial stress and cardiovascular disease part 2: effectiveness of the Transcendental Meditation program in treatment and prevention. Behav Med. 2002;28(3):106-23. [pmid: 16463759].
358 Alexander CN, Robinson P, Rainforth M. Treating and preventing alcohol, nicotine, and drug abuse through Transcendental Meditation: a review and statistical meta-analysis. Alcohol Treat Q. 1994;11(12):13-87.
359 Klein PJ, Adams WD. Comprehensive therapeutic benefits of taiji: a critical review. Am J Phys Med Rehabil. 2004;83(9):735-45. [pmid: 15314540].
360 Han A, Robinson V, Judd M, et al. Tai chi for treating rheumatoid arthritis. Cochrane Database Syst Rev 2004;(3):CD004849.
361 Taylor-Piliae RE, Froelicher ES. Effectiveness of tai chi exercise in improving aerobic capacity: a meta-analysis. J Cardiovasc Nurs. 2004;19(1):48-57. [pmid: 14994782].
362 Verhagen AP, Immink M, van der Meulen A, et al. The efficacy of tai chi chuan in older adults: a systematic review. Fam Pract. 2004;21(1):107-13. [pmid: 14760055].
363 Kirkwood G, Rampes H, Tuffrey V, et al. Yoga for anxiety: a systematic review of the research evidence. Br J Sports Med. 2005;39:884-91. [pmid: 16306493]. [pmcid: 1725091].
364 Chen K, Yeung R. A review of Qigong therapy for cancer treatment. J Int Soc Life Info Sci (ISLIS). 2002;20(2):532-42.
365 Mandle, Jacobs SC, Arcari PM, et al. The efficacy of relaxation response interventions with adult patients: a review of the literature. J Cardiovasc Nurs. 1996;10(3):4-26. [pmid: 8820317].
366 Alexander CN, Rainforth MV, Gelderloos P. Transcendental Meditation, self-actualization, and psychological health: a conceptual overview and statistical meta-analysis. J Soc Behav Pers. 1991;6(5):189-248.
367 Higgins JPT, Thompson SG, Deeks JJ. Measuring inconsistency in meta-analyses. BMJ. 2003;327:557-60. [pmid: 12958120]. [pmcid: 192859].
368 Herbert RD, Bo K. Analysis of quality of interventions in systematic reviews. BMJ. 2005;331:507-9. [pmid: 16141160]. [pmcid: 1199036].
369 Kuchera MM. The effectiveness of meditation techniques to reduce blood pressure levels: a meta-analysis [abstract]. Diss Abstr Int. 1987;47(11B):4639.
370 Schultz KF. Assessing allocation concealment and blinding in randomised controlled trials: why bother. Evid Based Ment Health. 2000;3(11):4-5.
371 ACP Online. A primer on before/after studies: evaluating a report of a “successful intervention”[web page]. Sep 1999–31 Oct 1999; Available at: http://www.acponline.org/journals/ecp/primers/sepoct99.htm. Accessed Jan 28, 2007.
372 Assendelft WJ, Scholten RJ, van Eijk JT, et al. [The practice of systematic reviews. III. Evaluation of methodological quality of research studies]. Ned Tijdschr Geneeskd. 1999;143(14):714-19. [pmid: 10347625].
373 Cook DJ, Sackett DL, Spitzer WO. Methodologic guidelines for systematic reviews of randomized control trials in health care from the Potsdam Consultation on Meta-Analysis. J Clin Epidemiol. 1995;48(1):167-71. [pmid: 7853043].
374 Lohr KN, Carey TS. Assessing ‘best evidence’: issues in grading the quality of studies for systematic reviews. Joint Commission Journal On Quality Improvement. 1999;25(9):470-9. [pmid: 10481816].
375 Moher D, Pham B, Jones A, et al. Does the quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9139):609-13. [pmid: 9746022].
376 Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16(1):62-73. [pmid: 7743790].
377 Vickers A, Cassileth B, Ernst E, et al. How should we research unconventional therapies? A report from the conference on complementary and alternative medicine research methodology, National Institute of Health. Int J Technol Assess Health Care. 1997;13(1):111-21. [pmid: 9119619].
378 Moja LP, Telaro E, D'Amico R, et al. Assessment of methodological quality of primary studies by systematic reviews: results of the metaquality cross sectional study. BMJ. 2005;330(7499):1053-7. [pmid: 15817526]. [pmcid: 557223].
379 West MA. Meditation and the EEG. Psychol Med. 1980;10(2):369-75. [pmid: 6992184].
380 Moher D, Pham, Klassen T, et al. What contributions do languages other than English make on the results of meta-analysis?. J Clin Epidemiol. 2000;53(9):964-72. [pmid: 11004423].
381 Arias A, Steinberg K, Banga A, et al. Systematic review of the efficacy of meditation techniques as treatments for medical illness. J Altern Complement Med. 2006;12(8):817-32. [pmid: 17034289].
382 Caspi O, Millen C, Sechrest L. Integrity and research: introducing the concept of dual blindness. How blind are double-blind clinical trials in alternative medicine?. J Altern Complement Med. 2000;6(6):493-8. [pmid: 11152053].
383 Rowe G, Wright G, Bolger F. Delphi: a reevaluation of research and theory. Technol Forecast Soc. 1991;39:235-51.
384 Anderson VL, Levinson EM, Barker W, et al. The effects of meditation on teacher perceived occupational stress, state and trait anxiety, and burnout. Sch Psychol Q. 1999;14(1):3-25.
385 Barnes VA, Treiber FA, Turner JR, et al. Acute effects of Transcendental Meditation on hemodynamic functioning in middle-aged adults. Psychosom Med. 1999;61(4):525-31. [pmid: 10443761].
386 Speca M, Carlson LE, Goodey E. A randomized,wait-list controlled clinical trial: the effect of a mindfulness meditation-based stress reduction program on mood and symptoms of stress in cancer outpatients. Psychosom Med. 2000;62(5):613-22. [pmid: 11020090].
387 Chang JC, Midlarsky E, Lin P. Effects of meditation on music performance anxiety. Med Probl Perform Art. 2003;18(3):126-30.
388 Chen K. The effects of tai chi on the well-being of community-dwelling elders in Taiwan [dissertation]. Minneapolis, MN: University of Minnesota; 2000.
389 Cusumano JA, Robinson SE. The short-term psychophysiological effects of hatha yoga and progressive relaxation on female Japanese students. Appl Psychol: Int Rev. 1993;42(1):77-90.
390 Daubenmier JJ. A comparison of hatha yoga and aerobic exercise on women's body satisfaction [dissertation]. Berkeley, CA: University of California; 2002.
391 Mustian KM. Breast cancer, tai chi chuan, and self-esteem: a randomized trial [dissertation]. Greensboro, NC: The University of North Carolina; 2003.
392 Delmonte MM. Physiological responses during meditation and rest. Biofeedback Self Regul. 1984;9(2):181-200. [pmid: 6391562].
393 Delmonte MM. Suggestibility and meditation. Psychol Rep. 1981;48(3):727-37.
394 Berger BG, Friedmann E, Eaton M. Comparison of jogging, the relaxation response, and group interaction for stress reduction. J Sport Exerc Psychol. 1988;10(4):431-47.
395 Gaston L, Crombez JC, Lassonde M, et al. Psychological stress and psoriasis: experimental and prospective correlational studies. Acta Der Venerol Suppl. 1991;156:37-43.
396 Goodale IL, Domar AD, Benson H. Alleviation of premenstrual syndrome symptoms with the relaxation response. Obstet Gynecol. 1990;75(4):649-55. [pmid: 2179779].
397 Wolf SL, Sattin RW, O'Grady M, et al. A study design to investigate the effect of intense tai chi in reducing falls among older adults transitioning to frailty. Control Clin Trials. 2001;22(6):689-704. [pmid: 11738125].
398 Irwin MR, Pike JL, Cole JC, et al. Effects of a behavioral intervention, tai chi chih, on varicella-zoster virus specific immunity and health functioning in older adults. Psychosom Med. 2003;65(5):824-30. [pmid: 14508027].
399 Jevning RA, Wilson AF, O'Halloran JP. Forearm blood flow and metabolsim during stylized and unstylized states of decreased activation. Am J Physiol. 1983;245:R110-6. [pmid: 6869572].
400 Jevning RA, Wilson AF, Smith WR. Transcendental Meditation technique, adrenocortical activity, and implications for stress. Experientia. 1978;34(5):618-9. [pmid: 350603].
401 Jevning RA, Wilson AF, Smith WR. Redistribution of blood flow in acute hypermetabolic behavior. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1548–54.
402 Gross CR, Kreitzer MJ, Russas V, et al. Mindfulness meditation to reduce symptoms after organ transplant: a pilot study. Adv Mind Body Med. 2004;20(2):20-9.
403 Kristeller JL, Quillian-Wolever RE, Sheets V. Mindfulness-based eating awareness training (MB-EAT): an innovative treatment for compulsive eating and obesity [abstract]. In: Society of Behavioral Medicine Annual Meeting; Boston.; 2005. p. S108.
404 Latha DR, Kaliappan KV. Efficacy of yoga therapy in the management of headaches. Indian J Psychol. 1992;10(12):41-7.
405 Lee MS, Huh HJ, Jeong SM. Effects of qigong on immune cells. Am J Chin Med. 2003;31(2):327-35. [pmid: 12856872].
406 Lee SW, Mancuso CA, Charlson ME. Prospective study of new participants in a community-based mind-body training program. J Gen Intern Med. 2004;19(7):760-5. [pmid: 15209590]. [pmcid: 1492489].
407 MacLean CR, Walton KG, Wenneberg SR. Effects of the Transcendental Meditation program on adaptive mechanisms: changes in hormone levels and responses to stress after 4 months of practice. Psychoneuroendocrinology. 1997;22(4):277-95. [pmid: 9226731].
408 Li F, Harmer P, Chaumeton NR. Tai chi as a means to enhance self-esteem: a randomized controlled trial. J Appl Gerontol. 2002;21(1):70-89.
409 Li F, Harmer P, Fisher KJ. Tai chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2005;60(2):187-94. [pmid: 15814861].
410 Lukoff DG, Wallace CJ, Liberman RP. A holistic program for chronic schizophrenic patients. Schizophr Bull. 1986;12(2):274-82. [pmid: 3520804].
411 Malathi A, Damodaran A, Shah N. Self-actualization and practice of yoga. NIMHANS Journal. 1999;17(1):39-44.
412 Mason LI. Electrophysiological correlates of higher states of consciousness during sleep [dissertation]. Fairfield, IA: Maharishi International University; 1995.
413 McGibbon CA, Krebs DE, Parker SW. Tai chi and vestibular rehabilitation improve vestibulopathic gait via different neuromuscular mechanisms: preliminary report. BMC Neurol 2005;5(3).
414 Nakao M, Myers P, Fricchione GL. Somatization and symptom reduction through a behavioral medicine intervention in a mind/body medicine clinic. Behav Med. 2001;26(4):169-76. [pmid: 11409219].
415 Narendran S, Nagarathna R, Narendran V. Efficacy of yoga on pregnancy outcome. J Altern Complement Med. 2005;11(2):237-44. [pmid: 15865489].
416 O'Halloran JP, Jevning RA, Wilson AF. Hormonal control in a state of decreased activation: potentiation of arginine vasopressin secretion. Physiol Behav. 1985;35(4):591-5. [pmid: 3906711].
417 Panjwani U, Selvamurthy W, Singh SH. Effect of sahaja yoga meditation on auditory evoked potentials (AEP) and visual contrast sensitivity (VCS) in epileptics. Appl Psychophysiol Biofeedback. 2000;25(1):1-12. [pmid: 10832506].
418 Pelletier KR. The effects of the Transcendental Meditation program on perceptual style: increased field independence. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 337–45.
419 Robinson FP, Mathews HL, Witek-Janusek L. Psycho-endocrine-immune response to mindfulness-based stress reduction in individuals infected with the human immunodeficiency virus: a quasiexperimental study. J Altern Complement Med. 2003;9(5):683-94. [pmid: 14629846].
420 Sagula DA, Rice KG. The effectiveness of mindfulness training on the grieving process and emotional well-being of chronic pain patients. J Clin Psychol Med Settings. 2004;11(4):333-42.
421 Lynch GV. Patient variables associated with treatment completion in a mindfulness meditation-based stress reduction (MBSR) treatment for fibromyalgia: implications for prescriptive matching and participation enhancement [dissertation]. Louisville, KY: University of Lousiville; 2004.
422 Shafil M, Lavely R, Jaffe R. Meditation and the prevention of alcohol abuse. Am J Psychiatry. 1975;132(9):942-5. [pmid: 1155631].
423 Shapiro SL. Mindfulness-based stress reduction and breast cancer [dissertation]. Tempe, AZ: University of Arizona; 2002.
424 Smith JC. Personality correlates of continuation and outcome in meditation and erect sitting control treatments. J Consult Clin Psychol. 1978;46(2):272-9. [pmid: 348733].
425 Taggart HM. Effects of tai chi exercise on balance, functional mobility, and fear of falling among older women. Appl Nurs Res. 2002;15(4):235-42. [pmid: 12444582].
426 Murata T, Takahashi T, Hamada T. Individual trait anxiety levels characterizing the properties of Zen meditation. Neuropsychobiology. 2004;50(2):189-94. [pmid: 15292676].
427 Teasdale JD, Segal ZV, Williams JM. Prevention of relapse/recurrence in major depression by mindfulness-based cognitive therapy. J Consult Clin Psychol. 2000;68(4):615-23. [pmid: 10965637].
428 Tebecis AK. A controlled study of the EEG during Transcendental Meditation: comparison with hypnosis. Folia Psychiatr Neurol Jpn. 1975;29(4):305-13. [pmid: 783025].
429 Throll DA. Transcendental Meditation and progressive relaxation: their physiological effects. J Clin Psychol. 1982;38(3):522-30. [pmid: 7050179].
430 Tiefenthaler T, Grossman P. Buddhist psychology's potential contribution to psychosomatic medicine: evidence from a mindfulness program for fibromyalgia [abstract]. In: 60th Annual Scientific Conference of the American Psychosomatic Society; Barcelona, Spain.; 2002. No. 1636.
431 Wagstaff GF, Brunas-Wagstaff J, Cole J, et al. Facilitating memory with hypnosis, focused meditation, and eye closure. Int J Clin Exp Hypn. 2004;52(4):434-55. [pmid: 15590510].
432 Wang JS, Lan C, Chen SY, et al. Tai chi chuan training is associated with enhanced endothelium-dependent dilation in skin vasculature of healthy older men. J Am Geriatr Soc. 2002;50(6):1024-30. [pmid: 12110061].
433 Maclean CRK. Mechanisms relating stress reduction and health: changes in neuroendocrine responses to laboratory stress after four months of Transcendental Meditation [dissertation]. Fairfield, IA: Maharishi International University; 1995.
434 Wolf DB, Abell N. Examining the effects of meditation techniques on psychosocial functioning. Res Soc Work Pract. 2003;13(1):27-42.
435 Yan JH. Tai chi practice improves senior citizens' balance and arm movement control. J Aging Phys Act. 1998;6(3):271-84.
436 Abrams AI. Paired-associate learning and recall: a pilot study of the Transcendental Meditation program. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 377–81.
437 Adler P, Good M, Roberts B, et al. The effects of Tai Chi on older adults with chronic arthritis pain. J Nurs Scholarship. 2000;32(4):377.
438 Alexander CN. Ego development, personality and behavioral change in inmates practicing the Transcendental Meditation technique or participating in other programs: a cross-sectional and longitudinal study [abstract]. Diss Abstr Int. 1982;43(2B):539.
439 Alexander CN, Orme-Johnson DW. Walpole study of the Transcendental Meditation program in maximum security prisoners II: longitudinal study of development and psychopathology. J Offender Rehabil. 2003;36(14):127-60.
440 Alexander CN, Swanson GC, Rainforth MV, et al. Effects of the Transcendental Meditation program on stress reduction, health, and employee development: a prospective study in two occupational settings. Anxiety Stress Coping: Int J. 1993;6(3):245-62.
441 Alexander CN, Walton KG, Goodman RS. Walpole study of the Transcendental Meditation program in maximum security prisoners I: cross-sectional differences in development and psychopathology. J Offender Rehabil. 2003;36(14):97-125.
442 Altman KER. A brief therapy model to reduce stress by practicing breathing exercises, mindful meditation, and yoga stretching [dissertation]. Chicago: Capella University; 2000.
443 Andersen DT. Empathy, attachment, meditation, and mental health [dissertation]. Garden City, NY: Adelphi University; 2000.
444 Arcari PM. Efficacy of a workplace smoking cessation program: mindfulness meditation vs cognitive-behavioral interventions [dissertation]. Boston: Boston University; 1996.
445 Armstrong WJ, Smedley JMS. Effects of a home-based yoga exercise program on flexibility in older women. Clin Kinesiology: J Am Kinesiotherapy Assoc. 2003;57(1):1-6.
446 Aron EN, Aron A. Transcendental Meditation program and marital adjustment. Psychol Rep. 1982;51(3 Pt 1):887-90. [pmid: 6761733].
447 Astin JA. Stress reduction through mindfulness meditation: effects on psychological symptomatology, sense of control, and spiritual experiences. Psychother Psychosom. 1997;66(2):97-106. [pmid: 9097338].
448 Astin JA, Berman BM, Bausell B, et al. The efficacy of mindfulness meditation plus qigong movement therapy in the treatment of fibromyalgia: a randomized controlled trial. J Rheumatol. 2003;30(10):2257-62. [pmid: 14528526].
449 Badawi K, Wallace RK, Orme-Johnson DW, et al. Electrophysiologic characteristics of respiratory suspension periods occurring during the practice of the Transcendental Meditation program. Psychosom Med. 1984;46(3):267-76. [pmid: 6377350].
450 Banquet JP, Haynes CT, Hebert JR. Analysis of sleep in altered states of consciousness by classical EEG and coherence spectra. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 835–6.
451 Banquet JP, Haynes CT, Hebert JR. Sleep and dream in altered states of consciousness. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 836–40.
452 Banquet JP, Sailhan M. Quantified EEG spectral analysis of sleep and Transcendental Meditation. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 182–6.
453 Barnes VA. Reduced cardiovascular and all-cause mortality in older African Americans practicing the Transcendental Meditation [dissertation]. Fairfield, IA: Maharishi International University; 1996.
454 Beauchamp-Turner DL, Levinson DM. Effects of meditation on stress, health, and affect. Med Psychother: Int J. 1992;5:123-31.
455 Becht AC. The effectiveness of deep muscle relaxation with positive imagery and cognitive meditative therapy in treatment of stress resulting from subjective continuous tinnitus in hearing adults [abstract]. Diss Abstr Int. 1982;43(6B):1968.
456 Becker DE, Shapiro D. Physiological responses to clicks during Zen, yoga, and TM meditation. Psychophysiology. 1981;18(6):694-9. [pmid: 7031742].
457 Beddoe AE, Murphy SO. Does mindfulness decrease stress and foster empathy among nursing students?. J Nurs Educ. 2004;43(7):305-12. [pmid: 15303583].
458 Bennett JE, Trinder J. Hemispheric laterality and cognitive style associated with Transcendental Meditation. Psychophysiology. 1977;14(3):293-6. [pmid: 323902].
459 Benson H, Alexander S, Feldman CL. Decreased premature ventricular contractions through use of the relaxation response in patients with stable ischaemic heart-disease. Lancet. 1975;2(7931):380-2. [pmid: 51189].
460 Benson H, Frankel FH, Apfel R, et al. Treatment of anxiety: a comparison of the usefulness of self-hypnosis and a meditational relaxation technique: an overview. Psychother Psychosom. 1978;30(34):229-42. [pmid: 368852].
461 Berger BG, Owen DR. Mood alteration with yoga and swimming: aerobic exercise may not be necessary. Percept Mot Skills. 1992;75(3 Pt 2):1331-43. [pmid: 1484805].
462 Berger BG, Owen DR. Stress reduction and mood enhancement in four exercise modes: swimming, body conditioning, hatha yoga, and fencing. Res Q Exerc Sport. 1988;59(2):148-59.
463 Berker E. Stability of skin resistance responses one week after instruction in the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 243–7.
464 Berman BM, Singh BB. Chronic low back pain: an outcome analysis of a mind-body intervention. Complement Ther Med. 1997;5(1):29-35.
465 Bernardi L, Passino C, Wilmerding V, et al. Breathing patterns and cardiovascular autonomic modulation during hypoxia induced by simulated altitude. J Hypertens. 2001;19(5):947-58. [pmid: 11393679].
466 Berrettini RB. The effects of the Transcendental Meditation program on short-term recall performance. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 975–82.
467 Bhatti T, Gillin J, Atkinson J, et al. T'ai chi chih as a treatment for chronic low back pain: a randomized, controlled study. Altern Ther. 1998;4(2):90-1.
468 Birkel DA, Edgren L. Hatha yoga: improved vital capacity of college students. Altern Ther Health Med. 2000;6(6):55-63.
469 Boes R. Mothers' adjustment after childbirth: examining effects of the mother baby program of Maharishi vedic approach to health on maternal postpartum health and recovery (Maharishi vedic science) [dissertation]. Fairfield, IA: Maharishi International University; 1999.
470 Bond DS, Lyle RM, Tappe MK, et al. Moderate aerobic exercise, t'ai chi, and social problem-solving ability in relation to psychological stress. Int J Stress Manage. 2002;9(4):329-43.
471 Bosmajian LS. Role of expectancy and pretreatment personality in subjects' self-actualizing changes while practicing Transcendental Meditation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1099–107.
472 Boswell PC, Murray EJ. Effects of meditation on psychological and physiological measures of anxiety. J Consult Clin Psychol. 1979;47(3):606-7. [pmid: 393736].
473 Boyle CA, Sayers SP, Jensen BE, et al. The effects of yoga training and a single bout of yoga on delayed onset muscle soreness in the lower extremity. J Strength Cond Res. 2004;18(4):723-9. [pmid: 15574074].
474 Brach AW. Clinical applications of meditation: a treatment outcome evaluation study of an intervention for binge eating among the obese that combines formal meditation and contingent formal and informal meditation [dissertation]. Santa Barbara, CA: The Fielding Graduate Institute; 1990.
475 Bradley BW, McCanne TR. Autonomic responses to stress: the effects of progressive relaxation, the relaxation response, and expectancy of relief. Biofeedback Self Regul. 1981;6(2):235-51. [pmid: 7020779].
476 Brandon JE, Eason RL, Warren B, et al. Training meditation and behavioral relaxation techniques. Health Values Achieving High Level Wellness. 1986;10(2):3-8.
477 Brandon JE, Poppen R. A comparison of behaviorial, meditation, and placebo control relaxation training procedures. Health Educ 1985;16(5):42–6,33.
478 Brooks JS, Scarano T. Transcendental Meditation in the treatment of post-Vietnam adjustment. J Couns Dev. 1985;64(3):212-5.
479 Brown D, Forte M, Dysart M. Differences in visual sensitivity among mindfulness meditators and non-meditators. Percept Mot Skills. 1984;58(3):727-33. [pmid: 6382144].
480 Brown DR, Wang Y, Ward A, et al. Chronic psychological effects of exercise and exercise plus cognitive strategies. Med Sci Sports. 1995;27(5):765-75.
481 Brown LL, Robinson SE. The relationship between meditation and/or exercise and three measures of self-actualization. J Ment Health Counc. 1993;15(1):85-93.
482 Bruckstein DC. Effects of acceptance-based and cognitive behavioral interventions on chronic pain management [dissertation]. Hempstead, NY: Hofstra University; 1999.
483 Bruning NS, Frew DR. Effects of exercise, relaxation, and management skills training on physiological stress indicators: a field experiment. J Appl Psychol. 1987;72(4):515-21. [pmid: 3316168].
484 Carr-Kaffashan L, Woolfolk RL. Active and placebo effects in treatment of moderate and severe insomnia. J Consult Clin Psychol. 1979;47(6):1072-80. [pmid: 41856].
485 Carson JW, Carson KM, Gil KM, et al. Mindfulness-based relationship enhancement. Behav Ther. 2004;35(3):471-94.
486 Cartwright R, Butters E, Weinstein M, et al. The effects of presleep stimuli of different sources and types on REM sleep. Psychophysiology. 1977;14(4):388-92. [pmid: 196307].
487 Chandler HM. Transcendental Meditation and awakening wisdom: a 10-year longitudinal study of self-development [dissertation]. Fairfield, IA: Maharishi International University; 1990.
488 Chang VY, Palesh O, Caldwell R, et al. The effects of a mindfulness-based stress reduction program on stress, mindfulness self-efficacy, and positive states of mind. Stress Health. 2004;20(3):141-7.
489 Christou EA, Yang Y, Rosengren KS. Taiji training improves knee extensor strength and force control in older adults. J Gerontol A Biol Sci Med Sci. 2003;58(8):763-6. [pmid: 12902537].
490 Clancy CP. Coping with intrusive thoughts and worries: what strategies work best? [dissertation]. Greensboro, NC: University of North Carolina; 2003.
491 Clay CC, Lloyd UK, Walker JL, et al. The metabolic cost of hatha yoga. J Strength Cond Res. 2005;19(3):604-10. [pmid: 16095417].
492 Cohen J. A preliminary investigation on time perception and autonomic self-regulation. Biofeedback Self Regul. 1981;6(3):289-93. [pmid: 7034787].
493 Cohen-Katz J, Wiley SD, Capuano T, et al. The effects of mindfulness-based stress reduction on nurse stress and burnout, part II: a quantitative and qualitative study. Holist Nurs Pract. 2005;19(1):26-35. Erratum in: Holist Nurs Pract 2005 Mar–Apr;19(2):78. [pmid: 15736727].
494 Colby F. An analogue study of the initial carryover effects of meditation, hypnosis, and relaxation using native college students. Biofeedback Self Regul. 1991;16(2):157-65. [pmid: 1854860].
495 Compton WC, Becker GM. Self-actualizations and experience with Zen meditation: is a learning period necessary for meditation?. J Clin Psychol. 1983;39(6):925-9. [pmid: 6363452].
496 Connell DM. The relationship between siddha meditation and stress in psychotherapists: a transcriptional perspective [dissertation]. Santa Barbara, CA: Fielding Graduate Institute; 1996.
497 Cooper AE. An investigation of the relationships among spirituality, prayer and meditation, and aspects of stress and coping [dissertation]. Berkeley, CA: Wright Institute; 2003.
498 Corby JC, Roth WT, Zarcone VP Jr,, et al. Psychophysiological correlates of the practice of tantric yoga meditation. Arch Gen Psychiatry. 1978;35(5):571-7. [pmid: 365124].
499 Corey PW. Airway conductance and oxygen consumption changes associated with practice of the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 94–107.
500 Cowger EL, Torrance EP. Further examination of the quality of changes in creative functioning resulting from meditation (zazen) training. Creative Child Adult Q. 1982;7(4):211-7.
501 Cranson RW, Orme-Johnson DW, Gackenbach J, et al. Transcendental Meditation and improved performance on intelligence-related measures: a longitudinal study. Pers Individ Dif. 1991;12(10):1105-16.
502 Creamer P, Singh BB, Hochberg MC, et al. Sustained improvement produced by nonpharmacologic intervention in fibromyalgia: results of a pilot study. Arthritis Care Res. 2000;13(4):198-204. [pmid: 14635274].
503 Credidio SG. Comparative effectiveness of patterned biofeedback vs meditation training on EMG and skin temperature changes. Behav Res Ther. 1982;20(3):233-41. [pmid: 7046724].
504 Crowe RL. Time perception and hassles appraisal in beginning meditators and non-meditators [dissertation]. New York: New York University; 1989.
505 Cunningham M, Koch W. The Transcendental Meditation program and rehabilitation: a pilot project at the federal correctional institution at Lompoc, California. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 562–7.
506 Currey MD III. Meditation, cognitive appraisal, and coping: a study of the influence of meditation on stress [dissertation]. Santa Babara, CA: Fielding Graduate Institute; 1993.
507 Curry NA, Kasser T. Can coloring mandalas reduce anxiety?. Art Ther. 2005;22(2):81-5.
508 Curtis WD, Wessberg HW. A comparison of heart rate, respiration, and galvanic skin response among meditators, relaxers, and controls. J Altered States Consciousness 1975-1976;2(4):319–24.
509 Daniels D. Comparison of the Transcendental Meditation technique to various relaxation procedures. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 864–8.
510 Datey KK, Deshmukh SN, Dalvi CP, et al. “Shavasan”: a yogic exercise in the management of hypertension. Angiology. 1969;20(6):325-33. [pmid: 5789748].
511 Davidson RJ, Goleman DJ, Schwartz GE. Attentional and affective concomitants of meditation: a cross-sectional study. J Abnorm Psychol. 1976;85(2):235-8. [pmid: 1254784].
512 Davidson RJ, Kabat-Zinn J, Schumacher J, et al. Alterations in brain and immune function produced by mindfulness meditation. Psychosom Med. 2003;65(4):564-70. [pmid: 12883106].
513 Dayton T, Boles DB. No difference in cerebral hemispheric asymmetry of meditators as opposed to nonmeditators. Bull Psychon Soc. 1990;28(3):211-4.
514 de Lone ST. The psychological effect of movement meditation as a self-control strategy for stress management [dissertation]. Philadelphia: Temple University; 1985.
515 Deckro GR, Ballinger KM, Hoyt M, et al. The evaluation of a mind/body intervention to reduce psychological distress and perceived stress in college students. J Am Coll Health. 2002;50(6):281-7. [pmid: 12701653].
516 DeMayo W, Singh BB, Duryea B, et al. Hatha yoga and meditation in patients with post-polio syndrome. Altern Ther Health Med. 2004;10(2):24-5. [pmid: 15055090].
517 Diebold JC. Mindfulness in the machine: a mindfulness-based cognitive therapy for the reduction of driving anger [dissertation]. Hempstead, NY: Hofstra University; 2003.
518 Dillbeck MC. Meditation and flexibility of visual perception and verbal problem solving. Mem Cognit. 1982;10(3):207-15.
519 Dillbeck MC, Bronson EC. Short-term longitudinal effects of the Transcendental Meditation technique on EEG power and coherence. Int J Neurosci. 1981;14(34):147-51. [pmid: 7030999].
520 Dillbeck MC, Vesely SA. Participation in the Transcendental Meditation program and frontal EEG coherence during concept learning. Int J Neurosci. 1986;29(12):45-55. [pmid: 3516902].
521 Domar AD, Noe JM, Benson H. The preoperative use of the relaxation response with ambulatory surgery patients. Hosp Top. 1987;65(4):30-5.
522 Domino G. Transcendental Meditation and creativity: an empirical investigation. J Appl Psychol. 1977;62(3):358-62. [pmid: 324968].
523 Duncan L, Weissenburger D. Effects of a brief meditation program on well-being and loneliness. TCA Journal. 2003;31(1):4-14.
524 Eisen AR, Rapee RM, Barlow DH. The effects of breathing rate and pCO-sub-2 levels on relaxation and anxiety in a non-clinical population. J Anxiety Disord. 1990;4(3):183-90.
525 Eisenberg DM, Landsberg L, Allred EN, et al. Inability to demonstrate physiologic correlates of subjective improvement among patients taught the relaxation response. J Gen Intern Med. 1991;6(1):64-70. [pmid: 1999748].
526 Elson BD, Hauri P, Cunis D. Physiological changes in yoga meditation. Psychophysiology. 1977;14(1):52-7. [pmid: 319471].
527 Engelman SR, Clance PR, Imes S. Self and body-cathexis change in therapy and yoga groups. J Am Soc Psychosom Dent Med. 1982;29(3):77-88. [pmid: 6958667].
528 English EH, Baker TB. Relaxation training and cardiovascular response to experimental stressors. Health Psychol. 1983;2(3):239-59.
529 Farge EJ, Hartung GH, Borland CM. Runners and meditators: a comparison of personality profiles. J Pers Assess. 1979;43(5):501-3. [pmid: 16367026].
530 Fasko D, Hall G, Osborne MR, et al. Comeditation—an exploratory study of pulse and respiration rates and anxiety. Percept Mot Skills. 1992;74(3):895-904. [pmid: 1608727].
531 Fee RA, Girdano DA. The relative effectiveness of three techniques to induce the trophotropic response. Biofeedback Self Regul. 1978;3(2):145-57. [pmid: 356900].
532 Fehrer FC. The awareness response: a transpersonal approach to reducing maladaptive emotional reactivity [dissertation]. Palo Alto, CA: Institute of Transpersonal Psychology; 2002.
533 Ferguson RE. The Transcendental Meditation program at Massachusetts Correctional Institution Walpole: an evaluaton report. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1146–52.
534 Fergusson LC. Field independence, Transcendental Meditation, and achievement in college art: a reexamination. Percept Mot Skills. 1993;77(3 Pt 2):1104-6. [pmid: 8170755].
535 Fergusson LC. Field independence and art achievement in meditating and nonmeditating college students. Percept Mot Skills. 1992;75(3 Pt 2):1171-5. [pmid: 1484781].
536 Fiedler N, Vivona VE, Gochfeld M. Evaluation of a work site relaxation training program using ambulatory blood pressure monitoring. J Occup Med. 1989;31(7):595-602. [pmid: 2671313].
537 Fling S, Thomas A, Gallaher M. Participant characteristics and the effects of two types of meditation vs quiet sitting. J Clin Psychol. 1981;37(4):784-90.
538 Floyd WT III, Haynes J. The influence of Transcendental Meditation on anxiety. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1037–9.
539 Kindlon DJ. Comparison of use of meditation and rest in treatment of test anxiety. Psychol Rep. 1983;53(3 Pt 1):931-8. [pmid: 6361836].
540 Frumkin LR, Pagano RR. The effect of Transcendental Meditation on iconic memory. Biofeedback Self Regul. 1979;4(4):313-22. [pmid: 393303].
541 Galantino MLA. Blending traditional and alternative strategies for rehabilitation: measuring functional outcomes and quality of life issues in an AIDS population [dissertation]. Philadelphia: Temple University; 1997.
542 Galantino MLA, Bzdewka TM, Eissler-Russo JL, et al. The impact of modified hatha yoga on chronic low back pain: a pilot study. Altern Ther Health Med. 2004;10(2):56-9.
543 Garfinkel MS, Schumacher HR Jr,, Husain A, et al. Evaluation of a yoga based regimen for treatment of osteoarthritis of the hands. J Rheumatol. 1994;21(12):2341-3. [pmid: 7699639].
544 Garfinkel MS, Singhal A, Katz WA, et al. Yoga-based intervention for carpal tunnel syndrome: a randomized trial. JAMA. 1998;280(18):1601-3. [pmid: 9820263].
545 Gaylord C, Orme-Johnson DW, Travis FT. The effects of the Transcendental Meditation technique and progressive muscle relaxation on EEG coherence, stress reactivity, and mental health in black adults. Int J Neurosci. 1989;46(12):77-86. [pmid: 2670798].
546 Gelderloos P, Beto ZH. The Transcendental Meditation and TM-sidhi program and reported experiences of transcendental consciousness. Psychologia: Int J Psychol Orient. 1989;32(2):91-103.
547 Gelderloos P, Goddard PH, Ahlstrom HH, et al. Cognitive orientation toward positive values in advanced participants of the TM and TM-sidhi program. Percept Mot Skills. 1987;64(3 Pt 1):1003-12.
548 Gelderloos P, Hermans HJ, Ahlscrom HH, et al. Transcendence and psychological health: studies with long-term participants of the Transcendental Meditation and TM-Sidhi program. J Psychol. 1990;124(2):177-97. [pmid: 2187979].
549 Ghoncheh S, Smith JC. Progressive muscle relaxation, yoga stretching, and ABC relaxation theory. J Clin Psychol. 2004;60(1):131-6. [pmid: 14692015].
550 Gillani NB, Smith JC. Zen meditation and ABC relaxation theory: an exploration of relaxation states, beliefs, dispositions, and motivations. J Clin Psychol. 2001;57(6):839-46. [pmid: 11344469].
551 Glaser JL, Brind JL, Vogelman JH, et al. Elevated serum dehydroepiandrosterone sulfate levels in practitioners of the Transcendental Meditation (TM) and TM-sidhi programs. J Behav Med. 1992;15(4):327-41. [pmid: 1404349].
552 Goddard PH. Transcendental Meditation as an intervention in the aging of neurocognitive function: reduced age-related declines of P300 latencies in elderly practitioners [ dissertation]. Fairfield, IA: Maharishi International University; 1992.
553 Goldenberg DL, Kaplan KH, Nadeau MG, et al. A controlled study of a stress-reduction, cognitive-behavioral treatment program in fibromyalgia. J Musculoskeletal Pain. 1994;2(2):53-66.
554 Goldman BL, Dormitor PJ, Murray EJ. Effects of Zen meditation on anxiety reduction and perceptual functioning. J Consult Clin Psychol. 1979;47(3):551-6. [pmid: 393735].
555 Goleman DJ, Schwartz GE. Meditation as an intervention in stress reactivity. J Consult Clin Psychol. 1976;44(3):456-66. [pmid: 777059].
556 Goodman M, Owens J, Plews-Ogan ML, et al. Treating chronic pain: a randomized trial of mindfulness based stress reduction, massage and usual care. J Gen Intern Med. 2004;19(1 Suppl):229. [pmid: 15009777]. [pmcid: 1492148].
557 Gore SW, Abrams AI, Ellis GA. The effect of statewide implementation of the Maharishi technology of the unified field in the Vermont Department of Corrections. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2453–64.
558 Green RG, Green ML. Relaxation increases salivary immunoglobulin A. Psychol Rep. 1987;61(2):623-9. [pmid: 3324145].
559 Greendale GA, McDivit A, Carpenter A, et al. Yoga for women with hyperkyphosis: results of a pilot study. Am J Pub Health. 2002;92(10):1611-4. [pmid: 12356608]. [pmcid: 1447294].
560 Griggs ST. A preliminary study into the effect of Transcendental Meditation on empathy. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1051–7.
561 Gupta NC. Effects of Transcendental Meditation on anxiety and self-concept. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1046–50.
562 Haber D. Yoga as a preventive health care program for white and black elders: an exploratory study. Int J Aging Hum Dev. 1983;17(3):169-76. [pmid: 6671816].
563 Hahn HR, Whalen TE. The effects of the Transcendental Meditation program on levels of hostility, anxiety, and depression. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1030–6.
564 Hain TC, Fuller L, Weil L, et al. Effects of t'ai chi on balance. Arch Otolaryngol Head Neck Surg. 1999;125(11):1191-5. [pmid: 10555688].
565 Hakim RM, DiCicco J, Burke JL, et al. Differences in balance related measures among older adults participating in tai chi, structured exercise, or no exercise. J Geriatr Phys Ther. 2004;27(1):11-5.
566 Hakim RM, Newton RA, Segal J, et al. A group intervention to reduce fall risk factors in community-dwelling older adults. Phys Occup Ther Geriatr. 2003;22(1):1-20.
567 Hall JM. The relaxation response as an inoculation to arousal and a facilitator of decision-making [dissertation]. Hempstead, NY: Hofstra University; 2003.
568 Handmacher BH. Length of time spent in the practice of Transcendental Meditation and sex differences related to intrapersonal and interpersonal orientation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2020–7.
569 Hankins KM. Comparison of the effects of two relaxation programs on the anxiety of freshmen and sophomore college students [dissertation]. Waco, TX: Baylor University; 1985.
570 Hanley CP, Spates JL. Transcendental Meditation and social psychological attitudes. J Psychol Interdisciplinary Appl. 1978;99(2):121-7.
571 Harrison SD, Pagano R, Warrenburg WS. Meditation and right hemispheric functioning—spatial localization. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 973–4.
572 Hart DE, Means JR. Effects of meditation vs professional reading on students' perceptions of paraprofessional counselors' effectiveness. Psychol Rep. 1982;51(2):479-82. [pmid: 6758012].
573 Hartman CA, Manos TM, Winter C, et al. Effects of t'ai chi training on function and quality of life indicators in older adults with osteoarthritis. J Am Geriatr Soc. 2000;48(12):1553-9. [pmid: 11129742].
574 Harvey JR. The effect of yogic breathing exercises on mood. J Am Soc Psychosom Dent Med. 1983;30(2):39-48. [pmid: 6350245].
575 Hebert JR, Ebbeling CB, Olendzki BC, et al. Change in women's diet and body mass following intensive intervention for early-stage breast cancer. J Am Diet Assoc. 2001;101(4):421-31. [pmid: 11320947].
576 Heide FJ. Psychophysiological responsiveness to auditory stimulation during Transcendental Meditation. Psychophysiology. 1986;23(1):71-5. [pmid: 3511490].
577 Heide FJ, Borkovec TD. Relaxation-induced anxiety: paradoxical anxiety enhancement due to relaxation training. J Consult Clin Psychol. 1983;51(2):171-82. [pmid: 6341426].
578 Helene B, Ford P. Mind-body innovations—an integrative care approach. Psychiatr Q. 2000;71(1):47-58. [pmid: 10736816].
579 Hellman CJ, Budd M, Borysenko JZ, et al. A study of the effectiveness of two group behavioral medicine interventions for patients with psychosomatic complaints. Behav Med. 1990;16(4):165-73. [pmid: 2271802].
580 Hewitt J, Miller R. Relative effects of meditation vs other activities on ratings of relaxation and enjoyment of others. Psychol Rep. 1981;48(2):395-8.
581 Hill DA. Beta-adrenergic receptor sensitivity, autonomic balance and serotonergic activity in practitioners of Transcendental Meditation [dissertation]. Fairfield, IA: Maharishi International University; 1989.
582 Hjelle LA. Transcendental Meditation and psychological health. Percept Mot Skills. 1974;39(1 Pt 2):623-8. [pmid: 4424110].
583 Holeman R, Seiler G. Effects of sensitivity training and Transcendental Meditation on perception of others. Percept Mot Skills. 1979;49(1):270.
584 Holmer ML. The effects of yoga on symptoms and psychosocial adjustment in fibromyalgia syndrome patients [dissertation]. San Diego, CA: California School of Professional Psychology; 2004.
585 Holmes DS, Solomon S, Cappo BM, et al. Effect of Transcendental Meditation versus resting on physiological and subjective arousal. J Pers Soc Psychol. 1983;44(6):1245-52. [pmid: 6348250].
586 Holt WR, Caruso JL, Riley JB. Transcendental Meditation vs pseudo-meditation on visual choice reaction time. Percept Mot Skills. 1978;46(3 Pt 1):726. [pmid: 353695].
587 Honsberger RW, Wilson AF. The effect of Transcendental Meditation upon bronchial asthma. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 279.
588 Hugel K, Sciandra T. The effects of a 12-week tai chi program on thoracolumbar, hip, and knee flexion in adults 50 years and older. Issues on Aging. 2000;23(3):15-8.
589 Humphrey CW. A stress management intervention with forgiveness as the goal (meditation, mind-body medicine) [dissertation]. Cincinnati, OH: Union Institute and University; 1999.
590 Husted C, Pham L, Hekking A, et al. Improving quality of life for people with chronic conditions: the example of t'ai chi and multiple sclerosis. Altern Ther Health Med. 1999;5(5):70-4.
591 Huynh LN. The effects of mantra meditation and religious orientation on psychological distress and self-actualization among Vietnamese American Buddhists [dissertation]. Los Angeles: California School of Professional Psychology; 2004.
592 Irvin JH, Domar AD, Clark C, et al. The effects of relaxation response training on menopausal symptoms. J Psychosom Obstet Gynaecol. 1996;17(4):202-7. [pmid: 8997686].
593 Jacobs BJ. The influence of a mindfulness-based stress reduction program on perceived quality of life [dissertation]. Albuquerque, NM: University of New Mexico; 2001.
594 Jacobs GD, Benson H, Friedman R. Topographic EEG mapping of the relaxation response. Biofeedback Self Regul. 1996;21(2):121-9. [pmid: 8805962].
595 Jacobson BH, Chen HC, Cashel C. The effect of t'ai chi chuan training on balance, kinesthetic sense, and strength. Percept Mot Skills. 1997;84(1):27-33. [pmid: 9132718].
596 Janer E, Valeriano J, Aziz NM, et al. Effect of tai-chi on bone mineral density: a clinical investigation. Arthritis Rheum. 1996;39(6 Suppl):R21.
597 Janowiak JJ, Hackman R. Meditation and college students' self-actualization and rated stress. Psychol Rep. 1994;75(2):1007-10. [pmid: 7862775].
598 Jevning RA, Anand R, Biedebach M. Effects on regional cerebral blood flow of Transcendental Meditation. Physiol Behav. 1996;59(3):399-402. [pmid: 8700938].
599 Jevning RA, Pirkle HC, Wilson AF. Behavioral alteration of plasma phenylalanine concentration. Physiol Behav. 1977;19(5):611-4. [pmid: 343124].
600 Jevning RA, Smith R, Wilson AF. Alterations in blood-flow during Transcendental Meditation. Clin Res. 1976;24(2):A139.
601 Jevning RA, Wilson AF, VanderLaan EF. Plasma prolactin and growth hormone during meditation. Psychosom Med. 1978;40(4):329-3. [pmid: 356081].
602 Jones JT. A growth curve analysis study examining the relationship between a meditation-based stress reduction program and components of subjective well-being [dissertation]. Urbana, IL: University of Illinois; 1999.
603 Judge JO, Lindsey C, Underwood M. Balance improvements in older women: effects of exercise training. Phys Ther. 1993;73(4):254-62. discussion 263–5. [pmid: 8456144].
604 Kabat-Zinn J. An outpatient program in behavioral medicine for chronic pain patients based on the practice of mindfulness meditation: theoretical considerations and preliminary results. Gen Hosp Psychiatry. 1982;4(1):33-47. [pmid: 7042457].
605 Kabat-Zinn J, Lipworth L, Burney R. The clinical use of mindfulness meditation for the self-regulation of chronic pain. J Behav Med. 1985;8(2):163-90. [pmid: 3897551].
606 Kabat-Zinn J, Massion AO, Kristeller JL, et al. Effectiveness of a meditation-based stress reduction program in the treatment of anxiety disorders. Am J Psychiatry. 1992;149(7):936-43. [pmid: 1609875].
607 Kanas N, Horowitz MJ. Reactions of transcendental meditators and nonmeditators to stress films: a cognitive study. Arch Gen Psychiatry. 1977;34(12):1431-6. [pmid: 400781].
608 Kaplan H, Brooks R, Cassone P, et al. The effects of tai-chi on seniors with developmental disabilities. Phys Occup Ther Geriatr. 2003;21(4):41-51.
609 Kaplan KH, Goldenberg DL, Galvin-Nadeau M. The impact of a meditation-based stress reduction program on fibromyalgia. Gen Hosp Psychiatry. 1993;15(5):284-9. [pmid: 8307341].
610 Keefer L, Blanchard EB. The effects of relaxation response meditation on the symptoms of irritable bowel syndrome: results of a controlled treatment study. Behav Res Ther. 2001;39(7):801-11. [pmid: 11419611].
611 Kennedy JE, Abbott RA, Rosenberg BS. Changes in spirituality and well-being in a retreat program for cardiac patients. Altern Ther Health Med. 1968;8(4):64-6.
612 Kesterson JB, Clinch NF. Metabolic rate, respiratory exchange ratio, and apneas during meditation. Am J Physiol. 1989;256(3 Pt 2):R632-8. [pmid: 2493750].
613 Khalsa SB. Treatment of chronic insomnia with yoga: a preliminary study with sleep-wake diaries. Appl Psychophysiol Biofeedback. 2004;29(4):269-78. [pmid: 15707256].
614 Khalsa SK. Effects of two types of meditation on self-esteem of introverts and extraverts [ dissertation]. Berkeley, CA: University of California; 1990.
615 Khasky AD, Smith JC. Stress, relaxation states, and creativity. Percept Mot Skills. 1999;88(2):409-16. [pmid: 10483629].
616 Kirkland K, Hollandsworth JG. Effective test taking: skills-acquisition versus anxiety-reduction techniques. J Consult Clin Psychol. 1980;48(4):431-9. [pmid: 7400428].
617 Kirsteins AE, Dietz F, Hwang SM. Evaluating the safety and potential use of a weight-bearing exercise, tai-chi chuan, for rheumatoid arthritis patients. Am J Phys Med Rehabil. 1991;70(3):136-41. [pmid: 2039615].
618 Klein MH, Greist JH, Gurman AS, et al. A comparative outcome study of group psychotherapy vs exercise treatments for depression. Int J Ment Health 1984-1985;13(3–4):148–77.
619 Klemons IM. Changes in inflammation in persons practicing the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 287–91.
620 Kristeller JL, Hallett CB. An exploratory study of a meditation-based intervention for binge eating disorder. J Health Psychol. 1999;4(3):357-63.
621 Kutz I, et al. Meditation as an adjunct to psychotherapy: an outcome study. Psychother Psychosom. 1985;43(4):209-18. [pmid: 3898186].
622 Lavey R, Sherman T, Mueser KT. The effects of yoga on mood in psychiatric inpatients. Psychiatr Rehabil J. 2005;28(4):399-402. [pmid: 15895926].
623 Lawson KL, Horneffer KJ. Roots and wings: a pilot of a mind-body-spirit program. J Holist Nurs. 2002;20(3):250-63. [pmid: 12240956].
624 Lazar Z, Farwell L, Farrow JT. The effects of the Transcendental Meditation program on anxiety, drug abuse, cigarette smoking, and alcohol consumption. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 524–35.
625 Lehmann JW, Goodale IL, Benson H. Reduced pupillary sensitivity to topical phenylephrine associated with the relaxation response. J Hum Stress. 1986;12(3):101-4.
626 Lehrer PM, et al. Progressive relaxation and meditation: a study of psychophysiological and therapeutic differences between two techniques. Behav Res Ther. 1983;21(6):651-62. [pmid: 6362649].
627 Lehrer PM, Schoicket SL, Carrington P. Psychophysiological and cognitive responses to stressful stimuli in subjects practicing progressive relaxation and clinically standardized meditation. Behav Res Ther. 1980;18(4):293-303. [pmid: 7002148].
628 Lepuschitz JK, Hartman VL. Meditation and psychosocial adaptation: an exploratory study. Curr Psychol: Dev Learning Pers Soc. 1996;15(3):215-22.
629 Lesh TV. Zen meditation and the development of empathy in counselors. J Hum Psychol. 1970;10(1):39-74.
630 Levy AS. An exploration into the psychoanalytic treatment of the meditating patient [dissertation]. Cincinnati, OH: Union Institute and University; 1985.
631 Li F, Fisher KJ, Harmer P. Tai chi and self-rated quality of sleep and daytime sleepiness in older adults: a randomized controlled trial. J Am Geriatr Soc. 2004;52(6):892-900. [pmid: 15161452].
632 Li QZ, Li P, Garcia GE. Genomic profiling of neutrophil transcripts in Asian qigong practitioners: a pilot study in gene regulation by mind-body interaction. J Altern Complement Med. 2005;11(1):29-39. [pmid: 15750361].
633 Lintel AG III. Physiological anxiety responses in transcendental meditators and nonmeditators. Percept Mot Skills. 1980;50(1):295-300. [pmid: 6988795].
634 Liu GL, Cui RQ, Li GZ. Changes in brainstem and cortical auditory potentials during qi-gong meditation. Am J Chin Med. 1990;18(34):95-103. [pmid: 2270854].
635 Lundgren JD. A mindfulness-based behavioral treatment for weight loss [dissertation]. Albany, NY: State University of New York; 2003.
636 Lutz A, Greischar LL, Rawlings NB. Long-term meditators self-induce high-amplitude gamma synchrony during mental practice. Proc Natl Acad Sci U S A. 2004;101(46):16369-73. [pmid: 15534199]. [pmcid: 526201].
637 Maddi SR, Kahn S, Maddi KL. The effectiveness of hardiness training. Consult Psychol J: Pract Res. 1998;50(2):78-86.
638 Madsen WC. Transcendental Meditation and the flexibility of constructions of reality. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1073–86.
639 Malec J, Sipprelle CN. Physiological and subjective effects of Zen meditation and demand characteristics. J Consult Clin Psychol. 1977;45(2):339-40. [pmid: 321493].
640 Martinetti RF. Influence of Transcendental Meditation of perceptual illusion: a pilot study. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 949–50.
641 Massion AO, Teas J, Hebert JR. Meditation, melatonin and breast/prostate cancer: hypothesis and preliminary data. Med Hypotheses. 1995;44(1):39-46. [pmid: 7776900].
642 McCain NL, Zeller JM, Cella DF. The influence of stress management training in HIV disease. Nurs Res. 1996;45(4):246-53. [pmid: 8700659].
643 Michaels RR, Huber MJ, McCann DS. Evaluation of Transcendental Meditation as a method of reducing stress. Science. 1976;192(4245):1242-4. [pmid: 775639].
644 Michaels RR, Parra J, McCann DS. Renin, cortisol, and aldosterone during Transcendental Meditation. Psychosom Med. 1979;41(1):50-4. [pmid: 373002].
645 Mihay L, Iltzsche E, Tribby A. Balance and perceived confidence with performance of instrumental activities of daily living: a pilot study of tai chi inspired exercise with elderly retirement-community dwellers. Phys Occup Ther Geriatr. 2003;21(3):75-86.
646 Mills PJ, Schneider RH, Hill DA. Beta-adrenergic receptor sensitivity in subjects practicing Transcendental Meditation. J Psychosom Res. 1990;34(1):29-33. [pmid: 2156071].
647 Mills WW, Farrow JT. The Transcendental Meditation technique and acute experimental pain. Psychosom Med. 1981;43(2):157-64. [pmid: 7022535].
648 Miskiman DE. Performance on a learning task by subjects who practice the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 382–4.
649 Monahan RJ. Secondary prevention of drug dependence through the Transcendental Meditation program in metropolitan Philadelphia. Int J Addict. 1977;12(6):729-54. [pmid: 338516].
650 Monk-Turner E. The benefits of meditation: experimental findings. Soc Sci J. 2003;40(3):465-70.
651 Morrell EM, Hollandsworth JG Jr. Norepinephrine alterations under stress conditions following the regular practice of meditation. Psychosom Med. 1986;48(34):270-7. [pmid: 3517923].
652 Morse DR, Cohen L, Furst ML. A physiological evaluation of the yoga concept of respiratory control of autonomic nervous system activity. Int J Psychosom. 1984;31(1):3-19.
653 Morse DR, Schacterie GR, Furst ML, et al. The effects of stress and relaxation on oral digestion of a complex carbohydrate food. Int J Psychosom. 1985;32(3):20-7.
654 Morse DR, Schacterie GR, Furst ML, et al. The effect of stress and meditation on salivary protein and bacteria: a review and pilot study. J Hum Stress. 1982;8(4):31-9.
655 Morse DR, Martin JS, Furst ML. A physiological and subjective evaluation of meditation, hypnosis, and relaxation. Psychosom Med. 1977;39(5):304-24. [pmid: 333497].
656 Moss SB. The effects of cognitive behavior therapy, meditation, and yoga on self-ratings of stress and psychological functioning in college students [dissertation]. Hattiesburg, MI: University of Southern Mississippi; 2003.
657 Murphy L, Riley D, Rodgers J. Effects of tai chi on balance, mobility, and strength among older persons participating in an osteoporosis prevention and education program. Explore: J Sci Healing. 2005;1(3):192-3.
658 Muskatel N, Woolfolk RL, Carrington P. Effect of meditation training on aspects of coronary-prone behavior. Percept Mot Skills. 1984;58(2):515-8. [pmid: 6377223].
659 Nidich SI. Effects of the Transcendental Meditation program on state-trait anxiety. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2063–5.
660 Nidich SI. The science of creative intelligence and the Transcendental Meditation program: reduction of drug and alcohol consumption. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2115–23.
661 Nidich SI, Nidich RJ. The Transcendental Meditation and TM-sidhi program and moral development. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2034–7.
662 Nidich SI, Seeman W, Dreskin T. Influence of Transcendental Meditation: a replication. J Couns Psychol. 1973;20(6):565-6.
663 Nidich SI, Seeman W, Seibert M. Influence of the Transcendental Meditation program on state anxiety. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 434–6.
664 Nielsen HL. Emotion experience and physiology in response to masked and non-masked presentations of emotional pictures [dissertation]. Tempe, AZ: University of Arizona; 2003.
665 Nowalk MP, Prendergast JM, Bayles CM. A randomized trial of exercise programs among older individuals living in two long-term care facilities: the FallsFREE program. J Am Geriatr Soc. 2001;49(7):859-65. [pmid: 11527475].
666 Oken BS, Kishiyama S, Zajdel D. Randomized controlled trial of yoga and exercise in multiple sclerosis. Neurology. 2004;62(11):2058-64. [pmid: 15184614].
667 Oleshansky MB. The effects of hatha yoga on stress and coping [dissertation]. Los Angeles: California School of Professional Psychology; 2004.
668 Orme-Johnson DW. Autonomic stability and Transcendental Meditation. Psychosom Med. 1973;35(4):341-9. [pmid: 4719021].
669 Orme-Johnson DW. Medical care utilization and the Transcendental Meditation program. Psychosom Med. 1987;49(5):493-507. Erratum in: Psychosom Med 1987 Nov–Dec;49(6):637. [pmid: 3313489].
670 Orme-Johnson DW, Arthur GK, Franklin L. The Transcendental Meditation technique and drug abuse counselors. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 597–9.
671 Orme-Johnson DW, Duck B. Psychological testing of MIU students: first report. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 470–5.
672 Orme-Johnson DW, Kolb K, Hebert JR. An experimental analysis of the effects of the Transcendental Meditation technique on reaction time. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 316–25.
673 Ospina-Kammerer V, Figley CR. An evaluation of the respiratory one method (ROM) in reducing emotional exhaustion among family physician residents. Int J Emerg Ment Health. 2003;5(1):29-32. [pmid: 12722487].
674 Ottens AJ. The effect of Transcendental Meditation upon modifying the cigarette smoking habit. J Sch Health. 1975;45(10):577-83. [pmid: 1042428].
675 Pagano RR, Frumkin LR. The effect of Transcendental Meditation on right hemispheric functioning. Biofeedback Self Regul. 1977;2(4):407-15. [pmid: 348241].
676 Pearl JH, Carlozzi AF. Effect of meditation on empathy and anxiety. Percept Mot Skills. 1994;78(1):297-8. [pmid: 8177673].
677 Puente AE, Beiman I. The effects of behavior therapy, self-relaxation, and Transcendental Meditation on cardiovascular stress response. J Clin Psychol. 1980;36(1):291-5. [pmid: 6993501].
678 Puente AE, Peacock LA. Effects of relaxation response training on attentional deficits in schizophrenics. Percept Mot Skills. 1988;66(3):789-90. [pmid: 3043371].
679 Punyaniyama N. Temporal awareness and hassles appraisal: a comparison of working adults who practice full awareness of breathing meditation with those who practice waking dream imagery [dissertation]. New York: New York University; 1996.
680 Puryear HB, Cayce CT, Thurston MA. Anxiety reduction associated with meditation: home study. Percept Mot Skills. 1976;42(43):527-31. [pmid: 790294].
681 Ramel W, Goldin PR, Carmona PE. The effects of mindfulness meditation on cognitive processes and affect in patients with past depression. Cognit Ther Res. 2004;28(4):433-55.
682 Randolph PD, Caldera YM, Tacone AM. The long-term combined effects of medical treatment and a mindfulness-based behavioral program for the multidisciplinary management of chronic pain in west Texas. Pain Digest. 1999;9(2):103-12.
683 Raskin M, Bali LR, Peeke HV. Muscle biofeedback and Transcendental Meditation: a controlled evaluation of efficacy in the treatment of chronic anxiety. Arch Gen Psychiatry. 1980;37(1):93-7. [pmid: 6986134].
684 Reibel DK, Greeson JM, Brainard GC. Mindfulness-based stress reduction and health-related quality of life in a heterogeneous patient population. Gen Hosp Psychiatry. 2001;23(4):183-92. [pmid: 11543844].
685 Rimol AGP. The Transcendental Meditation technique and its effects on sensory-motor performance. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 326–34.
686 Robertson DW, Peterson JW. Change in cardiac output during Transcendental Meditation as measured by noninvasive impedance plethysmography. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1596–8.
687 Rocheleau AE. Mindfulness-based intervention as an adjunctive treatment for enhancing outcomes obtained with traditional parent training for conduct problem children [dissertation]. Durham, NC: Duke University; 2002.
688 Rogers CA, Livingston DD. Accumulative effects of periodic relaxation. Percept Mot Skills. 1977;44(3 Pt 1):690. [pmid: 327429].
689 Rosenzweig S, Reibel DK, Greeson JM. Mindfulness-based stress reduction lowers psychological distress in medical students. Teach Learn Med. 2003;15(2):88-92. [pmid: 12708065].
690 Ross MC, Bohannon AS, Davis DC. The effects of a short-term exercise program on movement, pain, and mood in the elderly: results of a pilot study. J Holist Nurs. 1999;17(2):139-47. [pmid: 10633648].
691 Roth B, Robbins D. Mindfulness-based stress reduction and health-related quality of life: findings from a bilingual inner-city patient population. Psychosom Med. 2004;66(1):113-23. [pmid: 14747645].
692 Roth B, Stanley TW. Mindfulness-based stress reduction and healthcare utilization in the inner city: preliminary findings. Altern Ther Health Med. 1964;8(1):60-2.
693 Routt TJ. Low normal heart and respirator rates in individuals practicing the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 256–60.
694 Rowe K, Neuschatz JS, Nidich SI. Effect of the Transcendental Meditation and TM-sidhi program on reaction time. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1938–42.
695 Royer-Bounouar PA. The Transcendental Meditation technique: a new direction for smoking cessation programs [dissertation]. Fairfield, IA: Maharishi International University; 1989.
696 Sanderlin MA. The effects of open focus meditation versus progressive muscle relaxation on blood pressure, heart rate, and peripheral skin temperature [dissertation]. Manhattan, KS: Kansas State University; 1991.
697 Saxe GA, Hebert JR, Carmody JF. Can diet in conjunction with stress reduction affect the rate of increase in prostate specific antigen after biochemical recurrence of prostate cancer?. J Urol. 2001;166(6):2202-7. [pmid: 11696736].
698 Schaller KJ. Tai chi chih: an exercise option for older adults. J Gerontol Nurs. 1996;22(10):12-7.
699 Schneider D, Leung R. Metabolic and cardiorespiratory responses to the performance of wing chun and t'ai chi chuan exercise. Int J Sports Med. 1991;12(3):319-23. [pmid: 1889943].
700 Schneider RH, Mills PJ, Schramm W. Differential endocrine responses to stress in meditating and non-meditating type a subjects—a reflection of differences in central serotonergic tone. Neuro Endocrinol Lett. 1987;9(3):181.
701 Schneider RH, Nidich SI, Salerno JW. Lower lipid peroxide levels in practitioners of the Transcendental Meditation program. Psychosom Med. 1998;60(1):38-41. [pmid: 9492237].
702 Schoicket SL, Bertelson AD, Lacks P. Is sleep hygiene a sufficient treatment for sleep-maintenance insomnia?. Behav Ther. 1988;19(2):183-90.
703 Schwartz E. The effects of the Transcendental Meditation program on strength of the nervous system, perceptual reactance, reaction time, and auditory threshold. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2317–41.
704 Schwartz GE, Davidson RJ, Goleman DJ. Patterning of cognitive and somatic processes in the self-regulation of anxiety: effects of meditation versus exercise. Psychosom Med. 1978;40(4):321-8. [pmid: 356080].
705 Seeman W, Nidich SI, Banta T. Influence of Transcendental Meditation on a measure of self-actualization. J Couns Psychol. 1972;19(3):184-7.
706 Severtsen B, Bruya MA. Effects of meditation and aerobic exercise on EEG patterns. J Neurosci Nurs. 1986;18(4):206-10. [pmid: 2943837].
707 Shapiro D, Cline K. Mood changes associated with iyengar yoga practices: a pilot study. Int J Yoga Ther. 2004;14:35-44.
708 Shapiro DH. A mode of control and self-control profile for long term meditators. Psychologia: Int J Psychol Orient. 1992;35(1):1-11.
709 Shapiro J. The relationship of the Transcendental Meditation program to self-actualization and negative personality characteristics. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 462–7.
710 Shapiro SL, Astin JA, Bishop SR. Mindfulness-based stress reduction for health care professionals: results from a randomized trial. Int J Stress Manage. 2005;12(2):164-76.
711 Shapiro SL, Schwartz GE, Bonner G. Effects of mindfulness-based stress reduction on medical and premedical students. J Behav Med. 1998;21(6):581-99. [pmid: 9891256].
712 Shaw R, Kolb R. Reaction time following the transcedental meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 309–11.
713 Shen CL, Williams JK, Chyu MC. Comparison of effects of resistance training and tai chi on bone metabolism of the elderly. Med Sci Sports Exerc. 2004;36(5 Suppl):S290.
714 Sheppard WD II,, Staggers FJ Jr,, John L. The effects of a stress-management program in a high security government agency. Anxiety Stress Coping: Int J. 1997;10(4):341-50.
715 Shih J. Basic beijing twenty-four forms of t'ai chi exercise and average velocity of sway. Percept Mot Skills. 1997;84(1):287-90. [pmid: 9132721].
716 Singh BB, Berman BM, Hadhazy VA. A pilot study of cognitive behavioral therapy in fibromyalgia. Altern Ther Health Med. 1998;4(2):67-70. [pmid: 9682514].
717 Smith DE, Dillbeck MC, Sharma HM. Erythrocyte sedimentation rate and Transcendental Meditation. Altern Ther in Clin Pract. 1997;4(2):35-7.
718 Smith TR. The Transcendental Meditation technique and skin resistance response to loud tones. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 248–50.
719 Smith WP, Compton WC, West WB. Meditation as an adjunct to a happiness enhancement program. J Clin Psychol. 1995;51(2):269-73. [pmid: 7797651].
720 Solberg EE, Ingjer F, Ekberg O. Blood pressure and heart rate during meditation. J Psychosom Res. 2000;48(3):283.
721 Stehle R. Ventilation, heart rate and respiratory partial pressures of athletes practising the Transcendental Meditation technique. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 794–802.
722 Suarez VW. The relationship of the practice of Transcendental Meditation to subjective evaluations of marital satisfaction and adjustment. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1184–99.
723 Sultan SE. A study of the ability of individuals trained in Transcendental Meditation to achieve and maintain levels of physiological relaxation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 855–64.
724 Tacon AM, Caldera YM, Ronaghan C. Mindfulness-based stress reduction in women with breast cancer. Fam Syst Health. 2004;22(2):193-203.
725 Taggart HM, Arslanian CL, Bae S. Effects of t'ai chi exercise on fibromyalgia symptoms and health-related quality of life. Orthop Nurs. 2003;22(5):353-60. [pmid: 14595996].
726 Targ EF, Levine EG. The efficacy of a mind-body-spirit group for women with breast cancer: a randomized controlled trial. Gen Hosp Psychiatry. 2002;24(4):238-48. [pmid: 12100834].
727 Tate DB. Mindfulness meditation group training: effects on medical and psychological symptoms and positive psychological characteristics [dissertation]. Provo, UT: Brigham Young University; 1994.
728 Tloczynski J. A preliminary study of opening-up meditation college adjustment, and self-actualization. Psychol Rep. 1994;75(1 Pt 2):449-50. [pmid: 7809316].
729 Tloczynski J, Santucci A, Astor-Stetson E. Perception of visual illusions by novice and longer-term meditators. Percept Mot Skills. 2000;91(3 Pt 1):1021-6. [pmid: 11153836].
730 Traver MM. Efficacy of short term meditation as therapy for symptoms of stress [abstract]. Diss Abstr Int. 1990;50(12B Pt 1):5897.
731 Travis FT, Orme Johnson DW. EEG coherence and power during yogic flying. Int J Neurosci. 1990;54(12):1-12. [pmid: 2265953].
732 Travis FT, Tecce JJ, Guttman J. Cortical plasticity, contingent negative variation, and transcendent experiences during practice of the Transcendental Meditation technique. Biol Psychol. 2000;55(1):41-55. [pmid: 11099807].
733 Travis FT, Wallace RK. Autonomic and EEG patterns during eyes-closed rest and Transcendental Meditation (TM) practice: the basis for a neural model of TM practice. Conscious Cogn. 1999;8(3):302-18. [pmid: 10487785].
734 Travis TA, Kondo CY, Knott JR. Heart rate, muscle tension, and alpha production of transcendental meditators and relaxation controls. Biofeedback Self Regul. 1976;1(4):387-94. [pmid: 795471].
735 Tse SK, Bailey DM. T'ai chi and postural control in the well elderly. Am J Occup Ther. 1992;46(4):295-300. [pmid: 1566796].
736 Van Dalfsen PJ. Initial treatment response to relaxation and meditation procedures: the contribution of individual differences in anxiety [abstract]. Diss Abstr Int. 1987;47(10B):4317.
737 Vegors S. Transcendental Meditation and individual differences in mental capacity [dissertation]. Fairfield, IA: Maharishi International University; 1995.
738 Vroom PS. Meditation as a moderator of the effect of optimism on positive coping for cancer patients [dissertation]. New York: Columbia University; 2002.
739 Waelde LC, Thompson L, Gallagher TD. A pilot study of a yoga and meditation intervention for dementia caregiver stress. J Clin Psychol. 2004;60(6):677-87. [pmid: 15141399].
740 Wallace RK, Dillbeck MC, Jacobe E, et al. The effects of the Transcendental Meditation and TM-sidhi program on the aging process. Int J Neurosci. 1982;16(1):53-8. [pmid: 6763007].
741 Walrath LC, Hamilton DW. Autonomic correlates of meditation and hypnosis. Am J Clin Hypn. 1975;17(3):190-7. [pmid: 1146710].
742 Walsh R. Can synaesthesia be cultivated? Indications from surveys of meditators. J Consciousness Stud. 2005;12(45):5-17.
743 Walton KG, Fields JZ, Levitsky DK, et al. Lowering cortisol and CVD risk in postmenopausal women: a pilot study using the Transcendental Meditation program. Ann N Y Acad Sci. 2004;1032:211-5. [pmid: 15677413].
744 Walton KG, Pugh ND, Gelderloos P, et al. Stress reduction and preventing hypertension: preliminary support for a psychoneuroendocrine mechanism. J Altern Complement Med. 1995;1(3):263-83. [pmid: 9395623].
745 Wandhoeffer A, Kobal G, Plattig KH. Shortening of latencies of human auditory evoked brain potentials during the Transcendental Meditation technique. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 824–9.
746 Wang C, Roubenoff R, Lau J, et al. Effect of tai chi in adults with rheumatoid arthritis. Rheumatology. 2005;44(5):685-7. [pmid: 15741197].
747 Wang YT, Taylor L, Pearl M, et al. Effects of tai chi exercise on physical and mental health of college students. Am J Chin Med. 2004;32(3):453-9. [pmid: 15344428].
748 Warrenburg WS, Pagano R. Meditation and hemispheric specialization I: absorbed attention in long-term adherence. Imagination Cogn Pers. 1982-1983;2(3):211-29.
749 Warrenburg WS, Pagano RR, Woods M, et al. A comparison of somatic relaxation and EEG activity in classical progressive relaxation and Transcendental Meditation. J Behav Med. 1980;3(1):73-93. [pmid: 6995618].
750 Warshal D. Effects of the Transcendental Meditation technique on normal and Jendrassik reflex time. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1756–8.
751 Weinstein M, Smith JC. Isometric squeeze relaxation (progressive relaxation) vs meditation: absorption and focusing as predictors of state effects. Percept Mot Skills. 1992;75(3 Pt 2):1263-71. [pmid: 1484796].
752 Weiss M, Nordlie JW, Siegel EP. Mindfulness-based stress reduction as an adjunct to outpatient psychotherapy. Psychother Psychosom. 2005;74(2):108-12. [pmid: 15741760].
753 Weiss T, Cheatle MD, Rubin SI, et al. Effects of repeated ambulatory ECG monitoring and relaxation practice on premature ventricular contractions. Psychosom Med. 1985;47(5):446-50. [pmid: 3903824].
754 Wenk-Sormaz H. Meditation can reduce habitual responding. Altern Ther Health Med. 2005;11(2):42-58.
755 West J, Otte C, Geher K, et al. Effects of hatha yoga and African dance on perceived stress, affect, and salivary cortisol. Ann Behav Med. 2004;28(2):114-8. [pmid: 15454358].
756 Williams KA, Kolar MM, Reger BE, et al. Evaluation of a wellness-based mindfulness stress reduction intervention: a controlled trial. Am J Health Promot. 2001;15(6):422-32. [pmid: 11523499].
757 Williams LR, Vickerman BL. Effects of Transcendental Meditation on fine motor skill. Percept Mot Skills. 1976;42(43):607-13. [pmid: 790296].
758 Willis C. Transcendental Meditation and its influence on the self-concept. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1040–4.
759 Wilson AF, Honsberger RW, Chiu JT, et al. Transcendental Meditation and asthma. Respiration. 1975;32(1):74-80. [pmid: 1118672].
760 Wilson AF, Jevning RA, Guich S. Marked reduction of forearm carbon dioxide production during states of decreased metabolism. Physiol Behav. 1987;41(4):347-52. [pmid: 3124144].
761 Winzelberg AJ, Luskin FM. The effect of a meditation training in stress levels in secondary school teachers. Stress Med. 1999;15(2):69-77.
762 Wolanin AT. Mindfulness-acceptance-commitment (MAC) based performance enhancement for division I collegiate athletes: a preliminary investigation [dissertation]. Philadelphia: La Salle University; 2004.
763 Wood CJ. Evaluation of meditation and relaxation on physiological response during the performance of fine motor and gross motor tasks. Percept Mot Skills. 1986;62(1):91-8. [pmid: 3515311].
764 Woolery A, Myers H, Sternlieb B, et al. A yoga intervention for young adults with elevated symptoms of depression. Altern Ther Health Med. 2004;10(2):60-3. [pmid: 15055096].
765 Woolfolk RL, Carr-Kaffashan L, McNulty TF, et al. Meditation training as a treatment for insomnia. Behav Ther. 1976;7(3):359-65.
766 Wu G, Liu W, Hitt J, et al. Spatial, temporal and muscle action patterns of tai chi gait. J Electromyogr Kinesiol. 2004;14(3):343-54. [pmid: 15094148].
767 Wu WH, Bandilla E, Ciccone DS, et al. Effects of qigong on late-stage complex regional pain syndrome. Altern Ther Health Med. 1999;5(1):45-54. [pmid: 9893315].
768 Yalom ID, Bond G, Bloch S, et al. The impact of a weekend group experience on individual therapy. Arch Gen Psychiatry. 1977;34(4):399-415. [pmid: 322634].
769 Zuroff DC, Schwarz JC. Effects of Transcendental Meditation and muscle relaxation on trait anxiety, maladjustment, locus of control, and drug use. J Consult Clin Psychol. 1978;46(2):264-71. [pmid: 348732].
770 Bedard M, Felteau M, Mazmanian D, et al. Pilot evaluation of a mindfulness-based intervention to improve quality of life among individuals who sustained traumatic brain injuries. Disabil Rehabil. 2003;25(13):722-31. [pmid: 12791557].
771 Chenard JR. A controlled study of the influence of Transcendental Meditation on a specific value of the H-reflex (Hoffman reflex) recruitment curve and the surface EMG. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1660–5.
772 Dhanaraj VH, Singh M. Reduction in metabolic rate during the practice of the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 137–9.
773 Ferren DJ. The clinical use of mindfulness meditation within an intensive psychotherapy program for clients diagnosed with a personality disorder [dissertation]. Toronto, ON: University of Toronto; 2003.
774 Grace GD. Effects of meditation on personality and values. J Clin Psychol. 1976;32(4):809-13. [pmid: 789398].
775 Greene YN, Hiebert B. A comparison of mindfulness meditation and cognitive self-observation. Can J Counc. 1988;22(1):25-34.
776 Herron RE, Hillis SL. The impact of the Transcendental Meditation program on government payments to physicians in Quebec: an update. Am J Health Promot. 2000;14(5):284-91. [pmid: 11009854].
777 Keller S, Seraganian P. Physical fitness level and autonomic reactivity to psychosocial stress. J Psychosom Res. 1984;28(4):279-87. [pmid: 6481662].
778 Leung Y, Singhal A. An examination of the relationship between qigong meditation and personality. Soc Behav Pers. 2004;32(4):313-20.
779 Meissner J, Pirot M. Unbiasing the brain: the effects of meditation upon the cerebral hemispheres. Soc Behav Persf. 1983;11(1):65-76.
780 Miskiman DE. The treatment of insomnia by the Transcendental Meditation program. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 296–8.
781 Miskiman DE. The effect of the Transcendental Meditation program on compensatory paradoxical sleep. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 292–5.
782 Miskiman DE. The effect of the Transcendental Meditation program on the organization of thinking and recall (secondary organization). In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 385–92.
783 Moritz S. Does a spirituality programme on psychological well-being, quality of life and spirituality levels in distressed individuals—a randomized controlled trial. FACT. 2003;9(4):523.
784 Moustgaard AK. Mindfulness-based cognitive therapy (MBCT) for stroke survivors: an application of a novel intervention [dissertation]. Thunder Bay, ON: Lakehead University; 2004.
785 Murphy T, Persinger MA. Complex partial epileptic-like experiences in university students and practitioners of dharmakaya in Thailand: comparison with Canadian university students. Psychol Rep. 2001;89(1):199-206. [pmid: 11729543].
786 O'Haire TD, Marcia JE. Some personality characteristics associated with ananda marga meditators: a pilot study. Percept Mot Skills. 1980;51(2):447-52.
787 Royer A. The role of the Transcendental Meditation technique in promoting smoking cessation: a longitudinal study. Alcohol Treat Q. 1994;11(12):221-39.
788 Schiff BB, Rump SA. Asymmetrical hemispheric activation and emotion: the effects of unilateral forced nostril breathing. Brain Cogn. 1995;29(3):217-31. [pmid: 8838383].
789 Slater J, Hunt HT. Postural-vestibular integration and forms of dreaming: a preliminary report on the effects of brief t'ai chi chuan training. Percept Mot Skills. 1997;85(1):97-8. [pmid: 9293563].
790 Spanos NP, Steggles S, Radtke-Bodorik HL. Nonanalytic attending, hypnotic susceptibility, and psychological well-being in trained meditators and nonmeditators. J Abnorm Psychol. 1979;88(1):85-7. [pmid: 370175].
791 Spanos-Nicholas P, Gottlieb J, Rivers SM. The effects of short-term meditation practice on hypnotic responsivity. Psychol Rec. 1980;30(3):343-8.
792 Wolkove N, Kreisman H, Darragh D, et al. Effect of Transcendental Meditation on breathing and respiratory control. J Appl Physiol. 1984;56(3):607-12. [pmid: 6423589].
793 Yuille JC, Sereda L. Positive effects of meditation: a limited generalization?. J Appl Psychol. 1980;65(3):333-40. [pmid: 6991472].
794 Agte VV, Tarwadi K. Sudarshan kriya yoga for treating type 2 diabetes: a preliminary study. Altern Complement Ther. 2004;10(4):220-2.
795 Ahmad S, Ahmad H, Sumboo SS. Personality study of individuals regularly practicing Transcendental Meditation technique. J Pers Clin Stud. 1988;4(1):89-92.
796 Bagga OP, Gandhi A. A comparative study of the effect of Transcendental Meditation (TM) and shavasana practice on cardiovascular system. Indian Heart J. 1983;35(1):39-45. [pmid: 6343229].
797 Behera D. Yoga therapy in chronic bronchitis. J Assoc Physicians India. 1998;46(2):207-8. [pmid: 11273114].
798 Bhatia M, Kumar KA, Kumar N, et al. Electrophysiologic evaluation of sudarshan kriya: an EEG, BAER, P300 study. Indian J Physiol Pharmacol. 2003;47(2):157-63. [pmid: 15255618].
799 Bhattacharya S, Pandey US, Verma NS. Improvement in oxidative status with yogic breating in young healthy males. Indian J Physiol Pharmacol. 2002;46(3):349-54. [pmid: 12613400].
800 Bhushan S, Sinha P. Yoganidra and management of anxiety and hostility. Indian J Psychol. 2001;19(12):44-9.
801 Bijlani RL, Vempati RP, Yadav RK, et al. A brief but comprehensive lifestyle education program based on yoga reduces risk factors for cardiovascular disease and diabetes mellitus. J Altern Complement Med. 2005;11(2):267-74. [pmid: 15865492].
802 Bose S, Belapurkar N, Mishra U. Specific chiroglyphic, bronchial asthma and yoga. J Assoc Physicians India. 1992;40(4):279.
803 Dash M, Telles S. Yoga training and motor speed based on a finger tapping task. Indian J Physiol Pharmacol. 1999;43(4):458-62. [pmid: 10776461].
804 Dash M, Telles S. Improvement in hand grip strength in normal volunteers and rheumatoid arthritis patients following yoga training. Indian J Physiol Pharmacol. 2001;45(3):355-60. [pmid: 11881576].
805 Deepak KK, Manchanda SK, Maheshwari MC. Meditation improves clinicoelectroencephalographic measures in drug-resistant epileptics. Biofeedback Self Regul. 1994;19(1):25-40. [pmid: 8167162].
806 Devi SK, Chansauria JPN, Udupa KN. Mental depression and kundalini yoga. Ancient Sci Life. 1986;6(2):112-8.
807 Dhume RR, Dhume RA. A comparative study of the driving effects of dextroamphetamine and yogic meditation on muscle control for the performance of balance on balance board. Indian J Physiol Pharmacol. 1991;35(3):191-4. [pmid: 1791060].
808 Ganguli HC. Meditation subculture and drug use. Hum Relat. 1985;38(10):953-62.
809 Grover P, Varma VK, Verma SK, et al. Factors influencing treatment acceptance in neurotic patients referred for yoga therapy: an exploratory study. Indian J Psychiatr. 1989;31(3):250-7.
810 Grover P, Varma VK, Verma SK, et al. Relationship between the patient's attitude towards yoga and the treatment outcome. Indian J Psychiatr. 1987;29(3):253-8.
811 Harinath K, Malhotra AS, Pal K, et al. Effects of hatha yoga and omkar meditation on cardiorespiratory performance, psychologic profile, and melatonin secretion. J Altern Complement Med. 2004;10(2):261-8. [pmid: 15165407].
812 Jain S. Effect of preksha meditation on anxiety and operational efficiency of young convicts. Psychol Rep. 2003;48(3):82-7.
813 Jain SC, Talukdar B. Evaluation of yoga therapy programme for patients of bronchial asthma. Singapore Med J. 1993;34(4):306-8. [pmid: 8266199].
814 Jangid RK, Vays JN, Shukla TR. Effect of Transcendental Meditation in cases of anxiety neurosis. Indian J Clin Psychol. 1988;15(2):77-9.
815 Jangid RK, Vyas JN, Shukla TR. The effect of the Transcendental Meditation programme on the normal individuals. J Pers Clin Stud. 1988;4(2):145-9.
816 Joseph CD. Psychological supportive therapy for cancer patients. Indian J Cancer. 1983;20(5):268-70. [pmid: 6392068].
817 Khare KC, Nigam SK. A study of electroencephalogram in meditators. Indian J Physiol Pharmacol. 2000;44(2):173-8. [pmid: 10846631].
818 Khare KC, Sanghvi VC, Bhatnagar AD. Effect of yoga in treatment of bronchial asthma. Indian Pract. 1991;44(1):23-7.
819 Khumar SS, Kaur P, Kaur S. Effectiveness of shavasana on depression among university students. J Clin Psychol. 1993;20(2):82-7.
820 Kolsawalla MB. An experimental investigation into the effectiveness of some yogic variables as a mechanism of change in the value-attitude system. Indian J Psychol. 1978;1(1):59-68.
821 Latha DR. Nature of work and fatigue: role of yoga training. Indian J Psychol. 2003;21(1):54-61.
822 Madanmohan, Udupa K, Bhavanani AB. Modulation of cold pressor-induced stress by shavasan in normal adult volunteers. Indian J Physiol Pharmacol. 2002;46(3):307-12. [pmid: 12613393].
823 Malathi A, Damodaran A. Stress due to exams in medical students—role of yoga. Indian J Physiol Pharmacol. 1999;43(2):218-24. [pmid: 10365315].
824 Malhotra V, Singh S, Tandon OP. Effect of yoga asanas on nerve conduction in type 2 diabetes. Indian J Physiol Pharmacol. 2002;46(3):298-306. [pmid: 12613392].
825 Manjunath NK, Telles S. Influence of yoga & ayurveda on self-rated sleep in a geriatic population. Indian J Med Res. 2005;121(5):683-90. [pmid: 15937373].
826 Manjunath NK, Telles S. Factors influencing changes in tweezer dexterity scores following yoga training. Indian J Physiol Pharmacol. 1999;43(2):225-9. [pmid: 10365316].
827 Mishra M, Sinha RK. Effect of yogic practices on depression and anxiety. J Projective Psychol Ment Health. 2001;8(1):23-7.
828 Murthy CV, Rao TR. A study on the effect of japayoga on reactions to frustration- and personality dimensions. Indian J Behav. 1987;11(1):24-8.
829 Nagarathna R, Nagendra HR. Yoga for bronchial asthma: a controlled study. BMJ Clin Res Ed. 1985;291(6502):1077-9.
830 Naga-Venkatesha-Murthy PJ, Janakiramaiah N, Gangadhar BN. P300 amplitude and antidepressant response to sudarshan kriya yoga (SKY). J Affect Disord. 1998;50(1):45-8. [pmid: 9716279].
831 Patel CH. Yoga and bio-feedback in the management of hypertension. Lancet. 1973;2(7837):1053-5. [pmid: 4127312].
832 Prakasamma M, Bhaduri A. A study of yoga as a nursing intervention in the care of patients with pleural effusion. J Adv Nurs. 1984;9(2):127-33. [pmid: 6562134].
833 Raghuraj P, Telles S. Improvement in spatial and temporal measures of visual perception following yoga training. Indian J Psychol. 2002;20(1):23-31.
834 Raju PS, Madhavi S, Prasad KV. Comparison of effects of yoga & physical exercise in athletes. Indian J Med Res. 1994;100:81-6. [pmid: 7927562].
835 Rani NJ, Rao PVK. Effects of meditation on attention processes. Indian J Psychol. 2000;18(12):52-60.
836 Rawal SB, Singh MV, Tyagi AK. Effect of yogic exercises on thyroid function in subjects resident at sea level upon exposure to high altitude. Int J Biometeorol. 1994;38(1):44-7. [pmid: 8039950].
837 Ray US, Hegde KS, Selvamurthy W. Improvement in muscular efficiency as related to a standard task after yogic exercises in middle aged men. Indian J Med Res. 1986;83:343-8. [pmid: 3733196].
838 Ray US, Mukhopadhyay S, Purkayastha SS. Effect of yogic exercises on physical and mental health of young fellowship course trainees. Indian J Physiol Pharmacol. 2001;45(1):37-53. [pmid: 11211570].
839 Ray US, Sinha B, Tomer OS. Aerobic capacity and perceived exertion after practice of hatha yogic exercises. Indian J Med Res. 2001;114:215-21. [pmid: 12040766].
840 Sahajpal P, Ralte R. Impact of induced yogic relaxation training (IYRT) on stress-level, self-concept and quality of sleep among minority group individuals. Indian J Psychol. 2000;18(12):66-73.
841 Sahasi G, Mohan D, Kacker C. Effectiveness of yogic techniques in the management of anxiety. J Pers Clin Stud. 1989;5(1):51-5.
842 Salgar DC, Bisen VS, Jinturkar MJ. Effect of padmasana—a yogic exercise on muscular efficiency. Indian J Med Res. 1975;63(6):768-72. [pmid: 1213775].
843 Sathyaprabha TN, Murthy H, Murthy BT. Efficacy of naturopathy and yoga in bronchial asthma—a self controlled matched scientific study. Indian J Physiol Pharmacol. 2001;45(1):80-6. [pmid: 11211575].
844 Selvamurthy W, Ray US, Hegde KS. Physiological-responses to cold (10-degrees-C) in men after 6 months practice of yoga exercises. Int J Biometeorol. 1988;32(3):188-93. [pmid: 3198292].
845 Sharma AK, Singh RH, Shettiwar RM. Use of some hatha yogic practices in the management of certain chronic rheumatic diseases. Rheumatism. 1987;22(3):53-60.
846 Sharma I, Azmi SA, Settiwar RM. Evaluation of the effect of pranayama in anxiety state. Altern Med. 1991;3(4):227-35.
847 Sharma MP, Kumaraiah V, Mishra H. Therapeutic effects of vipassana meditation in tension headache. J Pers Clin Stud. 1990;6(2):201-6.
848 Sinha SN, Prasad SC, Sharma KN. An experimental study of cognitive control and arousal processes during meditation. Psychologia: Int J Psychol Orient. 1978;21(4):227-30.
849 Sridevi K, Krishna-Rao PV. Yoga practice and menstrual distress. J Indian Acad Appl Psychol. 1996;22(12):47-54.
850 Subrahmanyam S, Porkodi K. Neurohumoral correlates of Transcendental Meditation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1598–604.
851 Sundar S, Agrawal SK, Singh VP. Role of yoga in management of essential hypertension. Acta Cardiol. 1984;39(3):203-8. [pmid: 6331698].
852 Taneja I, Deepak KK, Poojary G. Yogic versus conventional treatment in diarrhea-predominant irritable bowel syndrome: a randomized control study. Appl Psychophysiol Biofeedback. 2004;29(1):19-33. [pmid: 15077462].
853 Telles S, Desiraju T. Recording of auditory middle latency evoked potentials during the practice of meditation with the syllable ‘OM’. Indian J Med Res. 1993;98:237-9. [pmid: 8119759].
854 Telles S, Hanumanthaiah BH, Nagarathna R. Plasticity of motor control systems demonstrated by yoga training. Indian J Physiol Pharmacol. 1994;38(2):143-4. [pmid: 8063362].
855 Telles S, Joshi M, Dash M. An evaluation of the ability to voluntarily reduce the heart rate after a month of yoga practice. Integr Physiol Behav Sci. 2004;39(2):119-25. [pmid: 15759599].
856 Telles S, Nagarathna R, Nagendra HR. Autonomic changes while mentally repeating two syllables—one meaningful and the other neutral. Indian J Physiol Pharmacol. 1998;42(1):57-63. [pmid: 9513794].
857 Telles S, Nagarathna R, Nagendra HR. Improvement in visual perception following yoga training. Indian J Psychol. 1995;13(1):30-2.
858 Telles S, Nagarathna R, Nagendra HR. Physiological measures of right nostril breathing. J Altern Complement Med. 1996;2(4):479-84. [pmid: 9395677].
859 Telles S, Nagarathna R, Nagendra HR. Alterations in auditory middle latency evoked potentials during meditation on a meaningful symbol—“Om”. Int J Neurosci. 1994;76(12):87-93. [pmid: 7960473].
860 Telles S, Nagarathna R, Vani PR. A combination of focusing and defocusing through yoga reduces optical illusion more than focusing alone. Indian J Physiol Pharmacol. 1997;41(2):179-82. [pmid: 9142567].
861 Telles S, Vani PR. Increase in voluntary pulse rate reduction achieved following yoga training. Int J Stress Manage. 2002;9(3):236-9.
862 Udupa KN, Singh RH, Settiwar RM. Physiological and biochemical studies on the effect of yogic and certain other exercises. Indian J Med Res. 1975;63(4):620-4. [pmid: 1213761].
863 Udupa KN, Singh RH, Yadav RA. Certain studies on psychological and biochemical responses to the practice in hatha yoga in young normal volunteers. Indian J Med Res. 1973;61(2):237-44. [pmid: 4758999].
864 Vani PR, Nagarathna R, Nagendra HR, et al. Progressive increase in critical flicker fusion frequency following yoga training. Indian J Physiol Pharmacol. 1997;41(1):71-4. [pmid: 10225037].
865 Venkatesh S, Pal M, Negi BS, et al. A comparative study of yoga practitioners and controls on certain psychological variables. Indian J Clin Psychol. 1994;21(1):22-7.
866 Vijayalakshmi S, Satyanarayana M, Krishna-Rao PV, et al. Combined effect of yoga and psychotherapy on management of asthma: a preliminary study. Indian J Psychol. 1988;7(2):32-9.
867 Vishal, Singh A, Madhu SV. A study of the effect of yogic practices on certain psychological parameters. Indian J Clin Psychol. 1987;14(2):80-3.
868 Visweswaraiah NK, Telles S. Randomized trial of yoga as a complementary therapy for pulmonary tuberculosis. Respirology. 2004;9(1):96-101. [pmid: 14982609].
869 Vyas R, Dikshit N. Effect of meditation on respiratory system, cardiovascular system and lipid profile. Indian J Physiol Pharmacol. 2002;46(4):487-91. [pmid: 12683226].
870 Yadav RK, Ray RB, Vempati RP, et al. Effect of a comprehensive yoga-based lifestyle modification program on lipid peroxidation. Indian J Physiol Pharmacol. 2005;49(3):358-62. [pmid: 16440857].
871 Chou KL, Lee PW, Yu EC, et al. Effect of tai chi on depressive symptoms amongst Chinese older patients with depressive disorders: a randomized clinical trial. Int J Geriatr Psychiatry. 2004;19(11):1105-7. [pmid: 15497192].
872 Jin W. Can tai chi exercise as a primary treatment prevent osteoporosis and improve health fitness in seniors?. J Bone Miner Res. 2004;19(1 Suppl):S317.
873 Kuang AK, Wang CX, Zhao GS, et al. Long-term observation on qigong in prevention of stroke—follow-up of 244 hypertensive patients for 18–22 years. J Tradit Chin Med. 1986;6(4):235-8. [pmid: 3600015].
874 Lai JS, Lan C, Wong MK. Two-year trends in cardiorespiratory function among older tai chi chuan practitioners and sedentary subjects. J Am Geriatr Soc. 1995;43(11):1222-7. [pmid: 7594155].
875 Liang YJ, Cai YY, Wang ZX. The effects of Chinese traditional breathing training on the exercise test, resistance breathing and quality of life in chronic obstructive pulmonary disease patients. Chin Med J. 1998;111(4):318.
876 Lin YC, Wong AM, Chou SW. The effects of tai chi chuan on postural stability in the elderly: preliminary report. Chang Gung Med J. 2000;23(4):197-204. [pmid: 10902224].
877 Qin L, Au S, Choy W, et al. Regular tai chi chuan exercise may retard bone loss in postmenopausal women: a case-control study. Arch Phys Med Rehabil. 2002;83(10):1355-9. [pmid: 12370867].
878 Tsang WWN, Hui-Chan CWY. Effect of 4- and 8-wk intensive tai chi training on balance control in the elderly. Med Sci Sports. 2004;36(4):648-57.
879 Tsang WWN, Hui-Chan CWY. Effects of exercise on joint sense and balance in elderly men: tai chi versus golf. Med Sci Sports. 2004;36(4):658-67.
880 Tsang WWN, Hui-Chan CWY. Effects of tai chi on joint proprioception and stability limits in elderly subjects. Med Sci Sports. 2003;35(12):1962-71.
881 Wu G, Zhao F, Zhou X, et al. Improvement of isokinetic knee extensor strength and reduction of postural sway in the elderly from long-term tai chi exercise. Arch Phys Med Rehabil. 2002;83(10):1364-9. [pmid: 12370869].
882 Xu DH. The effects of tai chi exercise on proprioception and neuromuscular responses in the elderly people [dissertation]. People's Republic of China: Chinese University of Hong Kong; 2003.
883 Yeung D, Ng G, Wong RWS, et al. Rehabilitation of patients with rheumatoid arthritis by tai chi chuen training. Arthritis Rheum. 2001;44(9 Suppl):S210.
884 Zhang W, Zheng R, Zhang B, et al. An observation on flash evoked cortical potentials and qigong meditation. Am J Chin Med. 1993;21(34):243-9. [pmid: 8135168].
885 Choi JH, Moon J, Song R. Effects of sun-style tai chi exercise on physical fitness and fall prevention in fall-prone older adults. J Adv Nurs. 2005;51(2):150-7. [pmid: 15963186].
886 Kim DH, Moon YS, Kim HS, et al. Effect of Zen meditation on serum nitric oxide activity and lipid peroxidation. Prog Neuropsychopharmacol Biol Psychiatry. 2005;29(2):327-31. [pmid: 15694242].
887 Lee MS, Jeong SM, Kim BG. A Minnesota multiphasic personality inventory profile of chundosunbup qi-trainees: a preliminary study. Am J Chin Med. 1999;27(34):307-13. [pmid: 10592839].
888 Lee MS, Jeong SM, Oh SW. Effects of chundosunbup qi-training on psychological adjustments: a cross-sectional study. Am J Chin Med. 1998;26(2):223-30. [pmid: 9799974].
889 Lee MS, Kang CW, Shin YS. Acute effects of chundosunbup qi-training on blood concentrations of TSH, calcitonin, PTH and thyroid hormones in elderly subjects. Am J Chin Med. 1998;26(34):275-82. [pmid: 9862015].
890 Lee MS, Ryu H, Chung HT. Stress management by psychosomatic training: effects of chundosunbup qi-training on symptoms of stress: a cross-sectional study. Stress Med. 2000;16(3):161-6.
891 Lee MS, Ryu H, Song J. Effects of qi-training (qigong) on forearm blood gas concentrations. Int J Neurosci. 2004;114(11):1503-10. [pmid: 15636359].
892 Ryu H, Jun CD, Lee BS. Effect of qigong training on proportions of T lymphocyte subsets in human peripheral blood. Am J Chin Med. 1995;23(1):27-36. [pmid: 7598089].
893 Ryu H, Mo HY, Mo GD. Delayed cutaneous hypersensitivity reactions in qigong (chun do sun bup) trainees by multitest cell mediated immunity. Am J Chin Med. 1995;23(2):139-44. [pmid: 7572774].
894 Song R, Lee EO, Lam P. Effects of tai chi exercise on pain, balance, muscle strength, and perceived difficulties in physical functioning in older women with osteoarthritis: a randomized clinical trial. J Rheumatol. 2003;30(9):2039-44. [pmid: 12966613].
895 Chan K, Qin L, Lau M, et al. A randomized, prospective study of the effects of tai chi chun exercise on bone mineral density in postmenopausal women. Arch Phys Med Rehabil. 2004;85(5):717-22. [pmid: 15129394].
896 Hong Y, Li JX, Robinson PD. Balance control, flexibility, and cardiorespiratory fitness among older tai chi practitioners. Br J Sports Med. 2000;34(1):29-34. [pmid: 10690447]. [pmcid: 1724150].
897 Ling KW, Wong FSY, Chan WK. Effect of a home exercise program based on tai chi in patients with end-stage renal disease. Perit Dial Int. 2003;23(2 Suppl):S99-S103. [pmid: 17986569].
898 Mak MK, Ng PL. Mediolateral sway in single-leg stance is the best discriminator of balance performance for tai-chi practitioners. Arch Phys Med Rehabil. 2003;84(5):683-6. [pmid: 12736881].
899 Qin L, Choy W, Leung K, et al. Beneficial effects of regular tai chi exercise on musculoskeletal system. J Bone Miner Metab. 2005;23(2):186-90. [pmid: 15750699].
900 Tsang HWH, Mok CK, Au-Yeung YT, et al. The effect of qigong on general and psychosocial health of elderly with chronic physical illnesses: a randomized clinical trial. Int J Geriatr Psychiatry. 2003;18(5):441-9. [pmid: 12766922].
901 Tsang WWN, Hui Chan CWY. Comparison of muscle torque, balance, and confidence in older tai chi and healthy adults. Med Sci Sports. 2005;37(2):280-9.
902 Tsang WWN, Wong VS, Fu SN, et al. Tai chi improves standing balance control under reduced or conflicting sensory conditions. Arch Phys Med Rehabil. 2004;85(1):129-37. [pmid: 14970980].
903 Xu DH, Hong Y, Li J, et al. Effect of tai chi exercise on proprioception of ankle and knee joints in old people. Br J Sports Med. 2004;38(1):50-4. [pmid: 14751946]. [pmcid: 1724726].
904 Yip VYB, Sit JWH, Wong DYS. A quasi-experimental study on improving arthritis self-management for residents of an aged people's home in Hong Kong. Psychol Health Med. 2004;9(2):235-46.
905 Lai JS, Wong MK, Lan C. Cardiorespiratory responses of tai chi chuan practitioners and sedentary subjects during cycle ergometry. J Formos Med Assoc. 1993;92(10):894-9. [pmid: 7908571].
906 Lan C, Chen SY, Lai JS. Relative exercise intensity of tai chi chuan is similar in different ages and gender. Am J Chin Med. 2004;32(1):151-60. [pmid: 15154294].
907 Lan C, Chou SW, Chen SY. The aerobic capacity and ventilatory efficiency during exercise in qigong and tai chi chuan practitioners. Am J Chin Med. 2004;32(1):141-50. [pmid: 15154293].
908 Lan C, Lai JS, Wong MK. Cardiorespiratory function, flexibility, and body composition among geriatric tai chi chuan practitioners. Arch Phys Med Rehabil. 1996;77(6):612-6. [pmid: 8831482].
909 Lu WA, Kuo CD. The effect of tai chi chuan on the autonomic nervous modulation in older persons. Med Sci Sports. 2003;35(12):1972-6.
910 Tsai SL, Crockett MS. Effects of relaxation training, combining imagery, and meditation on the stress level of Chinese nurses working in modern hospitals in Taiwan. Issues Ment Health Nurs. 1993;14(1):51-66. [pmid: 8454464].
911 Wong AM, Lin YC, Chou SW, et al. Coordination exercise and postural stability in elderly people: effect of tai chi chuan. Arch Phys Med Rehabil. 2001;82(5):608-12. [pmid: 11346836].
912 Hiraoka A, Kobayashi H, Shimono F, et al. Effects of kai-gou (air-ball handling), a qi-gong strategy, on the biofeedback training for enhancement of the electroencephalographic alpha-activity. Jpn J Biofeedback Res. 1997;24:74-8.
913 Ikemi A. Psychophysiological effects of self-regulation method: EEG frequency analysis and contingent negative variations. Psychother Psychosom. 1988;49(34):230-9. [pmid: 3070622].
914 Iwao M, Kajiyama S, Mori H. Effects of qigong walking on diabetic patients: a pilot study. J Altern Complement Med. 1999;5(4):353-8. [pmid: 10471015].
915 Kubose SK. An experimental investigation of psychological aspects of meditation. Psychologia: Int J Psychol Orient. 1976;19(1):1-10.
916 Kubota Y, Sato W, Toichi M, et al. Frontal midline theta rhythm is correlated with cardiac autonomic activities during the performance of an attention demanding meditation procedure. Brain Res Cogn Brain Res. 2001;11(2):281-7. [pmid: 11275489].
917 Murata T, Koshino Y, Omori M. Quantitative EEG study on Zen meditation (zazen). Jpn J Psychiatry Neurol. 1994;48(4):881-90.
918 Shiomi K. Respiratory and EEG changes by cotention of trigant burrow. Psychologia: Int J Psychol Orient. 1969;12(1):24-8.
919 Tsujiuchi T, Kumano H, Yoshiuchi K, et al. The effect of qi-gong relaxation exercise on the control of type 2 diabetes mellitus: a randomized controlled trial. Diabetes Care. 2002;25(1):241-2. [pmid: 11772923].
920 Disayavanish P. The effect of buddhist insight meditation on stress and anxiety [dissertation]. Normal, IL: Illinois State University; 1994.
921 Emavardhana T, Tori CD. Changes in self-concept, ego defense mechanisms, and religiosity following seven-day vipassana meditation retreats. J Sci Study Relig. 1997;36(2):194-206.
922 Chadwick P, Taylor KN, Abba N. Mindfulness groups for people with psychosis. Behav Cogn Psychother. 2005;33(3):351-9.
923 Fenwick PBC, Donaldson S, Gillis L, et al. Metabolic and EEG changes during Transcendental Meditation: an explanation. Biol Psychol. 1977;5(2):101-18. [pmid: 328063].
924 Haimerl CJ, Valentine ER. The effect of contemplative practice of intrapersonal, interpersonal, and transpersonal dimensions of the self-concept. J Transpersonal Psychol. 2001;33(1):37-52.
925 Haslock I, Monro R, Nagarathna R, et al. Measuring the effects of yoga in rheumatoid arthritis. Br J Rheumatol. 1994;33(8):787-8.
926 Kerr D, Gillam E, Ryder J. An Eastern art form for a Western disease: randomised controlled trial of yoga in patients with poorly controlled insulin-treated diabetes. Pract Diabetes Int. 2002;19(6):164-6.
927 Kras DJ. The Transcendental Meditation technique and EEG alpha activity. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 173–81.
928 Laurie G. An investigation into the changes in skin resistance during the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 216–23.
929 Ma SH, Teasdale JD. Mindfulness-based cognitive therapy for depression: replication and exploration of differential relapse prevention effects. J Consult Clin Psychol. 2004;72(1):31-40. [pmid: 14756612].
930 McMillan T, Robertson IH, Brock D. Brief mindfulness training for attentional problems after traumatic brain injury: a randomised control treatment trial. Neuropsychol Rehabil. 2002;12(2):117-25.
931 Okoli U, Dehaney M, Hillman A. Can we get away with anything less? Evaluating health promotion interventions: a tai chi exercise programme for older people. Public Health Med. 2002;4(1):10-3.
932 Sawada Y, Steptoe A. The effects of brief meditation training on cardiovascular stress responses. J Psychophysiol. 1988;2(4):249-57.
933 Steptoe A, Kearsley N. Cognitive and somatic anxiety. Behav Res Ther. 1990;28(1):75-81. [pmid: 2405835].
934 Surawy C, Roberts J, Silver A. The effect of mindfulness training on mood and measures of fatigue, activity, and quality of life in patients with chronic fatigue syndrome on a hospital waiting list: a series of exploratory studies. Behav Cogn Psychother. 2005;33(1):103-9.
935 Szabo A, Mesko A, Caputo A. Examination of exercise-induced feeling states in four modes of exercise. Int J Sport Psychol. 1998;29(4):376-90.
936 Turnbull MJ, Norris H. Effects of Transcendental Meditation on self-identity indices and personality. Br J Psychol. 1982;73(1):57-68.
937 Valentine ER, Sweet PLG. Meditation and attention: a comparison of the effects of concentrative and mindfulness meditation on sustained attention. Ment Health Religion Cult. 1999;2(1):59-70.
938 West MA. Physiological effects of meditation: a longitudinal study. Br J Soc Clin Psychol. 1979;18(2):219-26. [pmid: 378312].
939 Westcott M. Hemispheric symmetry of the EEG during the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 160–4. 940.
940 Williams JMG, Teasdale JD, Segal ZV, et al. Mindfulness-based cognitive therapy reduces overgeneral autobiographical memory in formerly depressed patients. J Abnorm Psychol. 2000;109(1):150-5. [pmid: 10740947].
941 Williams P, West MA. EEG responses to photic stimulation in persons experienced at meditation. Electroencephalogr Clin Neurophysiol. 1975;39(5):519-22. [pmid: 52446].
942 Fehr T. A longitudinal study of the effect of the Transcendental Meditation program on changes in personality. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 476–83.
943 Fluge T, Richter J, Wagner TOF, et al. Respiratory physiotherapy versus yoga in the treatment of asthma. Am Rev Respir Dis. 1993;147(4 Suppl):A587.
944 Friedrichs E, Pfistner B, Aldridge D. Qigong yangsheng—traditional Chinese medicine exercises for migraine and tension headache. Cephalalgia. 2003;23(7):755.
945 Kniffki C. Transcendental Meditation and autogenic training: a comparison. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2049–53.
946 Kroner-Herwig B, Hebing G, van Rijn-Kalkmann U. The management of chronic tinnitus—comparison of a cognitive-behavioural group training with yoga. J Psychosom Res. 1995;39(2):153-65. [pmid: 7595873].
947 Majumdar M, Grossman P, Dietz-Waschkowski B. Does mindfulness meditation contribute to health? Outcome evaluation of a German sample. J Altern Complement Med. 2002;8(6):719-30. discussion 731–5. [pmid: 12614525].
948 Schell FJ, Allolio B, Schonecke OW. Physiological and psychological effects of hatha-yoga exercise in healthy women. Int J Psychosom. 1994;41(14):46-52. [pmid: 7843867].
949 Schmidt T, Wijga AH, Von Zur Muhlen A. Changes in cardiovascular risk factors and hormones during a comprehensive residential three month kriya yoga training and vegetarian nutrition. Acta Physiol Scand Suppl. 1997;640:158-62. [pmid: 9401632].
950 Torber S, Mertesdorf F, Hiesel E. Effects of Transcendental Meditation on mood, and bodily sensations. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2391–407.
951 Ahlstrom HH. Transcendental Meditation, adaptation mechanisms and valuations [dissertation]. Fairfield, IA: Maharishi International University; 1991.
952 Barmark SM, Gaunitz SC. Transcendental Meditation and heterohypnosis as altered states of consciousness. Int J Clin Exp Hypn. 1979;27(3):227-39. [pmid: 396256].
953 Mannerkorpi K, Arndorw M. Efficacy and feasibility of a combination of body awareness therapy and qigong in patients with fibromyalgia: a pilot study. J Rehabil Med. 2004;36(6):279-81. [pmid: 15841606].
954 Wenneberg SR, Gunnarsson LG, Ahlstrom G. Using a novel exercise programme for patients with muscular dystrophy part II: a quantitative study. Disabil Rehabil. 2004;26(10):595-602. [pmid: 15204513].
955 Wiholm C, Arnetz B, Berg M. The impact of stress management on computer-related skin problems. Stress Med. 2000;16(5):279-85.
956 Oktedalen O, Solberg EE, Hauger AH. The influence of physical and mental training on plasma beta-endorphin level and pain perception after intensive physical exercise. Stress Health. 2001;17(2):121-7.
957 Solberg EE, Ekeberg O, Holen A. Hemodynamic changes during long meditation. Appl Psychophysiol Biofeedback. 2004;29(3):213-21. [pmid: 15497620].
958 Solberg EE, Halvorsen R, Holen A. Effect of meditation on immune cells. Stress Med. 2000;16(3):185-90.
959 Solberg EE, Halvorsen R, Sundgot-Borgen J. Meditation: a modulator of the immune response to physical stress? A brief report. Br J Sports Med. 1995;29(4):255-7. [pmid: 8808540]. [pmcid: 1332237].
960 Solberg EE, Holen A, Ekeberg O. The effects of long meditation on plasma melatonin and blood serotonin. Med Sci Monit. 2004;10(3):CR96-101. [pmid: 14976457].
961 Solberg EE, Ingjer F, Holen A. Stress reactivity to and recovery from a standardised exercise bout: a study of 31 runners practising relaxation techniques. Br J Sports Med. 2000;34(4):268-72. [pmid: 10953899]. [pmcid: 1724230].
962 Uhlig T, Larsson C, Hjorth AG, et al. No improvement in a pilot study of tai chi exercise in rheumatoid arthritis. Ann Rheum Dis. 2005;64(3):507-9. [pmid: 15708910]. [pmcid: 1755404].
963 Delmonte MM. Factors influencing the regularity of meditation practice in a clinical population. Br J Med Psychol. 1984;57(3):275-8. [pmid: 6386036].
964 Delmonte MM. Anxiety, defensiveness and physiological responsivity in novice and experienced meditators. J Integrative Eclectic Psychother. 1985;4(12):1-13.
965 Delmonte MM. Pilot study of conditioned relaxation during stimulation meditation. Psychol Rep. 1979;45(1):169-70.
966 Bernardi L, Sleight P, Bandinelli G, et al. Effect of rosary prayer and yoga mantras on autonomic cardiovascular rhythms: comparative study. BMJ. 2001;323(7327):1446-9. [pmid: 11751348]. [pmcid: 61046].
967 Fabbro F, Muzur A, Bellen R, et al. Effects of praying and a working memory task in participants trained in meditation and controls on the occurrence of spontaneous thoughts. Percept Mot Skills. 1999;88(3 Pt 1):765-70. [pmid: 10407883].
968 Spicuzza L, Gabutti A, Porta C. Yoga and chemoreflex response to hypoxia and hypercapnia. Lancet 2000;356(9240):1495–6. Erratum in: Lancet 2000 Nov 4;356(9241):1612.
969 Timio M, Verdecchia P, Venanzi S. Age and blood pressure changes: a 20-year follow-up study in nuns in a secluded order. Hypertension. 1988;12(4):457-61. [pmid: 3169953].
970 Hebert JR, Lehmann D. Theta bursts: An EEG pattern in normal subjects practising the Transcendental Meditation technique. Electroencephalogr Clin Neurophysiol. 1977;42(3):397-405. [pmid: 65275].
971 Koller A. Psychological effects of yoga [vervielfältigte lizentiatsarbeit]. Lausanne, Switzerland: Universität Freiburg; 2004.
972 Rouzere AM, Badawi K, Hartmann R. High amplitude fronto-central alpha and theta activity during the Transcendental Meditation technique. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1655–9.
973 Van den Berg WP, Mulder B. Psychological research on the effects of the Transcendental Meditation technique on a number of personality variables. Gedrag: Tijdschrift voor Psychologie. 1976;4(4):206-18.
974 Hawkins MA, Alexander CN, Travis FT, et al. Consciousness-based rehabilitation of inmates in the Netherlands Antilles: psychosocial and cognitive changes. J Offender Rehabil. 2003;36(14):205-28.
975 Infante JR, Peran F, Martinez M, et al. ACTH and beta-endorphin in Transcendental Meditation. Physiol Behav. 1998;64(3):311-5. [pmid: 9748098].
976 Infante JR, Torres-Avisbal M, Pinel P, et al. Catecholamine levels in practitioners of the Transcendental Meditation technique. Physiol Behav. 2001;72(12):141-6. [pmid: 11239991].
977 Manzaneque JM, Vera FM, Maldonado EF. Assessment of immunological parameters following a qigong training program. Med Sci Monit. 2004;10(6):CR264-70. [pmid: 15173671].
978 Bujatti M, Riederer P. Serotonin, noradrenaline, dopamine metabolites in Transcendental Meditation-technique. J Neural Transm. 1976;39(3):257-67. [pmid: 789821].
979 Lepicovska V, Dostalek C, Kovarova M. The influence of hathayogic exercise jalandhara bandha upon the cardiovascular system. Act Nerv Super (Praha). 1988;30(2):147-9. [pmid: 3048035].
980 Banquet JP, Lesevre N. Event-related potentials in altered states of consciousness. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1921–5.
981 Villien F, Yu M, Barthelemy P, et al. Training to yoga respiration selectively increases respiratory sensation in healthy man. Respir Physiol Neurobiol. 2005;146(1):85-96. [pmid: 15733782].
982 Dane S, Caliskan E, Karasen M, et al. Effects of unilateral nostril breathing on blood pressure and heart rate in right-handed healthy subjects. Int J Neurosci. 2002;112(1):97-102. [pmid: 12152408].
983 Stigsby B, Rodenberg JC, Moth HB. Electroencephalographic findings during mantra meditation (Transcendental Meditation) a controlled, quantitative study of experienced meditators. Electroencephalogr Clin Neurophysiol. 1981;51(4):434-42. [pmid: 6164542].
984 Zolnierczyk D. Perceived job stressors and mindfulness-based cognitive stress management intervention: The role of type A and reactivity. Polish Psychol Bull. 2004;35(1):25-33.
985 Stanescu DC, Nemery B, Veriter C. Pattern of breathing and ventilatory response to CO2 in subjects practicing hatha-yoga. J Appl Physiol. 1981;51(6):1625-9. [pmid: 6798002].
986 Davies JL. The Transcendental Meditation program and progressive relaxation: comparative effects on trait anxiety and self-actualization. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 449–52.
987 Dua JK, Swinden ML. Effectiveness of negative-thought-reduction, meditation and placebo training treatment in reducing anger. Scand J Psychol. 1992;33(2):135-46. [pmid: 1641608].
988 Gill S, Kolt GS, Keating J. Examining the multiprocess theory: an investigation of the effects of two relaxation techniques on state anxiety. J Bodywork Movement Ther. 2004;8(4):288-96.
989 Harte JL, Eifert GH, Smith R. The effects of running and meditation on beta-endorphin, corticotropin-releasing hormone and cortisol in plasma, and on mood. Biol Psychol. 1995;40(3):251-65. [pmid: 7669835].
990 Hood MA. Psychophysiological differences between meditators and non-meditators during anticipatory stress [dissertation]. Hobart, Tasmania: University of Tasmania; 1998.
991 Manocha R, Marks GB, Kenchington P. Sahaja yoga in the management of moderate to severe asthma: a randomised controlled trial. Thorax. 2002;57(2):110-5. [pmid: 11828038]. [pmcid: 1746263].
992 McIver S, O'Halloran JP, McGartland M. The impact of hatha yoga on smoking behavior. Altern Ther Health Med. 2004;10(2):22-3.
993 Nystul MS, Garde M. Comparison of self-concepts of transcendental meditators and nonmeditators. Psychol Rep. 1977;41(1):303-6. [pmid: 333493].
994 Nystul MS, Garde M. The self-concepts of regular transcendental meditators, dropout meditators, and nonmeditators. J Psychol. 1979;103(1):15-8. [pmid: 387951].
995 Pollard G, Ashton R. Heart rate decrease: a comparison of feedback modalities and biofeedback with other procedures. Biol Psychol. 1982;14(34):245-57. [pmid: 7126721].
996 Shaw RM, Dettmar DM. Monitoring behavioural stress control using a craniomandibular index. Aust Dent J. 1990;35(2):147-51. [pmid: 2189382].
997 Singh BS. Ventilatory response to CO2 II: studies in neurotic psychiatric patients and practitioners of Transcendental Meditation. Psychosom Med. 1984;46(4):347-62. [pmid: 6435149].
998 Tandon MK. Adjunct treatment with yoga in chronic severe airways obstruction. Thorax. 1978;33(4):514-7. [pmid: 694807]. [pmcid: 470924].
999 Tsang T, Orr R, Lam P, et al. Health benefits of tai chi for older adults with type 2 diabetes. J Am Geriatr Soc. 2005;53(4 Suppl):S174-5.
1000 1000. Wilcox GG. Autonomic functioning in subjects practicing the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 239–42.
1001 Xu H, Lawson D, Kras A. A study on tai ji exercise and traditional Chinese medical modalities in relation to bone structure, bone function and menopausal symptoms. Am J Chin Med. 2004;74:10-4.
1002 Lovell-Smith DH, Dickie A, Robinson J. Blood pressure and plasma cholesterol levels before and after learning Transcendental Meditation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 872–4.
1003 Williams LR, Herbert PG. Transcendental Meditation and fine perceptual-motor skill. Percept Mot Skills. 1976;43(1):303-9. [pmid: 958830].
1004 Williams LR, Lodge B, Reddish PS. Effects of Transcendental Meditation on rotary pursuit skill. Res Q. 1977;48(1):196-201. [pmid: 323947].
1005 Zika B. The effects of hypnosis and meditation on a measure of self-actualization. Aust J Clin Exp Hypn. 1987;15(1):21-8.
1006 Hart J, Kanner H, Gilboa-Mayo R. Tai chi chuan practice in community-dwelling persons after stroke. Int J Rehabil Res. 2004;27(4):303-4. [pmid: 15572994].
1007 Netz Y, Lidor R. Mood alterations in mindful versus aerobic exercise modes. J Psychol. 2003;137(5):405-19. [pmid: 14629072].
1008 Cooper R, Joffe BI, Lamprey JM, et al. Hormonal and biochemical responses to Transcendental Meditation. Postgrad Med J. 1985;61(714):301-4. [pmid: 3895206]. [pmcid: 2418240].
1009 Faber PA, Saayman GS, Touyz SW. Meditation and archetypal content of nocturnal dreams. J Anal Psychol. 1978;23(1):1-22. [pmid: 344296].
1010 Barros RML, Leite MRR, Brenzikofer R. Respiratory pattern changes in elderly yoga practitioners. J Hum Movement Stud. 2003;44(5):387-400.
1011 Flanzbaum N, Divita A, Notrica J, et al. Influence of mindfulness meditation on assisted reproduction treatment programmes. Hum Reprod. 2003;18(1 Suppl):207-8. [pmid: 12525468].
1012 Levitsky DK. Effects of the “Transcendental Meditation” program on neuroendocrine indicators of chronic stress [dissertation]. Fairfield, IA: Maharishi International University; 1998.
1013 Detsky AS, Naylor CD, O'Rourke K, et al. Incorporating variations in the quality of individual randomized trials into meta-analysis. J Clin Epidemiol. 1992;45(3):255-65. [pmid: 1569422].
1014 Dillbeck MC, Orme-Johnson DW. Physiological differences between Transcendental Meditation and rest. Am Psychol. 1987;42(9):879-81.
1015 Paul GL, Trimble RW. Recorded vs “live” relaxation training and hypnotic suggestion: comparative effectiveness for reducing physiological arousal and inhibiting stress response. Behav Ther. 1970;1(3):285-302.
1016 Riddle AG. Effects of selected elements of meditation on self-actualization, locus of control, and trait anxiety [abstract]. Diss Abstr Int. 1980;40(7B):3419.
1017 Smith JC. Psychotherapeutic effects of Transcendental Meditation with controls for expectation of relief and daily sitting. J Consult Clin Psychol. 1976;44(4):630-7. [pmid: 939847].
1018 Bevan AJW. Endocrine changes in Transcendental Meditation. Clin Exp Pharmacol Physiol. 1980;7(1):75-6.
1019 Werner OR, Wallace RK, Charles BM, et al. Long-term endocrinologic changes in subjects practicing the Transcendental Meditation and TM-sidhi program. Psychosom Med. 1986;48(12):59-66. [pmid: 3511493].
1020 Jevning RA, Wells I, Wilson AF. Plasma thyroid hormones, thyroid stimulating hormone, and insulin during acute hypometabolic states in man. Physiol Behav. 1987;40(5):603-6. [pmid: 3313447].
1021 Tooley GA, Armstrong SM, Norman TR, et al. Acute increases in night-time plasma melatonin levels following a period of meditation. Biol Psychol. 2000;53(1):69-78. [pmid: 10876066].
1022 Jevning RA, Wilson AF, Pirkle HC. Modulation of red cell metabolism by states of decreased activation: comparison between states. Physiol Behav. 1985;35(5):679-82. [pmid: 3936073].
1023 1023. Murphy MB. Theta bursts and rhythmical theta trains in the Transcendental Meditation technique and TM-Sidhi program: a qualitative and quantitative analysis of EEG theta activity [dissertation]. Melbourne, FL: Florida Institute of Technology; 1984.
1024 Pelletier KR. Influence of Transcendental Meditation upon autokinetic perception. Percept Mot Skills. 1974;39(3):1031-4.
1025 So KT, Orme-Johnson DW. Three randomized experiments on the longitudinal effects of the Transcendental Meditation technique on cognition. Intelligence. 2001;29(5):419-40.
1026 Dillbeck MC, Assimakis PD, Raimondi D, et al. Longitudinal effects on the Transcendental Meditation and TM-Sidhi program on cognitive ability and cognitive style. Percept Mot Skills. 1986;62(3):731-8.
1027 Reddy MK, Ath D, Bai AJL. The effects of the Transcendental Meditation program on athletic performance. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 346–58.
1027 Kember P. The Transcendental Meditation technique and academic performance: a short report on a controlled longitudinal pilot study. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2384.
1029 Heaton DP, Orme-Johnson DW. The Transcendental Meditation program and academic achievement. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 396–9.
1030 Aron A, Orme-Johnson DW, Brubaker P. The Transcendental Meditation program in the college curriculum: a 4-year longitudinal study on effects on cognitive and affective functioning. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1977–82.
1031 Eppley KR, Abrams AI, Shear J. Differential effects of relaxation techniques on trait anxiety: a meta-analysis. J Clin Psychol. 1989;45(6):957-74. [pmid: 2693491].