# Acknowledgments

We are grateful to members of the technical expert panel for their consultation with and advice to the Evidence-based Practice Center during the preparation of this report. The members of the panel include John Astin, Ph.D., Ruth Baer, Ph.D., Vernon Barnes, Ph.D., Linda E. Carlson, Ph.D., C.Psych., Jeffery Dusek, Ph.D., Thierry Lacaze-Masmonteil, M.D., Ph.D., F.R.C.P.C., Badri Rickhi, M.D., Ph.D., and David Shannahoff-Khalsa, B.A.

We would like to thank the peer reviewers, who provided valuable input into the draft report: Dr. Kirk Warren Brown (Virginia Commonwealth University, Richmond, VA), Dr. Bei-Hung Chang (Boston University School of Public Health, Boston, MA), Dr. Thawatchai Krisanaprakornkit (Khon Kaen University, Khon Kaen, Thailand), Dr. T. M. Srinivasan (The International Society for the Study of Subtle Energies and Energy Medicine, Chennai (Madras), India), Dr. Harald Walach (The University of Northampton, Northampton, United Kingdom), Dr. Ken Walton (Maharishi University of Management, Fairfield, IA), and Dr. Gloria Yeh (Osher Institute at Harvard Medical School, Boston, MA).

We thank Dr. Richard L. Nahin and Dr. Catherine Stoney from the National Center for Complementary and Alternative Medicine for their insight, recommendations, and support of this work. We are grateful to the Agency for Healthcare Research and Quality for granting the contract for this work and the Task Order Officer, Margaret Coopey, for facilitating the collaboration of the three organizations.

We are grateful to Lisa Hartling for her guidance when preparing the Work Plan for this report; Amy Couperthwaite, Lisa Malinowsky, and Kenneth Moreau for their assistance with article retrieval; Denise Adams, Mauricio Castillo, Carol Spooner, and Kate O'Gorman for their assistance with data extraction and quality assessment; and Christine Tyrell and Kelley Bessette for their administrative support.