# Appendix I. Characteristics of Studies Included in Topic V

Table I1 Country of study

| Country | N | References
North America | United States | 146 | ^126,^,^177,^,^205,^,^206,^,^208,^,^233,^,^234,^,^260,^,^279,^,^280,^,^289,^,^290,^,^304,^,^311,^,^387,^,^440,^,^442,^,^459,^,^460,^,^463,^,^468,^,^475,^,^477,^,^478,^,^480,^,^483,^,^489,^,^491,494b127,^,^197,^,^306,^,^500,503a306b91,^,^94,^,^134,^,^168,^,^178,^,^181,^,^188,^,^190,^,^198,^,^209,^,^210,^,^220,^,^221,^,^227,^,^228,^,^237,^,^241,^,^244,263^–^265,^,^272,^,^282,^,^284,^,^285,^,^288,^,^292,^,^293,^,^309,^,^316,^,^317,^,^319,^,^322,^,^325,^,^391,^,^396,^,^398,^,^407,^,^409,^,^418,^,^419,^,^433,^,^510,^,^512,517^–^519,^,^21,^,^524,^,^525,^,^528,^,^530,^,^531,^,^536,^,^539,^,^541,^,^544,^,^545,^,^554,^,^558,^,^559,^,^562,^,^567,^,^577,^,^594,^,^596,^,^602,^,^603,^,^608,^,^615,^,^616,^,^618,625^–^627,^,^634,^,^639,^,^642,651^–^654,^,^665,^,^666,^,^677,^,^678,^,^681,^,^683,^,^696,^,^697,^,^706,^,^713,^,^714,^,^733,^,^746,^,^750,^,^751,^,^753,754a,754b78,^,^191,^,^246,^,^252,^,^274,^,^287,^,^397,^,^435,^,^759,^,^764,766^
| Canada | 9 | ^97,^ ^182,^ ^194,^ ^296,^ ^386,^ ^413,^ ^777,^ ^782,^ ^793^
Asia | India | 71 | ^83,^,^133,^,^137,^,^140,^,^204,^,^212,^,^217,^,^226,^,^239,^,^240,^,^250,^,^273,^,^278,^,^294,^,^295,^,^298,^,^300,^,^301,^,^303,^,^305,^,^310,312^–^314,^,^318,^,^320,^,^321,^,^323,^,^417,^,^794,^,^796,^,^797,^,^799,^,^801,^,^802,^,^805,^,^806,811^–^815,^,^818,^,^822,^,^824,^,^829,^,^831,^,^832,^,^834,836^–^839,^,^841,^,^843,^,^844,^,^847,^,^848,850^–^852,^,^856,^,^858,^,^860,862^–^864,866^–^868,870^
| China | 8 | ^211,^ ^225,^ ^262,^ ^872,^ ^875,^ ^878,^ ^882,^ ^883^
| South Korea | 6 | ^213,^ ^214,^ ^405,^ ^889,^ ^891,^ ^894^
| Hong Kong | 5 | ^207,^ ^286,^ ^299,^ ^895,^ ^897^
| Taiwan | 4 | ^223,^ ^248,^ ^326,^ ^906^
| Japan | 7 | ^389,^,^426,913^–^916,919^
| Thailand | 3 | ^106,^ ^216,^ ^238^
| Malaysia | 2 | ^179,^ ^180^
Europe | United Kingdom | 14 | ^185,^ ^218,^ ^219,^ ^235,^ ^281,^ ^283,^ ^308,^ ^427,^ ^431,^ ^926,^ ^930,^ ^932,^ ^938,^ ^940^
| Germany | 4 | ^215,^ ^247,^ ^943,^ ^946^
| Sweden | 2 | ^302,^ ^955^
| Norway | 3 | ^956,^ ^959,^ ^961^
| Ireland | 2 | ^392,^ ^965^
| Italy | 1 | ^966^
| Switzerland | 1 | ^199^
| Netherlands | 1 | ^224^
| Spain | 1 | ^977^
| Austria | 1 | ^430^
| Czech Republic | 1 | ^183^
| France | 1 | ^981^
| Russia | 1 | ^203^
| Turkey | 2 | ^315,^ ^982^
Australasia | Australia | 7 | ^297,^ ^307,^ ^991,^ ^992,^ ^998,^ ^999,^ ^1001^
| New Zealand | 3 | ^222,^ ^429,^ ^1002^
Other | Israel | 2 | ^176,^ ^291^
| South Africa | 1 | ^86^
| Brazil | 1 | ^236^
| Netherlands Antilles | 1 | ^974^

Table I2 Study design

Study design | N | References
RCT | 167 | ^86,^,^91,^,^94,^,^97,^,^127,^,^134,^,^140,^,^168,^,^176,^,^177,^,^182,^,^185,^,^190,^,^194,203^–^224,233^–^241,^,^244,^,^260,262^–^265,278^–^286,^,^288,^,^304,^,^305,307^–^309,^,^325,^,^386,^,^387,^,^389,^,^391,^,^392,^,^396,^,^398,^,^405,^,^407,^,^409,^,^413,^,^417,^,^418,^,^427,^,^431,^,^433,^,^460,^,^475,^,^477,^,^478,^,^480,^,^483,^,^503,^,^512,^,^519,^,^521,^,^528,^,^530,^,^531,^,^536,^,^539,^,^541,^,^544,^,^545,^,^554,^,^558,^,^562,^,^567,^,^594,^,^603,^,^615,^,^616,^,^618,625^–^627,^,^651,^,^665,^,^666,^,^677,^,^683,^,^706,^,^714,^,^746,^,^751,^,^754,^,^777,^,^782,^,^796,^,^805,^,^811,^,^829,^,^832,836^–^839,^,^841,^,^844,^,^852,^,^858,^,^868,^,^894,^,^895,^,^919,^,^926,^,^930,^,^932,^,^943,^,^946,^,^956,^,^959,^,^961,^,^965,^,^977,^,^991,^,^998,999a754b78,^,^191,^,^225,^,^246,^,^287,^,^397,^,^759,^,^764,^,^793,^,^882,940^
NRCT | 65 | ^126,^,^289,^,^290,^,^440,^,^463,^,^489,^,^494,^,^794,799b197,^,^291,^,^306,500a306b106,^,^137,178^–^181,^,^183,^,^188,^,^198,^,^199,226^–^228,^,^247,^,^248,^,^250,^,^252,272^–^274,^,^292,^,^293,^,^326,^,^419,^,^429,^,^430,^,^435,^,^518,^,^577,^,^596,^,^602,^,^639,^,^642,^,^678,^,^681,^,^696,^,^713,^,^806,^,^818,^,^824,^,^834,^,^860,^,^864,^,^866,^,^878,^,^915,^,^938,^,^955,^,^974,^,^981,1001^
Before-and-after | 79 | ^83,^,^133,294^–^303,310^–^323,^,^426,^,^442,^,^459,^,^468,^,^491,^,^510,^,^517,^,^524,^,^525,^,^559,^,^608,^,^634,652^–^654,^,^697,^,^733,^,^750,^,^753,^,^766,^,^797,^,^801,^,^802,812^–^815,^,^822,^,^831,^,^843,^,^847,^,^848,^,^850,^,^851,^,^856,^,^862,^,^863,^,^867,^,^870,^,^872,^,^875,^,^883,^,^889,^,^891,^,^897,^,^906,^,^913,^,^914,^,^916,^,^966,^,^982,^,^992,1002^

NRCT = nonrandomized controlled trials; RCT = randomized controlled trials

Table I3 Type of publication

Type of publication | N | References
Journal article | 274 | ^176,^,^177,^,^203,^,^204,206^–^208,233^–^235,278^–^281,^,^289,^,^290,^,^295,^,^297,^,^304,^,^305,310^–^312,^,^387,^,^440,^,^459,^,^460,^,^463,^,^468,^,^475,^,^477,^,^478,^,^480,^,^483,^,^489,^,^491,^,^494,^,^794,^,^796,^,^797,^,^799,^,^801,^,^802,^,^895,966b127,^,^194,^,^236,^,^291,^,^306,^,^389,^,^500,503a306b83,^,^97,^,^106,^,^133,^,^137,^,^140,^,^168,178^–^183,^,^185,^,^188,^,^190,^,^198,^,^209,211^–^214,216^–^224,226^–^228,238^–^240,^,^244,^,^248,^,^262,^,^264,^,^265,^,^272,^,^273,282^–^286,^,^288,^,^293,^,^294,^,^296,298^–^303,307^–^309,313^–^316,318^–^321,^,^323,^,^325,^,^326,^,^386,^,^392,^,^396,^,^398,^,^405,^,^407,^,^409,^,^413,417^–^419,^,^426,^,^427,^,^429,^,^431,^,^510,^,^512,^,^518,^,^519,^,^521,^,^524,^,^525,^,^528,^,^530,^,^531,^,^536,^,^539,^,^544,^,^545,^,^554,^,^558,^,^559,^,^562,^,^577,^,^594,^,^603,^,^608,^,^615,^,^616,^,^618,625^–^627,^,^634,^,^639,^,^642,651^–^654,^,^665,^,^666,^,^677,^,^678,^,^681,^,^683,^,^697,^,^706,^,^714,^,^733,^,^750,^,^751,^,^753,^,^754,^,^777,^,^782,^,^805,^,^806,811^–^815,^,^818,^,^822,^,^824,^,^829,^,^831,^,^832,^,^834,836^–^839,^,^841,^,^843,^,^844,^,^847,^,^848,850^–^852,^,^856,^,^858,^,^860,862^–^864,866^–^868,^,^878,^,^889,^,^891,^,^894,^,^897,^,^906,913^–^916,^,^926,^,^930,^,^932,^,^946,^,^956,^,^959,^,^961,^,^965,^,^974,^,^977,^,^981,^,^982,^,^991,^,^992,^,^998,1002a754b191,^,^199,^,^225,^,^246,^,^250,^,^252,^,^274,^,^287,^,^397,^,^435,^,^759,^,^764,^,^766,^,^793,^,^870,^,^938,^,^940,^,^955,1001^
Thesis/Dissertation | 22 | ^78,^ ^86,^ ^91,^ ^126,^ ^134,^ ^197,^ ^205,^ ^210,^ ^237,^ ^241,^ ^260,^ ^263,^ ^292,^ ^391,^ ^433,^ ^442,^ ^517,^ ^541,^ ^567,^ ^602,^ ^696,^ ^882^
Abstract | 13 | ^94,^ ^215,^ ^247,^ ^317,^ ^322,^ ^430,^ ^596,^ ^713,^ ^872,^ ^875,^ ^883,^ ^943,^ ^999^
Research letter | 2 | ^746,^ ^919^

Table I4 Methodological quality—intervention studies

RCTs—Jadad scale | RCTs that obtained Jadad scores lower than 3 (n=145) ^94,^,^97,^,^134,^,^140,^,^176,^,^177,^,^182,^,^185,^,^190,^,^194,203^–^219,222^–^224,^,^233,235^–^241,^,^244,^,^260,262^–^265,278^–^281,^,^283,^,^285,^,^286,^,^288,^,^304,^,^305,307^–^309,^,^325,^,^387,^,^389,^,^392,^,^396,^,^405,^,^407,^,^413,^,^417,^,^418,^,^427,^,^431,^,^433,^,^460,^,^475,^,^477,^,^478,^,^480,^,^483,^,^503,^,^512,^,^519,^,^528,^,^530,^,^531,^,^536,^,^539,^,^545,^,^554,^,^558,^,^562,^,^567,^,^594,^,^603,^,^615,^,^616,^,^618,625^–^627,^,^651,^,^665,^,^666,^,^677,^,^683,^,^706,^,^714,^,^746,^,^751,^,^754,^,^777,^,^782,^,^796,^,^805,^,^811,^,^829,^,^832,836^–^838,^,^841,^,^844,^,^852,^,^858,^,^868,^,^895,^,^919,^,^926,^,^930,^,^932,^,^943,^,^946,^,^956,^,^959,^,^961,^,^965,^,^977,998a754b78,^,^191,^,^225,^,^246,^,^397,^,^759,^,^764,^,^793,^,^882,940^
| RCTs that obtained Jadad scores of 3 or greater (n=22) ^86,^,^91,^,^127,^,^168,^,^220,^,^221,^,^234,^,^265,^,^282,^,^284,^,^287,^,^386,^,^391,^,^398,^,^409,^,^521,^,^541,^,^544,^,^839,^,^894,^,^991,999^
| RCTs describing the methods of randomization (n=32) Appropriate (n=24)^86,^,^91,^,^127,^,^168,^,^206,^,^220,^,^221,^,^234,^,^260,^,^265,^,^282,^,^284,^,^287,^,^308,^,^386,^,^391,^,^398,^,^409,^,^521,^,^541,^,^544,^,^811,^,^839,894^Inappropriate (n=8)^134,^,^212,^,^213,^,^262,^,^478,^,^545,^,^841,868^
| RCTs described as double-blind (n=5) ^168,^,^424,^,^782,^,^991,999^
| RCTs describing withdrawals/dropouts (n=86) ^86,^,^91,^,^94,^,^97,^,^127,^,^168,^,^185,^,^203,^,^207,^,^210,^,^213,^,^214,^,^216,218^–^224,234^–^236,^,^238,^,^241,^,^244,263^–^265,278^–^286,^,^325,^,^386,^,^391,^,^398,^,^409,^,^478,^,^480,^,^503,^,^521,^,^528,^,^536,^,^541,^,^544,^,^562,^,^603,^,^616,^,^618,^,^626,^,^627,^,^651,^,^666,^,^683,^,^714,^,^754,^,^777,^,^829,^,^839,^,^841,^,^852,^,^868,^,^894,^,^895,^,^926,^,^930,^,^946,^,^977,^,^991,^,^998,999a754b78,^,^246,^,^287,^,^759,^,^764,^,^793,^,^882,940^
RCTs—concealment of treatment allocation | RCTs with adequate report of methods for concealment of allocation (n=8) ^168,^,^246,^,^418,^,^521,^,^544,^,^894,^,^926,991^
| RCTs with inadequate report of methods for concealment of allocation (n=2) ^545,868^
| RCTs that failed to describe the methods for concealment of allocation (n=157) ^86,^,^91,^,^94,^,^97,^,^127,^,^134,^,^140,^,^176,^,^177,^,^182,^,^185,^,^190,^,^194,203^–^224,233^–^241,^,^244,^,^260,262^–^265,278^–^286,^,^288,^,^304,^,^305,307^–^309,^,^325,^,^386,^,^387,^,^389,^,^391,^,^392,^,^396,^,^398,^,^405,^,^407,^,^409,^,^413,^,^417,^,^427,^,^431,^,^433,^,^460,^,^475,^,^477,^,^478,^,^480,^,^483,^,^503,^,^512,^,^519,^,^528,^,^530,^,^531,^,^536,^,^539,^,^541,^,^554,^,^558,^,^562,^,^567,^,^594,^,^603,^,^615,^,^616,^,^618,625^–^627,^,^651,^,^665,^,^666,^,^677,^,^683,^,^706,^,^714,^,^746,^,^751,^,^754,^,^777,^,^782,^,^796,^,^805,^,^811,^,^829,^,^832,836^–^839,^,^841,^,^844,^,^852,^,^858,^,^895,^,^919,^,^930,^,^932,^,^943,^,^946,^,^956,^,^959,^,^961,^,^965,^,^977,^,^998,999a754b78,^,^191,^,^225,^,^287,^,^397,^,^759,^,^764,^,^793,^,^882,940^
Before-and-after studies | Before-and-after studies with study population representative of the target population (n=3) ^294,^,^697,847^
| Before-and-after studies in which the method of outcome assessment was the same for the pre- and post- intervention periods for all participants (n=74) ^83,^,^133,294^–^298,300^–^303,^,^310,312^–^323,^,^426,^,^442,^,^459,^,^468,^,^491,^,^510,^,^517,^,^524,^,^525,^,^559,^,^608,^,^634,652^–^654,^,^733,^,^750,^,^753,^,^766,^,^797,^,^801,^,^802,812^–^815,^,^822,^,^831,^,^843,^,^847,^,^848,^,^850,^,^851,^,^856,^,^862,^,^863,^,^867,^,^870,^,^872,^,^875,^,^883,^,^889,^,^891,^,^897,^,^906,^,^913,^,^914,^,^982,^,^992,1002^
| Before-and-after studies in which outcome assessors were blind to intervention and assessment period (n=2) ^654,753^
| Before-and-after studies that reported the number of study withdrawals (n=12) ^295,^,^296,^,^442,^,^525,^,^559,^,^733,^,^753,^,^797,^,^801,^,^814,^,^851,897^
| Before-and-after studies that reported the reasons for study withdrawal (n=6) ^442,^,^525,^,^559,^,^733,^,^801,897^

Table I5 Clinical trials and before-and-after studies on physiological and neuropsychological effects of meditation practices

Category of meditation practices | Meditation practice | N | Associated references
Mantra meditation (105) | ACEM meditation | 3 | ^956,^ ^959,^ ^961^
| CSM | 4 | ^97,^ ^264,^ ^536,^ ^627^
| Mantra meditation | 17 | ^203,^,^260,^,^483,^,^494,706b194,^,^503,^,^531,^,^577,^,^626,652^–^654,^,^777,^,^805,^,^856,965^
| RR | 34 | ^208,^ ^234,^ ^236,^ ^304,^ ^306,^ ^459,^ ^460,^ ^475,^ ^477,^ ^480a^ ^306b^ ^91,^ ^94,^ ^191,^ ^209,^ ^218,^ ^228,^ ^265,^ ^283,^ ^284,^ ^288,^ ^396,^ ^521,^ ^524,^ ^525,^ ^530,^ ^558,^ ^567,^ ^594,^ ^616,^ ^625,^ ^678,^ ^753,^ ^938^
| TM® | 47 | ^78,^,^86,^,^188,^,^190,^,^205,^,^206,^,^210,220^–^222,^,^252,^,^279,^,^282,^,^289,291^–^293,^,^295,^,^309,^,^311,^,^319,^,^392,^,^407,^,^418,^,^429,^,^433,^,^440,^,^463,^,^478,^,^518,^,^519,^,^528,^,^545,^,^677,^,^683,^,^714,^,^733,^,^750,^,^759,^,^782,^,^793,^,^796,^,^814,^,^815,^,^850,^,^974,1002^
Mindfulness meditation (44) | MBSR | 12 | ^244,^ ^263,^ ^272,^ ^419,^ ^512,^ ^517,^ ^602,^ ^681,^ ^697,^ ^754,^ ^930a^ ^754b^
| MM (NS) | 8 | ^106,^ ^241,^ ^386,^ ^430,^ ^442,^ ^696,^ ^751,^ ^932^
| Zen Buddhist meditation | 10 | ^197,^ ^225,^ ^227,^ ^237,^ ^426,^ ^500,^ ^554,^ ^639,^ ^913,^ ^916^
| MBCT | 2 | ^427,^ ^940^
| Vipassana | 2 | ^847,^ ^848^
Meditation practices (ND) | | 9 | ^198,^ ^199,^ ^215,^ ^274,^ ^387,^ ^431,^ ^539,^ ^651,^ ^915^
Qigong | | 15 | ^207,^ ^211,^ ^213,^ ^214,^ ^262,^ ^299,^ ^316,^ ^405,^ ^634,^ ^875,^ ^889,^ ^891,^ ^914,^ ^919,^ ^977^
Tai Chi | | 38 | ^223,^,^235,^,^246,^,^248,285^–^287,^,^290,^,^296,^,^307,^,^317,^,^326,^,^391,^,^397,^,^398,^,^409,^,^413,^,^435,^,^489,^,^541,^,^596,^,^603,^,^608,^,^665,^,^713,^,^746,^,^766,^,^872,^,^878,^,^882,^,^883,^,^894,^,^895,^,^897,^,^906,^,^955,^,^999,1001^
Yoga | | 110 | ^83,^,^126,^,^127,^,^133,^,^134,^,^137,^,^140,^,^168,176^–^183,^,^185,^,^204,^,^212,^,^216,^,^217,^,^219,^,^224,^,^226,^,^233,238^–^240,^,^247,^,^250,^,^273,^,^278,^,^280,^,^281,^,^294,^,^297,^,^298,300^–^303,^,^305,^,^308,^,^310,312^–^315,^,^318,320^–^323,^,^325,^,^389,^,^417,^,^468,^,^491,^,^510,^,^544,^,^559,^,^562,^,^615,^,^618,^,^642,^,^666,^,^764,^,^794,^,^797,^,^799,^,^801,^,^802,^,^806,811^–^813,^,^818,^,^822,^,^824,^,^829,^,^831,^,^832,^,^834,836^–^839,^,^841,^,^843,^,^844,^,^851,^,^852,^,^858,^,^860,862^–^864,866^–^868,^,^870,^,^926,^,^943,^,^946,^,^966,^,^981,^,^982,^,^991,^,^992,998^

CSM = clinically standardized meditation; MBCT = mindfulness-based cognitive therapy; MBSR = mindfulness-based stress reduction; MM = mindfulness meditation; ND = not described; NS = not specified; RR = Relaxation Response; TM® = Transcendental Meditation®

Studies reporting outcome measures on the physiological and neuropsychological effects of meditation practices

Domain | Category | Subcategory | N | Studies reporting outcome measure
| Blood system (15) | Blood composition | 11 | ^213,^ ^273,^ ^302,^ ^309,^ ^320,^ ^746,^ ^794,^ ^843,^ ^919,^ ^926,^ ^977^
| | Blood enzyme | 4 | ^273,^ ^313,^ ^862,^ ^863^
| Cardiovascular system (186) | Blood gas measurement | 8 | ^233,^ ^296,^ ^320,^ ^524,^ ^813,^ ^839,^ ^891,^ ^998^
| | Cardiovascular functioning | 169 | ^213,^,^246,^,^250,^,^296,^,^297,^,^321,^,^426,^,^811,906^,^83,^,^106,^,^140,^,^185,^,^190,^,^199,^,^206,^,^208,^,^214,^,^217,^,^218,^,^221,^,^223,^,^224,^,^226,^,^235,^,^248,^,^252,^,^264,280^–^283,^,^286,^,^294,^,^299,^,^306,^,^307,^,^316,^,^323,^,^326,^,^326,^,^392,^,^396,^,^429,^,^480,^,^521,^,^525,^,^536,^,^562,^,^651,^,^733,^,^753,^,^777,^,^796,^,^813,^,^822,^,^834,^,^838,^,^838,^,^851,^,^852,^,^856,^,^858,^,^858,^,^894,^,^914,^,^916,^,^961,^,^966,9821306286,91,^,^94,^,^97,^,^126,^,^127,^,^134,^,^180,^,^194,^,^197,203^–^205,^,^207,209^–^212,^,^215,^,^216,^,^219,^,^220,^,^222,^,^225,^,^227,^,^228,^,^234,^,^236,^,^237,^,^241,^,^244,^,^260,^,^265,^,^278,^,^279,^,^284,^,^285,287^–^292,^,^295,302^–^305,309^–^313,^,^317,^,^319,^,^320,^,^322,^,^387,^,^389,^,^391,^,^433,^,^435,^,^442,^,^459,^,^460,^,^475,^,^483,^,^491,^,^510,^,^517,^,^524,^,^528,^,^530,^,^531,^,^539,^,^541,^,^577,^,^608,^,^616,^,^627,^,^652,^,^677,^,^696,^,^714,^,^806,^,^831,^,^839,^,^844,^,^862,^,^872,^,^883,^,^897,^,^915,^,^926,^,^932,^,^956,^,^998,1002^
| | Energy expenditure | 2 | ^233,^ ^491^
| | Physical performance | 7 | ^240,^ ^246,^ ^391,^ ^397,^ ^409,^ ^666,^ ^813^
Physiological | Digestive system (26) | Gastric function | 1 | ^852^
| | Lipoproteins | 25 | ^205^–^207,^,^213,^,^218,^,^223,238^–^240,^,^247,^,^250,^,^273,^,^278,^,^280,^,^282,^,^291,^,^292,^,^302,^,^313,^,^317,^,^794,^,^801,^,^850,^,^926,1002^
| Endocrine system (62) | Adrenocortical functioning | 26 | ^106,^ ^207,^ ^214,^ ^226,^ ^236,^ ^244,^ ^246,^ ^263,^ ^272,^ ^273,^ ^283,^ ^299,^ ^307,^ ^313,^ ^386,^ ^405,^ ^407,^ ^417,^ ^419,^ ^433,^ ^651,^ ^764,^ ^806,^ ^850,^ ^862,^ ^955^
| | Carbohydrate metabolism | 18 | ^273,^ ^278,^ ^282,^ ^298,^ ^301,^ ^308,^ ^313,^ ^317,^ ^321,^ ^391,^ ^405,^ ^794,^ ^801,^ ^850,^ ^862,^ ^914,^ ^961,^ ^999^
| | CNS hormone | 11 | ^211,^ ^246,^ ^313,^ ^386,^ ^405,^ ^407,^ ^433,^ ^806,^ ^811,^ ^889,^ ^956^
| | Genital gland secretion | 1 | ^433^
| | Parathyroid function | 4 | ^273,^ ^407,^ ^713,^ ^889^
| | Thyroid function | 2 | ^836,^ ^889^
| Immune system (14) | Cellular immunity | 7 | ^386,^ ^405,^ ^419,^ ^642,^ ^843,^ ^959,^ ^977^
| | Humoral immunity | 7 | ^299,^ ^386,^ ^398,^ ^512,^ ^558,^ ^697,^ ^977^
| Musculos keletal system (35) | Body index | 2 | ^391,^ ^559^
| | Bone density test | 6 | ^280,^ ^596,^ ^713,^ ^872,^ ^895,^ ^1001^
| EMG | | 23 | ^190,^ ^199,^ ^306,^ ^392,^ ^766,^ ^837a^ ^306b^ ^290,^ ^503,^ ^531,^ ^577,^ ^626,^ ^627,^ ^683,^ ^847,^ ^965^ ^191,^ ^228,^ ^274,^ ^477,^ ^639,^ ^844,^ ^882^
| Isometric contraction | | 3 | ^413,^ ^489,^ ^872^
| Reflex test | | 1 | ^750^
| Nervous system (63) | Autonomic functioning | 1 | ^852^
| | Brain electrophysiology | 17 | ^133,^ ^226,^ ^417,^ ^426,^ ^512,^ ^519,^ ^545,^ ^594,^ ^627,^ ^634,^ ^706,^ ^733,^ ^805,^ ^814,^ ^815,^ ^913,^ ^916^
| | Neuroendocrine measurement | 7 | ^227,^ ^273,^ ^407,^ ^433,^ ^806,^ ^850,^ ^863^
Physiological | | Peripheral nerve test | 40 | ^754a^ ^83,^ ^140,^ ^190,^ ^199,^ ^226,^ ^294,^ ^306,^ ^323,^ ^392,^ ^417,^ ^544,^ ^545,^ ^733,^ ^777,^ ^796,^ ^824,^ ^856,^ ^858,^ ^981a^ ^306b^ ^188,^ ^204,^ ^260,^ ^265,^ ^288,^ ^312,^ ^440,^ ^463,^ ^477,^ ^478,^ ^483,^ ^531,^ ^577,^ ^627,^ ^652,^ ^844,^ ^847,^ ^848,^ ^938^
| Nutrition/metabolism (32) | Antioxidants | 3 | ^137,^ ^238,^ ^799^
| | Cell metabolism | 1 | ^281^
| | Metabolic product | 16 | ^137,^ ^262,^ ^273,^ ^313,^ ^320,^ ^417,^ ^653,^ ^713,^ ^746,^ ^799,^ ^806,^ ^834,^ ^838,^ ^844,^ ^862,^ ^870^
| | Salivary test | 2 | ^198,^ ^654^
| | Serum protein | 6 | ^106,^ ^227,^ ^273,^ ^313,^ ^850,^ ^862^
| Ocular system (4) | Ophthalmologic test | 4 | ^176,^ ^297,^ ^315,^ ^625^
| Respiratory system (68) | Pulmonary function test | 68 | ^83,^ ^106,^ ^140,^ ^168,^ ^190,^ ^199,^ ^214,^ ^248,^ ^280,^ ^294,^ ^296,^ ^300,^ ^306,^ ^314,^ ^316,^ ^321,^ ^323,^ ^325,^ ^326,^ ^429,^ ^468,^ ^521,^ ^733,^ ^797,^ ^802,^ ^811,^ ^813,^ ^829,^ ^832,^ ^834,^ ^843,^ ^856,^ ^858,^ ^868,^ ^966,^ ^981,^ ^991a^ ^306b^ ^86,^ ^94,^ ^183,^ ^236,^ ^244,^ ^288,^ ^309,^ ^310,^ ^312,^ ^313,^ ^320,^ ^442,^ ^510,^ ^524,^ ^530,^ ^531,^ ^577,^ ^608,^ ^652,^ ^759,^ ^818,^ ^839,^ ^844,^ ^862,^ ^866,^ ^875,^ ^932,^ ^943,^ ^992,^ ^998^
| Sensory system (3) | Auditory test | 3 | ^300,^ ^946,^ ^981^
Physiological | Thermoregulatory system (10) | Body temperature | 10 | ^134,^ ^199,^ ^313,^ ^392,^ ^503,^ ^531,^ ^608,^ ^696,^ ^838,^ ^844^
| Urinary/excretory system (9) | Renal function | 7 | ^207,^ ^226,^ ^227,^ ^273,^ ^278,^ ^319,^ ^407,^ ^1012^
| | Salivary test | 2 | ^198,^ ^654^
Cognitive/neuropsychological | Cognitive/neuropsychological (93) | Attention | 19 | ^754a^ ^754b^ ^78,^ ^182,^ ^208,^ ^280,^ ^294,^ ^387,^ ^577,^ ^602,^ ^666,^ ^678,^ ^751,^ ^793,^ ^838,^ ^841,^ ^848,^ ^930,^ ^974^
| | Creativity | 4 | ^293,^ ^500,^ ^615,^ ^915^
| | Intelligence | 4 | ^78,^ ^309,^ ^793,^ ^863^
| | Language | 7 | ^754a^ ^78,^ ^177,^ ^178,^ ^181,^ ^279,^ ^793^
| | Memory | 12 | ^280,^ ^294,^ ^494b^ ^78,^ ^310,^ ^431,^ ^793,^ ^815,^ ^863,^ ^867,^ ^930,^ ^940^
| | Other cognitive functions | 11 | ^273,^ ^279,^ ^280,^ ^310,^ ^618,^ ^665,^ ^681,^ ^863,^ ^930,^ ^974,^ ^999^
| | Perception | 12 | ^417,^ ^494,^ ^860b^ ^78,^ ^208,^ ^418,^ ^518,^ ^554,^ ^616,^ ^654,^ ^915,^ ^974^
| | Reasoning | 10 | ^78,^ ^178,^ ^279,^ ^427,^ ^518,^ ^567,^ ^681,^ ^782,^ ^915,^ ^930^
| | Sensory motor functions | 10 | ^106,^ ^263,^ ^280,^ ^300,^ ^309,^ ^318,^ ^539,^ ^812,^ ^848,^ ^878^
| | Spatial ability | 4 | ^78,^ ^177,^ ^178,^ ^181^

CNS = central nervous system; EMG = electromyography