# Appendix H. Characteristics of Clinical Trials of Meditation Practices for the Three Most Studied Conditions

Table H1 Characteristics of clinical trials of meditation practices in hypertension

Study, country | Study design, followup duration, ITT | Characteristics of study population | | Intervention | | Comparison groups | | Outcomes | Authors' conclusions
| | Age (mean/range), gender, diagnosis | N participants | Type/name | N participants | Type/name | N participants
Aivazyan, TA 1988^203^ | RCT parallel 2 arms | 35.7 yr | R: 146 | Composite | R: 90 | NT | R: 56 | Primary: BP changes (SBP, DBP) | The intervention produced a significant antihypertensive effect lasting for 1 yr in outpatients with mild hypertension
Russia | Duration: 12 mo | F = 0 | C: 117 | Mantra meditation + relaxation techniques | C: 70 | | C: 47 | Secondary: time of BP restoration, HRQL, emotional stress, number of sick leaves | The intervention produced reduction in psychophysiological reactivity
| ITT: yes | M = 117 | W: 29 | | W: 20 | | W: 9 | | The intervention produced improvement in psychological adaptation and capacity for work
| | Mild HT (DBP 90–105 mm Hg)
Broota A, 1995^204^ | RCT parallel 4 arms | 35–59 yr | R: NR | Single | R: NR | Broota | R: NR | Primary: BP changes (SBP, DBP) | The three therapies are effective in reducing symptoms of hypertension when compared to the NT group
India | Duration: 8 d | F = 0 | C: 40 | | C: 10 | | C: 10 | Secondary: anxiety, GSR | Yoga was the most effective followed by the Broota technique and PMR
| ITT: No | M = 40 | W: NR | Yoga | W: NR | | W: NR
| | Essential HT (NR) | | | | PMR | R: NR
| | | | | | | C: 10
| | | | | | | W: NR
| | | | | | NT | R: NR
| | | | | | | C: 10
| | | | | | | W: NR
Calderon R Jr, 2000^205^ | RCT parallel 2 arms | 53.9 yr | R: 146 | Single | R: NR | HE | R: NR | Primary: TC, TG. LDL-C, HDL-C | There were no significant reductions in TC, TG, LDL-C and no significant increase in HDL-C between groups
United States | Duration: 6 mo | F = 48 | C: 72 | | C: 36 | | C: 36 | Secondary: BP changes, PR, anger, personal efficacy, diet, stress, physical activity | Both groups showed significant positive changes in BP, PR, diet, and psychological measures
| ITT: NR | M = 24 | W: 74 | TM^®^ | W: NR | | W: NR
| | Mild HT (SBP 130–140 mm Hg and DBP 85–89 mm Hg or SBP 140–150 mm Hg and DBP 90–99 mm Hg)
Castillo-Richmond A, 2000^206^ | RCT parallel 2 arms | 53.8 yr | R: 138 | Single | R: NR | HE | R: NR | Primary: cIMT | Stress reduction with TM^®^ is associated with reduced cIMT
United States | Duration: 9 mo | F = 41 | C: 60 | | C: 31 | | C: 29 | Secondary: BP changes, weight, PR, pulse pressure, TC, HDL-C, LDL-C, smoking, exercise | There were no significant changes associated with TM^®^ for the other outcomes
| ITT: Yes | M = 19 | W: 78 | TM^®^ | W: NR | | W: NR
| | Mild to moderate HT (SBP 130–139 mm Hg and DBP 80–85 mm Hg [high normal]; SBP 140–159 mm Hg and DBP 90–99 mm Hg [stage I]; SBP 160–179 mm Hg and DBP 100–109 mm Hg [stage 2])
Cheung BMY, 2005^207^ | RCT parallel 2 arms | 54.4 yr | R: 91 | Single | R: 47 | Exercise | R: 44 | Primary: BP, health status, anxiety, depression | Qi Gong and conventional exercise have similar effects on BP in patients with mild HT
Hong Kong | Duration: 16 wk | F = 51 | C: 88 | | C: 47 | | C: 44 | Secondary: HR, weight, BMI, body fat, waist/hip circumference, renin excretion, urinary albumin excretion, Na, K, urea, Cr, TC, HDL-C, LDL-C, TG, aldosterone, urine cortisolurine, Cr, urine Na, urine protein, LVMI, ejection fraction | Qi Gong is not superior to conventional exercise but can be used as an alternative to conventional exercise in those who prefer it as a form of nonpharmacological management of HT
| ITT: Yes | M = 37 | W: 3 | Qi Gong | W: 0 | | W: 3
| | Mild HT (SBP 140–170 mm Hg and/or DBP 90–105 mm Hg)
Cohen J, 1983^208^ | RCT parallel 3 arms | 44.5 yr | R: NR | Single | R: NR | BF | R: NR | Primary: attention (field independence, attention deployment, absorption) | The BF group became significantly more field independent than RR and WL groups
United States | Duration: 10 wk | F = 17 | C: 30 | | C: 10 | | C: 10 | Secondary: BP changes (SBP, DBP) | Increase in field independence in the BF group correlated with decreases in BP
| ITT: NR | M = 13 | W: NR | RR | W: NR | | W: NR
| | Essential HT (NR) | | | | WL | R: NR
| | | | | | | C: 10
| | | | | | | W: NR
Hafner RJ, 1982^185^ | RCT parallel 3 arms | 48.9 yr | R: 24 | Composite | R: 8 | Yoga | R: 8 | Primary: BP changes (SBP, DBP) | The addition of BF to meditation does not enhance reduction of BP
United Kingdom | Duration: 3 mo | F = NR | C: 22 | | C: 7 | | C: 7 | Secondary: hostility, assertive behavior, psychological symptoms | Overall reductions in blood pressure were not significantly greater in either program than in the control group
| IIT: NR | M = NR | W: 2 | Yoga + BF | W: 1 | | W: 1
| | Essential HY (NR) | | | | NT | R: 8
| | | | | | | C: 8
| | | | | | | W: 0
Hager JL, 1978^209^ | RCT parallel 2 arms | Age NR | R: 30 | Single | R: NR | BF (BP) | R: NR | Primary: BP changes (SBP, DBP) | Neither RR nor BF (BP) reduced SBP over the followup period
United States | Duration: 4 wk | F = NR | C: 17 | | C: 10 | | C: 7 | | Differences between RR and BF in BP reductions were not significant
| ITT: No | M = NR | W: 13 | RR | W: NR | | W: NR
| | BHT (SBP >145 mm Hg and/or DBP >95 mm Hg)
Kondwani KA, 1998^210,229^ | RCT parallel 2 arms | 50.7 yr | R: 42 | Single | R: 22 | HE | R:20 | Primary: LVMI | Both TM^®^ and health education reduced LVMI
United States | Duration: 1 yr | F = 19 | C: 34 | | C: 19 | | C:15 | Secondary: BP changes (SBP, DBP), weight, HR, PWT, LVIDD, LVIDS, IVST, E/A ratio, energy, sleep, positive affect, sleep pattern, anxiety, depression, anger, self-efficacy, locus of control, diet, activity level, compliance | The TM^®^ group showed significant improvements in HRQL, diastolic function and DBP
| ITT:NR | M = 15 | W: 8 | TM^®^ | W: 3 | | W: 5
| | Mild HT (DBP 90– 104 mm Hg)
Kuang AK, 1987^211^ | RCT parallel 2 arms | 40–60 yr | R: NR | Composite | R: NR | AHM | R: NR | Primary: plasma 18-OH-DOC levels | The addition of Qi Gong to AHM significantly reduced BP and plasma l8-0H-DOC
China | Duration: 1 yr | F = 0 | C: 46 | | C: 23 | | C: 23 | Secondary: BP changes (SBP, DBP)
| ITT: NR | M = 46 | W: NR | Qi Gong + AHM | W: NR | | W: NR
| | Essential HT (DBP 100–120 mm Hg)
Latha DR, 1991^212^ | RCT parallel 2 arms | 45–70 yr | R: 23 | Composite | R: NR | HE | R: NR | Primary: BP changes (SBP, DBP) | Training in yoga + BF was moderately effective in reducing SBP
India | Duration: 6 mo | F = NR | C: 14 | | C: 7 | | C: 7 | Secondary: AHM intake, stress control, negative responses to stress, coping behavior, somatic symptoms, symptom severity | Thermal BF seems to be more effective in reducing DBP
| ITT: NR | M = NR | W: 9 | Yoga + BF (thermal) | W: NR | | W: NR | | Training in Yoga and thermal BF was least effective in altering the perceptions associated with stressful experiences
| | Essential HT (NR)
Lee MS, 2003^214,230^ | RCT parallel 2 arms | 56.2 yr | R: 65 | Single | R: 33 | WL | R: 32 | Primary: BP changes (SBP, DBP, RPP) | Qi Gong reduced SBP, DBP, NE, EPI, cortisol, and stress levels
South Korea | Duration: 10 wk | F = 35 | C: 58 | | C: 29 | | C: 29 | Secondary: HR, PR, EPI, NE, FVC,^230^ FEV_1_,^230^ cortisol, stress level | Qi Gong significantly improved ventilation functions
| ITT: NR | M = 23 | W: 7 | Qi Gong | W: 4 | | W: 3 | | Qi Gong is an effective nonpharmacological modality to reduce BP in essential HT
| | Essential HT (SBP 140–180 mm Hg and DBP 90–100 mm Hg)
Lee MS, 2004^213,231^ | RCT parallel 2 arms | 53.4 yr | R: 47 | Single | R: 23 | WL | R: 24 | Primary: BP changes (SBP, DBP) | Qi Gong significantly reduced BP and changed lipid metabolism
South Korea | Duration: 8 wk | F = 22 | C: 36 | | C: 17 | | C: 19 | Secondary: APOA1, TC, HDL-C, TG, selfefficacy^231^ | Qi Gong significantly enhances perceptions of self-efficacy
| ITT: NR | M = 14 | W: 11 | Qi Gong | W: 6 | | W: 5
| | Essential HT (SBP 140–180 mm Hg and DBP 90–105 mm Hg)
Manikonda P, 2005^215^ | RCT parallel 2 arms | 30–70 yr | R: NR | Single | R: NR | NT | R: NR | Primary: BP changes | CMBT effectively reduces BP
Germany | Duration: 8 wk | F = 18 | C: 52 | | C: 26 | | C: 26
| ITT: NR | M = 34 | W: NR | CMBT | W: NR | | W: NR
| | Mild to moderate HT (JNC7 criteria)
McCaffrey R, 2005^216^ | RCT parallel 2 arms | 56.4 yr | R: 61 | Single | R: 32 | HE | R: 29 | Primary: stress, BP changes (SBP, DBP) | Practicing Yoga for 8 wk reduces stress, BP, BMI, and HR
Thailand | Duration: 8 wk | F = 35 | C: 54 | | C: 27 | | C: 27 | Secondary: BMI, HR
| ITT: NR | M = 19 | W: 7 | Yoga | W: 5 | | W: 2
| | Mild to moderate HT (BP>140/90 mm Hg)
Murugesan R, 2000^217^ | RCT parallel 3 arms | 35–65 yr | R: NR | Single | R: NR | AHM | R: NR | Primary: stress, BP changes (SBP, DBP) | Yoga was more effective than AHM in controlling SBP, PR, and weight, but not DBP
India | Duration: 11 wk | F = NR | C: 33 | | C: 11 | | C: 11 | Secondary: PR, weight
| ITT: NR | M = NR | W: NR | Yoga | W: NR | | W: NR
| | Essential HT (NR) | | | | NR | R: NR
| | | | | | | C: 11
| | | | | | | W: NR
Patel CH, 1985^218^ | RCT parallel 2 arms | 35–64 yr | R: 204 | Composite | R: 107 | HE | R: 97 | Primary: BP changes (SBP, DBP), TC | There was a significantly greater reduction in SBP, DBP and smoking in the intervention group compared to the control at 8 wk and 8 mo
United Kingdom | Duration: 8 wk8 mo4 yr | F = 74 | C: 192 | | C: 99 | | C: 93 | Secondary: smoking, morbidity, mortality | No significant differences in TC were found between the groups
| ITT: NR | M = 118 | W: 12 | RR + BE + PMR | W: 8 | | W: 4 | | Differences in BP between groups were maintained at 4-yr followup
| | Mild HT (BP>140/90 mm Hg) | | | | | | | Incidence of IHD and MI was significantly greater in the control group at 4- yr followup
Patel CH 1975^219^ | RCT parallel 2 arms | 59 yr | R: 36 | Composite | R: 18 | Rest | R: 18 | Primary: BP changes (SBP, DBP) | There was a significantly greater reduction in SBP and DBP in the intervention group compared with the control
United Kingdom | Duration: 6 wk | F = 21 | C: 34 | | C: 17 | | C: 17
| ITT: NR | M = 13 | W: 2 | Yoga + BF | W: 1 | | W: 1
| | Essential HT (DBP ≥110mm Hg)
Schneider RH, 1995^79,^,^221,232^ | RCT parallel 3 arms | 66.8 yr | R: 127 | Single | R: 40 | PMR | R: 42 | Primary: BP changes (SBP, DBP) | TM^®^ was was approximately twice as effective as PMR in controlling BP
United States | Duration: 3 mo | F = 64 | C: 111 | | C: 36 | | C: 37 | Secondary: compliance
| ITT: yes | M = 47 | W: 16 | TM^®^ | W: 4 | | W: 5
| | Mild HT (SBP ≤ 189 mm Hg and DBP 90–109 mm Hg) | | | | HE | R: 45
| | | | | | | C: 38
| | | | | | | W: 7
Schneider RH, 2005^220^ | RCT parallel 3 arms | 48.5 yr | R: 197 | Single | R: 65 | PMR | R: 68 | Primary: BP changes (SBP, DBP) | TM^®^ significantly decreased DBP more than PMR or HE, and there was a trend for a greater reduction in SBP
United States | Duration: 1 yr | F = 79 | C: 150 | | C: 54 | | C: 52 | Secondary: change in AHM | There was a significant reduction in AHM use in the TM^®^ group compared with PMR and HE
| ITT: yes | M = 71 | W: 47 | TM^®^ | W: 11 | | W: 16
| | Mild to moderate HT (SBP 140–179 or DBP 90–109mm Hg) | | | | HE | R: 64
| | | | | | | C: 44
| | | | | | | W: 20
Seer P, 1980^222^ | RCT parallel 3 arms | 43.3 yr | R: 41 | Single | R: 14 | PLB | R: 14 | Primary: BP changes (SBP, DBP) | There were modest reductions in blood pressure in both TM^®^ and placebo groups (identical training but without a mantra)
New Zealand | Duration: 3 mo | F = 18 | C: 36 | | C: 12 | | C: 11
| ITT: NR | M =23 | W: 5 | SRELAX (technique modeled after TM^®^) | W: 2 | | W: 3
| | Essential HT (DBP ≥ 100 mm Hg) | | | | WL | R: 13
| | | | | | | C: 13
| | | | | | | W: 0
Selvamurthy W, 1998^226^ | NRCT parallel 2 arms | 41.7 yr | E: NR | Single | E: NR | Orthostatic tilt | E: NR | Primary: BP changes (SBP, DBP) | Both Yoga and orthostatic tilt restored BP to normal level
India | Duration: 3 wk | F = 0 | C: 20 | | C: 10 | | C: 10 | Secondary: AIEEG, CO, HR, NE, EPI, PRA, urine K, urine Na, CPR | Both interventions dropped CO, HR, CPR, NE, EPI, PRA and increased AI-EEG
| ITT: NR | M = 20 | W: NR | Yoga | W: NR | | W: NR
| | Essential HT (SBP>140 mm Hg and DBP >90 mm Hg)
Stone RA, 1976^227^ | NRCT parallel 2 arms | 28 yr | E: NR | Single | E: NR | BP checks | E: NR | Primary: BP changes (SBP, DBP) | Meditation significantly improved BP control in certain patients with mild or moderate HT
United States | Duration: 6 mo | F = 2 | C: 19 | | C: 14 | | C: 5 | Secondary: changes in plasma DBH, plasma volume, PRA | PRA levels were significantly lower in the meditation group
| ITT: NR | M = 17 | W: NR | Zen Buddhist meditation | W: NR | | W: NR | | No differences in PRA and plasma were found
| | Mild to moderate HT (DBP > 105 mm Hg)
Surwit RS, 1978^228^ | NRCT parallel 3 arms | 46.4 yr | E: NR | Single | R: NR | BF (EMG) | E: NR | Primary: BP changes (SBP, DBP) | All groups showed moderate reductions in BP No technique produced a reduction in BP greater than baseline values
United States | Duration: 6 wk | F = 5 | C: 24 | | C: 8 | | C: 8
| ITT: NR | M =19 | W: NR | RR | W: NR | | W: NR
| | BHT (SBP ≥ 140 mm Hg or DBP ≥ 90 mm Hg) | | | | BF (BP) | E: NR
| | | | | | | C: 8
| | | | | | | W: NR
Tsai JC, 2003^223^ | RCT parallel 2 arms | 52 yr | R: 88 | Single | R: 44 | NT | R: 44 | Primary: BP changes (SBP, DBP) | Tai Chi decreased blood pressure produced favorable lipid profile changes and improved anxiety status in subjects with mild hypertension
Taiwan | Duration: 12 wk | F = 38 | C: 76 | | C: 37 | | C: 39 | Secondary: HR, TC, HDL-C, LDLC, TG, BMI, anxiety
| ITT: NR | M = 38 | W: 12 | Tai Chi | W: 7 | | W: 5
| | Borderline and Mild HT (SBP 130–159 mm Hg or DBP 85 –99 mm Hg)
van Montfrans GA, 1990^224^ | RCT parallel 2 arms | 41.4 yr | R: 42 | Composite | R: 23 | Rest | R: 19 | Primary: BP changes (SBP, DBP) | No relevant changes in BP or other parameters were found both in the intervention and the control groups
Netherlands | Duration: 1 yr | F = 17 | C: 35 | | C: 18 | | C: 17 | Secondary: body weight, urine Na, TC
| ITT: NR | M = 18 | W: 7 | Yoga + RR + PMR + AT | W: 5 | | W: 2
| | Mild HT (SBP 160–200 mm Hg and/or DBP 95–119 mm Hg)
Yen LL, 1996^225^ | RCT parallel 4 arms | 54.5 yr | R: 392 | Composite | R: NR | BP | R: NR | Primary: BP changes (SBP, DBP) | Zen Buddhist meditation + PMR, BP checks, and HE were significant and similarly effective in reduction of SBP compared with the NT group
China | Duration: 2 mo | F = 107 | C: 299 | | C: 56 | checks | C: 64
| ITT: NR | M = 192 | W: 93 | Zen Buddhist meditation + PMR | W: NR | | W: NR
| | Mild to moderate HT (SBP ≥ 140 mm Hg or DBP ≥ 90 mm Hg) | | | | HE | R: NR
| | | | | | | C: 69
| | | | | | | W: NR
| | | | | | NT | R: NR
| | | | | | | C: 110
| | | | | | | W: NR

® AHM = anti-hypertensive medication; AI = alpha index; APO-A1 = apolipoprotein A1; AT = autogenic training; BE = breathing exercises; BF = biofeedback; BHT = borderline hypertension; BMI = body mass index; BP = blood pressure; C = number completed; cIMT = carotid intima media thickness; CMBT = contemplative meditation with breathing techniques; CO = cardiac output; CPR = cold pressor response; Cr = creatinine; d = day(s); DBH = dopamine beta hydroxylase; DBP = diastolic blood pressure; E = number enrolled (for NRCTs); E/A ratio = early filling divided by atrial constriction; EEG = electroencephalogram; EMG = electromyography; EPI = epinephrine; FEV1 forced expiratory volume in 1 second; FVC = forced vital capacity; GSR = galvanic skin response; HDL-C = high density lipoprotein cholesterol; HE = health education; HR = heart rate; HRQL = health-related quality of life; HT = hypertension; IHD = ischemic heart disease; ITT = intention to treat; IVST = intraventricular septal thickness; JNC 7 = Joint National Committee 7; K = potassium; LDL-C = low density lipoprotein cholesterol; LVIDD = left ventricular internal dimension at diastole; LVDIS = left ventricular internal dimension at systole; LVMI = left ventricular mass index; MI = myocardial infarction; mo = month(s); Na = sodium; NA = not applicable; NE = norepinephrine; NR = not reported; NRCT = nonrandomized controlled trial; NS = not specified; NT = no treatment; PLB = placebo; PMR = progressive muscle relaxation; PRA = plasma renin activity; pR = Pulse rate; PWT = posterior wall thickness; R = number randomized (for RCTs); RPP = rate pressure product; RR = Relaxation Response; SBP = systolic blood pressure; TC = total cholesterol; TG = triglycerides; TM = Transcendental Meditation; wk = week(s); UC = usual care; W = number withdrawals/losses to folloup; WL = waiting list; yr = year(s); 18-OH-OHDOC = hydroxydeoxycorticosterone

Table H2 Characteristics of clinical trials of meditation practices in cardiovascular diseases

Study, country | Study, design, followup duration, ITT | Characteristics of study population | | Intervention | | Comparison groups | | Outcomes | Authors' conclusions
| | Age (mean/range), gender, diagnosis | N participants | Type/name | N participants | Type/name | N participants
Ades PA, 2005^233,253^ | RCT 2 arms | 72.7 yr | R: 51 | Composite | R: NR | Resistance training | R: NR | Primary: TEE | Resistance training was associated with significant increases in upper and lower body strength, but no change in fat-free mass or left ventricular function
United States | Duration: 6 mo. | F = 42 | C: 42 | | C: 21 | | C: 21 | Secondary: body Strength, body weight, BMI, fat free mass, left ventricular function, VO_2_ max, depression | Women in the Yoga group showed no changes in TEE
| ITT: NR | M = 0 | W: 9 | Yoga + BE | W: NR | | W: NR | | There were no differences between groups in body composition, aerobic capacity or measures of depression
| | CHD
Chang BH, 2005^234^ | RCT parallel 3 arms | 69.2 yr. | R: 95 | Single | R: 34 | HE | R: 32 | Primary: HRQL | The RR group had significantly better HRQL change scores in peacespiritual scales than did the UC. No significant difference was observed between the HE and UC groups
United States | Duration: 19 wk | F = 1 | C: 83 | | C: 31 | | C: 24 | Secondary: VO_2_ max | No statistically significant intervention effect on physical HRQL or exercise capacity was observed
| ITT: yes | M = 94 | W: 12 | RR | W: 3 | | W: 8
| | CHF | | | | UC (NS) | R: 29
| | | | | | | C: 28
| | | | | | | W: 1
Channer KS, 1996^235^ | RCT parallel 3 arms | 56 yr | R: 126 | Single | R: 38 | Exercise | R: 41 | Primary: BP changes (DBP, SBP) | There was a significant greater reduction in DBP in the Tai Chi group than in the exercise group
United Kingdom | Duration: 8 wk | F = 36 | C: 104 | | C: 31 | | C: 30 | Secondary: HR | Significant trends in SBP occurred for both Tai Chi and exercise groups
| ITT: NR | M = 90 | W: 22 | Tai Chi | W: 7 | | W: 11 | | Tai Chi was associated with a greater HR reduction than exercise
| | AMI | | | | HE | R: 47
| | | | | | | C: 43
| | | | | | | W: 4
Curiati JA, 2005^236^ | RCT parallel 2 arms | 74.7 yr | R: 19 | Composite | R: 10 | Group therapy | R: 9 | Primary: NE | RR + BE significantly reduced NE, VE/VCO_2_ slope, and improved HRQL
Brazil | Duration: 12 wk | F = 14 | C: 15 | | C: 8 | | C: 7 | Secondary: HRQL, VE/VCO_2_ slope, VO_2_, LVEF, LVDDi | No changes occurred in LVEF, LVDDi, or VO_2_
| ITT: NR | M = 5 | W: 4 | RR + BE | W: 2 | | W: 2
| | CHF
Friedman NL, 2002^237^ | RCT parallel 2 arms | 63 yr | R: 67 | Single | R: NR | HE | R: NR | Primary: HRV | Meditation singnificantly increased HRV compared with HE
United States | Duration: 90 min | F = 9 | C: 56 | | C: 28 | | C: 28
| ITT: NR | M = 47 | W: 11 | Zen Buddhist meditation | W: NR | | W: NR
| | CAD
Hipp A, 1998^247^ | NRCT parallel 2 arms | 64 yr | E: NR | Single | E: NR | NT | E: NR | Primary: TC | Yoga significantly reduced TC
Germany | Duration: 6 mo | F = 7 | C: 26 | | C: 20 | | C: 6 | Secondary: HDL- C, LDL-C, VLDL-C, TG | No significant effect on HDL-C, VLDL-C and TG was found
| ITT: NR | M = 19 | W: NR | Yoga | W: NR | | W: NR
| | CAD
Jatuporn S, 2003^238^ | RCT parallel 2 arms | 59 yr | R: 44 | Composite | R: 22 | LLM | R: 22 | Primary: total antioxidant status, vitamin C, vitamin E | Yoga + intensive lifestyle modification produced a signiificant increase in TC, HDL-C and decrease in TG and BMI
Thailand | Duration: 4 mo. | F = 9 | C: 44 | | C: 22 | | C: 22 | Secondary: TG, TC, HDL-C, LDL-C, P-MDA, erythrocyte GSH, BMI | Total antioxidant status, vitamin E and erythrocyte GSH were also increased
| ITT: NR | M = 35 | W: 0 | Yoga + intensive lifestyle modification program | W: 0 | | W: 0 | | There were no significant changes in P-MDA and vitamin C
| | CAD
Lan C, 1999^248^ | NRCT parallel 2 arms | 56.5 yr | E: 27 | Single | E: 12 | Exercise | E: 15 | Primary: peak VO_2_, | The Tai Chi group showed significant improvement in a 1-yr TCC program for low cardiorespiratory function
Taiwan | Duration: 1 yr. | F = 0 | C: 20 | | C: 9 | | C: 11 | Secondary: peak WR, HR
| ITT: NR | M = 27 | W: 7 | Tai Chi | W: 3 | | W: 4
| | CABS
Mahajan AS, 1999^239^ | RCT parallel 2 arms | 56–59 yr | R: 93 | Composite | R: 52 | Exercise + Diet changes | R: 41 | Primary: body weight, lipid profile (TC, HDL- C, LDL-C) | There were changes in body weight and lipid profile in both the control and intervention groups. However, the pattern of change was inconsistent in the controls
India | Duration: 14 wk | F = 0 | C: NR | | C: NR | | C: NR
| ITT: NR | M = 93 | W: NR | Yoga + diet changes | W: NR | | W: NR
| | CAD
Manchanda SC, 2000^240^ | RCT parallel 2 arms | 51.5 yr | R: 42 | Composite | R: 21 | Exercise + diet changes | R: 21 | Primary: number of angina episodes/wk, lesion severity, NYHA functional class | Yoga lifestyle intervention significantly improved NYHA functional class and reduced the number of angina episodes
India | Duration: 1 yr | F = 0 | C: NR | | C: NR | | C: NR | Secondary: exercise capacity, body weight, TC, HDL-C, LDL-C, TG | Yoga significantly decreased body weight, TC, LDL-C and TC. No changes were observed for HDL-C
| ITT: NR | M = 42 | W: NR | Yoga + diet + aerobic exercise | W: NR | | W: NR | | Yoga improved exercise duration and reduction in the degree of ST segment depression
| | CAD
Mandle CL, 1988^91,254^ | RCT parallel 3 arms | 59.8 yr | R: 45 | Single | R: 15 | Rest (1) Listening music | R: 14 | Primary: anxiety, pain | Patients in the RR group had significantly less anxietypainand medication use than both the music and blank tape groups
United States | Duration: NR | F = 28 | C: 45 | | C: 15 | | C: 14 | Secondary: medication use, HR, BP changes (DBP, SBP), PR
| ITT: NR | M = 17 | W: 0 | RR | W: 0 | | W: 0
| | PVD | | | | Rest (2) Listening blank tapes | R: 16
| | | | | | | C: 16
| | | | | | | W:0
Pool JI, 1995^241^ | RCT parallel 3 arms | 59.2 yr | R: 50 | Single | R: 16 | CRT | R: 13 | Primary: BP changes (DBP, SBP) | No statistically significant differences were found among mindfulness meditation, CRTand group therapy groups for any of the outcomes
United States | Duration: 9 wk | F = 36 | C: 35 | | C: 10 | | C: 9 | Secondary: HR, anxiety, depression, psychological distress, irritability, hostility
| ITT: NR | M = 16 | W: 15 | Mindfulness meditation (NS) | W: 6 | | W: 4
| | CHD | | | | | 11
| | | | | | Group therapy | R: 21
| | | | | | | C:16
| | | | | | | W: 5
Quillian-Wolever RE, 2005^242^ | RCT parallel 2 arms | Age NR | R: 154 | Composite | R: NR | UC (NS) | R: NR | Primary: coronary heart disease risk at 10 years | The treatment group demonstrated improvement in 10-yr risk compared with usual care
United States | Duration: 10 mo | F = NR | C: NR | | C: NR | | C: NR
| ITT: NR | M = NR | W: NR | Mindfulness meditation (NS) + HE + health coaching | W:NR | | W:NR
| | CHD
Stenlund T, 2005^243^ | RCT parallel 2 arms | 77.4 yr | R: 109 | Composite | R: 56 | HE | R: 53 | Primary: level of physical activity | Qi Gong significantly improved the level of physical activity and coordination
Sweden | Duration: 3 mo | F = 29 | C: 95 | | C: 48 | | C: 47 | Secondary: balance, coordination, fear of falling | No significant differences were found between the groups regarding fear of falling and balance
| ITT: NR | M = 66 | W: 14 | Qi Gong + discussions | W: 8 | | W: 6
| | CAD
Tacon AM, 2003^244,255^ | RCT parallel 2 arms | 60.3 yr | R: 20 | Single | R: 10 | WL | R: 10 | Primary: anxiety | There were significant differences between the MBSR and control groups on scores of anxiety, emotional control, coping, ventilation, and breathing frequency
United States | Duration: 8 wk | F = 18 | C: 18 | | C: 9 | | C: 9 | Secondary: coping styles, emotional control, health locus of control, cortisol^255^ breathing frequency,^255^ total catecholamines^255^ BP changes (DBP, SBP), HRQL | MBSR had no effect on health locus of control, cortisol, or physical functioning
| ITT: NR | M = 0 | W: 2 | MBSR | W: 1 | | W: 1
| | CAD
Tsai SL, 2004^249^ | NRCT parallel 2 arms | 63.2 yr | E: 146 | Composite | E: 67 | UC (NS) | E: 79 | Primary: anxiety | The composite intervention significantly improved anxiety, sleep, and relaxation when compared with the control group
China | Duration: 1 yr | F = 13 | C: 100 | | C: 41 | | C: 59 | Secondary: sleep, relaxation level
| ITT: NR | M = 87 | W: 46 | Mindfulness meditation (NS) + BE + PMR + imagery | W: 26 | | W: 20
| | CAD
Williams KA, 2001^245^ | RCT parallel 2 arms | Age NR | R: 35 | Single | R: 11 | NT | R: 24 | Primary: depression | MBSR produced significant reductions in depression, anger expression, and hostility. It also increased general health, vitality and mental health
United States | Duration: 12 wk | F = NR | C: NR | | C: NR | | C: NR | Secondary: anger, anxiety, hostility, vitality, mental health
| ITT: NR | M = NR | W: NR | MBSR | W: NR | | W: NR
| | CAD
Yeh GY, 2004^246,256^ | RCT parallel 2 arms | 64 yr | R: 30 | Single | R: 15 | Medication (NS) | R: 15 | Primary: HRQL, exercise capacity | Patients in the Tai Chi group improved HRQL, increased distance walked in 6 min, and decreased BNP levels compared with the control group. A trend towards improvement was seen in VO_2_ max
United States | Duration: 12 wk | F = 11 | C: 26 | | C: 15 | | C: 12 | Secondary: BNP, plasma catecholamines, VO_2_ max | No differences were detected in catecholamine levels
| ITT: Yes | M = 19 | W: 4 | Tai Chi | W: 0 | | W: 3
| | CHF
Yogendra J, 2004^250^ | NRCT parallel 2 arms | Age NR | E: 140 | Composite | E: 80 | Medication (NS) | E: 60 | Primary: TC, LDL-C | Significant changes were found in TC, LDL-C, regression of disease in the Yoga group
India | Duration: 1 yr | F = NR | C: 113 | | C: 71 | | C: 42 | Secondary: clinical improvement, caloric intake, regression of disease, anxiety, depression, myocardial perfusion | Differences between the groups on anxiety and depression were not statistically significant
| ITT: NR | M = NR | W: 27 | Yoga + risk factors control + diet + stress management | W: 9 | | W: 18
| | CAD
Young JW, 2001^251^ | NRCT parallel 2 arms | 63 yr | E: 44 | Single | E: 27 | NT | E: 17 | Primary: anxiety | The treatment group showed significantly greater improvement in anxiety, somatization, depression, tension, anger, global status, and mood
United States | Duration: 6 wk | F = 13 | C: 34 | | C: 17 | | C: 17 | Secondary: somatization, tension, depression, global status, mood disturbances | Inequities in baseline scores preclude atttributing improvement to Yoga except on somatization
| ITT: NR | M = 21 | W: 10 | Yoga | W: 10 | | W: 0
| | CHD
Zamarra JW1996^252,257^ | NRCT parallel 2 arms | 55 yr | E: 21 | Single | E: 12 | WL | E: 9 | Primary: Exercise tolerance | Compared with the control groupthe the patients who learned TM^®^ demonstrated significantly greater exercise tolerancehigher maximal workloaddelayed onset of ST segment depressionand decreases in double product at each exercise interval
United States | Duration: 8 mo | F= 0 | C: 16 | | C: 10 | | C: 6 | Secondary: Maximal workloadST depression onsetrate-pressure product
| ITT: NR | M = 21 | W: 5 | TM^®^ | W: 2 | | W: 3
| | CAD

® AMI = acute myocardial infarction; BE = breathing exercises; BNP = B-type natriuretic peptide; BMI = body mass index; BP = blood pressure; C = number completed; CABS = coronary artery bypass surgery; CAD = coronary artery disease; CHD = coronary heart disease; CHF = chronic heart failure; CRT = cognitive restructuring training; d = day(s); DBP = diastolic blood pressure; E = number enrolled (for NRCTs) GSH = glutathione; HDL-C = high-density lipoprotein cholesterol; HE = health education; HRQL = health-related quality of life; HRV = heart rate variability; ITT = intention to treat; LDL-C = low density lipoprotein cholesterol; LLM = lowering lipid medication; LVEF = left ventricular ejection fraction; LVDDi = left ventricular end diastolic volume index; min = minute(s); mo = month(s); NRCTs = nonrandomized controlled trial; MBSR = mindfulness-based stress reduction; NA = not applicable; NE = norepinephrine; NR = not reported; NS = not specified; NT = no treatment; NYHA = New York Heart Association; P-MDA = plasma malondialdehyde; PMR = Progressive muscle relaxation; PVD= peripheral vascular disease; PR = pulse rate; R = number randomized (for RCTs) SBP = systolic blood pressure; TC = total cholesterol; TEE = total energy expenditure; TG = triglycerides; TM = Transcendental Meditation; VE/VCO_2_ = rate of increase of ventilation per unit of increase of carbon dioxide production; VO_2_ max = maximum oxygen consumption; UC = usual care; VLDL-C = very low density lipoprotein cholesterol; W = number withdrawals/losses to followup; wk = week(s); WL = waiting list; WR = work rate; yr = year(s)

Table H3 Characteristics of clinical trials of meditation practices in substance abuse

Study, country | Study design, followup duration, ITT | Characteristics of study population | | Intervention | | Comparison groups | | Outcomes | Authors, conclusions
| | Age (mean/range), gender, diagnosis | N participants | Type/name | N participants | Type/name | N participants
Alterman AI, 2004^258^ | RCT parallel 2 arms | 36.5 yr | R: 31 | Single | R: 18 | UC (NS) | R: 13 | Primary: addiction severity | There is relatively little indication that mindfulness meditation enhanced treatment outcomes for substance abuse patients
United States | Duration: 5 mo | F = 17 | C: 25 | | C: 15 | | C: 10 | Secondary: medical problems, positive mood, positive health, personal meaning, optimism-pessimism, spirituality
| ITT: NR | M = 14 | W: 6 | Mindfulness meditation(NS) | W:3 | | W:3
| | Alcohol and drug abuse (cocaineheroin)
Ballou D, 1977^259^ | RCT parallel 3 arms | Age NR | R: 66 | Single | R: 30 | WL | R: 20 | Primary: anxiety | TM^®^ significantly decreased anxiety, frequency of inmate infractions, and increase the number of hours of recreational and educational activities
United States | Duration: 11 wk | F = 0 | C: NR | | C: NR | | C: NR | Secondary: behavioral changes, inmate infractions
| ITT: NR | M = 66 | W: NR | TM^®^ | W: NR | | W: NR
| | Drug dependency | | | | NT | R: 16
| | | | | | | C: NR
| | | | | | | W: NR
Barton MJ, 2004^260^ | RCT parallel 2 arms | Age NR | R: 10 | Single | R: 5 | Rest (music) | R: 5 | Primary: BP changes (DBP, SBP) | There were no significant changes in BP, GSR, or spirituality after practicing medical meditation as compared with the control group
United States | Duration: 1 d | F = 4 | C: NR | Medical meditation (mantra + BE) | C: NR | | C: NR | Secondary: PR, GSR, spirituality
| ITT: NR | M = 6 | W:NR | | W: NR | | W: NR
| | Alcohol abuse
Brautigam E, 1977^261^ | RCT Parallel 2 arms | 17–24 yr | R: 20 | Single | R: 10 | Group therapy | R: 10 | Primary: frequency of drug use | Meditators showed a marked decrease in drug use, whereas control subjects maintained high usage level
Sweden | Duration: 6 mo | F = 6 | C: NR | | C: NR | | C: NR | Secondary: leisure activity, self-confidence, anxiety, psychomotor retardation | Meditators showed an increase in level of self-acceptance, satisfaction, ability to adjust and a decrease in anxiety
| ITT: NR | M = 14 | W: NR | TM^®^ | W: NR | | W: NR
| | Alcohol and drug abuse (marijuana, hashish, LSD, amphetamines)
Kline KS, 1982^271^ | NRCT parallel 2 arms | 34.7 yr | E: 23 | Single | E: 11 | WL | E: 12 | Primary: personality profile | There were no significant changes in global personality or self-actualization in the intervention and control groups
United States | Duration: 12 wk | F = 9 | C: 8 | | C: 7 | | C: 8 | Secondary: self-actualization
| ITT: NR | M = 14 | W: 15 | TM^®^ | W: 4 | | W: 4
| | Alcohol abuse
Li M, 1956^262^ | RCT parallel 3 arms | 32.3 yr | R: 86 | Single | R: 34 | Lofexidine | R: 26 | Primary: withdrawal symptoms | Qi Gong significantly reduced withdrawal symptoms, anxietyand shortened recovery time
China | Duration: 10 days | F = 0 | C: NR | | C: NR | | C: NR | Secondary: anxiety, urine morphine
| ITT: NR | M = 86 | W: NR | Qi Gong | W: NR | | W: NR
| | Drug abuse (heroin) | | | | NT | R: 26
| | | | | | | C: NR
| | | | | | | W: NR
Marcus MT, 2001^272,275^ | NRCT parallel 2 arms | 34 yr | E: 36 | Single | E: 18 | NT | E: 18 | Primary: coping styles | There were no significant changes in coping styles and psychopathology symptoms resulting from the MBSR intervention when compared with a control group
United States | Duration: 8 wk | F = 2 | C: NR | | C: NR | | C: NR | Secondary: psychopathology symptoms
| | M = 34 | W: NR | MBSR | W: NR | | W: NR
| ITT: NR | Alcohol and drug abuse
Murphy R, 1995^263^ | RCT parallel 2 arms | 32.7 yr | R: 31 | Single | R: 15 | PMR | R: 16 | Primary: egocentrism | Reductions in self-reported anger in the MBSR and PMR groups were not significantly different from each other. No significant differences were found among groups for measures of egocentrism, impulsivity and cortisol levels
United States | Duration: 1 month | F = 0 | C: 27 | | C: 13 | | C: 14 | Secondary: anger, impulsivity, cortisol levels
| | M = 31 | W: 4 | MBSR | W: 2 | | W: 2
| ITT: NR | Alcohol and drug abuse
Murphy TJ, 1986^264^ | RCT parallel 3 arms | 24.7 yr | R: 60 | Single | R: 20 | Exercise | R: 20 | Primary: alcohol consumption | There were no significant differences in alcohol consumption or VO_2_ max between CSM and either exercise or NT groups
United States | Duration: 8 wk | F = 0 | C: 43 | | C: 14 | | C: 13 | Secondary: VO_2_ max | Subjects in the exercise condition significantly reduced their alcohol consumption
| ITT: NR | M = 43 | W: 17 | CSM | W: 6 | | W: 7
| | Alcohol abuse
| | | | | | NT | R: 20
| | | | | | | C: 16
| | | | | | | W: 4
Parker JC, 1978^265,^,^276,277^ | RCT parallel 3 arms | 45.1 yr | R: 30 | Single | R: 10 | PMR | R: 10 | Primary: anxiety | The results revealed generalized effects for BP, but not for the other outcome measures
United States | Duration: 3 wk | F = 0 | C: 30 | | C: 10 | | C: 10 | Secondary: BP changes (DBP, SBP), HR, GSR, tension | The RR and PMR groups did not exhibit increased BP as observed in control subjects
| ITT: NR | M = 30 | W: 0 | RR | W: 0 | | W: 0 | | RR and PMR produced significant changes in tension
| | Alcohol abuse
| | | | | | Rest | R: 10
| | | | | | | C: 10
| | | | | | | W: 0
Raina N, 2001^266^ | RCT parallel 2 arms | 34.9 yr | R: 50 | Single | R: 25 | Exercise | R: 25 | Primary: recovery rate | Yoga produced significantly greater recovery rate compared with exercise
India | Duration: 24 wk | F = 0 | C: 27 | | C: 13 | | C: 14
| ITT: NR | M = 50 | W: 23 | Yoga | W: 12 | | W: 11
| | Alcohol abuse
Ramirez J, 1990^267^ | RCT parallel 2 arms | 23.3 yr | R: 80 | Single | R: 40 | Control (NS) | R: 40 | Primary: self-concept | TM^®^ produced greater emotional stability and maturity and an improved self-concept while showing a decrease in aggressive tendencies and a lessened concern with physical symptoms
United States | Duration: NR | F = 40 | C: 68 | | C: NR | | C: NR | Secondary: emotional stability, maturity, hostility, over-concern with physical symptoms
| ITT: NR | M = 40 | W: 12 | TM^®^ | W: NR | | W: NR
| | Drug abuse
Rohsenow DJ, 1985^268^ | RCT parallel 2 arms | 21.3 yr | R: 40 | Composite | R: NR | Control (NS) | R: NR | Primary: anxiety | There is a modest and transitory overall success in modifying mood, cognition, and alcohol comsumption of heavy social drinkers through stress management training that incorporates the RR
United States | Duration: 6 mo | F = 0 | C: 36 | | C: 15 | | C: 21 | Secondary: anger, depression, alcohol consumption, locus of control, irrational beliefs
| ITT: NR | M = 36 | W: 5 | RR + PMR + CRT | W: NR | | W: NR
| | Heavy social drinkers
Shaffer HJ, 1997^269^ | RCT parallel 2 arms | 35.9 yr | R: 59 | Composite | R: 29 | Group therapy + methadone | R: 30 | Primary: addiction severity | There were no significant differences between a group therapy and Yoga for enhancing methadone maintenance treatment
United States | Duration: 6 mo | F = 24 | C: NR | | C: NR | | C: NR | Secondary: psychological symptoms
| ITT: NR | M = 35 | W: NR | Yoga + methadone | W: NR | | W: NR
| | Drug abuse
Subrahmanyam S, 1986^273^ | NRCT parallel | 20–45 yr | E: 100 | Single | E: 20 | Psychotherapy | E: 20 | Primary: clinical status | Improvement was noticed in all the intervention groups for the outcomes tested
India | Duration: 1 yr | F = 0 | C: NR | | C: NR | | C: NR | Secondary: psychological status, WBC count, ESR, blood glucose, TC, cortisol, lactic acid, PBI, 5-HIAA, Hb, catecholamines, S-Ca, S-Mg, VMA, HVA, 17- KS, PT, MHPG, cholinesterase | LFPMF seems to be more effective for improving clinical status
| ITT: NR | M = 100 | W: NR | Yoga | W: NR | | W: NR
| | Alcohol abuse | | | | Stereotaxic surgery | E: 20
| | | | | | | C: NR
| | | | | | | W: NR
| | | | | | BF | E: 20
| | | | | | | C: NR
| | | | | | | W: NR
| | | | | | LFPMF | E: 20
| | | | | | | C: NR
| | | | | | | W: NR
Taub E, 1994^270^ | RCT parallel 3 arms | 44.3 yr | R: NR | Single | R: NR | BF (EMG) | R: NR | Primary: drinking days | TM^®^ and BF (EMG) groups exhibited significant increases in percent of non-drinking days
United States | Duration: 18 mo | F = 0 | C: 67 | | C: 18 | | C: 13 | Secondary: complete abstinence, mood states | Both interventions were associated with greater abstinence rates and mood improvement
| ITT: NR | M = 67 | W: NR | TM^®^ | W: NR | | W: NR
| | Alcohol abuse | | | | Neurotherapy | R: NR
| | | | | | | C: 18
| | | | | | | W: NR
| | | | | | Counselling | R: NR
| | | | | | | C: 18
| | | | | | | W: NR
Wong MR, 1981^274^ | NRCT parallel 2 arms | 28.9 yr | E: 103 | Composite | E: NR | Relaxation | E: NR | Primary: physical tension | Meditation significantly increased the ability to control muscle relaxation, improve the level of self awareness as compared with the control group
United States | Duration: 6 mo | F = 0 | C: 91 | | C: 52 | | C: 39 | Secondary: anxiety, personality changes | The failure to detect any positive change at 6- mo. followup indicates that effects were not strong enough to be detected over time
| ITT: NR | M = 103 | W: 12 | Meditation practice (NS) | W: NR | | W: NR
| | Drug abuse

® 5-HIAA = 5-hydroxyindole acetic acid; 17-KS = 17-ketosteroids; BE = breathing exercises; BF = biofeedback; BP = blood pressure; C = number completed; CRT = cognitive restructuring training; CSM = clinically standardized meditation; d = day(s); DBP = diastolic blood pressure; E = number enrolled (for NRCTs); EMG = electromyography; ESR = erythrocyte sedimentation rate; GSR = galvanic skin response; Hb = hemoglobin; HR = heart rate; HVA = homovanillic acid; ITT = intention to treat; LFPMF = low-frequency pulsed magnetic field; LSD = lysergic acid diethylamide; MBSR = mindfulness-based stress reduction; MHPG = 3-methoxy-4-hydroxyphenylglycol; mo = month(s); NRCT = nonrandomized controlled trial; NR = not reported; NS = not specified; PBI = protein bound iodine; PMR = progressive muscle relaxation; PR = pulse rate; PT = prothrombine time; R = number randomized (for RCTs); RR = Relaxation Response; SBP = systolic blood pressure; S-Ca = serum calcium; S-Mg = serum magnesium; TM = Transcendental Meditation; VO_2_ max = maximum oxygen consumption; UC = usual care; VMA = vanillylmandelic acid; W = number withdrawals/losses to followup;WBC = white blood cell; wk = week(s); yr = year(s)