# Appendix G. Summary Tables for Topic II

Table G1 Country of study

| Country | N | References
North America | United States | 462 | ^111,^,^120,^,^126,^,^152,^,^175,^,^177,^,^193,^,^205,^,^206,^,^208,^,^233,^,^234,258^–^260,^,^279,^,^280,^,^289,^,^290,^,^304,^,^311,^,^384,^,^385,^,^387,^,^394,436^–^494a494b127,^,^171,^,^197,^,^306,495^–^508a306b192,509b509a80,^,^94,^,^134,^,^186,^,^187,^,^237,^,^282,^,^292,^,^324,^,^390,510^–^547a547b548^–^552a552b209,^,^396,^,^402,553^–^571b571a178,^,^195,^,^210,^,^271,398^–^401,^,^403,572^–^624a624b70,^,^75,^,^78,^,^91,^,^92,^,^105,^,^118,^,^141,^,^168,^,^174,^,^181,^,^188,^,^190,^,^191,^,^196,^,^198,^,^202,^,^220,^,^221,^,^227,^,^228,^,^241,^,^242,244^–^246,^,^251,^,^252,263^–^265,267^–^270,^,^272,^,^274,^,^284,^,^285,^,^287,^,^288,^,^293,^,^309,^,^316,^,^317,^,^319,^,^322,^,^325,^,^391,^,^397,406^–^410,^,^412,^,^414,^,^416,418^–^425,433^–^435,625^–^769^
| Canada | 32 | ^97,^,^182,^,^189,^,^194,^,^296,^,^386,^,^395,^,^413,770^–^793^
Asia | India | 115 | ^83,^,^133,^,^137,^,^138,^,^140,^,^142,^,^170,^,^172,^,^184,^,^204,^,^212,^,^217,^,^226,^,^239,^,^240,^,^250,^,^266,^,^273,^,^278,^,^294,^,^295,^,^298,^,^300,^,^301,^,^303,^,^305,^,^310,312^–^314,^,^318,^,^320,^,^321,^,^323,^,^404,^,^411,^,^415,^,^417,794^–^870^
| China | 19 | ^161,^,^211,^,^225,^,^249,^,^262,871^–^884^
| South Korea | 15 | ^200,^,^201,^,^213,^,^214,^,^405,885^–^894^
| Hong Kong | 13 | ^207,^,^286,^,^299,895^–^904^
| Taiwan | 12 | ^223,^,^248,^,^326,^,^388,^,^432,905^–^911^
| Japan | 10 | ^389,^,^426,912^–^919^
| Thailand | 5 | ^106,^ ^216,^ ^238,^ ^920,^ ^921^
| Malaysia | 2 | ^179,^ ^180^
Europe | United Kingdom | 31 | ^122,^,^167,^,^185,^,^218,^,^219,^,^235,^,^281,^,^283,^,^308,^,^427,^,^431,922^–^941^
| Germany | 12 | ^215,^,^247,942^–^950a950b^
| Sweden | 9 | ^951a951b243,^,^261,^,^302,952^–^955^
| Norway | 7 | ^956^–^962^
| Ireland | 5 | ^392,^,^393,963^–^965^
| Italy | 4 | ^966^–^969^
| Switzerland | 4 | ^199,970^–^972^
| Netherlands | 4 | ^973a^ ^973b^ ^224,^ ^974^
| Spain | 3 | ^975^–^977^
| Austria | 2 | ^430,^ ^978^
| Czech Republic | 2 | ^183,^ ^979^
| France | 2 | ^980,^ ^981^
| Russia | 2 | ^146,^ ^203^
| Turkey | 2 | ^315,^ ^982^
| Denmark | 1 | ^983^
| Poland | 1 | ^984^
| Belgium | 1 | ^985^
Australasia | Australia | 20 | ^169,^,^297,^,^307,^,^428,986^–^1001^
| New Zealand | 6 | ^222,^,^429,1002^–^1005^
Other | Israel | 4 | ^176,^ ^291,^ ^1006,^ ^1007^
| South Africa | 3 | ^86,^ ^1008,^ ^1009^
| Brazil | 2 | ^236,^ ^1010^
| Argentina | 1 | ^1011^
| Netherlands Antilles | 1 | ^974^

Table G2 Study design

| Study design | N | References
Intervention studies | RCTs | 286 | ^86,^,^111,^,^120,^,^176,^,^177,^,^189,^,^193,203^–^208,233^–^235,258^–^261,278^–^281,^,^304,^,^305,^,^384,^,^387,^,^394,^,^437,^,^444,^,^445,^,^447,^,^448,^,^455,^,^460,^,^467,^,^472,474^–^478,^,^480,483^–^485,^,^490,^,^493,^,^494,^,^796,^,^871,^,^885,895b127,^,^194,^,^236,^,^306,^,^389,^,^503,^,^504,507a70,^,^75,^,^78,^,^91,^,^92,^,^94,^,^97,^,^118,^,^134,^,^138,^,^140,167^–^170,^,^174,^,^182,184^–^186,190^–^192,^,^195,^,^196,209^–^225,237^–^246,262^–^270,282^–^288,307^–^309,^,^325,^,^386,^,^391,^,^392,395^–^398,403^–^405,407^–^409,^,^413,^,^417,^,^418,^,^421,^,^423,^,^424,^,^427,^,^431,^,^433,^,^434,^,^512,^,^514,^,^515,^,^519,^,^521,^,^528,^,^530,^,^531,^,^536,^,^537,^,^539,541^–^545,^,^549,^,^554,556^–^558,^,^562,^,^567,^,^569,^,^572,^,^573,^,^575,^,^579,^,^584,^,^589,^,^592,^,^594,^,^597,^,^603,^,^610,^,^615,^,^616,^,^618,625^–^627,^,^631,^,^637,^,^651,^,^658,^,^665,^,^666,^,^674,^,^676,^,^677,^,^680,^,^683,^,^687,^,^702,^,^706,^,^710,^,^711,^,^714,^,^719,^,^726,^,^736,^,^738,^,^746,^,^751,754^–^756,^,^759,^,^761,^,^764,^,^765,767^–^769,^,^774,^,^775,^,^777,^,^782,^,^783,^,^791,^,^793,^,^805,^,^811,^,^819,^,^823,^,^825,^,^829,^,^832,836^–^839,^,^841,^,^844,^,^852,^,^858,^,^868,^,^882,^,^894,^,^900,^,^910,^,^919,^,^920,^,^926,^,^929,^,^930,^,^932,^,^934,^,^940,^,^943,^,^945,^,^946,^,^953,^,^954,^,^956,^,^959,^,^961,^,^965,^,^971,^,^977,^,^984,^,^987,^,^988,^,^991,^,^998,^,^999,^,^1005,^,^1006,1011^
| NRCTs | 114 | ^126,^,^175,^,^289,^,^290,^,^440,461^–^463,^,^482,^,^489,^,^494,^,^794,799a197,^,^291,^,^306,500b106,^,^122,^,^137,178^–^181,^,^183,^,^187,^,^188,^,^198,^,^199,226^–^228,247^–^252,271^–^274,^,^292,^,^293,^,^326,^,^415,^,^419,^,^420,^,^429,^,^430,^,^435,^,^518,^,^523,^,^532,^,^538,^,^553,^,^566,^,^577,^,^587,^,^593,^,^595,^,^596,^,^602,^,^617,^,^629,^,^639,^,^642,^,^645,^,^650,^,^656,^,^659,^,^662,^,^673,^,^678,^,^679,^,^681,^,^689,^,^691,^,^696,^,^698,^,^705,^,^713,^,^728,^,^730,^,^752,^,^758,^,^762,^,^773,^,^787,^,^789,^,^804,^,^806,^,^809,^,^816,^,^818,^,^824,^,^826,^,^834,^,^846,^,^854,^,^860,^,^864,^,^866,^,^878,^,^904,^,^915,^,^925,^,^938,^,^955,^,^974,^,^981,^,^986,^,^1001,1007^
| Before-and-after | 147 | Controlled (2) ^171,172^
| | | Uncontrolled (145) ^83,^,^133,^,^152,294^–^303,310^–^324,^,^393,^,^402,^,^406,^,^411,^,^414,^,^425,^,^426,^,^442,^,^457,^,^459,^,^464,^,^468,^,^471,^,^488,^,^491,^,^502,^,^505,^,^510,^,^516,^,^517,^,^524,^,^525,^,^533,^,^559,^,^561,^,^564,^,^578,^,^580,^,^588,^,^590,^,^604,^,^606,^,^608,^,^609,^,^611,^,^613,620^–^623,^,^634,^,^635,652^–^654,^,^657,^,^682,^,^684,^,^690,^,^692,^,^697,^,^707,^,^709,^,^715,^,^716,^,^724,^,^725,^,^727,^,^733,^,^739,^,^747,^,^750,^,^753,^,^766,^,^770,^,^780,^,^784,^,^797,800^–^802,^,^808,^,^810,812^–^815,^,^821,^,^822,^,^827,^,^830,^,^831,^,^840,^,^843,^,^845,^,^847,^,^848,^,^850,^,^851,^,^856,^,^862,^,^863,^,^867,^,^870,^,^872,^,^875,^,^883,^,^889,^,^891,^,^897,^,^906,^,^913,^,^914,^,^916,^,^922,^,^931,^,^942,^,^944,^,^947,^,^962,^,^963,^,^966,^,^979,^,^982,^,^992,^,^996,1002^
Observational analytical studies | Cohort studies with controls | 149 | ^400,^,^422,^,^439,^,^450,^,^452,^,^453,^,^487,^,^492,^,^600,^,^601,^,^624,^,^669,^,^771,^,^776,^,^873,^,^949,970a624b80,^,^105,^,^141,^,^142,^,^161,200^–^202,^,^385,^,^399,^,^401,^,^416,^,^428,^,^436,^,^449,^,^456,^,^458,^,^466,^,^469,^,^479,^,^486,^,^498,^,^499,^,^501,^,^508,^,^520,^,^522,^,^526,^,^527,^,^540,^,^548,^,^550,^,^555,^,^563,^,^574,^,^576,^,^581,^,^583,^,^585,^,^586,^,^598,^,^599,^,^605,^,^607,^,^612,^,^614,^,^619,^,^630,^,^633,^,^643,^,^644,^,^647,^,^655,^,^663,^,^668,^,^670,^,^672,^,^675,^,^685,^,^686,^,^688,^,^693,^,^695,^,^699,^,^700,^,^703,^,^708,^,^712,^,^720,^,^721,^,^723,^,^772,^,^779,^,^781,^,^788,^,^790,^,^803,^,^807,^,^817,^,^820,^,^833,^,^835,^,^853,^,^855,^,^857,^,^861,^,^874,^,^877,^,^886,^,^907,^,^909,^,^912,^,^917,^,^921,^,^923,^,^927,^,^928,^,^935,^,^948,^,^950,^,^952,^,^958,^,^960,^,^964,^,^967,^,^969,^,^972,^,^983,^,^985,^,^989,^,^994,^,^995,^,^997,^,^1008,1009a950b731,^,^734,^,^936,973a973b741,^,^745,^,^749,^,^755,^,^757,^,^760,^,^763,^,^792,^,^939,1003^
| Cross-sectional studies with controls | 117 | ^412,^,^509,^,^529,^,^546,^,^582,^,^591,^,^704,^,^732,^,^740,^,^748,786b571b441,^,^534,^,^535,^,^551,^,^646,^,^649,^,^701,^,^722,^,^737,^,^743,^,^744,^,^859,^,^937,^,^941,^,^951,^,^957,^,^975,976a951b552a552b513,^,^547,^,^795,828a547b438,^,^446,^,^451,^,^568,^,^570,^,^571,^,^640,^,^660,^,^661,^,^694,^,^717,^,^978,^,^980,^,^993,1004a509,^,^560,^,^638,^,^648,^,^671,^,^718,1000a146,^,^388,^,^390,^,^432,^,^443,^,^454,^,^465,^,^470,^,^473,^,^481,495^–^497,^,^506,^,^511,^,^565,^,^628,^,^632,^,^636,^,^641,^,^664,^,^667,^,^729,^,^735,^,^742,^,^778,^,^785,^,^798,^,^842,^,^849,^,^865,^,^869,^,^876,879^–^881,^,^884,^,^887,^,^888,^,^890,^,^892,^,^893,^,^896,^,^898,^,^899,901^–^903,^,^905,^,^908,^,^911,^,^918,^,^924,^,^933,^,^968,^,^990,1010^

Table G3 Publication type

Type of publication | N | References
Journal article | 701 | ^120,^,^146,^,^176,^,^177,^,^189,^,^193,^,^203,^,^204,206^–^208,233^–^235,^,^258,^,^259,^,^261,278^–^281,^,^289,^,^290,^,^295,^,^297,^,^304,^,^305,310^–^312,^,^384,^,^385,^,^387,^,^394,436^–^440,445^–^452,^,^454,456^–^466,^,^468,470^–^473,475^–^481,483^–^486,^,^488,^,^489,491^–^494,^,^770,^,^771,794^–^802,^,^871,^,^885,^,^895,^,^922,^,^952,^,^966,^,^978,^,^980,1010a494b127,^,^171,^,^194,^,^236,^,^291,^,^306,^,^389,^,^495,498^–^503,^,^505,^,^507,^,^508,1008a306b192,^,^294,^,^509,982b509a80,^,^187,^,^282,^,^324,^,^392,^,^393,^,^395,510^–^513,^,^515,^,^516,518^–^531,533^–^540,542^–^547,^,^772,803^–^808,^,^921,^,^923,^,^942,963^–^965,^,^967,^,^986,^,^987,1009a547b185,^,^209,^,^396,^,^402,548^–^551,553^–^555,557^–^566,^,^568,^,^570,^,^571,^,^774,^,^775,809^–^811,^,^924,988b571a138,^,^178,^,^195,^,^211,^,^212,^,^238,^,^248,^,^271,^,^283,^,^296,^,^298,^,^299,^,^307,313^–^315,^,^326,398^–^401,^,^404,572^–^580,^,^582,^,^583,^,^585,^,^586,^,^588,^,^590,^,^592,^,^594,^,^595,597^–^599,^,^601,603^–^613,615^–^624,^,^776,^,^777,812^–^821,^,^873,^,^874,^,^886,^,^896,905^–^908,912^–^916,926^–^928,^,^945,^,^946,^,^970,^,^975,^,^976,^,^989,1006a624b92,^,^97,^,^161,^,^168,^,^172,179^–^182,^,^184,^,^188,^,^190,^,^198,200^–^202,^,^213,^,^214,216^–^222,^,^226,^,^239,^,^240,^,^262,264^–^269,^,^272,^,^284,^,^288,300^–^302,^,^308,^,^309,^,^316,318^–^320,405^–^411,413^–^420,^,^422,^,^426,625^–^629,631^–^634,636^–^655,657^–^663,^,^665,^,^666,668^–^678,680^–^686,688^–^694,697^–^699,^,^701,^,^702,704^–^706,778^–^782,785^–^788,822^–^844,^,^876,^,^877,887^–^893,897^–^899,^,^909,^,^917,929^–^932,947^–^949,^,^953,^,^956,^,^972,^,^974,^,^977,^,^979,991^–^995,^,^1002,^,^1007,^,^174,^,^707,^,^708,^,^709,^,^710,^,^711,^,^845,^,^137,^,^846,^,^847,^,^712,^,^996,^,^714,^,^715,^,^918,^,^716,^,^997,^,^321,^,^848,^,^789,^,^717,^,^424,^,^718,^,^719,^,^957,^,^958,^,^959,^,^960,^,^961,^,^894,^,^790,^,^791,^,^386,^,^849,^,^142,^,^183,^,^985,^,^721,^,^243,^,^933,^,^983,^,^227,^,^722,^,^850,^,^273,^,^106,^,^723,^,^285,^,^851,^,^934,^,^228,^,^935,^,^724,^,^244,^,^425,^,^725,^,^998,^,^852,^,^726,^,^270,^,^427,^,^428,^,^853,^,^83,^,^854,^,^133,^,^855,^,^856,^,^857,^,^858,^,^140,^,^859,^,^323,^,^860,^,^861,^,^286,^,^429,^,^969,^,^728,^,^729,^,^70,950a,950b,293,^,^731,^,^732,^,^733,^,^734,^,^223,^,^249,^,^910,^,^900,^,^901,^,^878,^,^879,^,^880,^,^902,^,^735,^,^936,^,^862,^,^863,^,^962,^,^170,^,^937,973a,973b,224,^,^864,^,^325,^,^865,^,^303,^,^866,^,^981,^,^867,^,^868,^,^869,^,^739,^,^431,^,^740,^,^741,^,^742,^,^743,^,^744,^,^745,^,^746,^,^432,^,^747,^,^748,^,^749,^,^750,^,^751,^,^752,^,^753,^,^754,^,^954,^,^755,^,^938,^,^939,^,^955,^,^1000,^,^940,^,^756,^,^118,^,^1003,^,^1004,^,^757,^,^941,^,^758,^,^759,^,^760,^,^761,^,^434,^,^397,^,^792,^,^911,^,^274,^,^122,^,^763,^,^764,^,^765,^,^766,^,^881,^,^767,^,^903,^,^1001,^,^870,^,^768,^,^435,^,^246,^,^225,^,^904,^,^250,^,^287,^,^251,^,^793,^,^191,^,^252,^,^199,^,^884,^,^1005,^,^984,769^
Thesis/Dissertation | 79 | ^951a951b86,^,^111,^,^126,^,^134,^,^152,^,^175,^,^197,^,^205,^,^237,^,^260,^,^292,^,^388,^,^390,442^–^444,^,^453,^,^455,^,^469,^,^474,^,^482,^,^487,^,^490,^,^496,^,^497,^,^504,^,^506,^,^514,^,^517,^,^532,^,^541,^,^552,^,^773,920a552b75,^,^78,^,^91,^,^105,^,^141,^,^196,^,^210,^,^241,^,^263,^,^391,^,^412,^,^421,^,^423,^,^433,^,^567,^,^569,^,^581,^,^584,^,^589,^,^591,^,^593,^,^602,^,^614,^,^630,^,^635,^,^656,^,^664,^,^667,^,^679,^,^687,^,^695,^,^696,^,^703,^,^727,736^–^738,^,^762,^,^784,^,^882,^,^971,990^
Abstract | 25 | ^94,^ ^215,^ ^242,^ ^245,^ ^247,^ ^317,^ ^322,^ ^403,^ ^430,^ ^467,^ ^556,^ ^587,^ ^596,^ ^600,^ ^700,^ ^713,^ ^720,^ ^730,^ ^872,^ ^875,^ ^883,^ ^943,^ ^944,^ ^999,^ ^1011^
Unpublished | 3 | ^167,^ ^169,^ ^783^
Research letter | 3 | ^919,^ ^925,^ ^968^
Book chapter | 2 | ^186,^ ^441^

Table G4 Methodological quality—intervention studies

RCTs—Jadad scale | RCTs that obtained Jadad scores lower than 3 (n = 246) ^111,^,^176,^,^177,^,^203,^,^204,^,^233,259^–^261,278^–^281,^,^304,^,^305,^,^384,^,^394,^,^437,^,^444,^,^445,^,^447,^,^448,^,^455,^,^460,^,^467,^,^472,474^–^478,^,^480,^,^796,^,^186,^,^189,192^–^194,205^–^208,^,^235,^,^236,^,^306,^,^387,^,^389,^,^392,483^–^485,^,^490,^,^493,^,^494,^,^503,^,^507,^,^512,^,^514,^,^515,^,^519,^,^805,^,^871,^,^895,^,^920,^,^965,987^,^94,^,^134,^,^185,^,^209,^,^237,^,^395,^,^396,^,^528,^,^530,^,^531,^,^536,^,^537,^,^539,^,^543,^,^545,^,^549,^,^554,556^–^558,^,^562,^,^567,^,^569,^,^572,^,^573,^,^575,^,^774,^,^775,^,^811,^,^943,^,^988,^,^1006,1011^,^138,^,^195,210^–^214,^,^238,^,^262,^,^283,^,^307,403^–^405,^,^408,^,^584,^,^594,^,^597,^,^603,^,^610,^,^615,^,^616,^,^618,625^–^627,^,^777,^,^819,^,^926,^,^945,^,^946,971^,^92,^,^97,215^–^219,^,^239,^,^240,^,^263,^,^264,^,^308,^,^407,^,^410,^,^413,^,^417,^,^433,^,^637,^,^651,^,^658,^,^665,^,^666,^,^674,^,^676,^,^782,^,^823,^,^825,^,^829,^,^929,^,^930,^,^953,^,^956,977^,^70,^,^78,^,^118,^,^140,^,^170,^,^182,^,^184,^,^190,^,^191,^,^196,222^–^225,241^–^246,267^–^270,^,^285,^,^286,^,^288,^,^309,^,^325,^,^397,^,^418,^,^423,^,^427,^,^431,^,^434,^,^677,^,^680,^,^683,^,^687,^,^702,^,^706,^,^710,^,^711,^,^714,^,^719,^,^726,^,^736,^,^746,^,^751,^,^754,^,^756,^,^759,^,^761,^,^764,^,^765,767^–^769,^,^791,^,^793,^,^832,836^–^838,^,^841,^,^844,^,^852,^,^858,^,^868,^,^882,^,^900,^,^910,^,^919,^,^932,^,^934,^,^940,^,^954,^,^959,^,^961,^,^984,^,^998,1005^
| RCTs that obtained Jadad scores greater than 3 (n = 40) ^75,^,^86,^,^91,^,^120,^,^127,167^–^169,^,^174,^,^220,^,^221,^,^234,^,^258,^,^265,^,^266,^,^282,^,^284,^,^391,^,^398,^,^409,^,^421,^,^504,^,^521,^,^541,^,^542,^,^544,^,^579,^,^589,^,^592,^,^631,^,^783,^,^839,^,^885,991^,^287,^,^386,^,^424,^,^738,^,^894,999^
| RCTs describing the methods of randomization (n = 60)
| Appropriate (n = 45) ^86,^,^120,^,^127,^,^167,^,^206,^,^234,^,^258,^,^260,^,^282,^,^398,^,^448,^,^504,^,^521,^,^541,^,^542,^,^544,^,^569,^,^573,^,^579,^,^589,^,^592,^,^631,^,^811,885^,^91,^,^265,^,^266,^,^284,^,^308,^,^391,^,^409,^,^421,^,^783,825^,^75,^,^168,^,^174,^,^220,^,^221,^,^287,^,^386,^,^738,^,^839,^,^894,910^
| Inappropriate (n = 15) ^134,^,^212,^,^213,^,^262,^,^404,^,^408,^,^478,^,^484,^,^545,^,^584,^,^761,^,^841,^,^868,^,^920,971^
| RCTs described as double-blind (n = 8) ^167^–^170,^,^424,^,^782,^,^991,999^
| RCTs describing withdrawals/dropouts (n = 145) ^86,^,^111,^,^120,^,^189,^,^193,^,^203,^,^207,^,^234,^,^258,278^–^281,^,^394,^,^444,^,^455,^,^467,^,^478,^,^480,^,^484,^,^485,^,^494,^,^885,895b75,^,^78,^,^91,^,^92,^,^94,^,^97,^,^127,167^–^169,^,^174,^,^185,^,^196,^,^210,^,^213,^,^214,^,^216,218^–^224,^,^236,^,^238,^,^241,^,^243,^,^244,^,^246,263^–^266,282^–^287,^,^325,^,^386,^,^391,^,^395,^,^398,408^–^410,^,^421,^,^423,^,^434,^,^503,^,^504,^,^507,^,^514,^,^515,^,^521,^,^528,^,^536,^,^537,^,^541,^,^542,^,^544,^,^556,^,^557,^,^562,^,^575,^,^579,^,^584,^,^589,^,^592,^,^603,^,^610,^,^616,^,^618,^,^626,^,^627,^,^631,^,^637,^,^651,^,^666,^,^683,^,^702,^,^710,^,^711,^,^714,^,^726,^,^738,^,^754,^,^759,^,^764,^,^765,767^–^769,^,^777,^,^783,^,^791,^,^793,^,^829,^,^839,^,^841,^,^852,^,^868,^,^882,^,^894,^,^920,^,^926,^,^929,^,^930,^,^940,^,^945,^,^946,^,^953,^,^954,^,^971,^,^977,^,^984,^,^991,^,^998,999^
RCTs—Concealment of treatment allocation | RCTs with adequate report of methods for concealment of allocation (n = 12) ^168,^,^169,^,^246,^,^418,^,^476,^,^521,^,^544,^,^589,^,^631,^,^894,^,^926,991^
| RCTs with inadequate report of methods for concealment of allocation (n = 2) ^545,868^
| RCTs that failed to describe the methods for concealment of allocation (n = 272) ^86,^,^111,^,^176,^,^177,^,^203,^,^204,^,^233,258^–^261,278^–^281,^,^304,^,^305,^,^384,^,^394,^,^437,^,^444,^,^445,^,^447,^,^448,^,^455,^,^460,^,^467,^,^472,^,^474,^,^475,^,^477,^,^478,796^,^120,^,^189,^,^193,205^–^208,^,^234,^,^235,^,^387,^,^480,483^–^485,^,^490,^,^493,^,^494,^,^871,^,^885,895b127,^,^194,^,^236,^,^306,^,^389,^,^503,^,^504,507a192,^,^512,^,^514,^,^515,805^,^94,^,^134,^,^185,^,^186,^,^237,^,^282,^,^392,^,^395,^,^396,^,^519,^,^528,^,^530,^,^531,^,^536,^,^537,^,^539,541^–^543,^,^549,^,^554,556^–^558,^,^562,^,^774,^,^775,^,^920,^,^943,^,^965,^,^987,^,^988,1011^,^138,^,^167,^,^195,209^–^211,^,^238,^,^283,^,^307,^,^398,^,^403,^,^567,^,^569,^,^572,^,^573,^,^575,^,^579,^,^584,^,^592,^,^594,^,^597,^,^603,^,^610,^,^615,^,^616,^,^618,^,^777,^,^811,^,^819,^,^945,^,^946,^,^971,1006^,^91,^,^92,212^–^216,^,^239,^,^240,^,^262,^,^308,^,^404,^,^405,407^–^410,^,^413,^,^421,^,^433,625^–^627,^,^637,^,^782,^,^783,^,^823,^,^825,^,^929,^,^930,^,^953,977^,^97,^,^190,217^–^219,^,^241,^,^242,263^–^267,^,^284,^,^288,^,^309,^,^391,^,^417,^,^651,^,^658,^,^665,^,^666,^,^674,^,^676,^,^677,^,^680,^,^683,^,^829,^,^832,836^–^839,956^,^75,^,^174,^,^182,^,^184,220^–^222,^,^243,^,^244,268^–^270,^,^285,^,^386,^,^423,^,^424,^,^687,^,^702,^,^706,^,^710,^,^711,^,^714,^,^719,^,^726,^,^791,^,^841,^,^844,^,^852,^,^932,^,^934,^,^959,^,^961,998^,^70,^,^78,^,^118,^,^140,^,^170,^,^191,^,^196,223^–^225,^,^245,^,^286,^,^287,^,^325,^,^397,^,^427,^,^431,^,^434,^,^736,^,^738,^,^746,^,^751,^,^754,^,^756,^,^759,^,^761,^,^764,^,^765,767^–^769,^,^793,^,^858,^,^882,^,^900,^,^910,^,^919,^,^940,^,^954,^,^984,^,^999,1005^
RCTs - Funding | Funding reported (n = (118) ^120,^,^189,^,^193,205^–^208,^,^233,^,^234,^,^279,^,^280,^,^394,^,^444,^,^448,^,^460,^,^474,^,^475,^,^478,^,^480,^,^485,^,^494,^,^871,895b194,^,^306,^,^503,507a94,^,^97,^,^118,^,^167,^,^168,^,^174,^,^185,^,^192,^,^195,^,^209,^,^214,218^–^222,^,^224,^,^225,^,^239,^,^240,^,^243,^,^246,^,^264,268^–^270,^,^282,^,^284,^,^288,^,^386,^,^395,^,^397,^,^398,^,^403,^,^405,407^–^410,^,^413,^,^421,^,^423,^,^427,^,^433,^,^512,^,^521,^,^536,^,^537,^,^544,^,^545,^,^557,^,^562,^,^573,^,^575,^,^579,^,^592,^,^610,^,^618,^,^625,^,^626,^,^631,^,^637,^,^651,^,^665,^,^683,^,^710,^,^726,^,^746,^,^754,^,^764,767^–^769,^,^774,^,^777,^,^783,^,^793,^,^825,^,^839,^,^852,^,^868,^,^894,^,^900,^,^930,^,^934,^,^940,^,^953,^,^954,^,^961,^,^991,999^
NRCTs—Jadad scale | NRCTs describing withdrawals/dropouts (n = 52) ^126,^,^175,^,^289,^,^290,^,^440,^,^461,^,^462,^,^482,494a197,^,^291,^,^292,^,^518,^,^532,^,^553,^,^577,^,^593,^,^773,^,^809,925^,^122,^,^228,248^–^252,^,^271,^,^293,^,^326,^,^419,^,^420,^,^435,^,^602,^,^617,^,^642,^,^645,^,^650,^,^679,^,^681,^,^691,^,^728,^,^762,^,^787,^,^816,^,^846,^,^866,^,^878,^,^904,^,^938,^,^955,1007^
Before-and-after studies | Before-and-after studies with study population representative of the target population (n = 23) ^294,^,^414,^,^425,^,^464,^,^502,^,^564,^,^590,^,^604,^,^606,^,^609,^,^613,621^–^623,^,^682,^,^692,^,^697,^,^716,^,^724,^,^808,^,^810,^,^847,962^
| Before-and-after studies in which the method of outcome assessment was the same for the pre- and post-intervention periods for all participants (n = 140) ^83,^,^133,^,^152,^,^171,^,^172,294^–^298,300^–^303,^,^310,312^–^324,^,^393,^,^402,^,^406,^,^411,^,^414,^,^425,^,^426,^,^442,^,^459,^,^464,^,^468,^,^471,^,^488,^,^491,^,^502,^,^505,^,^510,^,^516,^,^517,^,^524,^,^525,^,^533,^,^559,^,^561,^,^564,^,^578,^,^580,^,^588,^,^590,^,^604,^,^606,^,^608,^,^609,^,^613,620^–^623,^,^634,^,^635,652^–^654,^,^657,^,^682,^,^684,^,^690,^,^692,^,^707,^,^709,^,^715,^,^716,^,^724,^,^725,^,^727,^,^733,^,^739,^,^747,^,^750,^,^753,^,^766,^,^770,^,^780,^,^784,^,^797,800^–^802,^,^808,^,^810,812^–^815,^,^821,^,^822,^,^827,^,^830,^,^831,^,^840,^,^843,^,^845,^,^847,^,^848,^,^850,^,^851,^,^856,^,^862,^,^863,^,^867,^,^870,^,^872,^,^875,^,^883,^,^889,^,^891,^,^897,^,^906,^,^913,^,^914,^,^922,^,^931,^,^942,^,^944,^,^947,^,^962,^,^963,^,^979,^,^982,^,^992,^,^996,1002^
| Before-and-after studies in which outcome assessors were blind to intervention and assessment period (n = 3) ^654,^,^753,962^
| Before-and-after studies that reported the number of study withdrawals (n = 45) ^295,^,^296,^,^402,^,^406,^,^411,^,^414,^,^425,^,^442,^,^457,^,^471,^,^488,^,^502,^,^525,^,^533,^,^559,^,^561,^,^564,^,^604,^,^609,^,^611,^,^613,620^–^623,^,^635,^,^684,^,^690,^,^709,^,^716,^,^725,^,^727,^,^733,^,^739,^,^753,^,^770,^,^784,^,^797,^,^801,^,^814,^,^851,^,^897,^,^922,^,^942,996^
| Before-and-after studies that reported the reasons for study withdrawal (n = 20) ^411,^,^442,^,^471,^,^502,^,^525,^,^559,^,^561,^,^564,^,^609,^,^613,^,^623,^,^635,^,^684,^,^690,^,^725,^,^727,^,^733,^,^739,^,^801,897^
| Before-and-after studies that reported source of funding (n = 41) ^133,^,^294,296^–^303,^,^402,^,^406,^,^411,^,^459,^,^488,^,^502,^,^516,^,^533,^,^559,^,^606,^,^613,^,^621,^,^623,^,^634,^,^684,^,^697,^,^753,^,^766,^,^770,^,^800,^,^822,^,^830,^,^831,^,^843,^,^848,^,^850,^,^862,^,^863,^,^883,^,^889,944^

NRCT = nonrandomized controlled trials; RCT = randomized controlled trials

Table G5 Methodological quality—observational analytical studies

Cohort studies— NOS scale | Cohort studies describing representative samples of the target population (n = 55) ^80,^,^439,^,^449,^,^453,^,^456,^,^466,^,^469,^,^479,^,^487,^,^492,^,^501,^,^520,^,^522,^,^548,^,^550,^,^555,^,^563,^,^605,^,^607,^,^612,^,^619,^,^624,^,^776,^,^803,^,^874,^,^921,970a624b142,^,^161,^,^422,^,^428,^,^655,^,^669,^,^675,^,^695,^,^708,^,^835,^,^855,^,^861,^,^877,^,^935,^,^949,^,^950,^,^958,^,^969,^,^972,^,^994,997a950b973a741,^,^755,^,^760,792^
| Cohort studies describing nonexposed cohorts drawn from the same community as the exposed cohort (n = 56) ^80,^,^400,^,^401,^,^436,^,^439,^,^449,^,^453,^,^458,^,^466,^,^486,^,^520,^,^522,^,^527,^,^540,^,^548,^,^563,^,^599,^,^605,^,^614,^,^624,^,^772,^,^807,^,^873,^,^874,^,^907,^,^912,921a624b142,^,^416,^,^663,^,^668,^,^670,^,^685,^,^693,^,^695,^,^699,^,^703,^,^708,^,^712,^,^781,^,^788,^,^790,^,^857,^,^877,^,^935,^,^950,^,^958,969a950b973a741,^,^749,^,^755,^,^757,1003^
| Cohort studies that reported reliable methods for ascertainment of exposure (n = 10) ^141,^,^439,^,^456,^,^458,^,^668,^,^776,^,^835,^,^949,^,^969,973a^
| Cohort studies that reported reliable methods for ascertainment of outcome (n = 10) ^80,^,^453,^,^466,^,^469,^,^605,^,^619,^,^630,^,^695,^,^958,1009^
| Cohort studies that adjusted for important confounding factors in the design or analysis (n = 99) ^105,^,^142,^,^200,^,^201,^,^385,399^–^401,^,^422,^,^449,^,^466,^,^486,^,^492,^,^501,^,^522,^,^555,^,^574,^,^583,^,^585,^,^598,^,^599,^,^607,^,^612,^,^668,^,^669,^,^672,^,^675,^,^685,^,^693,^,^703,^,^723,^,^772,^,^779,^,^803,^,^833,^,^853,^,^873,^,^909,^,^923,^,^949,^,^950,^,^964,^,^972,^,^983,997a950b936,973a141,^,^416,^,^439,^,^453,^,^458,^,^487,49^,^8,^,^520,^,^526,^,^563,^,^576,^,^581,^,^644,^,^647,^,^695,^,^700,^,^712,^,^720,^,^731,^,^734,^,^741,^,^745,^,^749,^,^755,^,^757,^,^763,^,^776,^,^792,^,^807,^,^817,^,^835,^,^855,^,^857,^,^861,^,^874,^,^877,^,^886,^,^907,^,^921,^,^939,^,^948,^,^958,^,^960,^,^967,^,^969,^,^985,^,^989,^,^995,^,^1003,^,^1008,1009^
| Cohort studies that reported reliable methods for outcome assessment (n = 109) ^80,^,^161,200^–^202,^,^385,399^–^401,^,^416,^,^428,^,^439,^,^449,^,^450,^,^452,^,^456,^,^458,^,^466,^,^479,^,^486,^,^498,^,^499,^,^501,^,^508,^,^520,^,^526,^,^540,^,^555,^,^576,^,^581,^,^585,^,^586,598^–^601,^,^612,^,^619,^,^633,^,^643,^,^644,^,^647,^,^655,^,^668,^,^669,^,^672,^,^675,^,^685,^,^686,^,^693,^,^699,^,^700,^,^703,^,^712,^,^720,^,^721,^,^723,^,^731,^,^734,^,^741,^,^745,^,^749,^,^755,^,^757,^,^760,^,^763,^,^771,^,^772,^,^776,^,^779,^,^781,^,^792,^,^803,^,^807,^,^817,^,^833,^,^853,^,^855,^,^857,^,^861,^,^874,^,^877,^,^886,^,^907,^,^909,^,^912,^,^917,^,^923,^,^927,^,^928,^,^939,^,^948,^,^949,^,^952,^,^958,^,^960,^,^964,^,^967,^,^969,^,^970,^,^972,^,^983,^,^985,^,^989,^,^995,^,^997,^,^1003,^,^1008,1009^
| Cohort studies reporting length of followup enough for outcomes to occur (n = 44) ^439,^,^453,^,^456,^,^469,^,^487,^,^492,^,^501,^,^522,^,^548,^,^563,^,^574,^,^583,^,^599,^,^605,^,^614,^,^619,^,^624,^,^776,^,^820,^,^873,874a624b105,^,^141,^,^142,^,^422,^,^630,^,^663,^,^669,^,^670,^,^688,^,^695,^,^708,^,^833,^,^855,^,^861,^,^877,^,^949,^,^950,^,^969,994a950b936,973a^
| Cohort studies reporting adequate followup of cohorts (n = 29) ^141,^,^439,^,^469,^,^487,^,^501,^,^522,^,^548,^,^599,^,^605,^,^614,^,^619,^,^630,^,^669,^,^670,^,^708,^,^855,^,^857,^,^861,^,^873,^,^874,^,^877,^,^921,^,^949,^,^950,^,^969,994a950b936,973a^
| Cohort studies that reported source of funding (n = 41) ^161,^,^200,^,^201,^,^385,^,^399,^,^416,^,^422,^,^439,^,^453,^,^456,^,^486,^,^492,^,^498,^,^555,^,^585,^,^605,^,^607,^,^644,^,^734,^,^745,^,^755,^,^757,^,^760,^,^776,^,^788,^,^792,^,^807,^,^833,^,^874,^,^877,^,^886,^,^909,^,^912,^,^949,^,^960,^,^967,^,^989,^,^997,^,^1003,^,^1008,1009^
Cross sectional studies—NOS scale | Cross sectional studies describing representative samples of the target population (n = 62) ^951a951b388,^,^441,^,^443,^,^446,^,^454,^,^470,^,^473,^,^481,495^–^497,^,^506,^,^529,^,^534,^,^535,^,^551,^,^552,978a552b432,^,^560,^,^565,^,^568,^,^570,^,^582,^,^591,^,^628,^,^632,^,^646,^,^648,^,^649,^,^660,^,^661,^,^701,^,^717,^,^729,^,^740,^,^744,^,^748,^,^778,^,^865,^,^869,^,^876,^,^879,^,^880,^,^887,^,^888,^,^890,^,^892,^,^896,^,^899,^,^901,^,^902,^,^905,^,^908,^,^924,^,^933,^,^941,^,^976,990^
| Cross sectional studies describing that comparison groups were drawn from the same community as the study group (n = 24) ^951a951b388,^,^390,^,^441,^,^446,^,^454,^,^481,^,^497,^,^570,^,^582,^,^591,^,^628,^,^646,^,^648,^,^660,^,^701,^,^722,^,^737,^,^740,^,^778,^,^849,^,^899,924^
| Cross sectional studies that reported reliable methods for ascertainment of exposure (n = 0)
| Cross sectional studies that adjusted for important confounding factors in the design or analysis (n = 63) ^146,951a951b388,^,^390,^,^438,^,^441,^,^443,^,^446,^,^470,^,^473,495^–^497,^,^506,^,^511,^,^529,^,^546,^,^551,^,^552,^,^795,^,^798,980a552b412,^,^560,^,^568,^,^570,^,^591,^,^638,^,^640,^,^641,^,^646,^,^661,^,^664,^,^667,^,^701,^,^717,^,^722,^,^732,^,^735,^,^740,^,^743,^,^744,^,^748,^,^778,^,^849,^,^865,^,^876,^,^880,^,^884,^,^887,^,^888,^,^890,^,^892,^,^899,^,^901,^,^905,^,^911,^,^924,^,^933,^,^976,990^
| Cross sectional studies that reported reliable methods for outcome assessment (n = 62) ^146,^,^451,^,^465,^,^509,^,^798,^,^978,^,^980,1010a513,^,^551,552a552b432,^,^565,^,^632,^,^636,^,^640,^,^641,^,^646,^,^648,^,^664,^,^667,^,^694,^,^701,^,^717,^,^718,^,^729,^,^732,^,^735,^,^737,^,^740,^,^743,^,^744,^,^842,^,^859,^,^869,^,^876,879^–^881,^,^884,^,^892,^,^893,^,^896,^,^898,^,^899,901^–^903,^,^905,^,^908,^,^911,^,^918,^,^937,^,^941,^,^957,^,^968,^,^975,^,^976,^,^990,^,^1000,1004^
| Cross sectional studies that reported source of funding (n = 27) ^388,^,^432,^,^438,^,^473,^,^511,^,^632,^,^636,^,^641,^,^646,^,^649,^,^704,^,^744,^,^778,^,^798,^,^876,^,^879,^,^880,^,^888,^,^893,^,^896,901^–^903,^,^905,^,^908,^,^957,1010^

NOS = Newcastle-Ottawa scales

Table G6 Studies on meditation practices examined in clinical trials and observational studies

Category of meditation practice | Meditation practice | N | Study design and associated references
Mantra meditation (337) | ACEM meditation | 7 | RCT (3);^956,^,^959,961^ Cohort (3);^720,^,^958,960^ Cross sectional (1)^957^
| Ananda marga | 3 | Cohort (2);^498,526^ Cross sectional (1)^786^
| Cayce's meditation | 1 | RCT (1) ^680^
| CSM | 11 | RCT (11) ^97,^,^193,^,^264,^,^384,^,^410,^,^536,^,^537,^,^627,^,^658,^,^676,702^
| SRELAX (technique modeled after TM® | 1 | RCT (1) ^222^
| Concentrative/ rosary prayer | 2 | Before-and-after (1); ^966^ Cohort (1) ^969^
| Mantra meditation | 31 | RCT (17);^194,^,^203,^,^260,^,^434,^,^472,^,^483,^,^503,^,^531,^,^597,^,^626,^,^706,^,^719,^,^736,^,^761,^,^777,^,^805,965^ NRCT (3);^494,^,^577,650a^ Before-and-after (6);^393,652^–^654,^,^856,963^ Cohort (1);^853^ Cross sectional (4); ^591,^,^828,^,^859,937^
| RR | 51 | RCT (40);^208,^,^234,^,^236,^,^304,^,^306,^,^394,^,^460,475^–^477,^,^480,504a75,^,^91,^,^92,^,^94,^,^191,^,^192,^,^209,^,^218,^,^265,^,^268,^,^283,^,^284,^,^288,^,^396,^,^515,^,^521,^,^530,^,^558,^,^567,^,^569,^,^572,^,^592,^,^594,^,^610,^,^616,^,^625,^,^637,988^ NRCT (5);^306b228,^,^673,^,^678,938^ Before-and-after (5);^414,^,^459,^,^524,^,^525,753^ Cohort (1)^492^
| TM® | 230 | RCT (38);^86,^,^186,^,^189,^,^190,^,^205,^,^206,^,^210,^,^220,^,^221,^,^259,^,^261,^,^267,^,^279,^,^282,^,^309,^,^392,^,^407,^,^418,^,^433,^,^478,^,^519,^,^528,^,^545,^,^557,^,^674,^,^677,^,^683,^,^782,^,^796,945^,^78,^,^270,^,^424,^,^714,^,^759,^,^769,^,^793,1005^ NRCT (22); ^187,^,^188,^,^271,^,^289,^,^291,^,^292,^,^429,^,^440,^,^463,^,^518,^,^538,^,^587,^,^659,^,^662,^,^705,^,^787,^,^816,^,^974,^,^986,^,^293,^,^758,252^ Before-and-after (19); ^171,^,^295,^,^311,^,^319,^,^324,^,^471,^,^505,^,^533,^,^561,^,^709,^,^733,^,^750,^,^780,^,^814,^,^815,^,^850,^,^942,^,^996,1002^ Cohort (97); ^80,^,^385,399^–^401,^,^436,^,^439,^,^449,^,^450,^,^452,^,^453,^,^458,^,^466,^,^469,^,^487,^,^499,^,^501,^,^508,^,^520,^,^522,^,^540,^,^548,^,^555,^,^563,^,^576,^,^581,^,^583,^,^585,^,^586,598^–^601,^,^607,^,^612,^,^619,^,^624,^,^771,^,^772,^,^776,^,^817,^,^923,^,^927,^,^928,^,^952,^,^964,^,^970,1008a624b416,^,^422,^,^428,^,^633,^,^643,^,^644,^,^647,^,^655,^,^663,668^–^670,^,^672,^,^675,^,^685,^,^686,^,^688,^,^693,^,^695,^,^700,^,^703,^,^712,^,^721,^,^723,^,^779,^,^781,^,^790,^,^835,^,^950,^,^972,^,^983,^,^994,997a950b731,^,^734,^,^936,973a973b741,^,^745,^,^749,^,^757,^,^760,^,^763,^,^792,^,^939,1003^ Cross sectional (54) ^951a951b438,^,^441,^,^446,^,^451,^,^509,^,^795,^,^978,980a509b513,^,^529,^,^534,^,^535,^,^546,547a547b551,552a552b560,^,^568,^,^570,571a571b412,^,^582,^,^638,^,^640,^,^646,^,^648,^,^649,^,^660,^,^661,^,^671,^,^694,^,^701,^,^704,^,^717,^,^718,^,^722,^,^732,^,^737,^,^740,^,^743,^,^744,^,^748,^,^941,^,^975,^,^976,^,^993,^,^1000,1004^
Mindfulness meditation (127) | MBSR | 49 | RCT (22);^167,^,^195,^,^196,^,^244,^,^245,^,^263,^,^421,^,^423,^,^485,^,^493,^,^512,^,^556,^,^575,^,^579,^,^589,^,^687,^,^710,^,^711,^,^754,^,^756,^,^930,934;^ NRCT (11) ^272,^,^419,^,^420,^,^482,^,^593,^,^602,^,^681,^,^689,^,^691,^,^752,773^ Before-and-after (16) ^402,^,^457,^,^488,^,^517,^,^606,^,^609,^,^620,^,^622,^,^635,^,^682,^,^684,^,^692,^,^697,^,^724,^,^770,947^
| MM (NS) | 37 | RCT (16);^241,^,^242,^,^258,^,^386,^,^395,^,^403,^,^444,^,^447,^,^448,^,^474,^,^490,^,^738,^,^751,^,^775,^,^932,1011^ NRCT (8);^106,^,^249,^,^430,^,^523,^,^532,^,^696,^,^728,762^ Before-and-after (6);^442,^,^464,^,^604,^,^716,^,^727,922^ Cohort (4);^479,^,^486,^,^605,614^ Cross sectional (3)^497,^,^511,641^
| Zen Buddhist meditation | 28 | RCT (7); ^70,^,^225,^,^237,^,^554,^,^765,^,^774,920^ NRCT (5);^197,^,^227,^,^500,^,^629,639^ Cohort (6);^105,^,^456,^,^550,^,^886,^,^917,995^ Cross sectional (7);^443,^,^495,^,^636,^,^729,^,^742,^,^918,924^ Before-and-after (3) ^426,^,^913,916^
| MBCT | 7 | RCT (5);^427,^,^455,^,^929,^,^940,984^ NRCT (1);^553^ Before-and-after (1)^784^
| Vipassana | 6 | Before-and-after (2) ^847,848;^ Cohort (2) ^708,921;^ Cross sectional (2) ^664,990^
Meditation practices (ND) | | 21 | RCT (11);^387,^,^484,494b215,^,^431,^,^514,^,^539,^,^651,^,^783,^,^910,987^ NRCT (6);^198,^,^199,^,^274,^,^656,^,^730,915^ Before-and-after (2);^580,808^ Cohort (1);^630^ Cross sectional (1)^481^
Miscellaneous meditation practices | | 11 | RCT (3);^507,^,^726,791^ Before-and-after (3);^621,^,^623,801^ Cohort (2);^935,967^ Cross sectional (3)^454,^,^628,933^
Qi Gong | | 37 | RCT (13);^207,^,^211,^,^213,^,^214,^,^243,^,^262,^,^405,^,^767,^,^900,^,^919,^,^953,^,^954,977^ Before-and-after (9);^299,^,^316,^,^502,^,^634,^,^875,^,^889,^,^891,^,^914,944^ Cohort (7); ^161,200^–^202,^,^873,^,^907,912^ Cross sectional (8);^632,^,^778,^,^884,^,^887,^,^888,^,^890,^,^892,893^
Tai Chi | | 88 | RCT (29);^235,^,^285,^,^286,^,^307,^,^391,^,^398,^,^408,^,^409,^,^413,^,^437,^,^467,^,^541,^,^573,^,^603,^,^631,^,^665,^,^871,^,^885,^,^894,^,^895,^,^1006,^,^223,^,^999,^,^746,^,^397,^,^882,^,^768,^,^246,287^ NRCT(17);^248,^,^290,^,^326,^,^435,^,^489,^,^566,^,^595,^,^596,^,^617,^,^645,^,^698,^,^713,^,^789,^,^878,^,^904,^,^955,1001^ Before-and-after (20);^152,^,^296,^,^317,^,^425,^,^564,^,^588,^,^590,^,^608,^,^657,^,^690,^,^715,^,^725,^,^747,^,^766,^,^872,^,^883,^,^897,^,^906,^,^931,962^ Cohort (4);^699,^,^874,^,^877,909^ Cross sectional (18) ^388,^,^432,^,^470,^,^565,^,^735,^,^876,879^–^881,^,^896,^,^898,^,^899,901^–^903,^,^905,^,^908,911^
Yoga | | 192 | RCT (69);^111,^,^118,^,^120,^,^127,^,^134,^,^138,^,^140,168^–^170,^,^174,^,^176,^,^177,^,^182,^,^184,^,^185,^,^204,^,^212,^,^216,^,^217,^,^219,^,^224,^,^233,238^–^240,^,^266,^,^269,^,^278,^,^280,^,^281,^,^305,^,^308,^,^325,^,^389,^,^404,^,^417,^,^445,542^–^544,^,^549,^,^562,^,^584,^,^615,^,^618,^,^666,^,^764,^,^811,^,^819,^,^823,^,^825,^,^829,^,^832,836^–^839,^,^841,^,^844,^,^852,^,^858,^,^868,^,^926,^,^943,^,^946,^,^971,^,^991,998^ NRCT (36);^122,^,^126,^,^137,^,^175,178^–^181,^,^183,^,^226,^,^247,^,^250,^,^251,^,^273,^,^415,^,^461,^,^462,^,^642,^,^679,^,^794,^,^799,^,^804,^,^806,^,^809,^,^818,^,^824,^,^826,^,^834,^,^846,^,^854,^,^860,^,^864,^,^866,^,^925,^,^981,1007^ Before-and-after (54);^83,^,^133,^,^172,^,^294,^,^297,^,^298,300^–^303,^,^310,312^–^315,^,^318,320^–^323,^,^406,^,^411,^,^468,^,^491,^,^510,^,^516,^,^559,^,^578,^,^611,^,^613,^,^707,^,^739,^,^797,^,^800,^,^802,^,^810,^,^812,^,^813,^,^821,^,^822,^,^827,^,^830,^,^831,^,^840,^,^843,^,^845,^,^851,^,^862,^,^863,^,^867,^,^870,^,^979,^,^982,992^ Cohort (18);^141,^,^142,^,^527,^,^574,^,^755,^,^788,^,^803,^,^807,^,^820,^,^833,^,^855,^,^857,^,^861,^,^948,^,^949,^,^985,^,^989,1009^ Cross-sectional (15) ^146,^,^390,^,^465,^,^473,^,^496,^,^506,^,^667,^,^785,^,^798,^,^842,^,^849,^,^865,^,^869,^,^968,1010^

CSM = Clinically Standardized Meditation; MBCT = mindfulness-based cognitive therapy; MM = mindfulness meditation; ND = not described; NS = not specified; RR = Relaxation Response; TM® = Transcendental Meditation®

Table G7 Type of control groups for intervention studies on meditation practices

Type of control group | | N groups | N studies | References
Placebo/sham | | 18 | 18 | Mantra meditation (9 groups, 9 studies)
| | | | TM^®^ (3);^433^,^793,1005^ Mantra (NS) (3);^434,^,^472,531^ RR (2);^477,678^ SRELAX (1)^222^
| | | | Meditation practices (ND) (3 groups, 3 studies) ^484,^,^651,987^
| | | | Yoga (2 groups, 2 studies) ^170,846^
| | | | Mindfulness meditation (1 group, 1 study)
| | | | Zen Buddhist meditation (1) ^554^
| | | | Qi Gong (2 groups, 2 studies) ^405,767^
| | | | Tai Chi (1 group, 1 study) ^999^
No-treatment concurrent control | NT | 126 | 123 | Mantra meditation (44 groups, 43 studies)
| | | | TM^®^ (25);^86,^,^171,^,^187,^,^188,^,^190,^,^259,^,^279,^,^282,291^–^293^,^440,^,^463,^,^518,^,^538,^,^662,^,^674,^,^705,^,^758,^,^769,^,^793,^,^945,^,^974,^,^986,1005^ Mantra (NS) (8);^194,^,^203,^,^434,^,^472,^,^531,^,^597,^,^650,719^ RR (6);^92,^,^192,^,^284,^,^394,^,^480,673^ CSM (2);^264, 676^ ACEM meditation (1);^959^ Cayce's meditation (1)^680^
| | | | Yoga (31 groups, 30 studies) ^111,^,^126,^,^137,^,^168,^,^172,^,^175,^,^185,^,^204,^,^217,^,^247,^,^251,^,^305,^,^325,^,^417,^,^445,^,^542,^,^679,^,^799,^,^804,^,^806,^,^819,^,^823,^,^826,^,^838,^,^854,^,^860,^,^864,^,^925,^,^943,981^
| | | | Mindfulness meditation (23 groups, 22 studies)
| | | | MBSR (9);^167,^,^244,^,^245,^,^272,^,^419,^,^575,^,^593,^,^691,930^ MM (NS) (7);^106,^,^395,^,^474,^,^523,^,^728,^,^762,1011^ Zen Buddhist meditation (5);^70,^,^225,^,^554,^,^629,920^ MBCT (1) ^455^
| | | | Tai Chi (19 groups, 19 studies) ^223,^,^285,^,^286,^,^290,^,^326,^,^437,^,^467,^,^489,^,^541,^,^595,^,^596,^,^617,^,^645,^,^698,^,^882,^,^885,^,^894,^,^895,955^
| | | | Meditation practices (ND) (6 groups, 6 studies) ^215,^,^431,^,^656,^,^730,^,^915,987^
| | | | Qi Gong (2 groups, 2 studies) ^262,954^
| | | | Miscellaneous meditation practices (1 group, 1 study) ^791^
| WL | 62 | 62 | Mantra meditation (24 groups, 24 studies)
| | | | TM^®^ (10); ^86,^,^252,^,^259,^,^271,^,^289,^,^309,^,^418,^,^528,^,^557,677^ CSM (5);^193,^,^384,^,^536,^,^537,658^ RR (5); ^75,^,^208,^,^476,^,^515,610^ Mantra (NS) (3); ^626,^,^761,805^ SRELAX (1) ^222^
| | | | Mindfulness meditation (21 groups, 21 studies)
| | | | MBSR (11);^420,^,^421,^,^485,^,^493,^,^512,^,^589,^,^602,^,^681,^,^710,711^,^196^ MM (NS) (6); ^386,^,^395,^,^403,^,^430,^,^447,532^ MBCT (2); ^553,984^ Zen Buddhist meditation (2) ^765,774^
| | | | Yoga (10 groups, 10 studies) ^120,^,^169,^,^175,^,^280,^,^584,^,^666,^,^764,^,^825,^,^946,971^
| | | | Meditation practices (ND) (3 groups, 3 studies) ^387,^,^730,783^
| | | | Qi Gong (2 groups, 2 studies) ^213,214^
| | | | Tai Chi (2 groups, 2 studies) ^398,408^
Active (positive) concurrent controls—interventions other than meditation practices | Exercise/physical activity | 52 | 45 | Yoga (23 groups, 18 studies) ^233,^,^266,^,^280,^,^281,^,^415,^,^417,^,^461,^,^462,^,^618,^,^666,^,^811,^,^834,^,^836,^,^837,^,^839,^,^844,^,^998,1007^
| | | | Tai Chi (14 groups, 14 studies) ^235,^,^248,^,^287,^,^307,^,^409,^,^413,^,^435,^,^541,^,^603,^,^631,^,^665,^,^713,^,^789,1006^
| | | | Mantra meditation (13 groups, 10 studies)
| | | | Mantra (NS) (3); ^483,^,^706,777^ RR (3); ^304,^,^394,480^ TM^®^ (2); ^78,282^ ACEM meditation (1); ^956^ CSM (1) ^264^
| | | | Mindfulness meditation (1 group, 1 study) MBSR (1) ^930^
| | | | Meditation practices (ND) (1 group, 1 study) ^514^
| | | | Qi Gong (1 group, 1 study) ^207^
| Rest and states of relaxation | 47 | 45 | Mantra meditation (30 groups, 28 studies)
| | | | RR (14); ^304,^,^306,^,^475,504b91,^,^265,^,^283,^,^284,^,^288,^,^396,^,^558,^,^594,^,^625,938^ TM^®^ (9); ^186,^,^279,^,^392,^,^424,^,^519,^,^677,^,^683,^,^782,796^ Mantra (NS) (3); ^260,^,^503,965^ CSM (2) ^537,627^
| | | | Yoga (9 groups, 9 studies) ^134,^,^177,^,^181,^,^204,^,^219,^,^224,^,^615,^,^858,868^
| | | | Mindfulness meditation (6 groups, 6 studies)
| | | | Zen Buddhist meditation (3); ^70,^,^500,639^ MM (NS) (2); ^728,932^ MBSR (1) ^754^
| | | | Meditation practices (ND) (2 groups, 2 studies) ^274,^,^539,915^
| Education | 46 | 44 | Mantra meditation (19 groups, 17 studies)
| | | | TM^®^ (9); ^205,^,^206,^,^210,^,^220,^,^221,^,^407,^,^659,^,^714,787^ RR (5); ^94,^,^192,^,^218,^,^234,476^ Mantra (NS) (2); ^483,777^ CSM (1)^702^
| | | | Mindfulness meditation (10 groups, 10 studies)
| | | | MBSR (5); ^423,^,^575,^,^579,^,^689,756^ Zen Buddhist meditation (3); ^197,^,^225,237^ MM (NS) (2) ^403,448^
| | | | Yoga (8 groups, 8 studies) ^118,^,^212,^,^216,^,^461,^,^462,^,^562,^,^926,1007^
| | | | Tai Chi (6 groups, 6 studies) ^235,^,^307,^,^397,^,^665,^,^746,878^
| | | | Meditation practices (ND) (2 groups, 2 studies) ^656,910^
| | | | Miscellaneous meditation practices (1 groups, 1 study) ^791^
| PMR | 39 | 39 | Mantra meditation (27 groups, 27 studies)
| | | | TM^®^ (10); ^86,^,^220,^,^221,^,^429,^,^528,^,^545,^,^769,^,^945,^,^986,1005^ RR (8); ^191,^,^265,^,^288,^,^475,^,^477,^,^569,^,^616,988^ Mantra (NS) (5);^472,^,^531,^,^577,^,^626,736^ CSM (3); ^97,^,^193,627^ ACEM meditation (1) ^961^
| | | | Yoga (6 groups, 6 studies) ^122,^,^204,^,^389,^,^549,^,^615,991^
| | | | Mindfulness meditation (5 groups, 5 studies)
| | | | MBSR (2); ^196,263^ MM (NS) (2); ^696,751^ Zen Buddhist meditation (1) ^765^
| | | | Meditation practices (ND) (1 group, 1 study) ^494b^
| Cognitive behavioral techniques | 22 | 20 | Mantra meditation (9 groups, 9 studies)
| | | | TM^®^ (3); ^545,^,^674,677^; RR (3) ^476,^,^616,637^ CSM (2); ^410,702^ Mantra (NS) (1) ^483^
| | | | Mindfulness meditation (7 groups, 7 studies)
| | | | MM (NS) (4); ^241,^,^444,^,^474,775^ MBSR (3) ^482,^,^579,687^
| | | | Meditation practices (ND) (3 groups, 2 studies) ^656,987^
| | | | Yoga (3 groups, 2 studies) ^120^,^946^
| Miscellaneous active controls | 23 | 19 | Yoga (7 groups, 6 studies) ^138,^,^226,^,^273,^,^679,^,^825,943^
| | | | Mantra meditation (6 groups, 6 studies)
| | | | RR (3);^396,^,^558,592^ Mantra (NS) (2);^494a719^ TM^®^ (1) ^270^
| | | | Mindfulness meditation (6 groups, 4 studies)
| | | | MBSR (2);^195,754^ Zen Buddhist meditation (1);^225^ MM (NS) (1) ^490^
| | | | Miscellaneous meditation practices (2 groups, 1 study) ^507^
| | | | Meditation practices (ND) (1 group, 1 study) ^198^
| | | | Tai Chi (1 group, 1 study) ^1001^
| Group therapy | 14 | 13 | Mantra meditation (6 groups, 6 studies)
| | | | RR (3);^236,^,^394,637^ TM^®^ (2);^261,816^ ACEM meditation (1) ^961^
| | | | Mindfulness meditation (3 groups, 3 studies)
| | | | MBSR (1); ^482^ MM (NS) (2) ^241,738^
| | | | Tai Chi (3 groups, 2 studies): ^391,768^
| | | | Yoga (2 groups, 2 studies) ^269,618^
| Psychotherapy | 3 | 3 | Mantra meditation (1 group, 1 study) TM^®^ (1) ^478^
| | | | Mindfulness meditation (1 group, 1 study) MBSR (1) ^752^
| | | | Yoga (1 group, 1 study) ^273^
| BF | 13 | 12 | Mantra meditation (12 groups, 11 studies)
| | | | RR (6);^208,306b306a191,^,^209,228^ Mantra (NS) (3);^194,^,^503,531^ TM^®^ (2); ^270,683^
| | | | Yoga (1 group, 1 study) ^273^
| Reading | 8 | 8 | Mantra meditation (6 groups, 6 studies)
| | | | RR (4); ^521,^,^567,^,^572,592^ TM^®^ (2) ^587,759^
| | | | Tai Chi (1 group, 1 study) ^307^
| | | | Yoga (1 group, 1 study) ^615^
| Pharmacological interventions | 8 | 8 | Yoga (6 groups, 6 studies) ^138,^,^217,^,^806,^,^809,^,^818,841^ Qi Gong (2 groups, 2 studies) ^211,262^
| Hypnosis | 4 | 4 | Mantra meditation (2 groups, 2 studies) TM^®^ (2) ^75,460^
| | | | Meditation practices (ND) (2 groups, 2 studies) ^494b198^
| Massage | 3 | 2 | Mantra meditation (2 groups, 1 study) RR (1) ^558^
| | | | Mindfulness meditation (1 group, 1 study) MBSR (1) ^556^
| Acupuncture | 1 | 1 | Tai Chi (1 group, 1 study) ^1001^
Active (positive) concurrent controls—meditation practices as comparison groups | Yoga | 5 | 5 | Mantra meditation (4 groups, 4 studies)
| | | | TM^®^ (3); ^793,^,^796,816^ Mantra (NS) (1) ^597^
| | | | Meditation practices (ND) (1 group, 1 study) ^656^
| Mantra meditation | 3 | 3 | Yoga (3 groups, 3 studies) ^169,^,^174,175^
| Mindfulness meditation | 3 | 3 | Mantra meditation (2 groups, 2 studies)
| | | | TM^®^ (1); ^279^ Mantra (NS) (1) ^494a^
| | | | Meditation practices (ND) (1 group, 1 study) ^783^
| Meditation practices (ND) | 2 | 2 | Mantra meditation (2 groups, 2 studies)
| | | | RR (1); ^530^ TM^®^ (1) ^1005^
| Tai Chi | 1 | 1 | Mantra meditation (1 group, 1 study) RR (1) ^480^
Different dose or regimen of meditation practices—concurrent control groups | Yoga | 15 | 14 | Yoga (15 groups, 14 studies) ^111,^,^127,^,^140,175^–^185^
| Mantra meditation | 9 | 9 | Mantra meditation (9 groups, 9 studies)
| | | | TM^®^ (5); ^186^–^190^ RR (2); ^191,192^ CSM (1); ^193^ Mantra (NS) (1) ^194^
| Mindfulness meditation | 5 | 4 | Mindfulness meditation (5 groups, 4 studies)
| | | | MBSR (2); ^195,196^ Zen Buddhist meditation (1); ^197^ MM (NS) (1) ^395^
| Meditation practices (ND) | 2 | 2 | Meditation practices (ND) (2 groups, 2 studies) ^198,199^
Usual care | | 37 | 37 | Mindfulness meditation (9 groups, 9 studies)
| | | | MM (NS) (2); ^249,258^; MBSR (2)^556,^,^773,934^
| | | | MBCT (3); ^929^,^427,940^ Zen Buddhist (1) ^227^
| | | | Qi Gong (3 groups, 3 studies) ^243,^,^900,919^
| | | | Mantra meditation (2 groups, 2 studies)
| | | | RR (1)^268^ TM^®^ (2) ^78,270^
| | | | Tai Chi (4 groups, 4 studies) ^246,^,^566,^,^573,904^
| | | | Yoga (16 groups, 16 studies)^238^–^240,^,^250,^,^278,^,^308,^,^404,^,^543,^,^544,^,^642,^,^794,^,^824,^,^829,^,^832,^,^852,866^
| | | | Meditation practices (ND) (1 group, 1 study) ^274^
| | | | Miscellaneous meditation practices (1 group, 1 study)^726^
Control groups (ND) | | 6 | 6 | Mantra meditation (2 groups, 2 studies)
| | | | RR (1);^234^ TM^®^ (1) ^267^
| | | | Qi Gong (2 groups, 2 studies) ^953,977^
| | | | MM (NS) (1); ^242^
| | | | Tai Chi (1 groups, 1 studies) ^871^
Number of controls per study | Single control | 275 | 275 | Yoga (80 groups, 80 studies) ^118,^,^120,^,^126,^,^127,^,^134,^,^137,^,^168,^,^170,^,^172,^,^174,^,^176,178^–^180,182^–^184,^,^212,^,^216,^,^219,^,^224,^,^226,^,^233,238^–^240,^,^247,^,^250,^,^251,^,^266,^,^269,^,^278,^,^281,^,^308,^,^325,^,^389,^,^404,^,^415,^,^445,542^–^544,^,^549,^,^562,^,^584,^,^642,^,^764,^,^794,^,^799,^,^804,^,^809,^,^811,^,^818,^,^819,^,^823,^,^824,^,^826,^,^829,^,^832,^,^834,836^–^839,^,^841,^,^844,^,^846,^,^852,^,^854,^,^858,^,^860,^,^864,^,^866,^,^868,^,^925,^,^926,^,^971,^,^981,^,^991,998^
| | | | Mantra meditation (77 groups, 77 studies)
| | | | TM^®^ (34); ^171,^,^189,^,^205,^,^206,^,^210,^,^252,^,^261,^,^267,^,^271,^,^289,291^–^293,^,^309,^,^392,^,^407,^,^418,^,^424,^,^429,^,^433,^,^440,^,^463,^,^478,^,^518,^,^519,^,^538,^,^557,^,^587,^,^662,^,^705,^,^714,^,^758,^,^759,^,^782,^,^787,974^ RR (23);^236,^,^306,^,^460,504a92,^,^94,^,^209,^,^218,^,^268,^,^283,^,^515,^,^521,^,^530,^,^567,^,^569,^,^572,^,^594,^,^610,^,^625,^,^673,^,^678,^,^938,988^ Mantra (NS) (9);^203,^,^260,^,^577,^,^650,^,^706,^,^736,^,^761,^,^805,965^ CSM (6); ^97,^,^384,^,^410,^,^536,^,^658,676^ ACEM meditation (2); ^956,959^ Cayce's meditation (1) ^680^
| | | | Mindfulness meditation (55 groups, 55 studies)
| | | | MBSR (25) ^167,^,^244,^,^245,^,^263,^,^272,419^–^421,^,^423,^,^485,^,^493,^,^512,^,^589,^,^593,^,^602,^,^681,^,^687,^,^689,^,^691,^,^710,^,^711,^,^752,^,^756,^,^773,934^ MM (NS) (18) ^106,^,^242,^,^249,^,^258,^,^386,^,^430,^,^444,^,^447,^,^448,^,^523,^,^532,^,^696,^,^738,^,^751,^,^762,^,^775,^,^932,1011^; MBCT (6); ^427,^,^455,^,^553,^,^929,^,^940,984^ Zen Buddhist meditation (6); ^227,^,^237,^,^500,^,^639,^,^774,920^
| | | | Tai Chi (40 groups, 40 studies) ^223,^,^246,^,^248,285^–^287,^,^290,^,^326,^,^391,^,^397,^,^398,^,^408,^,^409,^,^413,^,^435,^,^437,^,^467,^,^489,^,^566,^,^573,^,^595,^,^596,^,^603,^,^617,^,^631,^,^645,^,^698,^,^713,^,^746,^,^789,^,^871,^,^878,^,^882,^,^885,^,^894,^,^895,^,^904,^,^955,^,^999,1006^
| | | | Qi Gong (12 groups, 12 studies) ^207,^,^211,^,^213,^,^214,^,^243,^,^405,^,^767,^,^900,^,^919,^,^953,^,^954,977^
| | | | Meditation practices (ND) (10 groups, 10 studies) ^199,^,^215,^,^274,^,^387,^,^431,^,^484,^,^514,^,^539,^,^651,910^
| | | | Miscellaneous meditation practices (1 group, 1 study) ^726^
| Multiple controls | 296 | 127 | Mantra meditation (152 groups, 65 studies)
| | | | TM^®^ (25); ^78,^,^86,186^–^188,^,^190,^,^220,^,^221,^,^259,^,^270,^,^279,^,^282,^,^528,^,^545,^,^659,^,^674,^,^677,^,^683,^,^769,^,^793,^,^796,^,^816,^,^945,^,^986,1005^ RR (22);^208,^,^234,^,^304,^,^306,^,^394,475^–^477,480b75,^,^91,^,^191,^,^192,^,^228,^,^265,^,^284,^,^288,^,^396,^,^558,^,^592,^,^616,637^ Mantra (NS) (11); ^472,^,^483,494a194,^,^434,^,^503,^,^531,^,^597,^,^626,^,^719,777^; CSM (5) ^193,^,^264,^,^537,^,^627,702^
| | | | ACEM meditation (1); ^961^ SRELAX (1) ^222,^
| | | | Yoga (63 groups, 26 studies) ^111,^,^122,^,^138,^,^140,^,^169,^,^175,^,^177,^,^181,^,^185,^,^204,^,^217,^,^273,^,^280,^,^305,^,^417,^,^461,^,^462,^,^615,^,^618,^,^666,^,^679,^,^806,^,^825,^,^943,^,^946,1007^
| | | | Mindfulness meditation (45 groups, 20 studies)
| | | | MBSR (8); ^195,^,^196,^,^482,^,^556,^,^575,^,^579,^,^754,930^ MM (NS) (6); ^241,^,^395,^,^403,^,^474,^,^490,728^ Zen Buddhist meditation (6)^70,^,^197,^,^225,^,^554,^,^629,765^
| | | | Meditation practices (ND) (17 groups, 7 studies) ^494b198,^,^656,^,^730,^,^783,^,^915,987^
| | | | Tai Chi (13 groups, 6 studies) ^235,^,^307,^,^541,^,^665,^,^768,1001^
| | | | Miscellaneous meditation practices (4 groups, 2 studies) ^507,791^
| | | | Qi Gong (2 groups, 1 study) ^262^

® BF = Biofeedback; CSM = Clinically Standardized Meditation; MBCT = mindfulness-based cognitive therapy; MBSR = Mindfulness-based stress reduction; MM = mindfulness meditation; = ND = not described; NS = not specified; NT = no treatment; PMR = progressive muscle relaxation; RR = Relaxation Response; TM = Transcendental Meditation; WL = waiting list

Table G8 Type of control groups for observational analytical studies on meditation practices

Type of control group | | N groups | N studies | References
Nonexposed cohorts/comparison groups | | 247 | 244 | Mantra meditation (155 groups, 153 studies)
| | | | TM® (140); ^509,994a638,^,^740,^,^748,951a951b80,^,^438,^,^441,^,^446,449^–^453,^,^458,^,^466,^,^487,^,^499,^,^508,^,^513,^,^520,^,^522,^,^534,^,^535,^,^540,^,^547,^,^771,^,^772,^,^795,^,^923,^,^964,^,^978,^,^980,1008a547b551,552a552b560,^,^563,^,^568,^,^570,571a400,^,^401,^,^576,^,^581,^,^585,^,^600,^,^601,^,^612,^,^619,^,^624,^,^776,^,^817,^,^927,^,^928,^,^970,^,^975,976a624b422,^,^428,^,^633,^,^640,^,^643,^,^644,^,^646,^,^648,^,^649,^,^655,^,^660,^,^661,^,^663,668^–^672,^,^685,^,^686,^,^688,693^–^695,^,^703,^,^712,^,^717,^,^718,^,^721,^,^723,^,^779,^,^781,^,^790,^,^835,^,^950,^,^972,^,^983,^,^993,997a950b385,^,^436,^,^469,^,^501,^,^509,^,^700,^,^731,^,^734,^,^737,^,^741,^,^745,^,^757,^,^760,^,^763,^,^792,^,^936,^,^941,^,^1000,^,^1003,1004b546,^,^555,571b399,^,^412,^,^416,^,^598,^,^599,^,^607,^,^647,^,^675,^,^701,^,^732,973b743,^,^744,973a^ Mantra (NS) (6); ^591,^,^828,^,^853,^,^859,^,^937,969^ ACEM meditation (4); ^720,^,^957,^,^958,960^ Ananda marga (3) ^498,^,^526,786^
| | | | Yoga (29 groups, 29 studies) ^141,^,^142,^,^146,^,^390,^,^465,^,^473,^,^496,^,^506,^,^527,^,^574,^,^667,^,^785,^,^798,^,^803,^,^807,^,^820,^,^833,^,^842,^,^849,^,^855,^,^857,^,^861,^,^865,^,^869,^,^949,^,^968,^,^985,^,^1009,1010^
| | | | Mindfulness meditation (21 groups, 21 studies)
| | | | Zen Buddhist meditation (12); ^105,^,^443,^,^456,^,^495,^,^636,^,^729,^,^742,^,^886,^,^917,^,^918,^,^924,995^ MM (NS) (6); ^479,^,^486,^,^497,^,^511,^,^605,641^ Vipassana (3) ^664,^,^921,990^
| | | | Tai Chi (22 groups, 21 studies) ^388,^,^432,^,^470,^,^565,^,^735,^,^874,^,^876,^,^877,879^–^881,^,^896,^,^898,^,^899,901^–^903,^,^905,^,^908,^,^909,911^
| | | | Qi Gong (13 groups, 13 studies) ^161,^,^200,^,^201,^,^632,^,^778,^,^884,^,^887,^,^888,^,^890,^,^892,^,^893,^,^907,912^
| | | | Miscellaneous meditation practices (5 groups, 5 studies) ^454,^,^628,^,^933,^,^935,967^
| | | | Meditation practices (ND) (2 groups, 2 studies) ^481,630^
Active (positive) concurrent controls exposed to Interventions other than meditation practices | Exercise/physical activity | 16 | 14 | Tai Chi (4 groups, 4 studies) ^470,^,^565,^,^879,903^
| | | | Yoga (4 groups, 4 studies) ^390,^,^755,^,^842,989^
| | | | Miscellaneous meditation practices (4 groups, 2 studies) ^933,935^
| | | | Mantra meditation (2 groups, 2 studies) TM® (2) ^529,704^
| | | | Meditation practices (ND) (1 group, 1 study) ^481^
| | | | Qi Gong (1 group, 1 study) ^202^
| Miscellaneous active controls | 7 | 5 | Mantra meditation (5 groups, 3 studies) TM® (3) ^439,^,^522,939^
| | | | Miscellaneous meditation practices (1 group, 1 study) ^935^
| | | | Tai Chi (1 group, 1 study) ^699^
| Progressive muscle relaxation | 5 | 4 | Mantra meditation (5 groups, 4 studies) TM® (4) ^509a509b508,749^
| Hypnosis | 3 | 3 | Mantra meditation (3 groups, 3 studies) TM® (3) ^655,^,^741,952^
| Rest and states of relaxation | 3 | 3 | Mantra meditation (3 groups, 3 studies) TM® (3) ^453,^,^586,939^
| Education | 2 | 2 | Qi Gong (1 group, 1 study) ^202^
| | | | Yoga (1 group, 1 study) ^755^
Active (positive) concurrent controls exposed to interventions other than meditation practices | Group therapy | 2 | 2 | Mantra meditation (1 group, 1 study) TM® (1) ^439^
| | | | Yoga (1 group, 1 study) ^527^
| Reading | 2 | 2 | Mindfulness meditation (1 group, 1 study) Zen Buddhist meditation (1) ^550^
| | | | Yoga (1 group, 1 study) ^948^
| Biofeedback | 1 | 1 | Mantra meditation (1 group, 1 study) RR (1) ^492^
| Cognitive behavioral techniques | 1 | 1 | Mantra meditation (1 group, 1 study) TM® (1) ^583^
Active (positive) concurrent controls exposed to meditation practices | Mantra meditation | 2 | 2 | Mindfulness meditation (2 groups, 2 studies)
| | | | Zen Buddhist meditation (1); ^456^ MM (NS) (1) ^614^
| Mindfulness meditation | 2 | 2 | Mantra meditation (2 groups, 2 studies)
| | | | TM® (1); ^453^ Mantra (NS) (1) ^937^
| Meditation practices (ND) | 2 | 2 | Yoga (1 group, 1 study) ^141^
| | | | Meditation practices (ND) (1 group, 1 study) ^481^
| Tai Chi | 1 | 1 | Qi Gong (1 group, 1 study) ^907^
| Yoga | 4 | 4 | Mantra meditation (2 groups, 2 studies) TM® (2) ^509a817^
| | | | Mindfulness meditation (1 group, 1 study) Zen Buddhist meditation (1) ^456^
| | | | Qi Gong (1 group, 1 study) ^202^
Concurrent control groups exposed to different dose or regimen of the same Meditation practice | Mantra meditation | 21 | 20 | Mantra meditation (21 groups, 20 studies)
| | | | TM® (17); ^436,509b522,^,^546,^,^548,571b412,^,^582,^,^586,^,^607,^,^655,^,^675,^,^722,^,^732,^,^740,^,^748,994^ Ananda marga (2); ^498,786^ Mantra (NS) (1) ^591^
| Mindfulness meditation | 8 | 6 | Mindfulness meditation (8 groups, 6 studies)
| | | | Zen Buddhist meditation (4); ^729,^,^742,^,^917,924^ Vipassana (1); ^708^ MM (NS) (1) ^511^
| Qi Gong | 11 | 6 | Qi Gong (11 groups, 6 studies) ^161,^,^873,^,^884,^,^888,^,^890,892^
| Yoga | 3 | 3 | Yoga (3 groups, 3 studies) ^788,^,^820,869^
| Tai Chi | 1 | 1 | Tai Chi (1 group, 1 study) ^911^
Historical controls | | 14 | 14 | Mantra meditation (11 groups, 11 studies)
| | | | TM® (10); ^400,^,^450,^,^452,^,^600,^,^601,^,^624,^,^771,970a624b688^ Ananda marga (1) ^720^
| | | | Qi Gong (3 groups, 3 studies) ^200^–^202^
Number of controls per study | Single control | 207 | 207 | Mantra meditation (136 groups, 136 studies)
| | | | TM® (126); ^951a951b80,^,^385,^,^438,^,^446,449^–^452,^,^458,^,^466,^,^469,^,^487,^,^499,^,^501,^,^513,^,^520,^,^529,^,^534,^,^535,^,^540,^,^547,^,^771,^,^772,^,^795,^,^923,^,^952,^,^964,^,^978,^,^980,1008a547b548,^,^551,552a552b555,^,^560,^,^563,^,^568,^,^570,571a399^–^401,^,^576,581^–^583,^,^585,598^–^601,^,^612,^,^619,^,^624,^,^776,^,^927,^,^928,^,^970,^,^975,976a624b416,^,^422,^,^428,^,^633,^,^638,^,^640,^,^643,^,^644,646^–^649,^,^661,^,^663,668^–^672,^,^685,^,^686,^,^688,693^–^695,^,^700,^,^701,^,^703,^,^704,^,^712,^,^717,^,^718,^,^721,^,^723,^,^779,^,^781,^,^790,^,^835,^,^950,^,^972,^,^983,^,^993,997a950b731,^,^734,^,^936,973b973a737,743^–^745,^,^757,^,^760,^,^763,^,^792,^,^941,^,^1000,^,^1003,1004^
| | | | ACEM meditation (4); ^720,^,^957,^,^958,960^ Mantra (NS) (4); ^828,^,^853,^,^859,969^ Ananda marga (1); ^526^ RR (1) ^492^
| | | | Yoga (26 groups, 26 studies) ^142,^,^146,^,^465,^,^473,^,^496,^,^506,^,^574,^,^667,^,^785,^,^788,^,^798,^,^803,^,^807,^,^833,^,^849,^,^855,^,^857,^,^861,^,^865,^,^948,^,^949,^,^968,^,^985,^,^989,^,^1009,1010^
| | | | Mindfulness meditation (17 groups, 17 studies)
| | | | Zen Buddhist meditation (8); ^105,^,^443,^,^495,^,^550,^,^636,^,^886,^,^918,995^ MM (NS) (6); ^479,^,^486,^,^497,^,^605,^,^614,641^ Vipassana (3) ^664,^,^921,990^
| | | | Tai Chi (16 groups, 16 studies) ^388,^,^699,^,^735,^,^874,^,^876,^,^877,^,^880,^,^881,^,^896,^,^898,^,^899,^,^901,^,^902,^,^905,^,^908,909^
| | | | Qi Gong (8 groups, 8 studies) ^200,^,^201,^,^632,^,^778,^,^873,^,^887,^,^893,912^
| | | | Miscellaneous meditation practices (3 groups, 3 studies) ^454,^,^628,967^
| | | | Meditation practices (ND) (1 group, 1 study) ^630^
| Multiple controls | 137 | 59 | Mantra meditation (65 groups, 29 studies)
| | | | TM® (25); ^436,^,^439,^,^441,^,^453,^,^508,509a509b522,^,^546,571b412,^,^586,^,^607,^,^655,^,^660,^,^675,^,^722,^,^732,^,^740,^,^741,^,^748,^,^749,^,^817,^,^939,994^ Ananda marga (2); ^498,786^ Mantra (NS) (2) ^591,937^
| | | | Mindfulness meditation (16 groups, 7 studies)
| | | | Zen Buddhist meditation (5); ^456,^,^729,^,^742,^,^917,924^ MM (NS) (1); ^511^ Vipassana (1) ^708^
| | | | Yoga (14 groups, 7 studies) ^141,^,^390,^,^527,^,^755,^,^820,^,^842,869^
| | | | Qi Gong (20 groups, 7 studies) ^161,^,^202,^,^884,^,^888,^,^890,^,^892,907^
| | | | Tai Chi (12 groups, 6 studies) ^432,^,^470,^,^565,^,^879,^,^903,911^
| | | | Miscellaneous meditation practices (7 groups, 2 studies): ^933,935^
| | | | Meditation practices (ND) (3 groups, 1 study) ^481^

MM = mindfulness meditation; ND = not described; NS = not specified; RR = Relaxation Response; TM® = Transcendental Meditation®

Table G9 Meditation practices separated by the diseases, conditions, and populations for which they have been examined

Category of meditation practices | Meditation practice | N | Study populations/conditions and associated references
Mantra meditation (337) | TM® ® | 231 | Intervention studies (80)
| | | Healthy populations (57) College/university students (24); ^186,^,^187,^,^189,^,^293,^,^424,^,^429,^,^433,^,^463,^,^518,^,^519,^,^538,^,^545,^,^659,^,^662,^,^705,^,^750,^,^758,^,^769,^,^782,^,^793,^,^796,^,^945,^,^986,1005^ Healthy volunteers from the community (19); ^171,^,^190,^,^291,^,^324,^,^392,^,^407,^,^418,^,^471,^,^505,^,^528,^,^533,^,^561,^,^677,^,^709,^,^733,^,^815,^,^942,^,^996,1002^; Prison inmates (4); ^188,^,^289,^,^557,974^ Workers (4); ^86,^,^292,^,^440,714^ Elderly (3); ^78,^,^279,282^ Smokers (2); ^674,787^ Athletes (1) ^309^
| | | Mental health disorders (9) Substance abuse (5); ^259,^,^261,^,^267,^,^270,271^ Anxiety disorders (2);^683,814^ Miscellaneous psychiatric conditions (1); ^850^ Posttraumatic stress disorder (1) ^478^
| | | Circulatory/cardiovascular (10) Coronary artery disease (1);^252^ Hypertension (9) ^205,^,^206,^,^210,220^–^222,^,^295,^,^311,319^
| | | Respiratory/Pulmonary (2) Asthma (2) ^587,759^
| | | Sleep disorders (1) Chronic insomnia (1) ^780^
| | | Oncology (1) Cancer (miscellaneous) (1) ^816^
| | | Observational analytical (151)
| | | Healthy populations (148) Healthy volunteers from the community (91); ^951a951b385,^,^446,449^–^452,^,^499,^,^508,^,^509,^,^771,^,^795,^,^952,^,^978,^,^980,1008a509b80,^,^513,^,^522,^,^529,^,^546,^,^551,^,^555,^,^560,^,^563,^,^571,^,^923,964a571b399,^,^400,^,^576,^,^581,^,^583,^,^585,^,^586,598^–^601,^,^607,^,^612,^,^624,^,^776,^,^928,^,^970,^,^975,976a624b412,^,^416,^,^422,^,^428,^,^633,^,^638,^,^640,^,^643,^,^644,^,^646,^,^647,^,^649,^,^655,^,^669,^,^675,^,^686,^,^695,^,^700,^,^703,^,^704,^,^717,^,^722,^,^723,^,^731,^,^779,^,^972,^,^973,^,^983,^,^993,^,^994,997b973a745,^,^748,^,^749,^,^760,^,^792,^,^939,^,^941,1004^ College/university students (48); ^436,^,^458,^,^466,^,^487,^,^501,^,^520,^,^534,^,^535,^,^540,^,^547,772a547b401,^,^548,^,^568,^,^570,^,^582,^,^648,^,^660,^,^661,^,^663,^,^668,^,^671,^,^672,^,^685,^,^688,^,^693,^,^694,^,^712,^,^718,^,^721,^,^781,^,^790,^,^817,^,^835,^,^927,950a950b732,^,^734,^,^737,^,^741,^,^744,^,^757,^,^763,^,^936,^,^1000,1003^ Elderly (5);^453,552a552b701,740^ Prison inmates (3); ^438,^,^439,441^ Workers (1) ^670^
| | | Gynecology (2) Pregnancy (1); ^469^ Postmenopause (1) ^743^
| | | Dental (1) Periodontitis (1) ^619^
| RR | 51 | Intervention studies (50)
| | | Healthy populations (31) College/university students (19); ^306,^,^394,475^–^477b306a75,^,^191,^,^515,^,^524,^,^530,^,^558,^,^567,^,^569,^,^572,^,^616,^,^625,^,^938,988^ Healthy volunteers from the community (8); ^94,^,^283,^,^284,^,^288,^,^304,^,^480,^,^525,594^ Prison inmates (1); ^92^ Workers (3) ^504,^,^637,673^
| | | Circulatory/cardiovascular (9) Other cardiovascular diseases (5); ^91,^,^234,^,^236,^,^459,753^ Hypertension (4) ^208,^,^209,^,^218,228^
| | | Mental health disorders (4) Substance abuse (2); ^265,268^ Anxiety disorders (1); ^460^ Schizophrenia or antisocial personality disorders (1) ^678^
| | | Gynecology (2) Menopause (1) ^592^; Premenstrual syndrome (1) ^396^
| | | Gastrointestinal (1) Irritable bowel syndrome (1) ^610^
| | | Miscellaneous medical conditions (1) Heterogeneous patient population (1) ^414^
| | | Musculoskeletal (1) Total knee replacement (1) ^192^
| | | Oncology (1) Skin cancer (1) ^521^
| | | Observational analytical (1)
| | | Circulatory/cardiovascular: Hypertension (1) ^492^.
| Mantra meditation (ND) | 32 | Intervention studies (26)
| | | Healthy populations (19) College/university students (10); ^472,494a531,^,^597,^,^650,^,^653,^,^654,^,^706,^,^719,965^ Healthy volunteers from the community (6); ^393,^,^434,^,^503,^,^652,^,^777,856^ Workers (2); ^483,761^ Army/military (1) ^194^
| | | Mental health disorders (5) Anxiety disorders (3);^577,^,^626,736^ Substance abuse (1);^260^ Miscellaneous psychiatric conditions (1) ^963^
| | | Circulatory/cardiovascular (1) Hypertension (1) ^203^
| | | Neurological (1) Epilepsy (1) ^805^
| | | Observational analytical (6)
| | | Healthy populations (6) Healthy volunteers from the community (6) ^591,^,^828,^,^853,^,^859,^,^937,969^
| CSM | 11 | Intervention studies (11)
| | | Healthy populations (7) College/university students (3); ^537,^,^658,676^ Workers (3); ^193,^,^384,536^ Healthy volunteers from the community (1) ^627^
| | | Mental health disorders (3) Anxiety disorders (1); ^97^ Schizophrenia (1); ^410^ Substance abuse (1) ^264^
| | | Sleep disorders (1) Chronic insomnia (1) ^702^
| ACEM meditation | 7 | Intervention studies (3)
| | | Healthy populations (3) Athletes (3) ^956,^,^959,961^
| | | Observational analytical (4)
| | | Healthy populations (4) Healthy volunteers from the community (4) ^720,^,^957,^,^958,960^
| Ananda marga | 3 | Observational analytical (3)
| | | Healthy populations (3) Healthy volunteers from the community (3) ^498,^,^526,786^
| Cayce's meditation | 1 | Intervention studies (1)
| | | Healthy populations (1) Healthy volunteers from the community (1) ^680^
| Concentrative/rosary prayer | 1 | Intervention studies (1)
| | | Healthy populations (1) Healthy volunteers from the community (1) ^966^
Yoga | | 191 | Intervention studies (158)
| | | Healthy populations (80) Healthy volunteers from the community (34); ^83,^,^111,^,^122,^,^126,^,^133,^,^140,^,^180,^,^183,^,^301,^,^302,^,^310,^,^312,^,^318,^,^320,^,^322,^,^323,^,^406,^,^411,^,^491,^,^578,^,^707,^,^739,^,^799,^,^821,^,^822,^,^826,^,^858,^,^860,^,^863,^,^864,^,^867,^,^979,^,^981,992^ College/university students (26); ^127,^,^134,^,^172,177^–^179,^,^181,^,^182,^,^297,^,^300,^,^305,^,^314,^,^315,^,^389,^,^462,^,^468,^,^615,^,^800,^,^802,^,^823,^,^838,^,^840,^,^854,^,^862,^,^971,982^ Army/military (7); ^137,^,^313,^,^811,^,^836,^,^837,^,^839,844^ Elderly (5); ^280,^,^281,^,^445,^,^562,825^ Workers (5) ^169,^,^176,^,^549,^,^679,1007^ Prison inmates (2); ^175,812^ Athletes (1) ^834^
| | | Circulatory/cardiovascular (21) Hypertension (13); ^185,^,^204,^,^212,^,^216,^,^217,^,^219,^,^224,^,^226,^,^294,^,^303,^,^510,^,^831,851^ Cardiovascular diseases (8) ^233,238^–^240,^,^247,^,^250,^,^251,611^;
| | | Mental health disorders (16) Depression (7);^138,^,^184,^,^618,^,^764,^,^806,^,^819,830^ Anxiety disorders (3); ^810,^,^841,846^ Substance abuse (3); ^266,^,^269,273^ Obsessive-compulsive disorder (1);^174^ Miscellaneous psychiatric conditions (1); ^170^ Neurosis (1) ^809^
| | 192 | Respiratory/Pulmonary (13) Asthma (9); ^168,^,^325,^,^813,^,^818,^,^829,^,^843,^,^866,^,^943,991^ Chronic airways obstruction (1) ^998^ Chronic bronchitis (1); ^797^ Pleural effusion (1); ^832^ Pulmonary tuberculosis (1) ^868^
| | | Muscoloskeletal (11) Chronic pain (2); ^118,542^ Rheumathoid arthritis (2); ^804,925^ Carpal tunnel syndrome (1); ^544^ Chronic rheumatic diseases (1); ^845^ Fibromyalgia (1); ^584^ Hyperkyphosis (1); ^559^ Multiple sclerosis (1); ^666^ Osteoarthritis (1); ^543^ Post-polio syndrome (1) ^516^
| | | Endocrine (7) Type 2 DM (7) ^278,^,^298,^,^308,^,^321,^,^794,^,^824,926^
| | | Gastrointestinal (2) Irritable bowel syndrome (1); ^852^ Miscellaneous gastrointestinal disorders (1) ^827^
| | | Neurological (2) Epilepsy (1); ^417^ Migraine/tension headaches (1) ^404^
| | | Gynecology (1) Pregnancy (1) ^415^
| | | Immunologic (1) HIV (1) ^642^
| | | Miscellaneous medical conditions (1) Heterogeneous patient population (1) ^870^
| | | Oncology (1) Lymphoma (1) ^120^
| | | Sleep disorders (1) Chronic insomnia (1) ^613^
| | | Vestibular (1) Tinnitus (1) ^946^
| | | Observational analytical (33)
| | | Healthy populations (33) Healthy volunteers from the community (23); ^141,^,^146,^,^390,^,^465,^,^473,^,^506,^,^527,^,^574,^,^667,^,^798,^,^803,^,^820,^,^833,^,^842,^,^855,^,^861,^,^865,^,^948,^,^949,^,^968,^,^985,^,^989,1009^ College/university students (7); ^142,^,^755,^,^785,^,^788,^,^807,^,^857,869^ Workers (2); ^496,849^ Elderly (1) ^1010^
Mindfulness meditation (127) | MBSR | 49 | Intervention studies (49)
| | | Healthy populations (12) College/university students (6); ^457,^,^488,^,^517,^,^689,^,^711,754^ Healthy volunteers from the community (3); ^485,^,^602,756^ Workers (3) ^512,^,^593,710^
| | | Mental health disorders (12) Anxiety disorders (3); ^196,^,^589,606^ Mood disorders (2); ^681,752^ Substance abuse (2); ^263,272^ Binge eating disorder (1); ^620^ Burnout (1); ^493^ Miscellaneous psychiatric conditions (1); ^622^ Personality disorders (1); ^773^ Parents of children with behavioral problems (1) ^687^
| | | Miscellaneous medical conditions (6) Heterogeneous patient population (5); ^579,^,^684,^,^691,^,^692,947^ Chronic fatigue (1) ^934^
| | | Musculoskeletal (6) Chronic pain (4); ^420,^,^482,^,^556,682^ Fibromyalgia (2) ^421,609^
| | | Oncology (4) Breast cancer (3); ^423,^,^575,724^ Prostate cancer (1) ^697^
| | | Dermatology (2) Psoriasis (2) ^167,195^
| | | Circulatory/Cardiovascular (2) Cardiovascular diseases (2) ^244,245^
| | | Neurological (2) Traumatic brain injuries (2) ^770,930^
| | | Endocrine (1) Obesity (1) ^635^
| | | Immunologic (1) HIV (1) ^419^
| | | Organ transplantation (1) Kidney, lung, pancreas (1) ^402^
| MM (NS) | 37 | Intervention studies (30)
| | | Healthy populations (11) College/university students (7); ^106,^,^447,^,^490,^,^523,^,^696,^,^728,775^ Athletes (1); ^762^ Healthy volunteers from the community (1); ^532^ Smokers (1); ^444^ Workers (1) ^932^
| | | Mental health disorders (5) Binge eating disorders (2); ^403,474^ Anxiety disorders (1); ^751^ Psychosis (1); ^922^ Substance abuse (1) ^258^
| | | Musculoskeletal (5) Fibromyalgia (3); ^430,^,^448,716^ chronic pain (2) ^464,604^
| | | Circulatory/Cardiovascular (3) Cardiovascular diseases (3) ^241,^,^242,249^
| | | Oncology (3) Cancer (miscellaneous) (3) ^386,^,^442,738^
| | | Dermatology (1) Psoriasis (1) ^395^
| | | Gynecology (1) Infertility (1) ^1011^
| | | Miscellaneous medical conditions (1) Heterogeneous patient population (1) ^727^
| | | Observational analytical (7)
| | | Healthy populations (6) College/university students (4); ^497,^,^511,^,^614,641^ Healthy volunteers from the community (2) ^479,486^
| | | Musculoskeletal (1) Chronic pain (1) ^605^
| Zen Buddhist meditation | 28 | Intervention studies (15)
| | | Healthy populations (11) College/university students (10); ^70,^,^426,^,^500,^,^554,^,^629,^,^639,^,^774,^,^913,^,^916,920^ Healthy volunteers from the community (1) ^197^
| | | Circulatory/Cardiovascular: Cardiovascular diseases (1); ^237^ Hypertension (2) ^225,227^
| | | Sleep disorders (1) Insomnia (1) ^765^
| | | Observational analytical (13)
| | | Healthy populations (13) Healthy volunteers from the community (12); ^105,^,^443,^,^456,^,^495,^,^550,^,^636,^,^729,^,^742,^,^886,^,^917,^,^924,995^ College/university students (1) ^918^
| MBCT | 7 | Intervention studies (7)
| | | Mental health disorders (3) Depression (3) ^427,^,^929,940^
| | | Healthy populations (1) Workers (1) ^984^
| | | Musculoskeletal (1) Fibromyalgia ^553^
| | | Neurological (1) Stroke (1) ^784^
| | | Vestibular (1) Tinnitus (1) ^455^
| Vipassana meditation | 6 | Intervention studies (2)
| | | Healthy populations: Healthy volunteers from the community (1) ^848^
| | | Neurological (1) Migraine/Tension headaches (1) ^847^
| | | Observational analytical (4)
| | | Healthy populations (4) Healthy volunteers from the community (2); ^708,990^ College/university students (1); ^921^ Elderly (1) ^664^
Tai Chi | | 88 | Intervention studies (66)
| | | Healthy populations (38) Elderly (25); ^285,^,^287,^,^290,^,^326,^,^397,^,^398,^,^408,^,^409,^,^425,^,^435,^,^489,^,^566,^,^588,^,^603,^,^631,^,^645,^,^657,^,^665,^,^690,^,^698,^,^872,^,^878,^,^882,^,^885,931^ Healthy volunteers from the community (8); ^152,^,^286,^,^296,^,^307,^,^595,^,^596,^,^766,906^ College/university students (4); ^317,^,^715,^,^747,789^ Workers (1) ^955^
| | | Musculoskeletal (13) Rheumatoid arthritis (4); ^617,^,^746,^,^883,962^ Osteoarthritis (3); ^573,^,^894,904^ Chronic pain (2); ^437,467^ Balance disorders (1); ^564^ Fibromyalgia (1); ^725^ Multiple sclerosis (1); ^590^ Osteoporosis (1) ^713^
| | | Circulatory/Cardiovascular (4) Cardiovascular diseases (3); ^235,^,^246,248^ Hypertension (1) ^223^
| | | Gynecology (2) Menopause (1); ^1001^ Postmenopause (1) ^895^
| | | Mental health disorders (2) Depression (1); ^871^ Miscellaneous psychiatric conditions (1) ^768^
| | | Neurological (2) Developmental disabilities (1); ^608^ Stroke (1) ^1006^
| | | Endocrine (1) Type 2 DM (1) ^999^
| | | Immunologic (1) HIV (1) ^541^
| | | Oncology (1) Breast cancer (1) ^391^
| | | Renal (1): End-stage renal disease (1) ^897^
| | | Vestibular (1) Vestibulopathy (1) ^413^
| | | Observational analytical (22)
| | | Healthy populations (20) Elderly (18); ^388,^,^432,^,^565,^,^735,^,^874,^,^876,879^–^881,^,^896,^,^898,901^–^903,^,^905,^,^908,^,^909,911^ Healthy volunteers from the community (2) ^470,699^
| | | Gynecology (2) Postmenopause (2) ^877,899^
Qi Gong | | 37 | Intervention studies (22)
| | | Healthy populations (7) Healthy volunteers from the community (4);^299,^,^405,^,^634,891^ College/university students (2); ^316,977^ Elderly (1) ^889^
| | | Circulatory/cardiovascular (5) Hypertension (4); ^207,^,^211,^,^213,214^ Cardiovascular diseases (1); ^243^
| | | Musculoskeletal (4) Fibromyalgia (2); ^502,953^ Muscular dystrophy (1); ^954^ Regional pain syndrome (1) ^767^
| | | Endocrine (2) Type 2 DM (2) ^914,919^
| | | Mental health disorders (1) Substance abuse (1) ^262^
| | | Miscellaneous medical conditions (1) Heterogeneous patient population (1) ^900^
| | | Neurological (1) Migraine/Tension headaches (1) ^944^
| | | Respiratory/Pulmonary (1) COPD (1) ^875^
| | | Observational analytical (15)
| | | Healthy populations (14) Healthy volunteers from the community (11); ^161,^,^200,^,^201,^,^632,^,^778,^,^884,^,^887,^,^888,^,^890,^,^892,893^ College/university students (2); ^202,912^ Elderly (1) ^907^
| | | Circulatory/Cardiovascular (1) Hypertension (1) ^873^
Meditation practices (ND) | | 21 | Intervention studies (19)
| | | Healthy populations (12) College/university students (9); ^387,494b199,^,^431,^,^539,^,^580,^,^656,^,^730,915^ Workers (2); ^514,910^ Healthy volunteers from the community (1) ^651^
| | | Mental health disorders (4) Substance abuse; (2) ^274,808^ Anger management problems (1); ^987^ Mood disorders (1) ^783^
| | | Circulatory/cardiovascular (1) Hypertension (1) ^215^
| | | Dental problems (1) Dental problems (1) ^198^
| | | Sleep disorders (1) Insomnia (1) ^484^
| | | Observational analytical (2)
| | | Healthy populations (1) College/university students (1) ^481^
| | | Mental health disorders (1) Miscellaneous psychiatric conditions (1) ^630^
Miscellaneous meditation practices | | 11 | Intervention studies (6)
| | | Healthy populations (3) College/university students (2); ^507,791^ Healthy volunteers from the community (1) ^623^
| | | Mental health disorders (1) Miscellaneous psychiatric conditions (1) ^621^
| | | Miscellaneous medical conditions (1) Heterogeneous patient population (1) ^801^
| | | Oncology (1) Breast cancer (1) ^726^
| | | Observational analytical (5)
| | | Healthy populations (5) Healthy volunteers from the community (4); ^454,^,^628,^,^933,967^ College/university students (1) ^935^

COPD = chronic obstructive pulmonary disease; CSM = clinically standardized meditation; DM = diabetes mellitus; HIV = human immunodeficiency virus; MBCT = mindfulness-based cognitive therapy; MBSR = mindfulness-based stress reduction; MM = mindfulness meditation; ND = not described; NS = not specified; RR = Relaxation Response; TM® = Transcendental Meditation®