# Appendix F. References of Multiple Publications (Topics II to V)

From 911 included articles, 108 were identified as multiple publications, that is, cases in which the same study was published more than once, available in another format, or part of data from an original report was republished. The multiple publications were not considered to be unique studies and any information that they provided was included with the data reported in the main study. The report that was published first was regarded as the main study.

## References

1 Ades PA, Savage PD, Cress ME, et al. Resistance training on physical performance in disabled older female cardiac patients. Med Sci Sports. 2003;35(8):1265-70. Associated publication of 233.
2 Alexander CN, Langer EJ, Newman RI, et al. Transcendental Meditation, mindfulness, and longevity: an experimental study with the elderly. J Pers Soc Psychol. 1989;57(6):950-64. Associated publication of 279. [pmid: 2693686].
3 Alexander CN, Schneider RH, Staggers F, et al. Trial of stress reduction for hypertension in older African Americans II: sex and risk subgroup analysis. Hypertension. 1996;28(2):228-37. Associated publication of 221. [pmid: 8707387].
4 Anderson VL. The effects of meditation on teacher perceived occupational stress and trait anxiety [dissertation]. Indiana, PA: Indiana University of Pennsylvania; 1996. Associated publication of 384
5 Barnes VA, Treiber FA, Turner JR, et al. Acute effects of Transcendental Meditation on hemodynamic functioning in middle aged adults [abstract]. In: 57th Annual Scientific Conference of the American Psychosomatic Society; Vancouver, BC; 1999. No. 1209. Associated publication of 385
6 Blumenthal JA, Emery CF, Madden DJ, et al. Effects of exercise training on cardiorespiratory function in men and women older than 60 years of age. Am J Cardiol. 1991;67(7):633-9. Associated publication of 280. [pmid: 2000798].
7 Blumenthal JA, Emery CF, Madden DJ, et al. Cardiovascular and behavioral effects of aerobic exercise training in healthy older men and women. J Gerontol. 1989;44(5):147-57. Associated publication of 280.
8 Blumenthal JA, Emery CF, Madden DJ, et al. Effects of exercise training on bone density in older men and women. J Am Geriatr Soc. 1991;39(11):1065-70. Associated publication of 280. [pmid: 1753043].
9 Bowman AJ. Effects of aerobic exercise training and yoga on cardiac and lymphocyte beta-adrenergic responses in sedentary elderly subjects. J Am Geriatr Soc. 1995;43(9):SA78. Associated publication of 281.
10 Carlson LE, Speca M, Patel KD, et al. Mindfulness-based stress reduction in relation to quality of life, mood, symptoms of stress and levels of cortisol, dehydroepiandrosterone sulfate (DHEAS) and melatonin in breast and prostate cancer outpatients. Psychoneuroendocrinology. 2004;29(4):448-74. Associated publication of 386. [pmid: 14749092].
11 Carlson LE, Speca M, Patel KD, et al. Mindfulness-based stress reduction in relation to quality of life, mood, symptoms of stress, and immune parameters in breast and prostate cancer outpatients. Psychosom Med. 2003;65(4):571-81. Associated publication of 386. [pmid: 12883107].
12 Carlson LE, Ursuliak Z, Goodey E, et al. The effects of a mindfulness meditation-based stress reduction program on mood and symptoms of stress in cancer outpatients: 6-month follow-up. Support Care Cancer. 2001;9(2):112-23. Associated publication of 386. [pmid: 11305069].
13 Chang JC, Chiung W. Effect of meditation on music performance anxiety [dissertation]. New York: Columbia University; 2001. Associated publication of 387
14 Chen KM, Snyder M, Krichbaum K. Tai chi and well-being of Taiwanese commmunity-dwelling elders. Clin Gerontol. 2001;24(34):137-56. Associated publication of 388.
15 Cohen L, Thornton B, Chanmdwani K. A randomized trial of a Tibetan yoga intervention for breast cancer patients [abstract]. In: 63rd Annual Scientific Conference of the American Psychosomatic Society; Vancouver, BC; 2005. No. 1607. Associated publication of 120
16 Cooper MJ, Aygen MM. A relaxation technique in the management of hypercholesterolemia. J Hum Stress. 1979;5(4):24-7. Associated publication of 291.
17 Cusumano JA. The short-term psychophysiological effects of hatha yoga and progressive relaxation on female Japanese students [dissertation]. Tempe, AZ: Arizona State University; 1991. Associated publication of 389
18 Daubenmier JJ. The relationship of yoga, body awareness, and body responsiveness to self objectification and disordered eating. Psychol Women Q. 2005;29(2):207-19. Associated publication of 390.
19 Davis PG, Mustian KM, Katula JA, et al. Tai chi chuan and insulin-like growth factor-I (Igf-I) in breast cancer survivors. Med Sci Sports Exerc. 2004;36(5 Suppl):S97-8. Associated publication of 391.
20 Delmonte MM. Effects of expectancy on physiological responsivity in novice meditators. Biol Psychol. 1985;21(2):107-21. Associated publication of 392. [pmid: 3907725].
21 Delmonte MM. Expectancy and response to meditation. Int J Psychosom. 1986;33(2):28-34. Associated publication of 393. [pmid: 3528015].
22 Delmonte MM. Expectation and meditation. Psychol Rep. 1981;49(3):699-709. Associated publication of 393.
23 Delmonte MM. Response to meditation in terms of physiological, behavioral and self-report measures. Int J Psychosom. 1984;31(2):3-17. Associated publication of 392.
24 Emery CF, Blumenthal JA. Perceived change among participants in an exercise program for older adults. Gerontologist. 1990;30(4):516-21. Associated publication of 280. [pmid: 2394387].
25 Friedman E, Berger BG. Influence of gender, masculinity, and femininity on the effectiveness of three stress reduction techniques: jogging, relaxation response, and group interaction. J Appl Sport Psychol. 1991;3(1):61-86. Associated publication of 394.
26 Gaston L, Crombez JC, Joly J, et al. Efficacy of imagery and meditation techniques in treating psoriasis. Imagination Cogn Pers. 1988-1989;8(1):25-38. Associated publication of 395.
27 Gilbert GS, Parker JC, Claiborn CD. Differential mood changes in alcoholics as a function of anxiety management strategies. J Clin Psychol. 1978;34(1):229-32. Associated publication of 265. [pmid: 346607].
28 Goodale IL. The effects of the relaxation response on premenstrual syndrome [abstract]. Diss Abstr Int. 1990;50(8B):3731. Associated publication of 396.
29 Hass CJ, Gregor RJ, Waddell DE, et al. The influence of tai chi training on the center of pressure trajectory during gait initiation in older adults. Arch Phys Med Rehabil. 2004;85(10):1593-8. Associated publication of 397. [pmid: 15468016].
30 Irwin MR, Pike JL, Cole JC, et al. Effects of a behavioral intervention, tai chi chih, on varicella-zoster virus. Specific immunity and health functioning in older adults. Psychosom Med. 2003;65:824-30. Associated publication of 398. [pmid: 14508027].
31 Jevning RA, Wells I, Wilson AF. Plasma thyroid hormones, thyroid stimulating hormone, and insulin during acute hypometabolic states in man. Physiol Behav. 1987;40(5):603-6. Associated publication of 399. [pmid: 3313447].
32 Jevning RA, Wilson AF. Acute decline in adrenocortical activity during Transcendental Meditation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 811. Associated publication of 400
33 Jevning RA, Wilson AF, Davidson JM. Adrenocortical activity during meditation. Horm Behav. 1978;10(1):54-60. Associated publication of 400. [pmid: 350747].
34 Jevning RA, Wilson AF, Pirkle HC. Modulation of red cell metabolism by states of decreased activation: comparison between states. Physiol Behav. 1985;35(5):679-82. Associated publication of 399. [pmid: 3936073].
35 Jevning RA, Wilson AF, Smith WR. Redistribution of blood flow in Transcendental Meditation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 787. Associated publication of 401
36 Kabat-Zinn J, Wheeler E, Light T, et al. Influence of a mindfulness meditation-based stress reduction intervention on rates of skin clearing in patients with moderate to severe psoriasis undergoing phototherapy (UVB) and photochemotherapy (PUVA). Psychosom Med. 1998;60(5):625-32. Associated publication of 195. [pmid: 9773769].
37 Kondwani K, Schneider RH, Alexander CN, et al. Left ventricular mass regression with the Transcendental Meditation technique and a health education program in hypertensive African Americans. J Soc Behav Pers. 2005;17(1):181-200. Associated publication of 210.
38 Kreitzer MJ, Gross CR, Ye X. Longitudinal impact of mindfulness meditation on illness burden in solid-organ transplant recipients. Prog Transplant. 2005;15(2):166-72. Associated publication of 402. [pmid: 16013466].
39 Kristeller JL, Quillian-Wolever RE, Sheets V. Mindfulness meditation in treating binge eating disorder: a randomized clinical trial. Int J Eat Disord. 2004;35(4):453. Associated publication of 403.
40 Kutner NG, Barnhart HX, Wolf SL. Self-report benefits of tai chi practice by older adults. J Gerontol B Psychol Sci Soc Sci. 1997;52(5):242-6. Associated publication of 397.
41 Lan C, Lai JS, Chen SY. Tai chi chuan to improve muscular strength and endurance in elderly individuals: a pilot study. Arch Phys Med Rehabil. 2000;81(5):604-7. Associated publication of 326. [pmid: 10807099].
42 Latha DR, Kaliappan KV. The efficacy of yoga therapy in the treatment of migraine and tension headaches. J Indian Acad Appl Psychol. 1987;13(2):95-100. Associated publication of 404.
43 Lee MS, Kang CW, Lim HJ. Effects of qi-training on anxiety and plasma concentrations of cortisol, acth, and aldosterone: a randomized placebo-controlled pilot dtudy. Stress Health. 2004;20(5):243-8. Associated publication of 405.
44 Lee MS, Kang CW, Ryu H. Acute effect of qi-training on natural killer cell subsets and cytotoxic activity. Int J Neurosci. 2005;115(2):285-97. Associated publication of 405. [pmid: 15764007].
45 Lee MS, Kang CW, Ryu H. Endocrine and immune effects of qi-training. Int J Neurosci. 2004;114(4):529-37. Associated publication of 405. [pmid: 15195356].
46 Lee MS, Lee MS, Choi ES. Effects of qigong on blood pressure, blood pressure determinants and ventilatory function in middle-aged patients with essential hypertension. Am J Chin Med. 2003;31(3):489-97. Associated publication of 214. [pmid: 12943180].
47 Lee MS, Lim HJ, Lee MS. Impact of qigong exercise on self-efficacy and other cognitive perceptual variables in patients with essential hypertension. J Altern Complement Med. 2004;10(4):675-80. Associated publication of 213. [pmid: 15353025].
48 Lee SW, Charlson ME, Mancuso CA. Practice of energy-yoga is associated with improvements in health-related quality of life. J Gen Intern Med. 2003;18(1 Suppl):267-8. Associated publication of 406.
49 Levitsky DK. Effects of the “Transcendental Meditation” (TM®) program on neuroendocrine indicators of chronic stress [dissertation]. Fairfield, IA: Maharishi International University; 1998. Associated publication of 407
50 Li F, Fisher KJ, Harmer P. Delineating the impact of tai chi training on physical function among the elderly. Am J Prev Med. 2002;23(2 Suppl):92-7. Associated publication of 408. [pmid: 12133743].
51 Li F, Fisher KJ, Harmer P. Falls self-efficacy as a mediator of fear of falling in an exercise intervention for older adults. J Gerontol B Psychol Sci Soc Sci. 2005;60(1):34-40. Associated publication of 409. [pmid: 16251588].
52 Li F, Harmer P, Fisher KJ. Tai chi: improving functional balance and predicting subsequent falls in older persons. Med Sci Sports. 2004;36(12):2046-52. Associated publication of 409.
53 Li F, Harmer P, Mcauley E. An evaluation of the effects of tai chi exercise on physical function among older persons: a randomized contolled trial. Ann Behav Med. 2001;23(2):139-46. Associated publication of 408. [pmid: 11394556].
54 Li F, Harmer P, Mcauley E. Tai chi, self-efficacy, and physical function in the elderly. Prev Sci. 2001;2(4):229-39. Associated publication of 408. [pmid: 11833926].
55 Li F, Mcauley E, Harmer P. Tai chi enhances self-efficacy and exercise behavior in older adults. J Aging Phys Act. 2001;9(2):161-71. Associated publication of 408.
56 Lukoff DG. Comparison of a holistic and a social skills training program for schizophrenics [dissertation]. Chicago: Loyola University; 1980. Associated publication of 410
57 MacLean CR, Walton KG, Wenneberg SR. Altered responses of cortisol, GH, TSH and testosterone to acute stress after four months' practice of Transcendental Meditation (TM). Ann N Y Acad Sci. 1994;746:381-4. Associated publication of 407. [pmid: 7825892].
58 Madden DJ, Blumenthal JA, Allen PA. Improving aerobic capacity in healthy older adults does not necessarily lead to improved cognitive performance. Psychol Aging. 1989;4(3):307-20. Associated publication of 280. [pmid: 2803624].
59 Malathi A, Damodaran A, Shah N. Effect of yogic practices on subjective well being. Indian J Physiol Pharmacol. 2000;44(2):202-6. Associated publication of 411. [pmid: 10846636].
60 Malhotra V, Singh S, Singh KP. Study of yoga asanas in assessment of pulmonary function in NIDDM patients. Indian J Physiol Pharmacol. 2002;46(3):313-20. Associated publication of 321. [pmid: 12613394].
61 Mandle CL, Domar AD, Harrington DP. Relaxation response in femoral angiography. Radiology. 1990;174(3 Pt 1):737-9. Associated publication of 91. [pmid: 2406782].
62 Marcus MT, Fine PM, Moeller FG. Change in stress levels following mindfulness-based stress reduction in a therapeutic community. Addict Disord Their Treat. 2003;2(3):63-8. Associated publication of 272.
63 Mason LI, Alexander CN, Travis FT. Electrophysiological correlates of higher states of consciousness during sleep in long-term practitioners of the Transcendental Meditation program. Sleep. 1997;20(2):102-10. Associated publication of 412. [pmid: 9143069].
64 McComb JJR, Tacon AM, Randolph PD. A pilot study to examine the effects of a mindfulness-based stress-reduction and relaxation program on levels of stress hormones, physical functioning, and submaximal exercise responses. J Altern Complement Med. 2004;10(5):819-27. Associated publication of 244. [pmid: 15650471].
65 McGibbon CA, Krebs DE, Wolf SL. Tai chi and vestibular rehabilitation effects on gaze and whole-body stability. J Vestib Res. 2004;14(6):467-78. Associated publication of 413. [pmid: 15735329].
66 Mustian KM, Katula JA, Gill DL. Tai chi chuan, health-related quality of life and self-esteem: a randomized trial with breast cancer survivors. Support Care Cancer. 2004;12(12):871-6. Associated publication of 391. [pmid: 15599776].
67 Mustian KM, Katula JA, Roscoe JA. The influence of tai chi (Tc) and support therapy (St) on fatigue and quality of life (Qol) in women with breast cancer (Bc). Am J Clin Oncol. 2004;22(14 Suppl):764S. Associated publication of 391.
68 Nakao M, Fricchione GL, Myers P. Anxiety is a good indicator for somatic symptom reduction through behavioral medicine intervention in a mind/body medicine clinic. Psychother Psychosom. 2001;70(1):50-7. Associated publication of 414. [pmid: 11150939].
69 Narendran S, Nagarathna R, Gunasheela S. Efficacy of yoga in pregnant women with abnormal doppler study of umbilical and uterine arteries. J Indian Med Assoc. 2005;103(1):12-4. Associated publication of 415. [pmid: 16008324].
70 O'Halloran JP, Jevning RA, Wilson AF. Behaviorally induced secretion of arginine vasopressin. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Scientific research on Maharishi's Transcendental Meditation and TM-Sidhi programme: collected papers. Vol. 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1640–5. Associated publication of 416
71 Orme-Johnson DW, Kiehlbauch J, Moore RG. Personality and autonomic changes in prisoners practicing the Transcendental Meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 556–68. Associated publication of 188
72 Panjwani U, Gupta HL, Singh SH. Effect of sahaja yoga practice on stress management in patients of epilepsy. Indian J Physiol Pharmacol. 1995;39(2):111-6. Associated publication of 417. [pmid: 7649596].
73 Panjwani U, Selvamurthy W, Singh SH. Effect of sahaja yoga practice on seizure control and EEG changes in patients of epilepsy. Indian J Med Res. 1996;103:165-72. Associated publication of 417. [pmid: 9062044].
74 Parker JC, Gilbert GS, Thoreson RW. Reduction of autonomic arousal in alcoholics: a comparison of relaxation and meditation techniques. J Consult Clin Psychol. 1978;46(5):879-86. Associated publication of 265. [pmid: 359608].
75 Patel CH. Yoga and biofeedback in the management of ‘stress’ in hypertensive patients. Clin Sci Mol Med Suppl. 1975;2:171-4. Associated publication of 219.
76 Pelletier KR. Influence of Transcendental Meditation upon autokinetic perception. Percept Mot Skills. 1974;39(3):1031-4. Associated publication of 418.
77 Peters RK, Benson H, Peters JM. Daily relaxation response breaks in a working population: II effects on blood pressure. Am J Pub Health. 1977;67(10):954-9. Associated publication of 284. [pmid: 333958]. [pmcid: 1653726].
78 Rani NJ, Rao PVK. Self-ideal disparity and yoga training. Indian J Psychol. 1992;10(12):35-40. Associated publication of 172.
79 Reddy MK, Ath D, Bai AJL. The effects of the Transcendental Meditation program on athletic performance. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 346–58. Associated publication of 309
80 Robinson FP. Psycho-endocrine-immune response to mindfulness-based stress reduction in HIV-infected individuals [dissertation]. Chicago: Loyola University; 2002. Associated publication of 419
81 Sagula DA. Varying treatment duration in a mindfulness meditation stress reduction program for chronic pain patients [dissertation]. East Lansing, MI: Michigan State University; 2000. Associated publication of 420
82 Schneider RH, Castillo-Richmond A, Alexander CN. Behavioral treatment of hypertensive heart disease in African Americans: rationale and design of a randomized controlled trial. Behav Med. 2001;27(2):83-95. Associated publication of 221. [pmid: 11763829].
83 Sephton SE, Lynch G, Weissbecker I. Effects of a meditation program on symptoms of illness and neuroendocrine responses in women with fibromyalgia [abstract]. In: 59th Annual Scientific Conference of the American Psychosomatic Society; Monterey, CA; 2001. No. 1456. Associated publication of 421
84 Shafii M, Lavely R, Jaffe R. Meditation and marijuana. Am J Psychiatry. 1974;131(1):60-3. Associated publication of 422. [pmid: 4808432].
85 Shapiro SL, Bootzin RR, Figueredo AJ. The efficacy of mindfulness-based stress reduction in the treatment of sleep disturbance in women with breast cancer: an exploratory study. J Psychosom Res. 2003;54(1):85-91. Associated publication of 423. [pmid: 12505559].
86 Smith JC. Psychotherapeutic effects of Transcendental Meditation with controls for expectation of relief and daily sitting. J Consult Clin Psychol. 1976;44(4):630-7. Associated publication of 424. [pmid: 939847].
87 Taggart HM. Tai chi, balance, functional mobility, fear of falling, and health perception among older women [dissertation]. Birmingham, AL: University of Alabama; 2000. Associated publication of 425
88 Takahashi T, Murata T, Hamada T. Changes in EEG and autonomic nervous activity during meditation and their association with personality traits. Int J Psychophysiol. 2005;55(2):199-207. Associated publication of 426. [pmid: 15649551].
89 Teasdale JD, Moore RG, Hayhurst H. Metacognitive awareness and prevention of relapse in depression: empirical evidence. J Consult Clin Psychol. 2002;70(2):275-87. Associated publication of 427. [pmid: 11952186].
90 Tebecis AK. Eye movements during Transcendental Meditation. Folia Psychiatr Neurol Jpn. 1976;30(4):487-93. Associated publication of 428.
91 Throll DA. Transcendental Meditation and progressive relaxation: their psychological effects. J Clin Psychol. 1981;37(4):776-81. Associated publication of 429.
92 Tiefenthaler U, Grossman P. Buddhist psychology's potential contribution to psychosomatic medicine: evidence from a mindfulness program for fibromyalgia. Psychosom Med. 2002;64(1):141. Associated publication of 430.
93 Travis FT. The Transcendental Meditation technique and creativity: a longitudinal study of Cornell University undergraduates. J Creat Behav. 1979;13(3):169-80. Associated publication of 293.
94 Vahia NS, Doongali DR, Jeste DV, et al. Further experience with the therapy based upon concepts of Patanjali in the treatment of psychiatric disorders. Indian J Psychiatr. 1973;15:32-7. Associated publication of 170.
95 Wagstaff GF, Brunas-Wagstaff J, Cole J, et al. New directions in forensic hypnosis: facilitating memory with a focused meditation technique. Contemp Hypn. 2004;21(1):14-27. Associated publication of 431.
96 Wang JS, Lan C, Wong MK. Tai chi chuan training to enhance microcirculatory function in healthy elderly men. Arch Phys Med Rehabil. 2001;82(9):1176-80. Associated publication of 432. [pmid: 11552187].
97 Weissbecker I, Salmon PG, Studts JL, et al. Mindfulness-based stress reduction and sense of coherence among women with fibromyalgia. J Clin Psychol Med Settings. 2002;9(4):297-307. Associated publication of 421.
98 Wenneberg SR. The effects of Transcendental Meditation on ambulatory blood pressure, cardiovascular reactivity, anger/hostility, and platelet aggregation [dissertation]. Fairfield, IA: Maharishi International University; 1994. Associated publication of 433
99 Wenneberg SR, Schneider RH, Walton KG, et al. A controlled study of the effects of the Transcendental Meditation program on cardiovascular reactivity and ambulatory blood pressure. Int J Neurosci. 1997;89(12):15-28. Associated publication of 433. [pmid: 9134445].
100 Williams KA, Steinberg L, Petronis J. Therapeutic application of iyengar yoga for healing chronic low back pain. Int J of Yoga Ther. 2003;13:55-67. Associated publication of 118.
101 Wolf DB. Effects of the hare krsna maha mantra on stress, depression, and the three gunas (spirituality, yoga) [dissertation]. Tallahassee, FL: Florida State University; 1999. Associated publication of 434
102 Wolf SL, Barnhart HX, Ellison GL, et al. The effect of tai chi quan and computerized balance training on postural stability in older subjects Atlanta FICSIT group frailty and injuries: cooperative studies on intervention techniques. Phys Ther. 1997;77(4):371-81. discussion 382–4. Associated publication of 397. [pmid: 9105340].
103 Wolf SL, Barnhart HX, Kutner NG, et al. Reducing frailty and falls in older persons: an investigation of tai chi and computerized balance training Atlanta FICSIT group frailty and injuries: cooperative studies of intervention techniques. J Am Geriatr Soc. 1996;44(5):489-97. Associated publication of 397. [pmid: 8617895].
104 Wolf SL, Barnhart HX, Kutner NG, et al. Selected as the best paper in the 1990s: reducing frailty and falls in older persons: an investigation of tai chi and computerized balance training. J Am Geriatr Soc. 2003;51(12):1794-803. Associated publication of 397. [pmid: 14687360].
105 Wolf SL, Sattin RW, Kutner M, et al. Intense tai chi exercise training and fall occurrences in older, transitionally frail adults: a randomized, controlled trial. J Am Geriatr Soc. 2003;51(12):1693-701. Associated publication of 397. [pmid: 14687346].
106 Yan JH. Tai chi practice reduces movement force variability for seniors. J Gerontol A Biol Sci Med Sci. 1999;54(12):M629-34. Associated publication of 435. [pmid: 10647969].
107 Yeh GY, Eisenberg DM, Wood MJ, et al. Tai chi as an adjunctive intervention for patients with heart failure: a pilot study. J Gen Intern Med. 2003;18(1 Suppl):161. Associated publication of ^246^.
108 Zamarra JW, Besseghini I, Wittenberg S. The effects of the Transcendental Meditation program on the exercise performance of patients with angina pectoris. In: Orme-Johnson DW, Farrow JT, eds. Scientific research on the Transcendental Meditation program: collected papers. Vol. 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 270–8. Associated publication of ^252^