# Appendix E. Excluded Studies and Nonobtained Studies

For the questions on the state of research on the therapeutic use of meditation in healthcare (topic II), 1,374 studies were excluded. The reasons for exclusion are as follows: (1) the study was not primary research on meditation (n= 909), (2) the study did not have a control group (n= 280), (3) the study did not report adequately on any measurable data for health related outcomes relevant to the review (n= 170), (4) the study did not examine an adult population (n= 9), and (5) the study sample included less than 10 participants (n= 6).

## Excluded: Not Primary Research on Meditation (N = 909)

The following studies were excluded because they were not relevant to the review topic.

### References

1 Abbey SE. Mindfulness based stress reduction for oncology patients. Psychooncology. 1999;8(6 Suppl):53.
2 Abbot NC. Yoga-based intervention for carpal tunnel syndrome. Focus Altern Complement Ther. 1999;4(2):81-2.
3 Abdullah S. Use of biofeedback in meditation technique: innovative combination in psychotherapy. J Contemp Psychother. 1973;5(2):101-6.
4 Abdullah S, Schucman H. Cerebral lateralization, bimodal consciousness, and related developments in psychiatry. Res Commun Psychol Psychiatr Behav. 1976;1(56):671-9.
5 Achterberg J, Kenner C, Lawlis GF. Severe burn injury: a comparison of relaxation, imagery and biofeedback for pain management. J Ment Imagery. 1988;12(1):71-87.
6 Adair L, Jean F. Structural integration and change in body experience [abstract]. Diss Abstr Int. 1981;41(7B):2741.
7 Ader R. Much ado about nothing. Adv Mind Body Med. 2001;17(4):293-5. [pmid: 11931053].
8 Ades PA, Wu G. Benefits of tai chi in chronic heart failure: body or mind?. Am J Med. 2004;117(8):611-2. [pmid: 15465511].
9 Adler SS. Seeking stillness in motion: an introduction to tai chi for seniors. Activ Adapt Aging. 1983;3(4):1-14.
10 Aerthayil J. Jesus prayer and stillness of heart. J Dharma. 2003;28(4):529-42.
11 Ai AL. Assessing mental health in clinical study on qigong: between scientific investigation and holistic perspectives. Semin Integrative Med. 2003;1(2):112-21.
12 Ai AL, Bolling SF, Peterson C. The use of prayer by coronary artery bypass patients. Int J Psychol Relig. 2000;10(4):205-20.
13 Ai AL, Dunkle RE, Peterson C, et al. The role of private prayer in psychological recovery among midlife and aged patients following cardiac surgery. Gerontologist. 1998;38(5):591-601. [pmid: 9803647].
14 Ai AL, Dunkle RE, Peterson C, et al. Spiritual well-being, private prayer, and adjustment of older cardiac patients. In: Thorson JA, ed. Perspectives on spiritual well-being and aging. Springfield (IL): Thomas; 2000. p. 98–119.
15 Ai AL, Peterson C, Bolling SF. Psychological recovery from coronary artery bypass graft surgery: the use of complementary therapies. J Altern Complement Med. 1997;3(4):343-53. [pmid: 9449056].
16 Ai AL, Peterson C, Gillespie B, et al. Designing clinical trials on energy healing: ancient art encounters medical science. Altern Ther Health Med. 2001;7(4):83-90. [pmid: 11452571].
17 Alexander CN, Alexander VK, Boyer RW, et al. The subjective experience of higher states of consciousness and the Maharashi technology of the unified field: personality, cognitive, perceptual, and physiological correlates of growth to enlightenment. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2423–42.
18 Alexander CN, Heaton DP, Chandler HM. Advanced human development in the vedic psychology of Maharishi mahesh yogi: theory and research. In: Miller M, Cook-Greuter S, eds. Transcendence and mature thought in adulthood. Lanham (MD): Rowman and Littlefield; 1994. p. 39–70.
19 Alexander CN, Rainforth MV, Gelderloos P. Transcendental meditation, self-actualization, and psychological health: a conceptual overview and statistical meta-analysis. J Soc Behav Pers. 1991;6(5):189-248.
20 Alexander CN, Robinson P, Orme-Johnson DW, et al. The effects of transcendental meditation compared to other methods of relaxation and meditation in reducing risk factors, morbidity, and mortality. Homeost Health Dis 1994;35(4–5):243–63. Erratum in: Homeost Health Dis 1995;36(4):240.
21 Alexander CN, Robinson P, Rainforth M. Treating and preventing alcohol, nicotine, and drug abuse through transcendental meditation: a review and statistical meta-analysis. Alcohol Treat Q 1994;11(1–2):13–87. Erratum in: Alcohol Treat Q 1995;13(4):97.
22 Alpher VS, Blanton RL. Motivational processes and behavioral inhibition in breath holding. J Psychol. 1991;125(1):71-81. [pmid: 2033561].
23 Amarosa TB, Tapp JT, Carida RV. Stress management through relaxation and imagery in the treatment of angina pectoris. J Cardiopulm Rehabil. 1989;9(9):348-55.
24 Amodei N, Nelson RO, Jarrett RB, et al. Psychological treatments of dysmenorrhea: differential effectiveness for spasmodics and congestives. J Behav Ther Exp Psychiatry. 1987;18(2):95-103. [pmid: 3301905].
25 Anderson EZ. Energy therapies for physical and occupational therapists working with older adults. Phys Occup Ther Geriatr. 2001;18(4):35-49.
26 Andersson G, Melin L, Hagnebo C, et al. A review of psychological treatment approaches for patients suffering from tinnitus. Ann Behav Med. 1995;17(4):357-66.
27 Andresen J. Meditation meets behavioural medicine: the story of experimental research on meditation. J Consciousness Stud. 2000;7(1112):17-73.
28 Ang DC, Ibrahim SA, Burant CJ, et al. Ethnic differences in the perception of prayer and consideration of joint arthroplasty. Med Care. 2002;40(6):471-6. [pmid: 12021673].
29 Anklesaria FK, King MS. A community based sentencing program for probationers: the enlightened sentencing project: a judicial innovation. J Offender Rehabil. 2003;36(14):35-46.
30 Anklesaria FK, King MS. Section IV: Transcendental meditation in prisons and prison systems the transcendental meditation program in the Senegalese penitentiary system. J Offender Rehabil. 2003;36(14):303-18.
31 Antoni MH. Session 3: automatic thoughts and cognitive distortions. In: Antoni MH, ed. Stress management intervention for women with breast cancer: participant's workbook. Washington DC: American Psychological Association; 2003. p. 21–31.
32 Antoni MH. Stress management and psychoneuroimmunology in HIV infection. CNS Spectr. 2003;8(1):40-51.
33 Aron A, Aron EN. The transcendental meditation program's effect on addictive behavior. Addict Behav. 1980;5(1):3-12. [pmid: 6994433].
34 Aron EN, Aron A. The transcendental meditation program for the reduction of stress related conditions. J Chronic Dis Ther Res. 1979;3(9):11-21.
35 Arpita HJ. Physiological and psychological effects of hatha-yoga: a review of the literature. Int J Yoga Ther. 1990;1:1-28.
36 Arora SS. Personal experience of an ex-patient of asthma. In: Sharma SK, Rai L, eds. Yoga therapy in bronchial asthma: proceedings of the first national conference on yoga therapy for asthma and other respiratory diseases; 1993 March 17–19; New Delhi, India. Central Research Institute for Yoga; 1993. p. 152–3.
37 Ashby JS, Lenhart RS. Prayer as a coping strategy for chronic pain patients. Rehabil Psychol. 1994;39(3):205-9.
38 Ashok KM. Yoga and healing: scientific connection. Science and Religion: Global Perspectives. Philadelphia: Metanexus Institute; 2005.
39 Astin JA. Mind-body therapies for the management of pain. Clin J Pain. 2004;20(1):27-32. [pmid: 14668653].
40 Astin JA, Beyerstein BL, Frenkel M, et al. Complementary and alternative medicine and the need for evidence-based criticism. Acad Med. 2002;77(9):864-75. [pmid: 12228075].
41 Astin JA, Forys KL. Psychosocial determinants of health and illness: integrating mind, body, and spirit. Adv Mind Body Med. 2004;20(4):14-21. [pmid: 15689022].
42 Astin JA, Shapiro SL, Eisenberg DM, et al. Mind-body medicine: state of the science, implications for practice. J Am Board Fam Med. 2003;16(2):131-47.
43 Astin JA, Shapiro SL, Schwartz GE. Meditation: Applications in medicine and health care. In: Novey D, ed. A clinician's rapid access guide to complementary and alternative medicine. St. Louis (MO): Mosby; 2000.
44 Atkinson RP, Earl H. Enhanced vigilance in guided meditation: implications of altered consciousness. Cambridge (MA): MIT Press; 1998.
45 Aung SKH. A brief introduction to the theory and practice of qigong. Am J Acupunct. 1994;22(4):335-48.
46 Austin TK. Stress management. J Orthomolecular Psychiatry. 1982;11(3):193-7.
47 Bachman JE. The effects of relaxation plus imaginal flooding versus relaxation only on panic attacks in veterans with posttraumatic stress disorder [abstract]. Diss Abstr Int. 1992;52(11B):6074-5.
48 Baer RA. Mindfulness training as a clinical intervention: a conceptual and empirical review. Clin Psychol: Sci Pract. 2003;10(2):125-43.
49 Bahrke MS. Exercise, meditation and anxiety reduction: a review. Am Correct Ther J. 1979;33(2):41-4. [pmid: 375705].
50 Baker DH. Lectio divina: toward a psychology of contemplation [dissertation]. Carpinteria, CA: Pacifica Graduate Institute; 2002.
51 Ballou SF. An existential-phenomenological historical inquiry into the awareness of silence as a transpersonal paradigm [dissertation]. Cincinnati: Union Institute and University; 1996.
52 Balodhi JP. Perspective of Rajayoga in its application to mental health. NIMHANS Journal. 1986;4(2):133-8.
53 Balodhi JP, Mishra H. Patanjala yoga and behavior therapy. Behav Therapist. 1983;6(10):196-7.
54 Bankart CP. A Western psychologist's inquiry into the nature of right effort. Constructivism Hum Sci. 2003;8(2):63-72.
55 Bankart CP, Koshikawa F, Nedate K, et al. When West meets East: contributions of Eastern traditions to the future of psychotherapy. Psychother: Theory Res Pract Training. 1992;29(1):141-9.
56 Barbieri P. Confronting stress: integrating control theory and mindfulness to cultivate our inner resources through mind/body health methods. J Reality Ther. 1996;15(2):3-13.
57 Barclay A. Studying the efficacy of prayer. Med Today. 2002;3(11):89-9.
58 Barker P. Zen and the art of losing your self. Nurs Times. 2000;96(26):23.
59 Barnes VA. EEG, hypometabolism, and ketosis during transcendental meditation indicate it does not increase epilepsy risk. Med Hypotheses. 2005;65(1):202-3. [pmid: 15893151].
60 Barnes VA, Schneider RH, Alexander CN, et al. Stress, stress reduction, and hypertension in African Americans: an updated review. J Natl Med Assoc. 1997;89(7):464-76. [pmid: 9220696]. [pmcid: 2568086].
61 Barrett S. Psychoneuroimmunology: the bridge between science and spirit. In: Kane B, Millay J, Brown D, eds. Silver threads: 25 years of parapsychology research. Westport (CT): Praeger; 1993. Chapter 12.
62 Baxter ES. The growth process inventory: a validation study. Eugene: University of Oregon; 1982.
63 Bell JA, Saltikov JB. Mitchell's relaxation technique: is it effective?. Physiotherapy. 2000;86(9):473-8.
64 Bellarosa C, Chen PY. The effectiveness and practicality of occupational stress management interventions: a survey of subject matter expert opinions. J Occup Health Psychol. 1997;2(3):247-62. [pmid: 9552295].
65 Bench SA. The therapeutic impact of therapist enthusiasm and scientific credibility on the relaxation response [dissertation]. Hempstead, NY: Hofstra University; 2000.
66 Benson H. The relaxation response and norepinephrine: a new study illuminates mechanisms. Integr Psychiatry. 1983;1(1):15-8.
67 Benson H. The relaxation response: its subjective and objective historical precedents and physiology. Trends Neurosci. 1983;6(7):281-4.
68 Benson H. Systemic hypertension and the relaxation response. N Engl J Med. 1977;296(20):1152-6. [pmid: 323702].
69 Benson H, Greenwood MM, Klemchuk HM. The relaxation response: psychophysiologic aspects and clinical applications. Int J Psychiatry Med. 1975;6(12):87-98. [pmid: 773864].
70 Benson H, Kotch JB, Crassweller KD, et al. Historical and clinical considerations of the relaxation response. Am Sci. 1977;65(4):441-5. [pmid: 329725].
71 Berry GC. Discriminating groups of hypnotized and meditating subjects from normal subjects with the altered states of consciousness inventory (ASCI) [abstract]. Diss Abstr Int. 1982;43(5B):1594.
72 Bi Y, Cao Z. Treatment of upper respiratory tract infection by qigong. J Tradit Chin Med. 1990;10(3):235-9.
73 Birnbaum L, Birnbaum A. In search of inner wisdom: guided mindfulness meditation in the context of suicide. ScientificWorldJournal. 2004;4:216-27. [pmid: 15105961].
74 Bishop RJ. Bodywork as mediation: using structural integration as a pathway. Massage Bodywork. 2005;20(4):52-63.
75 Bishop SR. What do we really know about mindfulness-based stress reduction? Psychosom Med 2002;64(1):71–83. Erratum in: Psychosom Med 2002;64(3):449.
76 Bishop SR, Lau M, Shapiro S, et al. Mindfulness: a proposed operational definition. Clin Psychol: Sci Pract. 2004;11(3):230-41.
77 Bitner R, Hillman L, Victor B, et al. Subjective effects of antidepressants: a pilot study of the varieties of antidepressant-induced experiences in meditators. J Nerv Ment Dis. 2003;191(10):660-7. [pmid: 14555868].
78 Blanchard EB, Appelbaum KA, Radnitz CL, et al. Placebo-controlled evaluation of abbreviated progressive muscle relaxation and of relaxation combined with cognitive therapy in the treatment of tension headache. J Consult Clin Psychol. 1990;58(2):210-5. [pmid: 2186066].
79 Blanchard EB, Appelbaum KA, Radnitz CL, et al. A controlled evaluation of thermal biofeedback and thermal biofeedback combined with cognitive therapy in the treatment of vascular headache. J Consult Clin Psychol. 1990;58(2):216-24. [pmid: 2186067].
80 Blanchard EB, Young LD. Self-control of cardiac functioning: a promise as yet unfulfilled. Psychol Bull. 1973;79(3):145-63. [pmid: 4570400].
81 Blanton PG. The use of Christian meditation with religious couples: a collaborative language systems perspective. J Fam Psychother. 2002;13(34):291-307.
82 Blows MW. Yoga meditation: history and philosophy of the wisdom traditions and practical contemporary clinical applications. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 35–48.
83 Boals GF. Toward a cognitive reconceptualization of meditation. J Transpersonal Psychol. 1978;10(2):143-82.
84 Body temperature changes during the practice of g tum-mo yoga. Nature 1982;298(5872):402.
85 Boerstler RW, Kornfeld HS. Meditation as a clinical intervention. J Psychosoc Nurs Ment Health Serv. 1987;25(6):29-32.
86 Bogart G. The use of meditation in psychotherapy: a review of the literature. Am J Psychiatry. 1991;45(3):383-412.
87 Bolen JS. Meditation and psychotherapy in the treatment of cancer. Psychic. 1973;4(6):19-22.
88 Bonadonna R. Meditation's impact on chronic illness. Holist Nurs Pract. 2003;17(6):309-19. [pmid: 14650573].
89 Borrie RA. The use of restricted environmental stimulation therapy in treating addictive behaviors. Int J Addict. 1990-1991;25(7A8A):995-1015.
90 Bourne A. Colour breathing for healing: the integration of colours and breathing for meditation, relaxation and healing. Positive Health 2002;(73):9–11.
91 Bower JE, Woolery A, Sternlieb B, et al. Yoga for cancer patients and survivors. Cancer Control. 2005;12(3):165-71. [pmid: 16062164].
92 Braud WG. Meditation and psychokinesis. Parapsychology Rev. 1990;21(1):9-11.
93 Breslin FC, Zack M, McMain S. An information-processing analysis of mindfulness: implications for relapse prevention in the treatment of substance abuse. Clin Psych: Sci Pract. 2002;9(3):275-99.
94 Broderick MA. A certain doubleness: reflexive thought and mindful experience as tools for transformative learning in the stress reduction clinic [dissertation]. Boston: Harvard University; 1996.
95 Broota A, Dhir R. Efficacy of two relaxation techniques in depression. J Pers Clin Stud. 1990;6(1):83-90.
96 Broota A, Sanghvi VC. Efficacy of two relaxation techniques in examination anxiety. J Pers Clin Stud. 1994;10(12):29-35.
97 Brown D. The path of meditation: affective development and psychological well-being. In: Ablon SL, Brown D, Khantzian EJ, et al., eds. Human Feelings: explorations in affect development and meaning. Hillsdale (NJ): Analytic Press, Inc; 1993. p. 373–402.
98 Brown DP, Engler J. The stages of mindfulness meditation: a validation study. J Transpersonal Psychol. 1980;12(2):143-92.
99 Brown KW, Ryan RM. The benefits of being present: mindfulness and its role in psychological well-being. J Pers Soc Psychol. 2003;84(4):822-48. [pmid: 12703651].
100 Brown KW, Ryan RM. Perils and promise in defining and measuring mindfulness: observations from experience. Clin Psychol: Sci Pract. 2004;11(3):242-8.
101 Brown M. Higher education for higher consciousness: a study of students at Maharishi International University. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 985–1000.
102 Brown RP, Gerbarg PL. Sudarshan kriya yogic breathing in the treatment of stress, anxiety, and depression: part I: neurophysiologic model. J Altern Complement Med 2005;11(1):189–201. Erratum in: J Altern Complement Med 2005;11(2):383–4.
103 Brown-Saltzman K. Replenishing the spirit by meditative prayer and guided imagery. Semin Oncol Nurs. 1997;13(4):255-9. [pmid: 9392033].
104 Bruner RL. The reduction of anxiety and tension states through learning the relaxation response: a theoretical study with clinical applications [abstract]. Diss Abstr Int. 1978;39(1B):370-1.
105 Bruton A, Lewith GT. The Buteyko breathing technique for asthma: a review. Complement Ther Med. 2005;13(1):41-6. [pmid: 15907677].
106 Burnard P. Meditation: uses and methods in psychiatric nurse education. Nurse Educ Today. 1987;7(4):187-91. [pmid: 3306329].
107 Butler MH, Stout JA, Gardner BC. Prayer as a conflict resolution ritual: clinical implications of religious couples' report of relationship softening, healing perspective, and change responsibility. Am J Fam Ther. 2002;30(1):19-37.
108 Calajoe A. Yoga as a therapeutic component in treating chemical dependency. Alcohol Treat Q. 1986;3(4):33-46.
109 Cambach W, Chadwick-Straver RV, Wagenaar RC, et al. The effects of a community-based pulmonary rehabilitation programme on exercise tolerance and quality of life: a randomized controlled trial. Eur Respir J. 1997;10(1):104-13. [pmid: 9032501].
110 Candelent T, Candelent G. Teaching transcendental meditation in a psychiatric setting. Hosp Community Psychiatry. 1975;26(3):156-9. [pmid: 1140761].
111 Canter PH. The therapeutic effects of meditation. BMJ. 2003;326(7398):1049-50. [pmid: 12750183]. [pmcid: 1125975].
112 Canter PH, Ernst E. The cumulative effects of transcendental meditation on cognitive function—a systematic review of randomised controlled trials. Wien Klin Wochenschr. 2003;115(2122):758-66. [pmid: 14743579].
113 Canter PH, Ernst E. Insufficient evidence to conclude whether or not transcendental meditation decreases blood pressure: results of a systematic review of randomized clinical trials. J Hypertens. 2004;22(11):2049-54. [pmid: 15480084].
114 Cardoso R, De Souza E, Camano L, et al. Meditation in health: an operational definition. Brain Res Protoc. 2004;14(1):58-60.
115 Carey MP. Providing relaxation training to cancer chemotherapy patients: a comparison of three delivery strategies [abstract]. Diss Abstr Int. 1986;47(4B):1714.
116 Carlson LE, Brown KW. Validation of the mindful attention awareness scale in a cancer population. J Psychosom Res. 2005;58(1):29-33. [pmid: 15771867].
117 Carmen JE. Yoga and singing: natural partners. J Singing. 2004;60(5):433-41.
118 Carmody JF, Hebert J. Mindfulness meditation as a support in dietary change. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [cited 2005 Oct 10]. Available at: http://www.psychosomatic.org/meeting/2005/pageS001-S215.pdf. Symposium #11A.
119 Carrington P. Freedom in meditation. Garden City, NY: Anchor Press/Doubleday; 1997.
120 Carruthers ME. Voluntary control of the involuntary nervous system: comparison of autogenic training and siddha meditation. Exp Clin Psychiatry. 1981;6:171-81.
121 Carter J. Yoga adjunct to psychiatric treatment and preventive intervention. Aust N Z J Psychiatry. 2002;36(6):A5.
122 Casler L. A simple verbal procedure for reducing the rates of psychosomatic enfeeblement and death in an aged population. Death Stud. 1985;9(34):295-307.
123 Caspi O, Burleson KO. Methodological challenges in meditation research. Adv Mind Body Med. 2005;21(1):4-11. [pmid: 15973854].
124 Cassel RN. Basic fundamentals of mind control and transcendental meditation. Psychology: J Hum Behav. 1974;11(2):26-33.
125 Cassel RN. Fostering transcendental meditation using bio-feedback eliminates hoax and restores creditability to art. Psychology: J Hum Behav. 1976;13(2):58-64.
126 Cassel RN. Fundamentals involved in the scientific process of transcendental meditation. J Instructional Psychol. 1976;3(3):2-11.
127 Caudill MA, Friedman R, Benson H. Relaxation therapy in the control of blood pressure. Bibl Cardiol. 1987;41:106-19. [pmid: 3555456].
128 Chalif RP. An exploration of the interface between countertransference phenomena and the practice of vipassana meditation [dissertation]. Boston: Massachusetts School of Professional Psychology; 2001.
129 Chalmers RA. Transcendental meditation does not predispose to epilepsy. Med Hypotheses. 2005;65(3):624-5. [pmid: 15913905].
130 Chan DW. Introducing the chinese hexiangzhuang (flying crane) qigong therapy. Int J Psychosom. 1987;34(4):28-34. [pmid: 3319929].
131 Chan TH. The use of prayer as a coping strategy in dealing with state-trait anxiety [abstract]. Diss Abstr Int. 1995;55(12B):5562.
132 Chan WW, Bartlett DJ. Effectiveness of tai chi as a therapeutic exercise in improving balance and postural control. Phys Occup Ther Geriatr. 2000;17(3):1-22.
133 Chandra FA. Respiratory practices in yoga. In: Timmons B, Ley R, eds. Behavioral and psychological approaches to breathing disorders. New York: Plenum Press; 1994. p. 221–32.
134 Chen K, He B, Rihacek G, et al. A pilot trial of external qigong therapy for arthritis pain. J Clin Rheumatol. 2003;9(5):332-5. [pmid: 17041488].
135 Chen K, Yeung R. Exploratory studies of qigong therapy for cancer in China. Integr Cancer Ther. 2002;1(4):345-70. [pmid: 14664729].
136 Chen KM, Snyder M. A research-based use of tai chi/movement therapy as a nursing intervention. J Holist Nurs. 1999;17(3):267-79. [pmid: 10690069].
137 Chen KM, Snyder M, Krichbaum K. Clinical use of tai chi in elderly populations. Geriatr Nurs. 2001;22(4):198-200. [pmid: 11505246].
138 Chen KM, Snyder M, Krichbaum K. Facilitators and barriers to elders' practice of t'ai chi: a mind-body, low-intensity exercise. J Holist Nurs. 2001;19(3):238-55. [pmid: 11847870].
139 Chen KW. An analytic review of studies on measuring effects of external qi in China. Altern Ther Health Med. 2004;10(4):38-50.
140 Chen KW, Liu T. Effects of qigong therapy on arthritis: a review and report of a pilot trial. Med Paradigm. 2004;1(1):36-48.
141 Cheng J. Tai chi chuan: a slow dance for health. Phys Sportsmed. 1999;27(6):109-10.
142 Cheshire CA. Spirituality and religiousness scales: their relationship to locus of control [dissertation]. Nashville: Tennessee State University; 2003.
143 Clark BJ. Group interventions for memory complaints, memory impairment, and depression in the able elderly [abstract]. Diss Abstr Int. 1995;56(3B):1694.
144 Clemens JG. Tae kwon do as a treatment for adult depression: a program design [dissertation]. Keene (NH): Antioch New England Graduate School; 2005.
145 Clements G, Krenner L, Molk W. The use of the transcendental meditation programme in the prevention of drug abuse and in the treatment of drug-addicted persons. Bull Narc. 1988;40(1):51-6. [pmid: 3064844].
146 Cohen K. Ken Cohen, MA, MSTh healing through ancient traditions: qigong and Native American medicine interview by Bonnie Horrigan. Altern Ther Health Med. 2003;9(3):82-91. [pmid: 12776479].
147 Cohen-Katz J, Wiley SD, Capuano T, et al. The effects of mindfulness-based stress reduction on nurse stress and burnout: a quantitative and qualitative study. Holist Nurs Pract. 2004;18(6):302-8. [pmid: 15624277].
148 Cohen MH. Regulation, religious experience, and epilepsy: a lens on complementary therapies. Epilepsy Behav. 2003;4(6):602-6. [pmid: 14698692].
149 Coker KH. Meditation and prostate cancer: integrating a mind/body intervention with traditional therapies. Semin Urol Oncol. 1999;17(2):111-8. [pmid: 10332925].
150 Collings GH. Stress containment through meditation. Prev Hum Serv. 1989;6(2):141-50.
151 Collins C. Yoga: intuition, preventive medicine, and treatment. JOGN Nurs. 1998;27(5):563-8.
152 Collins FC. The use of prayer and the self-reported anxiety and depression of retired adults [dissertation]. Minneapolis: Walden University; 2003.
153 Collipp PJ. The efficacy of prayer: a triple-blind study. Med Times. 1969;97(5):201-4. [pmid: 5786487].
154 Compton WC. On the validity of the East-West questionnaire. Psychol Rep. 1983;52(1):117-8.
155 Cooper SE, Oborne J, Newton S, et al. Effect of two breathing exercises (Buteyko and pranayama) in asthma: a randomised controlled trial. Thorax. 2003;58(8):674-9. [pmid: 12885982]. [pmcid: 1746772].
156 Cooper SE, Oborne J, Newton S, et al. The effect of two breathing exercises (Buteyko and pranayama) on the ability to reduce inhaled corticosteroids in asthma: a randomised controlled trial. Program and abstracts of the American Thoracic Society 99th International Conference; 2003 May 16–21; Seattle, WA: B023 Poster 924.
157 Corliss R. The power of yoga. Time. 2001;157(16):54-63.
158 Craven JL. Meditation and psychotherapy. Can J Psychiatry. 1989;34(7):648-53. [pmid: 2680046].
159 Crook J. Zen: the challenge to dependency. In: Watson G, Batchelor S, Claxton G, eds. The psychology of awakening. London: Rider; 1999. p. 197–214.
160 D'Souza RF, Rodrigo A. Spiritually augmented cognitive behavioural therapy. Australas Psychiatry. 2004;12(2):148-52. [pmid: 15715760].
161 Dalal AS, Barber TX. Yoga, “yoga feats,” and hypnosis in the light of empirical research. Am J Clin Hypn. 1969;11(3):155-66. [pmid: 5764616].
162 Danusantoso H, Heijnen L. Tai chi chuan for people with haemophilia. Haemophilia. 2001;7(4):437-9.
163 Davidson JM. The physiology of meditation and mystical states of consciousness. Perspect Biol Med. 1976;19(3):345-79. [pmid: 958856].
164 Davison GC, Williams ME, Nezami E, et al. Relaxation, reduction in angry articulated thoughts, and improvements in borderline hypertension and heart rate. J Behav Med. 1991;14(5):453-68. [pmid: 1744909].
165 Day P, O'Haver H, Deutsch S. Using mindfulness-based therapeutic interventions in psychiatric nursing practice-part I: description and empirical support for mindfulness-based interventions. Arch Psychiatr Nurs. 2004;18(5):164-9. [pmid: 15529281].
166 Day P, O'Haver H, Deutsch S. Using mindfulness-based therapeutic interventions in psychiatric nursing practice part II: mindfulness-based approaches for all phases of psychotherapy-clinical case study. Arch Psychiatr Nurs. 2004;18(5):170-7. [pmid: 15529282].
167 De Felice MG. Mindfulness meditation: a new tool for understanding and regulating musical performance anxiety an affective neuroscientific perspective [dissertation]. Coral Gables, FL: University of Miami; 2004.
168 De Silva P. Mindfulness-based cognitive therapy for depression: a new approach to preventing relapse. Behav Res Ther. 2003;41(5):629-30.
169 De Silva P. Early Buddhist meditation and mental health. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 25–34.
170 DeBerry S. The effects of meditation-relaxation on anxiety and depression in a geriatric population. Psychother: Theory Res Pract. 1982;19(4):512-21.
171 DeBerry S, Davis S, Reinhard KE. A comparison of meditationelaxation and cognitive/behavioral techniques for reducing anxiety and depression in a geriatric population. J Geriatr Psychiatry. 1989;22(2):231-47. [pmid: 2701175].
172 Decker TW, Cline EJ, Gallagher M. Relaxation therapy as an adjunct in radiation oncology. J Clin Psychol. 1992;48(3):388-93. [pmid: 1602030].
173 Dedert EA, Studts JL, Weissbecker I, et al. Religiosity may help preserve the cortisol rhythm in women with stress-related illness. Int J Psychiatry Med 2004;34(1):61–77 Erratum in: Int J Psychiatry Med 2004;34(3):287.
174 Deepak KK. Neurophysiological mechanisms of induction of meditation: a hypothetico-deductive approach. Indian J Physiol Pharmacol. 2002;46(2):136-58. [pmid: 12500489].
175 Deikman AJ. A functional approach to mysticism. J Consciousness Stud. 2000;7(1112):75-91.
176 Delmonte MM. Biochemical indices associated with meditation practice: a literature review. Neurosci Biobehav Rev. 1985;9(4):557-61. [pmid: 2867509].
177 Delmonte MM. The effects of meditation on drug usage: a literature review. Gedrag: Tijdschrift Voor Psychologie. 1985;13(2):36-48.
178 Delmonte MM. Electrocortical activity and related phenomena associated with meditation practice: a literature review. Int J Neurosci. 1984;24(34):217-31. [pmid: 6392127].
179 Delmonte MM. Mantras and meditation: a literature review. Percept Mot Skills. 1983;57(1):64-6.
180 Delmonte MM. Meditation and anxiety reduction: a literature review. Clin Psychol Rev. 1985;5(2):91-102.
181 Delmonte MM. Meditation and change: mindfulness versus repression. Aust J Clin Hypnotherapy Hypn. 1990;11(2):57-63.
182 Delmonte MM. Meditation as a clinical intervention strategy: a brief review. Int J Psychosom. 1986;33(3):9-12.
183 Delmonte MM. Meditation in the Christian tradition. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 121–30.
184 Delmonte MM. Meditation practice as related to occupational stress, health, and productivity. Percept Mot Skills. 1984;59(2):581-2. [pmid: 6393035].
185 Delmonte MM. Meditation, the unconscious, and psychosomatic disorders. Int J Psychosom. 1989;36(14):45-52. [pmid: 2689373].
186 Delmonte MM. Personality and meditation. In: West MA, ed. The psychology of meditation. Oxford, UK: Clarendon; 1987. p. 118–32.
187 Delmonte MM. Personality characteristics and regularity of meditation. Psychol Rep. 1980;46(3 Pt 1):703-12.
188 Delmonte MM. Personality correlates of meditation practice frequency and dropout in an outpatient population. J Behav Med. 1988;11(6):593-7. [pmid: 3075240].
189 Delmonte MM. Physiological concomitants of meditation practice. Int J Psychosom. 1984;31(4):23-36.
190 Delmonte MM. Psychometric scores and meditation practice: a literature review. Pers Individ Dif. 1984;5(5):559-63.
191 Delmonte MM. The relevance of meditation to clinical practice: an overview. Appl Psychol: Int Rev. 1990;39(3):331-54.
192 Delmonte MM. Response to meditation in terms of physiological, behavioural and self-report measures: a brief summary. Psychol Rep. 1985;56(1):9-10. [pmid: 3885286].
193 Delmonte MM. Silence and emptiness in the service of healing: lessons from meditation. Br J Psychother. 1995;11(3):368-78.
194 Delmonte MM. Some cognitive aspects of meditation practice. Percept Mot Skills. 1983;57(3 Pt 2):1160-2. [pmid: 6364034].
195 Delmonte MM. Therapeutic aspects of meditation. Int J Psychol. 1992;27(34):446.
196 Delmonte MM, Kenny V. Conceptual models and functions of meditation in psychotherapy. J Contemp Psychother. 1987;17(1):38-59.
197 Delmonte MM, Kenny V. An overview of the therapeutic effects of meditation. Psychologia: Int J Psychol Orient. 1985;28(4):189-202.
198 Devaki P. Yoga as neuropsychological modifier. Int J Psychol. 2004;39(56 Suppl):297-8.
199 Dikshit CS. Anatomical basis of yogic asanas. Clinician. 1978;42(1):18-21.
200 Dillbeck MC. The application of the transcendental meditation program to corrections. Int J Comp Appl Criminal Justice. 1987;1(11):111-32.
201 Dillbeck MC. Testing the vedic psychology of the bhagavad-gita. Psychologia: Int J Psychol Orient. 1983;26(4):232-40.
202 Dillbeck MC, Orme-Johnson DW. Physiological differences between transcendental meditation and rest. Am Psychol. 1987;42(9):879-81.
203 Dillbeck MC, Orme-Johnson DW. The use of the transcendental meditation and TM-Sidhi program in rehabilitation and crime-prevention. Bull Br Psychol Soc. 1982;35:A94.
204 Dillbeck MC, Raimondi D, Assimakis PD, et al. The longitudinal effects of the MIU curriculum on intelligence and field independence. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2385–6.
205 Dimidjian S, Linehan MM. Defining an agenda for future research on the clinical application of mindfulness practice. Clin Psychol: Sci Pract. 2003;10(2):166-71.
206 DiPietro L, Seeman TE, Stachenfeld NS, et al. Moderate-intensity aerobic training improves glucose tolerance in aging independent of abdominal adiposity. J Am Geriatr Soc. 1998;46(7):875-9. [pmid: 9670875].
207 Dixit SP, Agrawal A, Dubey GP. Management of essential hypertension by using biofeedback technique. Pharmacopsychoecologia. 1994;7(1):17-9.
208 Domar AD. The use of the relaxation response with skin cancer patients [abstract]. Diss Abstr Int. 1987;47(11B):4681.
209 Dorcas A. Chinese qigong research: an overview. In: Kao HSR, Sinha D, eds. Asian perspectives on psychology. Thousand Oaks: Sage; 1997. p. 309–32.
210 Dorcas A, Yung P. Qigong: harmonising the breath, the body and the mind. Complement Ther Nurs Midwifery. 2003;9(4):198-202. [pmid: 14556769].
211 Dosh SA. The treatment of adults with essential hypertension. J Fam Pract. 2002;51(1):74-80. [pmid: 11927069].
212 Dostalek C. Physiological bases of yoga techniques in the prevention of diseases. Homeost Health Dis. 1994;35(45):205-8.
213 Dostalek C. Psychophysiology of hatha-yoga and its use in prevention therapy of life-style related diseases. Int J Psychophysiol. 1989;7(24):185-6.
214 Dougherty AM, Deck MD. Helping teachers to help children cope with stress. J Hum Counc Educ Dev. 1984;23(1):36-44.
215 Downey N. Mindfulness training: the effect of process and outcome instructions on the experience of control and the level of mindfulness among older women. Educ Gerontol. 1991;17(2):97-109.
216 Dreher H. Cancer and the mind: current concepts in psycho-oncology. Advances. 1987;4(3):27-43.
217 Drettner B. Patophysiological relationship between the upper and lower airways. Ann Otol Rhinol Laryngol. 1970;79(3):499-505. [pmid: 5426882].
218 Driskill JD. Meditation as a therapeutic technique. Pastoral Psychol. 1989;38(2):83-103.
219 Dua JK. A technique of meditation based on yoga philosophy and cognitive-behavioural theory. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 185–204.
220 Dubin W. The use of meditative techniques in psychotherapy supervision. J Transpersonal Psychol. 1991;23(1):65-80.
221 Dubs G. Psycho-spiritual development in Zen Buddhism: a study of resistance in meditation. J Transpersonal Psychol. 1987;19(1):19-86.
222 Dusek JA, Astin JA, Hibberd PL, et al. Healing prayer outcomes studies: consensus recommendations. Altern Ther Health Med. 2003;9(3 Suppl):A44-53. [pmid: 12776464].
223 Dwivedi KN. Freedom from the self sufism, meditation and psychotherapy. Group Analysis. 1989;22(4):434-6.
224 Earle JB. Cerebral laterality and meditation: a review of the literature. J Transpersonal Psychol. 1981;13(2):155-73.
225 Echenhofer FG, Coombs MM. A brief review of research and controversies in EEG biofeedback and meditation. J Transpersonal Psychol. 1987;19(2):161-71.
226 Edwards DL. A meta-analysis of the effects of meditation and hypnosis on measures of anxiety [dissertation]. College Station, TX: Texas A & M University; 1990.
227 Edwards L. Meditation as medicine. Benefits go beyond relaxation. Adv Nurse Pract. 2003;11(5):49-52. [pmid: 12754983].
228 Edwards LA. Use of hypnosis and non-ordinary states of consciousness in facilitating significant psychotherapeutic change. Aust J Clin Hypnotherapy Hypn. 1999;20(2):86-107.
229 Eifert GH, Heffner M. The effects of acceptance versus control contexts on avoidance of panic-related symptoms. J Behav Ther Exp Psychiatry. 2003;34(34):293-312. [pmid: 14972675].
230 Ekkekakis P, Hall EE, Vanlanduyt LM, et al. Walking in (affective) circles: can short walks enhance affect?. J Behav Med. 2000;23(3):245-75. [pmid: 10863677].
231 Elder C. Ayurveda for diabetes mellitus: a review of the biomedical literature. Altern Ther Health Med. 2004;10(1):44-50.
232 Elias AN, Guich S, Wilson AF. Ketosis with enhanced gabaergic tone promotes physiological changes in transcendental meditation. Med Hypotheses. 2000;54(4):660-2. [pmid: 10859661].
233 Elias AN, Wilson AF. Serum hormonal concentrations following transcendental-meditation: potential role of gamma-aminobutyric acid. Med Hypotheses. 1995;44(4):287-91. [pmid: 7666830].
234 Elkins D, Anchor KN, Sandler HM. Physiological effects of relaxation training. Am J Clin Biofeedback. 1978;1(1):30.
235 Elkins D, Anchor KN, Sandler HM. Relaxation training and prayer behavior as tension reduction techniques. Behav Eng. 1979;5(3):81-7.
236 Ellis GA, Corum P. Removing the motivator: a holistic solution to substance abuse. Alcohol Treat Q. 1994;11(34):271-96.
237 Elzayat SG. Microsurgical lumbar-disk removal (elzayat approach) with Islamic prayer therapy. Sao Paulo Med J. 1989;10(3):221-2.
238 Eppley K, Rice D. Double-blind comparison of raimondi technique and relaxation in prophylaxis of migraine headache. Headache Q Curr Treatment Res. 1996;7(1):54-7.
239 Eppley KR, Abrams AI, Shear J. Differential effects of relaxation techniques on trait anxiety: a meta-analysis. J Clin Psychol. 1989;45(6):957-74. [pmid: 2693491].
240 Epstein RM. Mindful practice. J Am Med Assoc. 1999;282(9):833-9.
241 Ernst E. Breathing techniques: adjunctive treatment modalities for asthma? A systematic review. Eur Respir J. 2000;15(5):969-72. [pmid: 10853868].
242 Ernst E. A primer of complementary and alternative medicine commonly used by cancer patients. Aust Med Rec J. 2001;174(2):88-92.
243 Ernst E. A systematic review of tai chi studies. Focus Altern Complement Ther. 2004;9(4):307-8.
244 Esch T, Fricchione GL, Stefano GB. The therapeutic use of the relaxation response in stress-related diseases. Med Sci Monit 2003;9:RA23–34.
245 Ethan S. Spirituality vs. psychoanalysis: the example of Zen Buddhism. Issues Psychoanalytic Psychol. 1999;21(12):33-44.
246 Evans RP. Vividness of imagery as a factor in pain management [abstract]. Diss Abstr Int. 1990;51(2B):982.
247 Everly GS Jr, Benson H. Disorders of arousal and the relaxation response: speculations on the nature and treatment of stress-related diseases. Int J Psychosom. 1989;36(14):15-21. [pmid: 2689371].
248 Everly GS Jr, Lating JM. Neurologic desensitization in the treatment of posttraumatic stress. In: Everly GSJr, Lating JM, eds. Personality-guided therapy for posttraumatic stress disorder. Washington, DC: American Psychological Association; 2004. p. 161–76.
249 Fasko D Jr, Grueninger RW. T'ai chi ch'uan and physical and psychological health: a review. Clin Kinesiology: J Am Kinesiotherapy Assoc. 2001;55(1):4-12.
250 Ferguson PC. An integrative meta-analysis of psychological studies investigating the treatment outcomes of meditation techniques [abstract]. Diss Abstr Int. 1981;42(4A):1547.
251 Ferguson PC. The psychobiology of transcendental meditation: a review. J Altered States Consciousness. 1975;2(1):15-36.
252 Ferguson PC. Transcendental meditation and its potential application in the field of special education. J Spec Educ. 1976;10(2):211-20.
253 Ferrari M. Influence of expertise on the intentional transfer of motor skill. J Mot Behav. 1999;31(1):79-85. [pmid: 11177621].
254 Fey SG, Lindholm E. Biofeedback and progressive relaxation: effects on systolic and diastolic blood pressure and heart rate. Psychophysiology. 1978;15(3):239-47. [pmid: 351660].
255 Finney JR, Malony HN. Contemplative prayer and its use in psychotherapy: a theoretical model. J Psychol Theol. 1985;13(3):172-81.
256 Fontana D. Mind, senses and self. In: Claxton G, ed. Beyond therapy: the impact of Eastern religions on psychological theory and practices. London: Wisdom; 1996. p. 33–48.
257 Fox DA. Meditation and reality: a critical review. Atlanta (GA): John Knox Press; 1986.
258 Frank ED. Breathing training as a self-regulatory stress reduction method for asthma prone individuals [abstract]. Diss Abstr Int. 1987;47(11A):3980.
259 Frederick AN, Barber TX. Yoga, hypnosis, and self-control of cardiovascular functions. Proc Annu Convention Am Psychol Assoc 1972;(7 Pt 2):859–60.
260 Fredrickson WC. A program of teaching the practice of Christian meditation/contemplative prayer to HIV positive clients [abstract]. Diss Abstr Int. 1993;53(12A):4367.
261 Freed S. Induced specific immunological unresponsiveness and conditioned behavioral reflexes, in functional isomorphism-meditation and conditioned specific unresponsiveness. Int J Neurosci. 1989;44(34):275-81. [pmid: 2656566].
262 Freeman MT. Enlivening veda in consciousness and physiology by reading the vedic literature in conjunction with the experience of the transcendental meditation (TM) and TM-Sidhi [dissertation]. Fairfield, IA: Maharishi International University; 1997.
263 Friedman H, Taub HA. Brief psychological training procedures in migraine treatment. Am J Clin Hypn. 1984;26(3):187-200. [pmid: 6435442].
264 Friedman EH, Coats AJS. Neurobiology of exaggerated heart rate oscillations during two meditative techniques. Int J Cardiol. 2000;73(2):199. [pmid: 10905879].
265 Friedman R, Steinman M, Benson H. The relaxation response: physiological effects and medical applications. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 205–12.
266 Fromm E. Primary and secondary process in waking and in altered states of consciousness. Acad Psychol Bull. 1981;3(1):29-45.
267 Fromm GH. Neurophysiological speculations on Zen enlightenment. J Mind Behav. 1992;13(2):163-9.
268 Frumkin K, Nathan RJ, Prout MF, et al. Nonpharmacologic control of essential hypertension in man: a critical review of the experimental literature. Psychosom Med. 1978;40(4):294-320. [pmid: 356079].
269 Funderburk J. Science studies yoga: a review of physiological data. Oxford, England: Himalayan International Institute of Yoga Science and Philosophy; 1977.
270 Furian TC, Wanger D, Ritthaler F. Influence of tai chi training device on physical performance, ventilatory parameters and balance. Int J Sports Med. 1999;20:S58-9.
271 Furlow L, O'Quinn JL. Does prayer really help?. J Christ Nurs. 2002;19(2):31-4. [pmid: 11908050].
272 Gaik FV. Merging east and west: a preliminary study applying spring forest qigong to depression as an alternative and complementary treatment [dissertation]. Chicago (IL): Alder School of Professional Psychology; 2003.
273 Galantino MLA. Influence of yoga, walking, and mindfulness meditation on fatigue and body mass index in women living with breast cancer. Semin Integrative Med. 2003;1(3):151-7.
274 Garfield E. Meditation, learning, and creativity part 1. The practice and physiologic effects of meditation. Curr Contents Clin Med 1985;(29):3–11.
275 Garfinkel MS, Schumacher HR Jr. Yoga. Rheum Dis Clin North Am. 2000;26(1):125-32. [pmid: 10680200].
276 Garrison J, Scott PA. A group self-care approach to stress management. J Psychiatr Nurs Ment Health Serv. 1979;17(6):9-14.
277 Garssen B, de Ruiter C, Van Dyck R. Breathing retraining: a rational placebo?. Clin Psychol Rev. 1992;12(2):141-53.
278 Gawler I. Imagery and meditation: how to balance active and passive forms of meditation. First Annual International Conference: Mind, Immunity and Health; 1995; Lorne, Australia. Yarra Junction, Australia: Gawler Foundation; 1995. p. 89–100.
279 Gazella KA. David Simon, MD practicing mind-body-soul medicine. Altern Ther Health Med. 2004;10(6):63-8. [pmid: 15624351].
280 Gelderloos P, Ahlstrom HH, Orme-Johnson DW, et al. Influence of a Maharishi ayur-vedic herbal preparation on age-related visual discrimination. Int J Psychosom. 1990;37(14):25-9. [pmid: 2246098].
281 Gelderloos P, Walton KG, Orme-Johnson DW, et al. Effectiveness of the transcendental meditation program in preventing and treating substance misuse: a review. Int J Addict. 1991;26(3):293-325. [pmid: 1889927].
282 Geller SM. Becoming whole: a collaboration between experiential psychotherapies and mindfulness meditation. Pers Cent Experiential Psychother. 2003;2(4):258-73.
283 Germer CK. Mindfulness: what is it? What does it matter? In: Germer CK, Siegel RD, Fulton PR, eds. Mindfulness and Psychotherapy. New York: Guilford Publications; 2005. p. 3–27.
284 Gerrity ET, Solomon SD. The treatment of PTSD and related stress disorders: current research and clinical knowledge. In: Marsella AJ, Friedman MJ, Gerrity ET, et al., eds. Ethnocultural aspects of posttraumatic stress disorder: issues, research and clinical applications. Washington, DC: American Psychological Association Books; 2001. Chapter 3.
285 Giardini F. The conscious and unconscious mind in prayer. J Psychol Christianity. 1987;6(1):5-20.
286 Gilbert C. Yoga and breathing. J Bodywork Movement Ther. 1999;3(1):44-54.
287 Gimbel MA. Yoga, meditation, and imagery: clinical applications. Nurse Pract Forum. 1998;9(4):243-55. [pmid: 10214227].
288 Glueck BC, Stroebel CF. Biofeedback and meditation in the treatment of psychiatric illnesses. Compr Psychiatry. 1975;16(4):303-21. [pmid: 1157476].
289 Goldberg B. Slowing down the aging process through the use of altered states of consciousness: a review of the medical literature. Psychology: J Hum Behav. 1995;32(2):19-21.
290 Goldberg RJ. Anxiety reduction by self-regulation: theory, practice, and evaluation. Ann Intern Med. 1982;96(4):483-7. [pmid: 7039446].
291 Goleman DJ. Meditation and consciousness: an Asian approach to mental health. Am J Psychiatry. 1976;30(1):41-54.
292 Gong LS, Wang CX, Qian JA, et al. Cardiovascular effects of taijiquan and qigong exercises. New Horizons Prev Cardiovasc Dis 1989;163–7.
293 Goodman N. The application of Kundalini yoga practices in the clinical-psychology context. Int J Psychol. 1992;27(34):474.
294 Goodman RS, Walton KG, Orme-Johnson DW, et al. Introduction and overview: the transcendental meditation program: a consciousness-based developmental. In: Alexander CN, Walton KG, Orme-Johnson DW, et al., eds. Transcendental Meditation in Criminal Rehabilitation and Crime Prevention. Binghamton, NY: The Haworth Press Inc; 2003. p. 1–33.
295 Goyeche JRM. Yoga as therapy in psychosomatic medicine. Psychother Psychosom. 1979;31(14):373-81. [pmid: 482559].
296 Goyeche JRM, Abo Y, Ikemi Y. Asthma: the yoga perspective part II: yoga therapy in the treatment of asthma. J Asthma. 1982;19(3):189-201. [pmid: 7118825].
297 Grant JA, Rainville P. Hypnosis and meditation: similar experiential changes and shared brain mechanisms. Med Hypotheses. 2005;65(3):625-6. [pmid: 15982830].
298 Graves LA. A theoretical framework for the use of mindfulness meditation in the practice of pastoral counseling from the perspectives of transpersonal psychology and process theology [dissertation]. Claremont, CA: Claremont School of Theology; 1999.
299 Graves N, Krepcho M, Mayo HG. Does yoga speed healing for patients with low back pain?. J Fam Pract. 2004;53(8):661-2. [pmid: 15298844].
300 Greene KB, Berger J, Reeves C, et al. Most frequently used alternative and complementary therapies and activities by participants in the AMCOA study. J Assoc Nurses AIDS Care. 1999;10(3):60-73. [pmid: 10707696].
301 Greenspan M, Schneider S. Therapeutic touch and healing meditation: a threesome with education. Int J Adolesc Youth. 1994;5(12):115-25.
302 Greenspan MR. Helping meditation: creative growth in education. Early Child Dev Care. 1995;110:113-22.
303 Greenwood MM, Benson H. The efficacy of progressive relaxation in systematic desensitization and a proposal for an alternative competitive response: the relaxation response. Behav Res Ther. 1977;15(4):337-43. [pmid: 20875].
304 Greyson B. Some neuropsychological correlates of the physio-kundalini syndrome. J Transpersonal Psychol. 2000;32(2):123-34.
305 Griegel LE. Breathing retraining in panic disorder: physiological mechanisms or perceived controllability [abstract]. Diss Abstr Int. 1995;55(9B):4120.
306 Grossman P, Niemann L, Schmidt S, et al. Mindfulness-based stress reduction and health benefits: a meta-analysis. In: Proceedings of the 61st Annual Scientific Conference of the American Psychosomatic Society; 2003 March 13–16; Phoenix (AR) [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1. Abstract 1436.
307 Grossman P, Niemann L, Schmidt S, et al. Mindfulness-based stress reduction and health benefits: a meta-analysis. J Psychosom Res. 2004;57(1):35-43. [pmid: 15256293].
308 Gruber BL, Hall NR, Hersh SP, et al. Immune-system changes in breast-cancer patients given relaxation, guided imagery, and biofeedback training. Biofeedback Self Regul. 1989;14(2):142-3.
309 Gruber RG. The comparative effectiveness of similarly, dissimilarly, self and non-modeled covert imagery with and without relaxation with snake phobic females [abstract]. Diss Abstr Int. 1984;44(12B):3933.
310 Guo HZ, Zhang SX, Jing BS, et al. A preliminary report on a new anti-g maneuver. Aviat Space Environ Med. 1988;59(10):968-72. [pmid: 3190625].
311 Gura TS. Yoga for stress reduction and injury prevention at work. Work. 2002;19(1):3-7. [pmid: 12454346].
312 Haartman K. Watching and praying: a psychoanalytic view of personality change in 18th-century British methodism [dissertation]. Toronto: University of Toronto; 2000.
313 Haber D. A health promotion program in ten nursing homes. Activ Adapt Aging. 1988;11(1):75-84.
314 Hackett G, Horan JJ. Stress inoculation for pain: what's really going on?. J Couns Psychol. 1980;27(2):107-16.
315 Hainsworth T. The role of exercise in falls prevention for older patients. Nurs Times. 2004;100(18):28-9.
316 Haley KC, Koenig HG, Bruchett BM. Relationship between private religious activity and physical functioning in older adults. J Relig Health. 2001;40(2):305-12.
317 Hall H, Papas A, Tosi M, et al. Directional changes in neutrophil adherence following passive resting versus active imagery. Int J Neurosci. 1996;85(34):185-94. [pmid: 8734558].
318 Hall NRS, O'Grady MP. Psychosocial interventions and immune function. 2nd ed. Boston: Academic Press; 1991. p. 1067–79.
319 Han A, Robinson V, Judd M, et al. Tai chi for treating rheumatoid arthritis. Cochrane Database Syst Rev 2004;(3):CD004849.
320 Hankey DA. The awakening of full human potential through Maharishi mahesh yogi's vedic science: research on the experience of reading the vedic literature [dissertation]. Fairfield, IA: Maharishi International University; 2000.
321 Hanna PB, Berry ZM, Bennett T, et al. Stress as a diagnostic challenge for postconcussive symptoms: sequelae of mild traumatic brain injury or physiological stress response. Neuropsychol Dev Cogn Section D Clin Neuropsychol. 2001;15(3):289-304.
322 Hanna T. The project of somatology. J Hum Psychol. 1973;13(3):3-14.
323 Harari SS. What's the matter: your energy or your matter? an exploratory study examining body-mind-spirit correlates of Tibetans and Caucasian Americans for multicultural holistic health practice intake [dissertation]. Chicago: Chicago School of Professional Psychology; 2002.
324 Haridas NV. Physiological and philosophical aspects of yoga. In: Murali TS, editor. Sixth World Congress on Holistic Life and Medicine; 1996 Jan; Calicut, India. Kottakkal: Arya Vaidya Sala; 1998. p. 141–4.
325 Harmon RL, Myers MA. Prayer and meditation as medical therapies. Phys Med Rehabil Clin N Am. 1999;10(3):651-62. [pmid: 10516983].
326 Harris AH, Thoresen CE, McCullough ME, et al. Spiritually and religiously oriented health interventions. J Health Psychol. 1999;4(3):413-33.
327 Haruki Y, Ishii I, Suzuli M. Some aspects of meditation. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the Third Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 3–12.
328 Hassan-Schwarz Galle S. Hypnosis, yoga, and psychotherapy. Boca Raton, FL: CRC Press; 1999.
329 Hassed CS. To be or not to be. Evidence in support of contemplative practices: part 1. Aust Fam Physician. 2000;29(9):883-4. [pmid: 11008396].
330 Hassed CS. To be or not to be. The practical aspects of contemplative practices: part 2. Aust Fam Physician. 2000;29(10):985-7. [pmid: 11059091].
331 Hauser W, Biewer W. Pain management in patients with chronic rheumatic pain: a model for primary medical care. Schmerz. 1997;11(2):116-9. [pmid: 12799829].
332 Hawkins MA. Effectiveness of the transcendental meditation program in criminal rehabilitation. In: Alexander CN, Walton KG, Orme-Johnson DW, et al., eds. Transcendental Meditation in Criminal Rehabilitation and Crime Prevention. Binghamton, NY: The Haworth Press Inc; 2003. p. 47–65.
333 Hawkins MA. Section I: Theory and review effectiveness of the transcendental meditation program in criminal rehabilitation and substance abuse recovery: a review of the research. J Offender Rehabil. 2003;36(14):47-65.
334 Hawks SR, Hull ML, Thalman RL, et al. Review of spiritual health: definition, role, and intervention strategies in health promotion. Am J Health Promot. 1995;9(5):371-8. [pmid: 10150769].
335 Hayashi K. Integrated body control method with image, breath, intention, consciousness, cognition, qi and healing to make oneself healthy. J Int Soc Life Inf Sci. 2005;23(1):16-23.
336 Hayes AM, Feldman G. Clarifying the construct of mindfulness in the context of emotion regulation and the process of change in therapy. Clin Psychol: Sci Pract. 2004;11(3):255-62.
337 Hayes SC. Acceptance and commitment therapy and the new behavior therapies: mindfulness, acceptance, and relationship. In: Hayes SCE, Follette VME, Linehan MME. Mindfulness and acceptance: expanding the cognitive-behavioral tradition. New York: Guilford Press; 2004. p. 1–29.
338 Hayes SC, Shenk C. Operationalizing mindfulness without unnecessary attachments. Clin Psychol: Sci Pract. 2004;11(3):249-54.
339 Hayes SC, Wilson KG. Mindfulness: method and process. Clin Psychol: Sci Pract. 2003;10(2):161-5.
340 Hayward J. A rDzogs-chen Buddhist interpretation of the sense of self. J Consciousness Stud. 1998;5(56):611-26.
341 He D. Qigong: special psychotherapy. Int J Psychol. 1996;31(34):354-65.
342 Heaman D. The quieting response (QR): a modality for reduction of psychophysiologic stress in nursing students. J Nurs Educ. 1995;34(1):5-10. [pmid: 7876913].
343 Heilbronn FS. The use of hatha yoga as a strategy for coping with stress in management development. Manage Educ Dev. 1992;23(2):131-9.
344 Helm-Estabrooks N. The times they are a-changin': nontraditional treatment approaches to communications disorders. Semin Speech Lang. 2004;25(2):117-8. [pmid: 15118938].
345 Helm HM, Hays JC, Flint EP, et al. Does private religious activity prolong survival? A six-year follow-up study of 3,851 older adults. J Gerontol A Biol Sci Med Sci. 2000;55(7):400-5.
346 Helminiak DA. Meditation: psychologically and theologically considered. Pastoral Psychol. 1981;30(1):6-20.
347 Hendlin SJ. T'ai chi chaun and gestalt therapy. J Contemp Psychother. 1978;10(1):25-31.
348 Henry JP. Relaxation methods and the control of blood pressure. Psychosom Med. 1978;40(4):273-5. [pmid: 356077].
349 Henry JR. The effects of brief ruminating, distracting, and mindfulness interventions on public speaking anxiety [dissertation]. Greensboro: University of North Carolina; 2003.
350 Hernandez NE, Kolb S. Effects of relaxation on anxiety in primary caregivers of chronically ill children. Pediatr Nurs. 1998;24(1):51-6. [pmid: 9555445].
351 Herriott EM. Elements of entrepreneurial success: the links among inner competencies, inner development and success [dissertation]. Fairfield, IA: Maharishi International University; 2000.
352 Herron WJ. A questionnaire study comparing mystical experience among Zen, yoga, Christian, and non-spiritual groups [abstract]. Diss Abstr Int. 1993;54(4B):2179.
353 Heslet L. Effects of relaxation and diaphragmatic breathing on respiratory sinus arrhythmia: implications for cardiovascular disease [abstract]. Diss Abstr Int. 1996;56(10B):5754.
354 Hill RD, Sheikh JI, Yesavage JA. Pretraining enhances mnemonic training in elderly adults. Exp Aging Res. 1989;14(4):207-11.
355 Hirota A, Hirai H. Effects of relaxation-response- or arousal-response-oriented training on psychophysiological responses during fear imagery. Jpn Psychol Res. 1990;32(1):26-35.
356 Hohn T. Christian meditation paths? Development of a questionnaire for Christian contemplation based on descriptions of Master Eckhart and Teresa of Avila. J Medit Medit Res. 2003;3:7-20.
357 Holl RM. What is prayer?. Alernat Health Pract. 1998;4(2):109-14.
358 Holland D. Integrating mindfulness meditation and somatic awareness into a public educational setting. J Hum Psychol. 2004;44(4):468-84.
359 Holmes DS. The influence of meditation versus rest on physiological arousal: a second examination. Oxford: Clarendon Press; 1987. p. 81–103.
360 Holmes DS. Meditation and somatic arousal reduction: a review of the experimental evidence. Am Psychol. 1984;39(1):1-10. [pmid: 6142668].
361 Holmes DS. Self-control of somatic arousal: an examination of the effects of meditation and biofeedback. Am Behav Sci. 1985;28(4):486-96.
362 Holmes DS, McCaul KD, Solomon S. Control of respiration as a means of controlling responses to threat. J Pers Soc Psychol. 1978;36(2):198-204. [pmid: 624986].
363 Holroyd J. The science of meditation and the state of hypnosis. Am J Clin Hypn. 2003;46(2):109-28. [pmid: 14609297].
364 Hopper C, Kolt GS, McConville JC. Feldenkrais awareness through movement on hamstring length, flexibility, and perceived exertion. J Bodywork Movement Ther. 1999;3(4):238-47.
365 Horrigan B. Pamela Miles reiki vibrational healing. Altern Ther Health Med. 2003;9(4):75-83.
366 Hosaka T, Sugiyama Y, Tokuda Y, et al. Persistent effects of a structured psychiatric intervention on breast cancer patients' emotions. Psychiatry Clin Neurosci. 2000;54(5):559-63. [pmid: 11043806].
367 Hoshmand LT, Helmes E, Kazarian S, et al. Evaluation of two relaxation training programs under medication and no-medication conditions. J Clin Psychol. 1985;41(1):22-9. [pmid: 2857732].
368 Huang BH. Exploring oriental wisdom: self-transcendence and psychological well-being of adulthood in Taiwan [dissertation]. Madison: University of Wisconsin; 1999.
369 Huber HP, Gramer M. Psychophysiological response patterns in relaxation processes. German J Psychol. 1990;14(2):98-106.
370 Hunt HT, Gervais A, Shearing-Johns S, et al. Transpersonal experiences in childhood: an exploratory empirical study of selected adult groups. Percept Mot Skills. 1992;75(3 Pt 2):1135-53. [pmid: 1484777].
371 Ikemi Y, Ishikawa H, Goyeche JRM, et al. Positive and negative aspects of the altered states of consciousness induced by autogenic training, Zen and yoga. Psychosom Med. 1978;30(34):170-8.
372 Irvin JHA. The effects of relaxation response training on the frequency and intensity of menopausal hot flash symptoms [abstract]. Diss Abstr Int. 1994;55(6B):2391.
373 Irwin MR, Pike JL, Oxman MN. Shingles immunity and health functioning in the elderly: tai chi chih as a behavioral treatment. Evid Based Complement Alternat Med. 2004;1(3):223-32. [pmid: 15841255]. [pmcid: 538519].
374 Ishikawa H. Scientific evaluation of oriental approaches from the viewpoint of cybernetics. Indian J Psychol. 1981;3(2):37-40.
375 Jacka J. Meditation: the most natural therapy. Melbourne, Australia: Lothian; 1990.
376 Jacobs GD. Clinical applications of the relaxation response and mind-body interventions. J Altern Complement Med. 2001;7(1 Suppl):S93-101. [pmid: 11822640].
377 Jacobs GD. A controlled, longitudinal analysis of the effects of autogenic training and the relaxation response on central nervous system activity using computerized spectral analysis of EEG activity [abstract]. Diss Abstr Int. 1988;48(11B):3445-6.
378 Jacobs GD, Benson H, Friedman R. Home-based central nervous system assessment of a multifactor behavioral intervention for chronic sleep-onset insomnia. Behav Ther. 1993;24(1):159-74.
379 Jacobs GD, Heilbronner RL, Stanley JM. The effects of short term flotation REST on relaxation: a controlled study. Health Psychol. 1984;3(2):99-112. [pmid: 6399246].
380 Jacobs GD, Rosenberg PA, Friedman R, et al. Multifactor behavioral treatment of chronic sleep-onset insomnia using stimulus control and the relaxation response: a preliminary study. Behav Modif. 1993;17(4):498-509. [pmid: 8216184].
381 Jain S, Janssen K, DeCelle S. Alexander technique and feldenkrais method: a critical overview. Phys Med Rehabil Clin N Am. 2004;15(4):811-25. [pmid: 15458754].
382 Jakubczak M. The philosophical foundations of yoga therapy. In: Tymieniecka AT, Zalewski Z, eds. Life: the human being between life and death. Dordrecht, Boston: Kluwer Academic Publishers; 2000. p. 145–51.
383 James M, Kolt GS, McConville JC, et al. The effects of a Feldenkrais program and relaxation procedures on hamstring length. Aust J Physiother. 1998;44(1):49-54. [pmid: 11676714].
384 Jancewicz A. Tai chi chuan's role in maintaining independence in ageing people with chronic disease. J Bodywork Movement Ther. 2001;5(1):70-7.
385 Jang HS, Lee MS. Effects of qi therapy (external qigong) on premenstrual syndrome: a randomized placebo-controlled study. J Altern Complement Med. 2004;10(3):456-62. [pmid: 15253849].
386 Jang HS, Lee MS, Kim MJ, et al. Effects of qi therapy on premenstrual syndrome. Int J Neurosci. 2004;114(8):909-21. [pmid: 15527198].
387 Janisse M. The therapeutic use of yoga. Orthop Phys Ther Pract. 2002;14(1):7-12.
388 Jaseja H. Meditation may predispose to epilepsy: an insight into the alteration in brain environment induced by meditation. Med Hypotheses. 2005;64(3):464-7. [pmid: 15617849].
389 Jayasinghe SR. Yoga in cardiac health. Eur J Cardiovasc Prev Rehabil. 2004;11(5):369-75. [pmid: 15616408].
390 Jedrczak A, Miller D, Antoniou M. Transcendental meditation and health: an overview of experimental research and clinical experience. Health Promot. 1987;2(4):369-76.
391 Jeon J. Death anxiety and religious affiliation: a comparative study of military personnel [dissertation]. Tulsa (OK): School of Theology and Missions Oral Roberts University; 1996.
392 Jevning RA, Wallace RK, Beidebach M. The physiology of meditation: a review: a wakeful hypometabolic integrated response. Neurosci Biobehav Rev. 1992;16(3):415-24. [pmid: 1528528].
393 Jin P. Theoretical perspectives on a form of physical and cognitive exercise tai chi. Carlton, Victoria: Australian Psychological Society Ltd; 1994. p. 135–53.
394 Jonas WB, Chez RA. Recommendations regarding definitions and standards in healing research. J Altern Complement Med. 2004;10(1):171-81. [pmid: 15025892].
395 Jonte PD. The swami and the Rorschach: spiritual practice, religious experience, and perception. Amsterdam: New York: Rodapi; 2003.
396 Jorm AF, Christensen H, Griffiths KM, et al. Effectiveness of complementary and self-help treatments for anxiety disorders. Aust Med Rec J. 2004;181(7 Suppl):S29-46.
397 Juhan A. Open floor: dance, therapy, and transformation through the 5 rhythms [dissertation]. Cincinnati, OH: Union Institute and University; 2004.
398 Kabat-Zinn J. Mindfulness-based interventions in context: past, present, and future. Clin Psychol: Sci Pract. 2003;10(2):144-56.
399 Kabat-Zinn J. Mindfulness-based stress reduction (MBSR). Constructivism Hum Sci. 2003;8(2):73-107.
400 Kabat-Zinn J. Mindfulness meditation what it is, what it isn't, and its role in health care and medicine. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 161–70.
401 Kabat-Zinn J, Hosmer D. Response to the comments of Drs Relman and Riley. Advances. 2001;17(1):70-6. [pmid: 11270071].
402 Kamilar S. A Buddhist psychology. Binghamton, NY: The Haworth Press; 2002.
403 Kang D. Psychoneuroimmunology in nursing research: a biobehavioral model. Res Nurs Health. 2003;26(6):421-3. [pmid: 14689458].
404 Kaplan S. Meditation, restoration, and the management of mental fatigue. Environ Behav. 2001;33(4):480-506.
405 Keable D. Relaxation training techniques: a review: I what is relaxation?. Br J Occup Ther. 1985;48(4):99-102.
406 Kelley PL. Stress management strategies in the workplace: a meta-analysis of stress intervention techniques [dissertation]. State College (PA): Pennsylvania State University; 1995.
407 Kelly R. Sacred sound therapy for healing, spiritual growth and meditation. Positive Health 2003;(93):13–6.
408 Kemp CA. Qigong as a therapeutic intervention with older adults. J Holist Nurs. 2004;22(4):351-73. [pmid: 15486154].
409 Kennedy JE. Yoga breathing techniques: implications for stress management, health, and psychophysiological research [unpublished manuscript]. 1990; Available at: http://jeksite.org/yoga/resp.pdf.
410 Kenney EA, Rejeski WJ, Messier SP. Managing exercise distress: the effect of broad spectrum intervention on affect, RPE, and running efficiency. Can J Sport Sci. 1987;12(2):97-105.
411 Kerr GA, Kotynia F, Kolt GS. Feldenkraiss awareness through movement and state anxiety. J Bodywork Movement Ther. 2002;6(2):102-7.
412 Kerr K. Relaxation techniques: a critical review. Crit Rev Phys Rehabil Med. 2000;12(1):51-89.
413 Kessler RS, Patterson DR, Dane J. Hypnosis and relaxation with pain patients: evidence for effectiveness. Semin Pain Med. 2003;1(2):67-78.
414 Khalsa DS. Long deep breathing. J Back Musculoskeletal Rehabil. 1998;11(2):153-6.
415 Khalsa SB. Yoga as a therapeutic intervention: a bibliometric analysis of published research studies. Indian J Physiol Pharmacol. 2004;48(3):269-85. [pmid: 15648399].
416 Kim SD, Kim HS. Effects of a relaxation breathing exercise on anxiety, depression, and leukocyte in hemopoietic stem cell transplantation patients. Cancer Nurs. 2005;28(1):79-83. [pmid: 15681986].
417 Kimura H, Nagao F, Tanaka Y, et al. Beneficial effects of the nishino breathing method on immune activity and stress level. J Altern Complement Med. 2005;11(2):285-91. [pmid: 15865494].
418 Kindlon DJ. Comparison of use of meditation and rest in treatment of test anxiety. Psychol Rep. 1983;53(3 Pt 1):931-8. [pmid: 6361836].
419 King MS, Carr T, D'Cruz C. Transcendental meditation, hypertension and heart disease. Aust Fam Physician. 2002;31(2):164-8. [pmid: 11917830].
420 Kishiyama S, Carlsen J, Lawrence J, et al. Yoga as an experimental intervention for cognition in multiple sclerosis. Int J Yoga Ther 2002;12(57–62).
421 Kita T, Yokode M, Kume N, et al. The concentration of serum lipids in Zen monks and control males in Japan. Jpn Circ J. 1988;52(2):99-104. [pmid: 3361706].
422 Klein PJ, Adams WD. Comprehensive therapeutic benefits of taiji: a critical review. Am J Phys Med Rehabil. 2004;83(9):735-45. [pmid: 15314540].
423 Kleinschnitz KW. An investigation into field effects of consciousness from the perspectives of Maharishi's vedic science and physics [dissertation]. Fairfield, IA: Maharishi International University; 1997.
424 Knight S. Use of transcendental mediation to relieve stress and promote health. Br J Nurs. 1995;4(6):315-8. [pmid: 7727948].
425 Knox SS. Effect of passive concentration as instructional set for training enhancement of EEG alpha. Percept Mot Skills. 1980;51(3 Pt 1):767-75. [pmid: 7010297].
426 Koh TC. Tai chi chuan. Am J Chin Med. 1981;9(1):15-22. [pmid: 7030051].
427 Kokinakis CL. Teaching professional standards: training yoga therapists in loving presence [abstract]. Diss Abstr Int. 1996;57(2A):0588.
428 Kokoszka A. Relaxation as an altered state of consciousness: a rationale for a general theory of relaxation. Int J Psychosom. 1992;39(14):4-9. [pmid: 1428618].
429 Kolt GS, McConville JC. The effects of a feldenkrais awareness through movement program on state anxiety. J Bodywork Movement Ther. 2000;4(3):216-20.
430 Kondwani KA, Lollis CM. Is there a role for stress management in reducing hypertension in African Americans?. Ethn Dis. 2001;11(4):788-92. [pmid: 11763303].
431 Konzak B, Boudreau F. Martial arts training and mental health: an exercise in self-help. Can Ment Health. 1984;32(4):2-8. [pmid: 10273609].
432 Kornfield JM, Walsh R. Meditation: royal road to the transpersonal. Los Angeles, CA: Jeremy P. Tarcher/Perigee; 1993.
433 Krasner M. Mindfulness-based interventions: a coming of age?. Fam Syst Health. 2004;22(2):207-12.
434 Krippner S, Maliszewski M. Meditation and the creative process. Indian J Psychol. 1978;1(1):40-58.
435 Krisanaprakornkit T, Piyavhatkul N, Krisanaprakornkit W, et al. Meditation therapy for anxiety disorders. Cochrane Database Syst Rev 2004;(4):CD004998.
436 Krishna G. Understanding transformation of consciousness. Fields Within Fields. 1974;11:12-28.
437 Krishna-Rao PV. Yoga: its scientific and applied aspects. Indian J Psychol. 1995;13(2):1-12.
438 Kristeller JL. Meditation: multiple effects, a unitary process? In: Blows M, Haruki Y, Bankart, et al. The relevance of the wisdom traditions in contemporary society: the challenge to psychology. Delft: Eburon Academic Publishers; 2004.
439 Kristeller JL, Johnson T. Science looks at spirituality: cultivating loving kindness: a two stage model of the effects of meditation on empathy, compassion, and altruism. Zygon. 2005;40(2):391-407.
440 Kristof M, Servit Z, Manas K. Activating effect of nasal air flow on epileptic electrographic abnormalities in the human EEG: evidence for the reflex origin of the phenomenon. Physiol Bohemoslov. 1981;30(1):73-7. [pmid: 6452641].
441 Kron J. Meditation. J Complement Med. 2004;3(2):32-6.
442 Krucoff MW, Crater SW, Green CL, et al. Integrative noetic therapies as adjuncts to percutaneous intervention during unstable coronary syndromes: monitoring and actualization of noetic training (MANTRA) feasibility pilot. Am Heart J. 2001;142(5):760-9. [pmid: 11685160].
443 Krucoff MW, Crater SW, Green CL, et al. Novel applications of ECG monitoring for the quantification of noetic phenomena. J Electrocardiol. 1999;32(Suppl):22.
444 Kuang AK, Wang C, Xu DH, et al. Research on “anti-aging” effect of qigong. J Tradit Chin Med. 1991;11(2):153-8. [pmid: 1861523].
445 Kuchera MM. The effectiveness of meditation techniques to reduce blood pressure levels: a meta-analysis [abstract]. Diss Abstr Int. 1987;47(11B):4639.
446 Kuna DJ. Meditation and work. Vocational Guidance Q. 1975;23(4):342-6.
447 Kurtz R. Foundations of Hakomi therapy. Hakomi Forum 1985;3–7.
448 Kurtz R. On the uniqueness of Hakomi. Hakomi Forum 1987;(5):2–8.
449 Kurup J. Role of yoga vasthi in the treatment of gridhrasi. Rheumatism. 1989;25(1):52-4.
450 Kutz I, Borysenko JZ, Benson H. Meditation and psychotherapy: a rationale for the integration of dynamic psychotherapy, the relaxation response, and mindfulness meditation. Am J Psychiatry. 1985;142(1):1-8.
451 La Flamme DM. Holotropic breathwork and altered states of consciousness [abstract]. Diss Abstr Int. 1994;55(2B):597.
452 La Forge R. Mind-body fitness: encouraging prospects for primary and secondary prevention. J Cardiovasc Nurs. 1997;11(3):53-65. [pmid: 9095454].
453 Ladd KL, Spilka B. Inward, outward, and upward: cognitive aspects of prayer. J Sci Study Relig. 2002;41(3):475-84.
454 Laird SP. A preliminary investigation into the role of prayer as a coping technique for adult patients with arthritis [abstract]. Diss Abstr Int. 1993;54(1B):476.
455 Laird SP, Snyder CR, Rapoff MA, et al. Measuring private prayer: development, validation, and clinical application of the multidimensional prayer inventory. Int J Psychol Relig. 2004;14(4):251-72.
456 Lake J. Qigong. In: Shannon S, ed. Handbook of complementary and alternative medicines in mental health. San Diego, CA: Academic Press; 2001.
457 Lan C, Lai JS, Chen SY. Tai chi chuan: an ancient wisdom on exercise and health promotion. Sports Med. 2002;32(4):217-24. [pmid: 11929351].
458 Landsman-Dijkstra JJA, Van Wijck R, Groothoff JW, et al. The short-term effects of a body awareness program: better self-management of health problems for individuals with chronic a-specific psychosomatic symptoms. Patient Educ Couns. 2004;55(2):155-67. [pmid: 15530750].
459 Langer EJ, Piper A. Television from a mindful/mindless perspective. Appl Soc Psychol Ann. 1988;8:247-60.
460 Lantz MS, Buchalter EN, McBee L. The wellness group: a novel intervention for coping with disruptive behavior among elderly nursing home residents. Gerontologist 1997;37(4):551–6. Erratum in: Gerontologist 1997;37(5):687.
461 Larkin M. Meditation may reduce heart attack and stroke risk. Lancet. 2000;355(9206):812.
462 Lasater J. Down in the back: poses for lower back pain. Altern Ther Health Med. 1995;1(5):72-82. [pmid: 9359775].
463 Lavery LL, Studenski SA. Tai chi, falls, and the heritage of JAGS. J Am Geriatr Soc. 2003;51(12):1804-5. [pmid: 14687361].
464 Lazarus AA. Psychiatric problems precipitated by transcendental meditation. Psychol Rep. 1976;39(2):601-2. [pmid: 790439].
465 Lee M. Phoenix rising yoga therapy: a bridge from body to soul. Deerfield Beach, FL: Health Communications Inc; 1997.
466 Lee MS, Huh HJ, Hong SS, et al. Psychoneuroimmunological effects of qi-therapy: preliminary study on the changes of level of anxiety, mood, cortisol and melatonin and cellular function of neutrophil and natural killer cells. Stress Health. 2001;17(1):17-24.
467 Lee MS, Jang JW, Jang HS, et al. Effects of qi-therapy on blood pressure, pain and psychological symptoms in the elderly: a randomized controlled pilot trial. Complement Ther Med. 2003;11(3):159-64. [pmid: 14659379].
468 Lee MS, Rim YH, Kang CW. Effects of external qi-therapy on emotions, electroencephalograms, and plasma cortisol. Int J Neurosci. 2004;114(11):1493-502. [pmid: 15636358].
469 Lee Y, Hu PC. The effect of Chinese qi-gong exercises and therapy on diseases and health. Indian J Psychol. 1993;11(12):9-18.
470 Lee YH. Discovering the essential power of t'ai chi ch'uan: the yin and yang of leadership [dissertation]. San Antonia, TX: University of the Incarnate Word; 2002.
471 Lehrer PM, Hochron SM, Mayne T, et al. Relationship between changes in EMG and respiratory sinus arrhythmia in a study of relaxation therapy for asthma. Appl Psychophysiol Biofeedback. 1997;22(3):183-91. [pmid: 9428968].
472 Lekander M, Furst CJ, Rotstein S, et al. Immune effects of relaxation during chemotherapy for ovarian cancer. Psychother Psychosom. 1997;66(4):185-91. [pmid: 9259041].
473 Lepicovska V, Dostalek C, Vlcek M. Vasomotor changes effected by breathing manoeuvres. Act Nerv Super (Praha). 1983;25(3):195-6.
474 Lerner M. Choices in healing: integrating the best of conventional and complementary approaches to cancer. Cambridge (MA): MIT Press; 1994.
475 Leserman J, Stuart EM, Mamish ME, et al. The efficacy of the relaxation response in preparing for cardiac surgery. Behav Med. 1989;15(3):111-7. [pmid: 2676027].
476 Lester D. Transcendental meditation in correctional settings: a review and discussion. Correct Soc Psych J Behav Tech Methods Ther. 1982;28(2):63-4.
477 Levin JS. How prayer heals: a theoretical model. Altern Ther Health Med. 1996;2(1):66-73.
478 Lewis DE. T'ai chi ch'uan. Complement Ther Nurs Midwifery 2000;(4):204–6.
479 Li F, Fisher KJ, Harmer P, et al. A simpler eight-form easy tai chi for elderly adults. J Aging Phys Act. 2003;11(2):206-18.
480 Li JX, Hong Y, Chan KM. Tai chi: physiological characteristics and beneficial effects on health. Br J Sports Med. 2001;35(3):148-56. [pmid: 11375872]. [pmcid: 1724328].
481 Lichstein K, English. Clinical relaxation strategies. Oxford, England: John Wiley & Sons; 1988.
482 Lilie JK, Rosenberg RP. Behavioral treatment of insomnia. Prog Behav Modif. 1990;25:152-77. [pmid: 2274460].
483 Lindsay WR, Richardson I, Michie AM. Short-term generalised effects of relaxation training on adults with moderate and severe mental handicaps. Ment Handicap Res. 1989;2(2):197-206.
484 Lipinski B. Biological significance of piezoelectricity in relation to acupuncture, hatha-yoga, osteopathic medicine and action of air ions. Med Hypotheses. 1977;3(1):9-12. [pmid: 577004].
485 Lo PC, Leu JS. Adaptive baseline correction of meditation EGG. Am J Electroneurodiagnostic Technol. 2001;41(2):142-55.
486 Loew TH, Tritt K, Siegfried W, et al. Efficacy of ‘functional relaxation’ in comparison to terbutaline and a ‘placebo relaxation’ method in patients with acute asthma: a randomized, prospective, placebo-controlled, crossover experimental investigation. Psychother Psychosom. 2001;70(3):151-7. [pmid: 11340417].
487 Logsdon-Conradsen S. Using mindfulness meditation to promote holistic health in individuals with HIV/AIDS. Cogn Behav Pract. 2002;9(1):67-72.
488 Lohman R. Yoga techniques applicable within drug and alcohol rehabilitation programmes. Therap Communities: Int J Therap Support Organ. 1999;20(1):61-72.
489 Loveland MT, Sikkink DMDJ, Radcliff B. Private prayer and civic involvement. J Sci Study Relig. 2005;44(1):1-14.
490 Lowenstein KG. Meditation and self-regulatory techniques. In: Shannon S, ed. Handbook of complementary and alternative therapies in mental health. San Diego, CA: Academic Press; 2002. p. 159–80.
491 Lundh LG. An integrative model for the analysis and treatment of insomnia. Scandinavian J Behav Ther. 2000;29(34):118-26.
492 Luskin F. Transformative practices for integrating mind-body-spirit. J Altern Complement Med. 2004;10(1 Suppl):S15-23. [pmid: 15630819].
493 Luskin FM, Newell KA, Griffith M, et al. A review of mind-body therapies in the treatment of cardiovascular disease part 1: implications for the elderly. Altern Ther Health Med. 1998;4(3):46-61. [pmid: 9581321].
494 Lyttle TSK. The feldenkrais method: application, practice and principles. J Bodywork Movement Ther. 1997;1(5):262-9.
495 Machacova H. Psychological control of stress: relaxation—activation method. Homeost Health Dis. 1997;38(2):83-4.
496 MacIntosh A, Ball K. The effects of a short program of detoxification in disease-free individuals. Altern Ther Health Med. 2000;6(4):70-6.
497 Maex E, Zoeteman M, Remie M, et al. Meditation as supportive therapy. Psychooncology. 1999;8(6 Suppl):41.
498 Magarey C. Healing and meditation in medical-practice. Aust Med Rec J. 1981;1(7):338.
499 Magill DL. Cost savings from teaching the transcendental meditation program in prisons. J Offender Rehabil. 2003;36(14):319-31.
500 Mahal AS, Ramu NG, Chaturvedi DD, et al. Double blind controlled study of brahmyadiyoga and tagara in the management of various types of unmada (schizophrenia). Indian J Psychiatry. 1976;18(4):283-92.
501 Maier-Lorentz MM. The importance of prayer for mind/body healing. Nurs Forum. 2004;39(3):23-32.
502 Malmgren-Olsson E, Armelius B, Armelius K. A comparative outcome study of body awareness therapy, feldenkrais, and conventional physiotherapy for patients with nonspecific musculoskeletal disorders: changes in psychological symptoms, pain, and self-image. Physiother Theory Pract. 2001;17(2):77-95.
503 Maltby J. Personality, prayer, and church attendance among US female adults. J Soc Psychol. 1995;135(4):529-31.
504 Mamtani R, Cimino A. A primer of complementary and alternative medicine and its relevance in the treatment of mental health problems. Psychiatr Q. 2002;73(4):367-81. [pmid: 12418362].
505 Mamtani R, Mamtani R. Ayurveda and yoga in cardiovascular diseases. Cardiol Rev. 2005;13(3):155-62. [pmid: 15834238].
506 Mancini J, Lavecchia C, Clegg R. Graduate nursing students and stress. J Nurs Educ. 1983;22(8):329-34. [pmid: 6319633].
507 Mandle CL, Jacobs SC, Arcari PM, et al. The efficacy of relaxation response interventions with adult patients: a review of the literature. J Cardiovasc Nurs. 1996;10(3):4-26. [pmid: 8820317].
508 Manley HJ, Bailie GR, Grabe DW. Comparing meditation use in two hemodialysis units against national dialysis databases. Am J Health Syst Pharm. 2000;57(9):902-6. [pmid: 10840531].
509 Mann GV. Dietary intake, the first law of thermodynamics, and the properties of yoga. JAMA. 1986;255(9):1136-7. [pmid: 3945027].
510 Mannerkorpi K. Exercise in fibromyalgia. Curr Opin Rheumatol. 2005;17(2):190-4. [pmid: 15711234].
511 Manocha R. Why meditation?. Aust Fam Physician. 2000;29(12):1135-8. [pmid: 11140217].
512 Marcus DA, Scharff L, Turk DC. Nonpharmacological management of headaches during pregnancy. Psychosom Med. 1995;57(6):527-35. [pmid: 8600478].
513 Marcus JB. Transcendental meditation: a new method of reducing drug abuse. Drug Forum. 1974;3(2):113-36.
514 Marcus JB. Transcendental meditation: consciousness expansion as a rehabilitation technique. J Psychedelic Drugs. 1975;7(2):169-79.
515 Marks I, Dar R. Fear reduction by psychotherapies: recent findings, future directions. Br J Psychiatry. 2000;176:507-11. [pmid: 10974952].
516 Markula P. “Tuning into one's self”: foucault's technologies of the self and mindful fitness. Sociol Sport J. 2004;21(3):302-21.
517 Marlatt GA, Kristeller JL. Mindfulness and meditation. Washington, DC: American Psychological Association Books; 1999.
518 Marlatt GA, Witkiewitz K, Dillworth TM, et al. Vipassana meditation as a treatment for alcohol and drug use disorders. In: Hayes SCE, Follette VH, Linehan MM, eds. Mindfulness and acceptance: expanding the cognitive-behavioral tradition. New York: Guilford Press; 2004. Chapter 12.
519 Marler JD. Description of response, relaxation training, and directed imagery as adjuncts to biofeedback training: effects on subsequent hand temperature control [abstract]. Diss Abstr Int. 1978;39(4B):1963.
520 Martin JE, Carlson CR. Spiritual dimensions of health psychology. In: Miller WR, Martin JE, eds. Behavior therapy and religion: integrating spiritual and behavioral approaches to change. Newbury Park, CA: Sage Press; 1988. p. 57–110.
521 Matsumoto M, Smith JC. Progressive muscle relaxation, breathing exercises, and ABC relaxation theory. J Clin Psychol. 2001;57(12):1551-7. [pmid: 11745596].
522 Mayer M. Qigong and hypertension: a critique of research. J Altern Complement Med. 1999;5(4):371-82. [pmid: 10471018].
523 McCaffrey R, Fowler NL. Qigong practice: a pathway to health and healing. Holist Nurs Pract. 2003;17(2):110-6. [pmid: 12701998].
524 McCarberg B, Wolf J. Chronic pain management in a health maintenance organization. Clin J Pain. 1999;15(1):50-7. [pmid: 10206567].
525 McCarthy M. Yoga in the heartland. Lancet. 1993;342(8867):357-8. [pmid: 8101593].
526 McClernon FJ, Westman EC, Rose JE. The effects of controlled deep breathing on smoking withdrawal symptoms in dependent smokers. Addict Behav. 2004;29(4):765-72. [pmid: 15135559].
527 McCormack GL. The therapeutic benefits of the relaxation response. Occup Ther Pract. 1992;4(1):51-60.
528 McCracken LM, Carson JW, Eccleston C, et al. Acceptance and change in the context of chronic pain. Pain. 2004;109(12):4-7. [pmid: 15082120].
529 McCullough ME, Larson DB. Prayer. Washington, DC: American Psychological Association Books; 1999.
530 McDowell B. Mind body medicine: from the relaxation response to mindfulness. Altern Complement Ther. 1995;1(2):80-7.
531 McKenna M. The application of tai chi chuan in rehabilitation and preventive care of the geriatric population. Phys Occup Ther Geriatr. 2001;18(4):23-34.
532 McPeake JD, Kennedy BP, Gordon SM. Altered states of consciousness therapy a mission component in alcohol and drug rehabilitation treatment. J Subst Abuse Treat. 1991;8(12):75-82. [pmid: 2051500].
533 Meares A. A form of intensive meditation associated with the regression of cancer. Am J Clin Hypn. 1983;25(23):114-21.
534 Meares A. Regression of osteogenic sarcoma metastases associated with intensive meditation. Aust Med Rec J. 1978;2(9):433.
535 Meares A. Relief of cancer by meditation. Aust Med Rec J. 1975;2(17):689.
536 Meares A. Stress, meditation and the regression of cancer. Practitioner. 1982;226(1371):1607-9. [pmid: 6755432].
537 Medicate and meditate. Pharm J 2003;270(7256):28.
538 Mees PD. Yoga participation surges: exploring the clinical implications. Phys Sportsmed. 2005;33(5):12-5.
539 Meier D. Imagine that. Train Dev J. 1984;38(5):26-9.
540 Melmed RN, Roth D, Weinstock-Rosin M, et al. The influence of emotional state on the mobilization of marginal pool leukocytes after insulin-induced hypoglycemia: a possible role for eicosanoids as major mediators of psychosomatic processes. Ann N Y Acad Sci. 1987;496:467-76. [pmid: 3300473].
541 Merrill C, Andersen S. Person centred expressive therapy: an outcome study. In: Brazier D, ed. Beyond Carl Rogers. London: Constable & Robinson; 1993. p. 109–28.
542 Meuhlman M. Transcendental meditation. N Engl J Med. 1977;297(9):513.
543 Mihailescu V, Mihailescu G, Perlman AI, et al. Evolving approaches to management of osteoarthritis. Drug Benefit Trends. 2004;16(Suppl C):29-35.
544 Mikulas W. Behaviors of the mind, meditation, and health. In: Haruki Y, Kaku KT, eds. Meditation as Health Promotion: A Lifestyle Modification Approach. Proceedings of the 6th Conference; 2000 Jul 20–21; Noordwijkerhout, The Netherlands. Delft, Netherlands: Eburon Publishers; 2000. p. 32–49.
545 Miller D. The effects of relaxation training on the frequency of binge episodes. In: Proceedings of the 58th Annual Scientific Conference of the American Psychosomatic Society; 2000 March 1–4; Savannah, GA [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1. Abstract 1183.
546 Mitchell JL III. Martin Heidegger's meditative thinking and theravada Buddhist mindfulness: going towards a psychological interface (theravada Buddhism) [dissertation]. San Francisco: California Institute of Integral Studies; 2003.
547 Mitchell KR, White RG. Self-management of severe predormital insomnia. J Behav Ther Exp Psychiatry. 1977;8(1):57-63.
548 Mohan J. Stress management and yoga. Int J Psychol. 1996;31(34):1818.
549 Mohan SM. Svara (nostril dominance) and bilateral volar GSR. Indian J Physiol Pharmacol 1996;40(1):58–64. Erratum in: Indian J Physiol Pharacol 1996 Oct;40(4):391.
550 Molassiotis A, Maneesakorn S. Quality of life, coping and psychological status of Thai people living with AIDS. Psychol Health Med. 2004;9(3):350-61.
551 Monro R. Yoga therapy. J Bodywork Movement Ther. 1997;1(4):215-8.
552 Moriconi CB. A systemic treatment program of mindfulness meditation for fibromyalgia patients and their partners [dissertation]. Philadelphia, PA: La Salle University; 2003.
553 Morris EL. The relationship of spirituality to coronary heart disease. Altern Ther Health Med. 2001;7(5):96-8.
554 Morse DR. An exploratory study of the use of meditation alone and in combination with hypnosis in clinical dentistry. J Am Soc Psychosom Dent Med. 1977;24(4):113-20. [pmid: 338563].
555 Moss D, O'Niell B. Just another technique? Possibilities and paradoxes in working with mindfulness. Clin Psychol. 2003;31:29-33.
556 Moyer L. The context for Hakomi in the treatment of eating disorders. Hakomi Forum 1986;(4):33–41.
557 Mueller D. Yoga therapy. ACSMS Health Fitness J. 2002;6(1):18-24.
558 Mueller KM. The psychological effects of a “meditative therapy”. Int J Psychol. 1996;31(34):45438.
559 Mullen K. Pleasing to behold: healing and the visualized body. Ment Health Religion Cult. 2001;4(2):119-32.
560 Murakawa H. Phenomenology of the experience of qigong: a preliminary research design for the intentional bodily practices [dissertation]. San Francisco: California Institute for Integral Studies; 2002.
561 Muramoto S. Buddhism, religion and psychotherapy in the world today. In: Young-Eisendrath P, Muramoto S, eds. Awakening and insight: Zen Buddhism and psychotherapy. New York: Taylor & Francis Group/Brunner-Routledge; 2002. p. 15–29.
562 Murase T, Johnson F. Naikan, Morita, and Western psychotherapy: a comparison. Arch Gen Psychiatry. 1974;31(1):121-8. [pmid: 4835992].
563 Murphy LR. Occupational stress management: a review and appraisal. J Occup Psychol. 1984;57(1):1-15.
564 Murray JB. What is meditation? Does it help?. Genet Psychol Monogr. 1982;106(1):85-115.
565 Myers MJ. Psychological and other scientific perspectives of the new paradigm providing a rationale for meditation techniques in consciousness development [abstract]. Diss Abstr Int. 1985;46(6A):1553.
566 Naga-Venkatesha-Murthy PJ, Gangadhar BN, Janakiramaiah N, et al. Normalization of P300 amplitude following treatment in dysthymia. Biol Psychiatry. 1997;42(8):740-3. [pmid: 9325569].
567 Narayanan J, Krishnan VR. Impact of sativa and rajas gunas on transformational leadership and karma yoga. Indian J Psychol. 2003;21(2):1-11.
568 Nash JM. Psychologic and behavioral management of tension-type headache: treatment procedures. Curr Pain Headache Rep. 2003;7(6):475-81. [pmid: 14604507].
569 Nathan JH. Sitting, laboring, and changing: a critical examination of the indigenous Japanese psychotherapies. Psychologia: Int J Psychol Orient. 1990;33(3):163-70.
570 Naveen KV. Yoga and psychosis: risks and therapeutic potential. Indian J Psychol. 2003;21(1):34-7.
571 Naveen KV, Telles S. Sensory perception during sleep and meditation: common features and differences. Percept Mot Skills. 2003;96(3 Pt 1):810-1. [pmid: 12831256].
572 Nayak NN, Shankar K. Yoga: a therapeutic approach. Phys Med Rehabil Clin N Am 2004;15(4):783–98, vi.
573 Nelson MO, Jarratt K. Spiritual and mental health care of persons with AIDS. Individual Psychol: J Adlerian Theory Res Pract. 1987;43(4):479-89.
574 Nespor K. The combination of psychiatric treatment and yoga. Int J Psychosom. 1985;32(2):24-7.
575 Nespor K. Pain management and yoga. Int J Psychosom. 1991;38(14):76-81. [pmid: 1723397].
576 Nespor K. Psychosomatics of back pain and the use of yoga. Int J Psychosom. 1989;36(14):72-8. [pmid: 2532183].
577 Nespor K. Yoga in addictive diseases: practical experience. Alcologia. 2001;13(1):21-5.
578 Neuberg A. Bridging secular and spiritual approaches to neurotic misery and everyday unhappiness: a dialogue between psychoanalysis and Jewish and Zen Buddhist mystical traditions [dissertation]. New York: New York University; 2003.
579 Newberg AB. The neuropsychology of ritual and meditative states. Psyche En Geloof. 2002;13(4):174-84.
580 Newberg AB, Iversen J. The neural basis of the complex mental task of meditation: neurotransmitter and neurochemical considerations. Med Hypotheses. 2003;61(2):282-91. [pmid: 12888320].
581 Newman BY. Meditation as therapy. Optometry. 2000;71(9):555. [pmid: 11016245].
582 Ng BY. Qigong-induced mental disorders: a review. Aust N Z J Psychiatry. 1999;33(2):197-206. [pmid: 10336217].
583 Nicholas PK, Webster A. A behavioral medicine intervention in persons with HIV. Clin Nurs Res. 1996;5(4):391-406. [pmid: 8970278].
584 Nicolson DJ, Dickinson HO, Campbell F, et al. Relaxation therapies for the management of essential hypertension in adults. Cochrane Database of Systematic Reviews. 2004(3): CD004935.
585 Nidich SI, Nidich RJ, Alexander CN. Moral development and higher states of consciousness. J Adult Dev. 2000;7(4):217-25.
586 Noe A. Self psychology, buddhism, and mindfulness meditation: an integrated conceptualization and treatment approach for women experiencing post-abortion distress [dissertation]. Chicago (IL): Chicago School of Professional Psychology; 2004.
587 Nonsurgical treatment is effective for carpal tunnel syndrome. J Fam Pract 2004;53(9):685.
588 Norton GR, Johnson WE. A comparison of two relaxation procedures for reducing cognitive and somatic anxiety. J Behav Ther Exp Psychiatry. 1983;14(3):209-14. [pmid: 6358264].
589 Novick PK. A phenomenological inquiry into the experience and sources of meaning-perspective shift among participants in a ten-session holistic health program [dissertation]. Cincinnati: Union Institute University; 1994.
590 O'Connell DF, Alexander CN. Introduction: recovery from addictions using transcendental meditation and Maharishi ayur-veda. Alcohol Treat Q. 1994;11(12):1-10.
591 O'Connor D, Marshall S, Massy-Westropp N. Non-surgical treatment (other than steroid injection) for carpal tunnel syndrome. Cochrane Database Syst Rev 2003;(1):CD003219.
592 O'Connor PJ, Pronk NP, Tan A, et al. Characteristics of adults who use prayer as an alternative therapy. Am J Health Promot. 2005;19(5):369-75. [pmid: 15895540].
593 O'Hara DP. Is there a role for prayer and spirituality in health care?. Med Clin North Am. 2002;86(1):33-46. [pmid: 11795089].
594 O'Murchu D. Spirituality, recovery, and transcendental meditation. Alcohol Treat Q. 1994;11(12):169-84.
595 O'Neill LM, Barnier AJ, McConkey K. Treating anxiety with self-hypnosis and relaxation. Contemp Hypn. 1999;16(2):68-80.
596 Oman D, Beddoe AE. Health interventions combining meditation with learning from spiritual exemplars: conceptualization and review. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [cited 2005 Oct 10]. Available at: http://www.sbm.org/meeting/2005/SBM_fp05.pdf. Society of Behavioral Medicine Annual Meeting. Paper Session #25.
597 Oman D, Driskill JD. Holy name repetition as a spiritual exercise and therapeutic technique. J Psychol Christianity. 2003;22(1):5-19.
598 Omura Y. Storing of qi gong energy in various materials and drugs (qi gongnization): its clinical application for treatment of pain, circulatory disturbance, bacterial or viral infections, heavy metal deposits, and related intractable medical problems by selectively enhancing circulation and drug uptake. Acupunct Electrother Res. 1990;15(2):137-57. [pmid: 1978504].
599 Opat AJ, Cohen MM, Bailey MJ, et al. A clinical trial of the Buteyko breathing technique in asthma as taught by a video. J Asthma. 2000;37(7):557-64. [pmid: 11059522].
600 Orme-Johnson DW. An overview of Charles Alexander's contribution to psychology: developing higher states of consciousness in the individual and the society. J Adult Dev. 2000;7(4):199-215.
601 Orme-Johnson DW. Preventing crime through the Maharishi Effect. J Offender Rehabil. 2003;36(14):257-81.
602 Orme-Johnson DW. Transcendental meditation as an epidemiological approach to drug and alcohol abuse: theory, research, and financial impact evaluation. Alcohol Treat Q. 1994;11(12):119-68.
603 Orme-Johnson DW. Transcendental meditation does not predispose to epilepsy. Med Hypotheses. 2005;65(1):201-2. [pmid: 15893150].
604 Orme-Johnson DW, Herron RE. An innovative approach to reducing medical care utilization and expenditures. Am J Manag Care. 1997;3(1):135-44. [pmid: 10169245].
605 Orme-Johnson DW, Zimmerman E, Hawkins MA. Maharishi's vedic psychology: the science of the cosmic psyche. In: Kao HSR, Sinha D, ed. Asian perspectives on psychology. New Delhi, India: Sage Publications; 1997. p. 282–308.
606 Ormrod J, Budd R. A comparison of 2 treatment interventions aimed at lowering anxiety levels and alcohol-consumption amongst alcohol abusers. Drug Alcohol Depend. 1991;27(3):233-43. [pmid: 1884666].
607 Osowiec DA. Yogic breathwork and ultradian hypnosis. In: Leskowitz ED, ed. Transpersonal hypnosis: gateway to body, mind and spirit. Boca Raton, LA: CRC Press; 2000. p. 71–84.
608 Ost LG. Applied relaxation in the treatment of panic disorder. Scandinavian J Behav Ther. 1988;17(2):111-24.
609 Ost LG. Applied relaxation vs progressive relaxation in the treatment of panic disorder. Behav Res Ther. 1988;26(1):13-22. [pmid: 3277613].
610 Otani A. Eastern meditative techniques and hypnosis: a new synthesis. Am J Clin Hypn. 2003;46(2):97-108. [pmid: 14609296].
611 Ott MJ. Mindfulness meditation: a path of transformation and healing. J Psychosoc Nurs Ment Health Serv. 2004;42(7):22-9.
612 Owoeye IO. Samadhi tank: a floatcell for enhancement of learning and management of stress and some painful conditions. J Nigeria Soc of Physiother. 1994;12(2):46-59.
613 Oyao DA. Implementation of yoga therapy for peak athletic performance training. J Sports Chiropractic Rehabil. 1996;10(3):123-9.
614 Paradarami D. Yoga as neuropsychological modifier. Int J Psychol. 2004;39(56 Suppl):377.
615 Paranjpe AC. Parapsychology and patanjali's yoga. Indian J Psychol. 1985;4(2):13-20.
616 Parati G, Steptoe A. Stress reduction and blood pressure control in hypertension: a role for transcendental meditation?. J Hypertens. 2004;22(11):2057-60. [pmid: 15480086].
617 Park M, Park Y, Chang S, et al. Effects of qigong on the concentration of free radicals in blood. J Int Soc Life Inf Sci. 2000;18(2):358-60.
618 Parshad O. Role of yoga in stress management. West Indian Med J. 2004;53(3):191-4. [pmid: 15352751].
619 Patel CH. 12-month follow-up of yoga and biofeedback in the management of hypertension. Lancet. 1975;1(7898):62-4. [pmid: 46021].
620 Patel CH. Yoga and biofeedback in the management of hypertension. J Psychosom Res. 1975;19(56):355-60. [pmid: 1214232].
621 Patel CH, Carruthers ME. Coronary risk factor reduction through biofeedback-aided relaxation and meditation. J R Coll Gen Pract. 1977;27(180):401-5. [pmid: 330850]. [pmcid: 2158147].
622 Patel CH, Datey KK. Relaxation and biofeedback techniques in the management of hypertension. Angiology. 1976;27(2):106-13. [pmid: 802884].
623 Pathak MP, Mishra LS. Rehabilitation of mentally retarded through yoga therapy. Child Psychiatry Q. 1984;17(4):153-8.
624 Paul GL, Trimble RW. Recorded vs. “live” relaxation training and hypnotic suggestion: comparative effectiveness for reducing physiological arousal and inhibiting stress response. Behav Ther. 1970;1(3):285-302.
625 Pearl JH. The effects of TM-Sidhi meditation on nearby, non-meditating subjects. Indian J Psychol. 1986;5(1):24-31.
626 Pearson CA. The supreme awakening: Maharishi's model of higher states of consciousness applied to the experiences of individuals through history (Maharishi Mahesh Yogi) [dissertation]. Fairfield, IA: Maharishi International University; 2002.
627 Pekala RJ. The phenomenology of meditation. In: West MA, ed. The psychology of meditation. Oxford: Clarendon Press; 1990. p. 59–80.
628 Pekala RJ, Forbes EJ. Subjective effects of several stress management strategies: with reference to attention. Behav Med. 1990;16(1):39-43. [pmid: 2182141].
629 Pekala RJ, Levine RL. Quantifying states of consciousness via an empirical-phenomenological approach. Imagination Cogn Pers. 1983;2(1):51-71.
630 Pekala RJ, Wenger CF, Levine RL. Individual differences in phenomenological experience: states of consciousness as a function of absorption. J Pers Soc Psychol. 1985;48(1):125-32. [pmid: 3884768].
631 Perez de Albeniz A, Holmes J. Meditation: concepts, effects and uses in therapy. Int J Psychother. 2000;5(1):49-58.
632 Perry GH. The effects of breathing exercises and progressive relaxation on anxiety among newly-abstinent alcoholics [abstract]. Diss Abstr Int. 1985;46(5A):1196.
633 Peterson C, Monti DA. Mindfulness-mased art therapy (Mbat) for persons with cancer. Psychooncology. 2005;14(1 Suppl):S24-5.
634 Pettinati PM. Meditation, yoga, and guided imagery. Nurs Clin North Am. 2001;36(1):47-56. [pmid: 11342401].
635 Piazza-Waggoner CA, Cohen LL, Kohli K, et al. Stress management for dental students performing their first pediatric restorative procedure. J Dent Educ. 2003;67(5):542-8. [pmid: 12809189].
636 Piggins D, Morgan D. Note upon steady visual fixation and repeated auditory stimulation in meditation and the laboratory. Percept Mot Skills. 1977;44(2):357-8. [pmid: 325495].
637 Pilkington K, Kirkwood G, Rampes H, et al. Yoga for depression: the research evidence. J Affect Disord. 2005;89(13):13-24. [pmid: 16185770].
638 Plummer JP. Acupuncture and homeostasis: physiological, physical (postural) and psychological. Am J Chin Med. 1981;9(1):1-14. [pmid: 7304495].
639 Pollard I. Meditation and brain function: a review. Eubios J Asian Int Bioethics. 2004;14:28-34.
640 Poloma MM, Pendleton BF. The effects of prayer and prayer experiences on measures of general well-being. J Psychol Theol. 1991;19(1):71-83.
641 Pookayaporn J. Wisdom and compassion in action: theravada Buddhist nuns as facilitators of healing [dissertation]. San Francisco: California Institute for Integral Studies; 2002.
642 Poppen R, Wu JH. Physiological and psychological effects of tai chi practice. Biofeedback Self Regul. 1996;21(4):380.
643 Potts SG, Lewin R, Fox KAA, et al. Group psychological treatment for chest pain with normal coronary arteries. Qjm: Monthly J Assoc Physicians. 1999;92(2):81-6.
644 Prestwood K, Petrovic K, Kerins G. Complementary and alternative medicine for older adults with intellectual disabilities. Conn Med. 2004;68(8):505-6. [pmid: 15468621].
645 Proulx K. Integrating mindfulness-based stress reduction. Holist Nurs Pract. 2003;17(4):201-8. [pmid: 12889548].
646 Purdy M. Spiritual variations: developing a death perspective and its effects on quality of life [dissertation]. Reno: University of Nevada; 2004.
647 Qian M. Taijiquan, human mental activity and health. In: Haruki Y, Kaku KT, eds. Meditation as Health Promotion: A Lifestyle Modification Approach. Proceedings of the 6th Conference; 2000 Jul 20–21; Noordwijkerhout, The Netherlands. Delft, Netherlands: Eburon Publishers; 2000. p. 50–64.
648 Rachman AW. Clinical meditation in groups. Psychother: Theory Res Pract. 1981;18(2):252-8.
649 Radford J. What can we learn from Zen? a review and some speculations. Psychologia: Int J Psychol Orient. 1976;19(2):57-66.
650 Raghuraj P, Telles S. Effect of yoga-based and forced uninostril breathing on the autonomic nervous system. Percept Mot Skills. 2003;96(1):79-80. [pmid: 12705513].
651 Rainforth M, Schneider RH, Nidich SI, et al. Meditation in the prevention and treatment of cardiovascular disease: a review of controlled clinical research on the transcendental meditation program. In: Proceedings of the 60th Annual Scientific Conference of the American Psychosomatic Society; 2002 March 13–16; Barcelona, Spain [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1. Abstract 1774.
652 Rajagopal D, Mackenzie E, Bailey C, et al. The effectiveness of a spiritually-based intervention to alleviate subsyndromal anxiety and minor depression among older adults. J Relig Health. 2002;41(2):153-66.
653 Rajeswari KR, Satyanarayana M, Narayan PV, et al. Effect of extremely low frequency magnetic field on serum cholinesterase in humans and animals. Indian J Exp Biol. 1985;23(4):194-7. [pmid: 3908300].
654 Rajski P. Finding God in the silence: contemplative prayer and therapy. J Relig Health. 2003;42(3):181-90.
655 Ram FS, Holloway EA, Jones PW. Breathing retraining for asthma. Respir Med. 2003;97(5):501-7. [pmid: 12735667].
656 Ramachandran NP, Vijayan NP, Bhagavathy-Amma KC, et al. Action of sahacharadi yoga in khanja and pangu. Ancient Sci Life. 1984;4(1):20-7.
657 Ramaratnam S. Yoga for epilepsy: methodological issues. Seizure. 2001;10(1):3-6. [pmid: 11181092].
658 Ramaratnam S, Sridharan K. Yoga for epilepsy. Cochrane Database Syst Rev 2000;(3):CD001524.
659 Ramberg JBT. The effects of reading the Vedic literature on personal evolution in the light of Maharishi Vedic science and technology [dissertation]. Fairfield, IA: Marharishi International University; 1999.
660 Rao A. Supporting Australians with cancer: a critical review of complementary therapies in oncology. Cancer Forum. 2004;28(2):88-91.
661 Rao KR. Meditation: secular and sacred: a review and assessment of some recent research. J Indian Acad Appl Psychol. 1989;15(2):51-74.
662 Rasmussen LB. Medical effects of transcendental meditation. Tidsskr Nor Laegeforen. 2002;122(2):220. [pmid: 11873589].
663 Raub JA. Psychophysiologic effects of hatha yoga on musculoskeletal and cardiopulmonary function: a literature review. J Altern Complement Med. 2002;8(6):797-812. [pmid: 12614533].
664 Rawson JR, Bhatnagar NS, Schneider HG. Initial relaxation response: personality and treatment factors. Psychol Rep. 1985;57(3 Pt 1):827-30. [pmid: 3909188].
665 Ray TK. Hatha yoga: an exercise in biofeedback for youthful health. Appl Psychophysiol Biofeedback. 2002;27(4):316.
666 Reed H. Improved dream recall associated with meditation. J Clin Psychol. 1978;34(1):150-6.
667 Regner VA. Reexamining Christian conversion experiences: considering kundalini awakenings and spiritual emergencies [dissertation]. Claremont, CA: Claremont School of Theology; 1998.
668 Reinecke MA, Davison MR. Comparative treatments of depression: entering the Zen garden. In: Reinecke MA, Davison MR, eds. Comparative treatments of depression. New York: Springer Publishing; 2002. p. 453–63.
669 Reinemann D. ROM dance: a treatment for symptoms of depression and anxiety in adults with mental retardation [dissertation]. DeKalb, IL: Northern Illinois University; 1999.
670 Reza MF, Urakami Y, Mano Y. Evaluation of a new physical exercise taken from salat (prayer) as a short-duration and frequent physical activity in the rehabilitation of geriatric and disabled patients. Ann Saudi Med. 2002;22(34):177-80. [pmid: 17159390].
671 Rickard HC, Thrasher KA, Elkins PD. Responses of persons who are mentally retarded to four components of relaxation instruction. Ment Retard. 1984;22(5):248-52. [pmid: 6392819].
672 Riley D. Hatha yoga and the treatment of illness. Altern Ther Health Med. 2004;10(2):20-1.
673 Ritz T. Relaxation therapy in adult asthma: is there new evidence for its effectiveness?. Behav Modif. 2001;25(4):640-66. [pmid: 11530720].
674 Rohsenow DJ, Monti PM, Martin RA, et al. Motivational enhancement and coping skills training for cocaine abusers: effects on substance use outcomes. Addiction. 2004;99(7):862-74. [pmid: 15200582].
675 Rohsenow DJ, Monti PM, Martin RA, et al. Brief coping skills treatment for cocaine abuse: 12-month substance use outcomes. J Consult Clin Psychol. 2000;68(3):515-20. [pmid: 10883569].
676 Rohsenow DJ, Monti PM, Rubonis AV, et al. Cue exposure with coping skills training and communication skills training for alcohol dependence: 6- and 12-month outcomes. Addiction. 2001;96(8):1161-74. [pmid: 11487422].
677 Roney-Dougal SM. On a possible psychophysiology of the yogic chakra system. Indian J Psychol. 1999;17(2):18-40.
678 Roscoe SS. Mind-body conversations: hypnosis, meditation, and poetry [dissertation]. Fort Lauderdale-Davie, FL: Nova Southeastern University; 1997.
679 Rosen AS, Nordquist TA. Ego developmental level and values in yogic community. J Pers Soc Psychol. 1980;39(16):1152-60.
680 Rosengren KS, Christou EA, Yang Y, et al. Quantification of taiji learning in older adults. J Am Geriatr Soc. 2003;51(8):1186-7. [pmid: 12890093].
681 Rossi EL. From mind to molecule: a state-dependent memory, learning, and behavior theory of mind body healing. Advances. 1987;4(2):46-60.
682 Roth B. Mindfulness-based stress reduction in the inner city. Advances. 1997;13(4):50-8.
683 Roth B, Creaser T. Mindfulness meditation-based stress reduction: experience with a bilingual inner-city program. Nurse Pract 1997 Mar;22(3):150–2,154,157. Erratum in: Nurse Pract 1997 May;22(5):215.
684 Roy D. Stress management: some Indian concepts. Abhigyan. 2000;18(1):1-7.
685 Rubottom RL. The differences and similarities of Zen, autogenic training, hypnosis and acupuncture. J Am Inst of Hypn 14(5):226–7.
686 Rutledge JC, Hyson DA, Garduno D, et al. Lifestyle modification program in management of patients with coronary artery disease: the clinical experience in a tertiary care hospital. J Cardiopulm Rehabil. 1999;19(4):226-34. [pmid: 10453429].
687 Ryan PL. A personal account: Eastern meditation group. In: Langone MD, ed. Recovery from cults. New York: WW Norton; 1993. p.129–39.
688 Rybarczyk B, DeMarco G, DeLaCruz M, et al. Comparing mind-body wellness interventions for older adults with chronic illness: classroom versus home instruction. Behav Med. 1999;24(4):181-90. [pmid: 10023496].
689 Rybarczyk B, DeMarco G, DeLaCruz M, et al. A classroom mind/body wellness intervention for older adults with chronic illness: comparing immediate and 1-year benefits. Behav Med. 2001;27(1):15-27. [pmid: 11575169].
690 Sager DE, Sager WG. SANCTUS Marriage enrichment. Fam J: Counc Ther Couples Fam. 2005;13(2):212-8.
691 Sakin-Wolf S. Adler: east, west, and beyond. J Individ Psychol. 2003;59(1):72-83.
692 Salmon PG, Santorelli SF, Kabat-Zinn J. Intervention elements promoting adherence to mindfulness-based stress reduction programs in the clinical behavioral medicine setting. Shumaker SAE, Schron EBE, Ockene JKE, et al., eds. The handbook of health behavior change. 2nd ed. New York: Springer Publishing Co.; 1998. p. 239–68.
693 Salmon PG, Sephton SE, Weissbecker I, et al. Mindfulness meditation in clinical practice. Cogn Behav Pract. 2004;11(4):434-46.
694 Samano ES, Goldenstein PT, Ribeiro LdeM, et al. Praying correlates with higher quality of life: results from a survey on complementary/alternative medicine use among a group of Brazilian cancer patients. Sao Paulo Med J. 2004;122(2):60-3. [pmid: 15257361].
695 Sancier KM. Electrodermal measurements for monitoring the effects of a qigong workshop. J Altern Complement Med. 2003;9(2):235-41. [pmid: 12804076].
696 Sancier KM. Medical applications of qigong. Altern Ther Health Med. 1996;2(1):40-6.
697 Sancier KM. Therapeutic benefits of qigong exercises in combination with drugs. J Altern Complement Med. 1999;5(4):383-9. [pmid: 10471019].
698 Sandlund ES, Norlander T. The effects of tai chi chuan relaxation and exercise on stress responses and well-being: an overview of research. Int J Stress Manage. 2000;7(2):139-49.
699 Saraswati A. Yoga, a holistic approach to mental-health. J Dharma. 1995;20(3):287-96.
700 Save-Mundra J. The contextual, theoretical, and procedural basis of mantra meditation and guidelines for its integration in standard psychotherapy practice [dissertation]. West Hartford, CT: University of Hartford; 2002.
701 Sheng WJ. Chinese qigong and qigong psychology In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 77–94.
702 Scherer-Dickson N. Current developments of metacognitive concepts and their clinical implications: mindfulness-based cognitive therapy for depression. Couns Psychol Q. 2004;17(2):223-34.
703 Scheufele PM. The effects of progressive relaxation and music on attention, relaxation, and stress responses: an investigation of the cognitive-behavioral model of relaxation [dissertation]. Bethesda, MD: Uniformed Services University of the Health Sciences; 1999.
704 Schmidt TFH, Wijga AH, Robra BP, et al. Yoga training and vegetarian nutrition reduce cardiovascular risk factors in healthy Europeans. [erratum] Homeost Health Dis. 1995;36(23):66.
705 Schmidt-Wilk J, Alexander CN, Swanson GC. Developing consciousness in organizations: the transcendental meditation program in business. J Bus Psychol. 1996;10(4):429-44.
706 Schneider RH, Alexander CN, Salerno JW, et al. Disease prevention and health promotion in the aging with a traditional system of natural medicine: Maharishi vedic medicine. J Aging Health. 2002;14(1):57-78. [pmid: 11892761]. [pmcid: 2211377].
707 Schneider RH, Alexander CN, Staggers F, et al. Long-term effects of stress reduction on mortality in persons > or = 55 years of age with systemic hypertension. Am J Cardiol. 2005;95(9):1060-4. [pmid: 15842971]. [pmcid: 1482831].
708 Schneider RH, Alexander CN, Wallace RK. In search of an optimal behavioral treatment for hypertension: a review and focus on transcendental meditation. In: Johnson EH, Gentry WD, Julius S, eds. Personality, elevated blood pressure, and essential hypertension. Washington, DC: Hemisphere Publishing Corp; 1992. p. 291–316.
709 Schneider RH, Cavanaugh KL, Kasture HS, et al. Health promotion with a traditional system of natural health care: Maharishi ayur-veda. J Soc Behav Pers. 1990;5(3):1-27.
710 Schneider RH, Rainforth M, Nidich SI, et al. Meditation in the prevention and treatment of cardiovascular disease: a review of controlled clinical research on the transcendental meditation program. Psychosom Med. 2002;64(1):155.
711 Schulte HJ, Abhyanker VV. Yogic breathing and psychologic states. Ariz Med. 1979;36(9):681-3. [pmid: 496679].
712 Schuster DH. Preliminary evaluation of PAMFA: psychological assist to medical first aid. J Clin Psychol. 1975;31(1):97-100. [pmid: 1112910].
713 Scott DW, Donahue DC, Mastrovito RC, et al. The antiemetic effect of clinical relaxation: report of an exploratory pilot study. J Psychosoc Oncol. 1983;1(1):71-84.
714 Secheny S. Regression of cancer of the rectum after intensive meditation. Aust Med Rec J. 1980;1(3):136-7.
715 Seeman TE, Dubin LF, Seeman M. Religiosity/spirituality and health: a critical review of the evidence for biological pathways. Am Psychol. 2003;58(1):53-63. [pmid: 12674818].
716 Seer P. Psychological control of essential hypertension: review of the literature and methodological critique. Psychol Bull. 1979;86(5):1015-43. [pmid: 386400].
717 Segal ZV, Teasdale JD, Williams JMr. The mindfulness-based cognitive therapy adherence scale: inter-rater reliability, adherence to protocol and treatment distinctiveness. Clin Psychol Psychother. 2002;9(2):131-8.
718 Segal ZV, Teasdale JD, Williams JMG. Mindfulness-based cognitive therapy: theoretical rationale and empirical status. In: Hayes SC, Follette V, Linehan MM, eds. Mindfulness and acceptance: expanding the cognitive-behavioral tradition. New York: Guilford Publications; 2004.
719 Segal ZV, Williams JMG, Teasdale JD. Mindfulness-based cognitive therapy for depression: a new approach to preventing relapse. New York: Guilford Press; 2002.
720 Selvamurthy W. Application of yoga and ayurveda in stress management: scientific perspectives. Int J Psychol. 2000;35(34):186.
721 Sequeira W. Yoga in treatment of carpal-tunnel syndrome. Lancet. 1999;353(9154):689-90. [pmid: 10073507].
722 Servit Z, Kristof M, Strejekova A. Activating effect of nasal and oral hyperventilation on epileptic electrographic phenomena: reflex mechanisms of nasal origin. Epilepsia. 1981;22(3):321-9. [pmid: 6972302].
723 Shan G, Daniels D, Gu R. Artificial neural networks and center-of-pressure modeling: a practical method for sensorimotor-degradation assessment. J Aging Phys Act. 2004;12(1):75-89. [pmid: 15211022].
724 Shan H. Culture-bound psychiatric disorders associated with qigong practice in China. Hong Kong J Psychiatry. 2000;10(4):12-4.
725 Shang C. Emerging paradigms in mind-body medicine. J Altern Complement Med. 2001;7(1):83-91. [pmid: 11246939].
726 Shannahoff-Khalsa DS. Complementary healthcare practices stress management for gastrointestinal disorders: the use of Kundalini yoga meditation techniques. Gastroenterol Nurs. 2002;25(3):126-9. [pmid: 12055381].
727 Shannahoff-Khalsa DS. An introduction to Kundalini yoga meditation techniques that are specific for the treatment of psychiatric disorders. J Altern Complement Med. 2004;10(1):91-101. [pmid: 15025884].
728 Shannahoff-Khalsa DS. Kundalini yoga meditation techniques for the treatment of obsessive-compulsive and OC spectrum disorders. Brief Treatment Crisis Intervent. 2003;3(3):369-82.
729 Shannahoff-Khalsa DS. Patient perspectives: kundalini yoga meditation techniques for psycho-oncology and as potential therapies for cancer. Integr Cancer Ther. 2005;4(1):87-100. [pmid: 15695478].
730 Shannahoff-Khalsa DS. Unilateral forced nostril breathing: basic science, clinical trials, and selected advanced techniques. Subtle Energies Energy Med J. 2001;12(2):79-106.
731 Shannahoff-Khalsa DS, Bhajan Y. The healing power of sound: techniques from yogic medicine. In: Spintge R, Droh R, eds. Fourth International MUSICMEDICINE symposium 1989; Rancho Mirage, CA. St. Louis: MMB Music; 1992. p. 179–93.
732 Shannon JH. The aesthetics of spiritual practice and the creation of moral and musical subjectivities in Aleppo, Syria. Ethnology. 2004;43(4):381-91.
733 Shannon S, ed. Handbook of complementary and alternative therapies in mental health. San Diego, CA: Academic Press; 2002.
734 Shapiro DA. Implications of psychotherapy research for the study of meditation. In: West MA, ed. The psychology of meditation. New York: Clarendon Press/Oxford University Press; 1987. p.173–188.
735 Shapiro DH. Examining the content and context of meditation: a challenge for psychology in the areas of stress management, psychotherapy, and religion values. J Hum Psychol. 1994;34(4):101-35.
736 Shapiro DH. Instructions for a training package combining formal and informal Zen meditation with behavioral self-control strategies. Psychologia: Int J Psychol Orient. 1978;21(2):70-6.
737 Shapiro DH. Meditation as an altered state of consciousness: contributions of Western behavioral science. J Transpersonal Psychol. 1983;15(1):61-81.
738 Shapiro DH. Meditation: clinical and health-related applications. West J Med. 1981;134(2):141-2.
739 Shapiro DH. Overview: clinical and physiological comparison of meditation with other self-control strategies. Am J Psychiatry. 1982;139(3):267-74. [pmid: 7036760].
740 Shapiro DH, Zifferblatt SM. Zen meditation and behavior self-control: similarities, differences, and clinical applications. Am Psychol. 1976;31(7):519-32. [pmid: 786089].
741 Shapiro DH Jr, Giber D. Meditation and psychotherapeutic effects self-regulation strategy and altered state of consciousness. Arch Gen Psychiatry. 1978;35(3):294-302. [pmid: 365121].
742 Shapiro SL, Walsh R. An analysis of recent meditation research and suggestions for future directions. Hum Psychol. 2003;31(23):86-114.
743 Shapiro SL, Walsh R, Britton WB. An analysis of recent meditation research and suggestions for future directions. J Medit Medit Res. 2003;3:69-90.
744 Sharma AR. Psychotherapy with Hindus. In: Richards S, Bergin AE, eds. Handbook of psychotherapy and religious diversity. Washington DC: American Psychological Association; 2000. Chapter 14.
745 Sharma HM, Dillbeck MC, Dillbeck SL. Implementation of the transcendental meditation program and Maharishi ayur-veda to prevent alcohol and drug abuse among juveniles at risk. Alcohol Treat Q. 1994;11(34):429-57.
746 Sharma I, Singh P. Treatment of neurotic illnesses by yogic techniques. Indian J Med Sci. 1989;43(3):76-9. [pmid: 2670762].
747 Shastri MS. Pranayama in Patanjala yoga sutras. In: Murali TS, ed. Sixth World congress on Holistic Life and Medicine; 1996 Jan; Calicut, India. Kottakkal, India: Arya Vaidya Sala; 1998. p. 129–36.
748 Shealy CN, Cady RK, Cox RH. Pain, stress and depression: psychoneurophysiology and therapy. Stress Med. 1995;11(2):75-7.
749 Sheppard JL. Relaxation and meditation as techniques for stress reduction. In: Sheppard JL, ed. Advances in Behavioural Medicine. Sydney, Australia: Cumberland College of Health Sciences; 1989. p. 137–58.
750 Sierpina VS, Carter R. Alternative and integrative treatment of fibromyalgia and chronic fatigue syndrome. Clin Fam Pract. 2002;4(4):853-72.
751 Siganga WW, Dastani HB. An overview of four nonpharmacologic complementary and alternative medicine modalities. J Pharm Technol. 2002;18(4):171-7.
752 Sigdell JE. An alternative to the artificial kidney and an ancient procedure of kriya yoga. Ancient Sci Life. 1984;4(1):6-8.
753 Singh R. Role of yogic exercises/meditation in aircrew stress management. Aviat Space Environ Med. 1999;70(9):939.
754 Singh RG, Bajpai HS, Udupa KN, et al. Effect of yogic practices on patients of cardiac neurosis. J Mol Cell Cardiol. 1978;10(1 Suppl):106.
755 Singh RH. Evaluation of some Indian traditional methods of promotion of mental health. Act Nerv Super (Praha). 1986;28(1):67-9.
756 Singh V. Effect of respiratory exercises on asthma the pink city lung exerciser. J Asthma. 1987;24(6):355-9. [pmid: 3443597].
757 Singh V, Wisniewski A, Britton J, et al. Effect of yoga breathing exercises (pranayama) on airway reactivity in subjects with asthma. Lancet. 1990;335(8702):1381-3. [pmid: 1971670].
758 Siripoon M. Effect of the relaxation response in patients with essential hypertension [abstract]. Diss Abstr Int. 1986;47(2B):575.
759 Slavit MR. The effects of assessing and utilizing preferred sensory modality: an experiment with relaxation training [abstract]. Diss Abstr Int. 1984;44(9B):2907.
760 Smith A. Clinical uses of mindfulness training for older people. Behav Cogn Psychother. 2004;32(4):423-30.
761 Smith JC. Meditation as psychotherapy: a review of the literature. Psychol Bull. 1975;82(4):558-64. [pmid: 1099602].
762 Smith JC. Meditation, biofeedback, and the relaxation controversy: a cognitive-behavioral perspective. Am Psychol. 1986;41(9):1007-9.
763 Smith JC, McDuffie SR, Ritchie T, et al. Ethnic and racial differences in relaxation states for recalled relaxation activities. In: Smith JC, ed. Advances in ABC relaxation Training. New York: Springer; 2001. p. 115–6.
764 Smith JG. The luminas (TM) mind-body-spirit program: a clinical model of spiritual care for cancer patients [dissertation]. Cincinnati: Union Institute University; 2004.
765 Smith PJ. An empirically derived patient-centred behavioural procedure for reducing clinical anxiety. J Integrative Eclectic Psychother. 1983;2(2):44-59.
766 Snaith P. Meditation and psychotherapy. Br J Psychiatry. 1998;179:193-5.
767 Snaith P, Owens D, Kennedy E. An outcome study of a brief anxiety management programme: anxiety control training. Ir J Psychol Med. 1992;9(2):111-4.
768 Snyder M. Relaxation. Annu Rev Nurs Res. 1988;6:111-28. [pmid: 3291908].
769 Sobel DS. Mind matters, money matters: the cost-effectiveness of mind/body medicine. JAMA. 2000;284(13):1705. [pmid: 11015806].
770 Solloway SG. Teachers as contemplative practitioners: presence, meditation, and mindfulness as a classroom practice [dissertation]. Edmond: Oklahoma State University; 1999.
771 Solomon EG, Bumpus AK. The running meditation response: an adjunct to psychotherapy. Am J Psychiatry. 1978;32(4):583-92.
772 Sommer SJ, Hassed CS. Meditation-based stress management for doctors and students. Aust Med Rec J. 1995;163(2):112.
773 Sothers K, Anchor KN. Prevention and treatment of essential hypertension with meditation-relaxation methods. Med Psychother: Int J. 1989;2:137-56.
774 Spencer J, Shanor K. Mind-body medicine. In: Shanor KN, ed. The emerging mind. Los Angeles: Reinassance Books; 1999. Chapter 5.
775 Srinivasan TM. Pranayama and brain correlates. Ancient Sci Life. 1991;11(12):1-6.
776 Srinivasan S. Vipassana meditation as taught in the meditation centres initiated by S.N. Goenka. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 49–56.
777 Stainbrook GL, Hoffman JW, Benson H. Behavioral therapies of hypertension: psychotherapy, biofeedback, and relaxation/meditation. Int Rev Appl Psychol. 1983;32(2):119-35.
778 Stearns V. Management of hot flashes in breast cancer survivors and men with prostate cancer. Curr Oncol Rep. 2004;6(4):285-90. [pmid: 15161582].
779 Steptoe A. The processes underlying long-term blood pressure reductions in essential hypertensives following behavioural therapy. In: Elbert T, Langosch W, Steptoe A, et al., eds. Behavioral medicine in cardiovascular disorders. New York: Wiley; 1988. p. 139–48.
780 Stevens LC. Programs and metaprograms for the control of diabetic symptomatology: a comparative treatment study [abstract]. Diss Abstr Int. 1984;44(11B):3567.
781 Stevinson C. Preliminary results suggest that yoga can alleviate depression. Focus Altern Complement Ther. 2001;6(1):27-8.
782 Stewart RA. Self-realization as the basis of psychotherapy: a look at two Eastern-based practices, transcendental meditation and alpha brain wave biofeedback. Soc Behav Pers. 1974;2(2):191-200.
783 Stolley JM, Buckwalter KC, Koenig HG. Prayer and religious coping for caregivers of persons with Alzheimer's disease and related disorders. Am J Alzheimers Dis Other Demen. 1999;14(3):181-91.
784 Storer JH, Frate DA, Banahan BF, et al. Adapting relaxation techniques to rural populations: implications for high blood pressure therapy. J Rural Health. 1989;5(1):13-8.
785 Stoyva JM. Stress management: what can we learn from the meditative disciplines? In: Kenny DT, Carlson J, McGuigan FJ, et al., eds. Stress and health: research and clinical applications. Amsterdam: Harwood Academic; 2000. p. 179–94.
786 Strawbridge WJ, Shema SJ, Cohen RD, et al. Religiosity buffers effects of some stressors on depression but exacerbates others. J Gerontol B Psychol Sci Soc Sci. 1998;53(3):118-26.
787 Stuart EM. The efficacy of eliciting the relaxation response in preparing for cardiac surgery [abstract]. Circ Suppl 1988;78(4):II614.
788 Subramanian P. Meditation for prevention of disease. Indian J Med Sci. 1998;52(3):114-8. [pmid: 9770874].
789 Suler JR. The tai chi images: a Taoist model of psychotherapeutic change. Psychologia. 1991;34(1):18-27.
790 Sullivan MJ, Johnson DE, Wood L, et al. A comprehensive mindfulness based psychoeducational intervention for patients with chronic heart failure. Institute for Healing in Society and Medicine, Chapel Hill (NC); 2004. [cited 2005 Oct 9]. Available at: http://www.healinginmedicine.org/download/Procedure%20Paper.pdf.
791 Susman MP. Regression of metastases associated with intensive meditation. Aust Med Rec J. 1979;1(2):59.
792 Sutorius D. The transforming force of laughter, with the focus on the laughing meditation. Patient Educ Couns. 1995;26(13):367-71. [pmid: 7494752].
793 Svatmarama YS. Hatha yoga pradipika. Woodstock, NY: YogaVidya; 2000.
794 Swinyard CA, Chaube S, Sutton DB. Neurological and behavioral aspects of transcendental meditation relevant to alcoholism: a review. Ann N Y Acad Sci. 1974;233:162-73. [pmid: 4596657].
795 Syrjala KL, Donaldson GW, Davis MW, et al. Relaxation and imagery and cognitive-behavioral training reduce pain during cancer treatment: a controlled clinical trial. Pain. 1995;63(2):189-98. [pmid: 8628584].
796 Taams MK, Kwee MGT. Transcultural clinical meditation: a new direction in clinical psychology. Int J Psychol. 2004;39(56 Suppl):112.
797 Tacon AM. Meditation as a complementary therapy in cancer. Fam Community Health. 2003;26(1):64-73. [pmid: 12802129].
798 Taggart HM. Self-reported benefits of t'ai chi practice by older women. J Holist Nurs. 2001;19(3):223-32. quiz 233–7. [pmid: 11847869].
799 Takeichi M, Sato T. Studies on the psychosomatic functioning of ill-health according to eastern and western medicine 7 psychoimmuno-endocrinological changes induced by kampo medication and relaxation training. Am J Chin Heath. 2001;29(34):411-22.
800 Tang KC. Qigong therapy: its effectiveness and regulation. Am J Chin Med. 1994;22(34):235-42. [pmid: 7872235].
801 Targ R, Katra J. The scentific and spiritual implications of psychic abilities. Altern Ther Health Med. 2001;7(3):143-9. [pmid: 11347280].
802 Taylor DN. Effects of a behavioral stress-management program on anxiety, mood, self-esteem, and T-cell count in HIV positive men. Psychol Rep. 1995;76(2):451-7. [pmid: 7667456].
803 Taylor MJ. Yoga therapeutics: an ancient, dynamic systems theory. Techniques Orthop. 2003;18(1):115-25.
804 Taylor MJ, Majundmar M. Incorporating yoga therapeutics into orthopaedic physical therapy. Orthop Phys Ther Clin N Am. 2000;9(3):341-59.
805 Taylor-Piliae RE. Tai chi as an adjunct to cardiac rehabilitation exercise training. J Cardiopulm Rehabil. 2003;23(2):90-6. [pmid: 12668929].
806 Taylor-Piliae RE, Froelicher ES. Effectiveness of tai chi exercise in improving aerobic capacity: a meta-analysis. J Cardiovasc Nurs. 2004;19(1):48-57. [pmid: 14994782].
807 Taylor-Piliae RE, Froelicher ES. Measurement properties of tai chi exercise self-efficacy among ethnic Chinese with coronary heart disease risk factors: a pilot study. Eur J Cardiovasc Nurs. 2004;3(4):287-94. [pmid: 15572017].
808 Taylor SK. Tai chi for chronic pain and arthritis. Techniques Orthop. 2003;18(1):110-4.
809 Teasdale JD. Mindfulness-based cognitive therapy. In: Segal ZV, Williams JMG, Teasdale JD, eds. Mindfulness-based cognitive therapy for depression: a new approach for preventing relapse. New York: Guildford Publications; 2001. Part II.
810 Teasdale JD, Segal ZV, Williams JG. Mindfulness training and problem formulation. Clin Psychol: Sci Pract. 2003;10(2):157-60.
811 Teasdale JD, Segal ZV, Williams JMG. How does cognitive therapy prevent depressive relapse and why should attentional control (mindfulness) training help?. Behav Res Ther. 1995;33(1):25-39. [pmid: 7872934].
812 Telles S, Naveen KV. Yoga for rehabilitation: an overview. Indian J Med Sci. 1997;51(4):123-7. [pmid: 9355699].
813 Thomson RF. Zazen and psychotherapeutic presence. Am J Psychiatry. 2000;54(4):531-48.
814 Thoresen CE, Oman D, Harris AH. The effects of religious practices: a focus on health. In: Miller WR, Delaney HD. Judeo-Christian perspectives on psychology: Human nature, motivation, and change. Washington, DC: American Psychological Association; 2005. p. 205–26.
815 Timio M, Verdecchia P, Ronconi M, et al. Blood pressure changes over 20 years in nuns in a secluded order. J Hypertens Suppl. 1985;3(3):S387-8. [pmid: 2856746].
816 Titlebaum H. Relaxation. In: Zahourek RP, ed. Relaxation and imagery: tools for therapeutic communication and intervention. Philadelphia: WB Saunders; 1988. p. 28–52.
817 Todd C. Meditation, mystical and therapeutic. Bull Br Psychol Soc. 1981;34:101-2.
818 Toivanen H, Lansimies E, Jokela V, et al. Sympathovagal interaction in stress and relaxation heart rate variability in home elps. J Psychophysiol. 1994;8(1):11-21.
819 Torbert WR, Cook-Greuter SR. Cultivating postformal adult development: higher stages and contrasting interventions. In: Miller M, ed. Transcendence and mature thought in adulthood. Lanham, MD: Rowman & Littlefield; 1994. p. 186–201.
820 Torneke N. Book review: mindfulness and acceptance; expanding the cognitive-behavioral tradition. Cogn Behav Ther. 2005;34(2):124-5.
821 Toseland RW, Kabat D, Kemp K. Evaluation of a smoking-cessation group treatment program. Soc Work Res Abstr. 1983;19(1):12-9.
822 Totton CA. Meditation and altered states: a phenomenological and clinical synthesis [dissertation]. Malibu, CA: Pepperdine University; 1999.
823 Travis FT, Arenander A. EEG asymmetry and mindfulness meditation. Psychosom Med. 2004;66(1):147. [pmid: 14747649].
824 Treesak C, Ye X, Sakthong P, et al. Performance of the Sf-12 and rand-12 physical and mental health summary scores in people practicing meditation. Value Health. 2003;6(3):361.
825 Trunnell EP. Mindfulness and people with stomas. J Wound Ostomy Continence Nurs. 1996;23(1):38-45. [pmid: 8704849].
826 Tsang HWH. Qigong and suicide prevention. Br J Psychiatry. 2003;182:266-7.
827 Tsang HWH, Cheung L, Lak DCC. Qigong as a psychosocial intervention for depressed elderly with chronic physical illnesses. Int J Geriatr Psychiatry. 2002;17(12):1146-54. [pmid: 12461764].
828 Tseng RK. Qigong: an approach to health and longevity [dissertation]. Cincinnati: Union Institution University; 1998.
829 Tyni-Lenne R, Stryjan S, Eriksson B, et al. Beneficial therapeutic effects of physical training and relaxation therapy in women with coronary syndrome X. Physiother Res Int. 2002;7(1):35-43. [pmid: 11992983].
830 Udani JK, Ofman JJ. Tai chi for the prevention of falls in the elderly. Integr Med. 1998;1(4):167-9.
831 Udupa KN, Singh RH. The scientific basis of yoga. JAMA. 1972;220(10):1365.
832 Urbanowski FB, Miller JJ. Trauma, psychotherapy, and meditation. J Transpersonal Psychol. 1996;28(1):31-48.
833 Usandivaras RJ. Therapeutic use of regression in group analysis. Group Analysis. 1989;22(2):171-5.
834 Van der Lans JM. Frame of reference as a prerequisite for the induction of religious experience through meditation: an experimental study. In: Brown LB, ed. Advances in the Psychology of Religion. Oxford: Pergamon Press; 1985. p. 127–34.
835 Van der Lans JM. The value of Sunden's role-theory demonstrated and tested with respect to religious experiences in meditation. J Sci Study Relig. 1987;26(3):401-12.
836 Van Deusen J, Harlowe D. The efficacy of the ROM dance program for adults with rheumatoid arthritis. Am J Occup Ther. 1987;41(2):90-5. [pmid: 3551621].
837 Van Dixhoorn J. Cardiorespiratory effects of breathing and relaxation instruction in myocardial infarction patients. Biol Psychol. 1998;49(12):123-35. [pmid: 9792489].
838 Van Dixhoorn J, Duivenvoorden HJ, Staal HA, et al. Physical training and relaxation therapy in cardiac rehabilitation assessed through a composite criterion for training outcome. Am Heart J. 1989;118(3):545-52. [pmid: 2672755].
839 Varela FJ, Depraz N. Wisdom traditions and the ways of reduction. In: Varela FJ, Depraz N, Vermersch P, eds. On becoming aware: a pragmatics of experiencing. Philadelphia (VA): John Benjamins Publishing Company; 2003. p. 205–31.
840 Vasilos JG. Skin temperature control: a comparison of direct instruction, autogenic suggestion, relaxation, and biofeedback training [abstract]. Diss Abstr Int. 1977;38(3B):1427-8.
841 Vasilos JG, Hughes HH. Skin temperature control: a comparison of direct instruction, autogenic suggestion, relaxation, and biofeedback training in male prisoners. Correct Soc Psych J Behav Tech Methods Ther. 1979;25(4):119-22.
842 Velikonja D, Weiss D, Corning WC. The relationship of cortical activation to alternating autonomic activity. Electroencephalogr Clin Neurophysiol. 1993;87(1):38-45. [pmid: 7687952].
843 Verhagen AP, Immink M, van der Meulen A, et al. The efficacy of tai chi chuan in older adults: a systematic review. Fam Pract. 2004;21(1):107-13. [pmid: 14760055].
844 Verma SK, Rao AS. Recent trends in clinical psychological intervention (methods based on other than behaviour therapy). NIMHANS Journal. 1996;14(4):307-14.
845 Verman M, Shapiro DH. Jewish meditation: context and content historical background, types, purpose. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 95–120.
846 Vickers A, Zollman C. ABC of complementary medicine: hypnosis and relaxation therapies. BMJ. 1999;319:1346-9. [pmid: 10567143]. [pmcid: 1117083].
847 Vinck J, Arickx M, Hongenaert M. Predicting interindividual differences in blood-pressure response to relaxation training in normotensives. J Behav Med. 1987;10(4):395-410. [pmid: 3312614].
848 Vitale MS. Use of relaxation training with mentally retarded adults [abstract]. Diss Abstr Int. 1984;44(8B):2572.
849 Vrolijk A. Transcendental meditation and dianetics. Gedrag: Tijdschrift Voor Psychologie. 1978;6(34):181-206.
850 Wadden TA, de la Torre CS. Relaxation therapy as an adjunct treatment for essential hypertension. J Fam Pract. 1980;11(6):901-8. [pmid: 7005389].
851 Waelde LC. Dissociation and meditation. J Trauma Dissociation. 2004;5(2):147-62.
852 Walia IJ, Mehra P, Grover P, et al. Health status of nurses and yoga II: subjects with and without-health problems. Nurs J India. 1989;80(10):256-8. [pmid: 2631037].
853 Walker LG. Immunological effects of relaxation training and guided imagery in women with locally advanced breast cancer. Psychooncology. 1996;5(3 Suppl):16.
854 Wallace JM. Stress, relaxation and meditation. Br Dent J. 1982;153(1):29-30.
855 Wallace RK, Orme Johnson DW, Mills PJ, et al. Academic achievement and the paired Hoffman reflex in students practicing meditation. Int J Neurosci. 1984;24(34):261-6. [pmid: 6392128].
856 Walsh R. Meditation practice and research. J Hum Psychol. 1983;23(1):18-50.
857 Walsh R. The original goals of meditation. Am J Psychiatry. 1982;139(11):1525-6.
858 Walsh R. Shamanic experiences: a developmental analysis. J Hum Psychol. 2001;41(3):31-52.
859 Walsh RN. Asian contemplative disciplines: common practices, clinical applications, and research findings. J Transpersonal Psychol. 1999;31(2):83-107.
860 Walsh RN. Meditation research: an introduction and review. J Transpersonal Psychol. 1979;11(2):161-74.
861 Walsh RN. A model for viewing meditation research. J Transpersonal Psychol. 1982;14(1):69-84.
862 Walton KG, Levitsky DK. Effects of the transcendental meditation program on neuroendocrine abnormalities associated with aggression and crime. J Offender Rehabil. 2003;36(14):67-87.
863 Walton KG, Levitsky DK. A neuroendocrine mechanism for the reduction of drug use and addictions by transcendental meditation. Alcohol Treat Q. 1994;11(12):89-117.
864 Walton KG, Schneider RH, Nidich SI. Review of controlled research on the transcendental meditation program and cardiovascular disease: risk factors, morbidity, mortality. Cardiol Rev. 2004;12(5):262-6. [pmid: 15316306]. [pmcid: 2211376].
865 Walton KG, Schneider RH, Nidich SI, et al. Psychosocial stress and cardiovascular disease part 2: effectiveness of the transcendental meditation program in treatment and prevention. Behav Med. 2003;28(3):106-23.
866 Walton KG, Schneider RH, Salerno JW, et al. Psychosocial stress and cardiovascular disease part 3: clinical and policy implications of research on the transcendental meditation program. Behav Med. 2005;30(4):173-83. [pmid: 15981895].
867 Wang C, Collet JP, Lau J. The effect of tai chi on health outcomes in patients with chronic conditions: a systematic review. Arch Intern Med. 2004;164(5):493-501. [pmid: 15006825].
868 Wang C, Yuan XY, Xu DD, et al. Brief introduction to the keep-fit qigong exercise. J Tradit Chin Med. 1986;6(4):239-42. [pmid: 3600016].
869 Wang X. Combination of acupuncture, qigong and herbs in the treatment of parkinsonism. Int J Clin Acupunct. 1993;4(1):1-7.
870 Watson CG, Tuorila JR, Vickers KS, et al. The efficacies of three relaxation regimens in the treatment of PTSD in Vietnam War veterans. J Clin Psychol. 1997;53(8):917-23. [pmid: 9403395].
871 Watts FN. Psychological research questions about yoga. Ment Health Religion Cult. 2000;3(1):71-83.
872 Wayne PM, Krebs DE, Wolf SL, et al. Can tai chi improve vestibulopathic postural control?. Arch Phys Med Rehabil. 2004;85(1):142-52. [pmid: 14970982].
873 Weber S. The effects of relaxation exercises on anxiety levels in psychiatric inpatients. J Holist Nurs. 1996;14(3):196-205. [pmid: 8900613].
874 Weller KR. Dynamical analysis of human EEG: a comparative study of different states of wakefulness [dissertation]. Fairfield, IA: Maharishi International University; 1993.
875 Wenneberg SR, Schneider RH, Walton KG, et al. Anger expression correlates with platelet aggregation. Behav Med. 1997;22(4):174-7. [pmid: 9138626].
876 West MA. Meditation. Br J Psychiatry. 1979;135:457-67. [pmid: 395988].
877 West MA. Meditation and the EEG. Psychol Med. 1980;10(2):369-75. [pmid: 6992184].
878 West MA. Meditation: psychology and human experience. In: Claxton G, ed. Beyond therapy: the impact of Eastern religions and psychological theory and practice. London: Wisdom Publications; 1986. p. 245–67.
879 West MA. The psychosomatics of meditation. J Psychosom Res. 1980;24(5):265-73. [pmid: 7009847].
880 West MA ed. The psychology of meditation. New York: Oxford University Press; 1987.
881 Whitcher-Chenkin SB. Effects of imagery versus relaxation on white blood cell activity [abstract]. Diss Abstr Int. 1986;46(12B Pt 1):4418.
882 Wilbur ME. Zen at work: the use of meditation in nursing practice. Gastroenterol Nurs. 2003;26(4):168-9. [pmid: 12920433].
883 Wilcox JD. Kundalini: a study of spiritual awakening and movement toward the self [abstract]. Diss Abstr Int. 1985;46(1B):292.
884 Williams JMG. Mindfulness-based cognitive therapy for depression: a new approach to preventing relapse. Eur Psychiatry. 2004;19(1 Suppl):76S.
885 Williams JMG, Swales M. The use of mindfulness-based approaches for suicidal patients. Arch Suicide Res. 2004;8(4):315-29. [pmid: 16081399].
886 Willis RJ. Meditation to fit the person: psychology and the meditative way. J Relig Health. 1979;18(2):93-119.
887 Wilson SR, Spencer RC. Intense personal experiences: subjective effects, interpretations, and after-effects. J Clin Psychol. 1990;46(5):565-73. [pmid: 2246361].
888 Witte D, Dundes L. Harnessing life energy or wishful thinking? Reiki, placebo reiki, meditation, and music. Altern Complement Ther. 2001;7(5):304-9.
889 Wittrock DA, Blanchard EB, McCoy GC, et al. The relationship of expectancies to outcome in stress management treatment of essential hypertension: results from the joint USSR-USA behavioral hypertension project. Biofeedback Self Regul. 1995;20(1):51-68. [pmid: 7786927].
890 Wolf SL, Coogler CE, Xu T. Exploring the basis for tai chi chuan as a therapeutic exercise approach. Arch Phys Med Rehabil. 1997;78(8):886-92. [pmid: 9344312].
891 Wolfson L, Whipple R, Derby C, et al. Balance and strength training in older adults: intervention gains and tai chi maintenance. J Am Geriatr Soc. 1996;44(5):498-506. [pmid: 8617896].
892 Wong SS, Nahin RL. National center for complementary and alternative medicine perspectives for complementary and alternative medicine research in cardiovascular diseases. Cardiol Rev. 2003;11(2):94-8. [pmid: 12620133].
893 Woolfolk RL. Psychophysiological correlates of meditation. Arch Gen Psychiatry. 1975;32(10):1326-33. [pmid: 1180661].
894 Wu G. Evaluation of the effectiveness of tai chi for improving balance and preventing falls in the older population: a review. J Am Geriatr Soc. 2002;50(4):746-54. [pmid: 11982679].
895 Yalden J, Chung L. Tai chi: towards an exercise program for the older person. Aust J Holist Nurs. 2001;8(1):4-13.
896 Yamasaki T. Ajikan meditation of Shingon Buddhism. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 67–76.
897 Yan JH, Downing JH. Tai chi: an alternative exercise form for seniors. J Aging Phys Act. 1998;6(4):350-62.
898 Yang KH, Kim YH, Lee MS. Efficacy of qi-therapy (external qigong) for elderly people with chronic pain. Int J Neurosci. 2005;115(7):949-63. [pmid: 16051542].
899 Yardi N. Yoga for control of epilepsy. Seizure. 2001;10(1):7-12. [pmid: 11181093].
900 Young JDE, Taylor E. Meditation as a voluntary hypometabolic state of biological estivation. News Physiol Sci. 1998;13:149-53. [pmid: 11390779].
901 Zabel D, Haynes A. Meditation and health: an annotated bibliography. Reference User Serv Q. 2004;44(1):18-25.
902 Zabora JR, Loscalzo M, Brintzenhofezoc K, et al. Part X: Interventions. In: Holland JC, ed. Psycho-oncology. New York: Oxford University Press; 1998. p. 653–836.
903 Zachariae R, Hansen JB, Andersen M, et al. Changes in cellular immune function after immune specific guided imagery and relaxation in high and low hypnotizable healthy subjects. Psychother Psychosom. 1994;61(12):74-92. [pmid: 8121979].
904 Zachariae R, Jorgensen MM, Christensen S, et al. Effects of relaxation on the delayed-type hypersensitivity (DTH) reaction to diphenylcyclopropenone (DCP). Allergy. 1997;52(7):760-4. [pmid: 9265993].
905 Zachariae R, Oster H, Bjerring P, et al. Effects of psychologic intervention on psoriasis: a preliminary report. J Am Acad Dermatol. 1996;34(6):1008-15. [pmid: 8647966].
906 Zarrilli PB. Three bodies of practice in a traditional South Indian martial art. Soc Sci Med. 1989;28(12):1289-309. [pmid: 2660283].
907 Zastrow C. Using relaxation techniques with individuals and with groups. J Independent Soc Work. 1987;2(1):83-95.
908 Zika B. Meditation and altered states of consciousness: a psychodynamic interpretation. J Psychol Christianity. 1984;3(3):65-72.
909 Zwick D, Rochelle A, Choksi A, et al. Evaluation and treatment of balance in the elderly: a review of the efficacy of the berg balance test and tai chi quan. NeuroRehabilitation. 2000;15(1):49-56. [pmid: 11455081].

## Excluded: Design—No Control (N = 280)

The following studies were excluded because they did not have a control group.

### References

1 Abbey SE. Mindfulness-based stress reduction groups. J Psychosom Res. 2003;55(2):115.
2 Abrams AI. A follow-up study of the effects of the transcendental meditation program on inmates at Folsom prison. 1990;3:2108–12.
3 Adashko R, Alyson D. The experience of yoga during the transition to motherhood [dissertation]. Cincinnati: Union Institute and University; 2003.
4 Aftanas LI, Golocheikine SA. Changes in cortical activity in altered states of consciousness: the study of meditation by high-resolution EEG. Hum Physiol. 2003;29(2):143-51.
5 Aftanas LI, Golocheikine SA. Human anterior and frontal midline theta and lower alpha reflect emotionally positive state and internalized attention: high-resolution EEG investigation of meditation. Neurosci Lett. 2001;310(1):57-60. [pmid: 11524157].
6 Aftanas LI, Golocheikine SA. Non-linear dynamic complexity of the human EEG during meditation. Neurosci Lett. 2002;330(2):143-6. [pmid: 12231432].
7 Agran JL. The effects of relaxation-meditation procedures on federal supervisors: a case study [abstract]. Diss Abstr Int. 1989;49(9B):4062.
8 Akers TK, Tucker DM, Roth RS, et al. Personality correlates of EEG change during meditation. Psychol Rep. 1977;40(2):439-42. [pmid: 323900].
9 Allison J. Respiratory changes during transcendental meditation. Lancet. 1970;1(7651):833. [pmid: 4191449].
10 Altner N. Mindfulness practice and smoking cessation: the Essen hospital smoking cessation study (EASY). J Medit Medit Res. 2002;2:9-18.
11 Anderson DJ. Transcendental meditation as an alternative to heroin abuse in servicemen. Am J Psychiatry. 1977;134(11):1308-9. [pmid: 333955].
12 Aron A, Orme-Johnson DW, Brubaker P. The transcendental meditation program in the college curriculum: a 4-year longitudinal study on effects on cognitive and affective functioning. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1977–82.
13 Aron EN, Aron A. The patterns of reduction of drug and alcohol use among transcendental meditation participants. Bull Soc Psychol Addict Behav. 1983;2(1):28-33.
14 Assimakis PD. Change in the quality of life in Canada: intervention studies of the effect of the transcendental meditation and TM-Sidhi program [dissertation]. Fairfield, IA: Maharishi International University; 1989.
15 Assimakis PD, Dillbeck MC. Time series analysis of improved quality of life in Canada: social change, collective consciousness, and the TM-Sidhi program. Psychol Rep. 1995;76(3 Pt 2):1171-93. [pmid: 7480483].
16 Bache CM. On the emergence of perinatal symptoms in Buddhist meditation. J Sci Study Relig. 1981;20(4):339-50.
17 Backon J, Kullok S. Effect of forced unilateral nostril breathing on blink rates: relevance to hemispheric lateralization of dopamine. Int J Neurosci. 1989;46:53-9. [pmid: 2767903].
18 Baerentsen KB, Hartvig NV, Stokilde-Jorgensen H, Mammen J. Onset of meditation explored with fMRI. Neuroimage. 2001;13(6):S297.
19 Baglio S, Bucolo M, Fortuna L, et al. MEG signals spatial power distribution and gamma band activity in yoga breathing exercises. In: Proceedings of the 24th Annual International Conference of the IEEE Engineering in Medicine and Biology Society; 2002 Oct; Houston, TX: IEEE; 2002. p. 175–6.
20 Banquet JP, Sailhan M, Carette F, et al. EEG analysis of spontaneous and induced states of consciousness. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 165–72.
21 Bastille JV, Gill-Body KM. The effects of a yoga-based exercise program on individuals with chronic post-stroke hemiparesis: platform & poster presentations for CSM 2003. Neurol Rep. 2002;26(4):203.
22 Baum C, Gessert A. Mindfulness-based stress reduction (MBSR) classes as a tool to decrease the anxiety of cancer patients. Psychooncology. 2004;13(1 Suppl):S13.
23 Bedard M, Felteau M, Gibbons C, et al. A mindfulness-based intervention to improve quality of life among individuals who sustained traumatic brain injuries: one-year follow-up. J Clin Psychol Med Settings. 2005;23(1):8-13.
24 Benson H. Decreased alcohol intake associated with the practice of meditation: a retrospective investigation. Ann N Y Acad Sci. 1974;233:174-7. [pmid: 4523799].
25 Benson H, Malvea BP, Graham JR. Physiologic correlates of meditation and their clinical effects in headache: ongoing investigation. Headache. 1973;13(1):23-4. [pmid: 4696143].
26 Benson H, Steinert RF, Greenwood MM, et al. Continuous measurement of O2 consumption and CO2 elimination during a wakeful hypometabolic state. J Hum Stress. 1975;1(1):37-44.
27 Benson H, Wilcher M, Greenberg B, et al. Academic performance among middle-school students after exposure to a relaxation response curriculum. J Res Dev Educ. 2000;33(3):156-65.
28 Bentler SE, Hartz AJ, Kuhn EM. Prospective observational study of treatments for unexplained chronic fatigue. J Clin Psychiatry. 2005;66(5):625-32. [pmid: 15889950].
29 Beresford M, Clements G. Real time EEG coherence analysis of the transcendental meditation and the TM-Sidhi programme. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1738–42.
30 Bevan AJW. Endocrine changes in transcendental meditation. Clin Exp Pharmacol Physiol. 1980;7(1):75-6.
31 Blasdell KS. Acute immunoreactivity modified by psychosocial factors: type A/B behavior, transcendental meditation and lymphocyte transformation [dissertation]. Fairfield, IA: Maharishi International University; 1989.
32 Bleick CR. Case histories: using the transcendental meditation program with alcoholics and addicts. Alcohol Treat Q. 1994;11(34):243-69.
33 Bonadies V. A yoga therapy program for AIDS-related pain and anxiety: implications for therapeutic recreation. Ther Recreation J. 2004;38(2):148-66.
34 Bormann JE, Becker S, Gershwin M, et al. Mantra repetition for managing stress in veterans. Commun Nurs Res. 2004;37:340.
35 Britton WB, Shapiro SL, Penn PE, et al. Treating insomnia with mindfulness-based stress reduction. Sleep. 2003;26:A309-10.
36 Brown D, Forte M, Dysart M. Visual sensitivity and mindfulness meditation. Percept Mot Skills. 1984;58(3):775-84. [pmid: 6382145].
37 Brown DD, Mucci WG, Hetzler RK, et al. Cardiovascular and ventilatory responses during formalized tai chi chuan exercise. Res Q Exerc Sport. 1989;60(3):246-50. [pmid: 2489850].
38 Capurro A, Diambra L, Malta CP. Model for the respiratory modulation of the heart beat-to-beat time interval series. Phys Stat Mech Appl. 2005;355(24):439-60.
39 Carlson LE, Garland S, Speca M. Improvements in sleep quality in cancer outpatients participating in mindfulness-based stress reduction. Psychooncology. 2004;13(8 Suppl):S137-8.
40 Carter R, Meyer JE. The use of the transcendental meditation (TM) technique with severely disturbed psychiatric inpatients. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2112–5.
41 Cernovsky Z. Es scale level and correlates of MMPI elevation: alcohol abuse vs MMPI scores in treated alcoholics. J Clin Psychol. 1984;40(6):1502-9. [pmid: 6511972].
42 Chan SP, Luk TC, Hong Y. Kinematic and electromyographic analysis of the push movement in tai chi. Br J Sports Med. 2003;37(4):339-44. [pmid: 12893721]. [pmcid: 1724683].
43 Chao YF, Chen SY, Lan C, et al. The cardiorespiratory response and energy expenditure of tai-chi-qui-gong. Am J Chin Med. 2002;30(4):451-61. [pmid: 12568273].
44 Chaudhary AK, Bhatnagar HN, Bhatnagar LK, et al. Comparative study of the effect of drugs and relaxation exercise (yoga shavasan) in hypertension. J Assoc Physicians India. 1988;36(12):721-3. [pmid: 3069839].
45 Chen KM, Chen WT, Wang JJ, et al. Frail elders' views of tai chi. J Nurs Res. 2005;13(1):11-20. [pmid: 15977131].
46 Chen ME. A comparative study of dimensions of healthy functioning between families practicing the TM program for five years or for less than a year [dissertation]. Tallahassee: Florida State University; 1988.
47 Cheng-Kuo T, Ho FM, Lin CW. Physiological changes associated with neiyang qigong. J Health Sci. 2003;49:278-84.
48 Chihara T. Zen meditation and time-experience. Psychologia. 1989;32(4):211-20.
49 Christensen RE. Developing and evaluating a meditation and self-help group based on perceptual control theory [dissertation]. Alameda: California School of Professional Psychology; 1999.
50 Cohen-Katz J, Wiley SD, Capuano T, et al. The effects of mindfulness-based stress reduction on nurse stress and burnout: a qualitative and quantitative study, part III. Holist Nurs Pract. 2005;19(2):78-86. [pmid: 15871591].
51 Compton WC. Self-report of attainment in experienced Zen meditators: a cautionary note on objective measurement. Psychologia: Int J Psychol Orient. 1991;34(1):15-7.
52 Cox RJ. Relating different types of christian prayer to religious and psychological measures of well-being [dissertation]. Boston: Boston University; 2000.
53 Crumpler CA. Sufi practices, emotional state and DNA repair: implications for breast cancer [dissertation]. Berkeley: University of California; 1999.
54 Cummings RL. The phenomenology of meditation experiences: a developmental perspective [dissertation]. Athens: University of Georgia; 1994.
55 Davis J. Ego development of Buddhist meditators: a qualitative study [abstract]. Diss Abstr Int. 1987;48(5B):1527-8.
56 Dhanaraj VH. The influence of transcendental meditation on cessation of drug use: some preliminary findings. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1159–60.
57 Dillbeck MC. Test of a field theory of consciousness and social change: time series analysis of participation in the TM-Sidhi program and reduction of violent death in the US. Soc Indic Res. 1990;22(4):399-418.
58 Dillbeck MC, Assimakis PD, Raimondi D, et al. Longitudinal effects on the transcendental meditation and TM-Sidhi program on cognitive ability and cognitive style. Percept Mot Skills. 1986;62(3):731-8.
59 Dillbeck MC, Banus CB, Polanzi C, et al. Test of a field model of consciousness and social change: the transcendental meditation and TM-Sidhi program and decreased urban crime. J Mind Behav. 1988;9(4):457-85.
60 Dillbeck MC, Cavanaugh KL, Glenn T, et al. Consciousness as a field: the transcendental meditation and TM-Sidhi program and changes in social indicators. J Mind Behav. 1987;8(1):67-103.
61 Dillbeck MC, Orme Johnson DW, Wallace RK. Frontal EEG coherence, H-reflex recovery, concept learning, and the TM-Sidhi program. Int J Neurosci. 1981;15(3):151-7. [pmid: 7031000].
62 Dimsdale JE, Mills PJ. An unanticipated effect of meditation on cardiovascular pharmacology and physiology. Am J Cardiol. 2002;90(8):908-9. [pmid: 12372589].
63 Edwards LR. Psychological change and spiritual growth through the practice of siddha yoga [dissertation]. Philadelphia (PA): Temple University; 1986.
64 Fehr T, Nerstheimer U, Törber S. Study of personality changes resulting from the transcendental meditation program: freiburger personality inventory. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 420–4.
65 Fergusson LC, Bonshek AJ, Boudigues M. Transcendental meditation and five factors relevant to higher education in Cambodia. Coll Stud J. 1994;28(1):103-7.
66 Fischer S, Huss D, Baer RA, et al. Mindfulness based cognitive therapy for binge eating disorder: an uncontrolled pilot study. Int J Eat Disord. 2004;35(4):478.
67 Fontana JA, Colella C, Baas LS, et al. T'ai chi chih as an intervention for heart failure. Nurs Clin North Am. 2000;35(4):1031-46. [pmid: 11072287].
68 Fontana JA, Colella C, Wilson BR, et al. The energy costs of a modified form of t'ai chi exercise. Nurs Res 2000;49(2):91–6 Erratum in: Nurs Res 2000;49(3):145.
69 France R. An investigation into the effects of transcendental meditation upon hearing threshold. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2342–6.
70 Frew DR. Transcendental meditation and productivity. Acad Manage J. 1974;17(2):362-8.
71 Gardner FL, Moore ZE. A mindfulness-acceptance-commitment-based approach to athletic performance enhancement: theoretical considerations. Behav Ther. 2004;35(4):707-23.
72 Ghista DN, Nandagopal D, Mukherji A, et al. Physiological characterization of meditative state during intuitional practice (ananda-marga system of meditation) and its therapeutic value. Med Biol Eng. 1976;14(2):209-14. [pmid: 781406].
73 Gifford MD, Thompson NL. “Deep states” of meditation: phenomenological reports of experience. J Transpersonal Psychol. 1994;26(2):117-38.
74 Gillispie Z, Sherman A, Koran J, et al. Anxiety as a predictor of improvement following a yoga/meditation Intervention with dementia family caregivers. Gerontologist. 2003;43(1):325. [pmid: 12810896].
75 Greene PB. A path analytic approach to the relationship between meditation, stress, and health. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [cited 2005 Oct 10]. Available at: http://www.psychosomatic.org/meeting/2005/pageS001-S215.pdf. Paper Session #25.
76 Greene PB. Stress reactivity, health, and meditation: a path analytic approach [dissertation]. Boston: Boston University; 2004.
77 Hagelin JS, Rainforth MV, Orme-Johnson DW, et al. Effects of group practice of the transcendental meditation program on preventing violent crime in Washington, DC: results of the National Demonstration Project, June–July 1993. Soc Indic Res. 1999;47(2):153-201.
78 Hardesty MJ. The effect of transcendental meditation on reaction time. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 904–7.
79 Harding SD. The effects of transcendental meditation on an auditory temporal discrimination task. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1949–53.
80 Harrison LJ, Manocha R, Rubia K. Sahaja yoga meditation as a family treatment programme for children with attention deficit-hyperactivity disorder. Clin Child Psychol Psychiatry. 2004;9(4):479-97.
81 Hatchard GD, Deans AJ, Cavanaugh KL, et al. The Maharishi effect: a model for social improvement time series analysis of a phase transition to reduced crime in Merseyside metropolitan area. Psychol Crime Law. 1996;2(3):165-74.
82 Hayward CD. Physiologic effects of Benson's relaxation response during submaximal aerobic exercise in coronary artery disease patients [abstract]. Diss Abstr Int. 1987;47(9A):3354.
83 Hebert JR. Periodic suspension of respiration during the transcendental meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 134–6.
84 Herron RE. The impact of transcendental meditation practice on medical expenditures [dissertation]. Fairfield, IA: Maharishi International University; 1993.
85 Herron RE, Hillis SL, Mandarino JV, et al. The impact of the transcendental meditation program on government payments to physicians in Quebec. Am J Health Promot. 1996;10(3):208-16. [pmid: 10163301].
86 Hershfield NB, Kubryn W, Sutherland LR. Meditation training as adjunct therapy in the management of crohns-disease: a pilot-study. Can J Gastroenterol. 1993;7(8):613-5.
87 Heyes AD. Blindness and yoga. New Outlook Blind. 1974;68(9):385-93.
88 Huang GZ. Physiological effects during relaxation qigong exercise. Psychosom Med. 1991;53(2):228.
89 Ikemi A, Tomita S, Kuroda M, et al. Self-regulation method: psychological, physiological and clinical considerations: an overview. Psychother Psychosom. 1986;46(4):184-95. [pmid: 3306753].
90 Jain SC, Rai L, Valecha A, et al. Effect of yoga training on exercise tolerance in adolescents with childhood asthma. J Asthma. 1991;28(6):437-42. [pmid: 1744029].
91 Janakiramaiah N, Gangadhar BN, Vedamurthachar A. Enhancing wellbeing through yoga: a potential strategy for positive mental health. Aust N Z J Psychiatry. 2000;34(Suppl):A33.
92 Jedrczak A. The TM-Sidhi programme and age-related psychological variables. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1954–9.
93 Jedrczak A, Beresford M, Clements G. The TM-Sidhi program, pure consciousness, creativity and intelligence. J Creat Behav. 1985;19(4):270-5.
94 Jedrczak A, Clements G. The TM-Sidhi programme and field independence. Percept Mot Skills. 1984;59(3):999-1000. [pmid: 6395087].
95 Jedrczak A, Toomey M, Clements G. The TM-Sidhi programme, age, and brief tests of perceptual-motor speed and nonverbal intelligence. J Clin Psychol. 1986;42(1):161-4. [pmid: 3512605].
96 Jevning RA, Wilson AF, O'Halloran JP. Muscle and skin blood flow and metabolism during states of decreased activation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1633–9.
97 Jevning RA, Wilson AF, Pirkle HC. Behavioral control of red blood cell metabolism. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1605–9.
98 Jevning RA, Wilson AF, Pirkle HC, et al. Metabolic control in a state of decreased activation: modulation of red cell metabolism. Am J Physiol. 1983;245(5 Pt 1):C457-61. [pmid: 6416079].
99 Jevning RA, Wilson AF, Smith WR. Plasma amino acids during the transcendental meditation technique: comparison to sleep. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 145–7.
100 Jin P. Changes in heart rate, noradrenaline, cortisol and mood during tai chi. J Psychosom Res. 1989;33(2):197-206. [pmid: 2724196].
101 Kaldor P, Francis LJ, Fisher JW. Personality and spirituality: Christian prayer and Eastern meditation are not the same. Pastoral Psychol. 2002;50(3):165-72.
102 Kasamatsu A, Hirai T. An electroencephalographic study on the Zen meditation (Zazen). J Am Inst of Hypn. 1973;14(3):107-14.
103 Kaye VG. An innovative treatment modality for elderly residents of a nursing home. Clin Gerontol. 1985;3(4):45-51.
104 Keefer L, Blanchard EB. A one year follow-up of relaxation response meditation as a treatment for irritable bowel syndrome. Behav Res Ther. 2002;40(5):541-6. [pmid: 12038646].
105 Kenny M, Bernier R, DeMartini C. Chant and be happy: the effects of chanting on respiratory function and general well-being in individuals diagnosed with depression. Int J Yoga Ther. 2005;15:61-4.
106 Kirschner S. Zen meditators: a clinical study [abstract]. Diss Abstr Int. 1976;36(7B):3613-4.
107 Kjaer TW, Bertelsen C, Piccini P, et al. Increased dopamine tone during meditation-induced change of consciousness. Brain Res Cogn Brain Res. 2002;13(2):255-9. [pmid: 11958969].
108 Klein R, Pilon D, Prosser S, et al. Nasal airflow asymmetries and human performance. Biol Psychol. 1986;23(2):127-37. [pmid: 3790650].
109 Koar WH. Correlates of meditation, depression, anxiety and t cell counts in HIV positive patients [abstract]. Diss Abstr Int. 1996;56(9B):5174.
110 Kohr RL. Dimensionality in meditative experience: a replication. J Transpersonal Psychol. 1977;9(2):193-203.
111 Kornfield JM. The psychology of mindfulness meditation [dissertation]. San Francisco: Saybrook Graduate School; 1977.
112 Kristal AR, Littman AJ, Benitez D, et al. Yoga practice is associated with attenuated weight gain in healthy, middle-aged men and women. Altern Ther Health Med. 2005;11(4):28-33.
113 Kustner U. Effectiveness of a meditative method of therapy based on Buddhist psychology and practices: a pilot study. J Medit Medit Res. 2002;2:31-47.
114 Lan C, Chen SY, Lai JS, et al. Heart rate responses and oxygen consumption during tai chi chuan practice. Am J Chin Med. 2001;29(34):403-10. [pmid: 11789583].
115 Lang R, Dehof K, Meurer KA, et al. Sympathetic activity and transcendental meditation. J Neural Transm Gen Sect. 1979;44(12):117-35.
116 Lawrance WS. Psychotherapeutic factors of naturally occurring long-term meditation [abstract]. Diss Abstr Int. 1993;54(6A):2056.
117 Lazar SW, Bush G, Gollub RL, et al. Functional brain mapping of the relaxation response and meditation. NeuroReport. 2000;11(7):1581-5. [pmid: 10841380].
118 Lee GW. The subjective well-being of beginning vs. advanced hatha yoga practitioners [dissertation]. Honolulu: University of Hawaii; 2004.
119 Lee MS, Bae BH, Ryu H, et al. Changes in alpha wave and state anxiety during chundosunbup qi-training in trainees with open eyes. Am J Chin Med. 1997;25(34):289-99. [pmid: 9358902].
120 Lee MS, Kim BG, Huh HJ, et al. Effect of qi-training on blood pressure, heart rate and respiration rate. Clin Physiol. 2000;20(3):173-6. [pmid: 10792409].
121 Lee MS, Kim MK, Ryu H. Qi-training (qigong) enhanced immune functions: what is the underlying mechanism?. Int J Neurosci. 2005;115(8):1099-104. [pmid: 16040353].
122 Lee MS, Ryu H. Qi-training enhances neutrophil function by increasing growth hormone levels in elderly men. Int J Neurosci. 2004;114(10):1313-22. [pmid: 15370188].
123 Leffler DR. A vedic approach to military defense: reducing collective stress through the field effects of consciousness [dissertation]. Cincinnati, OH: Union Institute and University; 1997.
124 Lehmann D, Faber PL, Achermann P, et al. Brain sources of EEG gamma frequency during volitionally meditation-enduced, altered states of consciousness, and experience of the self. Psychiatry Res. 2001;108(2):111-21. [pmid: 11738545].
125 Lehrer PM, Sasaki Y, Saito Y. Zazen and cardiac variability. Psychosom Med. 1999;61(6):812-21. [pmid: 10593633].
126 Lepicovska V, Dostalek C, Kovarova M. Hatha yogic exercise jalandhara bandha in its effect on cardiovascular response to apnoea. Act Nerv Super (Praha). 1990;32(2):99-114. [pmid: 2399805].
127 Leserman J, Stuart EM, Mamish ME, et al. Nonpharmacologic intervention for hypertension: long-term follow-up. J Cardiopulm Rehabil. 1989;9(8):316-24.
128 Li Q, Matsuura Y, Tsubouchi S, et al. Changes of oxygen metabolism in the cerebrum during shaolin internal qigong. Journal of ISLIS. 2002;20(1):155-65.
129 Li Q, Matsuura Y, Tsubouchi S, Li Q, et al. A study on physiological changes in shaolin internal qigong. Journal of ISLIS. 2001;19(1):302-12.
130 Liu GL, Ciu R, Li G. Neural mechanisms of qigong state: an experimental study by the method of auditory evoked responses. J Tradit Chin Med. 1987;7(2):123-6. [pmid: 3448391].
131 Liu Y, Mimura K, Wang L, et al. Physiological benefits of 24-style taijiquan exercise in middle-aged women. J Physiol Anthropol Appl Human Sci. 2003;22(5):219-25.
132 Loliger SA. Relationship between subjective bliss, 5-hydroxy-3-indoleacetic acid and the collective practice of Maharishi's Transcendental Meditation and TM-Sidhi program [dissertation]. Fairfield, IA: Maharishi International University; 1990.
133 Lou HC, Kjaer TW, Friberg L, et al. A super(15)O-H sub(2)O PET study of meditation and the resting state of normal consciousness. Hum Brain Mapp. 1999;7(2):98-105. [pmid: 9950067].
134 Luk TC. Exploring the biomechanical characteristics of tai chi exercise and the postural balance of practitioners [dissertation]. People's Republic of China: Chinese University of Hong Kong; 2003.
135 Luzzatto P, Payne D. Creative arts and meditation retreat reduces psychological distress in cancer survivors. Psychooncology. 2004;13(1 Suppl):S11.
136 MacCallum MJ. The transcendental meditation program and creativity. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 410–4.
137 MacPhillamy DJ. Some personality effects of long-term Zen monasticism and religious understanding. J Sci Study Relig. 1986;25(3):304-19.
138 Manjunath NK, Telles S. Effects of sirsasana (headstand) practice on autonomic and respiratory variables. Indian J Physiol Pharmacol. 2003;47(1):34-42. [pmid: 12708122].
139 Maquet J. Meditation in contemporary Sri Lanka: idea and practice. J Transpersonal Psychol. 1975;7(2):182-96.
140 Maras ML, Rinke WJ, Stephens CR, et al. Effect of meditation on insulin dependent diabetes mellitus. Diabetes Educ. 1984;10(1):22-5.
141 Margid S. Meditation, creativity, and the composing process of student writers [abstract]. Diss Abstr Int. 1986;46(9A):2603.
142 McDowell AR. Faithwalk (TM): a psychospiritual approach to transformation [dissertation]. Cincinnati: Union Institute University; 2000.
143 Mcnaughton RD. The use of meditation and intuition in decision-making: reports from executive meditators [dissertation]. Santa Barbara, CA: Fielding Graduate Institute; 2003.
144 Miller JJ, Fletcher KE, Kabat-Zinn J. Three-year follow-up and clinical implications of a mindfulness meditation-based stress reduction intervention in the treatment of anxiety disorders. Gen Hosp Psychiatry. 1995;17(3):192-200. [pmid: 7649463].
145 Mills N, Allen J, Carey-Morgan S. Does tai chi/qi gong help patients with multiple sclerosis?. J Bodywork Movement Ther. 2000;4(1):39-48.
146 Mills PJ, Wallace RK. The effect of the transcendental meditation and TM-Sidhi program on the paired Hoffman reflex. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1752–5.
147 Minvaleev RS, Nozdrachev AD, Kiryanova VV, et al. Postural influences on the hormone level in healthy subjects. Communication I. The cobra posture and steroid hormones. Hum Physiol. 2004;30(4):452-6.
148 Mishra SP, Singh RH. Effect of certain yogic asanas on the pelvic congestion and it's anatomy. Ancient Sci Life. 1984;4(2):127-8.
149 Miszczak J, Achimowicz J. Hyprid analysis of spontaneous brain activity in different states of conscious experience. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2267–77.
150 Moane FM. The effect of yoga, in comparison to aerobic exercise, on anxiety and mood in a workplace setting [dissertation]. Chicago: Chicago School of Professional Psychology; 2003.
151 Morse DR. Use of meditative state for hypnotic induction in the practice of endodontics. Oral Surg Oral Med Oral Pathol. 1976;41(5):664-72. [pmid: 775373].
152 Morse DR, Martin JS, Furst ML, et al. A physiological and subjective evaluation of neutral and emotionally-charged words for meditation part I. J Am Soc Psychosom Dent Med. 1979;26(1):31-8. [pmid: 387680].
153 Motajova J, Vicenik K. Effect of hatha yoga on heart activity in exercising women. Act Nerv Super (Praha). 1980;22(2):125-6.
154 Motajova J, Vicenik K. Some relations between respiratory and heart-rate observed during yoga course. Int J Psychophysiol. 1989;7(24):320-1.
155 Murphy MB. Theta bursts and rhythmical theta trains in the transcendental meditation technique and TM-Sidhi program: a qualitative and quantitative analysis of EEG theta activity [dissertation]. Melbourne, FL: Florida Institute of Technology; 1984.
156 Mustafa S, Cooper L, Langrick N, et al. The effect of a tai chi exercise program on quality of life in patients on peritoneal dialysis: a pilot study. Perit Dial Int. 2005;25(3):291-4. [pmid: 15981780].
157 Nagendra HR, Nagarathna R. An integrated approach of yoga therapy for bronchial asthma: a 3–54-month prospective study. J Asthma. 1986;23(3):123-37. [pmid: 3745111].
158 Nidich RJ, Nidich SI, Schneider RH. The transcendental meditation program and quality of life in breast cancer patients: a feasibility study. J Psychosom Res. 2003;55(2):153.
159 Nidich SI, Abrams AI, Jones C, et al. Neurophysiological entry characteristics: correlation between EEG coherence and math achievement with subjects practicing the TM program. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1720–3.
160 Nidich SI, Nidich RJ, Abrams AI, et al. Frontal lobe functioning: EEG coherence as a predictor of highly pro-social behavior with subjects practicing the transcendental meditation and TM-Sidhi program. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2277–82.
161 Noyes L, Wong R. Demonstrating the benefits of physical therapy and tai chi for people with dementia. Gerontologist. 2004;44:95. [pmid: 14978325].
162 Orme-Johnson DW, Alexander CN, Davies JL, et al. International peace project in the Middle East: the effects of the Maharishi technology of the unified field. J Conflict Resolut. 1988;32(4):776-812.
163 Orme-Johnson DW, Clements G, Haynes CT, et al. Higher states of consciousness: EEG coherence, creativity, and experiences of the Sidhis. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 705–12.
164 Orme-Johnson DW, Dillbeck MC, Alexander CN. Preventing terrorism and international conflict: effects of large assemblies of participants in the transcendental meditation and TM-Sidhi programs. J Offender Rehabil. 2003;36(14):283-302.
165 Orme-Johnson DW, Dillbeck MC, Wallace RK, et al. Intersubject EEG coherence: is consciousness a field?. Int J Neurosci. 1982;16(34):203-9. [pmid: 6763008].
166 Orme-Johnson DW, Gelderloos P. Topographic EEG brain mapping during yogic flying. Int J Neurosci. 1988;38(34):427-34. [pmid: 3372156].
167 Orme-Johnson DW, Haynes CT. EEG phase coherence, pure consciousness, creativity, and TM-Sidhi experiences. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1687–94.
168 Orme Johnson DW, Wallace RK, Dillbeck MC. Longitudinal effects of the TM-Sidhi program on EEG phase coherence. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1678–86.
169 Orme-Johnson DW, Wallace RK, Dillbeck MC, et al. Improved functional organization in the brain through the Maharishi technology of the unified field as indicated by changes in EEG coherence and its cognitive correlates: a proposed model of higher states of consciousness. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2245–66.
170 Ornish D, Gotto AM, Miller RR, et al. Effects of a vegetarian diet and selected yoga techniques in the treatment of coronary heart disease. Clin Res. 1979;27(4):A720.
171 Osis K, Bokert E. ESP and changed states of consciousness induced by meditation. J Am Soc for Psychical Res. 1971;65(1):17-65.
172 Paty J, Vincent JD, Faure JMA. CNV studies during meditation. Electroencephalogr Clin Neurophysiol. 1977;43(4):341.
173 Peng CK, Henry IC, Mietus JE, et al. Heart rate dynamics during three forms of meditation. Int J Cardiol. 2004;95(1):19-27. [pmid: 15159033].
174 Penner WJ, Zingle HW, Dyke R, et al. Does an in-depth transcendental meditation course effect change in the personalities of the participants?. West Psychol. 1973;4(4):104-11.
175 Peper E, Kawakami M, Sata M, et al. Physiological correlates of very slow yogic breathing. Appl Psychophysiol Biofeedback. 2002;27(4):317-8.
176 Persinger MA. Enhanced incidence of “the sensed presence” in people who have learned to meditate: support for the right hemispheric intrusion hypothesis. Percept Mot Skills. 1992;75(3 Pt 2):1308-10. [pmid: 1484802].
177 Persinger MA. Transcendental meditation-super(TM) and general meditation are associated with enhanced complex partial epileptic-like signs: evidence for “cognitive” kindling?. Percept Mot Skills. 1993;76(1):80-2. [pmid: 8451153].
178 Piron H. Meditation depth, mental health, and personal development. J Medit Medit Res. 2003;3:45-58.
179 Plasse BR. A stress reduction and self-care group for homeless and addicted women: meditation, relaxation and cognitive methods. Soc Work Groups. 2001;24(34):117-33.
180 Pradhan N, Dutt ND. An analysis of dimensional complexity of brain electrical activity during meditation. In: Proceedings of the First Regional Conference of the Biomedical Engineering Society of India; 1995 Feb 15–18; New Delhi, India. New Delhi, India: IEEE; 1995. p. 92–3.
181 Raghuraj P, Ramakrishnan AG, Nagendra HR, et al. Effect of two selected yogic breathing techniques of heart rate variability. Indian J Physiol Pharmacol. 1998;42(4):467-72. [pmid: 10874345].
182 Raghuraj P, Telles S. Right uninostril yoga breathing influences ipsilateral components of middle latency auditory evoked potentials. Neurol Sci. 2004;25(5):274-80. [pmid: 15624085].
183 Rai L, Ram K. Energy expenditure and ventilatory responses during virasana, a yogic standing posture. Indian J Physiol Pharmacol. 1993;37(1):45-50. [pmid: 8449544].
184 Rai L, Ram K, Kant U, et al. Energy expenditure and ventilatory responses during siddhasana, a yogic seated posture. Indian J Physiol Pharmacol. 1994;38(1):29-33. [pmid: 8132240].
185 Rai PS. Ayurveda and yoga treatment for rheumatoid arthritis. Rheumatism. 1987;22(2):38-41.
186 Ramakrishna RK, Dukhan H, Krishna-Rao PV. Yogic meditation and psi scoring in forced-choice and free-response tests. Indian J Psychol. 1978;1(2):160-75.
187 Rao KR, Dukhan H, Rao PVK. Yogic meditation and psi scoring in forced-choice and free-response tests. In: Rao KR, ed. Basic research in parapsychology. 2nd ed. Jefferson (NC): McFarland & Co.; 2001.
188 Rao KR, Puri I. Subsensory perception (SSP), extrasensory perception (ESP) and transcendental meditation (TM). Indian J Psychol. 1978;1(1):69-74.
189 Ritskes R, Ritskes H, Merel S, et al. MRI Scanning during Zen meditation: the picture of enlightenment?. Constructivism Hum Sci. 2003;8(1):85-90.
190 Rivers SM, Spanos NP. Personal variables predicting voluntary participation in and attrition from a meditation program. Psychol Rep. 1981;49(3):795-801.
191 Rodrigues MR, Carvalho C, Resende MBD, et al. Yoga breathing exercises improve the respiratory function in duchenne dystrophy. Neuromuscul Disord. 2004;14(89):583.
192 Roldan E, Los J, Dostalek C, et al. Frequency characteristics, distribution and dominance of the EEG during rest and a yogic breathing exercise, Kapalabhati. Act Nerv Super (Praha). 1983;25(3):197.
193 Ryu H, Lee HS, Shin YS, et al. Acute effect of qigong training on stress hormonal levels in man. Am J Chin Med. 1996;24(2):193-8. [pmid: 8874677].
194 Sabel BA. Transcendental meditation and concentration ability. Percept Mot Skills. 1980;50(3 Pt 1):799-802.
195 Sachdeva U. The effect of yogic lifestyle on hypertension. Homeost Health Dis. 1994;35(45):264.
196 Sageman S. Breaking through the despair: spiritually oriented group therapy as a means of healing women with severe mental illness. J Am Acad Psychoanal Dyn Psychiatry. 2004;32(1):125-41. [pmid: 15132194].
197 Salman D. Attentional control and the deconstruction of the schemas underlying the perception of pain (New York City, somatic monitoring, cognitive flexibility) [abstract]. Diss Abstr Int. 1999;60(6B):2976.
198 Sancier KM. The effect of qigong on therapeutic balancing measured by electroacupuncture according to Voll (EAV): a preliminary study. Acupunct Electrother Res. 1994;19(23):119-27. [pmid: 7863836].
199 Sandahl FP. The effect of the practice of TM on the degree of neuroticism as measured by the defense mechanism test. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2028–33.
200 Schenkluhn H, Nat R, Geisler M. A longitudinal study of the influence of the transcendental meditation program on drug abuse. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 544–55.
201 Shannahoff-Khalsa DS, Boyle MR, Buebel ME. The effects of unilateral forced nostril breathing on cognition. Int J Neurosci. 1991;57(34):239-49. [pmid: 1938166].
202 Shapiro DH. A preliminary study of long-term meditators: goals, effects, religious orientation, cognitions. J Transpersonal Psychol. 1992;24(1):23-39.
203 Shapiro DH, Zifferblatt SM. Applied clinical combination of Zen meditation and behavioral self-management techniques: reducing methadone dosage in drug-addiction. Behav Ther. 1976;7(5):694-5.
204 Shapiro DH Jr. Adverse effects of meditation: a preliminary investigation of long-term meditators. Int J Psychosom. 1992;39(14):62-7. [pmid: 1428622].
205 Sharma HM, Stephens RE, Singh NP, et al. Physiological-response to transcendental meditation (TM) and TM-Sidhi program. Fed Proc. 1986;45(3):173.
206 Singh LN, Endo M, Yamaguchi K, et al. Imaging analysis of the brain state after performing hatha yoga: a PET study. J Cereb Blood Metab. 2001;21(Suppl 1):S35.
207 Singh R. Meditative intonation increases melatonin and positive psychophysiological effects: implications for cancer, longevity and consciousness studies. Appl Psychophysiol Biofeedback. 1998;23(2):129.
208 Singh R, Oberhummer I. Behavior-therapy within a setting of karma yoga. J Behav Ther Exp Psychiatry. 1980;11(2):135-41.
209 Sinha B, Ray US, Pathak A, et al. Energy cost and cardiorespiratory changes during the practice of surya namaskar. Indian J Physiol Pharmacol. 2004;48(2):184-90. [pmid: 15521557].
210 Smith JC, Amutio A, Anderson JP, et al. Relaxation: mapping an uncharted world. Biofeedback Self Regul. 1996;21(1):63-90. [pmid: 8833317].
211 Soskis DA, Orne EC, Orne MT, et al. Self-hypnosis and meditation for stress - a 6-month follow-up. Int J Clin Exp Hypn. 1986;34(3):272.
212 Spence NE. Following the “self” home: psycho-spiritual journeys of western women on Asian meditative paths [abstract]. Diss Abstr Int. 1994;55(5B):1995.
213 Spira JL, Kotay A. The influence of Zen meditation and stress on very low, low, and high frequency heart rate variability. Appl Psychophysiol Biofeedback. 2004;29(4):305.
214 Stancak A Jr,, Kuna M. EEG changes during forced alternate nostril breathing. Int J Psychophysiol. 1994;18(1):75-9. [pmid: 7876041].
215 Stancak A Jr,, Kuna M, Novak P, et al. Observations on respiratory and cardiovascular rhythmicities during yogic high-frequency respiration. Physiol Res. 1991;40(3):345-55. [pmid: 1751482].
216 Stancak A Jr,, Kuna M, Srinivasan DC, et al. Kapalabhati: yogic cleansing exercise II: EEG topography analysis. Homeost Health Dis. 1991;33(4):182-9. [pmid: 1818698].
217 Stancak A Jr, Kuna M, Srinivasan VS, et al. Kapalabhati: yogic cleansing exercise I: cardiovascular and respiratory changes. Homeost Health Dis. 1991;33(3):126-34. [pmid: 1818666].
218 Stück M, Meyer K, Rigotti T, et al. Evaluation of a yoga-based stress management training for teachers: effects on immunoglobulin A secretion and subjective relaxation. J Medit Medit Res. 2003;3:59-68.
219 Sung BE, Roussanov OA, Golden L. The effectiveness of relaxation techniques in the reversal of hemodynamic changes associated with mental stress. In: Proceedings of the 58th Annual Scientific Conference of the American Psychosomatic Society; 2000 March 1–4; Savannah (GA) [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1. Abstract 1256.
220 Tan G. Qigong and stress management - a preliminary inquiry. Biofeedback Self Regul. 1995;20(3):299.
221 Taneli B, Krahne W. EEG changes of transcendental meditation practitioners. Recent Adv Biol Psychiatry. 1987;16:41-71.
222 Taylor ME. Meditation as treatment for performance anxiety in singers [dissertation]. Tuscaloosa: University of Alabama; 2001.
223 Telles S, Desiraju T. Heart rate alterations in different types of pranayamas. Indian J Physiol Pharmacol. 1992;36(4):287-8. [pmid: 1291486].
224 Telles S, Desiraju T. Heart rate and respiratory changes accompanying yogic conditions of single thought and thoughtless states. Indian J Physiol Pharmacol. 1992;36(4):293-4. [pmid: 1291489].
225 Telles S, Desiraju T. Oxygen consumption during pranayamic type of very slow-rate breathing. Indian J Med Res. 1991;94:357-63. [pmid: 1794892].
226 Telles S, Naveen KV. Changes in middle latency auditory evoked potentials during meditation. Psychol Rep. 2004;94(2):398-400. [pmid: 15154162].
227 Telles S, Reddy SK, Nagendra HR. Oxygen consumption and respiration following two yoga relaxation techniques. Appl Psychophysiol Biofeedback. 2000;25(4):221-7. [pmid: 11218923].
228 Throll DA, Throll LA. The effect of a three-month residence course upon the personalities of experienced meditators. J Clin Psychol. 1990;2:1057-65.
229 Tjoa AS. Meditation, neuroticism and intelligence: a follow-up. Gedrag: Tijdschrift Voor Psychologie. 1975;3(3):167-82.
230 Tooley GA, Armstrong SM, Norman TR, et al. Acute increases in night-time plasma melatonin levels following a period of meditation. Biol Psychol. 2000;53(1):69-78. [pmid: 10876066].
231 Toomey M, Chalmers RA, Clements G. The transcendental meditation and TM-Sidhi programme and reversal of the ageing process: a longitudinal study. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1878–84.
232 Toomey M, Pennington B, Chalmers RA, et al. The practice of the transcendental meditation and the TM-Sidhi programme reverses the physiological ageing process. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1871–7.
233 Tory PB. A mindfulness-based stress reduction program for the treatment of anxiety [dissertation]. Hempstread, NY: Hofstra University; 2004.
234 Travis FT. Autonomic and EEG patterns distinguish transcending from other experiences during transcendental meditation practice. Int J Psychophysiol. 2001;42(1):1-9. [pmid: 11451476].
235 Travis FT. Testing the field paradigm of Maharishi's vedic psychology: EEG coherence and power as indices of states of consciousness and field effects. Farifield, IA: Mahrishi International University; 1989.
236 Travis FT, Olson T, Egenes T, et al. Physiological patterns during practice of the transcendental meditation technique compared with patterns while reading Sanskrit and a modern language. Int J Neurosci. 2001;109(12):71-80. [pmid: 11699342].
237 Travis FT, Pearson CA. Pure consciousness: distinct phenomenological and physiological correlates of “consciousness itself”. Int J Neurosci. 2000;100(14):77-89. [pmid: 10512549].
238 Travis FT, Tecce JJ, Arenander A, et al. Patterns of EEG coherence, power, and contingent negative variation characterize the integration of transcendental and waking states. Biol Psychol. 2002;61(3):293-319. [pmid: 12406612].
239 Travis FT, Wallace RK. Autonomic patterns during respiratory suspensions: possible markers of transcendental consciousness. Psychophysiology. 1997;34(1):39-46. [pmid: 9009807].
240 Treesak C. Mindfulness meditation as a health behavior and its relationships with health related quality of life and drug use [dissertation]. Minneapolis: University of Minnisota; 2003.
241 Tsao WY, Ratliff RA. Energy-cost of performing tai-chi. Med Sci Sports Exerc. 1982;14(2):174.
242 Udupa KN, Singh RH, Dwivedi KN, et al. Comparative biochemical studies on meditation. Indian J Med Res. 1975;63(12):1676-9. [pmid: 5370].
243 Udupa KN, Singh RH, Settiwar RM. A comparative study on the effect of some individual yogic practices in normal persons. Indian J Med Res. 1975;63(8):1066-71. [pmid: 1213802].
244 Vaananen J, Xusheng S, Wang S, et al. Taichiquan acutely increases heart rate variability. Clin Physiol Funct Imaging. 2002;22(1):2-3. [pmid: 12003094].
245 Van Nuys D. Meditation, attention, and hypnotic susceptibility: a correlational study. Int J Clin Exp Hypn. 1973;21(2):59-69.
246 Van Nuys D. A novel technique for studying attention during meditation. J Transpersonal Psychol. 1971;3(2):125-33.
247 Vempati RP, Telles S. Yoga-based guided relaxation reduces sympathetic activity judged from baseline levels. Psychol Rep. 2002;90(2):487-94. [pmid: 12061588].
248 Vempati RP, Telles S. Yoga based isometric relaxation versus supine rest: a study of oxygen consumption, breath rate and volume and autonomic measures. Indian J Psychol. 1999;17(2):46-52.
249 Venkatesh S, Raju TR, Shivani Y, et al. A study of structure of phenomenology of consciousness in meditative and non-meditative states. Indian J Physiol Pharmacol. 1997;41(2):149-53. [pmid: 9142560].
250 Vicenik K, Motajova J. Study of the heart rhythm variability during hatha yoga exercises. Act Nerv Super (Praha). 1982;24(3):175-6.
251 Wachholtz AB, Div M, Pargament K. Effect of spirituality on cardiac activity during pain and stress. Mindfulness-based stress reduction for hot flashes. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [cited 2005 Oct 10]. Available at: http://www.psychosomatic.org/meeting/2005/pageS001-S215.pdf. Paper Session #4.
252 Walia IJ, Mehra P, Grover P, et al. Health status of nurses and yoga: baseline data part 1. Nurs J India. 1989;80(9):235-7. [pmid: 2594536].
253 Walker CA. Treating chemical dependency using the 12-steps, buddhism, and complementary therapies [dissertation]. Carpinteria, CA: Pacifica Graduate Institute; 2004.
254 Wallace RK. The physiologic effects of transcendental meditation: a proposed fourth major state of consciousness. In: Orme-Johnson DW,Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 43–78.
255 Wallace RK. Physiological effects of transcendental meditation. Science. 1970;167(3926):1751. [pmid: 5416544].
256 Wallace RK, Benson H. The physiology of meditation. Sci Am. 1972;226(2):84-90. [pmid: 5058821].
257 Wallace RK, Benson H, Wilson AF. A wakeful hypometabolic physiologic state. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 79–85.
258 Wallace RK, Mills PJ, Orme Johnson DW, et al. Modification of the paired H reflex through the transcendental meditation and TM-Sidhi program. Exp Neurol. 1983;79(1):77-86. [pmid: 6337056].
259 Wallace RK, Orme-Johnson DW, Mills PJ, et al. The relationship between the paired Hoffman reflez and academic achievement in participants of the transcendental meditation (TM) program. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1772–5.
260 Wallace RK, Silver J, Mills PJ, et al. Systolic blood pressure and long-term practice of the transcendental meditation and TM-Sidhi program: effects of TM on systolic blood pressure. Psychosom Med. 1983;45(1):41-6. [pmid: 6405445].
261 Wang HM. Length and frequency of practice of Zen meditation and personality for meditators in Taiwan (China) [dissertation]. College Station: Texas A & M University; 2000.
262 Weathers RS. Meditation, altered states, and unpleasant experiences: a structural-development analysis [abstract]. Diss Abstr Int. 1986;46(10B):3620-1.
263 Weldon JT, Aron A. The transcendental meditation program and normalization of weight. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 301–6.
264 Werner OR, Wallace RK, Charles BM, et al. Endocrine balance and the TM-Sidhi programme. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1626–32.
265 Werner OR, Wallace RK, Charles BM, et al. Long-term endocrinologic changes in subjects practicing the transcendental meditation and TM-Sidhi program. Psychosom Med. 1986;48(12):59-66. [pmid: 3511493].
266 Werntz DA, Bickford RG, Shannahoff-Khalsa DS. Selective hemispheric stimulation by unilateral forced nostril breathing. Hum Neurobiol. 1987;6(3):165-71. [pmid: 3449485].
267 West MA. Changes in skin resistance in subjects resting, reading, listening to music or practicing the transcendental meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 224–9.
268 West MA. Meditation, personality and arousal. Pers Individ Dif. 1980;1(2):135-42.
269 Williams AP. The effects of yoga training on concentration and selected psychological variables in young adults [abstract]. Diss Abstr Int. 1993;53(7B):3801.
270 Windquist WT. The transcendental meditation program and drug abusers: a retrospective study. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 494–7.
271 Winters TH, Kabat-Zinn J. Awareness meditation for patients who have anxiety and chronic pain in the primary care unit. Clin Res. 1981;29(2):A642.
272 Woolfolk RL, Rooney AJ. The effect of explicit expectations on initial meditation experiences. Biofeedback Self Regul. 1981;6(4):483-91. [pmid: 7034791].
273 Wrycza P. Some effects of the transcendental meditation and TM-Sidhi programme on artistic creativity and appreciation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2378–83.
274 Wu PL. Zen meditation, self-awareness, and autonomy [abstract]. Diss Abstr Int. 1992;53(6B):3174.
275 Yadav RK, Das S. Effect of yogic practice on pulmonary functions in young females. Indian J Physiol Pharmacol. 2001;45(4):493-6. [pmid: 11883159].
276 Yin J, Levanon D, Chen JD. Inhibitory effects of stress on postprandial gastric myoelectrical activity and vagal tone in healthy subjects. Neurogastroenterol Motil. 2004;16(6):737-44. [pmid: 15601423].
277 Young RP. The experiences of cancer patients practicing mindfulness meditation [dissertation]. San Francisco: Saybrook Graduate School; 1999.
278 Zakutney MA. An investigation of the transcendental meditation technique as a positive health action: why people start and continue the practice [dissertation]. Salt Lake City: University of Utah; 1990.
279 Zetaruk MN, Violan MA, Zurakowski D, et al. Injuries in martial arts: a comparison of five styles. Br J Sports Med. 2005;39(1):29-33. [pmid: 15618336]. [pmcid: 1725005].
280 Zhang JZ, Zhao J, He QN. EEG findings during special psychical state (qi gong state) by means of compressed spectral array and topographic mapping. Comput Biol Med. 1988;18(6):455-63. [pmid: 3060312].

## Excluded: Outcomes—Inadequate Reporting (N = 170)

The following studies were excluded because data relevant to the outcomes of interest were inadequately reported.

### References

1 Albert IB, McNeece B. The reported sleep characteristics of meditators and nonmeditators. Bull Psychon Soc. 1974;3(1B):73-4.
2 Alexander CN, Grant JD, Von Stadte C. The effects of the transcendental meditation technique on recidivism: a retrospective archival analysis. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2135–51.
3 Alexander CN, Rainforth MV, Frank PR, et al. Walpole study of the transcendental meditation program in maximum security prisoners III: reduced recidivism. J Offender Rehabil. 2003;36(14):161-80.
4 Allen CP. Effects of transcendental meditation, electromyographic (EMG) biofeedback relaxation, and conventional relaxation on vasoconstriction, muscle tension, and stuttering: a quantitative comparison. In: Chalmers RA, Clements G,,Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2287–9.
5 Anderson DA. Meditation as a treatment for primary dysmenorrhea among women with high and low absorption scores [abstract]. Diss Abstr Int. 1984;45(1B):341.
6 Anthony W. An evaluation of meditation as a stress reduction technique for persons with spinal cord injury [abstract]. Diss Abstr Int. 1986;46(11A):3251.
7 Balzano JM, Burke JL, Hoy TW, et al. A comparative study of balance measures among elderly persons participating in tai chi or structured exercise programs. J Geriatr Phys Ther. 2002;25(3):44.
8 Banquet JP. Spectral analysis of the EEG in meditation. Electroencephalogr Clin Neurophysiol. 1973;35(2):143-51. [pmid: 4124606].
9 Bevan AJW, Young PM, Wellby ML, et al. Endocrine changes in relaxation procedures. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 803.
10 Bleick CR. Influence of the transcendental meditation program on criminal recidivism. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 3. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 2151–8.
11 Bleick CR, Abrams AI. The transcendental meditation program and criminal recidivism in California. J Crim Justice. 1987;15(3):211-30.
12 Bond DS, Lyle RM, Tappe MK, et al. An evaluation of the importance of moderate aerobic exercise, tai chi, and problem-solving ability in relation to psychological stress. Res Q Exerc Sport. 1999;70(1 Suppl):A36.
13 Brandon JE. A comparative evaluation of three relaxation training procedures. Diss Abstr Int. 1983;43(7A):2279.
14 Breda ML, Gevirtz R, Spira JL, et al. A controlled clinical trial of the effects of yoga on health status in fibromyalgia patients In: Proceedings of the 63rd Annual Scientific Conference of the American Psychosomatic Society; 2005 March 2–5; Vancouver (BC) [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1#. Abstract 1683
15 Bridgewater MJ. The relative efficacy of meditation in reducing an induced anxiety reaction [abstract]. Diss Abstr Int. 1979;40(2B):903-4.
16 Burrows CH. The effects of meditation on counselor candidates' self-actualization [abstract]. Diss Abstr Int. 1984;45(3A):749.
17 Campbell JF, Stenstrom RJ, Bertrand D. Systematic changes in perceptual reactance induced by physical fitness training. Percept Mot Skills. 1985;61(1):279-84. [pmid: 3900922].
18 Carlson LE, Culos-Reed SN, Daroux LM. The effects of therapeutic yoga on salivary cortisol, stress symptoms, quality of life and mood states in cancer outpatients: a randomized controlled study. In: Proceedings of the 63rd Annual Scientific Conference of the American Psychosomatic Society; 2005 March 2–5; Vancouver (BC) [cited 2005 Oct 9]. Available at: http://www.sbm.org/events/search2006/showkeysearch.cfm?authorsearch=1#. Abstract 1342.
19 Carmody J, Crawford SL, Kelsey JL. Mindfulness-based stress reduction for hot flashes. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [cited 2005 Oct 10]. Available at: http://www.psychosomatic.org/meeting/2005/pageS001-S215.pdf. Symposium 5-C.
20 Carrieri-Kohlmann V, Stulbarg S. Yoga for treating shortness of breath in chronic obstructive pulmonary disease (COPD). Bethesda (MD): National Library of Medicine (US). c2003 [updated 2006 Jul 25; cited 2006 Aug 7]. Available at: http://clinicaltrials.gov/ct/show/NCT00051792.
21 Carsello CJ, Creaser JW. Does transcendental meditation training affect grades?. J Appl Psychol. 1978;63(5):644-5. [pmid: 359536].
22 Carsello CJ, Creaser JW. Does transcendental meditation training affect grades?. J Appl Psychol. 1978;63(4):527-8.
23 Carson JW. Mindfulness meditation-based treatment for relationship enhancement [abstract]. Diss Abstr Int. 2003;63(8B):3906.
24 Carson JW, Keefe FF, Carson KM. Loving-kindness meditation for chronic low back pain. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [2005 Oct 10]. Available at: http://www.psychosomatic.org/meeting/2005/pageS001-S215.pdf. Paper Session #25.
25 Cauthen NR, Prymak CA. Meditation versus relaxation: an examination of the physiological effects of relaxation training and of different levels of experience with transcendental meditation. J Consult Clin Psychol. 1977;45(3):496-7. [pmid: 325034].
26 Cerpa H. The effects of clinically standardized meditation on type II diabetics [abstract]. Diss Abstr Int. 1989;49(8B):3432.
27 Chandiramani K, Jena R, Verma SK. Human figure drawings of prisoners and vipassana. J Projective Psychol Ment Health. 1995;2(2):153-8.
28 Chang BH, Jones D, Hendricks A, et al. Relaxation response for Veterans Affairs patients with congestive heart failure: results from a qualitative study within a clinical trial. Prev Cardiol. 2004;7(2):64-70. [pmid: 15133373].
29 Clark VL. Absorption as a mediator of the effect of meditation on attention and anxiety [abstract]. Diss Abstr Int. 1984;44(8B):2549.
30 Cohen L, Warneke C, Fouladi RT, et al. A Tibetan yoga program for cancer patients. In: Proceedings of the 61st Annual Scientific Conference of the American Psychosomatic Society; 2003 March 13–16; Phoenix (AR) [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1. Abstract 1234.
31 Colby F. The effects of three procedures designed to produce alternate states of consciousness upon self-reports of memory and current awareness [abstract]. Diss Abstr Int. 1987;47(8B):3513.
32 Collins LA. Stress management and yoga [abstract]. Diss Abstr Int. 1984;45(1A):116.
33 Couture RT. Effects of mental training on the performance of military endurance and precision tasks in the Canadian forces [abstract]. Diss Abstr Int. 1992;53(2A):440.
34 Cummings VT. The effects of endurance training and progressive relaxation-meditation on the physiological response to stress [abstract]. Diss Abstr Int. 1984;45(2A):451.
35 de Santis JJ. Effects of the intensive Zen Buddhist meditation retreat on Rogerian congruence as real-self/ideal-self disparity on the California Q-Sort [abstract]. Diss Abstr Int. 1986;46(8B):2801.
36 DeWolfe EJF III. Personal growth in the Maitri Space Awareness program [abstract]. Diss Abstr Int. 1994;55(2B):576.
37 Dice ML. The effectiveness of meditation on selected measures of self-actualization [abstract]. Diss Abstr Int. 1979;40(5A):2534.
38 Diefenbach K, Doig D, Mccaul A, et al. Short-term assessment of yoga or electromyographic (EMG) biofeedback (BF) in primary hypertension (PH). Clin Res. 1976;24(5):A647.
39 Ditto B, Eclache M, Goldman N. Short-term autonomic and cardiovascular effects of mindfulness meditation. In: Proceedings of the 2005 SBM Annual Meeting; 2005 Apr 13–16; Boston (MA) [cited 2005 Oct 10]. Available at: http://www.psychosomatic.org/meeting/2005/pageS001-S215.pdf. B32.
40 Dua JK. Effect of meditation and progressive relaxation training on reported relaxation and on blood pressure [abstract]. Aust Psychol. 1984;19(1):71.
41 Easterlin BL. Buddhist vipassana meditation and daily living: effect on cognitive style, awareness, affect and acceptance [abstract]. Diss Abstr Int. 1994;54(8B):4369.
42 Engel K. Meditative experience and different paths: data based analyses. J Medit Medit Res. 2001;1:35-54.
43 Esonis SS. The relative efficacy of the relaxation response, the self-control triad and food sensitivity intervention in the treatment of hypertension [abstract]. Diss Abstr Int. 1986;47(6B):2613.
44 Fabick SD. The relative effectiveness of systematic desensitization, cognitive modification, and mantra meditation in the reduction of test anxiety [abstract]. Diss Abstr Int. 1977;37(8A):4862.
45 Fehr T. The role of simplicity (effortlessness) as a prerequisite for the experience of pure consciousness the non-dual state of oneness: “turiya”, “samadhi” in meditation. J Medit Medit Res. 2002;2:49-77.
46 Fiebert MS, Mead TM. Meditation and academic performance. Percept Mot Skills. 1981;53(2):447-50.
47 Flarity JR. A physiological evaluation of two relaxation protocols on the elicitation of the relaxation response during treadmill walking exercise [abstract]. Diss Abstr Int. 1991;52(2B):688.
48 Francis TL. Meditation, flow, and heavy social alcohol use among college students [abstract]. Diss Abstr Int. 1993;54(2A):425.
49 Frank MR. Transactional analysis and meditation training as interventions in teacher education: an exploratory study [abstract]. Diss Abstr Int. 1978;39(2A):823-4.
50 Friskey LM. Effects of a combined relaxation and meditation training program on hypertensive patients [abstract]. Diss Abstr Int. 1985;46(1B):300.
51 Fritz G. The effects of meditation upon peer counselor effectiveness [abstract]. Diss Abstr Int. 1980;40(11A):5730-1.
52 Fulton MA. The effects of relaxation training and meditation on stress, anxiety, and subjective experience in college students [abstract]. Diss Abstr Int. 1990;51(2A):414-5.
53 Furedy JJ, Wright C. Effects of yoga training on sympathetic and parasympathetic reactions to relaxation instructions and cognitive stress: joint use of heart-rate and T-wave amplitude. Psychophysiology. 1988;25(4):448-9.
54 Garfinkel MS. The effect of yoga and relaxation techniques on outcome variables associated with osteoarthritis of the hands and finger joints [abstract]. Diss Abstr Int. 1992;53(5A):1408.
55 Gaughan AM. Pain perception following regular practice of meditation, progressive muscle relaxation and sitting [abstract]. Diss Abstr Int. 1991;52(4B):2295.
56 Gillis MW. A study of the effect of the relaxation response on women undergoing assisted reproductive technology [abstract]. Diss Abstr Int. 1992;53(5B):2530.
57 Gilmore JV. Relative effectiveness of meditation and autogenic training for the self-regulation of anxiety [abstract]. Diss Abstr Int. 1985;45(8B):2686.
58 Gitiban K. Anxiety reduction through muscular relaxation and meditation [dissertation]. Diss Abstr Int. 1983;44(2B):607.
59 Glanz RS. The effect of the relaxation response on complex cognitive processes [abstract]. Diss Abstr Int. 1991;53(4B):2088.
60 Goldberg LS, Meltzer G. Arrow-dot scores of drug-addicts selecting general or yoga therapy. Percept Mot Skills. 1975;40(3):726. [pmid: 1178355].
61 Goldman BL. The efficacy of meditation in the reduction of reported anxiety with controls for expectancy [abstract]. Diss Abstr Int. 1978;38(12B):6152-3.
62 Greeson JM, Rosenzweig S, Vogel W, et al. Mindfulness meditation and stress physiology in medical students. Psychosom Med. 2001;63(1):158.
63 Hall EG, Hardy CJ. Ready, aim, fire: relaxation strategies for enhancing pistol marksmanship. Percept Mot Skills. 1991;72(3 Pt 1):775-86.
64 Heaton DP, Orme-Johnson DW. The transcendental meditation program and academic achievement. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 396–9.
65 Herzberger HG. Voice quality and Maharishi's transcendental meditation and TM-Sidhi program: vocal acoustics in health and higher states of awareness [abstract]. Diss Abstr Int. 1992;53(6B):3190.
66 Higuchi AA. Effects of self-induced relaxation on autonomic responses and subjective distress of high and low-neuroticism scorers to aversive baby cries [abstract]. Diss Abstr Int. 1977;37(8B):4142-3.
67 Holmer ML, Gevirtz R, Spira JL, et al. The effects of yoga on symptoms and psychosocial adjustment in fibromyalgia syndrome patients. Appl Psychophysiol Biofeedback. 2004;29(4):302.
68 Howorka K, Pumpria J, Heger G, et al. Computerised assessment of autonomic influences of yoga using spectral analysis of heart rate variability. In: Proceedings of the First Regional Conference of the Biomedical Engineering Society of India; 1995 Feb 15–18; New Delhi, India. New Delhi, India: IEEE; 1995. p. 61–2.
69 Hsiao-Wecksler ET, Ramachandran AK, Yang Y, et al. Tai chi affects gait and obstacle crossing behaviors. Med Sci Sports Exerc. 2004;36(5 Suppl):S46.
70 Hungerman PW. The effectiveness of the relaxation response in reducing anxiety and promoting self-actualization in counselor trainees [abstract]. Diss Abstr Int. 1985;46(4B):1324.
71 Irwin MR. Effects of a behavioral intervention, tai chi chih, on elevated plasma levels of interleukin-6 in older adults. In: Proceedings of the 63rd Annual Scientific Conference of the American Psychosomatic Society; 2005 March 2–5; Vancouver (BC) [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1#. Abstract 1248.
72 Janowiak JJ. The effects of meditation on college students' self-actualization and stress management [abstract]. Diss Abstr Int. 1993;53(10A):3449-50.
73 Jevning RA, Smith R, Wilson AF, et al. Alterations of blood flow during transcendental meditation. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 786.
74 Jevning RA, Wilson AF. Altered red cell metabolism in TM. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 814.
75 Jewell HA. The effects of meditation and progressive relaxation upon heroin addicts during methadone-aided detoxification [abstract]. Diss Abstr Int. 1984;45(1B):354.
76 Johnson EM. Anxiety, drug consumption, and personality correlates of yoga and progressive muscle relaxation [abstract]. Diss Abstr Int. 1983;44(6B):1962.
77 Johnson TA, Kristeller JL, Sheets V, et al. A comparison of meditation, psychoeducational, and control groups on eating self-efficacy in an obese binge eating population. Int J Eat Disord. 2004;35(4):483-4.
78 Keating TM, Lightbody J, Adams D. Comparison of self-selected versus investigator-assigned mantras on the physiologic responses to breathing meditation. Res Q Exerc Sport. 2005;76(1 Suppl):A40-1.
79 Kember P. The transcendental meditation technique and academic performance: a short report on a controlled longitudinal pilot study. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2384.
80 Kember P. The transcendental meditation technique and postgraduate academic performance. Br J Educ Psychol. 1985;55(2):164-6.
81 Kesterson JB. Changes in respiratory patterns and control during the practice of the transcendental meditation technique [abstract]. Diss Abstr Int. 1987;47(10B):4337-8.
82 Kindler HS. The influence of a meditation-relaxation technique on group problem-solving effectiveness [abstract]. Diss Abstr Int. 1979;39(7A):4370-1.
83 Kirsch I, Henry D. Self-desensitization and meditation in the reduction of public speaking anxiety. J Consult Clin Psychol. 1979;47(3):536-41. [pmid: 43339].
84 Kobal G, Wandhoeffer A, Plattig KH. EEG power spectra and auditory evoked potentials in transcendental meditation (TM). In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 823–4.
85 Kolbell RM. Effects of stress management intervention on health and cognitive function: children's services division workers [abstract]. Diss Abstr Int. 1993;53(8A):2691.
86 Kristeller JL, Quillian-Wolever RE. The use of mindfulness meditation techniques in treatment of binge eating disorder. Abstracts at the 2003 International Conference On Eating Disorders Clinical And Scientific Challenges: The Interface Between Eating Disorders And Obesity; 2003 May 29–31; Denver, CO. Abstract 005. Available at: http://www3.interscience.wiley.com/cgi-bin/fulltext/104533973/PDFSTART.
87 Landrith GS III, Dillbeck MC. The growth of coherence in society through the Maharishi effect: reduced rates of suicides and auto accidents. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2479–86.
88 Lang D. Integrating a stress management mini-course into a personal health course. Education Resources Information Center (ERIC). Lanham, MD. ED228179; 1982.
89 Lee EO, Song R, Bae SC. Effects of 12-week tai chi exercise on pain, balance, muscle strength, and physical functioning in older patients with osteoarthritis: randomized trial. Arthritis Rheum. 2001;44(9 Suppl):S393.
90 Lee EO, Song R, Bae SC. Effects of a sun-style tai chi exercise on motivation and the performance of health behaviors in older women with osteoarthritis. Arthritis Rheum. 2003;48(9 Suppl):S689.
91 Lehrer PM, Woolfolk RL. Psychophysiological effects of progressive relaxation and mantra meditation. Biol Psychol. 1980;11:269.
92 Lesser DP. Yoga asana and self actualization: a Western psychological perspective [abstract]. Diss Abstr Int. 1986;46(10A):2972.
93 Lev D. Focused attention: the impact of concentrative meditation on cognitive control and altered states of consciousness [abstract]. Diss Abstr Int. 1995;55(8B):3618.
94 Levine PH, Hebert JR, Haynes CT, et al. EEG coherence during the transcendental meditation technique. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 187–207.
95 Li F, Fisher J. A tai chi intervention to improve balance: an examination of change in activity-related balance confidence and fear of falling. Gerontologist. 2002;42:222.
96 Li W, Xing Z, Pi D, et al. Influence of qi-gong on plasma TXB2 and 6-keto-PGF1 alpha in two TCM types of essential hypertension. Hunan Yi Ke Da Xue Xue Bao. 1997;22(6):497-9. [pmid: 10072988].
97 Li W, Xing Z, Pi D, et al. The efficacy of qigong training in patients with various TCM types of hypertension. Hunan Yi Ke Da Xue Xue Bao. 1996;21(2):123-6.
98 Lin PS. The effects of three-month tai-chi-chuan exercise program on health promotion for the community dwelling elderly. J Am Geriatr Soc. 2000;48(8):S74.
99 Maher MF. Movement exploration and Zazen meditation: a comparison of two methods of personal-growth-group approaches on the self-actualization potential of counselor candidates [abstract]. Diss Abstr Int. 1979;39(9A):5329.
100 Maldonado EF, Manzaneque JM, Vera FM, et al. Effects of a qigong meditation program on plasmatic lipid concentrations, cardiovascular function, and anxiety levels. J Psychophysiol. 2003;17(1):49.
101 Mandle CL, Domar AD, Harrington DP, et al. The relaxation response in patients undergoing femoral arteriograms. Circulation 1988;78(4 Suppl 2):II615.
102 Moadel AB, Shah C, Shelov D, et al. Effects of yoga on quality of life among breast cancer patients in Bronx, New York. Psychooncology. 2004;13(8 Suppl):S107-8.
103 Moles EA. Zen meditation: a study of regression in service of the ego [abstract]. Diss Abstr Int. 1977;38(6B):2871-2.
104 Moscoso MS, Reheiser EC, Hann DA. Effects of a brief mindfulness-based stress reduction intervention on cancer patients. Psychooncology. 2004;13(1 Suppl):S12.
105 Moscoso MS, Reheiser EC, Hann DA. Effects of a brief mindfulness meditation intervention in cancer patients. Psychooncology. 2004;13(8 Suppl):S108.
106 Motivala SJ, Irwin MR. A behavioral practice, tai chi, induces acute decreases in sympathetic nervous system activation in older adults In: Proceedings of the 63rd Annual Scientific Conference of the American Psychosomatic Society; 2005 March 2–5; Vancouver (BC) [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1#. Abstract 1454.
107 Naifeh KH. Meditation, rest, and sleep onset: a comparison of EEG and respiration changes [abstract]. Diss Abstr Int. 1993;53(12B):6608.
108 Newman JA. Affective empathy training with senior citizens using Zazen (Zen) meditation [abstract]. Diss Abstr Int. 1994;55(5A):1193.
109 Nidich SI, Schneider RH, Fields J, et al. Effects of the transcendental meditation program on emotional wellbeing in elderly breast cancer patients: preliminary results from a randomized controlled study. J Psychosom Res. 2003;55(2):153-4.
110 Niederman R. The effects of chi-kung on spirituality and alcohol/other drug dependency recovery. Alcohol Treat Q. 2003;21(1):79-87.
111 Nielsen HL, Kaszniak AW. Emotion experience and heartbeat detection in long-term meditators. Psychophysiology. 2002;39(1 Suppl):S62.
112 North AC, Hargreaves DJ. Responses to music in aerobic exercise and yogic relaxation classes. Br J Psychol. 1996;87(4):535-47.
113 O'Grady M, Wolf SL, Barnhart HX, et al. Tai chi effect on falls in frail older adults. Arch Phys Med Rehabil. 1997;178:1028.
114 Oken BS, Kishiyama S, Zajdel D, et al. Randomized controlled trial of exercise and yoga in healthy seniors. Neurology. 2004;62(7 Suppl 5):A130.
115 Otis LS. The facts on transcendental meditation: III if well-integrated but anxious, try TM. Psychol Today. 1974;7(11):45-6.
116 Ottens AJ. The effect of transcendental meditation upon modifying the cigarette smoking habit [abstract]. Diss Abstr Int. 1975;35(11A):7131.
117 Pickersgill MJ, White W. The physiological and psychological states of subjects practicing Transcendental Meditation. Bull Eur Physiopathol Respir. 1984;20(1):94-9.
118 Polowniak WA. The meditation-encounter-growth group [abstract]. Diss Abstr Int. 1973;34(4B):1732.
119 Rainforth MV, Alexander CN, Cavanaugh KL. Effects of the transcendental meditation program on recidivism among former inmates of Folsom Prison: survival analysis of 15-year follow-up data. J Offender Rehabil. 2003;36(14):181-203.
120 Ramsey MK. A comparative study of the effectiveness of the relaxation response and personalized relaxation tapes in medical technology students. Health Educ. 1986;17(5):22-5.
121 Ramsey MK. A comparative study of the effectiveness of the relaxation response and personalized relaxation tapes in medical technology students [abstract]. Diss Abstr Int. 1985;45(11A):3285.
122 Regan L, Murray ML, Quirk SW. Efficacy of meditation in the remediation of alexithymic characteristics. In: Proceedings of the 60th Annual Scientific Conference of the American Psychosomatic Society; 2002 March 13–16; Barcelona, Spain [cited 2005 Oct 9]. Available at: http://www.psychosomatic.org/events/search2006/showkeysearch.cfm?authorsearch=1. Abstract 1176.
123 Reiman JW. The impact of meditative attentional training on measures of select attentional parameters and on measure of client perceived counselor empathy [abstract]. Diss Abstr Int. 1985;46(6A):1569.
124 Ricci L. The effect of forced nostril breathing on verbal and spatial processing and on the duration of the spiral aftereffect in different visual half fields [abstract]. Diss Abstr Int. 1985;46(2B):657.
125 Rice S, Cucci III L, Williams J. Practice variables as predictors of stress and relaxation dispositions for yoga and meditation. In: Smith JC, ed. Advances in ABC relaxation. New York: Springer; 2001. p. 193–6.
126 Riddle AG. Effects of selected elements of meditation on self-actualization, locus of control, and trait anxiety [abstract]. Diss Abstr Int. 1980;40(7B):3419.
127 Riedesel BC. Meditation and empathic behavior: a study of clinically standardized meditation and affective sensitivity [abstract]. Diss Abstr Int. 1983;43(10A):3274.
128 Riley TG. A study of the attentional characteristics of long-term Zen meditators [abstract]. Diss Abstr Int. 1990;51(4B):2049.
129 Rios RJ. The effect of hypnosis and meditation on state and trait anxiety and locus of control. Int J Clin Exp Hypn. 1982;30(2):200.
130 Rosenthal JM. The effect of the transcendental meditation program on self-actualization, self-concept. and hypnotic susceptibility In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1036.
131 Rudolph SG. The effect on the self concept of female college students of participation in hatha yoga and effective interpersonal relationship development classes [dissertation]. Manhattan (KS): Kansas State University; 1991.
132 Russie RE. The influence of transcendental meditation on positive mental health and self-actualization; and the role of expectation, rigidity, and self-control in the achievement of these benefits [abstract]. Diss Abstr Int. 1976;36(11B):5816.
133 Rutschman JR. Effects of techniques of receptive meditation and relaxation on attentional processing. Can Undergraduate J Cogn Sci: CJUCS. 2004;7:6-16.
134 Salmon PG, Chmiel J, Christmas B, et al. The effect of brief physical activity and relaxation/meditation sessions on positive and negative affect. Med Sci Sports Exerc. 2004;36(5 Suppl):S286.
135 Saltzman AP, Fisk S, Shoor SM. Randomized controlled trial of the clinical and cost-effectiveness of mindfulness meditation in the treatment of chronic illness and chronic pain. Psychosom Med. 1995;57(1):89.
136 Schlesiger H. The effectiveness of anxiety reduction techniques in the foreign language classroom [abstract]. Diss Abstr Int. 1996;57(1A):139.
137 Schoicket SL. Meditation training and stimulus control as treatments for sleep-maintenance insomnia [abstract]. Diss Abstr Int. 1987;47(11B):4664.
138 Schuster L. The effects of brief relaxation techniques and sedative music on levels of tension [abstract]. Diss Abstr Int. 1982;43(6B):2002.
139 Sephton SE, Lynch G, Weissbecker I, et al. Effects of a meditation program on symptoms of illness and neuroendocrine responses in women with fibromyalgia. Psychosom Med. 2001;63(1):91-2.
140 Shaw PH. Relaxation training in anxiety and stress management: differential effects of an audible vs imaginal meditational focus [abstract]. Diss Abstr Int. 1987;47(11B):4664.
141 Shellman HF. Efficacy of electromyographic biofeedback and the relaxation response in the treatment of situation-specific anxiety [abstract]. Diss Abstr Int. 1980;40(12B Pt 1):5831-2.
142 Siddall YR. An experiment comparing the effects of two techniques that elicit the relaxation response on stress reduction and cognitive functioning in first year law students at Southern Illinois University at Carbondale [abstract]. Diss Abstr Int. 1986;46(11A):3299.
143 Siebert JR. Meditation, absorption, and anxiety: predisposition and training effects [abstract]. Diss Abstr Int. 1994;55(3B):1193.
144 Sime W. A comparison of exercise and meditation in reducing physiological responses to stress. Med Sports Sci. 1977;9:55.
145 Slaughter EJ. Hypertension: a comparative study of self-regulation strategies [abstract]. Diss Abstr Int. 1984;45(2B):687.
146 Slobodin P. A comparison of the effectiveness of progressive relaxation training and the relaxation response technique as a function of perceived locus of control of reinforcement in tension reduction [abstract]. Diss Abstr Int. 1979;39(12B):6167.
147 Smith JC. ABC relaxation theory and yoga, meditation, and prayer: relaxation dispositions, motivations, beliefs, and practice patterns. In: Smith JC, ed. Advances in ABC relaxation. New York: Springer; 2001. p. 197–201.
148 Smith JC, Goc NL, Kinzer DJ. Initial trial of the Smith intercentering inventory: progressive muscle relaxation versus yoga stretching versus breathing relaxation In: Smith JC, ed. Advances in ABC relaxation. New York: Springer; 2001. p. 212–24.
149 Solberg EE, Berglund KA, Engen O, et al. The effect of meditation on shooting performance. Br J Sports Med. 1996;30(4):342-6. [pmid: 9015599]. [pmcid: 1332422].
150 Soskis DA, Orne EC, Orne MT, et al. Self-hypnosis and meditation for stress management. Int J Clin Exp Hypn. 1989;37(4):285-9. [pmid: 2676870].
151 Spanos NP, Stam HJ, Rivers SM, et al. Meditation, expectation and performance on indices of nonanalytic attending. Int J Clin Exp Hypn. 1980;28(3):244-51. [pmid: 6993377].
152 Steinmiller GA. The relaxation response as a stress coping strategy for student teachers [abstract]. Diss Abstr Int. 1985;46(6A):1601-2.
153 Sterling SK. Affective change following a ten day vipassana meditation retreat [abstract]. Diss Abstr Int. 1996;57(6B):4044.
154 Tandon MK. Adjunct therapy with yoga in chronic severe airways obstruction. Aust N Z J Med. 1977;7(1):96.
155 Tercilla E. Efficacy of relaxation techniques in the attenuation of cognitive versus somatic anxiety [abstract]. Diss Abstr Int. 1981;41(7B):2783.
156 Thomas BL. Self-esteem and life satisfaction in noninstitutionalized elderly black females: effects of meditation/relaxation training [abstract]. Diss Abstr Int. 1987;48(4B):1180.
157 Tsang HWH, Mok CK, Yeung YTA, et al. The effect of qigong on general and psychosocial health of depressed elderly with chronic physical illnesses: a randomized clinical trial. Int Psychogeriatr. 2003;15(2 Suppl):189-90.
158 Val Marcus S. The influence of the transcendental meditation technique on the marital dyad. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2477–8.
159 Vedanthan PK, Murthy KC, Duvall K, et al. Clinical trial of yoga techniques in university students with asthma: a controlled study. J Allergy Clin Immunol. 1992;89(1):344.
160 Volweider FH. A comparison of short-term yoga and buddy-oriented groups with chronic psychiatric patients [abstract]. Diss Abstr Int. 1982;42(8B):3448.
161 Walder JM. The effects on a measure of self-actualization of adding a meditation exercise to a sensitivity group-group facilitator training program [abstract]. Diss Abstr Int. 1976;36(10A):6533-4.
162 Warrenburg WS. Meditation and hemispheric specialization [abstract]. Diss Abstr Int. 1979;40(6B):2892-3.
163 Williams RD. The effects of shamatha meditation on attentional and imaginal variables [abstract]. Diss Abstr Int. 1985;46(1B):319-20.
164 Wolf SL, Kutner NG, Green RC, et al. The Atlanta FICSIT study: two exercise interventions to reduce frailty in elders. J Am Geriatr Soc. 1993;41(3):329-32. [pmid: 8440859].
165 Wolfson L, Whipple R, Judge JO, et al. Training balance and strength in the elderly to improve function. J Am Geriatr Soc. 1993;41(3):341-3. [pmid: 8440862].
166 Wood CJ. Meditation and relaxation and their effect upon the pattern of physiological response during the performance of a fine motor and gross motor task [abstract]. Diss Abstr Int. 1983;44(5A):1378.
167 Woolfolk RL, Lehrer PM, McCann BS, et al. Effects of progressive relaxation and meditation on cognitive and somatic manifestations of daily stress. Behav Res Ther. 1982;20(5):461-7. [pmid: 6758758].
168 Zhang JZ, Li JZ, He QN. Statistical brain topographic mapping analysis for EEGs recorded during qi gong state. Int J Neurosci. 1988;38(34):415-25. [pmid: 3286559].
169 Zimmerman JD. The influence of attentional focus on mood, memory, and state self-consciousness following exercise and meditation [abstract]. Diss Abstr Int. 1986;47(4B):1751.
170 Zuroff DC, Schwarz JC. Transcendental meditation versus muscle relaxation: two-year follow-up of a controlled experiment. Am J Psychiatry. 1980;137(10):1229-2. [pmid: 6998304].

## Excluded: Population—Non-Adult (N = 9)

The following studies were excluded because they did not examine an adult population

### References

1 Barnes VA, Treiber FDH. Impact of transcendental meditation on cardiovascular function at rest and during acute stress in adolescents with high normal blood pressure. J Psychosom Res. 2001;51(4):597-605. [pmid: 11595248].
2 Borker AS, Pednekar JR. Effect of pranayam on visual and auditory reaction time. Indian J Physiol Pharmacol. 2003;47(2):229-30. [pmid: 15255631].
3 Gharote ML. Effect of yoga exercises on failures on the Kraus-Weber tests. Percept Mot Skills. 1976;43(2):654.
4 Kumar KG, Ali MH. Meditation: a harbinger of subjective well-being. J Pers Clin Stud. 2003;19(1):93-102.
5 Lee M. A comparison of transpersonal and physical stress reduction techniques in preparing students for entrance examinations in a Taiwan school [dissertation]. Palo Alto, CA: Institute of Transpersonal Psychology; 2000.
6 Pal GK, Velkumary S, Madanmohan. Effect of short-term practice of breathing exercises on autonomic functions in normal human volunteers. Indian J Med Res. 2004;120(2):115-21. [pmid: 15347862].
7 So KT. Testing and developing holistic intelligence in Chinese culture with Maharishi's vedic psychology: three experimental replications using transcendental meditation [dissertation]. Fairfield, IA: Maharishi International University; 1995.
8 So KT, Orme-Johnson DW. Three randomized experiments on the longitudinal effects of the transcendental meditation technique on cognition. Intelligence. 2001;29(5):419-40.
9 Verma IC, Jayashankarappa BS, Palani M. Effect of transcendental meditation on the performance of some cognitive psychological tests. Indian J Med Res. 1982;76(Suppl):136-43. [pmid: 6764454].

## Excluded: Population—Sample Size Less Than 10 (N = 6)

The following studies were excluded because the study sample included less than 10 participants

### References

1 Cimei T, Youjun G. Effects of qigong on reducing response to stress. Int J Psychol. 1992;27(34):607.
2 Fenwick PBC, Donaldson S, Bushman J, et al. EEG and metabolic changes during transcendental meditation. Electroencephalogr Clin Neurophysiol. 1975;39(2):220-1.
3 Galantino MLA, Capito L, Kane RJ, et al. The effects of tai chi and walking on fatigue and body mass index in women living with breast cancer: a pilot study. Rehabil Oncol. 2003;21(1):17-22.
4 Hustad P, Carnes J. The effectiveness of walking meditation on EMG readings in chronic pain patients. Biofeedback Self Regul. 1988;13(1):69.
5 Reuther I, Aldridge D. Qigong yangsheng as a complementary therapy in the management of asthma: a single-case appraisal. J Altern Complement Med. 1998;4(2):173-83. [pmid: 9628207].
6 Saletu B. Brain function during hypnosis, acupuncture and transcendental meditation: quantitative EEG studies. Recent Adv Biol Psychiatry. 1987;16:18-40.

## Nonobtained Studies (N = 81)

The following studies were not included in the review due to limitations in our library and retrieval resources.

### References

1 Arita H, Sato SI, Fumoto M, et al. Rhythmic behavior of Zen meditation produced appearance of high-frequency alpha band in EEG via activation of serotonergic neurons. Fifty-sixth Annual meeting of the Japan Society of Neurovegetative Research. Vol. 41. Japan Society of Neurovegetative Research; 2004. p. 338–42.
2 Arnhold E, Charles BM, Gandhi JS, et al. Endocrinological changes following instruction in the TM-Sidhi programme. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press, 1990. p. 1555.
3 Aslan UB, Livanelioglu A. Effects of hatha yoga training on aerobic power and anaerobic power in healthy young adults. Fizyoterapi Rehabilitasyon. 2002;13(1):24-30.
4 Bharshankar JR, Bharshankar RN, Deshpande VN, et al. Effect of yoga on cardiovascular system in subjects above 40 years. Indian J Physiol Pharmacol. 2003;47(2):202-6. [pmid: 15255625].
5 Bhatnagar OP, Anantharaman V. Effect of yoga training on neuromuscular excitability and muscular relaxation. Neurol India. 1977;25(4):230-2. [pmid: 614510].
6 Campbell DE, Moore KA. Yoga as a preventative and treatment for depression, anxiety, and stress. Int J Yoga Ther. 2004;14:53-8.
7 Carlson CR, Bacaseta PE, Simanton DA. A controlled evaluation of devotional meditation and progressive relaxation. J Psychol Theol. 1988;16(4):362-8.
8 Carlson LE, Speca M, Patel KD, et al. The effects of a mindfulness meditation intervention on psychological parameters, quality of life and immune, endocrine and autonomic functioning in breast and prostate cancer patients. Psychooncology. 2003;12(4 Suppl):S105.
9 Cilmore RSC. The effects of yoga asanas on blood pressure. Int J Yoga Ther 2002;12.
10 Cohen L, Warneke C, Fouladi RT, et al. A Tibetan yoga intervention for cancer patients. Psychooncology. 2003;12(4 Suppl):S132-3.
11 Cooper SE, Oborne J, Newton S, et al. Do breathing exercises (Buteyko and pranayama) help to control asthma: a randomised controlled trial. Eur Respir J. 2002;20(38 Suppl):307s.
12 Daroux LM, Culos-Reed SN, Carlson LE. Yoga and cancer: an examination of the physical and psychological benefits. Psychooncology. 2003;12(4 Suppl):S231-2.
13 Dillbeck MC. The effect of the transcendental meditation technique on anxiety level. J Clin Psychol. 1977;33(4):1076-8. [pmid: 336648].
14 Eide P, Blank S, Haberman M, et al. Beneficial outcomes of Iyengar yoga practice for breast cancer survivors. Commun Nurs Res. 2004;37:448.
15 Finney JR. Contemplative prayer as an adjunct to psychotherapy [abstract]. Diss Abstr Int. 1985;46(4B):1334.
16 Finney JR, Malony HN. An empirical study of contemplative prayer as an adjunct to psychotherapy. J Psychol Theol. 1985;13(4):284-90.
17 Flynn AP, Speca M. Being and doing: mindfulness meditation and dance improvisation: creative responses to serious illness. Psychooncology. 2003;12(4 Suppl):S166.
18 Gopinath KS, Rao R, Raghuram N, et al. Evaluation of yoga therapy as a psychotherapeutic intervention in breast cancer patients on conventional combined modality of treatment. Proceedings of the 39th Annual Meeting of the American Society of Clinical Oncology (ASCO); 2003 May 31–Jun 3; Chicago, IL. p. 26.
19 Griffiths TJ, Steel DH, Vaccaro P, et al. The effects of relaxation techniques on anxiety and underwater performance. Int J Sport Psychol. 1981;12(3):176-82.
20 Gupta HL, Dudani U, Singh SH, et al. Sahaja yoga in the management of intractable epileptics. J Assoc Physicians India. 1991;39(8):649.
21 Hebert JR, Tan G. Quantitative EEG phase evaluation of transcendental meditation. J Neurother. 2004;8(2):120-1.
22 Higuchi Y, Kotani Y, Hayashi Y, et al. Immune responses during zhang method qigong. Human Potential Science International Forum; 2002, Aug 22–27; Makuhari, Japan. ISLIS 2002;(20):449–52.
23 Hoffman K, Clarke J. A comparative study of the cardiac response to bhastrika: a yogic breathing exercise and the exercise tolerance test. Int J Yoga Ther. 1996;7:35-42.
24 Ito M, Singh LN, Yamaguchi K, et al. How does yoga affect the brain? Human Potential Science International Forum; 2002, Aug 22–27; Makuhari, Japan. ISLIS 2002(20):473–9.
25 Janakiramaiah N, Gangadhar BN, Naga-Venkatesha-Murthy PJ, et al. Therapeutic efficacy of sudarshan kriya yoga (Sky) in dysthymic disorder. Nimhans Journal. 1998;16(1):21-8.
26 Jedrczak A, Cox D, Cunningham C. Pilot testing of subjects practising the transcendental meditation and TM-Sidhi programme: neuroticism, anxiety, well-being, and the capacity for absorbing experiences. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol. 4. Switzerland: Maharishi European Research University - MVU Press; 1991. p. 2414–17.
27 Jevning RA, Wilson AF. Behavioral increase on cerebral blood flow. In: Chalmers RA, Clements G, Schenkluhn H, et al., eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol. 2. Switzerland: Maharishi European Research University - MVU Press; 1990. p. 1554–5.
28 Jevning RA, Wilson AF, VanderLaan EF, et al. Plasma prolactin and cortisol during transcendental meditation. In: Orme-Johnson DW, Farrow JT, eds. Sci Res Maharishi's Transcendental Meditation TM-Sidhi Programme: collected papers. Vol 1. Switzerland: Maharishi European Research University - MVU Press; 1977. p. 143–4.
29 Kawano K, Yamamoto M, Kokubo H, et al. Characteristics of EEG during various meditations. Human Potential Science International Forum; 2002, Aug 22–27; Makuhari, Japan. ISLIS 2002(20):512–6.
30 Kido M. Application of a single square voltage pulse method. J Int Soc Life Inf Sci. 1997;15(1):60-70.
31 King R, Brownstone A. Neurophysiology of yoga meditation. Int J Yoga Ther. 1999;9:9-17.
32 Koshii H, Liu C, Machi Y. A comparative study of physiological changes while playing a wind instrument and doing internal qigong. Proceedings of the 17th Symposium on Life Information Science; 2004, March 13–14; Tokyo, Japan. ISLIS. 2004;22:41-8.
33 Koshikawa F, Ichii M. An experiment on classifications of meditation methods on procedures, goals and effects. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 213–24.
34 Kotake J, Chen W, Parkhomtchouk D, et al. Comparison of the physiology between qigong and relaxation states. Human Potential Science International Forum; 2002 Aug 22–27; Makuhari, Japan. ISLIS 2002(20):606–9.
35 Kristeller JL, Quillian-Wolever RE. Meditation-based treatment for binge-eating disorder. Clin Trials 2003. Available at: http://clinicaltrials.gov/ct/show/NCT00032760.
36 Kulik A, Szewczyk L. Sense of meaning of life and the emotional reaction among young people pursuing different types of meditation. Stud Psychol. 2002;44(2):155-66.
37 Kwee MGT, Taams MK. Neozen: Buddhist meditation and the empirical evidence on health enhancement. Int J Psychol. 2004;39(56 Suppl):384.
38 Lee KK, Leung E, Wong S, et al. The effects of qigong and conventional exercise on type 2 diabetic patients. Diabetes. 2002;51(2 Suppl):A245.
39 Leung PC. Comparative effects of training in external and internal concentration on two counseling behaviors. J Couns Psychol. 1973;20(3):227-34.
40 Li Q, Matsuura Y, Tsubouchi S, et al. Influence of level of skill on physiological reaction in shaolin internal qigong. Proceedings of the 15th Symposium on Life Information Science; 2003, Mar 15–16; Tokyo, Japan. ISLIS 2003;(21):120.
41 Lindemann U, Hammer W, Muche R, et al. Postural control in the elderly: effect of a twelve week tai chi-qigong intervention in healthy elderly. Eur J Geriatr. 2003;5(4):182-6.
42 Liu C, Machi Y. Measurement of abdominal respiration patterns with indexes and the pulse delay time of physiological results in regimen qigong. Human Potential Science International Forum; 2002, Aug 22–27; Makuhari, Japan. ISLIS 2002;(20):570–7.
43 Liu C, Machi Y. The physiological effect of controlled respiration and the meaning of respiration method in qigong therapy. Proceedings of the 11th Symposium on Life Information Science, 2001, March 23–24; Tokyo, Japan. ISLIS 2001;(19):90–9.
44 Longo DJ. A psychophysiological comparison of three relaxation techniques and some implications in treating cardiovascular syndromes. Proceedings of the 1984 SBM Annual Meeting; 1984 May 23–26; Philadelphia, PA.
45 Lu LJ. Ninety two patients with cervical spondylopathy treated by massage and qigong. J Zhejiang Coll of Tradit Chin Med. 1996;20(1):39-40.
46 Mannerkorpi K, Arndorw M. Can body awareness therapy and qi gong improve movement harmony in patients with fibromyalgia: a pilot study. Proceedings of Myopain 2004: 6th World Congress on myofascial pain and fibromyalgia, 2004 July 18–22, Munich, Germany. HMP 2004;(12):60.
47 Mehling WE, Hamel KA, Acree M, et al. Randomized, controlled trial of breath therapy for patients with chronic low-back pain. Altern Ther Health Med. 2005;11(4):44-52. [pmid: 16053121].
48 Menon A, Krishnan VR. Transformational leadership and follower's karma-yoga: role of follower's gender. Indian J Psychol. 2004;22(2):50-62.
49 Moadel AB, Shah C, Patel S, et al. Randomized controlled trial of yoga for symptom management during breast cancer treatment. Proceedings of the 39th Annual Meeting of the American Society of Clinical Oncology (ASCO); 2003 May 31–Jun 3; Chicago, IL. p. 726.
50 Morse DR, Furst ML. Meditation: an in depth study. J Am Soc Psychosom Dent Med. 1982;29(5):96.
51 Murphy MJ. Explorations in the use of group meditation with persons in psychotherapy [abstract]. Diss Abstr Int. 1973;33:6089.
52 Nimmagadda J. Mental health promotion and stress management through yoga; effects of sudarshan kriya. Int J Psychol. 2000;35(34):77.
53 Palmer J, Khamashta K, Israelson K. An ESP ganzfeld experiment with transcendental meditators. J Am Soc for Psychical Res. 1979;73(4):333-8.
54 Payne D, Luzzatto P. Meditation and arts therapies: a mini retreat. Psychooncology. 2003;12(4 Suppl):S218.
55 Piggins D, Morgan D. Perceptual phenomena resulting from steady visual fixation and repeated auditory input under experimental conditions and in meditation. J Altered States Consciousness. 1978;3(3):197-203.
56 Ritter C, Aldridge D. Qigong yangsheng as a therapeutic approach for the treatment of essential hypertension in comparison with a western muscle relaxation therapy: a randomised, controlled pilot study. Chinesische Medizin. 2001;16(2):48-63.
57 Rosdahl DRL. The effect of mindfulness meditation on tension headaches and secretory immunoglobulin A in saliva [dissertation]. Tucson: University of Arizona; 2003.
58 Ross K, Adams K, Donner B. Mindfulness for inpatients?. Clin Psychol. 2005;47:13-5.
59 Sakairi Y. Application of the meditative method in psychotherapy with an emphasis on transcendental meditation and autogenic training. In: Haruki Y, Ishii Y, Suzuki M, eds. Comparative and psychological study on meditation. Proceedings of the 3rd Conference; 1993 Aug 30–Sept 2; Makuhari, Japan. Delft, Netherlands: Eburon Publishers; 1996. p. 171–84.
60 Sawada Y. Is meditation efficacious as a stress reduction intervention? A cardiovascular hemodynamic approach. In: Haruki Y, Kaku KT, eds. Meditation as Health Promotion: A Lifestyle Modification Approach. Proceedings of the 6th Conference; 2000 Jul 20–21; Noordwijkerhout, The Netherlands. Delft, Netherlands: Eburon Publishers; 2000. p. 132–51.
61 Shafil M, Lavely R, Jaffe R. Meditation and the prevention of alcohol abuse. Alcohol Health Res World 1976 Sum:18–21.
62 Shapiro DH, Shapiro J, Walsh RN, et al. Effects of intensive meditation on sex-role identification: implications for a control model of psychological health. Psychol Rep. 1982;51(1):44-6.
63 Sharma M. Pilot test of a Kundalinî-yoga intervention for developing the mind-body connection. Int J Yoga Ther. 2001;11:85-91.
64 Sharma NR, Yadava A, Hooda D. Effect of yoga on psycho-physical functions. Indian J Psychol. 2005;23(1):37-42.
65 Silva GD, Lage LV. Effects of stretching and relaxing yoga exercises versus stretching and relaxing yoga exercises induced through touch in fibromyalgia patients. Ann Rheum Dis. 2005;64(3 Suppl):347. [pmid: 15498797]. [pmcid: 1755414].
66 Spanos NP, Rivers SM, Gottlieb J. Hypnotic responsivity, meditation, and laterality of eye movements. J Abnorm Psychol. 1978;87(5):566-9. [pmid: 359619].
67 Sridevi K, Rao PVK. Temporal effects of meditation on cognitive style. Indian J Psychol. 2003;21(1):38-51.
68 Stephan K, Payne R. Iyengar yoga and neuromuscular therapy. Massage Bodywork. 2000;15(4):34-46.
69 Talukdar B, Verma S, Jain SC, et al. Effect of yoga training on plasma lipid profile, RBC membrane lipid peroxidation and Na+K+ ATPase activity in patients of essential hypertension. Indian J Clin Biochem. 1996;11(2):129-33.
70 Tanaka M, Kokubo H, Kokado T, et al. Physiological measurements during qigong training (II). Proceedings of the 10th Symposium on Life Information Science. ISLIS. 2000;18:383-94.
71 Teasdale JD. Mindfulness-based cognitive therapy in the prevention of relapse and recurrence in major depression. In: Haruki Y, Kaku KT, eds. Meditation as Health Promotion: A Lifestyle Modification Approach. Proceedings of the 6th Conference; 2000 Jul 20–21; Noordwijkerhout, The Netherlands. Delft, Netherlands: Eburon Publishers; 2000. p. 3–18.
72 Thomas D, Abbas KA. Comparison of transcendental meditation and progressive relaxation in reducing anxiety. BMJ. 1978;2(6154):1749.
73 Vedanthan PK. Yoga breathing techniques (YBT) in chronic obstructive pulmonary disease (COPD): a preliminary study. In: Program and Abstracts of the 94th International Conference of the American Thoracic Society; 1998 Apr 23–28; San Diego, CA. Poster A132.
74 Vedanthan PK, Raghuram NB. Yoga breathing techniques (YBTs) in exercise induced asthma: a pilot study. Int J Yoga Ther 2003;13.
75 Watanabe E, Fukuda S, Hara H, et al. Altered responses of saliva cortisol and mood status by long-period special yoga exercise mixed with meditation and guided imagery. J Int Soc Life Inf Sci. 2002;20(2):585-7.
76 Watanabe E, Fukuda S, Hara H, et al. The psycho-neuro-endocrinological effects of yoga exercise, meditation and guided imagery. Human Potential Science International Forum; 2002 Aug 22–27; Makuhari, Japan. ISLIS 2002;(20):585–9.
77 Yoshida K, Yoshihuku Y, Aoki T, et al. The effect of the qigong exercise suwaishou from the viewpoint of the sway of the center of gravity. Human Potential Science International Forum; 2002 Aug 22–27; Makuhari, Japan. ISLIS 2002;(20):563–9.
78 Yoshihuku Y, Yoshida K. The effects of various kinds of yoga exercises on grip strength of experienced and inexperienced people. Human Potential Science International Forum; 2002 Aug 22–27; Makuhari, Japan. ISLIS 2002;(20):578–84.
79 Zhang T, Chen W, Fukuda N, et al. Correlations between cardiac variability and alpha/theta activities of EEG during qigong task. Proceedings of the 15th Symposium on Life Information Science; 2003 Mar 15–16; Tokyo, Japan. ISLIS 2003;(21):278–84.
80 Zhang T, Chen W, Yoichi H, et al. Human Potential Science International Forum; 2002 Aug 22–27; Makuhari, Japan. ISLIS 2002;(20):517–25.
81 Zhang T, Sakaida H, Kawano K, et al. An experiment on cerebral activity during visual imagery. J Int Soc Life Inf Sci. 2000;18(2):400-3.