# Appendix D. Review Forms

To see the Review Forms, please select the link below. This link will take you to a PDF version of the forms.

Review Forms