# Appendix C. Exact Search Strings

Table C1 MEDLINE^®^—Ovid version

Years/issue searched: 1966 to August 2005, week 5
Search date: September 8, 2005
1 exp meditation/; 2 exp yoga/; 3 meditat$.mp.; 4 cogitat$.ti,ab.; 5 Pranayam$.mp.; 6 kapalabhati.ti,ab.; 7 (yoga or yogic$).mp.; 8 mindful$.mp.; 9 zen.ti,ab,sh.; 10 transcendental.ti,ab.; 11 TM-Sidhi.mp.; 12 mahayana.ti,ab.; 13 hiniyana.ti,ab.; 14 theravada$.ti,ab.; 15 vajrayana.ti,ab.; 16 (vipissana or vipashyana).ti,ab.; 17 (dhyana or dyana).ti,ab.; 18 dharana.ti,ab.; 19 zazen.ti,ab.; 20 (kinemantra or KM).ti,ab.; 21 (mantra or mantras).mp.; 22 (samadhi or samatha).ti,ab.; 23 pratyahara.ti,ab.; 24 purusha.ti,ab.; 25 prakruti.ti,ab.; 26 ((Visual or guided) adj5 imagery).mp.; 27 ((guided or creative or vivid) adj visualization).ti,ab.; 28 pray$.mp.; 29 Hesychasm.ti,ab.; 30 “lectio divina”.ti,ab.; 31 bonadona.ti,ab.; 32 (qigong or qi gong).mp.; 33 ch'i kung.ti,ab.; 34 “Tae Eul Ju”.ti,ab.; 35 “mind-body and relaxation techniques”/ or “mind-body relations (metaphysics)”/; 36 tai ji/; 37 (tai chi or tai ji).mp.; 38 Taijiquan.ti,ab.; 39 “open awareness”.mp.; 40 “focused awareness”.mp.; 41 “relaxation response”.mp.; 42 “progressive muscle relaxation”.ti,ab.; 43 progressive relaxation.ti,ab.; 44 “forced nostril breathing”.ti,ab.; 45 “Uninostril breathing”.ti,ab.; 46 “unilateral breathing”.ti,ab.; 47 (Khundalini or Kundalini).mp.; 48 raja.ti,ab.; 49 hatha.ti,ab.; 50 “sudarshan kriya”.ti,ab.; 51 RRMM.ti,ab.; 52 MBSR.ti,ab.; 53 MBCT.ti,ab.; 54 “Wide-angle lens attention”.ti,ab.; 55 (“Anapana Sati” or anapanasati).mp.; 56 kabat-zinn.ab.; 57 or/1–56; 58 RANDOMIZED CONTROLLED TRIAL.pt.; 59 CONTROLLED CLINICAL TRIAL.pt.; 60 RANDOMIZED CONTROLLED TRIALS; 61 RANDOM ALLOCATION/; 62 DOUBLE BLIND METHOD/; 63 SINGLE-BLIND METHOD/; 64 or/58–63; 65 ANIMAL/ not HUMAN/; 66 64 not 65; 67 CLINICAL TRIAL.pt.; 68 exp CLINICAL TRIALS/; 69 (clin$ adj25 (trial$ or study or studies or design)).ti,ab.; 70 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.; 71 PLACEBOS/; 72 placebo$.ti,ab.; 73 random$.ti,ab.; 74 RESEARCH DESIGN/; 75 or/67–74; 76 75 not 65; 77 76 not 66; 78 COMPARATIVE STUDY/; 79 exp EVALUATION STUDIES/; 80 FOLLOW UP STUDIES/; 81 (Follow up adj5 (study or studies or design)).ti,ab.; 82 PROSPECTIVE STUDIES/; 83 exp COHORT STUDIES/; 84 CROSS-SECTIONAL STUDIES/; 85 exp CASE-CONTROL STUDIES/; 86 Epidemiologic studies/; 87 Epidemiological factors/; 88 exp Causality/; 89 Age factors/; 90 Comorbidity/; 91 Odds ratio/; 92 exp Risk/; 93 Probability/; 94 ((Allocat$ or control$ or assign$ or treatment or compar$ or interven$ or experiment$) and (group or groups)).mp.; 95 (group or groups).ti,ab.; 96 (control$ or prospectiv$ or retrospectiv$ or volunteer$ or participant$ or compar$).mp. and (trial$ or study or studies or design).ti,ab,sh.; 97 cohort$.ti,ab.; 98 case-control$.ti,ab.; 99 Cross sectional.ti,ab.; 100 (observational adj5 (study or studies or design)).ti,ab.; 101 Longitudinal.mp.; 102 Retrospective.ti,ab.; 103 Relative risk.ti,ab.; 104 Odds ratio.ti,ab.; 105 (case adj (comparison or referent)).ti,ab.; 106 (Causation or causal$).ti,ab.; 107 (Analytic adj (study or studies)).ti,ab.; 108 or/78–107; 109 108 not 65; 110 109 not (66 or 77); 111 66 or 77 or 109; 112 57 and 111; 113 limit 112 to (humans and english language); 114 limit 113 to “all adult (19 plus years)”; 115 113 not 114; 116 limit 115 to “all child (0 to 18 years)”; 117 115 not 116; 118 114 or 117; 119 remove duplicates from 118; 120 systematic review$.mp.; 121 systematic literature review$.mp.; 122 meta-analysis.sh.; 123 (meta-analys?s or metaanalys?s).ti.; 124 evidence-based medicine.mp.; 125 quantitative review$.ti,ab.; 126 quantitative overview$.ti,ab.; 127 quantitative synthes?s.ti.; 128 quantitative analys?s.ti,ab.; 129 (evidence-based adj (guideline$ or recommendation$)).mp.; 130 health planning guideline$.mp.; 131 cochrane database of systematic reviews.mp.; 132 cdsr.mp.; 133 acp journal club.mp.; 134 (health tech$ assess$ or hta).mp.; 135 technolog$ assess$.mp.; 136 evidence based nursing.mp.; 137 evidence based mental health.mp.; 138 clinical evidence.mp.; 139 biomedical technology assessment.sh.; 140 evidence report$.mp.; 141 or/120–140; 142 systematic$.mp.; 143 critical.mp.; 144 (study and selection).ti,ab.; 145 ((predetermined or inclusion) and criteri$).mp.; 146 exclusion criteri$.mp.; 147 main outcome measure$.mp.; 148 “standard$ of care”.mp.; 149 or/142–148; 150 (survey$ or overview$ or review or reviews or search$ or handsearch$).mp.; 151 (analys?s or critique or appraisal).mp.; 152 (reduction and risk and (death or occurrence)).mp.; 153 or/150–152; 154 (literature or article$ or publication$ or bibliograph$ or published or unpublished or ciation$ or database$ or internet or reference$ or textbook$ or trial$).mp.; 155 meta-analysis.sh.; 156 (medline or medlars or pubmed or embase or index medicus or cochrane or scisearch or web of science or psychinfo or psychlit or cinahl or experta medica or science citation index or sciences citation index or biological abstracts).mp.; 157 (clinical and studies).mp.; 158 (treatment outcome or combine$ or combining or peto or der simonian or dersimonian or fixed effect$ or pooled or pooling or mantel haenszel).mp.; 159 or/154–157; 160 149 and 153 and 159; 161 141 or 160; 162 case report.ti,sh.; 163 editorial.ti,pt.; 164 letter.pt.; 165 note.pt.; 166 or/162–165; 167 161 not 166; 168 167 and 57; 169 168 not 119; 170 meta-analysis.pt.; 171 (meta-anal$ or metaanal$).mp.; 172 (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.; 173 (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.; 174 (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.; 175 (integrat$ adj5 research).mp.; 176 (quantitativ$ adj3 synthes$).mp.; 177 or/170–176; 178 review.pt. or (review$ or overview$).mp.; 179 (medline or medlars or pubmed or index medicus or embase or cochrane).mp.; 180 (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.; 181 (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.; 182 (hand search$ or manual search$).mp.; 183 ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.; 184 (pooling or pooled or mantel haenszel).mp.; 185 (peto or der simonian or dersimonian or fixed effect$).mp.; 186 ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.; 187 or/179–186; 188 178 and 187; 189 177 or 188; 190 (hta$ or health technology assessment$ or biomedical technology assessment$).mp.; 191 technology assessment, biomedical/ or biomedical technology assessment/; 192 190 or 191; 193 189 or 192; 194 119 and 193; 195 57 and 193; 196 119 or 195

Table C2 EMBASE—Ovid version

Years/issue searched: 1988 to 2005, week 36
Search date: September 8, 2005
1 exp meditation/; 2 Transcendental meditation/; 3 exp yoga/; 4 meditate$.mp.; 5 cogitat$.ti,ab.; 6 Pranayam$.mp.; 7 kapalabhati.ti,ab.; 8 (yoga or yogic$).mp.; 9 mindful$.mp.; 10 zen.ti,ab,sh.; 11 transcendental.ti,ab.; 12 TM-Sidhi.mp.; 13 mahayana.ti,ab.; 14 hiniyana.ti,ab.; 15 theravada$.ti,ab.; 16 vajrayana.ti,ab.; 17 (vipissana or vipashyana).ti,ab.; 18 (dhyana or dyana).ti,ab.; 19 dharana.ti,ab.; 20 zazen.ti,ab.; 21 (kinemantra or KM).ti,ab.; 22 (mantra or mantras).mp.; 23 (samadhi or samatha).ti,ab.; 24 pratyahara.ti,ab.; 25 purusha.ti,ab.; 26 prakruti.ti,ab.; 27 ((Visual or guided) adj5 imagery).mp.; 28 ((guided or creative or vivid) adj visualization).ti,ab.; 29 pray$.mp.; 30 Hesychasm.ti,ab.; 31 lectio divina.ti,ab.; 32 bonadona.ti,ab.; 33 (qigong or qi gong).mp.; 34 ch'i kung.ti,ab.; 35 “Tae Eul Ju”.ti,ab.; 36 relaxation training/ and (Psychophysiology/ or Breathing Exercise/); 37 “Mental Concentration”/ and (Breathing Exercise/ or relaxation training/); 38 (mind adj body).ti,ab.; 39 brain mind relationship/; 40 exp Tai Chi/; 41 (tai chi or tai ji).mp.; 42 Taijiquan.ti,ab.; 43 “open awareness”.mp.; 44 “focused awareness”.mp.; 45 “relaxation response”.mp.; 46 “progressive muscle relaxation”.ti,ab.; 47 progressive relaxation.ti,ab.; 48 “forced nostril breathing”.ti,ab.; 49 “Uninostril breathing”.ti,ab.; 50 “unilateral breathing”.ti,ab.; 51 (Khundalini or Kundalini).mp.; 52 raja.ti,ab.; 53 hatha.ti,ab.; 54 “sudarshan kriya”.ti,ab.; 55 RRMM.ti,ab.; 56 MBSR.ti,ab.; 57 MBCT.ti,ab.; 58 “zoom lens attention”.ti,ab.; 59 “Wide-angle lens attention”.ti,ab.; 60 (“Anapana Sati” or anapanasati).mp.; 61 kabat-zinn.ab.; 62 or/1–61; 63 Randomized Controlled Trial/; 64 exp Randomization/; 65 Double Blind Procedure/; 66 Single Blind Procedure/; 67 or/63–66; 68 Clinical Trial/; 69 (clin$ adj25 (trial$ or study or studies or design)).mp.; 70 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).mp.; 71 exp Placebo/; 72 (placebo$ or random$).mp.; 73 exp Methodology/; 74 exp Comparative Study/; 75 exp Evaluation/; 76 exp Follow Up/; 77 exp Prospective Study/; 78 clinical study/; 79 case control study/; 80 family study/; 81 longitudinal study/; 82 retrospective study/; 83 cohort analysis/; 84 exp Risk/; 85 ((allocat$ or compar$ or assign$ or treatment or control$ or interven$ or experiment$) and (group or groups)).mp.; 86 (group or groups).ti,ab.; 87 ((control$ or prospectiv$ or retrospectiv$ or volunteer$ or participant$ or compar$) and (trial$ or study or studies or design)).ti,ab,sh.; 88 cohort$.ti,ab.; 89 “case-control”.ti,ab.; 90 “Cross sectional”.ti,ab.; 91 (observational adj5 (study or studies or design)).ti,ab.; 92 Longitudinal.mp.; 93 Retrospective.ti,ab.; 94 “Relative risk”.ti,ab.; 95 “Odds ratio”.ti,ab.; 96 (Follow up adj5 (study or studies or design)).ti,ab.; 97 (case adj (comparison or referent)).ti,ab.; 98 (Causation or causal$).ti,ab.; 99 (Analytic adj (study or studies)).ti,ab.; 100 (epidemiologic$ adj (study or studies)).ti,ab.; 101 or/68–99; 102 67 or 101; 103 limit 102 to human; 104 Nonhuman/; 105 103 not 104; 106 62 and 105; 107 limit 106 to english language; 108 limit 107 to (adult <18 to 64 years> or aged <65+ years>); 109 107 not 108; 110 limit 109 to (embryo or infant or child or preschool child <1 to 6 years> or school child <7 to 12 years>); 111 109 not 110; 112 108 or 111; 113 remove duplicates from 112; 114 systematic review$.mp.; 115 systematic literature review$.mp.; 116 meta-analysis.sh.; 117 (meta-analys?s or metaanalys?s).ti.; 118 evidence-based medicine.mp.; 119 quantitative review$.ti,ab.; 120 quantitative overview$.ti,ab.; 121 quantitative synthes?s.ti.; 122 quantitative analys?s.ti,ab.; 123 (evidence-based adj (guideline$ or recommendation$)).mp.; 124 health planning guideline$.mp.; 125 cochrane database of systematic reviews.mp.; 126 cdsr.mp.; 127 acp journal club.mp.; 128 (health tech$ assess$ or hta).mp.; 129 technolog$ assess$.mp.; 130 evidence based nursing.mp.; 131 evidence based mental health.mp.; 132 clinical evidence.mp.; 133 biomedical technology assessment.sh.; 134 evidence report$.mp.; 135 or/114–134; 136 systematic$.mp.; 137 critical.mp.; 138 (study and selection).ti,ab.; 139 ((predetermined or inclusion) and criteri$).mp.; 140 exclusion criteri$.mp.; 141 main outcome measure$.mp.; 142 “standard$ of care”.mp.; 143 or/136–142; 144 (survey$ or overview$ or review or reviews or search$ or handsearch$).mp.; 145 (analys?s or critique or appraisal).mp.; 146 (reduction and risk and (death or occurrence)).mp.; 147 or/144–146; 148 (literature or article$ or publication$ or bibliograph$ or published or unpublished or ciation$ or database$ or internet or reference$ or textbook$ or trial$).mp.; 149 meta-analysis.sh.; 150 (medline or medlars or pubmed or embase or index medicus or cochrane or scisearch or web of science or psychinfo or psychlit or cinahl or experta medica or science citation index or sciences citation index or biological abstracts).mp.; 151 (clinical and studies).mp.; 152 (treatment outcome or combine$ or combining or peto or der simonian or dersimonian or fixed effect$ or pooled or pooling or mantel haenszel).mp.; 153 or/148–151; 154 143 and 147 and 153; 155 135 or 154; 156 case report.ti,sh.; 157 editorial.ti,pt.; 158 letter.pt.; 159 note.pt.; 160 or/156–159; 161 155 not 160; 162 meta-analysis.pt.; 163 (meta-anal$ or metaanal$).mp.; 164 (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.; 165 (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.; 166 (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.; 167 (integrat$ adj5 research).mp.; 168 (quantitativ$ adj3 synthes$).mp.; 169 or/162–168; 170 review.pt. or (review$ or overview$).mp.; 171 (medline or medlars or pubmed or index medicus or embase or cochrane).mp.; 172 (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.; 173 (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.; 174 (hand search$ or manual search$).mp.; 175 ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.; 176 (pooling or pooled or mantel haenszel).mp.; 177 (peto or der simonian or dersimonian or fixed effect$).mp.; 178 ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.; 179 or/171–178; 180 170 and 179; 181 169 or 180; 182 (hta$ or health technology assessment$ or biomedical technology assessment$).mp.; 183 technology assessment, biomedical/ or biomedical technology asssessment/; 184 182 or 183; 185 181 or 184; 186 161 or 185; 187 186 and 62; 188 limit 187 to (human and english language); 189 limit 188 to (adult <18 to 64 years> or aged <65+ years>); 190 188 not 189; 191 limit 190 to (embryo or infant or child or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>); 192 190 not 191; 193 189 or 192; 194 remove duplicates from 193; 195 113 or 194

Table C3 Central (EBM Reviews-Cochrane Central Register of Controlled Trials)—Ovid version

Years/issue searched: 3rd Quarter 2005
Search date: August 4, 2005
1 exp meditation/; 2 exp yoga/; 3 meditat$.mp.; 4 cogitat$.ti,ab.; 5 Pranayam$.mp.; 6 kapalabhati.ti,ab.; 7 (yoga or yogic$).mp.; 8 mindful$.mp.; 9 zen.ti,ab,sh.; 10 transcendental.ti,ab.; 11 TM-Sidhi.mp.; 12 mahayana.ti,ab.; 13 hiniyana.ti,ab.; 14 theravada$.ti,ab.; 15 vajrayana.ti,ab.; 16 (vipissana or vipashyana).ti,ab.; 17 (dhyana or dyana).ti,ab.; 18 dharana.ti,ab.; 19 zazen.ti,ab.; 20 (kinemantra or KM).ti,ab.; 21 (mantra or mantras).mp.; 22 (samadhi or samatha).ti,ab.; 23 pratyahara.ti,ab.; 24 purusha.ti,ab.; 25 prakruti.ti,ab.; 26 ((Visual or guided) adj5 imagery).mp.; 27 ((guided or creative or vivid) adj visualization).ti,ab.; 28 pray$.mp.; 29 Hesychasm.ti,ab.; 30 “lectio divina”.ti,ab.; 31 bonadona.ti,ab.; 32 (qigong or qi gong).mp.; 33 ch'i kung.ti,ab.; 34 “Tae Eul Ju”.ti,ab.; 35 “mind-body and relaxation techniques”/ or “mind-body relations (metaphysics)”/; 36 tai ji/; 37 (tai chi or tai ji).mp.; 38 Taijiquan.ti,ab.; 39 “open awareness”.mp.; 40 “focused awareness”.mp.; 41 “relaxation response”.mp.; 42 “progressive muscle relaxation”.ti,ab.; 43 progressive relaxation.ti,ab.; 44 “forced nostril breathing”.ti,ab.; 45 “Uninostril breathing”.ti,ab.; 46 “unilateral breathing”.ti,ab.; 47 (Khundalini or Kundalini).mp.; 48 raja.ti,ab.; 49 hatha.ti,ab.; 50 “sudarshan kriya”.ti,ab.; 51 RRMM.ti,ab.; 52 MBSR.ti,ab.; 53 MBCT.ti,ab.; 54 “zoom lens attention”.ti,ab.; 55 “Wide-angle lens attention”.ti,ab.; 56 (“Anapana Sati” or anapanasati).mp.; 57 kabat-zinn.ab.; 58 or/1–57; 59 adult.mp.; 60 elderly.mp.; 61 middle-age$.mp.; 62 aged.hw. or aged.kw. or aged.sh. or “aged 80 and over”.sh.; 63 or/59–62; 64 58 and 63; 65 58 not 64; 66 child$.hw.; 67 adolescen$.hw.; 68 infan$.hw.; 69 minors.hw.; 70 neonat$.hw.; 71 pediatric$.hw.; 72 (nurseries or nursery).hw.; 73 or/66–72; 74 child$.mp.; 75 paediatric$.mp.; 76 pediatric$.mp.; 77 (neonat$ or perinat$).mp.; 78 newborn$.mp.; 79 infan$.mp.; 80 preemie$.mp.; 81 (baby or babies).mp.; 82 (nursery or nurseries).mp.; 83 toddler$.mp.; 84 boy$.mp.; 85 girl$.mp.; 86 (schoolage$ or (school adj1 age$)).mp.; 87 (preschool$ or (pre adj1 school$)).mp.; 88 nursery school$.mp.; 89 kindergar?en$.mp.; 90 (schoolchild$ or (school adj1 child$)).mp.; 91 primary school$.mp.; 92 elementary school$.mp.; 93 (prepubescen$ or postpubescen$ or (pre adj1 pubescen$) or (post adj1 pubescen$)).mp.; 94 secondary school$.mp.; 95 (pubescen$ or pubert$).mp.; 96 adolescen$.mp.; 97 juvenil$.mp.; 98 underage$.mp.; 99 (teen or teens).mp.; 100 teenage$.mp.; 101 (youth or youths).mp.; 102 (highschool$ or (high adj1 school$)).mp.; 103 kid$1.mp.; 104 offspring.mp.; 105 or/74–104; 106 infan$.jw.; 107 (neonat$ or perinat$).jw.; 108 child$.jw.; 109 pediatric$.jw.; 110 paediatric$.jw.; 111 adolescen$.jw.; 112 youth$.jw.; 113 school$.jw.; 114 or/106–113; 115 or/105,114; 116 65 and 115; 117 65 not 116; 118 65 not 115; 119 118 or 64; 120 exp meditation/; 121 Transcendental meditation/; 122 exp yoga/; 123 meditat$.mp.; 124 cogitat$.ti,ab.; 125 Pranayam$.mp.; 126 kapalabhati.ti,ab.; 127 (yoga or yogic$).mp.; 128 mindful$.mp.; 129 zen.ti,ab,sh.; 130 transcendental.ti,ab.; 131 TM-Sidhi.mp.; 132 mahayana.ti,ab.; 133 hiniyana.ti,ab.; 134 theravada$.ti,ab.; 135 vajrayana.ti,ab.; 136 (vipissana or vipashyana).ti,ab.; 137 (dhyana or dyana).ti,ab.; 138 dharana.ti,ab.; 139 zazen.ti,ab.; 140 (kinemantra or KM).ti,ab.; 141 (mantra or mantras).mp.; 142 (samadhi or samatha).ti,ab.; 143 pratyahara.ti,ab.; 144 purusha.ti,ab.; 145 prakruti.ti,ab.; 146 ((Visual or guided) adj5 imagery).mp.; 147 ((guided or creative or vivid) adj visualization).ti,ab.; 148 pray$.mp.; 149 Hesychasm.ti,ab.; 150 lectio divina.ti,ab.; 151 bonadona.ti,ab.; 152 (qigong or qi gong).mp.; 153 ch'i kung.ti,ab.; 154 “Tae Eul Ju”.ti,ab.; 155 relaxation training/ and (Psychophysiology/ or Breathing Exercise/); 156 “Mental Concentration”/ and (Breathing Exercise/ or relaxation training/); 157 (mind adj body).ti,ab.; 158 brain mind relationship/; 159 exp Tai Chi/; 160 (tai chi or tai ji).mp.; 161 Taijiquan.ti,ab.; 162 “open awareness”.mp.; 163 “focused awareness”.mp.; 164 “relaxation response”.mp.; 165 “progressive muscle relaxation”.ti,ab.; 166 progressive relaxation.ti,ab.; 167 “forced nostril breathing”.ti,ab.; 168 “Uninostril breathing”.ti,ab.; 169 “unilateral breathing”.ti,ab.; 170 (Khundalini or Kundalini).mp.; 171 raja.ti,ab.; 172 hatha.ti,ab.; 173 “sudarshan kriya”.ti,ab.; 174 RRMM.ti,ab.; 175 MBSR.ti,ab.; 176 MBCT.ti,ab.; 177 “zoom lens attention”.ti,ab.; 178 “Wide-angle lens attention”.ti,ab.; 179 (“Anapana Sati” or anapanasati).mp.; 180 kabat-zinn.ab.; 181 or/120–180; 182 181 or 58; 183 182 not 58; 184 119 or 183

Table C4 PsycINFO^®^—Ovid version

Years/issue searched: 1872 to August 2005, week 4
Search date: September 9, 2005
1 exp meditation/; 2 exp yoga/; 3 exp Guided Imagery/; 4 exp Prayer/; 5 Autogenic Training/; 6 meditat$.mp.; 7 cogitat$.ti,ab.; 8 Pranayam$.mp.; 9 kapalabhati.ti,ab.; 10 (yoga or yogic$).mp.; 11 mindful$.mp.; 12 zen.ti,ab,sh.; 13 transcendental.ti,ab.; 14 TM-Sidhi.mp.; 15 mahayana.ti,ab.; 16 hiniyana.ti,ab.; 17 theravada$.ti,ab.; 18 vajrayana.ti,ab.; 19 (vipissana or vipashyana).ti,ab.; 20 (dhyana or dyana).ti,ab.; 21 dharana.ti,ab.; 22 zazen.ti,ab.; 23 (kinemantra or KM).ti,ab.; 24 (mantra or mantras).mp.; 25 (samadhi or samatha).ti,ab.; 26 pratyahara.ti,ab.; 27 purusha.ti,ab.; 28 prakruti.ti,ab.; 29 (((Visual or guided) adj3 imagery) and (therap$ or treat$ or interven$)).mp.; 30 imagery/ and relaxation therapy/; 31 ((guided or creative or vivid) adj visualization).ti,ab.; 32 pray$.mp.; 33 Hesychasm.ti,ab.; 34 lectio divina.ti,ab.; 35 bonadona.ti,ab.; 36 (qigong or qi gong).mp.; 37 ch'i kung.ti,ab.; 38 “Tae Eul Ju”.ti,ab.; 39 relaxation therapy/ and mind.ti,ab.; 40 Progressive relaxation therapy/; 41 ((mind adj body) and (therap$ or treat$ or interven$ or aware$ or breath$ or relax$ or conscious$)).ti,ab.; 42 (tai chi or tai ji).mp.; 43 Taijiquan.ti,ab.; 44 “open awareness”.mp.; 45 “focused awareness”.mp.; 46 “relaxation response”.mp.; 47 “progressive muscle relaxation”.ti,ab.; 48 progressive relaxation.ti,ab.; 49 “forced nostril breathing”.ti,ab.; 50 “Uninostril breathing”.ti,ab.; 51 “unilateral breathing”.ti,ab.; 52 (Khundalini or Kundalini).mp.; 53 raja.ti,ab.; 54 hatha.ti,ab.; 55 “sudarshan kriya”.ti,ab.; 56 RRMM.ti,ab.; 57 MBSR.ti,ab.; 58 MBCT.ti,ab.; 59 “zoom lens attention”.ti,ab.; 60 “Wide-angle lens attention”.ti,ab.; 61 (“Anapana Sati” or anapanasati).mp.; 62 kabat-zinn.ab.; 63 or/1–61; 64 exp CLINICAL TRIALS/; 65 control group/; 66 random$.mp.; 67 “sampling (experimental)”/ or Biased Sampling/ or Random Sampling/; 68 ((singl$ or doubl$ or tripl$ or trebl$) adj10 (blind$ or mask$)).mp.; 69 (cross?over or placebo$ or control$ or factorial or sham$).mp.; 70 double dummy.mp.; 71 ((clin$ or intervention$ or compar$ or experiment$ or preventive or therap$) adj10 (trial$ or study or studies)).mp.; 72 Experimental Subjects/ or Experiment volunteers/ or Experiment controls/ or Experimental Replication/; 73 clinical research.mp. or exp Treatment Effectiveness Evaluation/; 74 Treatment Outcomes/ or Psychotherapeutic outcomes/; 75 (outcome$ adj assessment).mp.; 76 (longitudinal study or meta analysis or program evaluation or prospective study or retrospective study or treatment outcome study or empirical study or experimental replication or followup study).fc.; 77 clinical case report.fc.; 78 (clin$ adj25 (trial$ or study or studies or design)).ti,ab.; 79 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.; 80 (efficacy or effective$ or findings or results).mp.; 81 RESEARCH DESIGN/; 82 FOLLOW-UP STUDIES/; 83 (Follow up adj5 (study or studies or design)).ti,ab.; 84 PROSPECTIVE STUDIES/; 85 LONGITUDINAL STUDIES/; 86 Comorbidity/; 87 exp Probability/; 88 ((Allocat$ or control$ or assign$ or treatment or compar$ or interven$ or experiment$) and (group or groups)).mp.; 89 (group or groups).ti,ab.; 90 ((control$ or multicenter or prospectiv$ or retrospectiv$ or evaluation or outcome$ or volunteer$ or subjects or participant$ or compar$) and (trial$ or study or studies or design)).mp.; 91 Ss.ab.; 92 cohort$.ti,ab.; 93 case-control$.ti,ab.; 94 Cross sectional.ti,ab.; 95 (observational adj5 (study or studies or design)).ti,ab.; 96 Longitudinal.mp.; 97 Retrospective.ti,ab.; 98 risk.ti,ab.; 99 Odds ratio.ti,ab.; 100 (case adj (comparison or referent)).ti,ab.; 101 (Causation or causal$).ti,ab.; 102 (Analytic adj (study or studies)).ti,ab.; 103 exp Placebo/; 104 exp Empirical Methods/; 105 Repeated Measures/; 106 Between Groups Design/; 107 exp Evaluation/; 108 cohort analysis/; 109 or/64–108; 110 63 and 109; 111 limit 110 to (human and english language); 112 limit 111 to adulthood <18+ years>; 113 111 not 112; 114 limit 113 to (childhood or adolescence <13 to 17 years>); 115 113 not 114; 116 112 or 115; 117 limit 116 to (chapter or journal or peer reviewed journal or dissertation abstract or report or “review”); 118 remove duplicates from 117; 119 meta analysis/ or statistical analysis/ or “literature review”/; 120 systematic review$.mp.; 121 systematic literature review$.mp.; 122 meta-analysis.sh.; 123 (meta-analys?s or metaanalys?s).ti.; 124 evidence-based medicine.mp.; 125 quantitative review$.ti,ab.; 126 quantitative overview$.ti,ab.; 127 quantitative synthes?s.ti.; 128 quantitative analys?s.ti,ab.; 129 (evidence-based adj (guideline$ or recommendation$)).mp.; 130 health planning guideline$.mp.; 131 cochrane database of systematic reviews.mp.; 132 cdsr.mp.; 133 acp journal club.mp.; 134 (health tech$ assess$ or hta).mp.; 135 technolog$ assess$.mp.; 136 evidence based nursing.mp.; 137 evidence based mental health.mp.; 138 clinical evidence.mp.; 139 biomedical technology assessment.sh.; 140 evidence report$.mp.; 141 or/120–140; 142 systematic$.mp.; 143 critical.mp.; 144 (study and selection).ti,ab.; 145 ((predetermined or inclusion) and criteri$).mp.; 146 exclusion criteri$.mp.; 147 main outcome measure$.mp.; 148 “standard$ of care”.mp.; 149 or/142–148; 150 (survey$ or overview$ or review or reviews or search$ or handsearch$).mp.; 151 (analys?s or critique or appraisal).mp.; 152 (reduction and risk and (death or occurrence)).mp.; 153 or/150–152; 154 (literature or article$ or publication$ or bibliograph$ or published or unpublished or ciation$ or database$ or internet or reference$ or textbook$ or trial$).mp.; 155 meta-analysis.sh.; 156 (medline or medlars or pubmed or embase or index medicus or cochrane or scisearch or web of science or psychinfo or psychlit or cinahl or experta medica or science citation index or sciences citation index or biological abstracts).mp.; 157 (clinical and studies).mp.; 158 (treatment outcome or combine$ or combining or peto or der simonian or dersimonian or fixed effect$ or pooled or pooling or mantel haenszel).mp.; 159 or/154–157; 160 149 and 153 and 159; 161 141 or 160; 162 case report.ti,sh.; 163 editorial.ti,pt.; 164 letter.pt.; 165 note.pt.; 166 or/162–165; 167 161 not 166; 168 systematic review$.mp.; 169 systematic literature review$.mp.; 170 meta-analysis.pt.; 171 (meta-analys?s or metaanalys?s).ti.; 172 evidence-based medicine.mp.; 173 quantitative review$.ti,ab.; 174 quantitative overview$.ti,ab.; 175 quantitative synthes?s.ti.; 176 quantitative analys?s.ti,ab.; 177 (evidence-based adj (guideline$ or recommendation$)).mp.; 178 consensus development conference.pt.; 179 health planning guideline$.mp.; 180 guideline.pt.; 181 cochrane database of systematic reviews.mp.; 182 cdsr.mp.; 183 acp journal club.mp.; 184 health tech$ assess$.mp.; 185 hta.mp.; 186 evidence based nursing.mp.; 187 evidence based mental health.mp.; 188 clinical evidence.mp.; 189 technolog$ assess$.mp.; 190 evidence report$.mp.; 191 or/168–190; 192 systematic$.mp.; 193 critical.mp.; 194 (study and selection).ti,ab.; 195 ((predetermined or inclusion) and criteri$).mp.; 196 exclusion criteri$.mp.; 197 main outcome measure$.mp.; 198 “standard$ of care”.mp.; 199 or/192–198; 200 (survey$ or overview$ or review or reviews or search$ or handsearch$).mp.; 201 (analys?s or critique or appraisal).mp.; 202 (reduction and risk and (death or occurrence)).mp.; 203 or/200–202; 204 (literature or article$ or publication$ or bibliograph$ or published or unpublished or ciation$ or database$ or internet or reference$ or textbook$ or trial$).mp.; 205 meta-analysis.sh.; 206 (medline or medlars or pubmed or embase or index medicus or cochrane or scisearch or web of science or psychinfo or psychlit or cinahl or experta medica or science citation index or sciences citation index or biological abstracts).mp.; 207 (clinical and studies).mp.; 208 (treatment outcome or combine$ or combining or peto or der simonian or dersimonian or fixed effect$ or pooled or pooling or mantel haenszel).mp.; 209 or/204–207; 210 199 and 203 and 209; 211 191 or 210; 212 case report.ti,sh.; 213 editorial.ti,pt.; 214 letter.pt.; 215 newspaper article.pt.; 216 comment.pt.; 217 or/212–216; 218 211 not 217; 219 meta-analysis.pt.; 220 (meta-anal$ or metaanal$).mp.; 221 (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.; 222 (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.; 223 (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.; 224 (integrat$ adj5 research).mp.; 225 (quantitativ$ adj3 synthes$).mp.; 226 or/219–225; 227 review.pt. or (review$ or overview$).mp.; 228 (medline or medlars or pubmed or index medicus or embase or cochrane).mp.; 229 (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.; 230 (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.; 231 (hand search$ or manual search$).mp.; 232 ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.; 233 (pooling or pooled or mantel haenszel).mp.; 234 (peto or der simonian or dersimonian or fixed effect$).mp.; 235 ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.; 236 or/228–235; 237 227 and 236; 238 226 or 237; 239 (hta$ or health technology assessment$ or biomedical technology assessment$).mp.; 240 technology assessment, biomedical/ or biomedical technology asssessment/; 241 239 or 240; 242 238 or 241; 243 63 and (119 or 167 or 218 or 242); 244 243 not 118; 245 limit 244 to (100 childhood or 200 adolescence ); 246 244 not 245; 247 limit 246 to (human and english language); 248 remove duplicates from 247; 249 118 or 248

Table C5 AMED (Allied and Complementary Medicine)—Ovid version

Years/issue searched: 1985 to September 2005
Search date: September 30, 2005
1 exp meditation/; 2 exp yoga/; 3 meditat$.mp.; 4 cogitat$.ti,ab.; 5 Pranayam$.mp.; 6 kapalabhati.ti,ab.; 7 (yoga or yogic$).mp.; 8 mindful$.mp.; 9 zen.ti,ab,sh.; 10 transcendental.ti,ab.; 11 TM-Sidhi.mp.; 12 mahayana.ti,ab.; 13 hiniyana.ti,ab.; 14 theravada$.ti,ab.; 15 vajrayana.ti,ab.; 16 (vipissana or vipashyana).ti,ab.; 17 (dhyana or dyana).ti,ab.; 18 dharana.ti,ab.; 19 zazen.ti,ab.; 20 (kinemantra or KM).ti,ab.; 21 (mantra or mantras).mp.; 22 (samadhi or samatha).ti,ab.; 23 pratyahara.ti,ab.; 24 purusha.ti,ab.; 25 prakruti.ti,ab.; 26 visualization/; 27 ((Visual or guided) adj5 imagery).mp.; 28 ((guided or creative or vivid) adj visualization).ti,ab.; 29 pray$.mp.; 30 Hesychasm.ti,ab.; 31 “lectio divina”.ti,ab.; 32 bonadona.ti,ab.; 33 (qigong or qi gong).mp.; 34 ch'i kung.ti,ab.; 35 “Tae Eul Ju”.ti,ab.; 36 “mind body medicine”/; 37 tai chi/; 38 (tai chi or tai ji).mp.; 39 Taijiquan.ti,ab.; 40 “open awareness”.mp.; 41 “focused awareness”.mp.; 42 relaxation/; 43 “relaxation response”.mp.; 44 “progressive muscle relaxation”.ti,ab.; 45 progressive relaxation.ti,ab.; 46 breathing therapies/; 47 “forced nostril breathing”.ti,ab.; 48 “Uninostril breathing”.ti,ab.; 49 “unilateral breathing”.ti,ab.; 50 (Khundalini or Kundalini).mp.; 51 raja.ti,ab.; 52 hatha.ti,ab.; 53 “sudarshan kriya”.ti,ab.; 54 RRMM.ti,ab.; 55 MBSR.ti,ab.; 56 MBCT.ti,ab.; 57 “Wide-angle lens attention”.ti,ab.; 58 (“Anapana Sati” or anapanasati).mp.; 59 or/1–58; 60 limit 59 to english; 61 ((singl$ or doubl$ or trebl$ or tripl$) and (blind$ or mask$)).mp.; 62 PLACEBOS/ or placebo$.mp.; 63 random$.mp.; 64 RESEARCH DESIGN/; 65 (control$ or prospective$ or volunteer$).ti,ab.; 66 “control (research)”.mp.; 67 (cross?over or factorial or sham$).mp.; 68 (meta?analy$ or systematic review$).mp.; 69 exp research/; 70 exp CLINICAL TRIALS/; 71 (cross?over or placebo$ or control$ or factorial or sham$).mp.; 72 double dummy.mp.; 73 ((clin$ or intervention$ or compar$ or experiment$ or preventive or therap$) adj10 (trial $ or study or studies)).mp.; 74 (outcome$ adj assessment).mp.; 75 (efficacy or effective$ or findings or results).mp.; 76 RESEARCH DESIGN/; 77 FOLLOW-UP STUDIES/; 78 (Follow up adj5 (study or studies or design)).ti,ab.; 79 PROSPECTIVE STUDIES/; 80 LONGITUDINAL STUDIES/; 81 Comorbidity/; 82 exp Probability/; 83 ((Allocat$ or control$ or assign$ or treatment or compar$ or interven$ or experiment$) and (group or groups)).mp.; 84 (group or groups).ti,ab.; 85 ((control$ or multicenter or prospectiv$ or retrospectiv$ or evaluation or outcome$ or volunteer$ or subjects or participant$ or compar$) and (trial$ or study or studies or design)).mp.; 86 Ss.ab.; 87 cohort$.ti,ab.; 88 case-control$.ti,ab.; 89 Cross sectional.ti,ab.; 90 (observational adj5 (study or studies or design)).ti,ab.; 91 Longitudinal.mp.; 92 Retrospective.ti,ab.; 93 risk.ti,ab.; 94 Odds ratio.ti,ab.; 95 (case adj (comparison or referent)).ti,ab.; 96 (Causation or causal$).ti,ab.; 97 (Analytic adj (study or studies)).ti,ab.; 98 RANDOMIZED CONTROLLED TRIAL.pt.; 99 CONTROLLED CLINICAL TRIAL.pt.; 100 RANDOMIZED CONTROLLED TRIALS/; 101 RANDOM ALLOCATION/; 102 DOUBLE BLIND METHOD/; 103 SINGLE-BLIND METHOD/; 104 CLINICAL TRIAL.pt.; 105 COMPARATIVE STUDY/; 106 exp COHORT STUDIES/; 107 Age factors/; 108 Comorbidity/; 109 exp Risk/; 110 (therapy or treat$).mp.; 111 (epidemiologic$ adj (study or studies)).ti,ab.; 112 clinical research.mp.; 113 or/61–112; 114 113 and 60; 115 meta-analysis.pt.; 116 (meta-anal$ or metaanal$).mp.; 117 (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.; 118 (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.; 119 (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.; 120 (integrat$ adj5 research).mp.; 121 (quantitativ$ adj3 synthes$).mp.; 122 or/115–121; 123 review.pt. or (review$ or overview$).mp.; 124 (medline or medlars or pubmed or index medicus or embase or cochrane).mp.; 125 (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.; 126 (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.; 127 (hand search$ or manual search$).mp.; 128 ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.; 129 (pooling or pooled or mantel haenszel).mp.; 130 (peto or der simonian or dersimonian or fixed effect$).mp.; 131 ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.; 132 or/124–131; 133 123 and 132; 134 122 or 133; 135 (hta$ or health technology assessment$ or biomedical technology assessment$).mp.; 136 technology assessment, biomedical/ or biomedical technology asssessment/; 137 135 or 136; 138 134 or 137; 139 60 and 138; 140 114 or 139

Table C6 CINAHL^®^ (Cumulative Index to Nursing and Allied Health Literature)—Ovid Version

Years/issue searched: 1982 to September 2005, week 5
Search date: October 4, 2005
1 exp “MEDITATION (IOWA NIC)”/ or exp MEDITATION/; 2 yoga/ or mind body techniques/; 3 exp Guided Imagery/; 4 exp Prayer/; 5 exp Tai Chi/; 6 exp Relaxation Techniques/; 7 exp “progressive muscle relaxation (iowa nic)”/; 8 exp “AUTOGENIC TRAINING (IOWA NIC)”/; 9 meditat$.mp.; 10 cogitat$.ti,ab.; 11 Pranayam$.mp.; 12 kapalabhati.ti,ab.; 13 (yoga or yogic$).mp.; 14 mindful$.mp.; 15 zen.ti,ab,sh.; 16 transcendental.ti,ab.; 17 TM-Sidhi.mp.; 18 mahayana.ti,ab.; 19 hiniyana.ti,ab.; 20 theravada$.ti,ab.; 21 vajrayana.ti,ab.; 22 (vipissana or vipashyana).ti,ab.; 23 (dhyana or dyana).ti,ab.; 24 dharana.ti,ab.; 25 zazen.ti,ab.; 26 (kinemantra or KM).ti,ab.; 27 (mantra or mantras).mp.; 28 (samadhi or samatha).ti,ab.; 29 pratyahara.ti,ab.; 30 purusha.ti,ab.; 31 prakruti.ti,ab.; 32 ((Visual or guided) adj5 imagery).mp.; 33 ((guided or creative or vivid) adj visualization).ti,ab.; 34 pray$.mp.; 35 Hesychasm.ti,ab.; 36 “lectio divina”.ti,ab.; 37 bonadona.ti,ab.; 38 (qigong or qi gong).mp.; 39 ch'i kung.ti,ab.; 40 “Tae Eul Ju”.ti,ab.; 41 (tai chi or tai ji).mp.; 42 Taijiquan.ti,ab.; 43 “open awareness”.mp.; 44 “focused awareness”.mp.; 45 “relaxation response”.mp.; 46 “progressive muscle relaxation”.ti,ab.; 47 progressive relaxation.ti,ab.; 48 “forced nostril breathing”.ti,ab.; 49 “Uninostril breathing”.ti,ab.; 50 “unilateral breathing”.ti,ab.; 51 (Khundalini or Kundalini).mp. [mp=title, subject heading word, abstract, instrumentation]; 52 raja.ti,ab.; 53 hatha.ti,ab.; 54 “sudarshan kriya”.ti,ab.; 55 RRMM.ti,ab.; 56 MBSR.ti,ab.; 57 MBCT.ti,ab.; 58 “Wide-angle lens attention”.ti,ab.; 59 (“Anapana Sati” or anapanasati).mp. [mp=title, subject heading word, abstract, instrumentation]; 60 or/1–59; 61 random assignment/; 62 exp random sample/; 63 crossover design/; 64 exp clinical trials/; 65 exp comparative studies/; 66 “control (research)”.mp.; 67 control group/; 68 factorial design/; 69 quasi-experimental studies/; 70 nonrandomized trials/; 71 placebos/; 72 meta analysis/; 73 clinical nursing research.mp. or clinical research/; 74 community trials/ or experimental studies/ or one- shot case study/ or pretest-posttest design/ or solomon four-group design/ or static group comparison/ or study design/; 75 (clinical trial or systematic review).pt.; 76 random$.mp.; 77 ((singl$ or doubl$ or tripl$ or trebl$) adj25 (blind$ or mask$ or dummy)).mp.; 78 (cross?over or placebo$ or control$ or factorial or sham$).mp.; 79 ((clin$ or intervention$ or compar$ or experiment$ or preventive or therapeutic) adj10 trial$).mp.; 80 (meta?analy$ or systematic review$).mp.; 81 convenience sample/ or sample size/; 82 exp research, allied health/ or research, medical/ or research, nursing/; 83 research question/; 84 nursing practice, research-based/; 85 exp research methodology/; 86 exp evaluation research/; 87 concurrent prospective studies/ or prospective studies/; 88 (nursing interventions or research or review or proceedings or “tables/charts” or protocol).pt.; 89 (Follow up adj5 (study or studies or design)).ti,ab.; 90 exp COHORT STUDIES/; 91 exp CROSS SECTIONAL STUDIES/; 92 exp CASE CONTROL STUDIES/; 93 Epidemiologic research/; 94 Seroprevalence studies/; 95 exp Causal Attribution/; 96 Reproducibility of results/; 97 Correlational Study/; 98 Age factors/; 99 Comorbidity/; 100 Odds ratio/; 101 Relative Risk/ or Risk Assessment/; 102 Probability/; 103 Patient Selection/; 104 ((Allocat$ or control$ or assign$ or treatment or compar$ or interven$ or experiment$) and (group or groups)).mp. [mp=title, subject heading word, abstract, instrumentation]; 105 (group or groups).ti,ab.; 106 (control$ or prospectiv$ or retrospectiv$ or volunteer$ or participant$ or compar$).mp. and (trial$ or study or studies or design).ti,ab,sh. [mp=title, subject heading word, abstract, instrumentation]; 107 cohort$.ti,ab.; 108 case-control$.ti,ab.; 109 Cross sectional.ti,ab.; 110 (observational adj5 (study or studies or design)).ti,ab.; 111 Longitudinal.mp.; 112 Retrospective.ti,ab.; 113 Relative risk.ti,ab.; 114 Odds ratio.ti,ab.; 115 (case adj (comparison or referent)).ti,ab.; 116 (Causation or causal$).ti,ab.; 117 (Analytic adj (study or studies)).ti,ab.; 118 or/61–117; 119 60 and 118; 120 limit 119 to english; 121 limit 120 to (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged <80 and over>”); 122 120 not 121; 123 limit 122 to (fetus or newborn infant or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>); 124 122 not 123; 125 121 or 124; 126 meta-analysis.pt.; 127 (meta-anal$ or metaanal$).mp.; 128 (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.; 129 (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.; 130 (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.; 131 (integrat$ adj5 research).mp.; 132 (quantitativ$ adj3 synthes$).mp.; 133 or/126–132; 134 review.pt. or (review$ or overview$).mp.; 135 (medline or medlars or pubmed or index medicus or embase or cochrane).mp.; 136 (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.; 137 (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.; 138 (hand search$ or manual search$).mp.; 139 ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.; 140 (pooling or pooled or mantel haenszel).mp.; 141 (peto or der simonian or dersimonian or fixed effect$).mp.; 142 ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.; 143 or/135–142; 144 134 and 143; 145 133 or 144; 146 (hta$ or health technology assessment$ or biomedical technology assessment$).mp.; 147 technology assessment, biomedical/ or biomedical technology asssessment/; 148 146 or 147; 149 145 or 148; 150 60 and 149; 151 limit 150 to english; 152 limit 151 to (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged <80 and over>”); 153 151 not 152; 154 limit 153 to (fetus or newborn infant or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>); 155 153 not 154; 156 152 or 155; 157 125 or 156

Table C7 Web of Science^®^-Institute for Scientific Information—The Thomson Corporation

Years/issue searched: 1900 to 2005
Search date: September 21, 2005
#1 TS=meditat* OR TS=yoga OR TS=yogic OR TS=(tai chi) OR TS=(tai ji) OR TS=(qi gong) OR TS=qigong OR TS=pray* OR TS=mantra* OR TS=(progressive muscle relaxation) OR TS=(relaxation response) OR TS=unilateral W/1 breath* OR TS=(guided imagery) OR TS=transcendental OR TS=zen OR TS=rrmm OR TS=mbsr OR TS=mbct OR TS=(unilateral forced) OR TS=(forced nostril) OR TS=(progressive relaxation) OR TS=mindful*
#2 TS=psychotherap* OR TS=sympt* OR TS=clinic* OR TS=illness* OR TS=rehab* OR TS=heal OR TS=healing OR TS=health OR TS=medicin* OR TS=medical* OR TS=therap* OR TS=counsel* OR TS=interven* OR TS=physiol* OR TS=heart* OR TS=cardiac OR TS=stress* OR TS=analges* OR TS=anxiety OR TS=stress* OR TS=cancer* OR TS=psychol* OR TS=metabol* OR TS=respirat* OR TS=neuro* OR TS=participants OR TS=patients OR TS=(control group*)
#3 SO=psychotherap* OR SO=sympt* OR SO=clinic* OR SO=illness* OR SO=rehab* OR SO=heal OR SO=healing OR SO=health OR SO=medicin* OR SO=medical* OR SO=therap* OR SO=counsel* OR SO=interven* OR SO=physiol* OR SO=heart* OR SO=cardiac OR SO=stress* OR SO=analges* OR SO=anxiety OR SO=stress* OR SO=cancer* OR SO=psychol* OR SO=metabol* OR SO=respirat* OR SO=neuro*
#4 #2 OR #3
#5 #1 AND #4
#6 #5
DocType=All document types; Language=English; Databases=SCI-EXPANDED, SSCI, A&HCI; Timespan=1900-2005
#7 #5
DocType=Art Exhibit Review OR Biographical-Item OR Book Review OR Dance Performance Review OR Database Review OR Fiction, Creative Prose OR Film Review OR Hardware Review OR Music Performance Review OR Music Score OR Music Score Review OR News Item OR Poetry OR Script OR Software Review OR TV Review, Radio Review OR Theater Review; Language=All languages; Databases=SCI-EXPANDED, SSCI, A&HCI; Timespan=1900-2005
#8 #6 NOT #7

Table C8 CSA Neurosciences Abstracts—CSA Illumina

Years/issue searched: 1982 to 2005
Search date: August 4, 2005
(((meditat* or yoga or yogic) or ((tai chi) or (tai ji) or (qi gong)) or (qigong or pray* or mantra*) or ((progressive muscle relaxation) or (relaxation response) or (unilateral breath*)) or ((guided imagery) or transcendental or zen) or AB=(rrmm or mbsr or mbct) or ((forced nostril breath*) or (progressive relaxation) or mindful*) or AB=(pmr or cogitat*)) and (PT=bibliography or PT=(book monograph) or PT=conference or PT=dissertation or PT=(journal article) or PT=report or PT=review or PT=(training manual))) not ((rat or rats or mantis* or pigeon*) or ((mice or mouse) or sheep or pig or pigs))

Table C9 Cochrane Complementary Medicine Trials Register and CAMPAIN (Complementary and Alternative Medicine and Pain Database)

Years/issue searched: 1983 to 2003
Search date: October 25, 2005
Meditation or meditate or meditating or mindful or mindfulness or qigong or qi gong or tai chi or taiji or yoga or yogic or relaxation response or autogenic or kundalini or pranayama or pranayam or samahdi or imagery or visualization or mantra or cogitation or mbsr or kinemantra or dyana or dhyana or naam or anapanasati or mbct or hatha or raja or vipashyana or vipassana

Table C10 CDSR- (EBM Reviews-Cochrane Database of Systematic Reviews)—Ovid version

Years/issue searched: 3rd Quarter 2005
Search date: September 9, 2005
1 exp meditation/; 2 exp yoga/; 3 meditat$.mp.; 4 cogitat$.ti,ab.; 5 Pranayam$.mp.; 6 kapalabhati.ti,ab.; 7 (yoga or yogic$).mp.; 8 mindful$.mp.; 9 zen.ti,ab,sh.; 10 transcendental.ti,ab.; 11 TM-Sidhi.mp.; 12 mahayana.ti,ab.; 13 hiniyana.ti,ab.; 14 theravada$.ti,ab.; 15 vajrayana.ti,ab.; 16 (vipissana or vipashyana).ti,ab.; 17 (dhyana or dyana).ti,ab.; 18 dharana.ti,ab.; 19 zazen.ti,ab.; 20 (kinemantra or KM).ti,ab.; 21 (mantra or mantras).mp.; 22 (samadhi or samatha).ti,ab.; 23 pratyahara.ti,ab.; 24 purusha.ti,ab.; 25 prakruti.ti,ab.; 26 ((Visual or guided) adj5 imagery).mp.; 27 ((guided or creative or vivid) adj visualization).ti,ab.; 28 pray$.mp.; 29 Hesychasm.ti,ab.; 30 “lectio divina”.ti,ab.; 31 bonadona.ti,ab.; 32 (qigong or qi gong).mp.; 33 ch'i kung.ti,ab.; 34 “Tae Eul Ju”.ti,ab.; 35 “mind-body and relaxation techniques”/ or “mind-body relations (metaphysics)”/; 36 tai ji/; 37 (tai chi or tai ji).mp.; 38 Taijiquan.ti,ab.; 39 “open awareness”.mp.; 40 “focused awareness”.mp.; 41 “relaxation response”.mp.; 42 “progressive muscle relaxation”.ti,ab.; 43 progressive relaxation.ti,ab.; 44 “forced nostril breathing”.ti,ab.; 45 “Uninostril breathing”.ti,ab.; 46 “unilateral breathing”.ti,ab.; 47 (Khundalini or Kundalini).mp.; 48 raja.ti,ab.; 49 hatha.ti,ab.; 50 “sudarshan kriya”.ti,ab.; 51 RRMM.ti,ab.; 52 MBSR.ti,ab.; 53 MBCT.ti,ab.; 54 “zoom lens attention”.ti,ab.; 55 “Wide-angle lens attention”.ti,ab.; 56 (“Anapana Sati” or anapanasati).mp.; 57 kabat-zinn.ab.; 58 or/1–57

Table C11 OCLC Article First and OCLC Proceedings First—OCLC First Search

Years/issue searched: 1993 to 2005
Search date: September 22, 2005
(kw: meditat* OR kw: yoga OR kw: yogic OR (kw: tai and kw: chi) OR (kw: tai and kw: ji) OR (kw: qi and kw: gong) OR kw: qigong OR kw: pray* OR kw: mantra* OR (kw: progressive and kw: muscle and kw: relaxation) OR (kw: relaxation and kw: response) OR ((kw: unilateral and kw: W/1 and kw: breath*) OR (kw: guided and kw: imagery)) OR kw: transcendental OR kw: zen OR kw: rrmm OR kw: mbsr OR kw: mbct OR (kw: unilateral and kw: forced) OR (kw: forced and kw: nostril) OR (kw: progressive and kw: relaxation) OR kw: mindful*) and ((kw: psychotherap* OR kw: sympt* OR kw: clinic* OR kw: illness* OR kw: rehab* OR kw: heal OR kw: healing) or (kw: health OR kw: medicin* OR kw: medical* OR kw: therap* OR kw: counsel* OR kw: interven* OR kw: physiol*) or (kw: heart* OR kw: cardiac OR kw: stress* OR kw: analges* OR kw: anxiety OR kw: stress* OR kw: cancer* OR kw: psychol*) or (kw: metabol* OR kw: respirat*) or (kw: neurosci* OR kw: neurol* OR kw: neuron+) or (kw: participant+ OR kw: patient+ OR kw: control w group*)).

Table C12 NLM Gateway-National Library of Medicine

Years/issue searched: 1950 to 2005
Search date: October 25, 2005
meditation or yoga or tai chi or qigong

Table C13 Current Clinical Trials—Biomed Central

Years/issue searched: 1998 to 2005
Search date: October 24, 2005
imagery OR mindful* OR “tai chi” OR qigong OR yoga OR ‘qi gong’ OR meditation

Table C14 National Research Register

Years/issue searched: 2000 to 2005
Search date: October 24, 2005
imagery OR mindful* OR “tai chi” OR qigong OR yoga OR ‘qi gong’ OR meditation

Table C15 CRISP (Computer Retrieval of Information on Scientific Projects)

Years/issue searched: 2005 to 2006
Search date: February 21, 2006
$(meditate ∣ meditation ∣ meditating ∣ mindful ∣ mindfulness ∣ yoga ∣ qigong