# Appendix B. Development of Consensus on a Set of Criteria for an Operational Definition of Meditation

A consensus definition of meditation has not been established. The rationale for developing a consensus definition for meditation was to guide an unbiased selection of studies to be included in the review. We sought to develop consensus among a panel of experts on a set of criteria for a working definition of meditation; the relative importance of these criteria in defining a practice as meditation; and on a classification of practices as meditation or not meditation.

## Methods

### Study Design

A five-round modified Delphi study was conducted from August to December 2006. The Delphi technique is a research tool designed to address complex problems with a high level of uncertainty that are not suited to statistical methods or open deliberation.^36,37^ Its goal is to obtain the most reliable consensus among a group of experts on a particular topic.^36^ The technique involves recruiting a group of experts to participate in an iterative process of answering questionnaire, receiving feedback regarding group responses, and revising their opinions in light of this feedback.^37^ The distinguishing characteristics of the Delphi technique are anonymity, iteration (processes occur in rounds), controlled feedback, (showing the distribution of the group's response) and statistical group response (expressing judgment using summary measures of the full group response). This method was chosen over other consensus techniques due to its ability to allow all group members equal participation and influence, even when separated geographically.^383^

### Study Participants

Participants were seven individuals who acted as members of the Technical Expert Panel (TEP) for a report on the state of the research of meditation practices in healthcare. Each member lived in the United States or Canada and had expertise and training in meditation practices.

### Development of Questionnaires

An initial list of potential criteria for an operational definition of meditation was generated from a preliminary list of key articles.^9,98^ Similarly, a list of potential meditation practices was developed based on an initial review of the literature. The items were refined through an iterative review process, until a set of nine criteria to define meditation was found. The first-round questionnaire consisted of two parts. In the first part of the survey, participants were asked to rate the importance of the nine criteria as “not important at all,” “important but not essential,” or "essential. They were also asked to suggest any other criteria that they felt were essential for a working definition of meditation. In the second part of the questionnaire, participants were given a list of 41 interventions and were asked to indicate which interventions qualified as meditation practices based on the essential criteria rated in the first part of the questionnaire. The participants were also asked to indicate any other intervention that they believed involved meditation but that was not represented in the list.

In round two, feedback was provided on the group responses from round one. The participants were asked to reflect on their responses from the first round in light of the peer responses and to either confirm or change their responses accordingly. Based on round one comments, the wording of some criteria was modified, and three practices were added to the list of interventions. The second-round process was repeated until consensus was reached in round five. Round three helped to establish consensus on items for which disagreement persisted. Round four aimed to determine if the criteria considered “essential” to meditation in previous rounds were, in fact, a necessary part of the practices. Participants were asked to indicate which of the “essential” and “important but not essential” criteria applied to each potential intervention. The list of potential meditation practices was refined until consensus was reached.

### Study Procedures

The TEP members received a personalized letter describing the Delphi process, and the expectations regarding their participation. The questionnaires were sent electronically. Participants were given up to 1 week to respond to each questionnaire, and nonresponders were sent one reminder. Although participants were aware of the identity of other responders, they were blind to individual responses, ensuring anonymity throughout the process.

### Data Analysis

Data from electronic questionnaires were exported into Microsoft Excel^™^ (Microsoft Corporation, Redmond, WA) spreadsheets and analyzed with Statistical Package for the Social Sciences for Windows (SPSS^™^ version 14.1, SPSS, Inc., Chicago, IL). Categorical data were collected from each survey round and expressed as frequencies. The frequency of endorsement was tabulated for each criteria and practice. A priori, it was established that a frequency of endorsement of five out of seven would be considered consensus.

## Results

The response rate in all rounds of the survey was 100 percent. Table B1 shows the experts' final-round responses regarding the importance of various criteria for a working definition of meditation. Participants in the Delphi study agreed that a meditation practice (1) uses a defined technique, (2) involves logic relaxation, and (3) involves a self-induced state/mode. These criteria were considered essential. Participants also agreed that a meditation practice may (1) involve a state of psychophysical relaxation somewhere in the process; (2) use a self-focus skill or anchor; (3) involve an altered state/mode of consciousness, mystic experience, enlightenment or suspension of logical thought processes; (4) be embedded in a religious/spiritual/philosophical context; or (5) involve an experience of mental silence. After round four, participants did not reach consensus on whether bringing about mental calmness and physical relaxation by suspending the stream of thoughts would be essential or important to define an intervention as meditation.

Table B1 Final responses for the importance of various criteria for an operational definition of meditation

Criteria | Not important at all | Important but not essential | Essential | Don't know
1. It uses a defined technique | 0 | 0 | 7 | 0
2. It involves logic relaxation: not “to intend” to analyze the possible psychophysical effects, not “to intend” to judge the possible results, not “to intend” to create any type of expectation regarding the process | 0 | 0 | 7 | 0
3. It involves a state of psychophysical relaxation installed somewhere during the process | 1 | 5 | 1 | 0
4. It involves a self-induced state/mode. It refers to a therapeutic method that can be taught by an instructor, but self-applied by the individual him/herself. It must, for instance, be feasible to be done at home, without the presence of the instructor. There must not be any relationship of dependence | 0 | 1 | 6 | 0
5. It uses a self-focus skill or “anchor. A concentration (“positive anchor”) or a turning off (“negative anchor”) focus is used, in order to avoid sequels of undesirable thinking, torpor, sleep | 0 | 5 | 2 | 0
6. It involves altered states/modes of consciousness, mystic experiences, “enlightenment” or suspension of logical thought processes | 1 | 5 | 1 | 0
7. It is embedded in a religious/ spiritual/philosophical context | 0 | 7 | 0 | 0
8. It involves an experience of mental silence | 0 | 5 | 1 | 1
9. It involves a self-paced systematic desensitization | 6 | 1 | 0 | 0
10. It brings about mental calmness and physical relaxation by suspending the stream of thoughts that normally occupy the mind | 0 | 3 | 4 | 0

Table B2 shows the experts' final responses regarding the interventions that can be considered as meditation practices or practices involving a meditative component. The experts agreed that 32 out of 41 potential interventions were meditation or involved a meditative component in the practice; therefore, these 32 practices were considered for inclusion in the review.

Table B2 Final responses for interventions considered meditation practices or practices involving a meditative component

Intervention | Yes | No | Don't know
1. Vipassana | 7 | 0 | 0
2. Dhyana | 7 | 0 | 0
3. Zen Budhhist meditation (Zazen) | 7 | 0 | 0
4. Kinemantra meditation (KM) | 7 | 0 | 0
5. Anapana sati | 6 | 1 | 0
6. Mindfulness-based stress reduction (MBSR) | 7 | 0 | 0
7. Mindfulness-based cognitive therapy (MBCT) | 7 | 0 | 0
8. Transcendental Meditation^®^ technique (TM^®^) | 7 | 0 | 0
9. Mindfulness meditation (MM) | 7 | 0 | 0
10. Relaxation response (RR) | 7 | 0 | 0
11. Progressive muscle relaxation (PMR) | 0 | 7 | 0
12. Unilateral forced nostril breathing | 6 | 1 | 0
13. Yoga (any) | 6 | 1 | 0
14. Kundalini yoga | 7 | 0 | 0
15. Raja yoga | 7 | 0 | 0
16. Hatha yoga | 5 | 2 | 0
17. Sudarshan kriya yoga | 6 | 1 | 0
18. Yogic breathing | 6 | 1 | 0
19. Pranayama | 6 | 1 | 0
20. Kapalabhati | 6 | 1 | 0
21. Centering prayer | 6 | 1 | 0
22. Qigong | 5 | 1 | 1
23. Tai chi | 5 | 2 | 0
24. Samadhi | 7 | 0 | 0
25. Visual imagery | 0 | 7 | 0
26. Guided imagery | 1 | 5 | 1
27. Guided visualization | 1 | 6 | 0
28. Creative visualization | 1 | 6 | 0
29. Mantra | 7 | 0 | 0
30. Pratyahara | 6 | 1 | 0
31. Dharana | 7 | 0 | 0
32. Tae eul ju | 5 | 1 | 1
33. Hesychasm | 5 | 2 | 0
34. Lectio divina | 2 | 5 | 0
35. Silva method | 1 | 6 | 0
36. Naam | 5 | 2 | 0
37. Dialectical behavior therapy | 1 | 6 | 0
38. Autogenic training | 0 | 7 | 0
39. Clinically standardized meditation | 5 | 2 | 0
40. Sound chanting | 5 | 2 | 0
41. Sufic practices | 7 | 0 | 0

This study was undertaken to develop a working definition of meditation that could be used to clearly differentiate meditation practices from those that are not meditation. These criteria formed part of a multicomponent approach to study selection in the report on the state of research of meditation practices for healthcare. The results of this study provide valuable insight into the problem of defining meditation and contribute with a preliminary set of criteria with which to judge potential meditation practices.