# Appendix J. Characteristics of Studies on the Physiological and Neuropsychological Effects of Meditation Practices

Table J1 Characteristics of randomized controlled trials on the physiological and neuropsychological effects of meditation practices

Study, country | Condition | Duration/followup, ITT | Characteristics of study population | | Intervention | | Comparison groups | | Outcome category (measure) | Authors' conclusions
| Outcome examined | | Age (mean/range) Gender | N participants | Intervention type Meditation practice | N participants | Control | N participants
| System evaluated
Agrawal RP, 2003^278^ | Type 2 DM | 3 mo | 51.6 yr | R: 200 | Single | R: 100 | Exercise | R: 100 | CVF (BP), DIG (LDL, HDL, VLDL, TC, TG), END (CM [FBS, Hb-A1c]), UE (RFT [urea, Cr, microalbuminuria]) | Yoga can be used as adjunct treatment in diabetes to improve glycemic control and quality of life
India | Physiological | No | F = 46 | C: 154 | | C: 72 | | C: 82
| Cardiovascular, digestive, endocrine, urinary/excretory | | M = 108 | W: 46 | Yoga | W: 28 | | W: 18
Alexander CN, 1991^279^ | Elderly | 18 mo | 80.7 yr | R: 73 | Single | R: 21 | MM | R: 23 | CVF (BP), COG/N (CF, RSG, VA) | TM^®^ group significantly improved cognitive flexibility, word fluency, and lowered SBP
United States | Physiological, neuropsychological | No | F = 60 | C: 73 | | C: 20 | | C: 21 | | TM^®^ group were more relaxed when finished
| Cardiovascular, cognitive/neuropsychological | | M = 13 | W: 0 | TM^®^ | W: 1 | | W: 2
| | | | | | | Rest | R: 22
| | | | | | | | C: 21
| | | | | | | | W: 1
| | | | | | | NT | R: 7
| | | | | | | | C: 11
| | | | | | | | W: NA
Bahrke MS, 1978^304^ | Healthy volunteers | 1 se | 51.9 yr | R: 75 | Single | R: 25 | Exercise | R: 25 | CVF (HR, BGM [VO_2_]) | Acute physical activitynon-cultic meditation and a quiet rest session are equally effective in reducing state anxiety
United States | Physiological | NR | F = 0 | C: 75 | | C: 25 | | C: 25
| Cardiovascular | | M = 75 | W: 0 | RR | W: 0 | | W: 0
| | | | | | | Rest | R: 25
| | | | | | | | C: 25
| | | | | | | | W: 0
Block RA, 1989^177^ | College/university students | 1 se | Age NR | R: 60 | Single | R: 20 | Yoga | R: 20 | COG/N (SA, VA) | Men performed better than women on spatial tasks but women had better results on verbal task
United States | Neuropsychological | NR | F = 30 | C: 60 | | C: 20 | | C: 20 | | Sex differences should be considered in cerebral processes and cognitive performance
| Cognitive/neuropsychological | | M = 30 | W: 0 | UFNB (Lt) | W: 0 | | W: 0
| | | | | | | Rest | R: 20
| | | | | | | | C: 20
| | | | | | | | W: 0
Blumenthal JA, 1991^280^ | Elderly | 14 mo | 67 yr | R: 101 | Single | R: 33 | Exercise | R: 34 | CVF (HR, BGM [VO_2_, VO_2_ max], ECG), COG/N (MEM, ATN, CF), DIG (LDL, HDL, TC, TG), MSK (BDT) | Subjects experienced 10%–15% improvement in aerobic capacity after 4 mo of aerobic exercise
United States | Physiological, neuropsychological | Yes | F = 51 | C: 97 | | C: 31 | | C: 34 | | Few improvements in cognitive performance
| Cardiovascular, cognitive/neuropsychological, digestive, musculoskeletal | | M = 50 | W: 4 | Yoga | W: 2 | | W: 0
| | | | | | | WL | R: 34
| | | | | | | | C: 32
| | | | | | | | W: 2
Bose S, 1987^305^ | College/university students | 3 mo | 17–23 yr | R: 200 | Single | R: 30 | NT | R: 29 | CVF (BP) | No significant differences in uric acidcholesterol or fibrinolysis time in the two groups;
India | Physiological | NR | F = 0 | C: 200 | | C: 30 | | C: 29 | | Significant reduction in response to cold pressor tests after Shavansana training
| Cardiovascular | | M = 200 | W: 0 | Shavasana | W: 0 | | W: 0
| | | | | | | NT | R: 141
| | | | | | | | C: 141
| | | | | | | | W: 0
Bowman AJ, 1997^281^ | Elderly | 1.5 mo | 67 yr | R: 40 | Single | R: 20 | Exercise | R: 20 | CVF (BP, HR, BGM [VO_2_ max], HR variability, baroreflex sensitivity, Max aortic velocity, PAA, cAMP) | Six wk of aerobic exercise training did not modify baroreflex sensitivity among healthy, elderly, sedentary, normotensive subjects
United Kingdom | Physiological | No | F = 17 | C: 26 | | C: 14 | | C: 12
| Cardiovascular | | M = 23 | W: 14 | Yoga | W: 6 | | W: 8
Broota A, 1995^204^ | Hypertension | 8 se | NR | R: 40 | Single | R: 10 | PMR | R: 10 | CVF (BP), NER (GSR) | Three Yoga techniques were effective in reducing symptoms of hypertension
India | Physiological | NR | F = 0 | C: 40 | | C: 10 | | C: 10 | | Shavasana was most effective, followed by Broota, and Jacobson's technique
| Cardiovascular, nervous | | M = 40 | W: 0 | Shavasana | W: 0 | | W: 0
| | | | | | | Rest | R: 10
| | | | | | | | C: 10
| | | | | | | | W: 0
| | | | | | | NT | R: 10
| | | | | | | | C: 10
| | | | | | | | W: 0
Fields JZ, 2002^282^ | Elderly | 12 mo | 74.2 yr | R: 57 | Composite | R: 14 | Exercise | R: 9 | CVF (BP, cIMT), DIG (LIP, LDL, HDL, TG), END ( CM [FBS, OGTT, glyco-Hb, fasting insuline]) | The multimodality traditional approach can attenuate atherosclerosis in older subjects particularly those with marked CHD risk
United States | Physiological | Yes | F = 16 | C: 43 | | C: 8 | | C: 5
| Cardiovascular, digestive, endocrine | | M = 27 | W: 14 | TM^®^ + herbal food + diet + Yoga asanas | W: 6 | | W: 4
| | | | | | | NT | R: 20
| | | | | | | | C: 16
| | | | | | | | W: 4
Hoffman JW, 1982^283^ | Healthy volunteers | 1 mo | 25.4 yr | R: 30 | Single | R: 15 | Rest | R: 15 | CVF (BP, HR), END (ACF [NE]) | With RR, more NE is required to produce the normal compensatory increase in HR and BP
United Kingdom | Physiological | No | F = 8 | C: 19 | | C: 10 | | C: 9 | | RR may reduce adrenergic end-organ responsivity
| Cardiovascular, endocrine | | M = 11 | W: 11 | RR | W: 5 | | W: 6
Jin P, 1992^307^ | Healthy volunteers | 2 d | 36.2 yr | R: 96 | Single | R: 24 | Exercise | R: 24 | CVF (BP, HR), END (ACF [cortisol, salivary EPI, NE, and dopamine]) | Tai Chi reduced state anxiety and enhanceed vigour
Australia | Physiological | NR | F = 48 | C: 96 | | C: 24 | | C: 24 | | This effect could be partially due to subjects' high expectations about gains from Tai Chi
| Cardiovascular, endocrine | | M = 48 | W: 0 | Tai Chi | W: 0 | | W: 0
| | | | | | | HE | R: 24
| | | | | | | | C: 24
| | | | | | | | W: 0
| | | | | | | Reading | R: 24
| | | | | | | | C: 24
| | | | | | | | W: 0
Monro R, 1992^308^ | Type 2 DM | 12 wk | 54.9 yr | R: 21 | Single | R: 11 | Medication | R: 10 | END (CM [FBS, Hb-A1c]) | Yoga classes improved glucose homeostasis in diabetic patients (NIDDM)
United Kingdom | Physiological | NR | F = 11 | C: 21 | | C: 11 | | C: 10
| Endocrine | | M = 11 | W: 0 | Yoga | W: 0 | | W: 0
Peters RK, 1977^284^ | Healthy volunteers | 12 wk | 33.4 yr | R: 190 | Single | R: 58 | Rest | R: 39 | CVF (BP) | RR significantly reduced BP even if the initial BP was within normal ranges
United States | Physiological | Yes | F = 96 | C: 178 | | C: 54 | | C: 36
| Cardiovascular | | M = 82 | W: 12 | RR | W: 4 | | W: 3
| | | | | | | NT | R: 39
| | | | | | | | C: 36
| | | | | | | | W: 3
| | | | | | | NT | R: 54
| | | | | | | | C: 52
| | | | | | | | W: 2
Pollak MH, 1979^288^ | Healthy volunteers | 1 se | NR | R: 41 | Single | R: 0 | PMR | R: NR | CVF (HR, DPV), NER (SCL), RES (respiratory rate) | RR can produce a significant changes in HR
United States | Physiological | No | F = 15 | C: 30 | | C: 10 | | C: 10
| Cardiovascular, nervous, respiratory | | M = 15 | W: 11 | RR | W: 0 | | W: NR
| | | | | | | Rest | R: NR
| | | | | | | | C: 10
| | | | | | | | W: NR
Reddy KM, 1990^309^ | Athletes | 6 wk | 19.8 yr | R: 30 | Single | R: 15 | WL | R: 15 | BC (Hb), CVF (HR, BP), COG/N (CF), RES (PFT [VT]) | TM^®^ improved both short- and long-term athletic performance and physiological development
United States | Physiological neuropsychological | NR | F = 7 | C: 30 | | C: 15 | | C: 15 | | TM^®^ increased physiological efficiency and flexibility
| Blood, cardiovascular, cognitive/neuropsychological, respiratory | | M = 23 | W: 0 | TM^®^ | W: 0 | | W: 0
Sun WY, 1996^285^ | Elderly | 12 wk | >60 yr | R: 20 | Single | R: 10 | NT | R: 10 | CVF (BP, HR) | Tai Chi produced significant improvements in resting BP, stress level, and shoulder and knee flexibility
United States | Physiological | Yes | F = 13 | C: 20 | | C: 10 | | C: 10
| Cardiovascular | | M = 7 | W: 0 | Tai Chi | W: 0 | | W: 0
Telles S, 1994^140^ | Healthy volunteers | 1 mo | 34 yr | R: 48 | Single | R: 12 | Yoga | R: 12 | CVF (HR, BGM [VO_2_]), NER (GSR), RES (respiratory rate) | UFNB have a marked activating or relaxing effect on the sympathetic nervous system
India | Physiological | NR | F = 0 | C: 48 | | C: 12 | | C: 12
| Cardiovascular, nervous, respiratory | | M = 48 | W: 0 | UFNB (Rt) | W: 0 | | W: 0
| | | | | | | Yoga | R: 24
| | | | | | | | C: 24
| | | | | | | | W: 0
Thornton EW, 2004^286^ | Healthy volunteers | 3 mo | 47.8 yr | R: 40 | Single | R: 20 | NT | R: 20 | CVF (BP) | A 12-wk Tai Chi program improved the dynamic balance of middle-aged adults
Hong Kong | Physiological | No | F = 40 | C: 34 | | C: 17 | | C: 17
| Cardiovascular | | M = 0 | W: 6 | Tai Chi | W: 3 | | W: 3
Young DR, 1999^287^ | Elderly | 12 wk | 66.7 yr | R: 62 | Single | R: 31 | Exercise | R: 31 | CVF (BP, BGM [VO_2_ max]) | Tai Chi and moderate intensity aerobic exercise may have similar effects on BP in previously sedentary older individuals
United States | Physiological | No | F = 49 | C: 62 | | C: 31 | | C: 31
| Cardiovascular | | M = 13 | W: 0 | Tai Chi | W: 0 | | W: 0
Zaichkowsky LD, 1978^191^ | College/university students | 12 wk | NR | R: 48 | Single | R: 14 | TM^®^ | R: 7 | MSK (EMG frontalis) | RR, TM^®^, and BF resulted in significant decreases in frontalis muscle tension
United States | Physiological | NR | F = 0 | C: 48 | | C: 14 | | C: 7
| Musculoskeletal | | M = 0 | W: 0 | RR | W: 0 | | W: 0
| | | | | | | BF | R: 14
| | | | | | | | C: 14
| | | | | | | | W: 0
| | | | | | | PMR | R: 13
| | | | | | | | C: 13
| | | | | | | | W: 0

® 5-HIAA = 5-hyroxyindol acetic acid; ACF = adrenocortical functioning; ATN = attention; BDT = bone density test; BF = biofeedback; BP = blood pressure; BGM = blood gas measurement; C = number completed; Ca = calcium; cAMP = cyclic adenosine monophosphate; CF = cognitive function; CHD = chronic heart disease; cIMT = carotid intima-media thickness; CM = carbohydrate; metabolism; CNS-H = central nervous system hormone; COG/N = cognitive/neuropsychological; Cr = creatinine; CVF = cardiovascular functioning; d = day(s); DIG = digestive; DHEAS = dehydroepiandrosterone; DPV = digital pulse volume; ECG = electrocardiography; EMG = electromyography; END = endocrine; EPI = epinephrine; FBS = fasting blood sugar; GH = growth hormone; GSR = galvanic skin response; Hb = hemoglobin; Hb- A1c = hemoglobin A1c; HDL = high density lipoprotein; HE = health education; HR = heart rate; K = potassium; LDL = low density lipoprotein; LIP = lipoproteins; Lt = left; MEM = memory; Mg = magnesium; mo = month(s); MSK = musculoskeletal; Na = sodium; NE = norepinephrine; NER = nervous; NIDDM = non-insulin-dependent diabetes mellitus; NR = not reported; NT = no treatment; OGTT = oral glucose tolerance test; PAA = peak aortic acceleration; PFT = pulmonary function test; PMR = progressive muscle relaxation; R = number randomized (for RCTs); RES = respiratory; RFT = renal function test; RR = Relaxation Response; RSG = reasoning; Rt = right; SA = spatial ability; SBP = systolic blood pressure; SCL = skin conductance level; se = session(s); TC = total cholesterol; TG = triglyceride; TM= Transcendental Meditation; TSH = thyroid stimulating hormone; UE = urinary excretory; UFNB = unilateral forced nostril breathing; VA = verbal ability; VLDL = very low density lipoprotein; VO_2_ = oxygen consumption; VO_2_ max = maximum oxygen consumption; W = number withdrawals/losses to followup; wk = week(s); WL = waiting list; yr = year(s); Zn = zinc

Table J2 Characteristics of nonrandomized controlled trials on the physiological and neuropsychological effects of meditation practices

Study, country | Condition | Duration/followup, ITT | Characteristics of study population | | Intervention | | Comparison groups | | Outcome category (measure) | Authors' conclusions
| Outcome examined | | Age (mean/range) Gender | N participants | Intervention type Meditation practice | N participants | Control | N participants
| System evaluated
Abrams AI, 1978^289^ | Prison inmates | 14 wk | Age NR | E: 115 | Single | E: 60 | WL | E: 55 | CVF (BP, HR) | TM^®^ reduced anxiety, neuroticism, hostility, and insomnia
United States | Physiological | No | F = 0 | C: 89 | | C: 49 | | C: 40
| Cardiovascular | | M = 89 | W: 26 | TM^®^ | W: 11 | | W: 15
Chen WW, 1997^290^ | Elderly | 16 wk | 50–74 yr | E: 36 | Single | E: 23 | NT | E: 13 | CVF (BP, HR), MSK (EMG) | Tai Chi can benefit health promotion and disease prevention for older adults
United States | Physiological | No | F = NR | C: 28 | | C: 18 | | C: 10
| Cardiovascular, musculoskeletal | | M = NR | W: 8 | Tai Chi | W: 5 | | W: 3
Cooper MJ, 1990^291^ | Healthy volunteers | 10 mo | 43 yr | E: 55 | Single | E: 34 | NT | E: 21 | CVF (BP), DIG (TC) | TM^®^ may have value as an adjunct treatment in reducing BP and cholesterol levels
Israel | Physiological | No | F = 19 | C: 44 | | C: 23 | | C: 21
| Cardiovascular, digestive | | M = 25 | W: 11 | TM^®^ | W: 11 | | W: 0
Cuthbert B, 1981^306b^ | College/university students | 3 se | Age NR | E: 60 | Single | E: 20 | BF | E: 20 | CVF (HR), MSK (EMG), NER (SRL), RES (Res-v) | Meditation leads to greater instructed heart rate slowing than does training that includes high-density biofeedback
United States | Physiological | NR | F= 0 | C: 60 | | C: 20 | | C: 20
| Cardiovascular, musculoskeletal, nervous, respiratory | | M=60 | W: 0 | RR | W: 0 | | W: 0
| | | | | | | Rest | E: 20
| | | | | | | | C: 20
| | | | | | | | W: 20
De Armond DL, 1996^292^ | Workers (Technology) | 3 mo | 43 yr | E: 76 | Single | E: 38 | NT | E: 38 | CVF (BP), DIG (TC) | TM^®^ has effects in psychology, behavior and physiology and is an effective stress-reduction intervention
United States | Physiological | NR | F= 17 | C: 75 | | C: 38 | | C: 37
| Cardiovascular, digestive | | M=58 | W: 1 | TM^®^ | W: 0 | | W: 1
Mohan SM, 2002^180^ | Healthy volunteers | 1 se | 19–24 yr. | E: 58 | Single | E: NR | Yoga | E: NR | CVF (PR) | UFNB may affect sympathetic tone
Malaysia | Physiological, cardiovascular | No | F= NR | C: NR | | C: NR | | C: NR
| | | M=NR | W: NR | UFNB (Lt) | W: NR | | W: NR
Sanders B, 1994^181^ | College/university students | NR | NR | E: 96 | Single | E: 32 | Yoga | E: 32 | COG/N (SA, VA) | UFNB did not significantly alter nostril dominance
United States | Neuropsychological | NR | F = 48 | C: 96 | | C: 32 | | C: 32
| Cognitive/neuropsychological | | M = 48 | W: 0 | UFNB (Lt) | W: 0 | | W: 0
| | | | | | | Rest | E: 32
| | | | | | | | C: 32
| | | | | | | | W: 0
Travis FT, 1990^293^ | College/university students | 5 mo | NR | E: 96 | Single | E: 46 | NT | E: 40 | COG/N (CTY) | Practicing TM^®^ for 5 mo had a significant effect on primary process creativity
United States | Neuropsychological | No | F = 37 | C: 71 | | C: 35 | | C: 36
| Cognitive/ Neuropsychological | | M = 34 | W: 25 | TM^®^ | W: 11 | | W: 4

® BF = biofeedback; BP = blood pressure; C = number completed; COG/N = cognitive/neuropsychological; CTY = creativity; CVF = cardiovascular functioning; DIG = digestive; E = number enrolled; EMG = electromyography; HR = heart rate; Lt = left; MSK = musculoskeletal; mo = month(s); NER = nervous; NR = not reported; NT = no treatment; PR = pulse rate; RES = respiratory; Res-v = respiratory variability; RR = Relaxation Response; SA = spatial ability; SRL = skin resistance level; TC = total cholesterol; TM = Transcendental Meditation; UFNB = unilateral forced nostril breathing; VA = verbal ability; W = number withdrawals/losses to followup; wk = week(s); yr = year(s)

Table J3 Characteristics of before-and-after studies on the physiological and neuropsychological effects of meditation practices

Study, country | Condition | Duration/followup | Characteristics of study population | | Intervention | Comparison groups | Outcome category (measure)
| Outcome examined | | Age (mean/range) Gender | N participants | Intervention type Meditation practice
| System evaluated
Agarwal BL, 1990^295^ | Hypertension | 6 mo | 49.9 yr | E: 24 | Single | CVF (BP) | TM^®^ may serve as initial treatment for moderate hypertension.
India | Physiological | | F= 4 | C: 16
| Cardiovascular | | M=12 | W: 8 | TM^®^
Anantharaman RN, 1984^310^ | Healthy volunteers | 3 mo | 34.2 yr | E: 20 | Composite | CVF (BP, HR), COG/N (CF, MEM), RES (BR) | Yoga practice significantly decreased physiological variables and improved some psychological variables
India | Physiological, neuropsychological | | F= 20 | C: 17
| Cardiovascular, cognitive/neuropsychological, respiratory | | M=0 | W: 3 | Yoga (asanas + pranayama)
Benson H, 1974^311^ | Hypertension | NR | Age NR | E: 22 | Single | CVF (BP) | TM^®^ reduced elevated systemic arterial BP
United States | Physiological | | F= NR | C: 22
| Cardiovascular | | M=NR | W: 0 | TM^®^
Bhargava R, 1988^312^ | Healthy volunteers | 4 wk | 19–28 yr | E: 10 | Single | CVF (BP, HR), NER (GSR), RES (BHT) | Pranayama breathing exercises altered autonomic responses to BH by increasing vagal tone and decreasing sympathetic discharges
India | Physiological | | F = 0 | C: 10
| Cardiovascular, nervous, respiratory | | M = 10 | W: 0 | Pranayama
Chen JC, 2004^297^ | College/university students | 1 se | 21.8 yr | E: 17 | Single | CVF (BP, HR), OCL (ophthalmologic test) | UFNB produced changes in intraocular pressure and had a greater effect on accomodation for those with high initial tonic activity
Australia | Physiological | | F = NR | C: 17
| Cardiovascular, ocular | | M = NR | W: 0 | UFNB
Damodaran A, 2002^294^ | Hypertension | 3 mo | 45.8 yr | E: 20 | Composite | CVF (BP, HR), COG/N (ATN, MEM, PER, SMF), NER (steadiness, coordination, choice RT, GSR, grip) RES (BR) | Yoga can play an important role in risk modification for CV diseases in mild to moderate hypertension
India | Physiological, neuropsychological | | F = 4 | C: 20
| Cardiovascular, cognitive/neuropsychological, nervous, respiratory | | M = 16 | W: 0 | Yoga (asanas + pranayama)
Jain SC, 1993^298^ | Type II DM | 40 d | 45.9 yr | E: 149 | Single | CM (FBS, OGTT) | Yoga may be considered as a beneficial adjuvant method for diabetic (NIDDM) patients
India | Physiological | | F = 30 | C: 149
| Endocrine | | M =119 | W: 0 | Yoga
Jones AY, 2005^296^ | Healthy volunteers | 12 wk | 52.6 yr | E: 60 | Single | CVF (BGM [SaO_2_, VCO_2_], BP, HR), RES (PFT [FEV_1_, FVC, PIFR, PEFR, PEF 25–50]) | A community-based Tai Chi program produced beneficial effects comparable to those reported from experimental laboratory trials of Tai Chi
Canada | Physiological | | F = 50 | C: 51
| Cardiovascular, respiratory | | M = 10 | W: 9 | Tai Chi
Jones BM, 2001^299^ | Healthy volunteers | 14 wk | 43.9 yr | E: 19 | Single | CVF (BP, HR), END (ACF [cortisol], IMS (HI [cytokines]) | Cortisol may be lowered by short-term practice of Qigong
Hong Kong | Physiological | | F = 11 | C: 10 | | | Concomitant changes in numbers of cytokine-secreting cells were observed
| Cardiovascular, endocrine, immune | | M = 8 | W: 9 | Qi Gong
Joseph S, 1981^313^ | Army/militar | 3 mo | 24.9 yr | E: 10 | Composite | BM (ChE, LDH), CVF (BP, HR, BGM [VO_2_]), DIG (TC, FFA, LIP) NER (CNS-H [dopamine-B hydroxylase]), END (CM [FBS]), N/M (MP [MAO], TP), RES (BR), THR (skin temperature) | A 3-mo Yoga program resulted in a gradual shift of the autonomic balance towards a relative parasympathetic dominance
India | Physiological | | F = 0 | C: 10
| Blood, cardiovascular, digestive, endocrine, nervous, nutrition/metabolism, respiratory, thermoregulatory | | M = 10 | W: 0 | Yoga (prayer + asanas + pranayama + meditation)
Joshi LN, 1992^314^ | College/university students | 6 wk | 18.5 yr | E: 75 | Single | RES (PFT [FEV_1_, FVC, BHt, MVV, PEFR, BR]) | Regular pranayama breathing improved pulmonary functions (FVC, MVV, PEFR), increased tolerance to CO_2_, and decreased BR
India | Physiological | | F = 42 | C: 75
| Respiratory | | M = 33 | W: 0 | Pranayama
Kocer I, 2002^315^ | College/university students | 3 se | 20.6 yr | E: 50 | Single | OCL (Intraocular pressure [Rt eye/Rt nostril, Rt eye/Lt nostril, Lt eye/Rt nostril, Lt eye/Lt nostril]) | UFNB decreased intraocular pressure especially in menperhaps due to increasing sympathetic nervous system activity
Turkey | Physiological | | F = 26 | C: 50
| Ocular | | M = 24 | W: 0 | UFNB
Lim YA, 1993^316^ | College/university students | 1 se | 20.5 yr | E: 10 | Single | CVF (HR, BGM [VO_2_, VCO_2_]), RES (PFT [TV, Ve, RER, BR]) | Qigong can can improve ventilatory efficiency of O_2_ uptake and CO_2_ production by 20%
United States | Physiological | | F = 5 | C: 10
| Cardiovascular, respiratory | | M = 5 | W: 0 | Qi Gong
Liu S, 1996^317^ | College/university students | 8 wk | 22.1 yr | E: 14 | Single | CVF (BP, HR, PPT), DIG (TC), CM (BS) | An 8-wk Tai Chi program can improve CV fitness, balance, flexibility, and stress control
United States | Physiological | | F = 8 | C: 14 | | | No effect on blood cholesterol and glucose levels was found
| Cardiovascular, digestive, endocrine | | M = 6 | W: 0 | Tai Chi
Madanmohan, 1992^300^ | College/university students | 12 wk | 18–21 yr | E: 27 | Single | COG/N (ATN), RES (MEP, MIP, BHT), SEN (auditory test) | A 12-wk yoga program resulted in a significant reduction in visual and auditory RT
India | Physiological | | F = 0 | C: 27 | | | Yoga increasd respiratory pressures, BHT, and hand grip strength
| Cognitive/neuropsychological, respiratory, sensory | | M = 27 | W: 0 | Yoga
Malathi A, 1989^318^ | Healthy volunteers | 6 wk | 30–45 yr | E: 83 | Composite | COG/N (SMF) | Either 1 hr or 6 wk of Yoga asanas significantly reduced visual and auditory reaction times
India | Neuropsychological | | F = 83 | C: 83
| Cognitive/neuropsychological | | M = 0 | W: 0 | Yoga (asanas + pranayama)
Manjunatha S, 2005^301^ | Healthy volunteers | 4 wk | 23.8 yr | E: 20 | Single | END (CM [SI, OGTT, FBS, insulin sensitivity, postprandial glucose test]) | Asanas can lead to increased sensitivity of pancreatic B cells to glucose signals
India | Physiological | | F = 3 | C: 20
| Endocrine | | M = 17 | W: 0 | Yoga (asanas)
Pollack AA, 1977^319^ | Hypertension | 6 mo | 40.5 yr | E: 20 | Single | CVF (BP, HR), UE (RA) | It is unlikely that TM^®^ contributes directly towards the lowering of BP
United States | Physiological | | F = 10 | C: 20 | | | The patients may experience a general feeling of well-being
| Cardiovascular, urinary/excretory | | M = 10 | W: 0 | TM^®^
Raju PS, 1986^320^ | Healthy volunteers | 3 mo | 23.7 yr | E: 12 | Composite | CVF (HR, BGM [PO_2_, SaO_2_, VO_2_ max]), N/M (BL, UL, blood pyruvate), RES (Ve) | After 90 d of Yoga, BL increased during phase I
India | Physiological | | F = 6 | C: 12 | | | Significant reduction of Ve and VO_2_ in males in phase I and II
| Cardiovascular, nutrition/metabolism, respiratory | | M = 6 | W: 0 | Yoga (asanas + pranayama) | | Females tolerate higher loads of exercise in phases I and II
Schmidt TFH, 1994^302^ | Healthy volunteers | 3 mo | 29.7 yr | E: 150 | Composite | BC (fibrinogen), CVF (BP, HR), DIG (LDL,VLDL, HDL, TG) | Yoga and meditation along with low-fat, low-salt vegetarian diet, smoking cessation resulted in a substantial reduction of cardiovascular risk in healthy volunteers
Sweden | Physiological | | F = 48 | C: 106
| Blood, cardiovascular, digestive | | M = 58 | W: 44 | Yoga + meditation + vegetarian diet
Singh S, 2004^321^ | Type II DM | 40 d | 30–60 yr | E: 24 | Composite | CVF (BP, HR, ECG), BGM [CM (FBS, OGTT, GLH]), RES (PFT [FEV_1_, FVC, PEFR, MVV]) | Yoga asanas and pranayama produced better glycemic control and stable autonomic functions in type II DM
India | Physiological | | F = NR | C: 24
| Cardiovascular, endocrine, respiratory | | M = NR | W: 0 | Yoga (asanas + pranayama)
Sung BH, 2002^322^ | Healthy volunteers | 1 se | 35 yr | E: 25 | Single | CVF (HR, BP, stroke volume, SVR, AEI [large/small]) | Yoga breathing has a favorable effect on small artery compliance resulting in lower BP
United States | Physiological | | F = NR | C: 25
| Cardiovascular | | M = NR | W: 0 | Yoga breathing
Telles S, 1993^323^ | Healthy volunteers | 3 mo | 34.7 yr | E: 40 | Composite | CVF (BP, HR), NER (GSR), RES (PFT [BR, FEV1, FVC, PEFR, BHT]) | 3 mo of Yoga produced significant improvement in general health (weight, BP reduction, and improved lung function)
India | Physiological | | F = 0 | C: 40
| Cardiovascular, nervous, respiratory | | M = 40 | W: 0 | Yoga (asanas + pranayama + mantra meditation + lectures)
Telles S, 1993^83^ | Healthy volunteers | 6 se | 34.1 yr | E: 18 | Single | CVF (HR, FPA), NER (GSR), RES (BR) | There is no single model of sympathetic activation to describe the physiological effects of a meditation technique
India | Physiological | | F = 0 | C: 18
| Cardiovascular, nervous, respiratory | | M = 18 | W: 0 | Yoga (Brahma-kumaris Raja)
Vijayalakshmi P, 2004^303^ | Hypertension | 4 wk | 50 yr | E: 13 | Composite | CVF (BP, HR, PP) | Yoga optimizes the sympathetic response to stressful stimuli (handgrip)
India | Physiological | | F = 0 | C: 13 | | | Yoga restores the autonomic regulatory reflex in hypertensive patients
| Cardiovascular | | M = 13 | W: 0 | Yoga (asanas + pranayama)

ACF = adrenocortical functioning; AEI = artery elasticity index; ATN = attention; BC = blood composition; BGM = blood gas measurement; BHT = breath holding time; BL = blood lactate; BM = blood measurement; BP = blood pressure; BR = breathing rate; BS = blood sugar; C = number completed; CF = cognitive function; ChE = cholinesterase; CM = carbohydrate; metabolism; COG/N = cognitive/neuropsychological; CV = cardiovascular; CVF = cardiovascular functioning; d = day(s); DIG = digestive; DM = diabetes mellitus; E = number enrolled; ECG = electrocardiography; END = endocrine; FBS = fasting blood sugar; FEV1 = forced expiratory volume in first second; FFA = free fatty acid; FPA = finger plethysmogram amplitude; FVC = forced vital capacity; Glc = glucose; GLH = glycosylated hemoglobin; GSR = galvanic skin response; HDL = high density lipoprotein; HI = humoral immunity; HR = heart rate; IMS = immune system; LDH = lactate dehydrogenase; LDL = low density lipoprotein; LIP = lipoproteins; Lt = left; MEM = memory; MEP = maximum expiratory pressure; MIP = maximum inspiratory pressure; mo = month(s); MVV = maximal voluntary ventilation; NIDDM = non-insulin-dependent diabetes mellitus; NER = nervous; N/M = nutrition/metabolism; NR = not reported; OCL = ocular; OGTT = oral glucose tolerance test; PEF (25–75) = peak expiratory flow at middle portion of expiration; PEFR = peak expiratory flow rate; PER = perception; PFT = pulmonary function test; PIFR = peak inspiratory flow rate; PO_2_ = pressure of oxygen; PP = pulse pressure; PPT = physical performance test; RA = renin activity; RER = respiratory exchange ratio; RES = respiratory; RT = reaction time; Rt = right; SaO_2_ = saturated oxygen; SBPse = session(s); SEN = sensory; SI = serum insulin; SMF = sensory motor function; SVR = systemic vascular resistance; TC = total cholesterol; TG = triglyceride; THR = thermo-regulatory; TM^®^ = Transcendental Meditation^®^; TP = total protein; TV = tidal volume; UE = urinary excretory; UFNB = unilateral forced nostril breathing; UL = urine lactate; VCO_2_ = carbon dioxide production; Ve = minute ventilation; VLDL = very low density lipoprotein; VO_2_ = oxygen consumption; VO_2_ max = maximum oxygen consumption; yr = year(s); W = number withdrawals/losses to followup; wk = week(s)