# Appendix A. Technical Experts and Peer Reviewers

## Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Name | Institution
John Astin, Ph.D. | California Pacific Medical Center, San Francisco, CA, United States
Ruth Baer, Ph.D. | University of Kentucky, Lexington, KT, United States
Vernon Barnes, Ph.D. | Medical College of Georgia, Augusta, GA, United States
Linda Carlson, Ph.D, C.Psych. | University of Calgary, Calgary, AB, Canada
Jeffery Dusek, Ph.D. | Harvard Medical School, Boston, MA, United States
Thierry Lacaze-Masmonteil, M.D., Ph.D., F.R.C.P.C. | University of Alberta, Edmonton, AB, Canada
Badri Rickhi, M.D., Ph.D. | Canadian Institute of Natural and Integrative Medicine (CINIM), Calgary, AB, Canada
David Shannahoff-Khalsa, B.A. | University of California at San Diego, San Diego, CA, United States

## Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

Name | Institution
Kirk Warren Brown, Ph.D. | Virginia Commonwealth University, Richmond, VA, United States
Bei-Hung Chang, Sc.D. | Boston University School of Public Health, Boston, MA, United States
Thawatchai Krisanaprakornkit, M.D. | Khon Kaen University, Khon Kaen, Thailand
T. M. Srinivasan, Ph.D. | The International Society for the Study of Subtle Energies and Energy Medicine, Madras (Chennai), India
Harald Walach, Ph.D. | The University of Northampton, Northampton, United Kingdom
Ken Walton, Ph.D. | Maharishi University of Management, Fairfield, IA, United States
Gloria Yeh, M.D., M.P.H. | Osher Institute at Harvard Medical School, Boston, MA, United States