# Appendixes

Appendix A. Technical Experts and Peer Reviewers

Appendix B. Development of Consensus on a Set of Criteria for an Operational Definition of Meditation

Appendix C. Exact Search Strings

Appendix D. Review Forms

Appendix E. Excluded Studies and Nonobtained Studies

Appendix F. References of Multiple Publications (Topics II to V)

Appendix G. Summary Tables for Topic II

Appendix H. Characteristics of Clinical Trials of Meditation Practices for the Three Most Studied Conditions

Appendix I. Characteristics of Studies Included in Topic V

Appendix J. Characteristics of Studies on the Physiological and Neuropsychological Effects of Meditation Practices