# References

1 Marshall LM, Spiegelman D, Barbieri RL, Goldman MB, Manson JE, Colditz GA, et al. Variation in the incidence of uterine leiomyoma among premenopausal women by age and race. Obstet Gynecol. 1997;90:967-73. [pmid: 9397113].
2 Baird DD, Dunson DB, Hill MC, Cousins D, Schectman JM. High cumulative incidence of uterine leiomyoma in black and white women: ultrasound evidence. Am J Obstet Gynecol. Jan. 2003;188(1):100-7. [pmid: 12548202].
3 Cramer SF, Horiszny JA, Leppert P. Epidemiology of uterine leiomyomas. With an etiologic hypothesis. J Reprod Med. Aug. 1995;40(8):595-600. [pmid: 7473458].
4 Schwartz SM, Marshall LM, Baird DD. Epidemiologic contributions to understanding the etiology of uterine leiomyomata. Environ Health Perspect. Oct. 2000;108(Suppl 5):821-7. [pmid: 11035989].
5 Vollenhoven B. Introduction: the epidemiology of uterine leiomyomas. Baillieres Clin Obstet Gynaecol. 1998;12:169-76. [pmid: 10023416].
6 Cramer SF, Patel A. The frequency of uterine leiomyomas. Am J Clin Pathol. 1990;94:435-8. [pmid: 2220671].
7 Romieu I, Walker AM, Jick S. Determinants of uterine fibroides. Postmarketing Surveillance. 1991;5:119-33.
8 Lumbiganon P, Rugpao S, Phandhu-fung S, Laopaiboon M, Vudhikamraksa N, Werawatakul Y. Protective effect of depot-medroxyprogesterone acetate on surgically treated uterine leiomyomas: a multicentre case-control study. Br J Obstet Gynaecol. 1996;103:909-14. [pmid: 8813312].
9 Parazzini F, Negri E, La Vecchia C, Chatenoud L, Ricci E, Guarnerio P. Reproductive factors and risk of uterine fibroids. Epidemiology. 1996;7:440-2. [pmid: 8793374].
10 Ross RK, Pike MC, Vessey MP, Bull D, Yeates D, Casagrande JT. Risk factors for uterine fibroids: reduced risk associated with oral contraceptives. Br Med J (Clin Res Ed). 1986;293:359-62.
11 Parazzini F, La Vecchia C, Negri E, Cecchetti G, Fedele L. Epidemiologic characteristics of women with uterine fibroids: a case-control study. Obstet Gynecol. 1988;72:853-7. [pmid: 3186092].
12 Samadi AR, Lee NC, Flanders WD, Boring JR 3rd, Parris EB. Risk factors for self-reported uterine fibroids: a case-control study. Am J Public Health. 1996;86:858-62. [pmid: 8659663]. [pmcid: 1380408].
13 Brett KM, Marsh JV, Madans JH. Epidemiology of hysterectomy in the United States: demographic and reproductive factors in a nationally representative sample. J Womens Health. 1997;6:309-16. [pmid: 9201665].
14 Marshall LM, Spiegelman D, Manson JE, Goldman MB, Barbieri RL, Stampfer MJ, et al. Risk of uterine leiomyomata among premenopausal women in relation to body size and cigarette smoking. Epidemiology. 1998;9:511-7. [pmid: 9730029].
15 Sato F, Miyake H, Nishi M, Kudo R. Fertility and uterine size among Asian women undergoing hysterectomy for leiomyomas. Int J Fertil Womens Med. Jan–Feb. 2000;45(1):34-7. [pmid: 10721742].
16 Chen CR, Buck GM, Courey NG, Perez KM, Wactawski-Wende J. Risk factors for uterine fibroids among women undergoing tubal sterilization. Am J Epidemiol. Jan 1. 2001;153(1):20-6. [pmid: 11159141].
17 Faerstein E, Szklo M, Rosenshein N. Risk factors for uterine leiomyoma: a practice-based case-control study. I. African-American heritage, reproductive history, body size, and smoking. Am J Epidemiol. Jan 1. 2001;153(1):1-10. [pmid: 11159139].
18 Fedele L, Parazzini F, Luchini L, Mezzopane R, Tozzi L, Villa L. Recurrence of fibroids after myomectomy: a transvaginal ultrasonographic study. Hum Reprod. 1995;10:1795-6. [pmid: 8582982].
19 Marshall LM, Spiegelman D, Goldman MB, Manson JE, Colditz GA, Barbieri RL, et al. A prospective study of reproductive factors and oral contraceptive use in relation to the risk of uterine leiomyomata. Fertil Steril. 1998;70:432-9. [pmid: 9757871].
20 Parazzini F, Negri E, La Vecchia C, Fedele L, Rabaiotti M, Luchini L. Oral contraceptive use and risk of uterine fibroids. Obstet Gynecol. 1992;79:430-3. [pmid: 1738528].
21 Faerstein E, Szklo M, Rosenshein NB. Risk factors for uterine leiomyoma: a practice-based case-control study. II. Atherogenic risk factors and potential sources of uterine irritation. Am J Epidemiol. Jan 1. 2001;153(1):11-9. [pmid: 11159140].
22 Baird DD, Schectman JM, Dixon D, Sandler DP, Hill MC. African Americans at higher risk than whites for uterine fibroids: ultrasound evidence. 1998;147:S90.
23 Ojeda VJ. The pathology of hysterectomy specimens. N Z Med J. 1979;89:169-71. [pmid: 287933].
24 Kjerulff KH, Langenberg P, Seidman JD, Stolley PD, Guzinski GM. Uterine leiomyomas. Racial differences in severity, symptoms and age at diagnosis. J Reprod Med. Jul. 1996;41(7):483-90. [pmid: 8829060].
25 Luoto R, Kaprio J, Rutanen EM, Taipale P, Perola M, Koskenvuo M. Heritability and risk factors of uterine fibroids—the Finnish Twin Cohort study. Maturitas. Nov 30. 2000;37(1):15-26. [pmid: 11099869].
26 Wise LA, Palmer JR, Spiegelman D, Harlow BL, Stewart EA, Adams-Campbell LL, et al. Influence of body size and body fat distribution on risk of uterine leiomyomata in U.S. black women. Epidemiology. May. 2005;16(3):346-54. [pmid: 15824551]. [pmcid: 1847589].
27 Baird DD, Dunson DB, Hill MC, Cousins D, Schectman JM. Association of physical activity with development of uterine leiomyoma. Am J Epidemiol. Jan 15. 2007;165(2):157-63. [pmid: 17090618].
28 Boynton-Jarrett R, Rich-Edwards J, Malspeis S, Missmer SA, Wright R. A prospective study of hypertension and risk of uterine leiomyomata. Am J Epidemiol. Apr 1. 2005;161(7):628-38. [pmid: 15781952].
29 Luoto R, Rutanen EM, Auvinen A. Fibroids and hypertension. A cross-sectional study of women undergoing hysterectomy. J Reprod Med. Apr. 2001;46(4):359-64. [pmid: 11354837].
30 Matchar DB, Myers ER, Barber MW, Couchman GM, Datta S, Gray RN, et al. Management of uterine fibroids. Evid Rep Technol Assess (Summ). 2001 Jan(34):1–6.
31 Wegienka G, Baird DD, Hertz-Picciotto I, Harlow SD, Steege JF, Hill MC, et al. Self-reported heavy bleeding associated with uterine leiomyomata. Obstet Gynecol. Mar. 2003;101(3):431-7. [pmid: 12636944].
32 Spies JB, Coyne K, Guaou Guaou N, Boyle D, Skyrnarz-Murphy K, Gonzalves SM. The UFS-QOL, a new disease-specific symptom and health-related quality of life questionnaire for leiomyomata. Obstet Gynecol. Feb. 2002;99(2):290-300. [pmid: 11814511].
33 Hartmann KE, Birnbaum H, Ben-Hamadi R, Wu EQ, Farrell MH, Spalding J, et al. Annual costs associated with diagnosis of uterine leiomyomata. Obstet Gynecol. 2006;108(4):930-7. [pmid: 17012456].
34 Becker ER, Spalding J, DuChane J, Horowitz IR. Inpatient surgical treatment patterns for patients with uterine fibroids in the United States, 1998-2002. J Natl Med Assoc. Oct. 2005;97(10):1336-42. [pmid: 16353655]. [pmcid: 2594714].
35 Schulz KF, Chalmers I, Grimes DA, Altman DG. Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals. Jama. Jul 13. 1994;272(2):125-8. [pmid: 8015122].
36 Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. Jama. Feb 1. 1995;273(5):408-12. [pmid: 7823387].
37 Sosa JL, Sleeman D, McKenney MG, Dygert J, Yarish D, Martin L. A comparison of laparoscopic and traditional appendectomy. J Laparoendosc Surg. Apr. 1993;3(2):129-31. [pmid: 8518464].
38 Martin LC, Puente I, Sosa JL, Bassin A, Breslaw R, McKenney MG, et al. Open versus laparoscopic appendectomy. A prospective randomized comparison. Ann Surg. Sep. 1995;222(3):256-61. discussion 61–2. [pmid: 7677456]. [pmcid: 1234801].
39 Fiscella K, Franks P, Gold MR, Clancy CM. Inequality in quality: addressing socioeconomic, racial, and ethnic disparities in health care. Jama. May 17. 2000;283(19):2579-84. [pmid: 10815125].
40 West S, King V, Carey TS, Lohr KN, McKoy N, Sutton SF, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ). 2002 Mar(47):1–11.
41 Wise LA, Palmer JR, Harlow BL, Spiegelman D, Stewart EA, Adams-Campbell LL, et al. Reproductive factors, hormonal contraception, and risk of uterine leiomyomata in African-American women: a prospective study. Am J Epidemiol. Jan 15. 2004;159(2):113-23. [pmid: 14718211]. [pmcid: 1847588].
42 Di Lieto A, De Falco M, Pollio F, Mansueto G, Salvatore G, Somma P, et al. Clinical response, vascular change, and angiogenesis in gonadotropin-releasing hormone analogue-treated women with uterine myomas. J Soc Gynecol Investig. Feb. 2005;12(2):123-8.
43 Di Lieto A, De Falco M, Staibano S, Iannotti F, Scaramellino M, Salvatore G, et al. Effects of gonadotropin-releasing hormone agonists on uterine volume and vasculature and on the immunohistochemical expression of basic fibroblast growth factor (bFGF) in uterine leiomyomas. Int J Gynecol Pathol. Oct. 2003;22(4):353-8. [pmid: 14501815].
44 Di Lieto A, De Rosa G, De Falco M, Iannotti F, Staibano S, Pollio F, et al. Relationship between platelet-derived growth factor expression in leiomyomas and uterine volume changes after gonadotropin-releasing hormone agonist treatment. Hum Pathol. Feb. 2002;33(2):220-4. [pmid: 11957148].
45 Di Lieto A, Iannotti F, De Falco M, Staibano S, Pollio F, Ciociola F, et al. Immunohistochemical detection of insulin-like growth factor type I receptor and uterine volume changes in gonadotropin-releasing hormone analog-treated uterine leiomyomas. Am J Obstet Gynecol. Mar. 2003;188(3):702-6. [pmid: 12634644].
46 Donnez J, Hervais Vivancos B, Kudela M, Audebert A, Jadoul P. A randomized, placebo-controlled, dose-ranging trial comparing fulvestrant with goserelin in premenopausal patients with uterine fibroids awaiting hysterectomy. Fertil Steril. Jun. 2003;79(6):1380-9. [pmid: 12798886].
47 Dousias V, Paraskevaidis E, Dalkalitsis N, Tsanadis G, Navrozoglou I, Lolis D. Recombinant human erythropoietin in mildly anemic women before total hysterectomy. Clin Exp Obstet Gynecol. 2003;30(4):235-8. [pmid: 14664421].
48 Mehl-Madrona L. Complementary medicine treatment of uterine fibroids: a pilot study. Altern Ther Health Med. 2002 Mar-Apr;8(2):34–6, 8–40, 2, 4–6.
49 Palomba S, Morelli M, Di Carlo C, Noia R, Pellicano M, Zullo F. Bone metabolism in postmenopausal women who were treated with a gonadotropin-releasing hormone agonist and tibolone. Fertil Steril. Jul. 2002;78(1):63-8. [pmid: 12095492].
50 Palomba S, Orio F Jr, Russo T, Falbo A, Tolino A, Lombardi G, et al. Antiproliferative and proapoptotic effects of raloxifene on uterine leiomyomas in postmenopausal women. Fertil Steril. Jul. 2005;84(1):154-61. [pmid: 16009171].
51 Palomba S, Orio F Jr, Morelli M, Russo T, Pellicano M, Nappi C, et al. Raloxifene administration in women treated with gonadotropin-releasing hormone agonist for uterine leiomyomas: effects on bone metabolism. J Clin Endocrinol Metab. Oct. 2002;87(10):4476-81. [pmid: 12364422].
52 Palomba S, Russo T, Orio F Jr, Tauchmanova L, Zupi E, Panici PL, et al. Effectiveness of combined GnRH analogue plus raloxifene administration in the treatment of uterine leiomyomas: a prospective, randomized, single-blind, placebo-controlled clinical trial. Hum Reprod. Dec. 2002;17(12):3213-9. [pmid: 12456626].
53 Palomba S, Orio F Jr, Russo T, Falbo A, Cascella T, Doldo P, et al. Long-term effectiveness and safety of GnRH agonist plus raloxifene administration in women with uterine leiomyomas. Hum Reprod. Jun. 2004;19(6):1308-14. [pmid: 15117890].
54 Palomba S, Russo T, Orio F Jr, Sammartino A, Sbano FM, Nappi C, et al. Lipid, glucose and homocysteine metabolism in women treated with a GnRH agonist with or without raloxifene. Hum Reprod. Feb. 2004;19(2):415-21. [pmid: 14747190].
55 Palomba S, Pellicano M, Affinito P, Di Carlo C, Zullo F, Nappi C. Effectiveness of short-term administration of tibolone plus gonadotropin-releasing hormone analogue on the surgical outcome of laparoscopic myomectomy. Fertil Steril. Feb. 2001;75(2):429-33. [pmid: 11172852].
56 Palomba S, Sammartino A, Di Carlo C, Affinito P, Zullo F, Nappi C. Effects of raloxifene treatment on uterine leiomyomas in postmenopausal women. Fertil Steril. Jul. 2001;76(1):38-43. [pmid: 11438317].
57 Palomba S, Sena T, Morelli M, Noia R, Zullo F, Mastrantonio P. Effect of different doses of progestin on uterine leiomyomas in postmenopausal women. Eur J Obstet Gynecol Reprod Biol. May 10. 2002;102(2):199-201. [pmid: 11950491].
58 Palomba S, Sena T, Noia R, Di Carlo C, Zullo F, Mastrantonio P. Transdermal hormone replacement therapy in postmenopausal women with uterine leiomyomas. Obstet Gynecol. Dec. 2001;98(6):1053-8. [pmid: 11755553].
59 Palomba S, Morelli M, Noia R, Santagata M, Oliverio A, Sena T, et al. Short-term administration of tibolone plus GnRH analog before laparoscopic myomectomy. J Am Assoc Gynecol Laparosc. May. 2002;9(2):170-4. [pmid: 11960042].
60 Somekawa Y, Chiguchi M, Ishibashi T, Wakana K, Aso T. Efficacy of ipriflavone in preventing adverse effects of leuprolide. J Clin Endocrinol Metab. Jul. 2001;86(7):3202-6. [pmid: 11443189].
61 Di Lieto A, De Falco M, Mansueto G, De Rosa G, Pollio F, Staibano S. Preoperative administration of GnRH-a plus tibolone to premenopausal women with uterine fibroids: evaluation of the clinical response, the immunohistochemical expression of PDGF, bFGF and VEGF and the vascular pattern. Steroids. Feb. 2005;70(2):95-102. [pmid: 15631865].
62 Verspyck E, Marpeau L, Lucas C. Leuprorelin depot 3.75 mg versus lynestrenol in the preoperative treatment of symptomatic uterine myomas: a multicentre randomised trial. Eur J Obstet Gynecol Reprod Biol. Mar. 2000;89(1):7-13. [pmid: 10733017].
63 Seracchioli R, Venturoli S, Colombo FM, Bagnoli A, Vianello F, Govoni F, et al. GnRH agonist treatment before total laparoscopic hysterectomy for large uteri. J Am Assoc Gynecol Laparosc. Aug. 2003;10(3):316-9. [pmid: 14567804].
64 Vercellini P, Trespidi L, Zaina B, Vicentini S, Stellato G, Crosignani PG. Gonadotropin-releasing hormone agonist treatment before abdominal myomectomy: a controlled trial. Fertil Steril. Jun. 2003;79(6):1390-5. [pmid: 12798887].
65 Eisinger SH, Meldrum S, Fiscella K, le Roux HD, Guzick DS. Low-dose mifepristone for uterine leiomyomata. Obstet Gynecol. Feb. 2003;101(2):243-50. [pmid: 12576246].
66 Eisinger SH, Bonfiglio T, Fiscella K, Meldrum S, Guzick DS. Twelve-month safety and efficacy of low-dose mifepristone for uterine myomas. J Minim Invasive Gynecol. May–Jun. 2005;12(3):227-33. [pmid: 15922980].
67 Palomba S, Orio F Jr, Morelli M, Russo T, Pellicano M, Zupi E, et al. Raloxifene administration in premenopausal women with uterine leiomyomas: a pilot study. J Clin Endocrinol Metab. Aug. 2002;87(8):3603-8. [pmid: 12161482].
68 Campo S, Campo V, Gambadauro P. Short-term and long-term results of resectoscopic myomectomy with and without pretreatment with GnRH analogs in premenopausal women. Acta Obstet Gynecol Scand. Aug. 2005;84(8):756-60. [pmid: 16026401].
69 Litta P, Cosmi E, Nardelli GB. Laparoscopic myomectomy following GnRH therapy. Int J Gynaecol Obstet. Jan. 2005;88(1):63-4. [pmid: 15617712].
70 Broder MS, Goodwin S, Chen G, Tang LJ, Costantino MM, Nguyen MH, et al. Comparison of long-term outcomes of myomectomy and uterine artery embolization. Obstet Gynecol. Nov. 2002;100(5 Pt 1):864-8. [pmid: 12423842].
71 Chrisman HB, West D, Corpuz B, Ryu RK, Salem R, Carr J, et al. Primary failure of uterine artery embolization: use of magnetic resonance imaging to select patients for repeated embolization. J Vasc Interv Radiol. Aug. 2005;16(8):1143-7. [pmid: 16105928].
72 Chrisman HB, Liu DM, Bui JT, Resnick SA, Sato K, Chen R, et al. The safety and efficacy of a percutaneous closure device in patients undergoing uterine artery embolization. J Vasc Interv Radiol. Mar. 2005;16(3):347-50. quiz 51. [pmid: 15758130].
73 Goodwin SC, Bradley LD, Lipman JC, Stewart EA, Nosher JL, Sterling KM, et al. Uterine artery embolization versus myomectomy: a multicenter comparative study. Fertil Steril. Jan. 2006;85(1):14-21. [pmid: 16412720].
74 Hald K, Langebrekke A, Klow NE, Noreng HJ, Berge AB, Istre O. Laparoscopic occlusion of uterine vessels for the treatment of symptomatic fibroids: Initial experience and comparison to uterine artery embolization. Am J Obstet Gynecol. Jan. 2004;190(1):37-43. [pmid: 14749632].
75 Healey S, Buzaglo K, Seti L, Valenti D, Tulandi T. Ovarian function after uterine artery embolization and hysterectomy. J Am Assoc Gynecol Laparosc. Aug. 2004;11(3):348-52. [pmid: 15559347].
76 Hehenkamp WJ, Volkers NA, Donderwinkel PF, de Blok S, Birnie E, Ankum WM, et al. Uterine artery embolization versus hysterectomy in the treatment of symptomatic uterine fibroids (EMMY trial): peri- and postprocedural results from a randomized controlled trial. Am J Obstet Gynecol. Nov. 2005;193(5):1618-29. [pmid: 16260201].
77 Huang JY, Kafy S, Dugas A, Valenti D, Tulandi T. Failure of uterine fibroid embolization. Fertil Steril. Jan. 2006;85(1):30-5. [pmid: 16412722].
78 Katsumori T, Nakajima K, Mihara T. Is a large fibroid a high-risk factor for uterine artery embolization?. AJR Am J Roentgenol. Nov. 2003;181(5):1309-14. [pmid: 14573425].
79 Lohle PN, Boekkooi FP, Smeets AJ, Pieters JJ, Vervest HA, Lampmann LE, et al. Limited uterine artery embolization for leiomyomas with tris-acryl gelatin microspheres: 1-year follow-up. J Vasc Interv Radiol. Feb. 2006;17(2 Pt 1):283-7. [pmid: 16517773].
80 McLucas B, Adler L, Perrella R. Uterine fibroid embolization: nonsurgical treatment for symptomatic fibroids. J Am Coll Surg. Jan. 2001;192(1):95-105. [pmid: 11192931].
81 McLucas B, Perrella R, Goodwin S, Adler L, Dalrymple J. Role of uterine artery Doppler flow in fibroid embolization. J Ultrasound Med. Feb. 2002;21(2):113-20. quiz 22–3. [pmid: 11833866].
82 Myers ER, Goodwin S, Landow W, Mauro M, Peterson E, Pron G, et al. Prospective data collection of a new procedure by a specialty society: the FIBROID registry. Obstet Gynecol. Jul. 2005;106(1):44-51. [pmid: 15994616].
83 Pron G, Bennett J, Common A, Sniderman K, Asch M, Bell S, et al. Technical results and effects of operator experience on uterine artery embolization for fibroids: the Ontario Uterine Fibroid Embolization Trial. J Vasc Interv Radiol. May. 2003;14(5):545-54. [pmid: 12761307].
84 Pron G, Bennett J, Common A, Wall J, Asch M, Sniderman K. The Ontario Uterine Fibroid Embolization Trial. Part 2. Uterine fibroid reduction and symptom relief after uterine artery embolization for fibroids. Fertil Steril. Jan. 2003;79(1):120-7. [pmid: 12524074].
85 Pron G, Cohen M, Soucie J, Garvin G, Vanderburgh L, Bell S. The Ontario Uterine Fibroid Embolization Trial. Part 1. Baseline patient characteristics, fibroid burden, and impact on life. Fertil Steril. Jan. 2003;79(1):112-9. [pmid: 12524073].
86 Pron G, Mocarski E, Bennett J, Vilos G, Common A, Zaidi M, et al. Tolerance, hospital stay, and recovery after uterine artery embolization for fibroids: the Ontario Uterine Fibroid Embolization Trial. J Vasc Interv Radiol. Oct. 2003;14(10):1243-50. [pmid: 14551270].
87 Pron G, Mocarski E, Cohen M, Colgan T, Bennett J, Common A, et al. Hysterectomy for complications after uterine artery embolization for leiomyoma: results of a Canadian multicenter clinical trial. J Am Assoc Gynecol Laparosc. Feb. 2003;10(1):99-106. [pmid: 12555002].
88 Rajan DK, Beecroft JR, Clark TW, Asch MR, Simons ME, Kachura JR, et al. Risk of intrauterine infectious complications after uterine artery embolization. J Vasc Interv Radiol. Dec. 2004;15(12):1415-21. [pmid: 15590799].
89 Rasuli P, Jolly EE, Hammond I, French GJ, Preston R, Goulet S, et al. Superior hypogastric nerve block for pain control in outpatient uterine artery embolization. J Vasc Interv Radiol. Dec. 2004;15(12):1423-9. [pmid: 15590800].
90 Razavi MK, Hwang G, Jahed A, Modanloo S, Chen B. Abdominal myomectomy versus uterine fibroid embolization in the treatment of symptomatic uterine leiomyomas. AJR Am J Roentgenol. Jun. 2003;180(6):1571-5. [pmid: 12760922].
91 Ryu RK, Omary RA, Sichlau MJ, Siddiqi A, Chrisman HB, Nemcek AA Jr, et al. Comparison of pain after uterine artery embolization using tris-acryl gelatin microspheres versus polyvinyl alcohol particles. Cardiovasc Intervent Radiol. Jul–Aug. 2003;26(4):375-8. [pmid: 14667120].
92 Spies JB, Ascher SA, Roth AR, Kim J, Levy EB, Gomez-Jorge J. Uterine artery embolization for leiomyomata. Obstet Gynecol. Jul. 2001;98(1):29-34. [pmid: 11430952].
93 Spies JB, Bruno J, Czeyda-Pommersheim F, Magee ST, Ascher SA, Jha RC. Long-term outcome of uterine artery embolization of leiomyomata. Obstet Gynecol. Nov. 2005;106(5 Pt 1):933-9. [pmid: 16260509].
94 Spies JB, Cooper JM, Worthington-Kirsch R, Lipman JC, Mills BB, Benenati JF. Outcome of uterine embolization and hysterectomy for leiomyomas: results of a multicenter study. Am J Obstet Gynecol. Jul. 2004;191(1):22-31. [pmid: 15295340].
95 Spies JB, Myers ER, Worthington-Kirsch R, Mulgund J, Goodwin S, Mauro M. The FIBROID Registry: symptom and quality-of-life status 1 year after therapy. Obstet Gynecol. Dec. 2005;106(6):1309-18. [pmid: 16319257].
96 Spies JB, Roth AR, Jha RC, Gomez-Jorge J, Levy EB, Chang TC, et al. Leiomyomata treated with uterine artery embolization: factors associated with successful symptom and imaging outcome. Radiology. Jan. 2002;222(1):45-52. [pmid: 11756703].
97 Spies JB, Spector A, Roth AR, Baker CM, Mauro L, Murphy-Skrynarz K. Complications after uterine artery embolization for leiomyomas. Obstet Gynecol. Nov. 2002;100(5 Pt 1):873-80. [pmid: 12423844].
98 Walker WJ, Pelage JP. Uterine artery embolisation for symptomatic fibroids: clinical results in 400 women with imaging follow up. Bjog. Nov. 2002;109(11):1262-72. [pmid: 12452465].
99 Watson GM, Walker WJ. Uterine artery embolisation for the treatment of symptomatic fibroids in 114 women: reduction in size of the fibroids and women's views of the success of the treatment. Bjog. Feb. 2002;109(2):129-35. [pmid: 11905428].
100 Worthington-Kirsch R, Spies JB, Myers ER, Mulgund J, Mauro M, Pron G, et al. The Fibroid Registry for outcomes data (FIBROID) for uterine embolization: short-term outcomes. Obstet Gynecol. Jul. 2005;106(1):52-9. [pmid: 15994617].
101 Wagner SC, Gonsalves CF, Eschelman DJ, Sullivan KL, Bonn J. Complications of a percutaneous suture-mediated closure device versus manual compression for arteriotomoy closure: a case-controlled study. J Vasc Interv Radiol. 2003;14:735-41. [pmid: 12817040].
102 Loffer FD. Improving results of hysteroscopic submucosal myomectomy for menorrhagia by concomitant endometrial ablation. J Minim Invasive Gynecol. May–Jun. 2005;12(3):254-60. [pmid: 15922984].
103 Stewart EA, Rabinovici J, Tempany CM, Inbar Y, Regan L, Gostout B, et al. Clinical outcomes of focused ultrasound surgery for the treatment of uterine fibroids. Fertil Steril. Jan. 2006;85(1):22-9. [pmid: 16412721].
104 Hindley J, Gedroyc WM, Regan L, Stewart E, Tempany C, Hynyen K, et al. MRI guidance of focused ultrasound therapy of uterine fibroids: early results. AJR Am J Roentgenol. Dec. 2004;183(6):1713-9. [pmid: 15547216].
105 Tempany CM, Stewart EA, McDannold N, Quade BJ, Jolesz FA, Hynynen K. MR imaging-guided focused ultrasound surgery of uterine leiomyomas: a feasibility study. Radiology. Mar. 2003;226(3):897-905. [pmid: 12616023].
106 Stewart EA, Gedroyc WM, Tempany CM, Quade BJ, Inbar Y, Ehrenstein T, et al. Focused ultrasound treatment of uterine fibroid tumors: safety and feasibility of a noninvasive thermoablative technique. Am J Obstet Gynecol. Jul. 2003;189(1):48-54. [pmid: 12861137].
107 U.S. Food and Drug Administration (US FDA). FDA Approves New Device to Treat Uterine Fibroids. 2004 [cited 4/4/07]; Available from: http://www.fda.gov/bbs/topics/ANSWERS/2004/ANS01319.html
108 Agostini A, Cravello L, Bretelle F, Shojai R, Roger V, Blanc B. Risk of uterine perforation during hysteroscopic surgery. J Am Assoc Gynecol Laparosc. Aug. 2002;9(3):264-7. [pmid: 12101319].
109 Agostini A, Cravello L, Shojai R, Ronda I, Roger V, Blanc B. Postoperative infection and surgical hysteroscopy. Fertil Steril. Apr. 2002;77(4):766-8. [pmid: 11937131].
110 Agostini A, Cravello L, Desbriere R, Maisonneuve AS, Roger V, Blanc B. Hemorrhage risk during operative hysteroscopy. Acta Obstet Gynecol Scand. Sep. 2002;81(9):878-81. [pmid: 12225306].
111 Boe Engelsen I, Woie K, Hordnes K. Transcervical endometrial resection: long-term results of 390 procedures. Acta Obstet Gynecol Scand. 2006;85(1):82-7. [pmid: 16521686].
112 Bulletti C, D DEZ, Levi Setti P, Cicinelli E, Polli V, Stefanetti M. Myomas, pregnancy outcome, and in vitro fertilization. Ann N Y Acad Sci. Dec. 2004;1034:84-92. [pmid: 15731301].
113 Cagnacci A, Pirillo D, Malmusi S, Arangino S, Alessandrini C, Volpe A. Early outcome of myomectomy by laparotomy, minilaparotomy and laparoscopically assisted minilaparotomy. A randomized prospective study. Hum Reprod. Dec. 2003;18(12):2590-4. [pmid: 14645175].
114 Cobellis L, Pecori E, Cobellis G. Hemostatic technique for myomectomy during cesarean section. Int J Gynaecol Obstet. Dec. 2002;79(3):261-2. [pmid: 12445997].
115 Damiani A, Melgrati L, Marziali M, Sesti F. Gasless laparoscopic myomectomy. Indications, surgical technique and advantages of a new procedure for removing uterine leiomyomas. J Reprod Med. Oct. 2003;48(10):792-8. [pmid: 14619647].
116 Dessolle L, Soriano D, Poncelet C, Benifla JL, Madelenat P, Darai E. Determinants of pregnancy rate and obstetric outcome after laparoscopic myomectomy for infertility. Fertil Steril. Aug. 2001;76(2):370-4. [pmid: 11476788].
117 Di Gregorio A, Maccario S, Raspollini M. The role of laparoscopic myomectomy in women of reproductive age. Reprod Biomed Online. 2002;4(Suppl 3):55-8. [pmid: 12470567].
118 Doridot V, Dubuisson JB, Chapron C, Fauconnier A, Babaki-Fard K. Recurrence of leiomyomata after laparoscopic myomectomy. J Am Assoc Gynecol Laparosc. Nov. 2001;8(4):495-500. [pmid: 11677326].
119 Dubuisson JB, Fauconnier A, Fourchotte V, Babaki-Fard K, Coste J, Chapron C. Laparoscopic myomectomy: predicting the risk of conversion to an open procedure. Hum Reprod. Aug. 2001;16(8):1726-31. [pmid: 11473973].
120 Elliot AP, Heazell AE, Judge JK, Downey GP. An evaluation of the use of an intra-operative uterine tourniquet during multiple myomectomy: does this reduce blood loss and the need for blood transfusion?. J Obstet Gynaecol. May. 2005;25(4):382-3. [pmid: 16091326].
121 Fanfani F, Fagotti A, Bifulco G, Ercoli A, Malzoni M, Scambia G. A prospective study of laparoscopy versus minilaparotomy in the treatment of uterine myomas. J Minim Invasive Gynecol. Nov–Dec. 2005;12(6):470-4. [pmid: 16337572].
122 Glasser MH. Minilaparotomy myomectomy: a minimally invasive alternative for the large fibroid uterus. J Minim Invasive Gynecol. May–Jun. 2005;12(3):275-83. [pmid: 15922987].
123 Hanafi M. Predictors of leiomyoma recurrence after myomectomy. Obstet Gynecol. Apr. 2005;105(4):877-81. [pmid: 15802421].
124 Istre O, Langebrekke A. Repeat hysteroscopic surgery reduces the hysterectomy rate after endometrial and myoma resection. J Am Assoc Gynecol Laparosc. May. 2003;10(2):247-51. [pmid: 12732779].
125 Landi S, Zaccoletti R, Ferrari L, Minelli L. Laparoscopic myomectomy: technique, complications, and ultrasound scan evaluations. J Am Assoc Gynecol Laparosc. May. 2001;8(2):231-40. [pmid: 11342730].
126 Landi S, Fiaccavento A, Zaccoletti R, Barbieri F, Syed R, Minelli L. Pregnancy outcomes and deliveries after laparoscopic myomectomy. J Am Assoc Gynecol Laparosc. May. 2003;10(2):177-81. [pmid: 12732768].
127 Malzoni M, Rotond M, Perone C, Labriola D, Ammaturo F, Izzo A, et al. Fertility after laparoscopic myomectomy of large uterine myomas: operative technique and preliminary results. Eur J Gynaecol Oncol. 2003;24(1):79-82. [pmid: 12691325].
128 Marret H, Chevillot M, Giraudeau B. A retrospective multicentre study comparing myomectomy by laparoscopy and laparotomy in current surgical practice. What are the best patient selection criteria?. Eur J Obstet Gynecol Reprod Biol. Nov 10. 2004;117(1):82-6. [pmid: 15474250].
129 Marret H, Chevillot M, Giraudeau B. Factors influencing laparoconversions during the learning curve of laparoscopic myomectomy. Acta Obstet Gynecol Scand. 2006;85(3):324-9. [pmid: 16553181].
130 Marziani R, Mossa B, Ebano V, Perniola G, Melluso J, Napolitano C. Transcervical hysteroscopic myomectomy: long-term effects on abnormal uterine bleeding. Clin Exp Obstet Gynecol. 2005;32(1):23-6. [pmid: 15864931].
131 Mettler L, Audebert A, Lehmann-Willenbrock E, Schive-Peterhansl K, Jacobs VR. A randomized, prospective, controlled, multicenter clinical trial of a sprayable, site-specific adhesion barrier system in patients undergoing myomectomy. Fertil Steril. Aug. 2004;82(2):398-404. [pmid: 15302290].
132 Munoz JL, Jimenez JS, Hernandez C, Vaquero G, Perez Sagaseta C, Noguero R, et al. Hysteroscopic myomectomy: our experience and review. Jsls. Jan–Mar. 2003;7(1):39-48. [pmid: 12722997].
133 Olufowobi O, Sharif K, Papaionnou S, Neelakantan D, Mohammed H, Afnan M. Are the anticipated benefits of myomectomy achieved in women of reproductive age? A 5-year review of the results at a UK tertiary hospital. J Obstet Gynaecol. Jun. 2004;24(4):434-40. [pmid: 15203587].
134 Ou CS, Harper A, Liu YH, Rowbotham R. Laparoscopic myomectomy technique. Use of colpotomy and the harmonic scalpel. J Reprod Med. Oct. 2002;47(10):849-53. [pmid: 12418070].
135 Rossetti A, Sizzi O, Soranna L, Cucinelli F, Mancuso S, Lanzone A. Long-term results of laparoscopic myomectomy: recurrence rate in comparison with abdominal myomectomy. Hum Reprod. Apr. 2001;16(4):770-4. [pmid: 11278231].
136 Roth TM, Gustilo-Ashby T, Barber MD, Myers ER. Effects of race and clinical factors on short-term outcomes of abdominal myomectomy. Obstet Gynecol. May. 2003;101(5 Pt 1):881-4. [pmid: 12738144].
137 Seracchioli R, Rossi S, Govoni F, Rossi E, Venturoli S, Bulletti C, et al. Fertility and obstetric outcome after laparoscopic myomectomy of large myomata: a randomized comparison with abdominal myomectomy. Hum Reprod. Dec. 2000;15(12):2663-8. [pmid: 11098042].
138 Silva BA, Falcone T, Bradley L, Goldberg JM, Mascha E, Lindsey R, et al. Case-control study of laparoscopic versus abdominal myomectomy. J Laparoendosc Adv Surg Tech A. Aug. 2000;10(4):191-7. [pmid: 10997841].
139 Soriano D, Dessolle L, Poncelet C, Benifla JL, Madelenat P, Darai E. Pregnancy outcome after laparoscopic and laparoconverted myomectomy. Eur J Obstet Gynecol Reprod Biol. Jun 10. 2003;108(2):194-8. [pmid: 12781410].
140 Subramanian S, Clark MA, Isaacson K. Outcome and resource use associated with myomectomy. Obstet Gynecol. Oct. 2001;98(4):583-7. [pmid: 11576571].
141 Surrey ES, Minjarez DA, Stevens JM, Schoolcraft WB. Effect of myomectomy on the outcome of assisted reproductive technologies. Fertil Steril. May. 2005;83(5):1473-9. [pmid: 15866587].
142 Takeuchi H, Kitade M, Kikuchi I, Shimanuki H, Kumakiri J, Kinoshita K. Adhesion-prevention effects of fibrin sealants after laparoscopic myomectomy as determined by second-look laparoscopy: a prospective, randomized, controlled study. J Reprod Med. Aug. 2005;50(8):571-7. [pmid: 16220761].
143 Tsuji S, Takahashi K, Yomo H, Fujiwara M, Kita N, Takebayashi K, et al. Effectiveness of antiadhesion barriers in preventing adhesion after myomectomy in patients with uterine leiomyoma. Eur J Obstet Gynecol Reprod Biol. Dec 1. 2005;123(2):244-8. [pmid: 15950364].
144 Vavilis D, Togaridou E, Agorastos T. Abdominal myomectomy and febrile morbidity. Int J Gynaecol Obstet. Jan. 2005;88(1):61-2. [pmid: 15617711].
145 Zullo F, Palomba S, Corea D, Pellicano M, Russo T, Falbo A, et al. Bupivacaine plus epinephrine for laparoscopic myomectomy: a randomized placebo-controlled trial. Obstet Gynecol. Aug. 2004;104(2):243-9. [pmid: 15291994].
146 Benassi L, Lopopolo G, Pazzoni F, Ricci L, Kaihura C, Piazza F, et al. Chemically assisted dissection of tissues: an interesting support in abdominal myomectomy. J Am Coll Surg. Jul. 2000;191(1):65-9. [pmid: 10898185].
147 Kumakiri J, Takeuchi H, Kitade M, Kikuchi I, Shimanuki H, Itoh S, et al. Pregnancy and delivery after laparoscopic myomectomy. J Minim Invasive Gynecol. May–Jun. 2005;12(3):241-6. [pmid: 15922982].
148 Agostini A, Ronda I, Franchi F, Bretelle F, Roger V, Cravello L, et al. Oxytocin during myomectomy: a randomized study. Eur J Obstet Gynecol Reprod Biol. Feb 1. 2005;118(2):235-8. [pmid: 15653210].
149 Dubuisson JB. Management of leiomyomata. Hum Reprod Update. Nov–Dec. 2000;6(6):587. [pmid: 11129691].
150 Seinera P, Farina C, Todros T. Laparoscopic myomectomy and subsequent pregnancy: results in 54 patients. Hum Reprod. Sep. 2000;15(9):1993-6. [pmid: 10967002].
151 Dubuisson JB, Fauconnier A, Deffarges JV, Norgaard C, Kreiker G, Chapron C. Pregnancy outcome and deliveries following laparoscopic myomectomy. Hum Reprod. Apr. 2000;15(4):869-73. [pmid: 10739835].
152 Casini ML, Rossi F, Agostini R, Unfer V. Effects of the position of fibroids on fertility. Gynecol Endocrinol. Feb. 2006;22(2):106-9. [pmid: 16603437].
153 Eskandar MA, Vilos GA, Aletebi FA, Tummon IS. Hysteroscopic endometrial ablation is an effective alternative to hysterectomy in women with menorrhagia and large uteri. J Am Assoc Gynecol Laparosc. Aug. 2000;7(3):339-45. [pmid: 10924627].
154 Loffer FD. Hysteroscopic myomectomy in postmenopausal women. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):323-5. [pmid: 16036191].
155 Benassi L, Rossi T, Kaihura CT, Ricci L, Bedocchi L, Galanti B, et al. Abdominal or vaginal hysterectomy for enlarged uteri: a randomized clinical trial. Am J Obstet Gynecol. Dec. 2002;187(6):1561-5. [pmid: 12501064].
156 Darai E, Soriano D, Kimata P, Laplace C, Lecuru F. Vaginal hysterectomy for enlarged uteri, with or without laparoscopic assistance: randomized study. Obstet Gynecol. May. 2001;97(5 Pt 1):712-6. [pmid: 11339921].
157 Soriano D, Goldstein A, Lecuru F, Darai E. Recovery from vaginal hysterectomy compared with laparoscopy-assisted vaginal hysterectomy: a prospective, randomized, multicenter study. Acta Obstet Gynecol Scand. Apr. 2001;80(4):337-41. [pmid: 11264609].
158 Dessole S, Rubattu G, Capobianco G, Caredda S, Cherchi PL. Utility of bipolar electrocautery scissors for abdominal hysterectomy. Am J Obstet Gynecol. Aug. 2000;183(2):396-9. [pmid: 10942476].
159 Falkeborn M, Schairer C, Naessen T, Persson I. Risk of myocardial infarction after oophorectomy and hysterectomy. J Clin Epidemiol. Aug. 2000;53(8):832-7. [pmid: 10942866].
160 Ferrari MM, Berlanda N, Mezzopane R, Ragusa G, Cavallo M, Pardi G. Identifying the indications for laparoscopically assisted vaginal hysterectomy: a prospective, randomised comparison with abdominal hysterectomy in patients with symptomatic uterine fibroids. Bjog. May. 2000;107(5):620-5. [pmid: 10826576].
161 Harmanli OH, Gentzler CK, Byun S, Dandolu MH, Grody T. A comparison of abdominal and vaginal hysterectomy for the large uterus. Int J Gynaecol Obstet. Oct. 2004;87(1):19-23. [pmid: 15464771].
162 McPherson K, Metcalfe MA, Herbert A, Maresh M, Casbard A, Hargreaves J, et al. Severe complications of hysterectomy: the VALUE study. Bjog. Jul. 2004;111(7):688-94. [pmid: 15198759].
163 Okin CR, Guido RS, Meyn LA, Ramanathan S. Vasopressin during abdominal hysterectomy: a randomized controlled trial. Obstet Gynecol. Jun. 2001;97(6):867-72. [pmid: 11384687].
164 Paparella P, Sizzi O, Rossetti A, De Benedittis F, Paparella R. Vaginal hysterectomy in generally considered contraindications to vaginal surgery. Arch Gynecol Obstet. Sep. 2004;270(2):104-9. [pmid: 12856131].
165 Seracchioli R, Venturoli S, Vianello F, Govoni F, Cantarelli M, Gualerzi B, et al. Total laparoscopic hysterectomy compared with abdominal hysterectomy in the presence of a large uterus. J Am Assoc Gynecol Laparosc. Aug. 2002;9(3):333-8. [pmid: 12101331].
166 Taylor SM, Romero AA, Kammerer-Doak DN, Qualls C, Rogers RG. Abdominal hysterectomy for the enlarged myomatous uterus compared with vaginal hysterectomy with morcellation. Am J Obstet Gynecol. Dec. 2003;189(6):1579-82. discussion 82–3. [pmid: 14710071].
167 Unger JB, Paul R, Caldito G. Hysterectomy for the massive leiomyomatous uterus. Obstet Gynecol. Dec. 2002;100(6):1271-5. [pmid: 12468173].
168 Gregoriou O, Konidaris S, Botsis D, Papadias C, Makrakis E, Creatsas G. Long term effects of Tibolone on postmenopausal women with uterine myomas. Maturitas. Oct 31. 2001;40(1):95-9. [pmid: 11684378].
169 Colacurci N, De Franciscis P, Cobellis L, Nazzaro G, De Placido G. Effects of hormone replacement therapy on postmenopausal uterine myoma. Maturitas. May 29. 2000;35(2):167-73. [pmid: 10924843].
170 Polatti F, Viazzo F, Colleoni R, Nappi RE. Uterine myoma in postmenopause: a comparison between two therapeutic schedules of HRT. Maturitas. Nov 30. 2000;37(1):27-32. [pmid: 11099870].
171 Reed SD, Cushing-Haugen KL, Daling JR, Scholes D, Schwartz SM. Postmenopausal estrogen and progestogen therapy and the risk of uterine leiomyomas. Menopause. Mar–Apr. 2004;11(2):214-22. [pmid: 15021452].
172 Baker CM, Winkel CA, Subramanian S, Spies JB. Estimated costs for uterine artery embolization and abdominal myomectomy for uterine leiomyomata: a comparative study at a single institution. J Vasc Interv Radiol. Dec. 2002;13(12):1207-10. [pmid: 12471183].
173 Beinfeld MT, Bosch JL, Gazelle GS. Hospital costs of uterine artery embolization and hysterectomy for uterine fibroid tumors. Acad Radiol. Nov. 2002;9(11):1300-4. [pmid: 12449362].
174 Edwards RD, Moss JG, Lumsden MA, Wu O, Murray LS, Twaddle S, et al. Uterine-artery embolization versus surgery for symptomatic uterine fibroids. N Engl J Med. Jan 25. 2007;356(4):360-70. [pmid: 17251532].
175 Katsumori T, Akazawa K, Mihara T. Uterine artery embolization for pedunculated subserosal fibroids. AJR Am J Roentgenol. Feb. 2005;184(2):399-402. [pmid: 15671352].