# Executive Summary

## Introduction

Fibroids are the most common female pelvic tumor; developing a fibroid or multiple fibroids by the time of menopause is the rule rather than the exception. The RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) conducted a systematic review of the literature to update the evidence on the management of uterine fibroids. We systematically assessed the evidence on seven key questions (KQs): (1) incidence and prevalence of uterine fibroids, (2) outcomes of treatment for symptoms, (3) outcomes of treatment for reasons other than symptoms, (4) costs, (5) modifiers of treatment outcomes, (6) comparisons of treatments, and (7) geographic variation in treatment.

## Methods

We searched MEDLINE^®^, Cochrane Collaboration resources, and Embase. We dually reviewed each study against a priori inclusion/exclusion criteria. For included articles, a primary reviewer abstracted data directly into evidence tables; a second senior reviewer confirmed accuracy. We included 107 studies in English, published from February 2000 through August 2006, from developed countries. We excluded studies with low sample size (based on study design, cases series < 100 and cohorts < 40) or lack of relevance to uterine fibroids.

## Results

The first Agency for Healthcare Research and Quality (AHRQ) systematic review on the management of uterine fibroids was published in January 2001. It found that the overall quality of the literature on the management of fibroids was poor, with almost no evidence to support the effectiveness of commonly recommended treatments. The review found consistent evidence from randomized trials that preoperative use of gonadotropin-releasing hormone (GnRH) agonist therapy reduced estimated blood loss and may facilitate the surgical approach by reducing uterine size. It also reported that the outcomes of hysterectomy up to 2 years after surgery are favorable for most symptomatic women, although up to 12 percent of women develop new symptoms after surgery. The review did not attempt to deduce the clinical significance of these outcomes compared with outcomes of other treatments, because of significant differences in the severity of preintervention disease. The prior review found almost no data to allow estimation of the overall costs of fibroids to the economy. The remainder of this summary reflects our update of the literature and synthesis of evidence.

### KQ 1: Incidence and Prevalence of Uterine Fibroids

Two studies provided weak evidence (limited number of studies) on the incidence and prevalence of uterine fibroids. One study used randomly selected participants from a prepaid urban health plan with 50 percent black membership to report ultrasound-confirmed incidence for premenopausal women and medical records and self-report for postmenopausal women for a cumulative incidence rates by age 50 of nearly 70 percent among white women and more than 80 percent among black women. Another study reported an incidence rate of 2.97 for every 100 person-years from a black nationwide U.S. sample. The literature provides no guidance on the overall burden of disease posed by uterine fibroids.

### KQ 2: Outcomes of Treatment of Uterine Fibroids for Symptoms

Studies provided information on effectiveness more commonly than on adverse outcomes. We summarize data on adverse outcomes when available below.

Expectant Management. We identified no literature to document the natural history of uterine fibroid incidence, growth, symptomatology, use of clinical care, or outcomes when women choose watchful waiting over intervention.

Pharmaceutical Management. GnRH agonists. Of the 19 studies that we reviewed for pharmaceutical management of fibroids, 13 (7 RCTs) addressed the effect of GnRH agonists. Eight of these studies provided moderate evidence (consistent effects and strong design but small sample sizes) that GnRH agonists were effective in decreasing overall uterine size when used either as preoperative treatment or as an alternative to surgery. Another subset (six studies) on hemoglobin levels provided weak evidence of increases in hemoglobin levels by 0.9 g/dL to 5.2 g/dL after treatment and before surgery.

Three studies provided weak evidence (limited number of studies, inconsistent effects) on the effect of GnRH agonists on symptom relief. A small nonrandomized study reported relief from hot flashes among women receiving tibolone and a GnRH agonist. The other two studies found that raloxifene was not effective in reducing fibroid symptoms compared with placebo.

Progestins. A small randomized controlled trial (RCT) presented weak evidence of reduction in fibroid size among women receiving lynestrenol compared with women receiving leuprolide acetate.

Mifepristone. One study (weak evidence) comparing two doses of mifepristone reported significant reductions in uterine size and menstrual blood loss from baseline values in both groups but no differences between the dose groups, suggesting that the lower dose is sufficient.

Estrogen Receptor Modulators and Antagonists. Three trials provided weak evidence (limited number of studies, inconsistent effects) comparing raloxifene with placebo; two reported a significant reduction in uterine and fibroid size compared with baseline values for postmenopausal women on raloxifene and an increase in uterine and fibroid size for premenopausal women on raloxifene. A fourth study was a five-arm trial of poor quality comparing three different doses of the estrogen receptor antagonist fulvestrant with goserelin and a placebo. Goserelin significantly reduced fibroid growth and endometrial thickness compared with placebo and fulvestrant, but fulvestrant did not significantly alter fibroid volume or endometrial thickness compared with placebo.

Uterine Artery Embolization (UAE). Twenty-three studies examined short- and long-term outcomes following UAE. Of these, six studies (one RCT) compared UAE with either hysterectomy or myomectomy. They yielded evidence of moderate strength (consistent effects but weak design) suggesting shorter procedure (operative) times and shorter lengths of hospital stay for UAE than for hysterectomy or myomectomy. However, they provided only weak evidence (either no significant differences or inconsistent direction of effect) about the impact of UAE on complications and symptom relief.

The remaining studies were case series or cohort studies, of poor or fair quality, with sample sizes ranging from 46 to 3,140. They do not provide consistent definitions or time points for measuring key outcomes such as complications. The largest case series on UAE reported an in-hospital complication rate of 2.7 percent, (0.6 percent rate of major events), and a postdischarge complication rate of 26.1 percent (4.1 percent rate of major events).

Only one study examined rates of subsequent interventions for UAE and another procedure. It reported statistically significant higher rates of subsequent interventions with UAE than with myomectomy (29 percent versus 3 percent) in followup ranging from 3 to 5 years. Another study reported a subsequent intervention rate of 20 percent at 5 years. The value of this information is limited by the lack of comparable data for other types of treatment.

Endometrial Ablation. We found only three studies, all of poor quality, about endometrial ablation, which is used to treat bleeding symptoms. Of these, two combined ablation with hysteroscopic resection (retrospective case series) and one evaluated ablation only (prospective case series). These publications poorly document operative and longer-term outcomes; they lack enough common data elements to permit any substantive summary of findings.

Magnetic Resonance Imaging (MRI) Guided Focused Ultrasound. The strength of evidence about MRI-guided ultrasound ablation of fibroids is weak, although we identified one carefully conducted prospective case series. Overall, the study suggested reasonable tolerance (16 percent of women reported severe pain at some point during the treatment and 8 percent reported severe to moderate pain after the procedure), improvement in quality of life (71 percent improved), and modest change in fibroid size (13 percent decrease). During more than a year of followup, 11 percent of women experienced worsened symptoms; 28 percent elected further treatment including myomectomy and hysterectomy.

Myomectomy. The strength of evidence overall is weak because of the predominance of weak study designs, the restricted scope of outcomes studied, and the limited quality of measurements in the few studies of stronger design.

Abdominal Myomectomy. The abdominal myomectomy literature comprised 13 studies of small to modest size. Transfusion risk in the eight studies that reported it varied widely, from 5 percent to 21 percent, with higher risk in studies in less specialized surgical settings. Among women for whom myomectomy had been the original plan, 3 percent to 4 percent required intraoperative conversion to hysterectomy. Wound healing complications affected 2 percent to 4 percent of women receiving abdominal myomectomy.

In four studies that assessed symptoms, most women reported improvements in symptoms such as bleeding, pressure, and pain, for which they sought care, although the degree of improvement varied by symptom. Recurrence of fibroids likely affected more than 18 percent of women and may have been as high as 62 percent within 3 to 4 years after surgery.

Laparoscopic Myomectomy. Transfusion ranged from <1 percent to 8 percent in 11 of 16 studies that reported. A single study provided direct comparison between abdominal and laparoscopic myomectomy, reporting statistically significant lower risk among those having laparoscopic procedures. Conversion to open procedures occurred in approximately 9 percent of women; a small proportion had an immediate hysterectomy. Length of stay in the hospital is shorter after laparoscopy than after abdominal procedures, and wound healing complications are rare. Recurrence of fibroids ranged from 13 percent to 27 percent, and 7 percent to 12 percent of women had additional surgery over the first few years after myomectomy, Although these operative risks appear similar to those for abdominal myomectomy, we found no direct comparisons with power adequate to compare long-term outcomes between laparoscopic and abdominal myomectomy.

Hysteroscopic Myomectomy. Across five studies with 2,061 participants, we found little detail about operative complexity and complications. The risk of perforations of the uterus (two studies) was consistent with the often clinically cited rate of 1 in 100. Repeat procedures and subsequent surgery affect 2 percent to 20 percent of women in the years immediately after hysteroscopic myomectomy. In these studies > 80 percent of women reported good outcomes as defined by self-report of “control of bleeding.”

Hysterectomy. Seventeen studies (eight RCTs) of poor and fair quality provided weak evidence on outcomes of hysterectomy, comparisons of types of hysterectomy, and modifiers of hysterectomy.

Outcomes. The hysterectomy literature is limited largely to short-term outcomes such as operative time, length of stay, and complications. Most studies reporting on comparative studies of hysterectomy either did not have sufficient sample sizes to derive estimates of risks of individual operative or postoperative complications or were not of generalizable practice settings.

Long-term outcomes are similarly limited to small studies of comparisons between treatments. These studies did not have sufficient sample sizes to derive estimates of long-term outcomes.

Comparisons of Types of Hysterectomy. In three studies comparing vaginal to abdominal hysterectomy, the most consistent finding was shorter average hospital stay (by 1 to 2 days) for patients undergoing vaginal procedures. Rates of transfusion and intraoperative complications were generally comparable; in one cohort study the combined rate of postoperative complications was significantly higher in women undergoing abdominal hysterectomy.

The two studies reporting on laparoscopically assisted vaginal hysterectomy (LAVH) and abdominal hysterectomy demonstrated improved outcomes for LAVH on a limited set of perioperative outcomes, namely hospital stay, convalescence, and use of analgesia.

The only study comparing outcomes of LAVH and vaginal hysterectomy reported significantly longer hospital stay and higher rates of total perioperative complications among women undergoing LAVH.

Complementary and Alternative Medicine. A single study of poor quality provided weak evidence favoring traditional Chinese medicine over standard medical management. Differences in degree of motivation between treatment arms may have potentially biased the results.

### KQ 3: Outcomes of Treatment of Uterine Fibroids for Other Reasons

The sole clinical trial comparing surgical intervention with no intervention to improve fertility (in the absence of assisted reproductive technology) supported benefit from removing fibroids that have a submucosal component. This benefit was substantial (>15 percent absolute increase in the proportion of women becoming pregnant); the trial was limited, however, by small study size, to reporting only ability to conceive and not other pregnancy outcomes. The 10 studies we identified provided weak evidence that was insufficient to assess risk of pregnancy complications related to myomectomy. Uterine rupture was rare (1 in 314 births); all studies combined are underpowered to estimate risk accurately.

We found no evidence on the effects of treatment to prevent further fibroid growth among asymptomatic women. However, concerns about further growth during the postmenopausal period limit the use of hormone replacement therapy to treat postmenopausal symptoms. Moderate evidence from three studies indicated that menopausal hormone therapy had no effect on fibroid size; one reported a higher rate of uterine growth with the percutaneous-oral schedule of hormone replacement therapy than with a single oral combination of oestradiol valerate and cyproterone acetate.

### KQ 4: Costs of Fibroid Treatment

Three studies report on UAE, either on its own or in comparison with other interventions. They do not suggest cost savings for UAE; rather, they demonstrate comparable or higher costs of UAE, despite shorter length of stay.

Our analysis of Healthcare Cost and Utilization Project data showed that the average costs of uterine fibroid treatment increased by almost 30 percent between 1997 and 2004. In 1997 the average inpatient costs were $11,978 (adjusted to 2004 dollars); by 2004 the average costs had increased to $15,405. During the same period, the average length of stay dropped from 2.9 days to 2.6 days.

The source of increase in costs is unclear; possible explanations include higher professional costs with procedures such as UAE and overall increase in health care costs. We found no information comparing average costs of procedural interventions with pharmaceutical treatments.

### KQ 5: Modifiers of Outcomes

In eight studies, larger and more numerous fibroids often predict worse outcomes for several uterine fibroid procedures other than UAE (seven studies), for which the evidence is unclear. Eight studies addressed patient health characteristics or provider characteristics as modifiers of outcomes; they suggested that greater provider experience predicts fewer adverse events. For UAE, three studies demonstrated that a history of previous procedures predicts a higher risk of failure and adverse events.

### KQ 6: Comparisons of Treatments

The majority of comparative studies (8 of 10) compared UAE with hysterectomy or myomectomy. They reported procedure time and length of stay favoring UAE. However, the inconsistency of the direction of effect for complications and the absence of information on longer-term outcomes suggested that this evidence base is inadequate to comment on the relative risks and benefits of UAE versus hysterectomy or myomectomy. Only one study addressed the need for further invasive therapy; it reported a much higher risk of hysterectomy, myomectomy, or repeat UAE in the UAE group than in the myomectomy group.

One study comparing abdominal hysterectomy with abdominal myomectomy reported no difference in the only outcome considered (febrile morbidity). Another study, comparing Chinese traditional medicine with conventional therapy, as discussed earlier in this summary, provides weak evidence (weak design, potential bias) favoring traditional Chinese medicine.

### KQ 7: Geographic Variation in Treatment

We found no study on geographic variation in treatment within the United States. Studies in our systematic review were generally conducted in academic medical centers, and we could not assess the generalizability of their patterns of care with the broader population from which they were drawn.

## Discussion

As with the prior review, we find a remarkable lack of high-quality evidence supporting the effectiveness of most interventions for symptomatic fibroids. Specifically notable is the lack of well-conducted trials in U.S. populations that directly compared treatment options, including the option of expectant management, and that followed women to determine whether their objectives for treatment were met by the intervention received.

Appearance of new fibroids and growth of existing fibroids after treatment are poorly studied. Trials of preoperative medical management indicate that treatment reduces fibroid volume but do not provide sufficient evidence of improvement in important operative outcomes. When women are treated for reasons other than symptom relief, such as when pregnancy is desired, weak evidence supports treating submucous fibroids via hysteroscopy.

We limited our search to articles published in English, primarily for reasons of time and resources; our review of complementary and alternative medicine is likely to be significantly limited by this constraint. We also excluded case reports and case series with fewer than 100 women; this may have resulted in underreports of rare complications of fibroid treatment.

Selection bias is an important weakness in trying to compare outcomes across different interventions in nonrandomized studies. Underlying features of the fibroids and patient risk factors likely influence clinicians in their choice of treatments and operative approaches. Few studies reported these details adequately to allow either adjustment for these potential confounders or pooling across studies.

Across management options, lack of evidence is not equivalent to evidence of no benefit or of harm. Some interventions may be effective in at least some patients. Research to assess how patient characteristics influence outcomes is meager. The current state of the literature does not permit definitive conclusions about benefit, harm, or relative costs to help guide women's choices. Significant research gaps include well-conducted trials in U.S. populations that directly compare interventions on short- and, especially, long-term outcomes, studies on therapeutics for medical management, and information on treatment decisions for women who desire a pregnancy.

Given how common and concerning fibroids can be to women and their health care providers, a redoubled emphasis on promoting high-quality fibroid research in the United States is imperative. Women deserve better information to guide their choices.