# Discussion

This chapter first discusses our findings for four key questions (KQs) relating to incidence and prevalence of uterine fibroids, outcomes of treatment for symptoms, outcomes of treatment for other reasons, and costs of treatment of uterine fibroids. We then address KQ 5, summarizing the effect of modifiers on outcomes, KQ 6, on comparisons between treatments, and KQ 7, on variation in treatment.

We note in this discussion both the quality of individual studies (good, fair, or poor, as explained in Chapter 2) and the strength of the evidence for each question or subquestion (also described in Chapter 2). To reiterate the strength grades, the levels of strength of evidence are as follows:

I Strong: The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
II Moderate: The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
III Weak: The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
IV No evidence: No published literature.

We conclude with a discussion of the limitations of this review and the evidence base, and we present our recommendations for future research.

## Principal Findings

### KQ 1: Incidence and Prevalence of Uterine Fibroids

Two studies, both of fair quality, provided weak evidence (Level III) on the incidence of uterine fibroids. One reported on incidence among black women alone and relied primarily on self-report of ultrasound- or hysterectomy-confirmed diagnosis of uterine fibroids.^41^ Although self-reports are likely to be accurate, this study very probably underestimates, perhaps to a considerable degree, the incidence of uterine fibroids because it was not based on ultrasound evidence for all women (diagnosed or undiagnosed). The second study relied primarily on ultrasound-confirmed diagnosis of a random sample of women.^2^ The results suggested cumulative incidence rates by age 50 of nearly 70 percent among white women and more than 80 percent among black women. Black women had earlier onset, and more and larger fibroids, than white women. Black women were more likely to have fibroids than white women, even after controlling for body mass index (BMI) and parity.^2^ Additionally, women who were young at menarche, had no children, or had not had a child within the previous 5 years were more likely to have uterine fibroids.^41^

The estimate of cumulative incidence of 70 percent to 80 percent suggests that the vast majority of women will experience uterine fibroids during their lifetimes. Given such high levels of cumulative incidence, the absence of evidence on the proportion of women with uterine fibroids is striking. Currently, the literature provides no guidance on the overall burden of disease posed by uterine fibroids.

### KQ 2: Outcomes of Treatment of Uterine Fibroids for Symptoms

Expectant Management. Evidence is lacking (Level IV) to address the subquestion about likely outcomes of expectant management. We identified no literature to document the natural history of uterine fibroid incidence, growth, symptomatology, use of clinical care, or outcomes when women choose watchful waiting over intervention.

Solely as a weak surrogate, we summarized the limited information about outcomes among women who received no intervention, or vitamin supplementation only, in 12 clinical trials and one retrospective clinical comparison group. None had been designed to assess expectant management. The quality of the identified literature for informing this question was poor, and all but one study reflected European populations recruited at specialized fibroid care centers.

Three sets of investigators used imaging to measure fibroids in three small samples (N = 22, 31, and 60) of premenopausal women.^44,^ ^46,^ ^55^ They followed up these women at 2 months to 3 months and documented no clinically meaningful or statistically significant changes in fibroid size as assessed by ultrasound in untreated women. Given that these studies were conducted among women awaiting surgery, this finding suggests an absence of rapid growth even among women in a highly symptomatic population. Another study reported that bleeding severity, pelvic pain, and pressure did not appreciably change in 2 months. The longest followup that addressed symptoms was 6 months, during which severity of bleeding, length of bleeding with menses, and hemoglobin levels remained unchanged.

These results have quite limited implications for clinical care; they provide minimal evidence that, at least among premenopausal women with symptoms, their condition and fibroid characteristics are not likely to change rapidly. This information, with the caveats noted, could be interpreted to mean that decisions about fibroid management do not need to be made with great urgency. Such findings also suggest that some number of months are available in which both women and their clinicians can consider options, continue watchful waiting, and treat discrete symptoms such as pain, with low risk of exacerbation of the condition.

The remaining studies, in postmenopausal women, were done to assess the influence of pharmaceutical agents on fibroids, with the goal of assessing whether use of these medications for menopausal symptoms or to treat other conditions (e.g., bone mineral density) would exacerbate fibroids. The untreated groups were followed for up to a year. The notable finding in the area of expectant management is that these women had little change in fibroid size.

Clinical wisdom reflects a general belief that fibroids undergo involution, or shrinking, after menopause. These findings raise the question about whether and in what circumstances that is the case. The data are poor for asserting the absence of involution for two reasons: (1) the studies had not been designed to assess the natural history of fibroids after menopause and (2) they represented only a cross-sectional sample of women at varied times after menopause and with a broad range of baseline fibroid characteristics that may influence the results observed.

These studies offer two preliminary impressions: (1) fibroids do not have a continuous slow growth pattern before menopause, and (2) after menopause, a decrease in size may not be as profound as believed. Nonetheless, we emphasize that these studies do not provide appropriate information about the growth trajectory or biological behavior of fibroids across the lifespan. The study populations are small, even for the purposes of preliminary descriptive data, and the research was not intended to assess changes in fibroids or related symptoms. In summary, we identified no evidence of sufficient quality to inform the decision to pursue expectant management of uterine fibroids.

Pharmaceutical Management. Although several new randomized controlled trials (RCTs) have been published since the prior review in 2001,^30^ together they provide moderate to weak evidence about the use of pharmaceutical management on fibroid growth and symptom relief.

Gonadotropin-Releasing Hormone (GnRH) Agonists. Of the 19 studies that we reviewed for pharmaceutical management of fibroids,^42^–^46,^ ^49^–^56,^ ^59^–^69^ 13 addressed the effect of GnRH agonists.^42^–^45,^ ^49,^ ^51^–^55,^ ^59^–^64,^ ^69^ Of these, eight reported on uterine and fibroid size changes in response to GnRH agonists.^42^–^45,^ ^55,^ ^61,^ ^63,^ ^64^ These studies together provided moderate evidence (Level II) that GnRH agonists were effective in decreasing overall uterine size when used either as preoperative treatment or as an alternative to surgery. A subset of these GnRH agonist studies (six studies) on hemoglobin levels provided weak evidence of increases in hemoglobin levels by 0.9 g/dL to 5.2 g/dL after treatment and before surgery.^42,^ ^55,^ ^59,^ ^61^–^63^ The results were statistically significant in two of these studies.^55,^ ^59,^ ^63^

Three studies provided weak evidence (Level III) on the effect of GnRH agonists on symptom relief. One study reported evidence from a single small nonrandomized study of relief from hot flashes from tibolone.^61^ The other two studies together provided no evidence of the effectiveness of raloxifene for dealing with symptomatology alone.^51^–^54,^ ^56^

One study found weak evidence (Level III) that adding raloxifene to leuprolide therapy improves bone mineral density.^51^ Two studies compared the effects of leuprolide plus supplemental therapy (ipriflavone or raloxifene) to leuprolide alone on low-density lipoprotein cholesterol (LDL).^51^–^54,^ ^60^ The studies found weak evidence (Level III) that levels of LDL increased after therapy for both groups, but leuprolide-only groups had significantly higher levels of LDL than did groups receiving leuprolide plus supplemental therapy.

Progestins. A single small RCT presented weak evidence (Level III) of reduction in fibroid size among women receiving lynestrenol compared with women receiving leuprolide acetate.^62^

Mifepristone. The literature provided weak evidence (Level III) comparing two different doses of mifepristone. The single study reported significant reductions in uterine volume and menstrual blood loss from baseline values in both groups but no differences between the groups.^65^

Estrogen Receptor Modulators and Antagonists. Three studies^50,^ ^56,^ ^67^ provided weak evidence (Level III) from trials comparing raloxifene with placebo: two reported a significant reduction in uterine and fibroid size compared with baseline values for postmenopausal women on raloxifene and an increase in uterine and fibroid size for premenopausal women on raloxifene.^50,^ ^56^

Uterine Artery Embolization (UAE). Twenty-four studies examined short- and long-term outcomes following UAE.^70^–^100^ Of these, six studies provided evidence on comparisons between UAE and either hysterectomy or myomectomy.^70,^ ^73,^ ^75,^ ^76,^ ^90,^ ^94^

The comparative studies yielded evidence of moderate strength (Level II) suggesting shorter procedure (operative) times and shorter lengths of hospital stay for UAE than for hysterectomy or myomectomy. However, we found only weak evidence (Level III), either no significant differences or inconsistent direction of effect, concerning the impact of UAE on complications and symptom relief.

Studies of UAE alone were generally case series or cohort studies, of poor or fair quality, ranging from a sample size of 46 to 3,140. They do not provide consistent definitions or time points for measuring key outcomes such as complications. Outcomes included all complications, major and minor complications, perioperative complications, or at least one adverse event; these outcomes are reported from points varying from within the hospital to a 2-year followup window.

The largest of these studies reported an in-hospital complication rate of 2.7 percent, of which 0.6 percent was for major events, and a postdischarge complication rate of 26.1 percent, of which 4.1 percent was for major events.^100^

Very few studies reported the rate of subsequent interventions in the long term; of these, only one compared the rate of subsequent interventions between UAE and another procedure. This study reported statistically significant higher rates of subsequent interventions for UAE than for myomectomy (29 percent versus 3 percent, in a follow-up period ranging from 3 to 5 years).^70^ Another study reported a subsequent intervention rate of 20 percent at 5 years.^93^ The lack of comparable data for other types of treatment limits the value of this information.

Since the formal compilation of this review, the REST trial of Embolization versus Surgical Management was published comparing outcomes for 106 women randomly assigned to UAE compared to surgery (43 hysterectomies and 8 myomectomies). This trial of good quality was designed to evaluate health-related quality of life at 1 year using the Medical Outcomes Study 36-item Short Form General Health Survey. The investigators found no differences between groups in health-related quality of life. UAE patients had shorter hospital stays (1 day compared to 5) and returned to work sooner. At 1 year, symptom scores were superior in the surgical intervention group although the majority of UAE (88 percent) and surgical (93 percent) patients would recommend the treatment they received to a friend. Fifteen and 20 percent of the groups, respectively, had major complications. Twenty percent of women who had UAE subsequently had additional procedures, the majority hysterectomies. Among adverse outcomes were two women who had a hysterectomy immediately due to technical failure of the UAE and one conversion in the operative group, of a myomectomy to an emergency hysterectomy.^174^

REST reinforces the general impression of the data in the review: Uterine artery embolization offers documented symptom improvement and a more rapid recovery trajectory. For the majority of women the procedure provides sufficient relief of symptoms that they do not pursue additional intervention. However, more than one in five women who have UAE are likely to seek additional management of their fibroids in the years immediately after UAE. This is important for women and their care providers to understand as is the small but consistently documented risk that women who choose uterus-conserving therapy may have hysterectomy as a complication of either UAE or myomectomy.

Endometrial Ablation. The strength of evidence on endometrial ablation, which is used to treat bleeding symptoms, is weak (Levels III). We found only three studies, all of poor quality. Of these, two combined ablation with hysteroscopic resection (retrospective case series) and one (prospective case series) evaluated ablation only. Operative and longer-term outcomes are poorly documented in each of these publications, such that across the studies they lack enough common data elements to permit any substantive summary of findings. In this and other areas lacking sufficient evidence, it is important to note that absence of evidence is equated not with absence of benefit but rather with lack of data to properly estimate benefit (if any) and potential risks. In these areas women and their health care providers lack meaningful information to guide treatment decisions.

Magnetic Resonance Imaging (MRI) Guided Focused Ultrasound. The strength of evidence about MRI-guided ultrasound ablation of fibroids is weak (Level III). The literature included one carefully conducted prospective case series (N = 109), but it nonetheless ranks as poor for informing clinical decisionmaking. This work had been conducted to support an application for approval from the U.S. Food and Drug Administration (FDA, given in 2004) of the system designed to conduct MRI-guided ultrasound.

Overall, women tolerated the procedure well. Sixteen percent of women reported severe pain at some point during the treatment, but few reported residual pain immediately after it was completed. Patient-reported outcomes were gathered using validated measures; 71 percent of women reported a 10-point or greater improvement on a quality-of-life measure. The investigators also documented improvements in bleeding and pressure. However, the change in fibroid size was modest (13 percent decrease), and 11 percent of women met criteria for treatment failure defined by worsening of symptoms, with 28 percent electing further treatment by other modalities including myomectomy and hysterectomy.

Clinicians need to consider carefully the reality that, now that the systems are in use, care providers are using this new modality to treat fibroids more aggressively than had been allowed during the strict study protocol. The major change in how the systems are now being used is that a greater proportion of the total volume of the fibroid is treated. Therefore, no information exists at present that reflects current practice in terms of procedure-related risks and anticipated outcomes.

Myomectomy. The quality of the evidence to guide decisions about myomectomy for management of uterine fibroids is poor to fair, with limited strength (Level III) because of the dominance of weak study designs, the restricted scope of outcomes studied, and the limited quality of measurements even in the few studies of stronger design. We identified 44 publications that represent 39 distinct study populations; ^70,^ ^73,^ ^90,^ ^102,^ ^108^–^148^ these included 24 case series studies, of which six were prospective; eight cohort studies that compared outcomes across two or more types of myomectomy, of which three were prospective; and five RCTs, of which two compared interventions to reduce blood loss, not broader outcomes of myomectomy.

Short-term outcomes were most robust for immediate measures of operative outcomes (blood loss, length of surgery) and for longer-term outcomes reflecting subsequent care received and fibroid recurrence. Few studies addressed resolution of symptoms, quality of life, sexual function, or satisfaction with treatment outcomes; those that do report such measures did not describe use of validated measures. We summarize here the main findings by type of myomectomy (abdominal, laparoscopic, laparoscopically assisted, and hysteroscopic).

Abdominal Myomectomy. The abdominal myomectomy literature consisted of studies of small to modest size, meaning that they generally lacked precision about risk.^90,^ ^113,^ ^121,^ ^122,^ ^128,^ ^133,^ ^136^–^138,^ ^140,^ ^144,^ ^146,^ ^148^ For instance, transfusion risk varied widely, from < 1 percent to 21 percent, with higher risk in studies in less specialized surgical settings. A single small trial of good quality reported promising results for using a “chemical aid for dissection” in reducing blood loss and operative time.^146^ Across studies 3 percent to 4 percent of women required intraoperative conversion to hysterectomy although myomectomy had originally been intended. Wound healing complications affected 2 percent to 4 percent of women having this form of myomectomy.

When the investigators studied improvement in symptoms, women did report improvements in symptoms for which they sought care, although improvements were not universal: 68 percent reported “improved symptoms”; 64 percent reported “completely” or “significantly” improved menorrhagia; 54 percent reported improved pain; and 91 percent reported resolution of mass effects.

Only one study with 30 participants provided any data about satisfaction, with 69 percent finding their results satisfactory.^70^ Recurrence of fibroids, when defined by identification of new fibroids through imaging, likely affected more than 18 percent of women and may be as high as 62 percent within 3 to 4 years after surgery. Between 1.4 percent and 17 percent of women have additional surgery after myomectomy, but we found only limited information to describe what proportion of these procedures were hysterectomy or another myomectomy.

The nature and strength of this evidence mean that it cannot be used to compare expected outcomes of abdominal myomectomy with those of other types of myomectomy. However, this literature does provide some cautionary data. Women and their surgeons should explicitly discuss risk of transfusion, conversion to hysterectomy, and wound healing complications; although the estimates that might be taken from this body of evidence are imprecise, they indicate that the risks are not negligible. Likewise, when symptoms are attributed to fibroids, a common belief among those seeking treatment is that their removal is a virtual guarantee of resolution of symptoms. Although the majority of women have improvements (poorly measured), that proportion is not likely to be as high as the 8 or 9 of 10 women undergoing this surgery. In the absence of higher quality research, women may still wish to weigh the information that likelihood of complete resolution of symptoms or complete satisfaction is meaningfully less than universal. Clinicians should also share information that emphasizes that myomectomy does not preclude continued appearance of new fibroids and that it is likely that more than 15 percent of women will have recurrence, some of whom will choose additional surgery in the years after myomectomy.

Laparoscopic Myomectomy. With respect to risks, and with the same caveats about study size, design, and generalizability that apply to the entire body of myomectomy literature, summaries of risks from 16 studies offer context for clinical decisionmaking.^115^–^117,^ ^119,^ ^121,^ ^125,^ ^127,^ ^128,^ ^134,^ ^137^–^140,^ ^145^ Transfusion ranged from < 1 percent to 8 percent; a single study provided direct comparison between abdominal and laparoscopic myomectomy, reporting statistically significant lower risk among those having laparoscopic procedures. Conversion to open procedures occurred in approximately 9 percent of women, with a range from < 1 percent to 29 percent, among which a small proportion goes to immediate hysterectomy. The less specialized the surgical setting, the more likely conversion appears. Women and their care providers should anticipate a conversion rate of 10 percent or higher when discussing likely outcomes of laparoscopic myomectomy and planning for postoperative recovery. When investigators did make direct comparisons, length of stay in the hospital was shorter after laparoscopy than abdominal procedures, and wound healing complications were rare.

Satisfaction with outcomes and resolution of specific symptoms was poorly studied after laparoscopic procedures. Most of the research emphasized technical and process outcomes, not providing data about how well surgery addressed the key indications for which women elected to have these procedures in the first place. Recurrence of fibroids ranged from 13 percent to 27 percent, and 7 percent to 12 percent of women had additional surgery during the first few years after myomectomy. Although these postoperative risks appear similar to those for abdominal myomectomy, and biologically would be expected to be similar, we found no direct comparisons with power adequate to declare them comparable. The same observations apply about the sole use of these data being cautionary information to provide rough estimates for counseling about probable risks.

Hysteroscopic Myomectomy. Across five studies with 2,061 participants, we found little detail about operative complexity and complications such as transfusions.^108^–^110,^ ^130,^ ^132,^ ^140,^ ^154^ The risk of perforations of the uterus, reported in two studies, was consistent with the often clinically cited rate of 1 in 100. Some proportion of resections will be incomplete (13 percent to 18 percent); conversions to abdominal myomectomy (7 percent) and hysterectomy (1 percent) do happen. Repeat procedures and subsequent surgery affect approximately 2 percent to 20 percent of women who are followed for the years immediately after hysteroscopic myomectomy. Because hysteroscopic interventions are generally outpatient procedures and associated with rapid return to usual activities, the limited data available suggest that the majority of women who have fibroids amenable to hysteroscopic intervention (> 80 percent) may achieve good outcomes without resorting to more complex and costly procedures that also have a longer recovery time.

Hysterectomy. A limited number of studies of poor and fair quality provided weak evidence (Level III) on outcomes of hysterectomy, comparisons of types of hysterectomy, and modifiers of hysterectomy.

Outcomes. The literature on hysterectomy is limited largely to short-term outcomes. Most of the studies reporting on comparative studies of hysterectomy did not have sufficient sample sizes to derive estimates of risks of individual operative or postoperative complications. A single study based on large case-series data reported severe operative and postoperative complications up to 6 weeks following surgery,^162^ but the time frame (1994-1995) and location of the study (United Kingdom) make generalizations to current U.S.-based practice uncertain.

Long-term outcomes are similarly limited to small studies of comparisons between treatments. These studies together did not have sufficient sample size to derive reliable estimates of long-term outcomes. The few studies that reported long-term outcomes examined a mix of variables, including comparisons of ovarian function 6 months following UAE and hysterectomy;^75^ comparisons of symptoms, quality of life, satisfaction, pain, and overall health 12 months following UAE and hysterectomy;^94^ and rates of myocardial infarction several years following hysterectomy.^159^ These studies did not yield sufficiently consistent or statistically significant variables to comment on long-term outcomes following hysterectomy within the first 12 months following the procedure. We found no evidence on quality of life or health outcomes beyond the first 12 months following hysterectomy.

Comparisons of Types of Hysterectomy. Studies comparing hysterectomy with UAE or myomectomy or comparing different types of hysterectomy all reported primarily on short-term outcomes. They were not powered to estimate rates of individual perioperative complications. From a small set of underpowered studies, the direction of effect suggested better outcomes on a limited range of perioperative measures (of which length of hospital stay has the most consistent direction and significance of effect) for vaginal hysterectomy and laparoscopically assisted vaginal hysterectomy (LAVH) compared with abdominal hysterectomy and for vaginal hysterectomy compared with LAVH.

All three studies that reported on vaginal versus abdominal hysterectomy focused on perioperative outcomes.^155,^ ^161,^ ^166^ They consistently reported significantly longer hospital stays with abdominal hysterectomy. Other perioperative outcomes occurred with higher frequency among the abdominal hysterectomy group, with significantly higher risk of ileus reported in one study,^161^ and significantly higher rates of postoperative outcomes (postoperative transfusion, pelvic hematoma, reoperation, febrile morbidity, and other complications) in another study.^166^

The interpretation of these results remains unclear. The studies were not powered to test differences in the occurrence of rare perioperative outcomes. Two of the three studies were not randomized trials; because they did not account for potential differences in baseline fibroid size, selection bias could have potentially influenced outcomes for these two groups.

The two studies reporting on LAVH and abdominal hysterectomy^160,^ ^165^demonstrated improved outcomes for LAVH on a limited set of perioperative outcomes, namely hospital stay, convalescence, and use of analgesia. These studies were not powered to test differences in perioperative complications: one of the studies noted that the absence of statistically significant differences for wound infection could be attributed to insufficient sample size.^165^

The only study reporting outcomes on the comparison between LAVH and vaginal hysterectomy reported significantly worse outcomes for LAVH for hospital stay and total perioperative complications.^156,^ ^157^ Again, the evidence is limited to perioperative outcomes, and the sample size is underpowered to test for differences in individual perioperative complications.

Modifiers of Hysterectomy. We also reviewed the literature for modifiers of hysterectomy outcomes; we sought information on age, race or ethnicity, parity, breastfeeding, contraceptive choices, body habitus, insulin resistance, concurrent medical conditions such diabetes, and hormone replacement status. We found no evidence at all for these variables. We found some evidence of effect of uterine weight and certain procedures on hysterectomy outcomes, described below.

Two studies found worse outcomes with larger uterine weight.^160,^ ^167^ Three studies comparing interventions to reduce postoperative blood loss and improve postoperative hemoglobin found some evidence of effectiveness on an inconsistent group of outcomes such as operating time and number of ligations for bipolar electrocautery scissors compared with conventional scissors,^158^ estimated blood losses for vasopressin compared with placebo,^163^ and hemoglobin levels and rates of blood transfusion for preoperative therapy of recombinant human erythropoietin plus iron compared with iron alone.^47^

Complementary and Alternative Medicine. A single study of poor quality compared traditional Chinese medicine with standard medical management (progestational agents, oral contraceptives, or nonsteroidal anti-inflammatory drugs).^48^ The investigator reported significantly smaller fibroid size, greater proportion of women improved, and greater satisfaction with their treatment among women in the traditional Chinese arm. As noted in Chapter 3, the author reported potential biases from the differences in degree of motivation between the two groups. Therefore, we consider the available evidence to be weak (Level III).

### KQ 3: Outcomes of Treatment of Uterine Fibroids for Other Reasons

In clinical care, women are often advised to consider surgical intervention for fibroids to achieve the goals delineated in this KQ: (a) to improve fertility; (b) to reduce adverse pregnancy outcomes; (c) to prevent further growth; or (d) to rule out uterine malignancy. For the last two of these indications, there is no recent evidence. Prior reviews have suggested that surgery is not required for ruling out malignancy.^30^ However, as emphasized in KQ 1, little evidence is available about the incidence and prevalence of uterine fibroids and even less about the natural history of how fibroids change over time. Our evidence review team is not aware of any publications that would allow projection of risk that a particular fibroid will grow.

Pregnancy Outcomes. The strength of the evidence is weak (Level III) about interventions intended to improve ability to conceive and have a successful pregnancy. The 16 studies we identified studied pregnancy after myomectomy and were of fair to poor quality with the exception of a single clinical trial of good quality. This body of literature comprised predominantly case series and retrospective analyses. The majority of research is descriptive with no additional statistical analysis, conducted in clinical settings outside the United States, and focused on women with known infertility who conceived after specialized fertility care. The sole clinical trial with evidence comparing surgical intervention to none, without additional assisted reproductive technology care, supports benefit from removing fibroids that have a submucosal component (i.e., those in which the fibroid is immediately adjacent to or distorts the uterine cavity). The benefit reported was substantial (> 15 percent absolute increase in proportion of women becoming pregnant); however, the work is limited, by small study size, to reflecting only on ability to conceive and not other pregnancy outcomes. The group of studies identified was insufficient to assess risk of complications at the time of birth that could be related to myomectomy; uterine rupture was rare in these studies. The designs, populations, and documentation of methods (as well as failure to document) for these studies were so divergent that pooled analyses of the observational studies is inappropriate. However, even if all studies could be combined, they would be underpowered to estimate risk accurately. Virtually all studies that summarized cesarean rates documented rates above the national average in the United States (which is rising); however, these study populations received care in European settings and Japan, and this information cannot be meaningfully interpreted.

In summary, women with fibroids who hope to have a pregnancy soon or in the future are faced with difficult decisions about whether, and in what circumstances, to seek care for fibroids. When an exposure is common, such as fibroids, and distressing events are also common, such as difficulty conceiving or miscarriage, there is substantial risk of assuming a direct causal association that may be unwarranted; such assumptions call for careful investigation. Current research is meager for assisting women who do not have known fertility impairment in assessing the risks and benefits of intervention. Additional research in representative U.S. populations is essential.

Preventing Further Growth. We found no evidence on the effects of treatment to prevent further fibroid growth. However, concerns about further growth of fibroids after menopause limit the use of hormone replacement therapy to treat postmenopausal symptoms. We found five studies that provide moderate evidence (Level III) on the effects of menopausal hormone therapy on uterine fibroids. One study reports higher risks of first diagnosis of fibroids in peri- and postmenopausal women with a body mass index (BMI) less than 24 and 5 years or more of estrogen and progestogen therapy. Three of four studies reported no effect on fibroid size; one reported a higher rate of uterine growth with the percutaneous-oral schedule of hormone replacement therapy than with a single oral combination of oestradiol valerate and cyproterone acetate.

### KQ 4: Costs of Fibroid Treatment

The literature is limited in its evaluation of costs of the treatment of uterine fibroids. Included studies are retrospective in design and may not record all costs, inputs are heterogeneous, and sample sizes are very small. Studies from a single institution are necessarily limited in their generalizability, and insurance claims data are limited in their completeness. Two studies report on UAE costs and costs of other interventions. One compared the hospital, professional, and imaging costs for 23 UAE patients ($6,708 on average) with the same costs for 17 myomectomy patients ($7,630 on average);^172^ the other compared total hospital costs for 58 UAE patients ($8,223 per patient ) and 306 hysterectomy patients ($6,406 per patient).^173^ A third study reported on facility and professional costs of inpatient and outpatient abdominal myomectomy.^140^ The investigators reported that outpatient hysteroscopic myomectomy per patient ($4,291) was less than half the cost of inpatient abdominal myomectomy per patient ($8,860). They also found that, because of repeated procedures (at the rate of about 16.5 percent over 2 years), the mean overall cost rose from $6,737 for the initial procedure to a mean of $8,001 at 2 years for the repeat procedure.

In an attempt to estimate changes in the costs of treating uterine fibroids, we analyzed Healthcare Cost and Utilization Project (HCUP) data. As part of the HCUP's family of databases, the National Inpatient Sample (NIS) presents detailed information on individual inpatient visits, including diagnoses and procedures utilized. Figure 3 illustrates the rising costs of treating women with uterine fibroids, specifically those admitted with uterine fibroids as a primary diagnosis; we adjusted the figures to 2004 dollars. The average cost of uterine fibroid treatment increased by almost 30 percent between 1997 and 2004. In 1997, the average inpatient costs were $11,978; by 2004 the average costs had risen to $15,405. During the same period, the average length of stay dropped from 2.9 days to 2.6 days.

Figure 3. Average inpatient costs for treatment of uterine fibroids, by year

The source of increase in costs is unclear. Possible explanations include higher professional costs with procedures such as UAE and overall increase in health care costs relative to other costs. We found no information comparing average costs of procedural interventions with pharmaceutical treatments.

### KQ 5: Modifiers of Outcomes

KQ 5 asks about the short- and long-term outcomes of these treatment approaches (including risk of fibroid recurrence), modified by age, race or ethnicity, parity, breastfeeding, contraceptive choices, body habitus, insulin resistance, concurrent medical conditions such as diabetes, hormone replacement status, or other factors. Despite the relatively large number of studies reporting on modifiers of outcomes of treatment for fibroids (Table 23 to Table 26 below and Evidence Table 13 in Appendix C *), the wide range of modifiers and outcomes and the limited number of studies make the summative assessment of each modifier extremely challenging. In Chapter 3, we addressed each intervention and reported on modifiers of each intervention. In this section, we report all included evidence for each modifier. We note the specific relationship between modifier, intervention, and outcome within the table, and discuss overall issues of modifiers below.

* Appendixes cited in this report are provided electronically at http://ahrq.gov/clinic/tp/uteruptp.htm

Table 23 Patient demographics as modifiers of outcomes of fibroid treatment

Modifier | Author, Year | Intervention | Outcome | Direction of Effect
Age | McLucas et al., 2001^80^ | UAE | UAE failure | No association between age and UAE failure
| Kumakiri et al., 2005^147^ | Laparoscopic myomectomy | Pregnancy success | Pregnancy success is negatively correlated with age at myomectomy
| Spies, Ascher et al., 2001^92^ | UAE | Satisfaction with outcomes | No association between age and satisfaction
| Spies, Roth et al., 2002,^96^
| Spies, Bruno et al., 2005^93^
Race/ethnicity | Spies, Ascher et al., 2001^92^ | UAE | Satisfaction with outcomes | No association between race and satisfaction
| Spies, Roth et al., 2002,^96^
| Spies, Bruno et al., 2005^93^
| Worthington-Kirsch et al., 2005^100^ | UAE | Risk of adverse events by 30 days following procedure | Black women are more likely than other women to have an adverse event
Parity | Doridot et al., 2001^118^ | Laparoscopic myomectomy | Fibroid recurrence | Nulliparity is significantly associated with a higher risk of recurrence
| Hanafi et al., 2005^123^ | Myomectomy | Fibroid recurrence | Subsequent parity is significantly associated with reduced recurrence
| McLucas et al., 2001^80^ | UAE | UAE failure | No association between parity and UAE failure

UAE, uterine artery embolization.

Table 24 Health status characteristics as modifiers of outcomes of fibroid treatment

Modifier | Author, Year | Intervention | Outcome | Direction of Effect
Menopausal status | McLucas et al., 2001^80^ | UAE | UAE failure | No association between menopausal status and UAE failure
BMI | Roth et al., 2003^136^ | Abdominal myomectomy | Complications and transfusions | No association between BMI and complications and transfusions
Prior surgery/ surgical pathology | Huang et al., 2006^77^ | UAE | UAE failure | Prior myomectomy significantly increases the risk of UAE failure
| McLucas et al., 2001^80^ | UAE | UAE failure | Earlier pelvic surgery significantly associated with likelihood of UAE failure
| Roth et al., 2003^136^ | Abdominal myomectomy | Complications and transfusions | No association between prior abdominal surgery or adhesion and complications and transfusions
| Worthington-Kirsch et al., 2005^100^ | UAE | Risk of adverse events by 30 days following procedure | Prior procedures significantly predict the risk of an adverse event
Smoking status | Worthington-Kirsch et al., 2005^100^ | UAE | Risk of adverse events by 30 days following procedure | Smoking status significantly predicts the risk of an adverse event
Medical conditions | Roth et al., 2003^136^ | Abdominal myomectomy | Complications and transfusions | Comorbidities significantly predict complications and transfusions

BMI, body mass index; UAE, uterine artery embolization.

Table 25 Uterine and fibroid characteristics as modifiers of outcomes of fibroid treatment

Modifier | Author, Year | Intervention | Outcome | Direction of Effect
Uterine characteristics | Ferrari et al., 2000^160^ | Laparoscopically assisted vaginal hysterectomy | Laparotomy | Uterine size > 500 grams significantly predicts conversion to laparotomy
| Huang et al., 2006^77^ | UAE | UAE failure | No association between baseline uterine size and UAE failure
| Spies, Ascher et al., 2001^92^ | UAE | Satisfaction with outcomes | No association between baseline uterine volume and satisfaction
| Spies, Roth et al., 2002,^96^
| Spies, Bruno et al., 2005^93^
| McLucas et al., 2001^80^ | UAE | UAE failure | No association between uterine characteristics and UAE failure
Fibroid number | Doridot et al., 2001^118^ | Laparoscopic myomectomy | Fibroid recurrence | > 1 fibroid is significantly associated with a higher risk of recurrence
| Hanafi et al., 2005^123^ | Myomectomy by exploratory laparotomy | Fibroid recurrence | > 1 fibroid is significantly associated with fibroid recurrence compared with 1 fibroid
| Kumakiri et al., 2005^147^ | Laparoscopic myomectomy | Pregnancy | Positively correlated with number of removed fibroids
| Marziani et al., 2005^130^ | Hysteroscopic myomectomy | Control of menorrhagia | Higher numbers of fibroids are significantly associated with poorer control of menorrhagia postprocedure
| Roth et al., 2003^136^ | Abdominal myomectomy | Complications and transfusions | Higher numbers of fibroids significantly predict complications and transfusions
Fibroid size | Hanafi et al., 2005^123^ | Myomectomy by exploratory laparotomy | Fibroid recurrence | Fibroid size > 10 weeks is significantly associated with fibroid recurrence compared with fibroid size ≤ 10 weeks
| Huang et al., 2006^77^ | UAE | UAE failure | No association between baseline fibroid size and UAE failure
| Katsumori et al., 2005^175^ | UAE | Complications and menorrhagia | No effect of fibroid size on complications
| | | | Significantly greater improvement of menorrhagia likely with smaller fibroids
| Kumakiri et al., 2005^147^ | Laparoscopic myomectomy | Pregnancy | Size of fibroid removed positively predictive of conception
| Litta et al., 2005^69^ | GnRH versus no treatment prior to myomectomy | Blood loss and operating time | Increasing fibroid volume and weight associated with blood loss and operating time across groups
| Marret et al., 2006^129^ | Myomectomy | Laparotomy | Greater fibroid size significantly predicts more laparoconversions
| McLucas et al., 2001^80^ | UAE | UAE failure | Size of largest fibroid does not predict failure
| Munoz et al., 2003^132^ | Hysteroscopic myomectomy | Operative time | Fibroid size > 3 cm is significantly associated with longer procedure times
| Rajan et al., 2004^88^ | UAE | Intrauterine infection | No association between size of dominant fibroid and development of intrauterine infection
| Roth et al., 2003^136^ | Abdominal myomectomy | Complications and transfusions | Greater fibroid size significantly predicts complications and transfusions
| Pron, Bennett, Common, Sniderman et al., 2003^83^ | UAE | Decrease in fibroid volume | Larger fibroids more likely to have volume decrease
| Pron, Bennett, Common, Wall et al., 2003^84^
| Pron, Couchie, Soucie et al., 2003^85^
| Pron, Mocarski, Bennett et al., 2003^86^
| Pron, Mocarski, Cohen et al., 2003^87^
| Spies, Myers et al., 2005^95^ | UAE | Decrease in fibroid volume | Size of the dominant fibroid at baseline volume predicted less volume reduction at both 3 and 12 months after therapy
| Spies, Ascher et al., 2001^92^ | UAE | Satisfaction with outcomes | No association between baseline fibroid volume and satisfaction
| Spies, Roth et al., 2002,^96^ | | Decrease in fibroid volume | Size of the dominant fibroid at baseline volume predicted less volume reduction at 3 months after therapy
| Spies, Bruno et al., 2005^93^
Fibroid type | Marret et al., 2006^129^ | Myomectomy | Laparotomy | Intramural fibroid significantly predicts fewer laparoconversions
| Rajan et al., 2004^88^ | UAE | Intrauterine infection | Submucosal fibroids are more likely to be associated with intrauterine infections than nonsubmucosal fibroids; the relationship is not statistically significant in multivariate analysis
| Spies, Myers et al., 2005^95^ | UAE | Improvement in symptoms | Submucosal dominant fibroids predict significantly greater improvement in symptoms than subserosal fibroids
| Spies, Ascher et al., 2001^92^ | UAE | Volume reduction | Submucosal dominant fibroids predict significantly greater volume reduction than subserosal fibroids at 3 months, but not at 12 months
| Spies, Roth et al., 2002,^96^
| Spies, Bruno et al., 2005^93^

GnRH, gonadotropin-releasing hormone; UAE, uterine artery embolization.

Table 26 Provider and intervention characteristics as modifiers of outcomes of fibroid treatment

Modifier | Author, Year | Intervention | Outcome | Direction of Effect
Surgical skills | Marret et al., 2006^129^ | Myomectomy | Laparotomy | Greater experience significantly predicts fewer laparoconversions
| Lohle et al., 2006^79^ | EmboGold^®^ vs. Embospheres^®^ for UAE | Skin rash, return to usual activities, volume reduction, satisfaction, and fibroid expulsion | Similar volume reduction, satisfaction, and fibroid expulsion for both agents
| | | | Significantly greater risk of skin rash and slower return to usual activities with EmboGold^®^
Procedure characteristics | McLucas et al., 2001^80^ | UAE | UAE failure | No association between procedure characteristics (size of particles and particle load in UAE) and UAE failure
| Worthington-Kirsch et al., 2005^100^ | UAE | Risk of adverse events by 30 days following procedure | Greater length of procedure significantly predicts the risk of an adverse event
| Rajan et al., 2004^88^ | UAE | Intrauterine infection | No association between pre-procedure antibiotics, type of particles used, or vials of particles used and development of intrauterine infection
Post-procedure complications | McLucas et al., 2001^80^ | UAE | UAE failure | No association between complications and UAE failure
Subsequent interventions | Spies, Ascher et al., 2001^92^ | UAE | Satisfaction with outcomes | No association between subsequent interventions and satisfaction
| Spies, Roth et al., 2002^96^
| Spies, Bruno et al., 2005^93^

UAE, uterine artery embolization.

In Chapter 1, we presented a summary of risk factors for uterine fibroids. Few of the studies evaluated in this review address the modifying effects of these risk factors on the treatment of uterine fibroids. Many studies focus on patient demographics and fibroid characteristics as modifiers of fibroid treatment. Comparatively fewer studies address patient health characteristics or provider characteristics as modifiers of outcomes.

### KQ 6: Comparisons of Treatments

Several studies in our review compared different modalities of the same treatment—for example, different drug regimens for pharmaceutical management or different types of hysterectomy. From the point of view of clinical management, these studies do not address the larger issue of how to weigh outcomes across treatments; they weigh outcomes following the decision to choose a primary clinical pathway.

We previously discussed comparisons of modalities of a single treatment within each relevant section; this section singles out comparisons across treatments (Table 27 and Evidence Table 14 in Appendix C *). Ten studies compared different types of treatment. Of these, eight compared UAE with other treatments,^70,^ ^73,^ ^75,^ ^76,^ ^90,^ ^94,^ ^172,^ ^173^ one compared myomectomy with hysterectomy,^144^ and one compared traditional Chinese medicine with standard medical therapy.^48^ Two of the 10 studies report on cost.^70,^ ^173^

Table 27 Papers with direct comparisons of treatments

Author, Year | Direction of Effect
Comparisons of UAE and Myomectomy
Broder et al., 2002^70^ | Significantly higher risk of further invasive therapy (hysterectomy, myomectomy, or repeat UAE) in 3–5 years with UAE; no significant difference in worsening of symptoms; higher proportion dissatisfied with myomectomy, differences are not statistically significant at P < 0.05
Goodwin et al., 2006^73^ | Significantly fewer adverse events; shorter length of hospital stay, fewer days missed from work, and shorter time to resume normal activities with UAE; no difference in dominant fibroid volume, quality of life assessments, or menstrual bleeding scores
Razavi et al., 2003^90^ | Significantly fewer days of pain medication use, shorter length of stay, fewer complications, and fewer days to resume normal activities with UAE; significantly greater menorrhagia relief with UAE; no significant differences in bulk symptoms and proportion experiencing pain
Baker et al., 2002^172^ (Cost) | Higher overall costs with myomectomy; differences are not statistically significant at P< 0.05
Comparisons of UAE and Hysterectomy
Healey et al., 2004^75^ | No significant difference in ovarian function at 6 months following procedure
Hehenkamp et al., 2005^76^ | Significantly shorter procedure time and length of stay with UAE; no difference in operative complications; significantly more minor complications and readmissions with UAE
Spies et al., 2004^94^ | Significantly shorter procedure time and length of stay with UAE
Beinfeld, Bosch, Gazelle, 2002^173^ (Cost) | Significantly shorter length of stay with UAE; significantly higher costs with UAE
Comparison of Abdominal Myomectomy and Abdominal Hysterectomy
Vavilis, Togaridoce, Agorastos, 2005^144^ | No significant differences in febrile morbidity (other outcomes not reported)
Comparison of Chinese Traditional Medicine and Standard Medical Therapy
Mehl-Madrona, 2002^48^ | Significantly smaller fibroids, significantly greater proportion improved, and significantly higher proportion likely to be satisfied with Chinese traditional medicine

UAE, uterine artery embolization.

Four studies compared UAE with myomectomy.^70,^ ^73,^ ^90,^ ^172^ Of the three studies that addressed clinical outcomes,^70,^ ^73,^ ^90^only one study reported on the need for further invasive therapy; the study reported a much higher risk (adjusted odds ratio, 12.5; 95% confidence interval [CI], 1.4–110.1) of hysterectomy, myomectomy, or repeat UAE in the UAE group than in the myomectomy group.^70^ Two other studies in this group were consistent in reporting shorter procedure times and length of stay and fewer adverse events; the studies were also consistent in not finding statistically significant differences in symptoms.^73,^ ^90^ A single study reported a trend toward higher overall costs with myomectomy, although the differences were not statistically significant.^172^

Four studies compared UAE with hysterectomy. None of the studies that compared UAE outcomes and hysterectomy outcomes reported on the proportion of women in the UAE arm who had had to undergo additional treatment.^75,^ ^76,^ ^94^ Studies reporting procedure time and length of stay favored UAE, but the inconsistency of the direction of effect for complications and the absence of information on longer-term outcomes suggested that this evidence base is inadequate to comment on the relative risks and benefits of UAE versus hysterectomy. A study comparing costs of UAE with those of hysterectomy found that UAE, despite significantly shorter length of hospital stay, had significantly higher costs.^173^

As noted earlier, the only study in our review on complementary and alternative medicine (Chinese traditional medicine versus conventional therapy) favored Chinese traditional medicine, but it has distinctly different comparisons with an unknown degree of bias that would favor Chinese traditional medicine.^48^ We also note that our limitation to English-language studies limits our ability to summarize the evidence on Chinese traditional medicine.

### KQ 7: Geographic Variation in Treatment

We did not find any studies that reported on geographic variation in treatment within the United States (Level IV). We did not attempt to derive an estimate of variation in treatment from the studies that we included in our systematic review. These studies were generally conducted in academic medical centers; we could not assess the generalizability of their patterns of care for the broader population from which they were drawn.

## Limitations of the Evidence Base and This Review

### Limitations of the Evidence Base

The original systematic review on this topic highlighted several limitations of the literature.^30^ Specifically, those authors pointed out the paucity of data from randomized trials, the lack of comparability of women in nonrandomized trials, the lack of comparability of outcome measures, and the limited duration of followup. Six years after that report appeared, our update, which covers only “new” publications appearing in the intervening period, finds that most of these limitations continue. As documented above, most of the key questions posed for this update had Level III strength of evidence (weak); none had Level I (strong) evidence, only two had Level II (moderate) evidence (limited to intermediate outcomes of uterine size, procedure time, and length of hospital stay), and a dismaying number had no evidence (Level IV).

The lack of robust epidemiologic information over time on rates of incidence or prevalence of uterine fibroids among U.S. women is striking. What is available suggests that between 70 percent and 80 percent of women will experience fibroids (either symptomatic or asymptomatic) in their lifetimes, and the evidence that fibroids might shrink after menopause is not as solid as clinical opinion might have it. Moreover, little information is available, except for race (black women being more likely than white women to have fibroids), to clarify how the risk of fibroids might differ by sociodemographic or health characteristics.

The treatment literature is larger than the epidemiologic literature, but it is not of much better quality. Of the 102 studies we examined across all treatment modalities, only 35 were randomized trials, and only 20 were prospective cohorts. The prospective cohort studies in this review often did test for comparability of subjects. The remaining studies were either prospective case series or retrospective studies.

Studies continued to report on a wide variety of outcomes, often using unvalidated instruments. Most postprocedural studies focused on perioperative outcomes, although a small minority recorded long-term outcomes, with one study reporting on 5-year outcomes.^93^

The literature is further restricted in its ability to answer questions of immediate relevance to the management of uterine fibroids because only a small number of studies compared different types of fibroid management. Although several studies compared different types of hysterectomy, myomectomy, or pharmaceutical management, only 10 studies compared two different treatments. Of the remainder, a single RCT compared hysterectomy with myomectomy.

Finally, the cost data were quite meager; our analyses of HCUP data document a steady escalation in costs of procedural interventions. Because of the aggregate nature of these data, we cannot pinpoint the causes of these increases or whether they are associated with patient characteristics, particular types of treatments, or even secular increases in the cost of medical care in general.

### Limitations of the Review

As with the earlier review,^30^ we limited our search to articles published in English, primarily for reasons of time and resources. We acknowledge that our review of complementary and alternative medicine is likely to be significantly limited by this constraint. We also excluded case reports and case series with fewer than 100 women; as with the original review, our exclusion may have resulted in underreports of rare complications of fibroid treatment.

For similar time and resource reasons, we did not conduct dual independent, blinded review of articles for inclusion or abstraction of information into evidence tables. Instead, one reviewer performed the initial review, and a second reviewer examined that input and recommended changes or corrections when needed. These two reviewers reconciled any differences by consensus discussion. These procedures are generally in accord with the usual procedures for the RTI-UNC EPC. To enable us to address any systematic bias in our work that the above approach may have introduced, however, we did apply dual independent review for assessing the quality of individual articles and grading the strength of evidence.

The paucity of “similar” articles (populations, settings, patient characteristics, and outcomes measured) precluded any efforts to pool findings statistically.

## Future Research Directions

Key components of study design, analysis, and reporting are the leading weaknesses of the literature for every topic addressed in this systematic review. Overall, the literature identified is limited by the following gaps and problems.

### Ability To Assess Internal and External Validity

Key characteristics of populations studied (e.g., race/ethnicity, reproductive history) are not reported consistently. Many studies mix groups of women with varied indications for treatment without separately reporting outcomes or adjusting for differences among participants that may be confounders (e.g., age, smoking status, menopausal status). Furthermore, the dominance of European literature means that we cannot assume that processes of care and outcomes will be similar to those in the United States. Moreover, practice variation and outcomes have been shown in other areas of research such as cardiac care to have substantial variability within the United States and even within individual states and facilities. We see no reason to believe that such variation is not also at work in the care of fibroids; more and better information from U.S. studies is required to advance our understanding about this important women's health issue.

### Study Populations of Adequate Size for Assessing Key Outcomes

The majority of the studies reviewed were observational; they were not well suited to hypothesis testing or causal inference. Moreover, the small size of observational studies and clinical trials generally precluded both meaningful descriptive analysis of modifiers of outcomes and appropriate adjustment in multivariable models. Although most trials and many study designs, other than case series, reported power calculations, those calculations were most often linked to intermediate outcomes such as blood loss at surgery, length of hospital stay, or bleeding pattern at 3 months of medical therapy; generally, even with power calculations, the sizes of the samples precluded having adequate numbers of participants for the types of answers that are needed to inform women and their care providers about the critical questions raised for this report. Future research would be better able to provide such answers if funding agencies supported studies of adequate size to answer questions about resolution of symptoms, satisfaction with outcomes, recurrence or growth of fibroids, and further care needs at time horizons of a year and longer.

### Standard Nomenclature and Validated Measures

To advance knowledge, investigators need to adopt common classifications across the whole spectrum of operational definitions required for research. Several deficiencies introduce bias and handicap our ability to compare interventions and populations or aggregate data to estimate effect size and outcome probabilities. Three shortcomings are especially problematic: (1) failure to define operationally details such as inclusion and exclusion parameters and fibroid type or position in the uterus; (2) reliance on clinical measures such as estimated blood loss from operative reports or febrile morbidity from nursing notes; and (3) use of ad hoc measures of outcome that lack validity and reliability data (e.g., intuitively derived approaches to collecting data about success in controlling bleeding or altering bleeding patterns).

### Analysis Methods Matched to the Outcomes of Interest

Follow-up data that investigate topics such as time to return to work, maintenance of symptom control, recurrence of fibroids, subsequent surgery, and fertility and pregnancy outcomes should be addressed with analysis methods that explicitly incorporate time to event. Few studies used life table or hazard model approaches to reporting outcomes; even fewer used such advanced models either to assess for confounding of the relationship between the management received and outcomes or to investigate modifiers of outcomes.

### Direct Comparisons of Treatment Options

Randomized trials with common endpoints that reflect the treatment goals of women with fibroids must become a priority. New medical therapeutics are needed. Studies that are currently under way on antiprogestin and progestin treatments, if promising, should be rapidly followed by larger effectiveness and comparison studies. If such pharmacotherapies are introduced into the market, then population-level surveillance efforts will be required to examine safety across methods.

Although changing entrenched treatment patterns is often difficult, especially for surgical procedures that have been clinically available in varied forms for decades, trials must be done. Researchers would do well to incorporate into such trials comparisons of older methods with newer techniques such as UAE and MRI-guided ultrasound ablation, and endometrial ablation, because these therapies are currently unsupported by adequate data from controlled comparisons. When possible, such as for women without or with mild symptoms, trials should include a delayed treatment arm or expectant management group in order to better understand the natural history of fibroids and to examine the degree to which symptoms may wax and wane.

### Content Priorities

With the goal of achieving care tailored to the individual woman's fibroid status and characteristics, we need sophisticated information about a considerable array of issues. These include the burden of disease for both her and, possibly, her family; along with societal costs from loss of ability to function well in the usual family or occupational roles. Transitions associated with appearance of uterine fibroids, growth patterns, and influences on growth (e.g., concurrent medical conditions like diabetes, use of medications like hormonal contraception, influence of lactation and duration) are also high-priority topics, as are predictors of symptom development and resolution. Care-seeking behaviors and health and quality-of-life outcomes with and without treatment are yet other matters that investigators should attempt to address. Such data will also be required to examine the disparities between white and black women in the age at appearance of fibroids and in the number and size of fibroids, and we note as well the critical need for documenting fibroid status in other racial and ethnic groups. Variations in incidence, prevalence, and the natural course of fibroid development have potential to generate new hypotheses about etiology and such comparative studies must be pursued.

Current practice suggests that women without symptoms may forego intervention because of the general belief that care should be aimed at improving symptoms or addressing a specific clinical concern such as difficulty conceiving or recurrent pregnancy loss. Although foregoing intervention can be wise in the absence of data that the intervention will prevent future difficulties, nonetheless we emphasize that no data yet support expectant management as a “safe” choice; neither do any data indicate whether use of therapeutics short of surgery might forestall or prevent future changes in fibroids or appearance of symptoms.

The concept of preventive strategies is appealing. However, as long as the etiology of fibroids remains unclear and medical treatment choices are few, the prospect for dietary management, exercise, hormonal management, or other prevention trials is slim. The clinical research agenda will likely depend on new translational research and large-scale epidemiology studies that are yet to be done.

Much remains to be learned that will require large-scale prospective observational studies of sufficient size and rigor to support time-to-event analysis of outcomes. We emphasize in particular both the appearance of symptoms and the modifiers of risk of growth and symptoms. We must also invest in basic and translational research to understand the pathogenesis and pathophysiology of uterine fibroids. Such research is required to best guide selection of pathways for exploration of genetic determinants of the timing and severity of disease, gene-environment interactions that may influence onset and symptoms, proteomic and treatment targeting research, as well as to discover potential prevention strategies. Research effort must be focused on documenting first the course and consequences of uterine fibroids using optimal imaging strategies, then the modifiers of that course, so that we can offer women an accurate account of the likely outcome of expectant management based on their individual status.

## Conclusions

In accord with the prior systematic evidence review on management of uterine fibroids, we find a remarkable lack of high-quality evidence supporting the effectiveness of most interventions for symptomatic fibroids. Specifically notable is the lack of well-conducted trials in U.S. populations that provided direct comparisons among treatment options, including the option of expectant management, and that follow women to determine whether their objectives for treatment were met by the intervention received. Trials of preoperative medical management do support decrease in fibroid volume with treatment, but they do not provide sufficient evidence of improvement in important operative outcomes. The lack of available therapeutics for medical management without surgery is striking. Tremendously common procedures like hysterectomy and myomectomy, including the choice among types of myomectomy, still cannot be meaningfully compared. Appearance of new fibroids and growth of existing fibroids is poorly studied among the management options that leave the uterus in situ. Data to help women with fibroids who desire a pregnancy make treatment decisions are problematic because they originate in populations dominated by participants with known fertility impairments and adverse pregnancy outcomes. With these caveats, some evidence supports intervention for submucous fibroids via hysteroscopy when pregnancy is desired.

Across management options, we must note that lack of evidence is not equivalent to evidence of no benefit or of harm. Some of these interventions may well be effective in at least some patients. Research to assess how patient characteristics influence outcomes is also meager. Uncontrolled studies are notably biased for overestimating the degree of benefit subsequently reported in randomized trials. Indeed, not uncommonly, trials negate the findings of what in this case is largely retrospective and case series research. The current state of the literature does not permit definitive conclusions about benefit, harm, or relative costs to achieve similar results. Given how common and concerning fibroids can be to women and their care providers, a redoubled emphasis on promoting high-quality fibroid research in the United States is imperative. Women deserve better information to guide their choices.