# Methods

In this chapter, we document the procedures that the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop this comprehensive evidence report on management of uterine fibroids. We first describe our strategy for identifying articles relevant to our seven key questions, our inclusion and exclusion criteria, and the process we used to abstract relevant information from the eligible articles and generate our evidence tables. We also discuss our criteria for grading the quality of individual articles and for rating the strength of the evidence as a whole. Finally, we explain the peer-review process.

## Literature Review Methods

### Inclusion and Exclusion Criteria

Our inclusion and exclusion criteria are documented in Table 1. As noted in Chapter 1, this is an update of a systematic review originally published by the Agency for Healthcare Research and Quality (AHRQ) in 2001. Largely for that reason, we limited our searches to articles published in or after February 2000 through August 2006. We also restricted our searches to developed countries so that we could have data generally comparable to the standard of care in the United States.

Table 1 Inclusion/exclusion criteria for management of uterine fibroids

Category | Criteria
Study population | Women (all ages)
Study settings and geography | Developed nations: United States, Canada, United Kingdom, Western Europe, Scandinavia, Japan, Australia, New Zealand, Israel
Time period | February 2000 through August 2006
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible study designs]
| Controlled trials, prospective trials with historical controls, prospective or retrospective cohort studies, and medium-to-large case series (n > 100)
| [underlined: Other criteria]; - Original research studies must provide sufficient detail regarding methods and results to enable use and adjustment of the data and results.; - Patient populations must include women with uterine fibroids.; - Studies must address one or more of the following for uterine fibroids:; - Treatment modality; - Symptom management approach; - Short- and long-term outcomes and quality of life.; - Relevant outcomes must be able to be abstracted from data presented in the papers.; - Sample sizes must be appropriate for the study question addressed in the paper; single case reports or small case series (fewer than 100 subjects) are excluded.

We excluded studies that (1) were published in languages other than English (given the available time and resources); (2) did not report information pertinent to the key clinical questions; (3) had fewer than 40 subjects for randomized controlled trials (RCTs) or nonrandomized cohorts with comparisons or fewer than 100 subjects for case series; and (4) were not original studies.

For most of our key questions, the relevant population consists of women with fibroids. For KQ 3a and 3b, however, the relevant population is a subset of women with treatment for fibroids. For KQ 3a, on outcomes of treatment for enhancing fertility, and KQ 3b, on outcomes of treatment to reduce adverse pregnancy outcomes, the relevant subpopulation is women with treatment for fibroids who are attempting to get pregnant. For these two subquestions, we applied our sample size criterion to the relevant subpopulation of interest. To illustrate this strategy: assume that a publication about a cohort of 80 women with and without prior myomectomy reported treatment outcomes and 30 pregnancies but that it did not report the number of women trying to conceive. We would exclude this publication from KQ 3a and 3b (the section on enhancing fertility) but include it in KQ 2 (the section on treatment outcomes).

We included studies that did not provide a denominator (number attempting conception) but had sufficient pregnancies to infer that the denominator exceeded our size cutoff. To illustrate, we included case series examining the effect of assisted reproductive technologies on pregnancies that did not report the number attempting conception, if number of pregnancies was 100 or higher.

Our definitions of study design appear in Appendix B *.

* Appendixes cited in this report are provided electronically at http://ahrq.gov/clinic/tp/uteruptp.htm

### Literature Search and Retrieval Process

Databases. We used multifaceted search strategies to include current and valid research on the KQs, which we applied to three standard electronic databases—MEDLINE^®^, Cochrane Collaboration resources, and Embase. We also hand-searched the reference lists of relevant articles to make sure that we did not miss any relevant studies. We consulted with our Technical Expert Panel (TEP) about any studies or trials that are currently under way or that may not be published yet.

Search Terms. Based on the inclusion/exclusion criteria above, we generated a list of Medical Subject Heading (MeSH) search terms (Table 2 and Appendix A *). Our TEP also reviewed these terms to ensure that we were not missing any critical areas, and this list represents our collective decisions as to the MeSH terms used for all searches.

Table 2 MEDLINE® search strategy and unduplicated results

Search Terms | Search Results
#7 Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata | 13,887
#8 Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Field: All Fields, Limits: Publication Date from 2000, English, Humans | 2,584
#19 Search Editorial OR Letter OR Practice Guideline OR Review Limits: Publication Date from 2000, English, Humans | 547
#20 Search #8 NOT #19 Limits: Publication Date from 2000, English, Humans | 1,983

Our searches on EMBASE and Cochrane used the search term “Leiomyoma OR Fibroid^*^” and retrieved 3 and 52 citations, respectively, that had also been identified by our MEDLINE^®^ searches. Peer reviewers suggested an additional eight citations.

Figure 2 presents the yield and results from our searches, which we conducted from March through August 2006. Beginning with a yield of 1,991 articles, we retained 124 articles covering 107 studies that we determined were relevant to address our KQs and met our inclusion/exclusion criteria (Table 1). We reviewed titles and abstracts of the articles against the basic inclusion criteria above; we retained relevant articles, all published after our search cutoff date of February 2000, and used them as appropriate in the discussion in Chapter 4.

Figure 2. Disposition of articles for management of uterine fibroids

Article Selection Process. Once we had identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an Abstract Review Form (Appendix B *). If one abstractor concluded that the article should be included in the review, we retained it. The group included three physicians (Katherine Hartmann, MD, PhD, Scientific Director, Gretchen Stuart, MD, and Nicole Rankins, MD), one senior health services researcher (Meera Viswanathan, PhD, Study Director), and two junior health services researchers (Nikki McKoy, BS, and Patricia Thieda, MS).

Of this entire group of 1,991 articles, 201 required full review because of missing or uninformative abstracts. For the full article review, one reviewer read each article and decided whether it met our inclusion criteria, using a Full Text Inclusion/Exclusion Form (Appendix B *). Reasons for article exclusion are listed in Appendix D *.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The staff members who conducted this systematic review jointly developed the evidence tables. We designed the tables to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our KQs. We based the format of our evidence tables on successful designs that we have used for prior systematic reviews; we incorporated some elements of the tables in the prior review on uterine fibroids.^30^

We trained abstractors by having them abstract several articles into evidence tables and then reconvening as a group to discuss the utility of the table design. The abstractors repeated this process through several iterations until they decided that the tables included the appropriate categories for gathering the information contained in the articles.

All team members shared the task of initially entering information into the evidence tables. Another member of the team also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The two abstractors reconciled all disagreements concerning the information reported in the evidence tables. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process.

The final evidence tables are presented in their entirety in Appendix C *. Studies are presented in the evidence tables alphabetically by the last name of the first author. A list of abbreviations and acronyms used in the tables appears at the beginning of that appendix.

### Quality Rating of Individual Studies

Rating the Quality of Individual Articles. We developed our approach to assessing the quality of individual articles based on the prior review on management of uterine fibroids conducted by the Duke EPC;^30^ the rationale is that we wished to preserve as much consistency as appropriate between that review and this update. The original review assessed each study on a range of factors affecting internal and external validity and generally assigned “+” scores when studies met criteria, and “-” scores when studies did not, but it did not aggregate those factors into a single score. We made minor modifications to that earlier quality assessment list to allow us to construct an aggregate score; our final set of criteria is described below. Our final assessment of quality is based largely on the prior review, presented below in double-indented text, with our modifications, presented in regular text. We included citations from the prior review in the text below but recoded them to follow in numerical sequence in our own text and reference list.

Internal Validity. The criteria for assessing internal validity were as follows:

Randomized Allocation to Treatment. We modified the approach to this variable by combining randomization and method of randomization into a single criterion with a three-point scale. We employed the same rationale to evaluate this criterion, as follows (Matchar et al., 2001, pp.36–37):^30^

- Rationale: By randomly assigning groups to the intervention of interest, other factors that may confound the results are equally distributed between groups (assuming a large enough sample size). This equal distribution minimizes the chances of over- or underestimation of treatment effect based on unequal distribution of confounding factors.

If randomized, we evaluated the study for randomization methods, using the rationale described in Matcher et al., 2001, p.37:^30^

- Rationale: “Pseudo-randomization” methods may be susceptible to bias, as demonstrated by evidence of unequal distribution of subject characteristics^35^ and larger effect sizes compared with studies using more rigorous methods.^36^ In addition, methods of allocation concealment are also important in preventing bias (e.g., use of prepared sealed envelopes).

We combined these elements into a single operational definition, as described below:

- Operational definition: Criterion met if randomization methods were not susceptible to bias, such as computer-generated numbers in sealed envelopes (+). Criterion not met by studies that either used methods more prone to bias, such as alternate medical record numbers, or did not describe randomization methods or methods of allocation concealment (-). Criterion not applicable if treatment was not randomly allocated (NA).

We added a criterion to measure blinding.

Blinding.

- Rationale: Blinding, also known as masking, refers to the concealment of treatment allocation from the care provider, the assessor, and the patient. In certain trials, particularly surgical trials, masking the patient or the surgeon from the treatment allocation can be challenging or impossible. Similarly, masking the assessor assigned to record immediate postprocedural outcomes such as wound healing can also be difficult. Nevertheless, when possible, masking prevents expectations from influencing findings.
- Operational definition: Criterion met if at least assessors were blinded (+). Criterion not met if care provider, assessor, or patient were not blinded (-). Criterion not applicable if treatment was not randomly allocated or blinding was not possible (NA).

For adequate description of patients and controls, we relied on the scoring used by the prior review (Matcher et al., 2001, p.37).^30^ Unless otherwise specified, we followed the prior review's practice of assigning a ‘+’ for studies that met the criterion or ‘-’ for studies that did not meet the criterion:

Adequate Description of Patients and Controls.

- Rationale: Patient characteristics that might affect outcomes (such as obesity, prior surgery, or medical comorbidities) are likely to differ between two interventions. If these differences are not characterized, then erroneous conclusions may be drawn. For example, comparison of outcomes from a series of laparoscopic appendectomies with those from concurrent open appendectomies found better outcomes with the laparoscopic procedure.^37^ These differences were not seen when the same group performed a randomized trial, a finding attributable to differential patient selection criteria in the nonrandomized study.^38^
- Operational definition: Criterion met if (a) inclusion and exclusion criteria for participation in the study were described or (b) for nonrandomized studies, description of the rationale for selecting a particular intervention was given. Criterion not met if (a) inclusion/exclusion criteria were not described or (b) description of the rationale for selection of the interventions was not given (e.g., a nonrandomized comparison of concurrent laparoscopic and abdominal myomectomies that did not describe why patients received one or the other procedure).

We modified our reporting of the item on description of patient and control to account separately for missing versus inadequate inclusion and exclusion criteria. We assigned a ‘-’ score (negative) to studies with no description of inclusion and exclusion, a ‘+’ score to studies unable to control or account for confounding factors, and a ‘++’ score to studies able to control and account for confounding factors in patient selection through clear inclusion and exclusion criteria.

We did not include the prior review's item on description of loss to followup as an additional internal validity criterion, because we accounted for loss to followup in internal validity and appropriateness of length of followup in evaluating external validity. We retained other aspects of the prior review's internal validity assessment as follows:^30^ ^(p38)^

Description of Loss to Followup.

- Rationale: Failing to account for patients lost to followup may lead to erroneous conclusions, especially if the loss to followup is related to either the underlying disease or the intervention (e.g., patients seeking care elsewhere because of continuing symptoms or unacceptable side effects of treatment).
- Operational definition: Criterion met if (a) loss to followup was explicitly reported, (b) number of subjects for whom data were presented was equal to number of subjects receiving intervention at start of study, or (c) for studies reporting only hospital-based outcomes, number of missing charts or records was reported. Criterion not met if loss to followup was not reported and number of subjects at beginning and end of study was not equal.

Description of Dropout Rates.

- Rationale: Dropout rates may reflect differences in clinically important variables, such as side effects or treatment response. Failure to account for dropouts may result in erroneous conclusions similar to those seen with failure to account for loss to followup.
- Operational definition: Criterion met if (a) patients dropping out of the study prior to completion were reported or (b) number of subjects at beginning and end of study were equal. Criterion not met if patients dropping out were not reported and numbers of subjects at beginning and end of study were not equal. Criterion not applicable for studies reporting only hospital-based outcomes.

We made minor modifications to the assessment above by distinguishing among three loss-to-followup rates: <10 percent (++), 10 percent to 20 percent (+), and >20 percent (-). We also distinguished among dropout rates of <5 percent (++), 5 percent to 10 percent (+), and >10 percent (-).

Recognition and Description of Statistical Issues.

- Rationale: Use of inappropriate tests may lead to misleading conclusions. For example, variables such as blood loss, length of stay, or costs are often not normally distributed; use of means instead of medians when data may be affected by outlying observations can be misleading. Many studies, especially case series, may lack sufficient power to detect clinically important differences in outcomes or patient characteristics.
- Operational definition: Criterion met if (a) appropriate statistical tests were used (e.g., nonparametric methods for variables with nonnormal distributions, or survival analysis techniques to account for loss to followup and dropouts) and (b) potential study limitations regarding design and analysis, especially sample size and power issues, were discussed. Criterion not met if (a) inappropriate statistical tests were used or (b) study limitations were not discussed.

We modified this aspect of quality by crediting studies that accounted for crossover and loss to followup in intention-to-treat analysis.

External Validity. We also modeled our assessment of external validity on the earlier review. The criteria for assessing external validity were as follows:^30^ ^(pp39–42)^

Description of Age of Study Population.

- Rationale: The outcomes of many interventions are affected by patient age. Age is especially important in studies of reproductive disorders in women, since childbearing potential and ovarian hormone production, both key components in decisionmaking regarding management of fibroids, are directly related to age.
- Operational definition: Criterion met if summary statistics of subject age were given. Criterion not met if summary statistics were not given.

Description of Racial/Ethnic Distribution of Population.

- Rationale: The epidemiology, and possibly the biology, of fibroids clearly varies between white and black women. Additionally, there is widespread racial variation in the United States in utilization and outcomes of a wide variety of interventions.^39^
- Operational definition: Criterion met if (a) racial/ethnic distribution was described or (b) the geographical setting of the study strongly implied the racial/ethnic background of the entire population (e.g., studies of hysterectomy outcomes in Japan or Nigeria). Criterion not met if (a) racial/ethnic distribution was not described and (b) geographic setting was likely to include subjects of diverse racial/ethnic background.

Description of Pregnancy History of Population.

- Rationale: Pregnancy history may affect the natural history or biology of fibroids.^9^ For surgical interventions, pregnancy history may affect the technical difficulty of a procedure; for example, prior vaginal delivery may facilitate vaginal hysterectomy, while prior cesarean section, by increasing the risk of adhesions, may make either abdominal or vaginal hysterectomy more difficult.
- Operational definition: Criterion met if (a) summary statistics on gravidity or parity were given or (b) percentage of women with prior pregnancy was given. Criterion not met if (a) no summary statistics were given and (b) no distribution data on prior pregnancies were given.

Description of Prior Surgery.

- Rationale: A history of prior surgery for fibroids might reflect differences in the natural history or biology between patients. Additionally, previous abdominal surgery might increase the risk of complications by increasing the likelihood of intraperitoneal adhesions.
- Operational definition: Criterion met if (a) any description of history of intra-abdominal surgery was given or (b) proportion of women with prior surgery for fibroids was given. Criterion not met if no description of prior surgery was given.

We modified this criterion for studies of pharmaceutical management and complementary alternative medicine. For these studies, we assigned the category as ‘not applicable’ since surgical history was unlikely to influence the likelihood of complications.

Adequate Characterization of Fibroid and/or Uterine Size.

- Rationale: Individual fibroid size, or aggregate uterine size, may affect the nature or severity of symptoms, the response to various treatments, and the risk of complications of surgical treatments.
- Operational definition: Criterion met if data given on (a) uterine size in weeks of gestational age; (b) uterine volume, area, or length as estimated by radiologic techniques; (c) uterine weight in grams (for hysterectomy specimens); (d) fibroid diameter or volume as estimated by radiologic techniques; or (e) fibroid dimensions or weight based on pathological examinations. Criterion not met if none of the above were provided.

Adequate Characterization of Fibroid Number.

- Rationale: The number of fibroids may affect the nature or severity of symptoms, the response to various treatments, and the risk of complications of surgical treatments.
- Operational definition: Criterion met if summary statistics or distribution of number of fibroids was provided. Criterion not met if no data were provided on number of fibroids.

Adequate Characterization of Fibroid Location.

- Rationale: The location of fibroids may affect the nature or severity of symptoms, the response to various treatments, and the risk of complications of surgical treatments.
- Operational definition: Criterion met if (a) distribution of fibroids by location (subserosal, intramural, submucosal, or pedunculated) was given or (b) other anatomical descriptions were given (e.g., anterior, posterior, fundal, or within the broad ligament). Criterion not met if no anatomical description was given.

Adequate Characterization of Baseline Symptoms.

- Rationale: Because fibroids may present with a variety of symptoms, assessing the effectiveness of therapy requires an adequate description of the nature and severity of symptoms prior to institution of therapy.
- Operational definition: Criterion met if distribution of specific symptoms or symptom classes associated with fibroids were provided. Criterion not met if specific symptoms were not described (e.g., if the only description of inclusion criteria was “symptomatic fibroids”).

Adequate Description of Timing of Outcome Measurement.

- Rationale: Outcome measures may vary depending on when they are obtained. Description of when outcomes were measured facilitates comparison between studies.
- Operational definition: Criterion met if (a) time after initiation of therapy at which outcomes were measured was reported or (b) study was limited to hospital-based outcomes. Criterion not met if (a) time was not reported and (b) study was not strictly hospital-based.

We expanded the measure on adequacy of description of the timing of outcome measures to include appropriateness of the timing of outcome measures. Specifically, we assigned a ‘-’ score to studies that were missing descriptions of the length of followup, a ‘+’ score to studies that had insufficient followup to comment meaningfully on relevant outcomes, and a ‘++’ score to studies that had adequate length of followup.

Adequate Description of Methods Used for Outcome Measurement.

- Rationale: Comparison between studies requires common methods of measurement, which in turn requires adequate description of the methods used to assess comparability.
- Operational definition: Criterion met if (a) methods used to measure outcomes were adequately described or referenced (e.g., pain or bleeding scales), (b) definitions were given (e.g., description of outcomes classified as “complications”), or (c) outcomes were unambiguous (e.g., pregnancy, need for hysterectomy). Criterion not met if (a), (b), or (c) was not present.

Adequate Description of Validity and Reliability of Outcome Measurement.

- Rationale: Measurements of outcomes are only useful if changes in the outcome being measured are reflected in changes in the measurement (validity) and if these changes are reasonably consistent between the same observer measuring at different times or between different observers (reliability). For example, changes in a scale to assess menstrual blood flow should correlate with some other physiological measure of menstrual blood loss, and this correlation should be consistent when different women apply the same scale.
- Operational definition: Criterion met if (a) a description of the methods used to assess validity and reliability of at least one outcome measure was provided, (b) a reference to another article documenting validity and reliability was provided, or (c) only unambiguous outcomes such as pregnancy were included. Criterion not met if (a), (b), or (c) was not present.

Adequate Description of Clinical Care Provided to Subjects.

- Rationale: The ability to replicate study results is dependent on adequate description of methods. Additionally, readers should be aware of aspects of clinical care that might influence outcomes.
- Operational definition: Criterion met if (a) a detailed description of the therapy (dose, dosing schedule, and route of administration for medications and/or techniques for invasive therapies) was provided; (b) a reference to another publication describing the procedure was provided; or (c) statistical adjustment was made for likely sources of variation in clinical care (e.g., site where care was given, type of specialist providing care, individual provider). Criterion not met if (a), (b), or (c) was not provided.

Use of Previously Validated and Standardized Measures.

- Rationale: Use of measures used by other researchers enhances the ability to compare results across studies. Use of measures used with other medical conditions enhances the ability to compare the impact of uterine fibroids to that of other common conditions, which may be important when setting research and resource allocation priorities.
- Operational definition: Criterion met if at least one measure previously used by another group was used. Criterion not met if all measures were internally developed.

We then combined these scores into an aggregate measure of quality for internal and external validity (Table 3). To receive a rating of good overall, the study had receive good scores for both internal and external validity (that is, no negative scores and the lowest level of loss to followup or dropout). To receive a rating of fair overall, the study could receive a fair rating for both internal and external validity, or a mixed rating (good and fair, or good and poor) for internal and external validity. We assigned studies with one negative score for internal validity or intermediate loss to followup (10 percent to 20 percent), or intermediate dropout rate (5 percent to 10 percent) a rating of fair for internal validity. We assigned studies with one to three negative scores for external validity a rating of fair for external validity.

Table 3 Scoring algorithm for internal validity, external validity, and overall quality rating for individual studies

Definition and Scoring Algorithm* | Rating
Score Algorithm for Internal Validity Quality Rating
• No negative scores, lowest level of loss-to-followup score, and lowest dropout rate | Good internal validity
• One negative score, or intermediate loss-to-followup, or intermediate dropout rate | Fair internal validity
- Poor randomization, high loss-to-followup score, or high dropout rate OR; - Two negative scores OR; - One negative score and one intermediate loss-to-followup score or dropout rate | Poor internal validity
Score Algorithm for External Validity Quality Rating
• No negative scores | Good external validity
• One to three negatives scores | Fair external validity
• Four negatives scores | Poor external validity
Score Algorithm for Overall Quality Rating
•Good internal validity and good external validity | Good overall
- Fair internal validity and fair external validity OR; - Good internal validity and fair external validity OR; - Good internal validity and poor external validity OR; - Fair internal validity and good external validity OR; - Poor internal validity and good external validity | Fair overall
- Poor internal validity and poor external validity OR; - Fair internal validity and poor external validity OR; - Poor internal validity and fair external validity | Poor overall

*Negative scores are those scored ‘-.’

To receive a rating of poor overall, the study could receive a poor rating for both internal and external validity, or a mixed rating of fair and poor for internal and external validity. We considered poor randomization, high loss to followup (> 20 percent), or high dropout rates (> 10 percent) to be in the nature of fatal flaws, and we assigned these studies poor ratings for internal validity. Studies without these flaws that nevertheless received two or more negative scores for internal validity were also rated poor for internal validity. Studies with four or more negative scores for external validity were assigned a poor rating for external validity.

## Strength of Available Evidence

Our scheme follows the criteria applied in an earlier RTI-UNC EPC systematic review of systems for rating the strength of a body of evidence.^40^ That system included three domains: quality of the research, quantity of studies (including number of studies and adequacy of the sample size), and consistency of findings. Two senior staff members assigned grades by consensus.

We graded the body of literature for each KQ and present those ratings as part of the discussion in Chapter 4. The possible grades in our scheme are as follows:

I Strong: The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
II Moderate: The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
III Weak: The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
IV No evidence: No published literature.

## External Peer Review

As is customary for all evidence reports and systematic reviews done for AHRQ, the RTI-UNC EPC requested review of this report from a wide array of individual outside experts in the field, including our TEP, and from relevant professional societies and public organizations. AHRQ also requested review from its own staff. We sent 15 invitations for peer review: 7 TEP members, 3 relevant organizations, and 5 individual experts. Reviewers included clinicians (e.g., obstetrics and gynecology, reproductive endocrinology, family practice), representatives of federal agencies, advocacy groups, and potential users of the report.

We charged peer reviewers with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we had conceptualized and defined the topic and KQs. We also asked them to complete a peer review checklist. We received 9 responses in addition to comments from AHRQ staff. The individuals listed in Appendix E * gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate.