# Introduction

Uterine leiomyomata, or fibroids, are benign growths of smooth muscle and connective tissue anchored in the muscular wall of the uterus. Fibroids are the most common female pelvic tumor; their etiology is unknown. They develop from microscopic nests of uterine muscle cells and have been documented to be composed of numerous copies of the same or very few cells, which is termed monoclonal expansion. Clinically they may initially be detected as small nodules identified only by imaging studies; they can potentially progress through a spectrum of growth from grape size to large masses that can be palpated through the abdominal wall. Research is limited for the purposes of describing the typical fibroid because most data are derived from intervention studies in which the participants had sought treatment and further determined by the inclusion and exclusion criteria of the studies. With that caveat, fibroids documented in treatment studies are often in the size range of 2 to 7.5 centimeters or the dimensions of a large marble to modestly smaller than a baseball.

Clinical convention holds that symptoms and need for treatment are in large part related to a combination of type of fibroid, position within the uterus, and fibroid size. Fibroids are most often grouped as one of four types: submucous (beneath the mucosa, or uterine lining) are immediately adjacent to or jut into the uterine cavity; intramural are entirely within the wall of the uterus; subserous (beneath the serosa) distort the contour of the outer surface of the uterus; and pedunculated are attached to the uterus by a stalk. Some larger fibroids may have characteristics of each type, for instance distorting the interior of the uterus, occupying a component of the uterine wall, and distorting the external contour. Thus, in examining articles for systematic review, noting how authors have operationalized these categories for analysis is important.

Submucous fibroids are clinically described as having the greatest influence on irregular bleeding and reproductive outcomes because the fibroid may act as a physical irritant, much like a foreign body in the uterus, that interferes with the stability of the uterine lining, called endometrium, or with successful implantation of an embryo. Architectural explanations, such as overall enlargement of the uterus by the size and number of fibroids, are often used to describe why fibroids cause common symptoms like heavy menstrual bleeding. Position and size with respect to other structures such as the bladder, bowel, vaginal vault, and nerve bundles in the pelvis are most often used to explain bulk symptoms (i.e., pressure, urinary frequency, constipation or pain with bowel movements, pressure or pain with intercourse, and more generalized pain symptoms). Nonetheless, many fibroids across a large range of sizes do not cause symptoms. The factors that determine which women develop symptoms are unknown.

Fibroids have not been identified before onset of menses. Prevalence increases with age until the hormonal changes of menopause, after which new fibroids are rare.^1^–^4^ Developing a fibroid or multiple fibroids by the time of menopause is the rule rather than the exception; the cumulative incidence by age 49 is nearly 70 percent among white women and more than 80 percent among black women.^2^ Thus, across the reproductive years, most women whether with or without symptoms are developing fibroids from initial microscopic nests of monoclonal uterine muscle cells. Prevalence estimates, from clinical populations, range from 20 percent to 77 percent.^1,^ ^5,^ ^6^ The highest of these estimates is from a study that evaluated all hysterectomy specimens from a single institution by using 2 millimeter sections to detect even very small fibroids.^6^ The central challenge in understanding the onset of fibroids and their growth is the need for uniform documentation using imaging techniques in women, across a wide age spectrum and variety of reproductive histories.

## Risk Factors for Uterine Fibroids

Valid population-based estimates of fibroid prevalence in younger reproductive years, teens through 30s among U.S. women, are not yet available. Incidence is also poorly documented. However, cross-sectional studies, clinical databases, and case-control studies are investigating epidemiologic markers of risk of fibroids. Because fibroids arise after menarche and become largely quiescent after menopause, they clearly are subject to hormonal stimuli. Age at onset of menstrual cycles, a surrogate for cumulative exposure to menstrual cycle hormonal changes, is inconsistently associated with risk. In studies that find a relationship, younger age at menarche is associated with increased probability of having a diagnosis of fibroids.^7,^ ^8^ Parity has been consistently associated with a 20 percent to 40 percent reduction in risk of having fibroids, with risk declining as number of births increases.^7^–^17^ In addition, a birth after myomectomy (surgical removal of fibroids), compared with no further births, has been associated with reduced recurrence.^18^ The few studies that report on miscarriage or induced abortion^8,^ ^9,^ ^13,^ ^16^ show little or no evidence of a protective effect of these early pregnancy losses. One exception reported that induced abortion showed a protective association, but the study had no adjustment for parity.^9^ Protective associations with pregnancy do not appear to result from infertility among women with fibroids.^19^ Age at first birth categorized as ≥ 35 years has suggested a protective association with relative risk reductions of 40 percent to 50 percent.^7,^ ^10,^ ^13^ Shorter interval since last birth is also related to lower risk.^15,^ ^16,^ ^19^ Because age at first birth, age at last birth, and time since last birth are correlated, these factors would be expected to interact to determine risk. The direction of these associations suggests that the process of uterine renovation that occurs after term pregnancy may mitigate or resolve fibroids, but this has not been proven.

Links between contraceptive history and fibroids are inconsistent; most have focused on oral contraceptives because they expose women to pharmacologic levels of estrogen and progesterone. Taking into account interaction with use of gynecologic care (which increased likelihood of detection), Samadi and colleagues^12^ found that women who self-reported a diagnosis of fibroids were 4.3- to 5.0-fold more likely to have used oral contraceptives for 3 months or longer, adjusting for many other factors, including menopausal status and age at menarche but not for parity or other measures of reproductive history. Others have reported less pronounced associations of a 1.4–1.5-fold increase in fibroids for ever-use of these agents.^9,^ ^11^ In the Nurses Health Study cohort, risk was unrelated to current use and modestly associated with past use.^1^ Other reports have found no relationship^7,^ ^20^ or reduced risk.^8,^ ^10,^ ^21^ Because women with abnormal bleeding patterns or heavy menstrual bleeding may be treated with hormonal contraceptives, confounding by indication may also be at work when an association is seen.

Use of the intrauterine device (IUD) has been investigated based on an inflammatory, rather than a strictly hormonal, model of promotion of fibroid growth. A clinical case-control study found that women with fibroids had 5.3-fold greater odds (95% confidence interval [CI]: 1.8–16.3) of having had IUD use complicated by infection.^21^ Likewise, this study showed that a history of pelvic inflammatory disease and chlamydia were also associated with fibroids; however, models were not adjusted for parity or history of infertility.

African-American women have consistently been found to have a 2-fold or higher risk of fibroids than white women.^1,^ ^6,^ ^17,^ ^22^–^24^ However, as discussed below, such estimates may be confounded by other characteristics such as body weight and diabetes status. Baird and colleagues, using ultrasound assessment and pathology reports from a cohort of women ages 35 to 49 years randomly selected from registrants in a health maintenance organization, found that black women developed fibroids at younger ages and were more likely to have a clinical diagnosis and a hysterectomy.^22^ Overall, the odds of developing fibroids by age 50 were 2.9 times higher among blacks than whites. Less is known about the prevalence of fibroids among other minority women in the United States, although Asian and Hispanic women have been reported to have rates similar to those for whites.^1^

Body mass index (BMI) is associated with increased risk of fibroids,^9,^ ^10,^ ^25^ in a dose-response relationship, in most studies.^14,^ ^17^ Those that adjust for age and race or ethnicity found, at the extremes of their weight categories, that BMI ≥ 25.4 compared with ≤ 20.3, and ≥ 30.0 compared with < 20.0 were associated with 1.5- and 2.3-fold increase in odds, respectively.^17^ Other findings in large prospective cohorts suggest a more complex relationship.^14,^ ^26^ African-American women had lower risk at the extremes of BMI and had the highest adjusted incidence of fibroids for BMIs between 25 and 30; the influence was more pronounced among women who have had births.^26^ The effect of BMI was relatively modest: from 23 percent to 47 percent greater in the higher risk categories.^14,^ ^26^

The effect of race has been reported to be diminished when BMI enters multivariable models and vice versa,^12^ although others have found little influence of race. The risk estimate for incidence among African-American women from Baird and colleagues falls from 2.9 to 2.7, when adjusting for parity and BMI.^2^ A potential explanation for the influence of BMI is that both increased production of estrogens in peripheral body fat and increased risk of anovulatory cycles are associated with increasing body weight. Both mechanisms would increase cumulative estrogen exposure over time, in the latter case simultaneously decreasing exposure to progesterone because of an absence of the luteal phase (the second half of an ovulatory menstrual cycle in which progesterone levels peak).

Physical activity is also intimately related to body habitus, energy metabolism, sex steroid levels, and ovulatory function. Based on self-report of physical activity levels for recreation and household chores, the highest levels of activity compared with the lowest may be protective, reducing risk of having fibroids by 40 percent. The general trend for both African-American and white women is that increasing levels of activity were associated with lower risk.^27^ Hypertension and correlates of atherosclerosis and heart disease risk have also been related to likelihood of developing fibroids;^21,^ ^28,^ ^29^ such findings suggest either a common smooth muscle abnormality that promotes proliferation of uterine or vascular smooth muscle cells or direct damage to myometrium or vascular structures in the uterus from elevated blood pressure. In the Nurses Health Study prospective cohort, elevated blood pressure was linked to higher risk of clinical diagnosis of fibroids even after taking into account use of medical care and treatment with blood pressure medications.^28^

Smoking is associated with impaired production and reduced levels of endogenous circulating estrogens. This is a potential dual effect of direct inhibition by nicotine and of trends toward lower body weight among smokers. Smoking status has been variably reported to relate to fibroid risk in a fashion that fits this model; heavier smoking or longer histories of smoking (or both) have been linked to decreased risk of fibroids. The reductions in relative risk (adjusting for BMI, age, education, oral contraceptive use, and parity) range from 30 percent for ever smoked to approximately 50 percent for current smokers.^9,^ ^11^ Consistent with body weight as an important predictor, others have reported that the influence of smoking is not significant when BMI and reproductive factors are included in multivariable models.^17,^ ^19,^ ^28^

Each of these characteristics may influence risk of fibroids. Many others, which are biologically plausible and largely uninvestigated (e.g., genetic, environmental, and dietary factors), also have potential to modify the course and consequences of fibroids. We would expect that they would also influence treatment outcomes and risk of recurrence.

## Management of Uterine Fibroids

Conservatively estimated, 35 million women in the United States have uterine fibroids (www.census.gov/popest/national).^30^ Fewer than half are likely to have a diagnosis of fibroids made by a clinical care provider,^31^ in part because many women with fibroids have no symptoms.^2,^ ^31^ When symptomatic, fibroids can be linked to at least three major problems: (1) bleeding complaints including heavy menstrual cycles, irregular bleeding, and anemia; (2) mass effects related to the size and location of fibroids, including pelvic pressure or pain, urinary frequency, constipation or painful bowel movements, and discomfort or pain with intercourse; and (3) pregnancy complications that may include difficulty conceiving, increased miscarriage risk, and later complications such as preterm birth. These symptoms and consequences have been shown to diminish quality of life.^32^

Up to one in three women who receive a new diagnosis of fibroids have related surgery within the year.^33^ Indeed, fibroids are currently the leading indication for hysterectomy in the United States.^34^ Myomectomy—surgical removal of fibroids—is the second most common fibroid surgery.^34^

The proportions of women with fibroids likely to be receiving medical therapy to address symptoms are higher than those receiving surgery. In a large U.S. claims database, 34 percent of women with a new diagnosis of uterine fibroids filled prescriptions for hormone-based therapies (including oral contraceptives and other hormonal treatments) and 28 percent were given nonsteroidal anti-inflammatory agents (NSAIDS). Much smaller proportions (< 2 percent) were treated with hormone antagonists, such as gonadotropin-releasing hormone (GnRH) agonists, or with aggressive treatments for anemia such as erythropoietin injections, both most often used in preparation for surgery.^33^

Large-scale observational research has not yet identified target risk factors suitable for intervention to prevent, resolve, or reduce symptoms associated with uterine fibroids. Nonetheless, fibroids are common and often concerning for women and their health care providers, as well as costly to the individual and the health care system. Thus, this evidence review focuses on summarizing the evidence about currently available clinical management options and updating evidence about burden of disease, geographic variation in choice of treatment, and cost of care.

## Key Questions and Analytic Framework

### Key Questions

The first Agency for Healthcare Research and Quality (AHRQ) systematic review on the management of uterine fibroids was published in January 2001.^30^ That review found that the overall quality of the literature on the management of fibroids was poor, with almost no evidence to support the effectiveness of commonly recommended medical treatments. The review found consistent evidence from randomized trials that preoperative use of GnRH agonist therapy reduced estimated blood loss and may facilitate the surgical approach by reducing uterine size. The review also found that the outcomes of hysterectomy up to 2 years after surgery are favorable for most symptomatic women, although up to 12 percent of women develop new symptoms after surgery. The review did not attempt to deduce the clinical significance of these outcomes compared with outcomes of myomectomy, medical therapy, or no intervention, because of significant differences in the severity of preintervention disease. The prior review found almost no data to allow estimation of the overall costs of fibroids to the economy.

Since then, new treatment approaches, such as uterine artery embolization and ablation of fibroids via ultrasound guided by magnetic resonance imaging (MRI), have become available for management of uterine fibroids. More recent publications have also expanded the evidence base and may better reflect the variety of currently available medical management resources and the range of surgical interventions in use. New direct comparisons of different types of management approaches, as well as new research with longer lengths of followup of participants, have also become available.

The American College of Obstetricians and Gynecologists (ACOG) (the partner for this evidence report) proposed an update to the 2001 systematic review. ACOG developed the initial scope of this review; AHRQ forwarded it to the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC). The original work assignment proposed eight provisional questions for review; they recapitulate those of the original review.

The RTI-UNC EPC revised the proposed questions after discussions with internal technical staff, AHRQ staff, ACOG, and our Technical Expert Panel (TEP, see below). We aimed to allow a cross-walk between the 2001 report and this update while expanding the modalities considered and regrouping questions to result in chapters that better conform to the clinical care concerns confronting women and their care providers. The final seven key questions (KQs) are listed below.

KQ 1. What is the incidence and prevalence of uterine fibroids, as estimated in representative U.S. populations through use of diagnostic imaging or histology to document uniformly the presence or absence of fibroids? Among women with symptomatic fibroids, what are the incidence, type, and severity of symptoms?

KQ 2. Among women with symptomatic fibroids (e.g., anemia, problem bleeding patterns, bulk symptoms, pain, dyspareunia), what are the short- and long-term outcomes of the following treatment approaches or combinations of treatment approaches:

1 expectant management without intervention?
2 medical (pharmaceutical) management (including oral contraceptives, menopausal hormone therapy, GnRH agonist therapy, antiprogestins, progesterone-containing IUDs, and nonsteroidal anti-inflammatory drugs)?
3 uterine artery embolization?
4 endometrial ablation (with or without myomectomy)?
5 in situ destructive techniques (MRI-guided focused ultrasound and cryotherapy)?
6 myomectomy (abdominal, laparoscopic, and hysteroscopic)?
7 hysterectomy (abdominal, laparoscopic, vaginal)?
8 complementary and alternative therapies including acupuncture?

KQ 3. Among women with fibroids (symptomatic or asymptomatic), what are the short- and long-term outcomes of these treatment approaches when used with the objective of:

a enhancing fertility?
b reducing adverse pregnancy outcomes?
c preventing further growth?
d ruling out uterine malignancy?

KQ 4. What are the costs associated with fibroids care?

KQ 5. Are the short- and long-term outcomes of these treatment approaches (including risk of fibroid recurrence) modified by age, race or ethnicity, parity, breastfeeding, contraceptive choices, body habitus, insulin resistance, concurrent medical conditions such as diabetes, hormone replacement status, or other factors?

KQ 6. Where direct comparisons have been made between or among the treatment modalities of interest, which modalities achieve superior outcomes with respect to benefits, short- and long-term risks, quality of life, and costs?

KQ 7. Do rates of use of these treatments for fibroids vary geographically in the United States?

## Analytic Framework for the Management of Uterine Fibroids

The analytic framework in Figure 1 (i.e., the conceptual model developed to guide this systematic review) summarizes the critical topics addressed by this report and their links to the key questions. The KQs are noted on the boxes on arrows as appropriate; KQ 7, which is essentially derivative of KQ 1, is not shown. The starting population of interest is women with identified fibroids, with and without symptoms (KQs 1 and 2). Treatment choices have several objectives (KQ 3) and vary markedly (KQ 6), producing both benefits and harms (noted in the short and long run [far right boxes]); they also are associated with variable costs (KQ 4). We recognize that outcomes of fibroid therapy are modified by a host of medical and individual characteristics; we address a subset of these in KQ 5.

Figure 1. Analytic framework for management of uterine fibroids

BMI, body mass index; GnRH, gonadotropin-releasing hormone; IUD, intrauterine device; KQ, key question; MRI, magnetic resonance imaging; NSAIDs, non-steroidal anti-inflammatory drugs; Sx, symptom; Tx, treatment.

## Production of This Evidence Report

### Organization of This Evidence Report

Chapter 2 describes our methods, including our search strategies and inclusion/exclusion criteria; we also document our approach to grading the quality of articles and rating the strength of evidence. In Chapter 3, we present the results of our literature search and synthesis of retained articles by key question. Specifically, we address KQs 1, 2, 3, and 4, as they directly draw upon evidence. Chapter 4 further discusses the findings and addresses KQs 5, 6, and 7, as they are further analyses of the evidence presented in Chapter 3. Chapter 4 also presents our conclusions, and offers recommendations for future research.

Our references and included studies follow Chapter 4. Appendices include a detailed description of our search strings (Appendix A *), data collection forms (Appendix B *), detailed evidence tables (Appendix C *), excluded studies (Appendix D *), and acknowledgments (Appendix E *). Appendixes and evidence tables cited in this report are provided electronically at http://www.ahrq.gov.

* Appendixes cited in this report are provided electronically at http://ahrq.gov/clinic/tp/uteruptp.htm

### Technical Expert Panel (TEP)

We identified technical experts in the field of fibroid evaluation and treatment to provide assistance throughout the project. The TEP (see Appendix E *) was expected to contribute to AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts, including an ACOG representative. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and key questions at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria; and
- Provide input on the information and categories included in evidence tables.

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in professional societies and as practitioners in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Uses of This Report

This evidence report addresses the key questions outlined above using methods described in Chapter 2 to conduct a systematic review of published literature. We anticipate that the report will be of value to all women's health care providers, including ACOG (the original partner), the American Academy of Family Physicians, American Academy of Nurse Practitioners, and other clinical groups who care for women from menarche through the remainder of their lives, such as the American Society of Reproductive Medicine. In addition, this review will be of use to the National Institutes of Health, Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, and the Health Resources and Services Administration - all of which have offices or bureaus devoted to women's health issues. This report can bring practitioners up to date about the current state of evidence, and it provides an assessment of the quality of studies that aim to determine the outcomes of therapeutic options for the management of uterine fibroids. It will be of interest to individual women and the general public because of the high prevalence of fibroids and the recurring need for women and their health care providers to make the best possible decisions among numerous options. We also anticipate it will be of use to private sector organizations concerned with women's health, such as Our Bodies Ourselves, the National Women's Health Network, and the National Black Women's Health Imperative.

Researchers can obtain a concise analysis of the current state of knowledge in this field. They will be poised to pursue further investigations that are needed to understand the causes of fibroids, clarify risk factors, develop prevention strategies, develop new treatment options, and optimize the effectiveness and safety of clinical care.