# Appendix E. List of Peer Reviewers

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 5. We acknowledge the continuing support of Beth Collins Sharp, Ph.D., R.N. Acting Director of the AHRQ Evidence-Based Practice Center (EPC) Program and Stephanie Chang, M.D., M.P.H., the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, M.D., M.P.H.; EPC Literature Search Specialist, B. Lynn Whitener, Ph.D. We express our gratitude to Loraine Monroe, EPC word processing specialist, Jennifer Drolet, M.A., editor, and Tammeka Swinson, B.A., research specialist, at RTI International.

## Technical Expert Panel

We extend our appreciation to the members of our Technical Expert Panel (TEP), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEP members from the beginning of the project. TEP members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEP members are listed below (* also a peer review):

- Dr. Kevin Fiscella M.D., M.P.H.*
- Associate Professor, Associate Director
- Departments of Family Medicine and Community & Preventive Medicine
- University of Rochester School of Medicine & Dentistry,
- Rochester Center to Improve Communication in Health Care
- Building Relationships, Eliminating Disparities

- Dr. Miriam Kupperman Ph.D., M.P.H.*
- Professor
- University of California, San Francisco
- Department of Obstetrics, Gynecology & Reproductive Sciences

- Dr. Valerie Montgomery Rice, M.D.*
- Senior Vice-President Health Affairs and Dean, School of Medicine
- Meharry Medical College

- Dr. Evan Myers M.D., M.P.H.
- Professor (faculty)
- OB/GYN - Clinical & Epidemiologic Research Div
- Duke University Medical Center

- Dr. Vivian Pinn, M.D.
- Associate Director for Research on Women's Health
- Director, Office of Research on Women's Health
- National Institutes of Health
- Department of Health and Human Services

- Dr. Elizabeth Stewart, M.D.*
- Division of Reproductive Endocrinology and Infertility
- Mayo Clinic

- Dr. Howard Sharp, M.D.*
- Associate Professor and Chief
- General Division of Obstetrics and Gynecology
- University of Utah Health Sciences Center

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to Stephanie Chang, MD, MPH, Task Order Officer from AHRQ for contributing peer review comments. Our peer review panel also includes five members of the TEP. Peer review was a separate duty for these individuals and not part of their commitment as TEP members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- Donna D. Baird, Ph.D.
- Senior Investigator
- Epidemiology Branch
- National Institute of Environmental Health Sciences (NIEHS)

- Steven H. Eisinger, M.D.
- Professor
- Department of Family Medicine
- University of Rochester School of Medicine & Dentistry

- Hope Waltman
- President and Founder
- Hope for Fibroids, Inc.

- Donna Savage, M.Ed., ELS
- President
- Intelligent Fingers Writing & Editing