# Appendix D. List of Excluded Studies

## Excluded Articles

### Full Text Article Exclusion Criteria Codes for Database

X-1: Not original research

X-2: Not published from February 2000-February 2006

X-3: Not published in English

X-4: Study not conducted in appropriate geographic location

X-5: Ineligible study design

X-6: Study does not answer study question

CASE REPORT: Case report

## List of Excluded Studies

1 Women's Health and the Environment: The Next Century—Advances in Uterine Leiomyoma Research. Conference proceedings. 7–8 October 1999, Research Triangle Park, North Carolina, USA. Environ Health Perspect. 2000 Oct; 108 Suppl 5:767–853. X-1
2 Procedure minimizes need for hysterectomies. Rep Med Guidel Outcomes Res. 2000 Aug 3;11(16):8–10. X-1
3 The future of women's health. Harv Womens Health Watch. 2000 Jan;7(5):4–6. X-1
4 Uterine artery embolization for leiomyomata. Clin Privil White Pap. 2001 Jul 19(63):1–7. X-1
5 Leuprorelin and triptorelin: new indication. Preoperative treatment of uterine leiomyoma: no proven value. Prescrire Int. 2001 Jun;10(53):73–7. X-1
6 Gastrointestinal: gastric inflammatory fibroid polyp. J Gastroenterol Hepatol. 2001 Sep;16(9):1069. X-6
7 Alternatives to hysterectomy. Harv Womens Health Watch. 2001 Apr;8(8):5–7. X-1
8 Uterine artery embolization for treatment of symptomatic uterine fibroids. TEC Bull (Online). 2002 Jul 8;19(2):37–9. X-1
9 Stopping heavy periods. For some women, endometrial ablation is a viable alternative to hysterectomy. Health News. 2002 Aug;8(8):4. X-1
10 HRT patches: ok for women with fibroids? Health News. 2002 Feb;8(2):9. X-1
11 Patient page. Uterine fibroid embolization. Radiol Technol. 2003 Nov–Dec;75(2):176. X-1
12 Ultrasound treatment zaps fibroids. Health News. 2004 Aug;10(8):2. X-1
13 Medical image. Pseudocyesis. N Z Med J. 2004 Mar 12;117(1190):2 p following U801. X-6
14 Uterine artery embolization for fibroids. Med Lett Drugs Ther. 2005 Apr 11;47(1206):31–2. X-1
15 Noninvasive treatment for uterine fibroids. FDA Consum. 2005 Jan–Feb;39(1):4. X-1
16 Molecule of the month: asoprisnil. Drug News Perspect. 2005 Jul–Aug;18(6):404. X-1
17 Magnetic resonance-guided focused ultrasound therapy for symptomatic uterine fibroids. Technol Eval Cent Asses Program Exec Summ. 2005 Oct;20(10):1–3. X-1
18 Health highlights. Good news that greeted women in 2005. Mayo Clin Womens Healthsource. 2005 Dec;9(12):1–2. X-1
19 Can you tell me about the new device the FDA has approved for treating uterine fibroids? Mayo Clin Womens Healthsource. 2005 Apr;9(4):8.X-1
20 Abbas M, Al-Kandari M, FM Dashti. Laparoscopic-assisted resection of bleeding jejunal leiomyoma. Surg Endosc. Nov. 2001;15(11):1359. CASE REPORT. [pmid: 11727152].
21 Abdulkader I, Cameselle-Teijeiro J, Gude F, Fraga M, Varela-Duran J, Barreiro F, et al. Predictors of malignant behaviour in gastrointestinal stromal tumours: a clinicopathological study of 34 cases. Eur J Surg. 2002;168(5):288-96. X-6. [pmid: 12375611].
22 Aboyeji AP, Ijaiya MA. Uterine fibroids: a ten-year clinical review in Ilorin, Nigeria. Niger J Med. Jan–Mar. 2002;11(1):16-9. X-4. [pmid: 12073294].
23 Abramson S, Gilkeson RC, Goldstein JD, Woodard PK, Eisenberg R, Abramson N. Benign metastasizing leiomyoma: clinical, imaging, and pathologic correlation. AJR Am J Roentgenol. Jun. 2001;176(6):1409-13. CASE REPORT. [pmid: 11373202].
24 Abulafia O, Kleinhaus K, Levi G, Lee YC, Sherer DM. Effect of gonadotropin-releasing hormone agonist treatment upon angiogenesis in uterine leiomyoma. Gynecol Obstet Invest. 2001;52(2):108-13. X-6. [pmid: 11586038].
25 Adani GL, Marcello D, Sanna A, Mazzetti J, Anania G, Donini A. Gastrointestinal stromal tumours: evaluation of biological and clinical current opinions. Chir Ital. Mar–Apr. 2002;54(2):127-31. X-6. [pmid: 12038102].
26 Adelusola KA, Ogunniyi SO. Hysterectomies in Nigerians: histopathological analysis of cases seen in Ile-Ife. Niger Postgrad Med J. Mar. 2001;8(1):37-40. X-4. [pmid: 11487782].
27 Adolfsson PI, Haug I, Berg G, Svensson SP. Changes in beta(2)-adrenoceptor expression and in adenylyl cyclase and phosphodiesterase activity in human uterine leiomyomas. Mol Hum Reprod. Sep. 2000;6(9):835-42. X-6. [pmid: 10956556].
28 Advincula AP, Hernandez JC, Lieberman R. Images in reproductive medicine. Disseminated leiomyomatosis peritonei. Fertil Steril. Nov. 2005;84(5):1505-7. CASE REPORT. [pmid: 16275251].
29 Advincula AP, Song A, Burke W, Reynolds RK. Preliminary experience with robot-assisted laparoscopic myomectomy. J Am Assoc Gynecol Laparosc. Nov. 2004;11(4):511-8. X-5. [pmid: 15701195].
30 A. K. Agarwal, R. Bansal and D. Singhal. Sinonasal leiomyoma: report of 2 cases. Ear Nose Throat J. 2005 Apr;84(4):224, 226–30. CASE REPORT
31 Agoff SN, Grieco VS, Garcia R, Gown AM. Immunohistochemical distinction of endometrial stromal sarcoma and cellular leiomyoma. Appl Immunohistochem Mol Morphol. Jun. 2001;9(2):164-9. X-6. [pmid: 11396634].
32 Agoff SN, Mendelin JE, Grieco VS, Garcia RL. Unexpected gynecologic neoplasms in patients with proven or suspected BRCA-1 or -2 mutations: implications for gross examination, cytology, and clinical follow-up. Am J Surg Pathol. Feb. 2002;26(2):171-8. X-6. [pmid: 11812938].
33 Agorastos T, Dinas K, Patsiaoura K. Cystic degenerated angioleiomyoma mimicking ovarian pathology. Acta Obstet Gynecol Scand. Sep. 2001;80(9):863-5. CASE REPORT. [pmid: 11531639].
34 Agostini A, Banet J, Bretelle F, Cravello L, Blanc B. Leiomyoma remaining after vaginal hysterectomy for symptomatic leiomyomas. A case report. J Reprod Med. Feb. 2003;48(2):119-20. CASE REPORT. [pmid: 12621796].
35 Agostini A, Beerli M, Franchi F, Bretelle F, Blanc B. Garnerella vaginalis bacteremia after vaginal myomectomy. Eur J Obstet Gynecol Reprod Biol. Jun 10. 2003;108(2):229. CASE REPORT. [pmid: 12781418].
36 Agostini A, Vejux N, Capelle M, Ronda I, Blanc B. Laparoscopic removal of a remaining myoma after vaginal hysterectomy: a case report. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):372-3. CASE REPORT. [pmid: 16036202].
37 Ahamed KS, Raymond GS. Answer to case of the month #103. Large subserosal uterine leiomyoma with cystic degeneration presenting as an abdominal mass. Can Assoc Radiol J. Oct. 2005;56(4):245-7. CASE REPORT. [pmid: 16419377].
38 Ahmad A, Qadan L, Hassan N, Najarian K. Uterine artery embolization treatment of uterine fibroids: effect on ovarian function in younger women. J Vasc Interv Radiol. Oct. 2002;13(10):1017-20. X-4. [pmid: 12397123].
39 Ahmad I, Ray CE Jr, Conyers C. Transvaginal sonographic appearance of thrombosed uterine arteries after uterine artery embolization: the “white snake” sign. J Clin Ultrasound. Oct. 2003;31(8):401-6. X-5. [pmid: 14528437].
40 Ahmed AH, Martin D, Onon TS. Secondary abdominal pregnancy associated with uterine fibroid. J Obstet Gynaecol. Feb. 2005;25(2):206-8. CASE REPORT. [pmid: 15814414].
41 Ahmed M, Zangos S, Bechstein WO, Vogl TJ. Intravenous leiomyomatosis. Eur Radiol. Jul. 2004;14(7):1316-7. X-6. [pmid: 14710312].
42 Ahn WS, Kim KW, Bae SM, Yoon JH, Lee JM, Namkoong SE, et al. Targeted cellular process profiling approach for uterine leiomyoma using cDNA microarray, proteomics and gene ontology analysis. Int J Exp Pathol. Dec. 2003;84(6):267-79. X-6. [pmid: 14748746].
43 Ahsan S, Naeem S, Ahsan A. A case notes analysis of hysterectomy performed for non-neoplastic indications at Liaquat National Hospital, Karachi. J Pak Med Assoc. Oct. 2001;51(10):346-9. X-4. [pmid: 11768934].
44 Ak I, Ozalp S, Yalcin OT, Zor E, Vardareli E. Uptake of 2-[18F]fluoro-2-deoxy-D-glucose in uterine leiomyoma: imaging of four patients by coincidence positron emission tomography. Nucl Med Commun. Sep. 2004;25(9):941-5. X-4. [pmid: 15319600].
45 Akaeda T, Isaka K, Nakaji T, Kakizaki D, Abe K. Clinical application of virtual hysteroscopy by CO(2)-multidetector-row computed tomography to submucosal myomas. J Minim Invasive Gynecol. May–Jun. 2005;12(3):261-6. X-6. [pmid: 15922985].
46 Akase T, Onodera S, Jobo T, Matsushita R, Kaneko M, Tashiro S. A comparative study of the usefulness of toki-shakuyaku-san and an oral iron preparation in the treatment of hypochromic anemia in cases of uterine myoma. Yakugaku Zasshi. Sep. 2003;123(9):817-24. X-5. [pmid: 14513774].
47 Akinola OI, Fabamwo AO, Ottun AT, Akinniyi OA. Uterine artery ligation for management of uterine fibroids. Int J Gynaecol Obstet. Nov. 2005;91(2):137-40. X-5. [pmid: 16168993].
48 T. Akisue, K. Matsumoto, N. Tsumura, I. Fujita, T. Yamamoto and S. Yoshiya. Bone marrow edema syndrome associated with uterine myoma: a case report. Clin Orthop Relat Res. 2003 Apr(409):151–7. CASE REPORT
49 Aksu F, Gezer A, Oral E. Seventeen-year review of hysterectomy procedures in a university clinic in Istanbul (1985-2001). Arch Gynecol Obstet. Dec. 2004;270(4):217-22. X-4. [pmid: 14513260].
50 Al Azzam M, Orrell JM, Vasey DP. Vulval leiomyoma with a myxoid hyaline stroma. J Obstet Gynaecol. Nov. 2004;24(8):936. CASE REPORT. [pmid: 16147667].
51 Alam M, Rabinowitz AD, Engler DE. Gabapentin treatment of multiple piloleiomyoma-related pain. J Am Acad Dermatol. Feb. 2002;46(2 Suppl Case Reports):S27-9. CASE REPORT. [pmid: 11807464].
52 Alam NA, Barclay E, Rowan AJ, Tyrer JP, Calonje E, Manek S, et al. Clinical features of multiple cutaneous and uterine leiomyomatosis: an underdiagnosed tumor syndrome. Arch Dermatol. Feb. 2005;141(2):199-206. X-6. [pmid: 15724016].
53 Alam NA, Bevan S, Churchman M, Barclay E, Barker K, Jaeger EE, et al. Localization of a gene (MCUL1) for multiple cutaneous leiomyomata and uterine fibroids to chromosome 1q42.3-q43. Am J Hum Genet. May. 2001;68(5):1264-9. X-6. [pmid: 11283798]. [pmcid: 1226106].
54 Alam NA, Gorman P, Jaeger EE, Kelsell D, Leigh IM, Ratnavel R, et al. Germline deletions of EXO1 do not cause colorectal tumors and lesions which are null for EXO1 do not have microsatellite instability. Cancer Genet Cytogenet. Dec. 2003;147(2):121-7. X-6. [pmid: 14623461].
55 Alam NA, Olpin S, Rowan A, Kelsell D, Leigh IM, Tomlinson IP, et al. Missense mutations in fumarate hydratase in multiple cutaneous and uterine leiomyomatosis and renal cell cancer. J Mol Diagn. Oct. 2005;7(4):437-43. X-6. [pmid: 16237213]. [pmcid: 1888487].
56 Alam NA, Rowan AJ, Wortham NC, Pollard PJ, Mitchell M, Tyrer JP, et al. Genetic and functional analyses of FH mutations in multiple cutaneous and uterine leiomyomatosis, hereditary leiomyomatosis and renal cancer, and fumarate hydratase deficiency. Hum Mol Genet. Jun 1. 2003;12(11):1241-52. X-6. [pmid: 12761039].
57 Al-Badr A, Faught W. Uterine artery embolization in an undiagnosed uterine sarcoma. Obstet Gynecol. May. 2001;97(5 Pt 2):836-7. CASE REPORT. [pmid: 11336773].
58 Alenda C, Aranda FI, Paya A, Cordoba C. Mesectodermal leiomyoma of ciliary body. Int J Surg Pathol. Oct. 2002;10(4):309-12. CASE REPORT. [pmid: 12490985].
59 Alessi G, Lemmerling M, Vereecken L, De Waele L. Benign metastasizing leiomyoma to skull base and spine: a report of two cases. Clin Neurol Neurosurg. Jul. 2003;105(3):170-4. CASE REPORT. [pmid: 12860509].
60 Al-Fozan H, Dufort J, Kaplow M, Valenti D, Tulandi T. Cost analysis of myomectomy, hysterectomy, and uterine artery embolization. Am J Obstet Gynecol. Nov. 2002;187(5):1401-4. X-5. [pmid: 12439538].
61 Al-Hendy A, Lee EJ, Wang HQ, Copland JA. Gene therapy of uterine leiomyomas: adenovirus-mediated expression of dominant negative estrogen receptor inhibits tumor growth in nude mice. Am J Obstet Gynecol. Nov. 2004;191(5):1621-31. X-6. [pmid: 15547533].
62 Ali-El-Dein B, Abdel-Latif M, Mosbah A, Eraky I, Shaaban AA, Taha NM, et al. Secondary malignant involvement of gynecologic organs in radical cystectomy specimens in women: is it mandatory to remove these organs routinely?. J Urol. Sep. 2004;172(3):885-7. X-4. [pmid: 15310990].
63 Al-Kadri HM, Al-Turki HA, Saleh AM. Short and long term complications of abdominal and vaginal hysterectomy for benign disease. Saudi Med J. Jul. 2002;23(7):806-10. X-4. [pmid: 12174230].
64 Almeida EC, Nogueira AA, Candido dos Reis FJ, Rosa e Silva JC. Cesarean section as a cause of chronic pelvic pain. Int J Gynaecol Obstet. Nov. 2002;79(2):101-4. X-4. [pmid: 12427392].
65 Alper M, Aydin A, Ozdemir I, Suna M, Ciralik H, Aksoy KA. Blue nevus with an unusual presentation: two patients with endocervical location. Ceska Gynekol. Sep. 2004;69(5):411-3. X-4. [pmid: 15587900].
66 Alper M, Parlak AH, Kavak A, Aksoy KA. Bilateral multiple piloleiomyomas on the breast. Breast. Apr. 2004;13(2):146-8. CASE REPORT. [pmid: 15019696].
67 Al-Shanafey S, Cartier Y, Stiles GE, Casson AG. Circumferential giant leiomyoma of the esophagus. J Am Coll Surg. Oct. 2001;193(4):453. CASE REPORT. [pmid: 11584975].
68 Altinok G, Usubutun A, Kucukali T, Gunalp S, Ayhan A. Disseminated peritoneal leiomyomatosis. A benign entity mimicking carcinomatosis. Arch Gynecol Obstet. Jul. 2000;264(1):54-5. CASE REPORT. [pmid: 10985626].
69 Altman D, Lopez A, Falconer C, Zetterstrom J. The impact of hysterectomy on lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):418-23. X-5. [pmid: 14677004].
70 Alvarado-Cabrero I, Candanedo-Gonzalez F, Sosa-Romero A. Leiomyoma of the urethra in a Mexican woman: a rare neoplasm associated with the expression of estrogen receptors by immunohistochemistry. Arch Med Res. Jan–Feb. 2001;32(1):88-90. X-4. [pmid: 11388165].
71 Amagasaki K, Takeuchi N, Kakizawa T, Shimizu T. Bilateral cortical blindness associated with cerebral angiitis. Acta Neurochir (Wien). Jul. 2002;144(7):749. CASE REPORT. [pmid: 12181712].
72 Amant F, Debiec-Rychter M, Schoenmakers EF, Hagemeijer-Hausman A, Vergote I. Cumulative dosage effect of a RAD51L1/HMGA2 fusion and RAD51L1 loss in a case of pseudo-Meigs' syndrome. Genes Chromosomes Cancer. Dec. 2001;32(4):324-9. CASE REPORT. [pmid: 11746973].
73 Amant F, Dorfling CM, de Brabanter J, Vandewalle J, Vergote I, Lindeque BG, et al. A possible role of the cytochrome P450c17alpha gene (CYP17) polymorphism in the pathobiology of uterine leiomyomas from black South African women: a pilot study. Acta Obstet Gynecol Scand. Mar. 2004;83(3):234-9. X-4. [pmid: 14995917].
74 Amant F, Gabriel C, Timmerman D, Vergote I. Pseudo-Meigs' syndrome caused by a hydropic degenerating uterine leiomyoma with elevated CA 125. Gynecol Oncol. Oct. 2001;83(1):153-7. X-6. [pmid: 11585430].
75 Amant F, Huys E, Geurts-Moespot A, Lindeque BG, Vergote I, Sweep F, et al. Ethnic variations in uterine leiomyoma biology are not caused by differences in myometrial estrogen receptor alpha levels. J Soc Gynecol Investig. Feb. 2003;10(2):105-9. X-6.
76 Amant F, Steenkiste E, Schurmans K, Verbist L, Abeler VM, Tulunay G, et al. Immunohistochemical expression of CD10 antigen in uterine adenosarcoma. Int J Gynecol Cancer. Nov–Dec. 2004;14(6):1118-21. X-6. [pmid: 15571618].
77 Amato P, Roberts AC. Transient ovarian failure: a complication of uterine artery embolization. Fertil Steril. Feb. 2001;75(2):438-9. CASE REPORT. [pmid: 11172854].
78 Ambekar A, Vogelzang RL. Aberrant uterine artery as a cause of uterine artery embolization treatment failure. Int J Gynaecol Obstet. Jul. 2001;74(1):59-60. CASE REPORT. [pmid: 11430943].
79 Ameh EA, Shehu SM, Rafindadi AH, Nmadu PT. Small intestinal leiomyoma in childhood: a case report. West Afr J Med. Apr–Jun. 2002;21(2):157-8. CASE REPORT. [pmid: 12403042].
80 Amre R, Constantino J, Lu S, Charney D. Pathologic quiz case: a 52-year-old woman with a uterine mass. Leiomyo-adenomatoid tumor of the uterus. Arch Pathol Lab Med. Mar. 2005;129(3):e77-8. CASE REPORT. [pmid: 15737061].
81 Ande AB, Ehigiegba AE, Umeora OU. Repeat myomectomy at caesarean section. Arch Gynecol Obstet. Dec. 2004;270(4):296-8. CASE REPORT. [pmid: 14513259].
82 Andersen J. Comparing regulation of the connexin43 gene by estrogen in uterine leiomyoma and pregnancy myometrium. Environ Health Perspect. Oct. 2000;108(Suppl 5):811-5. X-6. [pmid: 11035987].
83 Andersen PE, Lund N, Justesen P, Munk T, Elle B, Floridon C. Uterine artery embolization of symptomatic uterine fibroida . Initial success and short-term results. Acta Radiol. Mar. 2001;42(2):234-8. X-5. [pmid: 11259954].
84 Anderson TD, Weinstein GS. Recurrent angiomyoma (vascular leiomyoma) of the larynx after laser excision. Otolaryngol Head Neck Surg. Nov. 2000;123(5):646-7. X-6. [pmid: 11077360].
85 Andre J, Theunis A, Richert B, de Saint-Aubain N. Superficial acral fibromyxoma: clinical and pathological features. Am J Dermatopathol. Dec. 2004;26(6):472-4. CASE REPORT. [pmid: 15618928].
86 Andrews RT, Binkert CA. Digital subtraction fluoroscopy to enhance visualization during uterine fibroid embolization. Cardiovasc Intervent Radiol. May–Jun. 2003;26(3):296-7. X-6. [pmid: 14562982].
87 Andrews RT, Bromley PJ, Pfister ME. Successful embolization of collaterals from the ovarian artery during uterine artery embolization for fibroids: a case report. J Vasc Interv Radiol. May. 2000;11(5):607-10. CASE REPORT. [pmid: 10834492].
88 Anichini C, Calamai G, Pedemonte E, Moroni M, Tozzini S, Nesi G. Intravenous leiomyoma with cardiac involvement. Int Angiol. Dec. 2001;20(4):345-7. CASE REPORT. [pmid: 11782702].
89 Ankem K. Influence of information sources on the adoption of uterine fibroid embolization by interventional radiologists. J Med Libr Assoc. Oct. 2003;91(4):450-9. X-6. [pmid: 14566376]. [pmcid: 209511].
90 Anker MC, Arnemann J, Neumann K, Ahrens P, Schmidt H, Konig R. Alport syndrome with diffuse leiomyomatosis. Am J Med Genet A. Jun 15. 2003;119(3):381-5. CASE REPORT. [pmid: 12784310].
91 Appiah-Sakyi K, Byrd L, Slade RJ. Thermal balloon ablation—a rare case of fibroid necrosis. J Obstet Gynaecol. Jun. 2004;24(4):467. CASE REPORT. [pmid: 15203602].
92 Aranovich D, Kaminsky O, Schindel A. Retroareolar leiomyoma of the male breast. Isr Med Assoc J. Feb. 2005;7(2):121-2. CASE REPORT. [pmid: 15729968].
93 Argibay Vazquez S, Lancha Hernandez C, Martinez Muniz A. Metastases in the sphenoidal sinus in a patient with papillary thyroid cancer. Clin Transl Oncol. Aug. 2005;7(7):324-7. CASE REPORT. [pmid: 16185596].
94 Arici A, Sozen I. Transforming growth factor-beta3 is expressed at high levels in leiomyoma where it stimulates fibronectin expression and cell proliferation. Fertil Steril. May. 2000;73(5):1006-11. X-6. [pmid: 10785229].
95 Arici A, Sozen I. Expression, menstrual cycle-dependent activation, and bimodal mitogenic effect of transforming growth factor-beta1 in human myometrium and leiomyoma. Am J Obstet Gynecol. Jan. 2003;188(1):76-83. X-6. [pmid: 12548199].
96 Arleo EK, Pollak J, Tal MG. Changing trends in gynecologists' opinions of uterine artery embolization for fibroids: the patient's perspective. J Vasc Interv Radiol. Dec. 2003;14(12):1559-61. X-5. [pmid: 14654491].
97 Armstrong PJ, Franklin DP. Pararenal vena cava leiomyosarcoma versus leiomyomatosis: difficult diagnosis. J Vasc Surg. Dec. 2002;36(6):1256-9. CASE REPORT. [pmid: 12469059].
98 Asakura H, Oda T, Tsunoda Y, Matsushima T, Kaseki H, Takeshita T. A case report: change in fetal heart rate pattern on spontaneous uterine rupture at 35 weeks gestation after laparoscopically assisted myomectomy. J Nippon Med Sch. Feb. 2004;71(1):69-72. CASE REPORT. [pmid: 15129599].
99 Ashby HE. The Ebony Sex Survey and the sex lives of African-American women: a call to healthcare providers. Ethn Dis. Spring. 2005;15(2 Suppl 2):S40-4. X-6. [pmid: 15822837].
100 Ashfaq R, Sharma S, Dulley T, Saboorian MH, Siddiqui MT, Warner C. Clinical relevance of benign endometrial cells in postmenopausal women. Diagn Cytopathol. Oct. 2001;25(4):235-8. X-6. [pmid: 11599107].
101 Aslan E, Kilicdag EB, Haydardedeoglu B, Yildirim T. Lipoleiomyoma of the uterus: A diagnostic problem. J Obstet Gynaecol. Aug. 2005;25(6):610-1. X-6. [pmid: 16234157].
102 Attilakos G, Fox R. Regression of tamoxifen-stimulated massive uterine fibroid after conversion to anastrozole. J Obstet Gynaecol. Aug. 2005;25(6):609-10. CASE REPORT. [pmid: 16234156].
103 Auguste T, Murphy B, Oyelese Y. Appendicitis in pregnancy masquerading as recurrent preterm labor. Int J Gynaecol Obstet. Feb. 2002;76(2):181-2. CASE REPORT. [pmid: 11818117].
104 Aung T, Goto M, Nomoto M, Kitajima S, Douchi T, Yoshinaga M, et al. Uterine lipoleiomyoma: a histopathological review of 17 cases. Pathol Int. Oct. 2004;54(10):751-8. X-6. [pmid: 15482564].
105 Aurea P, Grazia M, Petrella F, Bazzocchi R. Giant leiomyoma of the esophagus. Eur J Cardiothorac Surg. Dec. 2002;22(6):1008-10. CASE REPORT. [pmid: 12467830].
106 Aviram R, Ochshorn Y, Markovitch O, Fishman A, Cohen I, Altaras MM, et al. Uterine sarcomas versus leiomyomas: gray-scale and Doppler sonographic findings. J Clin Ultrasound. Jan. 2005;33(1):10-3. X-6. [pmid: 15690441].
107 Avritscher R, Iyer RB, Ro J, Whitman G. Lipoleiomyoma of the uterus. AJR Am J Roentgenol. Oct. 2001;177(4):856. CASE REPORT. [pmid: 11566688].
108 Aydin A, Tekin F, Gunsar F, Tuncyurek M. Gastric inflammatory fibroid polyp. Gastrointest Endosc. Nov. 2004;60(5):802-3. CASE REPORT. [pmid: 15557964].
109 Ayoubi JM, Fanchin R, Ferretti G, Pons JC, Bricault I. Three-dimensional ultrasonographic reconstruction of the uterine cavity: toward virtual hysteroscopy?. Eur Radiol. Aug. 2002;12(8):2030-3. X-6. [pmid: 12136321].
110 Aziz N, Lenzi TA, Milki AA. Severe intrauterine growth restriction associated with the development of a submucosal leiomyoma during pregnancy: a case report. J Reprod Med. Jul. 2005;50(7):553-6. CASE REPORT. [pmid: 16130857].
111 Azzie G, Bensoussan A, Spitz L. The association of anorectal leiomyomatosis and diffuse oesophageal leiomyomatosis. Pediatr Surg Int. Aug. 2003;19(6):424-6. CASE REPORT. [pmid: 12942269].
112 Baba K, Ishihara O, Hayashi N, Saitoh M, Taya J, Kinoshita K. Where does the embryo implant after embryo transfer in humans?. Fertil Steril. Jan. 2000;73(1):123-5. X-6. [pmid: 10632425].
113 Baba K, Kobayashi K, Hayashi M, Kozuma S, Takeda S, Kinoshita K. Extended field-of-view ultrasound imaging in obstetrics and gynecology: preliminary experience. Ultrasound Obstet Gynecol. Feb. 2000;15(2):157-9. X-6. [pmid: 10776002].
114 Baek WK, Kim D, Jung N, Yi YW, Kim JM, Cha SD, et al. Increased expression of cyclin G1 in leiomyoma compared with normal myometrium. Am J Obstet Gynecol. Mar. 2003;188(3):634-9. X-6. [pmid: 12634633].
115 Bai SW, Jang JB, Lee do Y, Jeong KA, Kim SK, Park KH. Uterine arterial embolization for the treatment of uterine leiomyomas. Yonsei Med J. Jun. 2002;43(3):346-50. X-4. [pmid: 12089743].
116 Baird DD. Invited commentary: uterine leiomyomata-we know so little but could learn so much. Am J Epidemiol. Jan 15. 2004;159(2):124-6. X-1. [pmid: 14718212].
117 Baird DD, Dunson DB. Why is parity protective for uterine fibroids?. Epidemiology. Mar. 2003;14(2):247-50. X-5. [pmid: 12606893].
118 Baird DD, Newbold R. Prenatal diethylstilbestrol (DES) exposure is associated with uterine leiomyoma development. Reprod Toxicol. May–Jun. 2005;20(1):81-4. X-6. [pmid: 15808789].
119 Bajaj P, Kumar G, Agarwal K. Lipoleiomyoma of broad ligament: a case report. Indian J Pathol Microbiol. Oct. 2000;43(4):457-8. CASE REPORT. [pmid: 11344612].
120 Bajo A, Carrero I, Hristov RL, Valenzuela P, Martinez P, Cortes J, et al. Impairment of adenylate cyclase activity and G-proteins in human uterine leiomyoma. Tissue Cell. Oct. 2000;32(5):399-404. X-6. [pmid: 11201279].
121 Baker PM, Moch H, Oliva E. Unusual morphologic features of endometrial stromal tumors: a report of 2 cases. Am J Surg Pathol. Oct. 2005;29(10):1394-8. CASE REPORT. [pmid: 16160484].
122 Balci NC, Radjazi S, Polat H. Adult intussusception secondary to inflammatory fibroid polyp: demonstration by MRI. Eur Radiol. 2000;10(11):1708-10. CASE REPORT. [pmid: 11097392].
123 Ballard L, Lyon DS, Jones JL. Inpatients with menometrorrhagia: etiologies, treatments, and outcomes. South Med J. Jun. 2000;93(6):571-4. X-5. [pmid: 10881771].
124 Banas T, Klimek M, Fugiel A, Skotniczny K. Spontaneous uterine rupture at 35 weeks' gestation, 3 years after laparoscopic myomectomy, without signs of fetal distress. J Obstet Gynaecol Res. Dec. 2005;31(6):527-30. CASE REPORT. [pmid: 16343253].
125 Banerjee K, Datta Gupta S, Mathur SR. Vaginal angiomyofibroblastoma. Arch Gynecol Obstet. Sep. 2004;270(2):124-5. CASE REPORT. [pmid: 15449071].
126 Banerjee K, Mittal S, Mishra R, Gulati MS, Gupta SD. Bladder leiomyoma: rare presentation as a pelvic mass. J Obstet Gynaecol Res. Aug. 2003;29(4):239-42. CASE REPORT. [pmid: 12959145].
127 Banovac F, Ascher SM, Jones DA, Black MD, Smith JC, Spies JB. Magnetic resonance imaging outcome after uterine artery embolization for leiomyomata with use of tris-acryl gelatin microspheres. J Vasc Interv Radiol. Jul. 2002;13(7):681-8. X-5. [pmid: 12119326].
128 Bapuraj JR, Suri S, Sidhu R, Nadh OV, Vasistha K. Uterine artery embolisation for the treatment of symptomatic uterine fibroids: short-term results of work in progress. Aust N Z J Obstet Gynaecol. Nov. 2002;42(5):508-12. X-4. [pmid: 12495096].
129 Barbarisi A, Petillo O, Di Lieto A, Melone MA, Margarucci S, Cannas M, et al. 17-beta estradiol elicits an autocrine leiomyoma cell proliferation: evidence for a stimulation of protein kinase-dependent pathway. J Cell Physiol. Mar. 2001;186(3):414-24. X-6. [pmid: 11169981].
130 Barisic D, Bagovic D. A single, continuous spiraling suture for uterine wall reconstruction after laparoscopic enucleation of intramural myomas. J Am Assoc Gynecol Laparosc. Aug. 2001;8(3):409-11. X-5. [pmid: 11509783].
131 Barker KT, Bevan S, Wang R, Lu YJ, Flanagan AM, Bridge JA, et al. Low frequency of somatic mutations in the FH/multiple cutaneous leiomyomatosis gene in sporadic leiomyosarcomas and uterine leiomyomas. Br J Cancer. Aug 12. 2002;87(4):446-8. X-6. [pmid: 12177782].
132 Barnes SJ, van Pettius DG, Maffulli N. Angioleiomyoma of the Achilles tendon. Bull Hosp Jt Dis. 2003;61(34):137-9. CASE REPORT. [pmid: 15156814].
133 Baron JA, Weiderpass E, Newcomb PA, Stampfer M, Titus-Ernstoff L, Egan KM, et al. Metabolic disorders and breast cancer risk (United States). Cancer Causes Control. Dec. 2001;12(10):875-80. X-6. [pmid: 11808705].
134 Barrett JC, Davis BJ, Bennett LM. Pregnancy and protection from hormonally associated tumor development. Epidemiology. Mar. 2003;14(2):139-40. X-1. [pmid: 12606877].
135 Barth MM, Spies JB. Ovarian artery embolization supplementing uterine embolization for leiomyomata. J Vasc Interv Radiol. Sep. 2003;14(9 Pt 1):1177-82. X-5. [pmid: 14514810].
136 Baruah S, Sturdee DW. The myomatous erythropoiesis syndrome. J Obstet Gynaecol. Nov. 2004;24(8):934-5. CASE REPORT. [pmid: 16147665].
137 Baschinsky DY, Isa A, Niemann TH, Prior TW, Lucas JG, Frankel WL. Diffuse leiomyomatosis of the uterus: a case report with clonality analysis. Hum Pathol. Nov. 2000;31(11):1429-32. X-6. [pmid: 11112221].
138 Bashir R, Parveen Z, Sultana R, Khan B. A two years audit of complications of hysterectomy at Ayub Teaching Hospital Abbottabad. J Ayub Med Coll Abbottabad. Apr–Jun. 2005;17(2):47-9. X-4. [pmid: 16092651].
139 Baskett TF. Hysterectomy: evolution and trends. Best Pract Res Clin Obstet Gynaecol. Jun. 2005;19(3):295-305. X-1. [pmid: 15985249].
140 Basso N, Rosato P, De Leo A, Picconi T, Trentino P, Fantini A, et al. Laparoscopic treatment of gastric stromal tumors. Surg Endosc. Jun. 2000;14(6):524-6. X-6. [pmid: 10890957].
141 Baugh W, Quigley MM, Barrett TL. Palisaded angioleiomyoma. J Cutan Pathol. Nov. 2000;27(10):526-8. CASE REPORT. [pmid: 11100812].
142 Bayer-Garner I, Morgan M, Smoller BR. Caveolin expression is common among benign and malignant smooth muscle and adipocyte neoplasms. Mod Pathol. Jan. 2002;15(1):1-5. X-6. [pmid: 11796834].
143 Bays D, Anagnostopoulos GK, Katsaounos E, Filis P, Missas S. Inflammatory fibroid polyp of the small intestine causing intussusception: a report of two cases. Dig Dis Sci. Oct. 2004;49(10):1677-80. CASE REPORT. [pmid: 15573926].
144 Bazot M, Cortez A, Darai E, Rouger J, Chopier J, Antoine JM, et al. Ultrasonography compared with magnetic resonance imaging for the diagnosis of adenomyosis: correlation with histopathology. Hum Reprod. Nov. 2001;16(11):2427-33. X-6. [pmid: 11679533].
145 Beal DR, Titball RW, Lindsay CD. The development of tolerance to Clostridium perfringens type D epsilon-toxin in MDCK and G-402 cells. Hum Exp Toxicol. Nov. 2003;22(11):593-605. X-6. [pmid: 14686482].
146 Becker E Jr, Lev-Toaff AS, Kaufman EP, Halpern EJ, Edelweiss MI, Kurtz AB. The added value of transvaginal sonohysterography over transvaginal sonography alone in women with known or suspected leiomyoma. J Ultrasound Med. Mar. 2002;21(3):237-47. X-6. [pmid: 11883534].
147 Becker ER, Spalding J, DuChane J, Horowitz IR. Inpatient surgical treatment patterns for patients with uterine fibroids in the United States, 1998-2002. J Natl Med Assoc. Oct. 2005;97(10):1336-42. X-6. [pmid: 16353655]. [pmcid: 2594714].
148 Bedaiwy MA, Paraiso MF. Pelvic organ prolapse after uterine artery embolization for uterine myoma. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):214-5. CASE REPORT. [pmid: 15168005].
149 Beer TW. Cutaneous angiomyolipomas are HMB45 negative, not associated with tuberous sclerosis, and should be considered as angioleiomyomas with fat. Am J Dermatopathol. Oct. 2005;27(5):418-21. CASE REPORT. [pmid: 16148412].
150 Begum S, Khan S. Audit of leiomyoma uterus at Khyber teaching hospital Peshawar. J Ayub Med Coll Abbottabad. Apr–Jun. 2004;16(2):46-9. X-4. [pmid: 15455617].
151 Beissert M, Kenn W, Schultz G, Keberle M, Eck M, Hahn D. Hepatic angiomyoma: CT and MRI findings. Abdom Imaging. Jan–Feb. 2002;27(1):40-2. CASE REPORT. [pmid: 11740605].
152 Bekker G, Gavrilescu T, Rickets-Holcomb L, Puka-Khandam P, Akhtar A, Ansari A. Symptomatic fibroid uterus in a 15-year-old girl. Int Surg. Apr–Jun. 2004;89(2):80-2. CASE REPORT. [pmid: 15285238].
153 Belenky A, Cohen M, Bachar GN. Uterine arterial embolization for the management of leiomyomas. Isr Med Assoc J. Oct. 2001;3(10):719-21. X-5. [pmid: 11692543].
154 Bennett ES, Arora NS, Kay M, Robinson TT, Fergus I. Intracardiac leiomyomatosis: iliac vein to right-ventricular outflow tract. Nat Clin Pract Cardiovasc Med. Jul. 2005;2(7):369-72. quiz 373. CASE REPORT. [pmid: 16265563].
155 Benson CB, Chow JS, Chang-Lee W, Hill JA 3rd, Doubilet PM. Outcome of pregnancies in women with uterine leiomyomas identified by sonography in the first trimester. J Clin Ultrasound. Jun. 2001;29(5):261-4. X-6. [pmid: 11486319].
156 Bentes de Souza AM, Rogers MS, Wang CC, Yuen PM, Ng PS. Comparison of peritoneal oxidative stress during laparoscopy and laparotomy. J Am Assoc Gynecol Laparosc. Feb. 2003;10(1):65-74. X-5. [pmid: 12554997].
157 Bergamini V, Ghezzi F, Cromi A, Bellini G, Zanconato G, Scarperi S, et al. Laparoscopic radiofrequency thermal ablation: a new approach to symptomatic uterine myomas. Am J Obstet Gynecol. Mar. 2005;192(3):768-73. X-5. [pmid: 15746670].
158 Berhan Y, Isehak A, Legesso S, Tsegaye B. Pseudo-Meig's syndrome: parasitic leiomyoma with ascites in a 52-year old lady. Ethiop Med J. Oct. 2003;41(4):363-6. X-4. [pmid: 15296418].
159 Bernard G, Darai E, Poncelet C, Benifla JL, Madelenat P. Fertility after hysteroscopic myomectomy: effect of intramural myomas associated. Eur J Obstet Gynecol Reprod Biol. Jan. 2000;88(1):85-90. X-2. [pmid: 10659923].
160 Berto AG, Oba SM, Michelacci YM, Sampaio LO. Galactosaminoglycans from normal myometrium and leiomyoma. Braz J Med Biol Res. May. 2001;34(5):633-7. X-6. [pmid: 11323750].
161 Berto AG, Sampaio LO, Franco CR, Cesar RM Jr, Michelacci YM. A comparative analysis of structure and spatial distribution of decorin in human leiomyoma and normal myometrium. Biochim Biophys Acta. Jan 2. 2003;1619(1):98-112. X-6. [pmid: 12495820].
162 Bertolini F, Bianchi B, Corradi D, Caradonna L, Sesenna E. Mandibular intraosseous leiomyoma in a child: report of a case. J Clin Pediatr Dent. Summer. 2003;27(4):385-7. CASE REPORT. [pmid: 12924741].
163 Berzal-Cantalejo F, Montesinos-Carbonell M, Montesinos-Carbonell ML, Calabuig-Crespo C, Martorell-Cebollada MA. Solitary fibrous tumor arising in the fallopian tube. Gynecol Oncol. Mar. 2005;96(3):880-2. CASE REPORT. [pmid: 15721444].
164 Bettocchi S, Ceci O, Di Venere R, Pansini MV, Pellegrino A, Marello F, et al. Advanced operative office hysteroscopy without anaesthesia: analysis of 501 cases treated with a 5 Fr. bipolar electrode. Hum Reprod. Sep. 2002;17(9):2435-8. X-5. [pmid: 12202437].
165 Bettocchi S, Nappi L, Ceci O, Santoro A, Fattizzi N, Nardelli C, et al. The role of office hysteroscopy in menopause. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):103-6. X-6. [pmid: 15104845].
166 Beukenholdt R, Guerrero K. An audit of a specialist registrar-run outpatient diagnostic hysteroscopy service in a district general hospital. J Obstet Gynaecol. May. 2003;23(3):294-6. X-6. [pmid: 12850865].
167 Bhansali A, Singh S, Singh R, Kumar V, Khandelwal N, Sialy R. Leiomyomata of the uterus presenting as an abdominal mass in a true hermaphrodite. J Obstet Gynaecol. May. 2005;25(4):401-3. CASE REPORT. [pmid: 16091339].
168 Bhatia KG, Singh VR. Ultrasonic characteristics of leiomyoma uteri in vitro. Ultrasound Med Biol. Jul. 2001;27(7):983-7. X-6. [pmid: 11476932].
169 Bhattacharjee PK, Chaudhuri T, Roy D. An unusual abdominal lumpa—a case report. J Indian Med Assoc. May. 2003;101(5):322-3. X-4. [pmid: 14575225].
170 Bhattacharyya I, Summerlin DJ, Cohen DM, Ellis GL, Bavitz JB, Gillham LL. Granular cell leiomyoma of the oral cavity. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Sep. 2006;102(3):353-9. CASE REPORT. [pmid: 16920544].
171 Bhavnani V, Clarke A. Women awaiting hysterectomy: a qualitative study of issues involved in decisions about oophorectomy. Bjog. Feb. 2003;110(2):168-74. X-5. [pmid: 12618161].
172 Biankin SA, O'Toole VE, Fung C, Russell P. Bizarre leiomyoma of the vagina: report of a case. Int J Gynecol Pathol. Apr. 2000;19(2):186-7. CASE REPORT. [pmid: 10782419].
173 Biderman-Madar T, Sheiner E, Levy A, Potashnik G, Mazor M. Uterine leiomyoma among women who conceived following fertility treatment. Arch Gynecol Obstet. Sep. 2005;272(3):218-22. X-6. [pmid: 15971053].
174 Bilgin S, Yilmaz A, Okur E, Duzgun S, Tahaoglu C, Akkaya E. Primary endobronchial leiomyoma: a case report. Tuberk Toraks. 2004;52(3):272-4. X-4. [pmid: 15351942].
175 Billings SD, Folpe AL, Weiss SW. Do leiomyomas of deep soft tissue exist? An analysis of highly differentiated smooth muscle tumors of deep soft tissue supporting two distinct subtypes. Am J Surg Pathol. Sep. 2001;25(9):1134-42. X-6. [pmid: 11688572].
176 Binkert CA, Andrews RT, Kaufman JA. Utility of nonselective abdominal aortography in demonstrating ovarian artery collaterals in patients undergoing uterine artery embolization for fibroids. J Vasc Interv Radiol. Jul. 2001;12(7):841-5. X-5. [pmid: 11435540].
177 Binkert CA, Petersen BD. Two fatal complications after parallel tracheal-esophageal stenting. Cardiovasc Intervent Radiol. Mar–Apr. 2002;25(2):144-7. CASE REPORT. [pmid: 11901435].
178 Birchard KR, Brown MA, Hyslop WB, Firat Z, Semelka RC. MRI of acute abdominal and pelvic pain in pregnant patients. AJR Am J Roentgenol. Feb. 2005;184(2):452-8. X-6. [pmid: 15671363].
179 Birinyi L, Darago P, Torok P, Csiszar P, Major T, Borsos A, et al. Predictive value of hysteroscopic examination in intrauterine abnormalities. Eur J Obstet Gynecol Reprod Biol. Jul 15. 2004;115(1):75-9. X-4. [pmid: 15223169].
180 Birinyi L, Kalamasz N, Juhasz AG, Major T, Borsos A, Bacsko G. Follow-up study on the effectiveness of transcervical myoma resection (TCRM). Eur J Obstet Gynecol Reprod Biol. Mar 15. 2004;113(1):78-82. X-4. [pmid: 15036716].
181 Birsan A, Deval B, Detchev R, Poncelet C, Darai E. Vaginal and laparoscopic myomectomy for large posterior myomas: results of a pilot study. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):89-93. X-5. [pmid: 12932879].
182 Biswas S, Alauddin M, Sarkar SK, Sen S, Laha RN, Bhattacharya N. Leiomyomatosis peritonealis disseminata—a rare case report. J Indian Med Assoc. Jan. 2004;102(1):43-45. X-4. [pmid: 15195861].
183 Black MH, Giai M, Ponzone R, Sismondi P, Yu H, Diamandis EP. Serum total and free prostate-specific antigen for breast cancer diagnosis in women. Clin Cancer Res. Feb. 2000;6(2):467-73. X-6. [pmid: 10690525].
184 Blair SL, Al-Refaie WB, Wang-Rodriguez J, Behling C, Ali MW, Moossa AR. Gastrointestinal stromal tumors express ras oncogene: a potential role for diagnosis and treatment. Arch Surg. Jun. 2005;140(6):543-7. discussion 547–8. X-6. [pmid: 15967901].
185 Blaivas JG, Flisser AJ, Bleustein CB, Panagopoulos G. Periurethral masses: etiology and diagnosis in a large series of women. Obstet Gynecol. May. 2004;103(5 Pt 1):842-7. X-6. [pmid: 15121554].
186 Blank C, Rogalla P, Tran KH, Bullerdiek J. A novel high mobility group protein gene is a candidate for Xp22 abnormalities in uterine leiomyomas and other benign tumors. Cancer Genet Cytogenet. Sep. 2000;121(2):172-80. X-6. [pmid: 11063803].
187 Blockeel C, De Beeck BO, Bourgain C, Amy JJ. Myomatous erythrocytosis syndrome. Natl Med J India. Sep–Oct. 2005;18(5):247-9. CASE REPORT. [pmid: 16433138].
188 Bloom DC, Finley JC Jr, Broberg TG, Cueva RA. Leiomyoma of the nasal septum. Rhinology. Dec. 2001;39(4):233-5. CASE REPORT. [pmid: 11826696].
189 Bodner K, Bodner-Adler B, Kimberger O, Czerwenka K, Mayerhofer K. Estrogen and progesterone receptor expression in patients with uterine smooth muscle tumors. Fertil Steril. Apr. 2004;81(4):1062-6. X-6. [pmid: 15066464].
190 Bodner K, Bodner-Adler B, Kimberger O, Czerwenka K, Mayerhofer K. Bcl-2 receptor expression in patients with uterine smooth muscle tumors: an immunohistochemical analysis comparing leiomyoma, uterine smooth muscle tumor of uncertain malignant potential, and leiomyosarcoma. J Soc Gynecol Investig. Apr. 2004;11(3):187-91. X-6.
191 Bodner K, Bodner-Adler B, Wierrani F, Mayerhofer K, Grunberger W. . Intravenous leiomyomatosis of the uterus. Anticancer Res. May–Jun. 2002;22(3):1881-3. CASE REPORT. [pmid: 12168887].
192 Bodner-Adler B, Bodner K, Czerwenka K, Kimberger O, Leodolter S, Mayerhofer K. Expression of p16 protein in patients with uterine smooth muscle tumors: an immunohistochemical analysis. Gynecol Oncol. Jan. 2005;96(1):62-6. X-6. [pmid: 15589581].
193 Bodner-Adler B, Bodner K, Kimberger O, Czerwenka K, Leodolter S, Mayerhofer K. Expression of matrix metalloproteinases in patients with uterine smooth muscle tumors: an immunohistochemical analysis of MMP-1 and MMP-2 protein expression in leiomyoma, uterine smooth muscle tumor of uncertain malignant potential, and leiomyosarcoma. J Soc Gynecol Investig. Apr. 2004;11(3):182-6. X-6.
194 Boos CJ, Calver AL, Moors A, Dawkins KD, Hacking CN. Uterine artery embolisation for massive uterine fibroids in the presence of submassive pulmonary emboli. Bjog. Oct. 2005;112(10):1440-2. CASE REPORT. [pmid: 16167954].
195 Borch K, Skarsgard J, Franzen L, Mardh S, Rehfeld JF. Benign gastric polyps: morphological and functional origin. Dig Dis Sci. Jul. 2003;48(7):1292-7. X-6. [pmid: 12870785].
196 Borgfeldt C, Andolf E. Transvaginal ultrasonographic findings in the uterus and the endometrium: low prevalence of leiomyoma in a random sample of women age 25–40 years. Acta Obstet Gynecol Scand. Mar. 2000;79(3):202-7. X-5. [pmid: 10716301].
197 Borri A, Nesi G, Bencini L, Pernice LM. Bizarre leiomyoma of the epididymis. A case report. Minerva Urol Nefrol. Mar. 2000;52(1):29-31. CASE REPORT. [pmid: 11517827].
198 Borski TG, Stucker FJ, Grafton WD, Nathan CA. Leiomyoma of the trachea: a case report and a novel surgical approach. Am J Otolaryngol. Mar–Apr. 2000;21(2):119-21. CASE REPORT. [pmid: 10758998].
199 Botsis D, Koliopoulos C, Kondi-Pafitis A, Creatsas G. Frequency, histological, and immunohistochemical properties of massive inflammatory lymphocytic infiltration of leiomyomas of the uterus: an entity causing diagnostic difficulties. Int J Gynecol Pathol. Oct. 2005;24(4):326-9. X-6. [pmid: 16175076].
200 Bourlev V, Pavlovitch S, Stygar D, Volkov N, Lindblom B, Olovsson M. Different proliferative and apoptotic activity in peripheral versus central parts of human uterine leiomyomas. Gynecol Obstet Invest. 2003;55(4):199-204. X-4. [pmid: 12904692].
201 Bowling CB, Lipscomb GH. Torsion of the appendix mimicking ovarian torsion. Obstet Gynecol. Feb. 2006;107(2 Pt 2):466-7. CASE REPORT. [pmid: 16449151].
202 Boynton-Jarrett R, Rich-Edwards J, Malspeis S, Missmer SA, Wright R. A prospective study of hypertension and risk of uterine leiomyomata. Am J Epidemiol. Apr 1. 2005;161(7):628-38. X-6. [pmid: 15781952].
203 Bozlu M, Orhan D, Baltaci S, Muftuoglu YZ, Tulunay O. Leiomyoma of the epididymis. Int Urol Nephrol. 2000;32(1):95-6. CASE REPORT. [pmid: 11057783].
204 Bozzini N, Messina ML, Borsari R, Hilario SG, Pinotti JA. Comparative study of different dosages of goserelin in size reduction of myomatous uteri. J Am Assoc Gynecol Laparosc. Nov. 2004;11(4):462-3. X-4. [pmid: 15701186].
205 Bozzini N, Rodrigues CJ, Petti DA, Bevilacqua RG, Goncalves SP, Pinotti JA. Effects of treatment with gonadotropin releasing hormone agonist on the uterine leiomyomata structure. Acta Obstet Gynecol Scand. Apr. 2003;82(4):330-4. X-4. [pmid: 12716317].
206 Bracey EE, Mathur P, Dooldeniya M, Joshi A, Dawson PM. Unusual perianal tumours masquerading as abscesses. Int J Clin Pract. May. 2003;57(4):343-6. CASE REPORT. [pmid: 12800470].
207 Bradley LD. New endometrial ablation techniques for treatment of menorrhagia. Surg Technol Int. 2004;12:161-70. X-1. [pmid: 15455321].
208 Braithwaite SS, Bitterman P, DeGeest K, Lebbin DR. Postmenopausal virilization, simple ovarian cyst, and hilus cell hyperplasia—is there an association?. Endocr Pract. Jan–Feb. 2001;7(1):40-3. CASE REPORT. [pmid: 11250768].
209 Brandimarte G, Tursi A, Elisei W, Annunziata V, Monardo E. Symptomatic gastric leiomyoma mimicking giant gastric polyp: endoscopic diagnosis and removal. Eur Rev Med Pharmacol Sci. May–Jun. 2004;8(3):107-10. CASE REPORT. [pmid: 15368793].
210 Brannan SO, Cheung D, Trotter S, Tyler AJ, Reuser TQ. A conjunctival leiomyoma. Am J Ophthalmol. Oct. 2003;136(4):749-50. CASE REPORT. [pmid: 14516824].
211 Brannstrom M, Jones I, Lew W, Davy M. Ovarian lipoleiomyoma—a rare benign ovarian tumor with pre- and intra-operative features suggestive of malignancy. Acta Obstet Gynecol Scand. Sep. 2001;80(9):866-8. CASE REPORT. [pmid: 11531640].
212 Braun HL, Wheelock JB, Amaker BH, Seeds JW. Sonographic evaluation of a uterine angiolipoleiomyoma. J Clin Ultrasound. May. 2002;30(4):241-4. CASE REPORT. [pmid: 11981935].
213 Breitkopf DM, Frederickson RA, Snyder RR. Detection of benign endometrial masses by endometrial stripe measurement in premenopausal women. Obstet Gynecol. Jul. 2004;104(1):120-5. X-6. [pmid: 15229010].
214 Bricault I, Ayoubi JM. Is 3-D ultrasound-based virtual hysteroscopy feasible?. J Obstet Gynaecol. Jul. 2002;22(4):438-9. X-6. [pmid: 12521475].
215 Brinton LA, Sakoda LC, Sherman ME, Frederiksen K, Kjaer SK, Graubard BI, et al. Relationship of benign gynecologic diseases to subsequent risk of ovarian and uterine tumors. Cancer Epidemiol Biomarkers Prev. Dec. 2005;14(12):2929-35. X-6. [pmid: 16365012].
216 Bristow RE, Montz FJ. Leiomyomatosis peritonealis disseminata and ovarian Brenner tumor associated with tamoxifen use. Int J Gynecol Cancer. Jul–Aug. 2001;11(4):312-5. CASE REPORT. [pmid: 11520371].
217 Briton-Jones C, Lok IH, Chiu TT, Cheung LP, Haines C. Human chorionic gonadotropin and 17-beta estradiol regulation of human oviductin/oviduct specific glycoprotein mRNA expression in vitro. Fertil Steril. Sep. 2003;80(Suppl 2):720-6. X-6. [pmid: 14505745].
218 Briton-Jones C, Lok IH, Yuen PM, Chiu TT, Cheung LP, Haines C. Regulation of human oviductin mRNA expression in vivo. Fertil Steril. May. 2001;75(5):942-6. X-6. [pmid: 11334906].
219 Briton-Jones C, Lok IH, Yuen PM, Chiu TT, Cheung LP, Haines C. Human oviductin mRNA expression is not maintained in oviduct mucosal cell culture. Fertil Steril. Mar. 2002;77(3):576-80. X-6. [pmid: 11872215].
220 Broaddus RR, Xie S, Hsu CJ, Wang J, Zhang S, Zou C. The chemopreventive agents 4-HPR and DFMO inhibit growth and induce apoptosis in uterine leiomyomas. Am J Obstet Gynecol. Mar. 2004;190(3):686-92. X-6. [pmid: 15042000].
221 Broder MS, Bovone S. Improving treatment outcomes with a clinical pathway for hysterectomy and myomectomy. J Reprod Med. Dec. 2002;47(12):999-1003. X-6. [pmid: 12516317].
222 Broder MS, Kanouse DE, Bernstein SJ. Assessing symptoms before hysterectomy: is the medical record accurate?. Am J Obstet Gynecol. Jul. 2001;185(1):97-102. X-6. [pmid: 11483911].
223 Broder MS, Kanouse DE, Mittman BS, Bernstein SJ. The appropriateness of recommendations for hysterectomy. Obstet Gynecol. Feb. 2000;95(2):199-205. X-6. [pmid: 10674580].
224 Bromley B, Shipp TD, Benacerraf B. Adenomyosis: sonographic findings and diagnostic accuracy. J Ultrasound Med. Aug. 2000;19(8):529-34. quiz 535–6. X-6. [pmid: 10944038].
225 Brooks JK, Nikitakis NG, Goodman NJ, Levy BA. Clinicopathologic characterization of oral angioleiomyomas. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Aug. 2002;94(2):221-7. X-6. [pmid: 12221390].
226 Brooks JK, Ricalde P, Nikitakis NG, Levy BA. Angioleiomyoma of the tongue. Gen Dent. Jan–Feb. 2004;52(1):52-4. CASE REPORT. [pmid: 15055672].
227 Browne RF, McCann J, Johnston C, Molloy M, O'Connor H, McEniff N. Emergency selective arterial embolization for control of life-threatening hemorrhage from uterine fibroids. AJR Am J Roentgenol. Oct. 2004;183(4):1025-8. X-5. [pmid: 15385297].
228 Bruecks AK, Trotter MJ. Expression of desmin and smooth muscle myosin heavy chain in dermatofibromas. Arch Pathol Lab Med. Oct. 2002;126(10):1179-83. X-6. [pmid: 12296754].
229 Brummitt K, Harmanli OH, Gaughan J, Dandolu V, Chatwani AJ, Hernandez E. Gynecologists' attitudes toward hysterectomy: is the sex of the clinician a factor?. J Reprod Med. Jan. 2006;51(1):21-5. X-6. [pmid: 16482772].
230 Brunereau L, Herbreteau D, Gallas S, Cottier JP, Lebrun JL, Tranquart F, et al. Uterine artery embolization in the primary treatment of uterine leiomyomas: technical features and prospective follow-up with clinical and sonographic examinations in 58 patients. AJR Am J Roentgenol. Nov. 2000;175(5):1267-72. X-5. [pmid: 11044020].
231 Bryan S. Abnormal vaginal bleeding. Emerg Med (Fremantle). Jun. 2003;15(3):215-8. X-1. [pmid: 12786640].
232 S. Buchholz, P. Szawarski and S. L. Dawson. An odd case of multiple “cannonball metastases”. Postgrad Med J. 2003 Sep;79(935):542–3, 547. CASE REPORT
233 Buhimschi CS, Marvel RP. Degenerated uterine leiomyoma mimicking a hematoma associated with gas formation. Int J Gynaecol Obstet. Jun. 2001;73(3):271-3. CASE REPORT. [pmid: 11376678].
234 Bukhari AS, Bukhari S. Vaginal fibroid—a case report. J Obstet Gynaecol. Jan. 2005;25(1):83-4. CASE REPORT. [pmid: 16147714].
235 Burn PR, McCall JM, Chinn RJ, Vashisht A, Smith JR, Healy JC. Uterine fibroleiomyoma: MR imaging appearances before and after embolization of uterine arteries. Radiology. Mar. 2000;214(3):729-34. X-6. [pmid: 10715038].
236 Caglar GS, Tasci Y, Kayikcioglu F. Management of prolapsed pedunculated myomas. Int J Gynaecol Obstet. May. 2005;89(2):146-7. X-4. [pmid: 15847881].
237 Cai S, Everitt JI, Kugo H, Cook J, Kleymenova E, Walker CL. Polycystic kidney disease as a result of loss of the tuberous sclerosis 2 tumor suppressor gene during development. Am J Pathol. Feb. 2003;162(2):457-68. X-6. [pmid: 12547704]. [pmcid: 1851170].
238 Calabrese C, Fabbri A, Fusaroli P, Di Gaetano P, Miglioli M, Di Febo G. Diffuse esophageal leiomyomatosis: case report and review. Gastrointest Endosc. Apr. 2002;55(4):590-3. CASE REPORT. [pmid: 11923782].
239 Cameron RI, McCluggage WG. Extensive psammomatous calcification of the uterus and cervix associated with a uterine serous carcinoma. J Clin Pathol. Aug. 2004;57(8):888-90. CASE REPORT. [pmid: 15280415]. [pmcid: 1770391].
240 Campo S, Campo V, Gambadauro P. Reproductive outcome before and after laparoscopic or abdominal myomectomy for subserous or intramural myomas. Eur J Obstet Gynecol Reprod Biol. Oct 10. 2003;110(2):215-9. X-5. [pmid: 12969587].
241 Canevari RA, Pontes A, Rosa FE, Rainho CA, Rogatto SR. Independent clonal origin of multiple uterine leiomyomas that was determined by X chromosome inactivation and microsatellite analysis. Am J Obstet Gynecol. Oct. 2005;193(4):1395-403. X-6. [pmid: 16202732].
242 Canevari Rde A, Pontes A, Rogatto SR. Microallelotyping defines novel regions of loss of heterozygosity in uterine leiomyomas. Mol Carcinog. Mar. 2005;42(3):177-82. X-6. [pmid: 15605361].
243 Cao D, Srodon M, Montgomery EA, Kurman RJ. Lipomatous variant of angiomyofibroblastoma: report of two cases and review of the literature. Int J Gynecol Pathol. Apr. 2005;24(2):196-200. CASE REPORT. [pmid: 15782077].
244 Caoili EM, Hertzberg BS, Kliewer MA, DeLong D, Bowie JD. Refractory shadowing from pelvic masses on sonography: a useful diagnostic sign for uterine leiomyomas. AJR Am J Roentgenol. Jan. 2000;174(1):97-101. X-2. [pmid: 10628461].
245 Cario GM, Carlton MA. Total laparoscopic hysterectomy with laparosonic coagulating shears: a retrospective report of 200 consecutive cases. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):307-10. X-6. [pmid: 11592546].
246 Carlson NL, Krivak TC, Winter WE 3rd, Macri CI. Port site metastasis of ovarian carcinoma remote from laparoscopic surgery for benign disease. Gynecol Oncol. Jun. 2002;85(3):529-31. CASE REPORT. [pmid: 12051886].
247 Carney SA, Tahara H, Swartz CD, Risinger JI, He H, Moore AB, et al. Immortalization of human uterine leiomyoma and myometrial cell lines after induction of telomerase activity: molecular and phenotypic characteristics. Lab Invest. Jun. 2002;82(6):719-28. X-6. [pmid: 12065682].
248 Carpenter TT, Walker WJ. Pregnancy following uterine artery embolisation for symptomatic fibroids: a series of 26 completed pregnancies. Bjog. Mar. 2005;112(3):321-5. X-5. [pmid: 15713147].
249 Carr BR, Breslau NA, Peng N, Adams-Huet B, Bradshaw KD, Steinkampf MP. Effect of gonadotropin-releasing hormone agonist and medroxyprogesterone acetate on calcium metabolism: a prospective, randomized, double-blind, placebo-controlled, crossover trial. Fertil Steril. Nov. 2003;80(5):1216-23. X-6. [pmid: 14607578].
250 Carrieri G, Corvasce T, Annese P, Tolve I, Caniglia A, Di Sabato G. Endoscopic treatment of a large leiomyoma of the bladder. Arch Ital Urol Androl. Jun. 2005;77(2):111-2. CASE REPORT. [pmid: 16146274].
251 Casey R, Rogers PA, Vollenhoven BJ. An immunohistochemical analysis of fibroid vasculature. Hum Reprod. Jul. 2000;15(7):1469-75. X-6. [pmid: 10875852].
252 Catherino WH, Leppert PC, Stenmark MH, Payson M, Potlog-Nahari C, Nieman LK, et al. Reduced dermatopontin expression is a molecular link between uterine leiomyomas and keloids. Genes Chromosomes Cancer. Jul. 2004;40(3):204-17. X-6. [pmid: 15139000].
253 Catherino WH, Prupas C, Tsibris JC, Leppert PC, Payson M, Nieman LK, et al. Strategy for elucidating differentially expressed genes in leiomyomata identified by microarray technology. Fertil Steril. Aug. 2003;80(2):282-90. X-6. [pmid: 12909487].
254 Catherino WH, Segars JH. Microarray analysis in fibroids: which gene list is the correct list?. Fertil Steril. Aug. 2003;80(2):293-4. X-6. [pmid: 12909489].
255 Cavallotti D, Casilla G, Piantelli G, Verrotti C, Fieni S, Gramellini D. Early complications of prenatal invasive diagnostics: perspective analysis. Acta Biomed Ateneo Parmense. 2004;75(Suppl 1):23-6. X-6.
256 Cea-Calvo L, Lozano F, Pombo M, Serrano A, Rodriguez E, Porto J, et al. Images in cardiovascular medicine. Uterine intravenous leiomyomatosis extending through the inferior vena cava into the right cardiac cavities. Circulation. Feb 8. 2000;101(5):581-3. X-6. [pmid: 10662757].
257 Celia A, Bruschi M, De Stefani S, Baisi B, Cesinaro AM, Micali S, et al. Bizarre leiomyoma of scrotum. Arch Ital Urol Androl. Jun. 2005;77(2):113-4. CASE REPORT. [pmid: 16146275].
258 Celik C, Acar A, Cicek N, Gezginc K, Akyurek C. Can myomectomy be performed during pregnancy?. Gynecol Obstet Invest. 2002;53(2):79-83. X-4. [pmid: 11961378].
259 Celik H, Sapmaz E. Use of a single preoperative dose of misoprostol is efficacious for patients who undergo abdominal myomectomy. Fertil Steril. May. 2003;79(5):1207-10. X-4. [pmid: 12738519].
260 Celik O, Sarac K, Hascalik S, Alkan A, Mizrak B, Yologlu S. Magnetic resonance spectroscopy features of uterine leiomyomas. Gynecol Obstet Invest. 2004;58(4):194-201. X-4. [pmid: 15286450].
261 Cepni I, Ocal P, Erkan S, Saricali FS, Akbas H, Demirkiran F, et al. Comparison of transvaginal sonography, saline infusion sonography and hysteroscopy in the evaluation of uterine cavity pathologies. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):30-5. X-6. [pmid: 15730362].
262 Cermik D, Arici A, Taylor HS. Coordinated regulation of HOX gene expression in myometrium and uterine leiomyoma. Fertil Steril. Nov. 2002;78(5):979-84. X-6. [pmid: 12413981].
263 Ceyhan K, Simsir C, Dolen I, Calyskan E, Umudum H. Multinodular hydropic leiomyoma of the uterus with perinodular hydropic degeneration and extrauterine extension. Pathol Int. Aug. 2002;52(8):540-3. X-6. [pmid: 12366814].
264 Chamberlain G. The master of myomectomy. J R Soc Med. Jun. 2003;96(6):302-4. X-1. [pmid: 12782700]. [pmcid: 539516].
265 Chan AH, Fujimoto VY, Moore DE, Martin RW, Vaezy S. An image-guided high intensity focused ultrasound device for uterine fibroids treatment. Med Phys. Nov. 2002;29(11):2611-20. X-5. [pmid: 12462728].
266 Chan CY. A woman with a pelvic mass and pulmonary nodules. Br J Radiol. May. 2004;77(917):459-60. CASE REPORT. [pmid: 15121714].
267 Chan I, Wong T, Martinez-Mir A, Christiano AM, McGrath JA. Familial multiple cutaneous and uterine leiomyomas associated with papillary renal cell cancer. Clin Exp Dermatol. Jan. 2005;30(1):75-8. X-6. [pmid: 15663510].
268 Chan JK. Images in pathology. GIST versus inflammatory fibroid polyp. Int J Surg Pathol. Apr. 2001;9(2):147. X-6. [pmid: 11757490].
269 Chan JW, Law WL, Cheung SO, Lee MP, Ng CK, Lee S, et al. Benign metastasising leiomyoma: a rare but possible cause of bilateral pulmonary nodules in Chinese patients. Hong Kong Med J. Aug. 2005;11(4):303-6. CASE REPORT. [pmid: 16085949].
270 Chan KC, Cheng YJ, Huang GT, Wen YJ, Lin CJ, Chen LK, et al. The effect of IVPCA morphine on post-hysterectomy bowel function. Acta Anaesthesiol Sin. Jun. 2002;40(2):61-4. X-6. [pmid: 12194392].
271 Chan LY, Fok WY, Yuen PM. Pitfalls in diagnosis of interstitial pregnancy. Acta Obstet Gynecol Scand. Sep. 2003;82(9):867-70. X-6. [pmid: 12911450].
272 Chan SC, Yuen PM. Torsion of a paraovarian myoma in a teenage woman. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):96-8. CASE REPORT. [pmid: 15104843].
273 Chan TF, Su JH, Chung YF, Chang HL, Yuan SS. Decreased serum leptin levels in women with uterine leiomyomas. Acta Obstet Gynecol Scand. Feb. 2003;82(2):173-6. X-6. [pmid: 12648181].
274 Chang FW, Yu MH, Ku CH, Chen CH, Wu GJ, Liu JY. Effect of uterotonics on intra-operative blood loss during laparoscopy-assisted vaginal hysterectomy: a randomised controlled trial. Bjog. Jan. 2006;113(1):47-52. X-4. [pmid: 16398771].
275 Chang JY, Wang S, Hung CC, Tsai TF, Hsiao CH. Multiple Epstein-Barr virus-associated subcutaneous angioleiomyomas in a patient with acquired immunodeficiency syndrome. Br J Dermatol. Sep. 2002;147(3):563-7. CASE REPORT. [pmid: 12207602].
276 Chang SD, Cooperberg PL, Wong AD, Llewellyn PA, Bilbey JH. Limited-sequence magnetic resonance imaging in the evaluation of the ultrasonographically indeterminate pelvic mass. Can Assoc Radiol J. Apr. 2004;55(2):87-95. X-6. [pmid: 15131929].
277 Chang WC, Torng PL, Huang SC, Sheu BC, Hsu WC, Chen RJ, et al. Laparoscopic-assisted vaginal hysterectomy with uterine artery ligation through retrograde umbilical ligament tracking. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):336-42. X-4. [pmid: 16036194].
278 Chang YC, Lin CD, Chiang IP, Cheng YK, Tsai MH. Subglottic leiomyoma: report of a case. J Formos Med Assoc. Nov. 2002;101(11):795-7. CASE REPORT. [pmid: 12517061].
279 Chaparala RP, Fawole AS, Ambrose NS, Chapman AH. Large bowel obstruction due to a benign uterine leiomyoma. Gut. Mar. 2004;53(3):386-430. CASE REPORT. [pmid: 14960521]. [pmcid: 1773948].
280 Charvolin JY, Salmon RJ, Pecking A, Mareschal V. Positron emission tomography detection of breast cancer metastasis to the uterus. Obstet Gynecol. May. 2002;99(5 Pt 2):915-7. X-6. [pmid: 11975957].
281 Chavez NF, Garner EO, Khan W, Quade BJ, Sharif NA, Syed F, et al. Does the introduction of new technology change population demographics? Minimally invasive technologies and endometrial polyps. Gynecol Obstet Invest. 2002;54(4):217-20. X-6. [pmid: 12592065].
282 Chavez NF, Zweizig SL, Stewart EA. Neuropathic uterine pain after hysterectomy. A case report. J Reprod Med. Jun. 2003;48(6):466-8. CASE REPORT. [pmid: 12856521].
283 Cheah WK, Lenzi JE, Chong S, Goh PM. Laparoscopic excision of duodenal tumors. Surg Endosc. Aug. 2001;15(8):898. CASE REPORT. [pmid: 11443432].
284 Check JH, Choe JK, Lee G, Dietterich C. The effect on IVF outcome of small intramural fibroids not compressing the uterine cavity as determined by a prospective matched control study. Hum Reprod. May. 2002;17(5):1244-8. X-6. [pmid: 11980746].
285 Chegini N, Kornberg L. Gonadotropin releasing hormone analogue therapy alters signal transduction pathways involving mitogen-activated protein and focal adhesion kinases in leiomyoma. J Soc Gynecol Investig. Jan. 2003;10(1):21-6. X-6.
286 Chegini N, Luo X, Ding L, Ripley D. The expression of Smads and transforming growth factor beta receptors in leiomyoma and myometrium and the effect of gonadotropin releasing hormone analogue therapy. Mol Cell Endocrinol. Nov 14. 2003;209(12):9-16. X-6. [pmid: 14604812].
287 Chegini N, Ma C, Tang XM, Williams RS. Effects of GnRH analogues, ‘add-back’ steroid therapy, antiestrogen and antiprogestins on leiomyoma and myometrial smooth muscle cell growth and transforming growth factor-beta expression. Mol Hum Reprod. Dec. 2002;8(12):1071-8. X-6. [pmid: 12468639].
288 Chegini N, Verala J, Luo X, Xu J, Williams RS. Gene expression profile of leiomyoma and myometrium and the effect of gonadotropin releasing hormone analogue therapy. J Soc Gynecol Investig. Apr. 2003;10(3):161-71. X-6.
289 Chen CA, Chen M. Simultaneous occurrence of hepatic focal nodular hyperplasia and uterine endometrial stromal nodule in a patient having treated breast infiltrating ductal carcinoma. Acta Obstet Gynecol Scand. Jun. 2003;82(6):585-6. X-4. [pmid: 12780434].
290 Chen CC, Huang CH, Chu CH, Su CM, Chou YH, Chai CY, et al. Leiomyoma of the urinary bladder: a case report. Kaohsiung J Med Sci. Mar. 2003;19(3):141-5. X-4. [pmid: 12751876].
291 Chen CP, Yang YC, Lin SP, Wang W, Chang CL, Chang KM. Bilateral calcified ovarian fibromas in a patient with Sotos syndrome. Fertil Steril. Jun. 2002;77(6):1285-7. X-4. [pmid: 12057743].
292 Chen CR, Buck GM, Courey NG, Perez KM, Wactawski-Wende J. Risk factors for uterine fibroids among women undergoing tubal sterilization. Am J Epidemiol. Jan 1. 2001;153(1):20-6. X-6. [pmid: 11159141].
293 Chen DC, Liu JY, Wu GJ, Ku CH, Su HY, Chen CH. Serum vascular endothelial growth factor165 levels and uterine fibroid volume. Acta Obstet Gynecol Scand. Apr. 2005;84(4):317-21. X-6. [pmid: 15762959].
294 Chen HS, Chan TF, Chung YF, Su JH, Yuan SS. Aberrant serum adiponectin levels in women with uterine leiomyomas. Gynecol Obstet Invest. 2004;58(3):160-3. X-6. [pmid: 15249743].
295 Chen JB, Kudzu T, Hishikawa E, Miyazaki S. Endoscopic resection of a large esophageal leiomyoma. Endoscopy. May. 2002;34(5):428. X-4. [pmid: 11972281].
296 L. L. Chen and R. B. Goldstein. Case 11. Benign leiomyoma. J Ultrasound Med. 2002 May;21(5):597, 615–6. CASE REPORT
297 Chen MJ, Peng Y, Yang YS, Huang SC, Chow SN, Torng PL. Increased hyaluronan and CD44 expressions in intravenous leiomyomatosis. Acta Obstet Gynecol Scand. Apr. 2005;84(4):322-8. X-4. [pmid: 15762960].
298 Chen MJ, Yang JH, Lin MC, Ho HN, Yang YS. An unusual gestational choriocarcinoma occurring primarily on the surface of a subserous leiomyoma. Bjog. Feb. 2004;111(2):188-90. CASE REPORT. [pmid: 14723763].
299 S. Chen. MRI-guided focused ultrasound treatment of uterine fibroids. Issues Emerg Health Technol. 2005 Jul(70):1–4. X-1
300 Chen W, Yoshida S, Ohara N, Matsuo H, Morizane M, Maruo T. Gonadotropin-releasing hormone antagonist cetrorelix down-regulates proliferating cell nuclear antigen and epidermal growth factor expression and up-regulates apoptosis in association with enhanced poly(adenosine 5'-diphosphate-ribose) polymerase expression in cultured human leiomyoma cells. J Clin Endocrinol Metab. Feb. 2005;90(2):884-92. X-6. [pmid: 15536154].
301 Chen YC, Li CY, Kuo YH, Ho JD, Chen SN. Bilateral diffuse uveal melanocytic proliferation in a woman with uterine leiomyoma: case report. Chang Gung Med J. Apr. 2001;24(4):274-9. X-4. [pmid: 11413887].
302 Chen YJ, Wang PH, Yuan CC, Wu YC, Liu WM. Early pregnancy uninterrupted by laparoscopic bipolar coagulation of uterine vessels. J Am Assoc Gynecol Laparosc. Feb. 2002;9(1):79-83. X-4. [pmid: 11821611].
303 Chen YJ, Wang PH, Yuan CC, Yang MJ, Yen YK, Liu WM. Successful pregnancy in a woman with symptomatic fibroids who underwent laparoscopic bipolar coagulation of uterine vessels. Fertil Steril. Apr. 2002;77(4):838-40. X-4. [pmid: 11937144].
304 Chen YJ, Wang PH, Yuan CC, Yen YK, Yang MJ, Ng HT, et al. Pregnancy following treatment of symptomatic myomas with laparoscopic bipolar coagulation of uterine vessels. Hum Reprod. May. 2003;18(5):1077-81. X-4. [pmid: 12721187].
305 Cheng BC, Chang S, Mao ZF, Li MJ, Huang J, Wang ZW, et al. Surgical treatment of giant esophageal leiomyoma. World J Gastroenterol. Jul 21. 2005;11(27):4258-60. X-4. [pmid: 16015702].
306 Cheng CL, Wee A. Diffuse uterine adenomatoid tumor in an immunosuppressed renal transplant recipient. Int J Gynecol Pathol. Apr. 2003;22(2):198-201. X-4. [pmid: 12649678].
307 Cheng YL, Hsu JY, Hsu HH, Yu CP, Lee SC. Diffuse leiomyomatosis of the esophagus. Dig Surg. 2000;17(5):528-31. CASE REPORT. [pmid: 11124564].
308 Cheng YM, Chou CY, Huang SC, Lin HC. Oestrogen deficiency causes DNA damage in uterine leiomyoma cells: a possible mechanism for shrinkage of fibroids by GnRH agonists. Bjog. Jan. 2001;108(1):95-102. X-6. [pmid: 11213012].
309 Cheng YM, Lin BL. Modified sonohysterography immediately after hysteroscopy in the diagnosis of submucous myoma. J Am Assoc Gynecol Laparosc. Feb. 2002;9(1):24-8. X-6. [pmid: 11821602].
310 Chetty R, Serra S. Spindle cell pancreatic endocrine tumor associated with Cushing's syndrome. Endocr Pathol. Summer. 2005;16(2):145-51. CASE REPORT. [pmid: 16199900].
311 Chez RA. Etiology and treatment of uterine fibroids. Altern Ther Health Med. Mar–Apr. 2002;8(2):32-3. X-1. [pmid: 11890383].
312 Chiesa AG, Hart WR. Uterine artery embolization of leiomyomas with trisacryl gelatin microspheres (TGM): pathologic features and comparison with polyvinyl alcohol emboli. Int J Gynecol Pathol. Oct. 2004;23(4):386-92. CASE REPORT. [pmid: 15381909].
313 Chin HY, Lee CL, Yen CF, Wang CJ, Soong YK. Laparoscopic-assisted vaginal myomectomy through an anterior approach. J Laparoendosc Adv Surg Tech A. Jun. 2004;14(3):135-8. X-4. [pmid: 15245664].
314 Chiong E, Tan KB, Siew E, Rajwanshi A, See H, Esuvaranathan K. Uncommon benign intrascrotal tumours. Ann Acad Med Singapore. May. 2004;33(3):351-5. CASE REPORT. [pmid: 15175778].
315 Chiu CY, Wong WK, Mak HL, Chan CS, Kwok CH, Chan CH, et al. Uterine artery embolisation for treatment of fibroids: experience in Chinese women. Singapore Med J. Apr. 2001;42(4):148-54. X-4. [pmid: 11465313].
316 Choe KS, Sclafani AP, McCormick SA. Angioleiomyoma of the auricle: a rare tumor. Otolaryngol Head Neck Surg. Jul. 2001;125(1):109-10. CASE REPORT. [pmid: 11458228].
317 Chotiner EA, Shields CL, Shields JA, Gunduz K, Eagle RC Jr. Ciliary body leiomyoma with anterior chamber invasion. Arch Ophthalmol. Aug. 2001;119(8):1218-9. CASE REPORT. [pmid: 11483100].
318 Chow KM, Lam CM, Szeto CC. Pseudo-renal failure following total abdominal hysterectomy. J Nephrol. Jul–Aug. 2005;18(4):442-6. CASE REPORT. [pmid: 16245251].
319 Chow SN, Chen M. Tuboovarian abscess mimicking malignancy: report of two cases. J Formos Med Assoc. Oct. 2000;99(10):779-82. CASE REPORT. [pmid: 11061074].
320 Chrisman HB, Saker MB, Ryu RK, Nemcek AA Jr, Gerbie MV, Milad MP, et al. The impact of uterine fibroid embolization on resumption of menses and ovarian function. J Vasc Interv Radiol. Jun. 2000;11(6):699-703. X-5. [pmid: 10877413].
321 Christenson LJ, Smith K, Arpey CJ. Treatment of multiple cutaneous leiomyomas with CO2 laser ablation. Dermatol Surg. Apr. 2000;26(4):319-22. CASE REPORT. [pmid: 10759817].
322 Chrobak A, Gmyrek GB, Sozanski R, Sieradzka U, Paprocka M, Gabrys M, et al. The influence of extracellular matrix proteins on T-cell proliferation and apoptosis in women with endometriosis or uterine leiomyoma. Am J Reprod Immunol. Feb. 2004;51(2):123-9. X-6. [pmid: 14748838].
323 Chu PG, Arber DA, Weiss LM, Chang KL. Utility of CD10 in distinguishing between endometrial stromal sarcoma and uterine smooth muscle tumors: an immunohistochemical comparison of 34 cases. Mod Pathol. May. 2001;14(5):465-71. X-6. [pmid: 11353058].
324 Chua GC, Wilsher M, Young MP, Manyonda I, Morgan R, Belli AM. Comparison of particle penetration with non-spherical polyvinyl alcohol versus trisacryl gelatin microspheres in women undergoing premyomectomy uterine artery embolization. Clin Radiol. Jan. 2005;60(1):116-22. X-6. [pmid: 15642302].
325 Chuang GS, Martinez-Mir A, Engler DE, Gmyrek RF, Zlotogorski A, Christiano AM. Multiple cutaneous and uterine leiomyomata resulting from missense mutations in the fumarate hydratase gene. Clin Exp Dermatol. Jan. 2006;31(1):118-21. X-6. [pmid: 16309500].
326 Chuang GS, Martinez-Mir A, Geyer A, Engler DE, Glaser B, Cserhalmi-Friedman PB, et al. Germline fumarate hydratase mutations and evidence for a founder mutation underlying multiple cutaneous and uterine leiomyomata. J Am Acad Dermatol. Mar. 2005;52(3 Pt 1):410-6. X-6. [pmid: 15761418].
327 Chuang J, Tsai HW, Hwang JL. Fetal compression syndrome caused by myoma in pregnancy: a case report. Acta Obstet Gynecol Scand. May. 2001;80(5):472-3. CASE REPORT. [pmid: 11328228].
328 Chuang SS, Lin CN, Li CY, Wu CH. Uterine leiomyoma with massive lymphocytic infiltration simulating malignant lymphoma. A case report with immunohistochemical study showing that the infiltrating lymphocytes are cytotoxic T cells. Pathol Res Pract. 2001;197(2):135-8. CASE REPORT. [pmid: 11261818].
329 Chung S, Cooper JE, Roberts-Thomson IC. Images of interest. Gastrointestinal: stromal cell tumours of the stomach. J Gastroenterol Hepatol. Jul. 2000;15(7):807. X-6. [pmid: 10937689].
330 Cinel L, Dusmez D, Nabaei SH, Taner D, Pata O. Two intraligamentary lipomatous tumors with immunohistochemical features. Acta Obstet Gynecol Scand. Aug. 2002;81(8):786-7. CASE REPORT. [pmid: 12174167].
331 Ciray HN, Fu X, Olovsson M, Ahlsen G, Shuman C, Lindblom B, et al. Presence and localization of connexins 43 and 26 in cell cultures derived from myometrial tissues from nonpregnant and pregnant women and from leiomyomas. Am J Obstet Gynecol. Apr. 2000;182(4):926-30. X-6. [pmid: 10764475].
332 Cislo M, Szepietowski F, Wasik JC, Maj J, Hryncewicz-Gwozdz A, Nockowski P. Familial cutaneous and uterine leiomyomas: case report. Acta Dermatovenerol Croat. Dec. 2003;11(4):212-6. CASE REPORT. [pmid: 14670220].
333 Clark TJ, Mahajan D, Sunder P, Gupta JK. Hysteroscopic treatment of symptomatic submucous fibroids using a bipolar intrauterine system: a feasibility study. Eur J Obstet Gynecol Reprod Biol. Jan 10. 2002;100(2):237-42. X-5. [pmid: 11750972].
334 Clement GT. Perspectives in clinical uses of high-intensity focused ultrasound. Ultrasonics. Aug. 2004;42(10):1087-93. X-1. [pmid: 15234170].
335 Coard KC, Fletcher HM. Leiomyosarcoma of the uterus with a florid intravascular component (“intravenous leiomyosarcomatosis”). Int J Gynecol Pathol. Apr. 2002;21(2):182-5. CASE REPORT. [pmid: 11917229].
336 Cobellis G, Messalli EM, Stradella L, Pecori E, Cobellis L. Restitutio ad integrum of myometrium after myomectomy. Different results in pregnant and non-pregnant patients. Minerva Ginecol. Oct. 2002;54(5):393-5. X-5. [pmid: 12364885].
337 Cobellis L, Florio P, Stradella L, Lucia ED, Messalli EM, Petraglia F, et al. Electro-cautery of myomas during caesarean section—two case reports. Eur J Obstet Gynecol Reprod Biol. Apr 10. 2002;102(1):98-9. CASE REPORT. [pmid: 12039100].
338 Coccia ME, Becattini C, Bracco GL, Bargelli G, Scarselli G. Intraoperative ultrasound guidance for operative hysteroscopy. A prospective study. J Reprod Med. May. 2000;45(5):413-8. X-6. [pmid: 10845176].
339 Colgan TJ, Pron G, Mocarski EJ, Bennett JD, Asch MR, Common A. Pathologic features of uteri and leiomyomas following uterine artery embolization for leiomyomas. Am J Surg Pathol. Feb. 2003;27(2):167-77. X-6. [pmid: 12548162].
340 Comino R, Torrejon R, Sanchez-Ortega I. Long-term results of endometrial ablation-resection. J Am Assoc Gynecol Laparosc. Aug. 2002;9(3):268-71. X-5. [pmid: 12101320].
341 Common AA, Mocarski EJ, Kolin A, Pron G, Soucie J. Therapeutic failure of uterine fibroid embolization caused by underlying leiomyosarcoma. J Vasc Interv Radiol. Dec. 2001;12(12):1449-52. CASE REPORT. [pmid: 11742024].
342 Compagnoni GM, Talamonti MS, Joob A, Ergun GA, Rao S. Esophageal leiomyomatosis in a woman with a history of vulvar leiomyoma and Barrett's esophagus: a case report and review of the literature. Dig Surg. 2000;17(3):306-9. CASE REPORT. [pmid: 10867474].
343 Coral RP, Madke G, Westphalen A, Tressino D, Carvalho LA, Mastalir E. Thoracoscopic enucleation of a leiomyoma of the upper thoracic esophagus. Dis Esophagus. 2003;16(4):339-41. CASE REPORT. [pmid: 14641301].
344 Coronado GD, Marshall LM, Schwartz SM. Complications in pregnancy, labor, and delivery with uterine leiomyomas: a population-based study. Obstet Gynecol. May. 2000;95(5):764-9. X-6. [pmid: 10775744].
345 Costa PM, Marques A, Tavora, Oliveira E, Diaz M. Inflammatory fibroid polyp of the esophagus. Dis Esophagus. 2000;13(1):75-9. CASE REPORT. [pmid: 11005337].
346 Cowan BD, Sewell PE, Howard JC, Arriola RM, Robinette LG. Interventional magnetic resonance imaging cryotherapy of uterine fibroid tumors: preliminary observation. Am J Obstet Gynecol. Jun. 2002;186(6):1183-7. X-5. [pmid: 12066095].
347 Cramer SF, Marchetti C, Freedman J, Padela A. Relationship of myoma cell size and menopausal status in small uterine leiomyomas. Arch Pathol Lab Med. Oct. 2000;124(10):1448-53. X-6. [pmid: 11035573].
348 Cristi E, Perrone G, Battista C, Benedetti-Panici P, Rabitti C. A rare case of solitary fibrous tumour of the pre-sacral space: morphological and immunohistochemical features. In Vivo. Jul–Aug. 2005;19(4):777-80. CASE REPORT. [pmid: 15999548].
349 H. O. Critchley, P. Warner, A. J. Lee, S. Brechin, J. Guise and B. Graham. Evaluation of abnormal uterine bleeding: comparison of three outpatient procedures within cohorts defined by age and menopausal status. Health Technol Assess. 2004 Sep;8(34):iii–iv, 1–139. X-6
350 Crowther KS, Wyld L, Yamani Q, Jacob G. Case report: gastroduodenal intussusception of a gastrointestinal stromal tumour. Br J Radiol. Dec. 2002;75(900):987-9. CASE REPORT. [pmid: 12515708].
351 Cruz M, Murakami T, Tsuda K, Kurachi H, Enomoto T, Kim T, et al. Myxoid leiomyoma of the uterus: CT and MRI features. Abdom Imaging. Jan–Feb. 2001;26(1):98-101. X-6. [pmid: 11116372].
352 Cserni G, Kocsis L, Pusztai Z, Godo G. Endometrial adenocarcinoma with coexisting adenomatoid tumor of the uterus. Gynecol Oncol. Jul. 2003;90(1):207-10. CASE REPORT. [pmid: 12821367].
353 Culhaci N, Ozkara E, Yuksel H, Ozsunar Y, Unal E. Spontaneously ruptured uterine angioleiomyoma. Pathol Oncol Res. 2006;12(1):50-1. CASE REPORT. [pmid: 16554917].
354 Cunningham RE, Abbondanzo SL, Chu WS, Emory TS, Sobin LH, O'Leary TJ. Apoptosis, bcl-2 expression, and p53 expression in gastrointestinal stromal/smooth muscle tumors. Appl Immunohistochem Mol Morphol. Mar. 2001;9(1):19-23. X-6. [pmid: 11277409].
355 Cyr E. Uterine fibroid embolization. Radiol Technol. Sep–Oct. 2001;73(1):69-70. X-1. [pmid: 11579772].
356 Dabral C, Singh N, Singh PA, Misra V. Inflammatory fibroid polyp of small intestine in a child. Indian J Gastroenterol. May–Jun. 2003;22(3):101. CASE-REPORT. [pmid: 12839383].
357 Dahan MH, Ahmadi R. Spontaneous subserosal venous rupture overlying a uterine leiomyoma. A case report. J Reprod Med. May. 2002;47(5):419-20. CASE REPORT. [pmid: 12063882].
358 Dal Cin P, Quade BJ, Neskey DM, Kleinman MS, Weremowicz S, Morton CC. Intravenous leiomyomatosis is characterized by a der(14)t(12;14)(q15;q24). Genes Chromosomes Cancer. Feb. 2003;36(2):205-6. X-6. [pmid: 12508249].
359 Dalton VK, Lebovic DI. Use of a flexible cannula to bypass an obstructing fibroid during a first-trimester surgical abortion. A case report. J Reprod Med. Jul. 2003;48(7):551-2. CASE REPORT. [pmid: 12953330].
360 Damiani A, Melgrati L, Marziali M, Sesti F, Piccione E. . Laparoscopic myomectomy for very large myomas using an isobaric (gasless) technique. Jsls. Oct–Dec. 2005;9(4):434-8. X-5. [pmid: 16381362].
361 Damodaran P, Subramaniam R, Omar SZ, Nadkarni P, Paramsothy M. Profile of a menopause clinic in an urban population in Malaysia. Singapore Med J. Sep. 2000;41(9):431-5. X-4. [pmid: 11193115].
362 D'Angelo A, Amso NN, Wood A. Uterine leiomyosarcoma discovered after uterine artery embolisation. J Obstet Gynaecol. Nov. 2003;23(6):686-7. CASE REPORT. [pmid: 14617492].
363 D'Angelo A, Amso NN, Wood A. Spontaneous multiple pregnancy after uterine artery embolization for uterine fibroid: case report. Eur J Obstet Gynecol Reprod Biol. Oct 10. 2003;110(2):245-6. CASE REPORT. [pmid: 12969595].
364 Danikas D, Goudas VT, Rao CV, Brief DK. Luteinizing hormone receptor expression in leiomyomatosis peritonealis disseminata. Obstet Gynecol. Jun. 2000;95(6 Pt 2):1009-11. CASE REPORT. [pmid: 10808006].
365 Danzer E, Holzgreve W, Batukan C, Miny P, Tercanli S, Hoesli I. Myomectomy during the first trimester associated with fetal limb anomalies and hydrocephalus in a twin pregnancy. Prenat Diagn. Oct. 2001;21(10):848-51. CASE REPORT. [pmid: 11746127].
366 Darbhamulla A, Watson AJ, Benatar B. Recurrent vulval fibroids—an unusual indication for selective oestrogen receptor modulators (SERMs). J Obstet Gynaecol. Jan. 2004;24(1):95-6. X-6. [pmid: 14675999].
367 Darwish A. Modified hysteroscopic myomectomy of large submucous fibroids. Gynecol Obstet Invest. 2003;56(4):192-6. X-4. [pmid: 14576470].
368 Darwish AM, Nasr AM, El-Nashar DA. Evaluation of postmyomectomy uterine scar. J Clin Ultrasound. May. 2005;33(4):181-6. X-4. [pmid: 15856511].
369 Daskalakis GJ, Karabinas CD, Papantoniou NE, Papaspyrou IA, Antsaklis AJ, Michalas S. Vaginal fibroma. Case report. Eur J Gynaecol Oncol. 2002;23(6):575-6. CASE REPORT. [pmid: 12556111].
370 Daum O, Hes O, Vanecek T, Benes Z, Sima R, Zamecnik M, et al. Vanek's tumor (inflammatory fibroid polyp). Report of 18 cases and comparison with three cases of original Vanek's series. Ann Diagn Pathol. Dec. 2003;7(6):337-47. X-6. [pmid: 15018116].
371 Davids MR, Lin SH, Edoute Y, Cheema-Dhadli S, Halperin ML. Hyponatraemia and hyperglycaemia during laproscopic surgery. Qjm. May. 2002;95(5):321-30. X-4. [pmid: 11978904].
372 de Blok S, de Vries C, Prinssen HM, Blaauwgeers HL, Jorna-Meijer LB. Fatal sepsis after uterine artery embolization with microspheres. J Vasc Interv Radiol. Jun. 2003;14(6):779-83. CASE REPORT. [pmid: 12817046].
373 De Carolis S, Fatigante G, Ferrazzani S, Trivellini C, De Santis L, Mancuso S, et al. Uterine myomectomy in pregnant women. Fetal Diagn Ther. Mar–Apr. 2001;16(2):116-9. X-5. [pmid: 11173960].
374 de Csepel J, Jossart G, Salky BA. Laparoscopic resection of an extraesophageal leiomyoma presenting as an intra-abdominal mass. Surg Laparosc Endosc Percutan Tech. Apr. 2001;11(2):116-8. CASE REPORT. [pmid: 11330376].
375 De Falco M, Staibano S, Pollio F, Salvatore G, Pontillo M, Ciociola F, et al. Expression of proliferating cell nuclear antigen and bcl-2 during a pseudomenopausal state induced by presurgical treatment of uterine leiomyomas with gonadotropin-releasing hormone analogues plus tibolone. Int J Gynecol Pathol. Jul. 2005;24(3):286-91. X-6. [pmid: 15968206].
376 De Iaco P, Golfieri R, Ghi T, Muzzupapa G, Ceccarini M, Bovicelli L. Uterine fistula induced by hysteroscopic resection of an embolized migrated fibroid: a rare complication after embolization of uterine fibroids. Fertil Steril. Apr. 2001;75(4):818-20. CASE REPORT. [pmid: 11287042].
377 De Iaco PA, Muzzupapa G, Golfieri R, Ceccarini M, Roset B, Baroncini S. A uterine wall defect after uterine artery embolization for symptomatic myomas. Fertil Steril. Jan. 2002;77(1):176-8. CASE REPORT. [pmid: 11779611].
378 de Kroon CD, Louwe LA, Trimbos JB, Jansen FW. The clinical value of 3-dimensional saline infusion sonography in addition to 2-dimensional saline infusion sonography in women with abnormal uterine bleeding: work in progress. J Ultrasound Med. Nov. 2004;23(11):1433-40. X-6. [pmid: 15498907].
379 de Vries LD, Dijkhuizen FP, Mol BW, Brolmann HA, Moret E, Heintz AP. Comparison of transvaginal sonography, saline infusion sonography, and hysteroscopy in premenopausal women with abnormal uterine bleeding. J Clin Ultrasound. Jun. 2000;28(5):217-23. X-6. [pmid: 10799999].
380 de Wit AC, Vleugels MP, de Kruif JH. Diagnostic hysteroscopy: a valuable diagnostic tool in the diagnosis of structural intra-cavital pathology and endometrial hyperplasia or carcinoma?. Six years of experience with non-clinical diagnostic hysteroscopy. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):79-82. X-6. [pmid: 12932877].
381 Deering S, Miller B, Kopelman JN, Reed M. Recurrent leiomyomatosis peritonealis disseminata exacerbated by in vitro fertilization. Am J Obstet Gynecol. Mar. 2000;182(3):725-6. CASE REPORT. [pmid: 10739537].
382 Deevaguntla CR, Prabhakar B, Prasad GR, Bhaskaran S, Venkateswarlu K. Gastric leiomyoma presenting as gastric volvulus. Indian J Gastroenterol. Nov–Dec. 2003;22(6):230-1. CASE REPORT. [pmid: 15030039].
383 Deligeoroglou E, Kontoravdis A, Makrakis E, Christopoulos P, Kountouris A, Creatsas G. Development of leiomyomas on the uterine remnants of two women with Mayer-Rokitansky-Kuster-Hauser syndrome. Fertil Steril. May. 2004;81(5):1385-7. CASE REPORT. [pmid: 15136107].
384 Demopoulos RI, Mesia AF. Mitotic activity in spindle cell neoplasms treated with gonadotropin-releasing hormone agonists (leuprolide acetate). Int J Gynecol Pathol. Jul. 2000;19(3):295. X-6. [pmid: 10907181].
385 den Bakker MA, Hegt VN, Sleddens HB, Nuijten AS, Dinjens WN. Malignant mesenchymoma of the uterus, arising in a leiomyoma. Histopathology. Jan. 2002;40(1):65-70. CASE REPORT. [pmid: 11903599].
386 Dennery MP, Rushton HG, Belman AB. Sonography for the detection and follow-up of primary nonsarcomatous bladder tumors in children. Urology. Jan. 2002;59(1):119-21. discussion 121–2. CASE REPORT. [pmid: 11796293].
387 Denschlag D, Bentz EK, Hefler L, Pietrowski D, Zeillinger R, Tempfer C, et al. Genotype distribution of estrogen receptor-alpha, catechol-O-methyltransferase, and cytochrome P450 17 gene polymorphisms in Caucasian women with uterine leiomyomas. Fertil Steril. Feb. 2006;85(2):462-7. X-6. [pmid: 16595228].
388 Denschlag D, Bettendorf H, Watermann D, Keck C, Tempfer C, Pietrowski D. Polymorphism of the p53 tumor suppressor gene is associated with susceptibility to uterine leiomyoma. Fertil Steril. Jul. 2005;84(1):162-6. X-6. [pmid: 16009172].
389 D'Errico A, Corti B, Fiorentino M, Di Simone M, Mattioli S, Grigioni WF. Endoscopic finding of granular cell tumour associated with leiomyomas in the oesophagus. Dig Liver Dis. Apr. 2004;36(4):292-5. CASE REPORT. [pmid: 15115343].
390 Derubertis BG, Clair D, Faries P, Kapur S, Park K, Kent KC. Resection of an intravenous leiomyoma with intracardiac extension with use of endovascular techniques. J Vasc Surg. Sep. 2004;40(3):554-8. CASE REPORT. [pmid: 15337888].
391 deSouza NM, Williams AD. Uterine arterial embolization for leiomyomas: perfusion and volume changes at MR imaging and relation to clinical outcome. Radiology. Feb. 2002;222(2):367-74. X-5. [pmid: 11818601].
392 Dessole S, Ruiu GA, Cherchi PL, Ambrosini G. Uterine adenocarcinoma after GnRH agonist treatment. Arch Gynecol Obstet. Feb. 2000;263(3):148-9. CASE REPORT. [pmid: 10763848].
393 Devendra K, Tay SK. Laparoscopically-assisted vaginal hysterectomy (LAVH)—an alternative to abdominal hysterectomy. Singapore Med J. Mar. 2002;43(3):138-42. X-5. [pmid: 12005340].
394 Devireddy RV, Coad JE, Bischof JC. Microscopic and calorimetric assessment of freezing processes in uterine fibroid tumor tissue. Cryobiology. Jun. 2001;42(4):225-43. X-6. [pmid: 11748932].
395 DeWaay DJ, Syrop CH, Nygaard IE, Davis WA, Van Voorhis BJ. Natural history of uterine polyps and leiomyomata. Obstet Gynecol. Jul. 2002;100(1):3-7. X-5. [pmid: 12100797].
396 Di Salvo DN. Sonographic imaging of maternal complications of pregnancy. J Ultrasound Med. Jan. 2003;22(1):69-89. X-6. [pmid: 12523613].
397 Diakomanolis E, Elsheikh A, Sotiropoulou M, Voulgaris Z, Vlachos G, Loutradis D, et al. Intravenous leiomyomatosis. Arch Gynecol Obstet. Feb. 2003;267(4):256-7. CASE REPORT. [pmid: 12592433].
398 Dicaprio MR, Jokl P. Vascular leiomyoma presenting as medial joint line pain of the knee. Arthroscopy. Mar. 2003;19(3):E24. CASE REPORT. [pmid: 12627141].
399 Dickner SK, Cooper JM, Diaz D. A nonincisional, Doppler-guided transvaginal approach to uterine artery identification and control of uterine perfusion. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):55-8. X-6. [pmid: 15104832].
400 Dietterich C, Check JH, Choe JK, Nazari A, Fox F. The presence of small uterine fibroids not distorting the endometrial cavity does not adversely affect conception outcome following embryo transfer in older recipients. Clin Exp Obstet Gynecol. 2000;27(34):168-70. X-5. [pmid: 11214940].
401 Dietz DM, Stahlfeld KR, Bansal SK, Christopherson WA. Buttock necrosis after uterine artery embolization. Obstet Gynecol. Nov. 2004;104(5 Pt 2):1159-61. CASE REPORT. [pmid: 15516436].
402 Dijkhuizen FP, De Vries LD, Mol BW, Brolmann HA, Peters HM, Moret E, et al. Comparison of transvaginal ultrasonography and saline infusion sonography for the detection of intracavitary abnormalities in premenopausal women. Ultrasound Obstet Gynecol. May. 2000;15(5):372-6. X-6. [pmid: 10976476].
403 Diment J, Tamborini E, Casali P, Gronchi A, Carney JA, Colecchia M. Carney triad: case report and molecular analysis of gastric tumor. Hum Pathol. Jan. 2005;36(1):112-6. CASE REPORT. [pmid: 15712189].
404 Ding DC, Yu MH, Wu CC, Liu JY. Urachal myoma: a case report. Acta Obstet Gynecol Scand. May. 2003;82(5):481-3. CASE REPORT. [pmid: 12752081].
405 Ding L, Xu J, Luo X, Chegini N. Gonadotropin releasing hormone and transforming growth factor beta activate mitogen-activated protein kinase/extracellularly regulated kinase and differentially regulate fibronectin, type I collagen, and plasminogen activator inhibitor-1 expression in leiomyoma and myometrial smooth muscle cells. J Clin Endocrinol Metab. Nov. 2004;89(11):5549-57. X-6. [pmid: 15531510].
406 Dixon D, Flake GP, Moore AB, He H, Haseman JK, Risinger JI, et al. Cell proliferation and apoptosis in human uterine leiomyomas and myometria. Virchows Arch. Jul. 2002;441(1):53-62. X-6. [pmid: 12111201].
407 Dixon D, He H, Haseman JK. Immunohistochemical localization of growth factors and their receptors in uterine leiomyomas and matched myometrium. Environ Health Perspect. Oct. 2000;108(Suppl 5):795-802. X-6. [pmid: 11035985].
408 Djaiani GN, Glower DD, Heneghan JP, Stafford-Smith M. An unexpected intraoperative finding. J Cardiothorac Vasc Anesth. Jun. 2002;16(3):382-3. CASE REPORT. [pmid: 12073217].
409 Djelmis J, Mayer D, Majerovic M, Radanovic B, Starcevic V. Giant uterine leiomyoma devascularized by embolization prior to surgical removal. Eur J Obstet Gynecol Reprod Biol. Dec 1. 2001;99(2):278-80. CASE REPORT. [pmid: 11788190].
410 Dobashi Y, Noguchi T, Nasuno S, Katayama K, Kameya T. CDK-inhibitors-associated kinase activity: a possible determinant of malignant potential in smooth muscle tumors of the external soft tissue. Int J Cancer. Nov 1. 2001;94(3):353-62. X-6. [pmid: 11745414].
411 Dohi M, Harada J, Mogami T, Fukuda K, Kobayashi S, Yasuda M. MR-guided transvaginal cryotherapy of uterine fibroids with a horizontal open MRI system: initial experience. Radiat Med. Nov–Dec. 2004;22(6):391-7. X-5. [pmid: 15648454].
412 Dohi O, Hatori M, Ohtani H, Watanabe M, Kokubun S. Leiomyosarcoma of the sacral bone in a patient with a past history of resection of uterine leiomyoma. Ups J Med Sci. 2003;108(3):213-20. CASE REPORT. [pmid: 15000459].
413 Domanski HA. Cytologic features of angioleiomyoma: cytologic-histologic study of 10 cases. Diagn Cytopathol. Sep. 2002;27(3):161-6. X-6. [pmid: 12203864].
414 Dorenberg EJ, Novakovic Z, Smith HJ, Hafsahl G, Jakobsen JA. Uterine fibroid embolization can still be improved: observations on post-procedure magnetic resonance imaging. Acta Radiol. Aug. 2005;46(5):547-53. X-6. [pmid: 16224935].
415 Douchi T, Kuwahata R, Yamasaki H, Yamamoto S, Oki T, Nakae M, et al. Inverse relationship between the changes in trunk lean and fat mass during gonadotropin-releasing hormone agonist therapy. Maturitas. May 20. 2002;42(1):31-5. X-5. [pmid: 12020977].
416 Douchi T, Kuwahata T, Yoshimitsu N, Iwamoto I, Yamasaki H, Nagata Y. Changes in serum leptin levels during GnRH agonist therapy. Endocr J. Jun. 2003;50(3):355-9. X-5. [pmid: 12940465].
417 Drake A, Dhundee J, Buckley CH, Woolas R. Disseminated leiomyomatosis peritonealis in association with oestrogen secreting ovarian fibrothecoma. Bjog. Jun. 2001;108(6):661-4. CASE REPORT. [pmid: 11426907].
418 B J. Dubuisson. Management of leiomyomata. Hum Reprod Update. Nov–Dec. 2000;6(6):587. X-1. [pmid: 11129691].
419 Dubuisson JB, Fauconnier A, Chapron C, Kreiker G, Norgaard C. Reproductive outcome after laparoscopic myomectomy in infertile women. J Reprod Med. Jan. 2000;45(1):23-30. X-2. [pmid: 10664943].
420 Dueholm M, Forman A, Jensen ML, Laursen H, Kracht P. Transvaginal sonography combined with saline contrast sonohysterography in evaluating the uterine cavity in premenopausal patients with abnormal uterine bleeding. Ultrasound Obstet Gynecol. Jul. 2001;18(1):54-61. X-6. [pmid: 11489227].
421 Dueholm M, Lundorf E, Hansen ES, Ledertoug S, Olesen F. Accuracy of magnetic resonance imaging and transvaginal ultrasonography in the diagnosis, mapping, and measurement of uterine myomas. Am J Obstet Gynecol. Mar. 2002;186(3):409-15. X-6. [pmid: 11904599].
422 Dueholm M, Lundorf E, Sorensen JS, Ledertoug S, Olesen F, Laursen H. Reproducibility of evaluation of the uterus by transvaginal sonography, hysterosonographic examination, hysteroscopy and magnetic resonance imaging. Hum Reprod. Jan. 2002;17(1):195-200. X-6. [pmid: 11756387].
423 Duffy S, Jackson TL, Lansdown M, Philips K, Wells M, Pollard S, et al. The ATAC adjuvant breast cancer trial in postmenopausal women: baseline endometrial subprotocol data. Bjog. Dec. 2003;110(12):1099-106. X-6. [pmid: 14664881].
424 Dunson B, Baird DD. Bayesian modeling of incidence and progression of disease from cross-sectional data. Biometrics. Dec. 2002;58(4):813-22. X-6. [pmid: 12495135].
425 Dunson DB, Baird DD. A flexible parametric model for combining current status and age at first diagnosis data. Biometrics. Jun. 2001;57(2):396-403. X-6. [pmid: 11414562].
426 Dunson DB, Baird DD. A proportional hazards model for incidence and induced remission of disease. Biometrics. Mar. 2002;58(1):71-8. X-6. [pmid: 11890329].
427 Dunson DB, Dinse GE. Bayesian models for multivariate current status data with informative censoring. Biometrics. Mar. 2002;58(1):79-88. X-6. [pmid: 11890330].
428 Dunson DB, Holloman C, Calder C, Gunn LH. Bayesian modeling of multiple lesion onset and growth from interval-censored data. Biometrics. Sep. 2004;60(3):676-83. X-1. [pmid: 15339290].
429 Duplantier N, Begneaud W, Wood R, Dabezies C. Torsion of a gravid uterus associated with maternal trauma. A case report. J Reprod Med. Aug. 2002;47(8):683-5. CASE REPORT. [pmid: 12216438].
430 Duplantier N, Finan MA, Barbe T. Necessity of endometrial biopsy in women with enlarged uteri and a preoperative diagnosis of uterine leiomyomata. J Reprod Med. Jan. 2003;48(1):23-7. X-6. [pmid: 12611090].
431 Dursun P, Salman MC, Taskiran C, Yuce K, Ayhan A. Retroperitoneal leiomyomatosis: a case report. Int J Gynecol Cancer. Nov–Dec. 2005;15(6):1222-5. CASE REPORT. [pmid: 16343219].
432 Edmonds DK. Multiple fibroids in a postmenopausal woman with Mayer Rokitansky Kuster Hauser syndrome. J Pediatr Adolesc Gynecol. Apr. 2003;16(2):65-6. CASE REPORT. [pmid: 12742138].
433 Edwards JT, Wood CJ, Mendelson RM, Forbes GM. Extracolonic findings at virtual colonoscopy: implications for screening programs. Am J Gastroenterol. Oct. 2001;96(10):3009-12. X-6. [pmid: 11693340].
434 Ehigiegba AE, Ande AB, Ojobo SI. Myomectomy during cesarean section. Int J Gynaecol Obstet. Oct. 2001;75(1):21-5. X-4. [pmid: 11597615].
435 El Bouhmadi A, Laffargue F, Brun JF. Aggregability and disaggregability of erythrocytes in women suffering from ovarian cancer: evidence for an increased disaggregation threshold. Clin Hemorheol Microcirc. 2000;22(2):91-7. X-6. [pmid: 10831060].
436 El Hamamy E, Maulik TG. A bladder leiomyoma. J Obstet Gynaecol. May. 2003;23(3):317-8. CASE REPORT. [pmid: 12918481].
437 El Shabrawi-Caelen L, Kerl K, Cerroni L, Soyer HP, Kerl H. Cutaneous inflammatory pseudotumor—a spectrum of various diseases?. J Cutan Pathol. Oct. 2004;31(9):605-11. X-6. [pmid: 15330992].
438 Elkington NM, Carlton M. Recurrent intravenous leiomyomatosis with extension up the inferior vena cava. Aust N Z J Obstet Gynaecol. Apr. 2005;45(2):167. CASE REPORT. [pmid: 15760324].
439 Elli E, Espat NJ, Berger R, Jacobsen G, Knoblock L, Horgan S. Robotic-assisted thoracoscopic resection of esophageal leiomyoma. Surg Endosc. Apr. 2004;18(4):713-6. CASE REPORT. [pmid: 15026895].
440 Elliott J, Connor ME, Lashen H. The value of outpatient hysteroscopy in diagnosing endometrial pathology in postmenopausal women with and without hormone replacement therapy. Acta Obstet Gynecol Scand. Dec. 2003;82(12):1112-9. X-6. [pmid: 14616256].
441 El-Rifai W, Sarlomo-Rikala M, Andersson LC, Miettinen M, Knuutila S. High-resolution deletion mapping of chromosome 14 in stromal tumors of the gastrointestinal tract suggests two distinct tumor suppressor loci. Genes Chromosomes Cancer. Apr. 2000;27(4):387-91. X-6. [pmid: 10719369].
442 El-Shalakany AH, Nasr El-Din MH, Wafa GA, Azzam ME, El-Dorry A. Massive vault necrosis with bladder fistula after uterine artery embolisation. Bjog. Feb. 2003;110(2):215-6. CASE REPORT. [pmid: 12618170].
443 Elshebiny YH, Ashebu SD, Hussein HM, El-Naser AM. Leiomyoma of the urinary bladder: case report. East Afr Med J. Oct. 2002;79(10):557-9. CASE REPORT. [pmid: 12635765].
444 Elusoji SO, Coker B. Gastric volvulus and gastroduodeno-jejunal intussusception (an unusual cause of acute abdomen). West Afr J Med. Apr–Jun. 2002;21(2):166-7. CASE REPORT. [pmid: 12403046].
445 Emanuel MH, Wamsteker K. The Intra Uterine Morcellator: a new hysteroscopic operating technique to remove intrauterine polyps and myomas. J Minim Invasive Gynecol. Jan–Feb. 2005;12(1):62-6. X-5. [pmid: 15904601].
446 English JC 3rd, Derdeyn AS, Smith PD, Patterson JW. Adult acral cutaneous myofibromas in a patient with generalized morphea. J Am Acad Dermatol. Jun. 2002;46(6):953-6. CASE REPORT. [pmid: 12063499].
447 Englund K, Lindblom B, Carlstrom K, Gustavsson I, Sjoblom P, Blanck A. Gene expression and tissue concentrations of IGF-I in human myometrium and fibroids under different hormonal conditions. Mol Hum Reprod. Oct. 2000;6(10):915-20. X-6. [pmid: 11006320].
448 Epstein E, Ramirez A, Skoog L, Valentin L. Transvaginal sonography, saline contrast sonohysterography and hysteroscopy for the investigation of women with postmenopausal bleeding and endometrium > 5 mm. Ultrasound Obstet Gynecol. Aug. 2001;18(2):157-62. X-6. [pmid: 11529998].
449 Eren F, Akpulat S, Gokaslan H. Primary leiomyoma of the ovary co-existing with serous cystadenofibroma. Apmis. Feb. 2005;113(2):145-7. CASE REPORT. [pmid: 15723690].
450 Erian J, El-Toukhy T, Chandakas S, Kazal O, Hill N. Rapidly enlarging cervical fibroids during pregnancy: a case report. J Obstet Gynaecol. Aug. 2004;24(5):578-9. CASE REPORT. [pmid: 15369948].
451 Erkaya S, Kutlay B, Uygur D, Kara F, Tezer A. Primary ovarian leiomyoma in a postmenopausal woman. Acta Obstet Gynecol Scand. Jan. 2000;79(1):79-87. CASE REPORT. [pmid: 10646822].
452 Erkilic S, Erkilic A, Bayazit YA. Primary leiomyoma of the thyroid gland. J Laryngol Otol. Oct. 2003;117(10):832-4. CASE REPORT. [pmid: 14653931].
453 Ernst LM, Hui P, Parkash V. Intraplacental smooth muscle tumor: a case report. Int J Gynecol Pathol. Jul. 2001;20(3):284-8. CASE REPORT. [pmid: 11444205].
454 Eskandar MA, Vilos GA, Aletebi FA, Tummon IS. Hysteroscopic endometrial ablation is an effective alternative to hysterectomy in women with menorrhagia and large uteri. J Am Assoc Gynecol Laparosc. Aug. 2000;7(3):339-45. X-5. [pmid: 10924627].
455 Eslami-Varzaneh F, Washington K, Robert ME, Kashgarian M, Goldblum JR, Jain D. Benign fibroblastic polyps of the colon: a histologic, immunohistochemical, and ultrastructural study. Am J Surg Pathol. Mar. 2004;28(3):374-8. X-6. [pmid: 15104300].
456 Esposito NN, Hunt JL, Bakker A, Jones MW. Analysis of allelic loss as an adjuvant tool in evaluation of malignancy in uterine smooth muscle tumors. Am J Surg Pathol. Jan. 2006;30(1):97-103. X-6. [pmid: 16330948].
457 Estes CM, Maye JP. Severe intraoperative hyponatremia in a patient scheduled for elective hysteroscopy: a case report. Aana J. Jun. 2003;71(3):203-5. CASE REPORT. [pmid: 12847943].
458 Eude I, Dallot E, Vacher-Lavenu MC, Chapron C, Ferre F, Breuiller-Fouche M. Potentiation response of cultured human uterine leiomyoma cells to various growth factors by endothelin-1: role of protein kinase C. Eur J Endocrinol. May. 2001;144(5):543-8. X-6. [pmid: 11331222].
459 Eude I, Tertrin-Clary C, Vacher-Lavenu MC, Chapron C, Ferre F, Breuiller-Fouche M. Differential regulation of protein kinase C isoforms in human uterine leiomyoma. Gynecol Obstet Invest. 2001;51(3):191-6. X-6. [pmid: 11306908].
460 Exacoustos C, Zupi E, Marconi D, Romanini ME, Szabolcs B, Piredda A, et al. Ultrasound-assisted laparoscopic cryomyolysis: two- and three-dimensional findings before, during and after treatment. Ultrasound Obstet Gynecol. Apr. 2005;25(4):393-400. X-6. [pmid: 15789352].
461 Eyden B. Case for the panel of ultrastructural pathology—uterine leiomyoma. Ultrastruct Pathol. Mar–Apr. 2004;28(2):115-7. X-6. [pmid: 15205112].
462 Eyden B, Chorneyko KA, Shanks JH, Menasce LP, Banerjee SS. . Contribution of electron microscopy to understanding cellular differentiation in mesenchymal tumors of the gastrointestinal tract: a study of 82 tumors. Ultrastruct Pathol. Sep–Oct. 2002;26(5):269-85. X-6. [pmid: 12396237].
463 Facchetti F. A proposal for the adoption of a uniform metrical system for mitosis counting. Int J Surg Pathol. Apr. 2005;13(2):157-9. X-6. [pmid: 15864378].
464 Fadare O, Qin L, Martel M, Tavassoli FA. Pathology of the NovaSure (radio-frequency) impedance-controlled endometrial ablation system. Arch Pathol Lab Med. Sep. 2005;129(9):1175-8. CASE REPORT. [pmid: 16119995].
465 Fadare O, Wang S, R M. Mariappan. Pathologic quiz case: a 69-year-old asymptomatic man with a scrotal mass. Atypical (symplastic or bizarre) leiomyoma of the scrotum. Arch Pathol Lab Med. Feb. 2004;128(2):e37-8. CASE REPORT. [pmid: 14736263].
466 Fadare O, Zheng W. A 44-year-old woman with menometrorrhagia. Arch Pathol Lab Med. Oct. 2005;129(10):e195-8. CASE REPORT. [pmid: 16196533].
467 Faerstein E, Szklo M, Rosenshein N. Risk factors for uterine leiomyoma: a practice-based case-control study. I. African-American heritage, reproductive history, body size, and smoking. Am J Epidemiol. Jan 1. 2001;153(1):1-10. X-6. [pmid: 11159139].
468 Faerstein E, Szklo M, Rosenshein NB. Risk factors for uterine leiomyoma: a practice-based case-control study. II. Atherogenic risk factors and potential sources of uterine irritation. Am J Epidemiol. Jan 1. 2001;153(1):11-9. X-6. [pmid: 11159140].
469 Falcone M, Serra P. Massive pulmonary embolism in a woman with leiomyomatous uterus causing pelvic deep venous thrombosis. Ann Ital Med Int. Apr–Jun. 2005;20(2):104-7. CASE REPORT. [pmid: 16052843].
470 X. Fan, T. M. Semchyshyn, L. A. Mawn, J. B. Atkinson, J. C. Anderson, S. A. Toms, et al. July 2002: 66-year-old female with a one-year history of progressive left proptosis. Brain Pathol. 2003 Jan;13(1):111–2, 117. CASE REPORT
471 Fanfani F, Fagotti A, Longo R, Marana E, Mancuso S, Scambia G. Minilaparotomy in the management of benign gynecologic disease. Eur J Obstet Gynecol Reprod Biol. Apr 1. 2005;119(2):232-6. X-5. [pmid: 15808386].
472 Farquhar CM, Naoom S, Steiner CA. The impact of endometrial ablation on hysterectomy rates in women with benign uterine conditions in the United States. Int J Technol Assess Health Care. Summer. 2002;18(3):625-34. X-6. [pmid: 12391955].
473 Farquhar CM, Steiner CA. Hysterectomy rates in the United States 1990-1997. Obstet Gynecol. Feb. 2002;99(2):229-34. X-6. [pmid: 11814502].
474 Fauconnier A, Dubuisson JB, Ancel PY, Chapron C. Prognostic factors of reproductive outcome after myomectomy in infertile patients. Hum Reprod. Aug. 2000;15(8):1751-7. X-5. [pmid: 10920098].
475 Fearfield LA, Smith JR, Bunker CB, Staughton RC. Association of multiple familial cutaneous leiomyoma with a uterine symplastic leiomyoma. Clin Exp Dermatol. Jan. 2000;25(1):44-7. CASE REPORT. [pmid: 10671972].
476 Fedele L, Bianchi S, Raffaelli R, Zanconato G. A randomized study of the effects of tibolone and transdermal estrogen replacement therapy in postmenopausal women with uterine myomas. Eur J Obstet Gynecol Reprod Biol. Jan. 2000;88(1):91-4. X-2. [pmid: 10659924].
477 Fedele L, Bianchi S, Zanconato G, Carinelli S, Berlanda N. Conservative treatment of diffuse uterine leiomyomatosis. Fertil Steril. Aug. 2004;82(2):450-3. X-5. [pmid: 15302299].
478 Felemban A, Stein L, Tulandi T. Uterine restoration after repeated expulsion of myomas after uterine artery embolization. J Am Assoc Gynecol Laparosc. Aug. 2001;8(3):442-4. CASE REPORT. [pmid: 11509790].
479 Feliciano DV. Special feature: image of the month. Gastric Stromal tumor (leiomyoma vs. leiomyosarcoma). Arch Surg. May. 2001;136(5):597-9. X-6. [pmid: 11343554].
480 Feng F, Liu XH, Xie Q, Liu WQ, Bai CG, Ma DL. Expression and mutation of c-kit gene in gastrointestinal stromal tumors. World J Gastroenterol. Nov. 2003;9(11):2548-51. X-6. [pmid: 14606094].
481 Feng G, Jing J, Lan F. Intravenous leiomyomatosis—report of two cases. Chin Med Sci J. Mar. 2004;19(1):55. CASE REPORT. [pmid: 15104226].
482 Fernandez H, Sefrioui O, Virelizier C, Gervaise A, Gomel V, Frydman R. Hysteroscopic resection of submucosal myomas in patients with infertility. Hum Reprod. Jul. 2001;16(7):1489-92. X-5. [pmid: 11425835].
483 Fetsch JF, Laskin WB, Miettinen M. Superficial acral fibromyxoma: a clinicopathologic and immunohistochemical analysis of 37 cases of a distinctive soft tissue tumor with a predilection for the fingers and toes. Hum Pathol. Jul. 2001;32(7):704-14. X-6. [pmid: 11486169].
484 Filsoufi F, Farivar RS, Anderson C, Santerre D, Adams DH. Renal vein injury complicating removal of intravenous leiomyoma. J Thorac Cardiovasc Surg. Apr. 2002;123(4):820-2. CASE REPORT. [pmid: 11986614].
485 Fiscella K, Eisinger SH, Meldrum S, Feng C, Fisher SG, Guzick DS. Effect of mifepristone for symptomatic leiomyomata on quality of life and uterine size: a randomized controlled trial. Obstet Gynecol. Dec. 2006;108(6):1381-7. X-2. [pmid: 17138770].
486 Fitzgerald JF, Troncone R, Ahmed M, Dale PJ. Leiomyomatosis of the oesophagus. J Pediatr Gastroenterol Nutr. Aug. 2004;39(2):211-231. CASE REPORT. [pmid: 15269632].
487 Flavin R, Finn S, McErlean A, Smyth P, Meaney J, O'Connell F, et al. Cannonball metastases with favourable prognosis. Ir J Med Sci. Jan–Mar. 2005;174(1):61-4. CASE REPORT. [pmid: 15868893].
488 Fleischer AC, Donnelly EF, Campbell MG, Mazer MJ, Grippo D, Lipsitz NL. Three-dimensional color Doppler sonography before and after fibroid embolization. J Ultrasound Med. Oct. 2000;19(10):701-5. X-6. [pmid: 11026583].
489 Fleischer AC, Shappell HW. Color Doppler sonohysterography of endometrial polyps and submucosal fibroids. J Ultrasound Med. Jun. 2003;22(6):601-4. X-6. [pmid: 12795556].
490 Fleischmann A, Waser B, Gebbers JO, Reubi JC. Gastrin-releasing peptide receptors in normal and neoplastic human uterus: involvement of multiple tissue compartments. J Clin Endocrinol Metab. Aug. 2005;90(8):4722-9. X-6. [pmid: 15941862].
491 Flierman PA, Oberye JJ, van der Hulst VP, de Blok S. Rapid reduction of leiomyoma volume during treatment with the GnRH antagonist ganirelix. Bjog. May. 2005;112(5):638-42. X-5. [pmid: 15842290].
492 Floer M, Hlouschek V, Krieglstein CF, Bettendorf O, Domschke W, Pohle T. “Pancreatic lesion” outside the pancreas: value of endoscopic ultrasound. Scand J Gastroenterol. Apr. 2005;40(4):482-5. CASE REPORT. [pmid: 16028445].
493 Floyd SE, Proctor JA, Couchman G. Abdominal myomectomy after failed uterine artery embolization. Fertil Steril. Jun. 2005;83(6):1842. CASE REPORT. [pmid: 15950659].
494 Fogt F, Hinds N, Zimmerman RL. Histologic features of uterine leiomyomata treated with microsphere embolization. Obstet Gynecol. Sep. 2003;102(3):600-2. CASE REPORT. [pmid: 12962949].
495 Foksinski M, Kotzbach R, Szymanski W, Olinski R. The level of typical biomarker of oxidative stress 8-hydroxy-2'-deoxyguanosine is higher in uterine myomas than in control tissues and correlates with the size of the tumor. Free Radic Biol Med. Oct 1. 2000;29(7):597-601. X-6. [pmid: 11033411].
496 Fong K, Causer P, Atri M, Lytwyn A, Kung R. Transvaginal US and hysterosonography in postmenopausal women with breast cancer receiving tamoxifen: correlation with hysteroscopy and pathologic study. Radiographics. Jan–Feb. 2003;23(1):137-50. discussion 151–5. X-6. [pmid: 12533649].
497 Fong K, Kung R, Lytwyn A, Trudeau M, Chapman W, Nugent P, et al. Endometrial evaluation with transvaginal US and hysterosonography in asymptomatic postmenopausal women with breast cancer receiving tamoxifen. Radiology. Sep. 2001;220(3):765-73. X-6. [pmid: 11526280].
498 Forte F, Scarfini M, Spera E, De Carolis A, Sansalone S, Virgili G, et al. Leiomyoma of the epididymis and testicular adnexa: apropos of 3 cases. Arch Ital Urol Androl. Sep. 2004;76(3):119-20. CASE REPORT. [pmid: 15568302].
499 Foss RD, Ellis GL. Myofibromas and myofibromatosis of the oral region: A clinicopathologic analysis of 79 cases. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jan. 2000;89(1):57-65. X-6. [pmid: 10630943].
500 Foth D, Nawroth F, Schmidt T, Ortmann M, Romer T. Bilateral ovarian fibromas and endometrial adenocarcinoma in a postmenopausal patient with growing uterine myomas. Maturitas. Sep 28. 2001;39(3):259-64. CASE REPORT. [pmid: 11574186].
501 Foucher F, Leveque J, Le Bouar G, Grall J. Uterine rupture during pregnancy following myomectomy via coelioscopy. Eur J Obstet Gynecol Reprod Biol. Oct. 2000;92(2):279-81. CASE REPORT. [pmid: 10996694].
502 Fraenkel-Rubin M, Ergas D, Sthoeger ZM. Limited polyarteritis nodosa of the male and female reproductive systems: diagnostic and therapeutic approach. Ann Rheum Dis. Apr. 2002;61(4):362-4. CASE REPORT. [pmid: 11874844]. [pmcid: 1754071].
503 Frederick J, Hardie M, Reid M, Fletcher H, Wynter S, Frederick C. Operative morbidity and reproductive outcome in secondary myomectomy: a prospective cohort study. Hum Reprod. Nov. 2002;17(11):2967-71. X-5. [pmid: 12407058].
504 Freije WA. Genome biology and gynecology: the application of oligonucleotide microarrays to leiomyomata. Fertil Steril. Aug. 2003;80(2):277-8. X-6. [pmid: 12909485].
505 Friedrich M, Meyberg R, Friedrich G, Villena-Heinsen C. Atrial natriuretic factor (ANF) after laparoscopy and morphine application for pain therapy. Clin Exp Obstet Gynecol. 2000;27(1):9-11. X-5. [pmid: 10758788].
506 Friedrich M, Villena-Heinsen C, Axt-Fliedner R, Meyberg R, Tilgen W, Schmidt W, et al. Analysis of 25-hydroxyvitamin D3-1alpha-hydroxylase in cervical tissue. Anticancer Res. Jan–Feb. 2002;22(1A):183-6. X-6. [pmid: 12017284].
507 Froehner M, Gaertner HJ, Hakenberg OW, Wirth MP. Malignant fibrous histiocytoma of the ileum at a site of previous surgery: report of a case. Surg Today. 2001;31(3):242-5. CASE REPORT. [pmid: 11318129].
508 Fruhauf C, Garcia A, Rosso R. Stromal tumor in a perforated Meckel's diverticulum: a case report. Swiss Surg. 2002;8(6):273-6. CASE REPORT. [pmid: 12520847].
509 Fu KI, Muto M, Mera K, Sano Y, Nagashima F, Tahara M, et al. Carcinoma coexisting with esophageal leiomyoma. Gastrointest Endosc. Aug. 2002;56(2):272-3. CASE REPORT. [pmid: 12145610].
510 Fujimoto J, Hirose R, Sakaguchi H, Tamaya T. Expression of size-polymorphic androgen receptor gene in uterine leiomyoma according to the number of cytosine, adenine, and guanine repeats in androgen receptor alleles. Tumour Biol. Jan–Feb. 2000;21(1):33-7. X-6. [pmid: 10601839].
511 Fujimoto Y, Nakanishi Y, Yoshimura K, Shimoda T. Clinicopathologic study of primary malignant gastrointestinal stromal tumor of the stomach, with special reference to prognostic factors: analysis of results in 140 surgically resected patients. Gastric Cancer. 2003;6(1):39-48. X-6. [pmid: 12673425].
512 Fujishita A, Masuzaki H, Khan KN, Kitajima M, Ishimaru T. Modified reduction surgery for adenomyosis. A preliminary report of the transverse H incision technique. Gynecol Obstet Invest. 2004;57(3):132-8. X-6. [pmid: 14707472].
513 Fujita S, Kushihata F, Yachnis A, Winter W, Schell S. Images of interest. Gastrointestinal: symptomatic pelvic mass. J Gastroenterol Hepatol. Jul. 2004;19(7):826. X-6. [pmid: 15209632].
514 Fujiwara K, Haba M, Noguchi Y, Yamamoto S, Iwasaki M. Successful one-stage surgical removal of intravenous uterine leiomyomatosis with right heart extension. Jpn J Thorac Cardiovasc Surg. Sep. 2003;51(9):462-5. CASE REPORT. [pmid: 14529168].
515 Fuke H, Hashimoto A, Shimizu A, Yoshimura H, Nakano T, Shiraki K. Computed tomographic image of an inflammatory fibroid polyp of the stomach. Clin Imaging. Nov–Dec. 2003;27(6):400-2. CASE REPORT. [pmid: 14585568].
516 Fukuhara K, Kariya M, Kita M, Shime H, Kanamori T, Kosaka C, et al. Secreted frizzled related protein 1 is overexpressed in uterine leiomyomas, associated with a high estrogenic environment and unrelated to proliferative activity. J Clin Endocrinol Metab. Apr. 2002;87(4):1729-36. X-6. [pmid: 11932307].
517 Fukunaga M. Benign “metastasizing” lipoleiomyoma of the uterus. Int J Gynecol Pathol. Apr. 2003;22(2):202-4. CASE REPORT. [pmid: 12649679].
518 Funakoshi Y, Sawabata N, Takeda S, Hayakawa M, Okumura Y, Maeda H. Pulmonary benign metastasizing leiomyoma from the uterus in a postmenopausal woman: report of a case. Surg Today. 2004;34(1):55-7. CASE REPORT. [pmid: 14714229].
519 Furugaki K, Satoh H, Shinohara M, Saimura M, Nagai E, Yonemasu H, et al. Benign pseudotumorous lesion (fibroangiomyomatous hyperplasia with elastosis) in the gallbladder. J Gastroenterol. Jul. 2001;36(7):504-7. CASE REPORT. [pmid: 11480797].
520 Furuhashi M, Suganuma N. Recurrent bladder leiomyoma with ovarian steroid hormone receptors. J Urol. Mar. 2002;167(3):1399-400. CASE REPORT. [pmid: 11832749].
521 Furuike S, Ito T, Yamazaki M. Mechanical unfolding of single filamin A (ABP-280) molecules detected by atomic force microscopy. FEBS Lett. Jun 1. 2001;498(1):72-5. X-6. [pmid: 11389901].
522 Gabriel H, Pinto CM, Kumar M, Nikolaidis P, Miller FH, Weinrach DM, et al. MRI detection of uterine necrosis after uterine artery embolization for fibroids. AJR Am J Roentgenol. Sep. 2004;183(3):733-6. X-6. [pmid: 15333363].
523 Gainer EE, Ulmann A. Pharmacologic properties of CDB(VA)-2914. Steroids. Nov. 2003;68(1013):1005-11. X-6. [pmid: 14667993].
524 Gal R, Rath-Wolfson L, Rosenblatt Y, Halpern M, Schwartz A, Koren R. An improved technique for mitosis counting. Int J Surg Pathol. Apr. 2005;13(2):161-5. X-6. [pmid: 15864379].
525 Galajdova L, Verbeken K, Dhont M. Recurrent multiple leiomyomata in a patient with Mayer-Rokitansky-Kuster-Hauser syndrome. J Obstet Gynaecol. Jul. 2003;23(4):448-9. CASE REPORT. [pmid: 12881101].
526 Galia M, Lo Casto A, Midiri M, Bellia M, Bartolotta TV, Cademartiri F, et al. Virtual bronchoscopy in patients with central endobronchial stenosing lesions. Technique optimisation with single slice spiral CT. Radiol Med (Torino). Jul–Aug. 2004;108(12):28-38. X-6. [pmid: 15269688].
527 Gallimore FM, Booker A, Fielding IR, Roach VJ. An unusual case of a retroperitoneal mass causing urinary retention in a 40-year-old woman. Aust N Z J Obstet Gynaecol. Aug. 2000;40(3):352-3. CASE REPORT. [pmid: 11065049].
528 Gandolfo N, Gandolfo NG, Serafini G, Martinoli C. Endometrial stromal sarcoma of the uterus: MR and US findings. Eur Radiol. 2000;10(5):776-9. CASE REPORT. [pmid: 10823632].
529 Gao Z, Bhuiya T, Anderson A. Perivascular epithelioid cell tumour (PEComa) of the uterus associated with malignant neoplasm of the female genital tract. J Obstet Gynaecol. Aug. 2004;24(5):600-4. CASE REPORT. [pmid: 15369963].
530 Gao Z, Matsuo H, Nakago S, Kurachi O, Maruo T. p53 Tumor suppressor protein content in human uterine leiomyomas and its down-regulation by 17 beta-estradiol. J Clin Endocrinol Metab. Aug. 2002;87(8):3915-20. X-6. [pmid: 12161533].
531 Gao Z, Matsuo H, Wang Y, Nakago S, Maruo T. Up-regulation by IGF-I of proliferating cell nuclear antigen and Bcl-2 protein expression in human uterine leiomyoma cells. J Clin Endocrinol Metab. Nov. 2001;86(11):5593-9. X-6. [pmid: 11701740].
532 Garcia MJ, Gheyi VK, Uppot RN, Nowakowski FS, Storm ES. Uterine fibroids: primary treatment with therapeutic embolization. Del Med J. Sep. 2000;72(9):397-401. CASE REPORT. [pmid: 11042954].
533 Gardner FJ, Konje JC, Abrams KR, Brown LJ, Khanna S, Al-Azzawi F, et al. Endometrial protection from tamoxifen-stimulated changes by a levonorgestrel-releasing intrauterine system: a randomised controlled trial. Lancet. Nov 18. 2000;356(9243):1711-7. X-6. [pmid: 11095258].
534 Gargett CE, Bucak K, Zaitseva M, Chu S, Taylor N, Fuller PJ, et al. Estrogen receptor-alpha and -beta expression in microvascular endothelial cells and smooth muscle cells of myometrium and leiomyoma. Mol Hum Reprod. Aug. 2002;8(8):770-5. X-6. [pmid: 12149410].
535 Gassel F, Kraft CN, Wallny T, Hess L, Schmitt O. Soft-tissue angioleiomyoma of the hand as a rare differential diagnosis of haemophilic pseudotumour. Haemophilia. Sep. 2001;7(5):528-31. CASE REPORT. [pmid: 11554947].
536 Gaudino M, Spatuzza P, Snider F, Luciani N, Cina G, Possati G. Surgical management of a uterine leiomyoma extending through the inferior vena cava into the right heart. Heart Vessels. Dec. 2002;17(2):80-2. CASE REPORT. [pmid: 12541100].
537 Gavrilova-Jordan LP, Rose CH, Traynor KD, Brost BC, Gostout BS. Successful term pregnancy following MR-guided focused ultrasound treatment of uterine leiomyoma. J Perinatol. Jan. 2007;27(1):59-61. CASE REPORT. [pmid: 17180132].
538 Gaym A. Elective hysterectomy at Tikur Anbessa Teaching Hospital, Addis Ababa. Ethiop Med J. Jul. 2002;40(3):217-26. X-4. [pmid: 12602245].
539 Gaym A. Leiomyoma uteri in Ethiopian women: a clinical study. Ethiop Med J. Jul. 2004;42(3):199-204. X-4. [pmid: 16895038].
540 Gaynor-Krupnick DM, Kreder KJ. Bladder neck leiomyoma presenting as voiding dysfunction. J Urol. Jul. 2004;172(1):249-50. CASE REPORT. [pmid: 15201786].
541 Gemer O, Kapustian V, Kroll D, Tur-Kaspa I, Segal S. Perioperative factors for predicting successful hysteroscopic endometrial ablation. J Reprod Med. Sep. 2003;48(9):677-80. X-5. [pmid: 14562630].
542 Gentry CC, Okolo SO, Fong LF, Crow JC, Maclean AB, Perrett CW. Quantification of vascular endothelial growth factor-A in leiomyomas and adjacent myometrium. Clin Sci (Lond). Dec. 2001;101(6):691-5. X-6. [pmid: 11724658].
543 Ghadially FN, Erlandson RA. Case for the panel. Numerous small vesicles in a case of clear cell leiomyoma of deep soft tissue: an ultrastructural study. Ultrastruct Pathol. Jan–Feb. 2000;24(1):41-5. discussion 47, 49. CASE REPORT. [pmid: 10721151].
544 Ghani KR, Cotton MH. Uterine fibroid in a man: how African tradition solved a social crisis. Trop Doct. Jul. 2004;34(3):173-4. X-4. [pmid: 15267053].
545 Gharoro EP, Adeyemo SI. Care for the terminally ill: a review of deaths in the gynaecological wards of a tertiary institution, 1986-2000. Niger Postgrad Med J. Mar. 2004;11(1):64-7. X-4. [pmid: 15254575].
546 Ghomi A, Hantes J, Lotze EC. Incidence of cyclical bleeding after laparoscopic supracervical hysterectomy. J Minim Invasive Gynecol. May–Jun. 2005;12(3):201-5. X-5. [pmid: 15922975].
547 Ghumman S, Goel N, Rajaram S, Singh KC, Kansal B, Dewan P. Pregnancy in an achondroplastic dwarf: a case report. J Indian Med Assoc. Oct. 2005;103(10):536-538. CASE REPORT. [pmid: 16498757].
548 Gianaroli L, Gordts S, D'Angelo A, Magli MC, Brosens I, Cetera C, et al. Effect of inner myometrium fibroid on reproductive outcome after IVF. Reprod Biomed Online. Apr. 2005;10(4):473-7. X-6. [pmid: 15901454].
549 Gichangi PB, Bwayo J, Estambale B, De Vuyst H, Ojwang S, Rogo K, et al. Impact of HIV infection on invasive cervical cancer in Kenyan women. Aids. Sep 5. 2003;17(13):1963-8. X-4. [pmid: 12960829].
550 Gimbel H, Ottesen B, Tabor A. Danish gynecologists' opinion about hysterectomy on benign indication: results of a survey. Acta Obstet Gynecol Scand. Dec. 2002;81(12):1123-31. X-5. [pmid: 12519108].
551 Glaser SL, Clarke CA, Nugent RA, Stearns CB, Dorfman RF. Reproductive factors in Hodgkin's disease in women. Am J Epidemiol. Sep 15. 2003;158(6):553-63. X-6. [pmid: 12965881].
552 Glasser MH, Zimmerman JD. The HydroThermAblator system for management of menorrhagia in women with submucous myomas: 12- to 20-month follow-up. J Am Assoc Gynecol Laparosc. Nov. 2003;10(4):521-7. X-5. [pmid: 14738642].
553 Gocmen A, Kara IH, Karaca M. The effects of add-back therapy with tibolone on myoma uteri. Clin Exp Obstet Gynecol. 2002;29(3):222-4. X-4. [pmid: 12519049].
554 Godfrey CD, Zbella EA. Uterine necrosis after uterine artery embolization for leiomyoma. Obstet Gynecol. Nov. 2001;98(5 Pt 2):950-2. CASE REPORT. [pmid: 11704217].
555 Goh SG, Ho JM, Chuah KL, Tan PH, Poh WT, Riddell RH. Leiomyomatosis-like lymphangioleiomyomatosis of the colon in a female with tuberous sclerosis. Mod Pathol. Nov. 2001;14(11):1141-6. CASE REPORT. [pmid: 11706076].
556 Gojnic M, Likic I, Pervulov M, Petkovic S, Fazlagic A, Vasiljevic B. The significance of Doppler flow in early detection of uterine sarcoma in older primigravida pregnancies. Eur J Gynaecol Oncol. 2005;26(3):291-3. X-6. [pmid: 15991529].
557 Gojnic M, Pervulov M, Mostic T, Petkovic S. Doppler ultrasound as an additional parameter for the evaluation of myomas and the indication of myomectomy during pregnancy. Fetal Diagn Ther. Sep–Oct. 2004;19(5):462-4. X-6. [pmid: 15305105].
558 Gokdeniz R, Mizrak B, Ozen S, Bazoglu N. Endothelial nitric oxide synthase expression in leiomyoma and parental myometrium. Gynecol Obstet Invest. 2000;49(2):132-6. X-6. [pmid: 10671823].
559 Gokdeniz R, Ozen S, Mizrak B, Bazoglu N. GnRH agonist decreases endothelial nitric oxide synthase (eNOS) expression in leiomyoma. Int J Gynaecol Obstet. Sep. 2000;70(3):347-52. X-6. [pmid: 10967169].
560 Goldberg J. Uterine fibroid embolization: a hidden alternative?. Obstet Gynecol Surv. Apr. 2005;60(4):209-10. X-1. [pmid: 15795610].
561 Goldberg J, Boyle K, Choi M, Panchal N. Small bowel obstruction due to adhesive disease observed after uterine fibroid embolization. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 1):892-3. CASE REPORT. [pmid: 16150299].
562 Goldberg J, Burd I, Price FV, Worthington-Kirsch R. Leiomyosarcoma in a premenopausal patient after uterine artery embolization. Am J Obstet Gynecol. Nov. 2004;191(5):1733-5. CASE REPORT. [pmid: 15547555].
563 Goldberg J, Bussard A, McNeil J, Diamond J. Cost and reimbursement for three fibroid treatments: abdominal hysterectomy, abdominal myomectomy, and uterine fibroid embolization. Cardiovasc Intervent Radiol. Jan–Feb. 2007;30(1):54-8. X-2. [pmid: 17031734].
564 Goldberg J, McCrosson S, Kaulback KR. Delayed leiomyoma degeneration after microwave endometrial ablation. Obstet Gynecol. Nov. 2005;106(5 Pt 2):1176-8. CASE REPORT. [pmid: 16260561].
565 Goldberg J, Pereira L, Berghella V, Diamond J, Darai E, Seinera P, et al. Pregnancy outcomes after treatment for fibromyomata: uterine artery embolization versus laparoscopic myomectomy. Am J Obstet Gynecol. Jul. 2004;191(1):18-21. X-5. [pmid: 15295339].
566 Goldstein HB, Steinberg AC, Hunter R. A menopausal woman with mullerian agenesis, a leiomyoma, an inguinal hernia, and cystadenofibromas. Obstet Gynecol. May. 2004;103(5 Pt 2):1123-5. CASE REPORT. [pmid: 15121631].
567 Goldstein SR. The endometrial echo revisited: have we created a monster?. Am J Obstet Gynecol. Oct. 2004;191(4):1092-6. X-6. [pmid: 15507926].
568 Goldstein SR. The case for less-than-monthly progestogen in women on HT: is transvaginal ultrasound the key?. Menopause. Jan–Feb. 2005;12(1):110-3. X-6. [pmid: 15668608].
569 Gomez NA, Cozzarelli R, Alvarez LR, Fabre E, Vargas PE, Zapatier JA. Rectum leiomyoma in a 10-month-old female. Pediatr Surg Int. Apr. 2003;19(12):104-5. CASE REPORT. [pmid: 12721738].
570 Gomez-Jorge J, Keyoung A, Levy EB, Spies JB. Uterine artery anatomy relevant to uterine leiomyomata embolization. Cardiovasc Intervent Radiol. Nov–Dec. 2003;26(6):522-7. X-6. [pmid: 15061175].
571 Gonul II, Erdem O, Ataoglu O. Inflammatory fibroid polyp of the ileum causing intussusception: a case report. Turk J Gastroenterol. Mar. 2004;15(1):59-62. CASE REPORT. [pmid: 15264125].
572 Goodwin SC, Bonilla SM, Sacks D, Reed RA, Spies JB, Landow WJ, et al. Reporting standards for uterine artery embolization for the treatment of uterine leiomyomata. J Vasc Interv Radiol. Sep. 2001;12(9):1011-20. X-1. [pmid: 11535763].
573 Goto A, Takeuchi S, Sugimura K, Maruo T. Usefulness of Gd-DTPA contrast-enhanced dynamic MRI and serum determination of LDH and its isozymes in the differential diagnosis of leiomyosarcoma from degenerated leiomyoma of the uterus. Int J Gynecol Cancer. Jul–Aug. 2002;12(4):354-61. X-6. [pmid: 12144683].
574 Goto K, Orisaka S, Kurokawa T, Miyazaki M, Kotsuji F. Leiomyoma of the female urethra: urodynamic changes after surgical intervention. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):162-4. CASE REPORT. [pmid: 15365598].
575 Gousse AE, Barbaric ZL, Safir MH, Madjar S, Marumoto AK, Raz S. Dynamic half Fourier acquisition, single shot turbo spin-echo magnetic resonance imaging for evaluating the female pelvis. J Urol. Nov. 2000;164(5):1606-13. X-6. [pmid: 11025716].
576 Gowri R, Soundararaghavan S, Oumachigui A, Sistla SC, Iyengar KR. Leiomyoma of the vagina: an unusual presentation. J Obstet Gynaecol Res. Dec. 2003;29(6):395-8. CASE REPORT. [pmid: 14641688].
577 Goyle KK, Moore DF Jr, Garrett C, Goyle V. Benign metastasizing leiomyomatosis: case report and review. Am J Clin Oncol. Oct. 2003;26(5):473-6. CASE REPORT. [pmid: 14528073].
578 Grande N, Catalano GF, Ferrari S, Marana R. Spontaneous uterine rupture at 27 weeks of pregnancy after laparoscopic myomectomy. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):301. CASE REPORT. [pmid: 16036186].
579 Greene JF, DeRoche ME, Ingardia C, Curry SL. Large myomatous uterus resulting in complete obstruction of the inferior vena cava during pregnancy. Bjog. Oct. 2002;109(10):1189-91. CASE REPORT. [pmid: 12387478].
580 Grigorieva V, Chen-Mok M, Tarasova M, Mikhailov A. Use of a levonorgestrel-releasing intrauterine system to treat bleeding related to uterine leiomyomas. Fertil Steril. May. 2003;79(5):1194-8. X-5. [pmid: 12738516].
581 Gross KL, Neskey DM, Manchanda N, Weremowicz S, Kleinman MS, Nowak RA, et al. HMGA2 expression in uterine leiomyomata and myometrium: quantitative analysis and tissue culture studies. Genes Chromosomes Cancer. Sep. 2003;38(1):68-79. X-6. [pmid: 12874787].
582 Gross KL, Panhuysen CI, Kleinman MS, Goldhammer H, Jones ES, Nassery N, et al. Involvement of fumarate hydratase in nonsyndromic uterine leiomyomas: genetic linkage analysis and FISH studies. Genes Chromosomes Cancer. Nov. 2004;41(3):183-90. X-6. [pmid: 15334541].
583 Gruessner SE. Intrauterine versus transvaginal sonography for benign and malignant disorders of the female reproductive tract. Ultrasound Obstet Gynecol. Apr. 2004;23(4):382-7. X-6. [pmid: 15065190].
584 Guarch R, Puras A, Ceres R, Isaac MA, Nogales FF. Ovarian endometriosis and clear cell carcinoma, leiomyomatosis peritonealis disseminata, and endometrial adenocarcinoma: an unusual, pathogenetically related association. Int J Gynecol Pathol. Jul. 2001;20(3):267-70. CASE REPORT. [pmid: 11444203].
585 Guest AR, Strouse PJ, Hiew CC, Arca M. Progressive esophageal leiomyomatosis with respiratory compromise. Pediatr Radiol. Apr. 2000;30(4):247-50. CASE REPORT. [pmid: 10789903].
586 Guillaume J, Benjamin F, Jean-Gilles M, Ajah M, Tabassi G, Kenel-Pierre C. Myomectomy and tuboplasty performed at the same time in cases of distal tubal obstruction with associated fibroids. J Reprod Med. Jun. 2000;45(6):461-4. X-6. [pmid: 10900578].
587 Guillem P, Delcambre F, Cohen-Solal L, Triboulet JP, Antignac C, Heidet L, et al. Diffuse esophageal leiomyomatosis with perirectal involvement mimicking Hirschsprung disease. Gastroenterology. Jan. 2001;120(1):216-20. CASE REPORT. [pmid: 11208731].
588 Gull B, Karlsson B, Milsom I, Granberg S. Factors associated with endometrial thickness and uterine size in a random sample of postmenopausal women. Am J Obstet Gynecol. Aug. 2001;185(2):386-91. X-6. [pmid: 11518897].
589 Gupta R, Singal A, Pandhi D. Skin-colored nodules in zosteriform pattern. Indian J Dermatol Venereol Leprol. Jan–Feb. 2006;72(1):81-2. X-6. [pmid: 16481725].
590 Gupta S, Lim J, Merrett ND. Oesophageal leiomyoma: a case report. ANZ J Surg. Mar. 2002;72(3):240-2. CASE REPORT. [pmid: 12071464].
591 Gurbuz Y, Ozkara SK. Immunohistochemical profile of serous papillary cystadenofibroma of the fallopian tube: a clue of paramesonephritic origin. Appl Immunohistochem Mol Morphol. Jun. 2003;11(2):153-5. CASE REPORT. [pmid: 12778000].
592 Gurung G, Rana A, Magar DB. Utero-vaginal prolapse due to portio vaginal fibroma. J Obstet Gynaecol Res. Jun. 2003;29(3):157-9. CASE REPORT. [pmid: 12841699].
593 Gustavsson I, Englund K, Faxen M, Sjoblom P, Lindblom B, Blanck A. Tissue differences but limited sex steroid responsiveness of c-fos and c-jun in human fibroids and myometrium. Mol Hum Reprod. Jan. 2000;6(1):55-9. X-6. [pmid: 10611261].
594 Guven MA, Bese T, Demirkiran F, Idil M, Mgoyi L. Hydrosonography in screening for intracavitary pathology in infertile women. Int J Gynaecol Obstet. Sep. 2004;86(3):377-83. X-6. [pmid: 15325856].
595 Guven S, Esinler D, Salman MC, Gultekin M, Ayhan A. Recurrent vulval leiomyoma in a postmenopausal patient mimicking vulval carcinoma. J Obstet Gynaecol. Oct. 2005;25(7):732-3. CASE REPORT. [pmid: 16263563].
596 Habek D, Has B, Habek JC. Tuboovarian abscess mimicking intraligamentar uterine myoma and a intrauterine device: a case report. Eur J Contracept Reprod Health Care. Sep. 2005;10(3):168-70. CASE REPORT. [pmid: 16318964].
597 Hagspiel KD, Matsumoto AH, Berr SS. Uterine fibroid embolization: assessment of treatment response using perfusion-weighted extraslice spin tagging (EST) magnetic resonance imaging. J Magn Reson Imaging. Jun. 2001;13(6):982-6. X-5. [pmid: 11382963].
598 Hague S, Zhang L, Oehler MK, Manek S, MacKenzie IZ, Bicknell R, et al. Expression of the hypoxically regulated angiogenic factor adrenomedullin correlates with uterine leiomyoma vascular density. Clin Cancer Res. Jul. 2000;6(7):2808-14. X-6. [pmid: 10914728].
599 Hamatake M, Ishida T, Fukuyama Y, Yamazaki K, Sugio K, Sugimachi K. Bronchial leiomyoma with atelectasis in the left lower lobe. Jpn J Thorac Cardiovasc Surg. Feb. 2002;50(2):77-80. CASE REPORT. [pmid: 11905063].
600 Hameed A, Coleman RL. Fine-needle aspiration cytology of primary granulosa cell tumor of the adrenal gland: a case report. Diagn Cytopathol. Feb. 2000;22(2):107-9. CASE REPORT. [pmid: 10649522].
601 Hameed M, Heller DS, Murphy G. Squamous metaplasia of endometrium after uterine artery embolization for symptomatic leiomyomata. J Am Assoc Gynecol Laparosc. Feb. 2002;9(1):70-2. CASE REPORT. [pmid: 11821609].
602 Hameed N. Leiomyoma of the vagina. J Ayub Med Coll Abbottabad. Apr–Jun. 2003;15(2):63-4. CASE REPORT. [pmid: 14552254].
603 Hamid SA, Ferguson LE, McGavigan CJ, Howe DC, Campbell S. Observing three-dimensional human microvascular and myogenic architecture using conventional fluorescence microscopy. Micron. 2006;37(2):134-8. X-6. [pmid: 16242938].
604 Hamod H, Chamberlain PF, Moore NR, Mackenzie IZ. Conservative treatment of an incarcerated gravid uterus. Bjog. Sep. 2002;109(9):1074-5. CASE REPORT. [pmid: 12269687].
605 Han DH, Cheon YK, Cho JY, Kim YS, Lee JS, Lee MS, et al. Pedunculated leiomyoma. Gastrointest Endosc. Mar. 2005;61(3):429. CASE REPORT. [pmid: 15758916].
606 Hanada S, Okumura Y, Kaida K. Multicentric adenomatoid tumors involving uterus, ovary, and appendix. J Obstet Gynaecol Res. Aug. 2003;29(4):234-8. CASE REPORT. [pmid: 12959144].
607 Hansson B, Bogers J, Colpaert C, De Roeck J, De Backer A, Ceulemans P, et al. Leiomyoma of the right common iliac vein presenting as a duodenal tumour. Eur J Surg Oncol. Nov. 2000;26(7):717-9. CASE REPORT. [pmid: 11078622].
608 Harb TS, Adam RA. Predicting uterine weight before hysterectomy: ultrasound measurements versus clinical assessment. Am J Obstet Gynecol. Dec. 2005;193(6):2122-5. X-6. [pmid: 16325627].
609 Harmanli OH, Khandelwal M. Transvaginal uterine artery ligation in a woman with uterine leiomyomas. A case report. J Reprod Med. May. 2003;48(5):384-6. CASE REPORT. [pmid: 12815915].
610 Harmanli OH, Khilnani R, Dandolu V, Chatwani AJ. Narrow pubic arch and increased risk of failure for vaginal hysterectomy. Obstet Gynecol. Oct. 2004;104(4):697-700. X-6. [pmid: 15458888].
611 Harris A, Monga M, Wicklund CA, Robbins-Furman PJ, Strecker MN, Doyle NM, et al. Clinical correlates of pain with amniocentesis. Am J Obstet Gynecol. Aug. 2004;191(2):542-5. X-6. [pmid: 15343234].
612 Hart R, Khalaf Y, Yeong CT, Seed P, Taylor A, Braude P. A prospective controlled study of the effect of intramural uterine fibroids on the outcome of assisted conception. Hum Reprod. Nov. 2001;16(11):2411-7. X-6. [pmid: 11679530].
613 Has R, Balci NC, Ibrahimoglu L, Rozanes I, Topuz S. Uterine artery embolization in a 10-week cervical pregnancy with coexisting fibroids. Int J Gynaecol Obstet. Mar. 2001;72(3):253-8. CASE REPORT. [pmid: 11226446].
614 Hasbargen U, Strauss A, Summerer-Moustaki M, Baretton G, Roth U, Kimmig R, et al. Myomectomy as a pregnancy-preserving option in the carefully selected patient. Fetal Diagn Ther. Mar–Apr. 2002;17(2):101-3. CASE REPORT. [pmid: 11844914].
615 Hasbargen U, Summerer-Moustaki M, Hillemanns P, Scheidler J, Kimmig R, Hepp H. Uterine dehiscence in a nullipara, diagnosed by MRI, following use of unipolar electrocautery during laparoscopic myomectomy: Case report. Hum Reprod. Aug. 2002;17(8):2180-2. CASE REPORT. [pmid: 12151455].
616 Hascalik S, Celik O, Sarac K, Hascalik M. Transient ovarian failure: a rare complication of uterine fibroid embolization. Acta Obstet Gynecol Scand. Jul. 2004;83(7):682-5. CASE REPORT. [pmid: 15225195].
617 Haskins RD Jr, Haskins CJ, Gilmore R, Borel MA, Mancuso P. Intramural leiomyoma during pregnancy becoming pedunculated postpartally. A case report. J Reprod Med. Mar. 2001;46(3):253-5. CASE REPORT. [pmid: 11304868].
618 Hayasaka K, Tanaka Y, Fujii M, Himi K, Negishi N. . Intravenous leiomyomatosis. J Comput Assist Tomogr. Jan–Feb. 2000;24(1):83-5. CASE REPORT. [pmid: 10667665].
619 Hayashi A, Maruyama Y, Saze M, Okada E. Ulnar recurrent adipofascial flap for reconstruction of massive defects around the elbow and forearm. Br J Plast Surg. Oct. 2004;57(7):632-7. X-6. [pmid: 15380696].
620 Healy DL. Impact of uterine fibroids on ART outcome. Environ Health Perspect. Oct. 2000;108(Suppl 5):845-7. X-6. [pmid: 11035993].
621 Heazell AE, Tripathi S, Thompson A, Pirie AM. Vasculitic lesion involving the uterine cervix in a patient with anti-nuclear antibodies. J Obstet Gynaecol. Sep. 2004;24(6):711-2. CASE REPORT. [pmid: 16147626].
622 Hebbar S, Nayak S. Ethical issues in laparoscopic hysterectomy. Indian J Med Ethics. Jan–Mar. 2006;3(1):19-20. X-1. [pmid: 16832925].
623 Heer IM, Middendorf K, Muller-Egloff S, Dugas M, Strauss A. Ultrasound training: the virtual patient. Ultrasound Obstet Gynecol. Sep. 2004;24(4):440-4. X-6. [pmid: 15343601].
624 Heer IM, Strauss A, Muller-Egloff S, Hasbargen U. Telemedicine in ultrasound: new solutions. Ultrasound Med Biol. Sep. 2001;27(9):1239-43. X-6. [pmid: 11597365].
625 Hehenkamp WJ, Volkers NA, Van Swijndregt AD, De Blok S, Reekers JA, Ankum WM. Myoma expulsion after uterine artery embolization: complication or cure?. Am J Obstet Gynecol. Nov. 2004;191(5):1713-5. CASE REPORT. [pmid: 15547547].
626 Heinemann K, Thiel C, Mohner S, Lewis MA, Raff T, Kuhl-Habich D, et al. Benign gynecological tumors: estimated incidence. Results of the German Cohort Study on Women's Health. Eur J Obstet Gynecol Reprod Biol. Mar 26. 2003;107(1):78-80. X-5. [pmid: 12593900].
627 Heinig J, Neff A, Cirkel U, Klockenbusch W. Recurrent leiomyomatosis peritonealis disseminata after hysterectomy and bilateral salpingo-oophorectomy during combined hormone replacement therapy. Eur J Obstet Gynecol Reprod Biol. Dec 10. 2003;111(2):216-8. CASE REPORT. [pmid: 14597256].
628 Hejmadi RK, Ganesan R, Todd RW, Rollason TP. Mitotically active cervical leiomyoma in a non-HIV immunosuppressed case. Bjog. Dec. 2003;110(12):1135-6. CASE REPORT. [pmid: 14664890].
629 Held RT, Zderic V, Nguyen TN, Vaezy S. Annular phased-array high-intensity focused ultrasound device for image-guided therapy of uterine fibroids. IEEE Trans Ultrason Ferroelectr Freq Control. Feb. 2006;53(2):335-48. X-6. [pmid: 16529108].
630 Hemmings R, Rivard M, Olive DL, Poliquin-Fleury J, Gagne D, Hugo P, et al. Evaluation of risk factors associated with endometriosis. Fertil Steril. Jun. 2004;81(6):1513-21. X-6. [pmid: 15193470].
631 Heniford BT, Arca MJ, Walsh RM. The mini-laparoscopic intragastric resection of a gastroesophageal stromal tumor: a novel approach. Surg Laparosc Endosc Percutan Tech. Apr. 2000;10(2):82-5. CASE REPORT. [pmid: 10789578].
632 Hepworth CC, Menzies D, Motson RW. Minimally invasive surgery for posterior gastric stromal tumors. Surg Endosc. Apr. 2000;14(4):349-53. X-6. [pmid: 10790553].
633 Herbert M, Segal M, Hermann G, Sandbank J. Pleomorphic Leimyoma of the scrotum: immunohistochemical stains. Isr Med Assoc J. Jul. 2001;3(7):543-4. X-6. [pmid: 11791429].
634 Herzog AG. Migraine with ectopic hyperprolactinemia from uterine fibroids. Neurology. Jul 12. 2000;55(1):148-9. CASE REPORT. [pmid: 10891931].
635 Heyer H, Ohlinger R, Schimming A, Schwesinger G, Grunwald S. Parenchymal leiomyoma of the breast—clinical, sonographic, mammographic and histological features. Ultraschall Med. Feb. 2006;27(1):55-8. CASE REPORT. [pmid: 16470480].
636 Hillard JB, Malpica A, Ramirez PT. Conservative management of a uterine tumor resembling an ovarian sex cord-stromal tumor. Gynecol Oncol. Jan. 2004;92(1):347-52. CASE REPORT. [pmid: 14751183].
637 Hinckley MD, Milki AA. 1000 office-based hysteroscopies prior to in vitro fertilization: feasibility and findings. Jsls. Apr–Jun. 2004;8(2):103-7. X-6. [pmid: 15119651].
638 Hindley JT, Law PA, Hickey M, Smith SC, Lamping DL, Gedroyc WM, et al. Clinical outcomes following percutaneous magnetic resonance image guided laser ablation of symptomatic uterine fibroids. Hum Reprod. Oct. 2002;17(10):2737-41. X-5. [pmid: 12351555].
639 Hirai K, Kanaoka Y, Ishiko O, Mitsuhashi T, Ogita S. A novel technique for myomectomy. Intranodal surgery with an electromechanical tissue borer. J Reprod Med. Oct. 2000;45(10):813-6. X-5. [pmid: 11077629].
640 Hirasaki S, Endo H, Nishina T, Masumoto T, Tanimizu M, Hyodo I. Gastric cancer concomitant with inflammatory fibroid polyp treated with endoscopic mucosal resection using an insulation-tip diathermic knife. Intern Med. Mar. 2003;42(3):259-62. CASE REPORT. [pmid: 12705791].
641 Hirasaki S, Tanimizu M, Tsubouchi E, Nasu J, Masumoto T. Gastritis cystica polyposa concomitant with gastric inflammatory fibroid polyp occurring in an unoperated stomach. Intern Med. Jan. 2005;44(1):46-9. CASE REPORT. [pmid: 15704662].
642 H. Hirata, K. Kusuzaki, K. Fukutome, M. Maeda and A. Uchida. A hand mass that became painful 13 years after onset. Clin Orthop Relat Res. 2005 Apr(433):265–70. CASE REPORT
643 Hizawa K, Esaki M, Iwai K, Yao T, Sato H, Matsumoto T, et al. EUS in the diagnosis of diffuse esophageal leiomyomatosis. Gastrointest Endosc. Nov. 2002;56(5):764-6. X-6. [pmid: 12397297].
644 Ho SS, Cowan NC. Uterine artery embolisation for uterine fibroids using a 4F Rosch inferior mesenteric catheter. Eur Radiol. Jun. 2005;15(6):1168-72. X-5. [pmid: 15538579].
645 Hock YL, Goswami P, Rollason TP. Mitotically active haemorrhagic cellular (apoplectic) leiomyoma. Eur J Gynaecol Oncol. 2000;21(1):28-9. CASE REPORT. [pmid: 10726614].
646 Hockstein S. Spontaneous uterine rupture in the early third trimester after laparoscopically assisted myomectomy. A case report. J Reprod Med. Feb. 2000;45(2):139-41. CASE REPORT. [pmid: 10710746].
647 Hoffman MK, Sciscione AC. Placenta accreta and intrauterine fetal death in a woman with prior endometrial ablation: a case report. J Reprod Med. May. 2004;49(5):384-6. CASE REPORT. [pmid: 15214713].
648 Hoffman PJ, Milliken DB, Gregg LC, Davis RR, Gregg JP. Molecular characterization of uterine fibroids and its implication for underlying mechanisms of pathogenesis. Fertil Steril. Sep. 2004;82(3):639-49. X-6. [pmid: 15374708].
649 Holder R Jr, Dellinger TM, Krolls SO, Hill WJ, Livingston HM, Alemar GO. Myxoid angiomyoma of the hard palate: a case report. Ear Nose Throat J. Dec. 2001;80(12):872-5. CASE REPORT. [pmid: 11775520].
650 Holub Z, Eim J, Jabor A, Hendl A, Lukac J, Kliment L. Complications and myoma recurrence after laparoscopic uterine artery occlusion for symptomatic myomas. J Obstet Gynaecol Res. Feb. 2006;32(1):55-62. X-4. [pmid: 16445526].
651 Holub Z, Jabor A, Lukac J, Kliment L, Urbanek S. Laparoscopic myomectomy with lateral dissection of the uterine artery. Jsls. Oct–Dec. 2005;9(4):447-53. X-4. [pmid: 16381365].
652 Holub Z, Janousek M, Lukac L, Kliment L. Uterine necrosis after laparoscopic uterine vessel dissection for symptomatic fibroid—a case report. Clin Exp Obstet Gynecol. 2004;31(2):149-50. CASE REPORT. [pmid: 15266775].
653 Holub Z, Kliment L. Laparoscopic ultrasonic dissection of uterine vessels in women with benign uterine pathologies. Clin Exp Obstet Gynecol. 2002;29(1):54-6. X-4. [pmid: 12013096].
654 Holub Z, Kliment L, Ouhrabkova R. Laparoscopic hysterectomy using ultrasonic instruments in at risk women with cardiovascular disease: 2 cases reports. Clin Exp Obstet Gynecol. 2000;27(1):39-41. CASE REPORT. [pmid: 10758798].
655 Holub Z, Lukac J, Kliment L, Urbanek S. Short-term results from laparoscopic dissection of uterine vessels in women with symptomatic fibroids. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):94-8. X-4. [pmid: 12932880].
656 Holub Z, Lukac J, Kliment L, Urbanek S. Variability of the origin of the uterine artery: laparoscopic surgical observation. J Obstet Gynaecol Res. Apr. 2005;31(2):158-63. X-4. [pmid: 15771643].
657 Holub Z, Rokyta Z, Kliment L. Laparoscopic uterine artery dissection in an undiagnosed endometrial stromal sarcoma. Case report. Eur J Gynaecol Oncol. 2005;26(1):111-2. CASE REPORT. [pmid: 15755016].
658 Hong T, Shimada Y, Uchida S, Itami A, Li Z, Ding Y, et al. Expression of angiogenic factors and apoptotic factors in leiomyosarcoma and leiomyoma. Int J Mol Med. Aug. 2001;8(2):141-8. X-6. [pmid: 11445864].
659 Honore JC, Robert B, Vacher-Lavenu MC, Chapron C, Breuiller-Fouche M, Ferre F. Expression of endothelin receptors in human myometrium during pregnancy and in uterine leiomyomas. J Cardiovasc Pharmacol. Nov. 2000;36(5 Suppl 1):S386-9. X-6. [pmid: 11078428].
660 Hori M, Iwasaki M, Shimazaki J, Inagawa S, Itabashi M. Assessment of hypermethylated DNA in two promoter regions of the estrogen receptor alpha gene in human endometrial diseases. Gynecol Oncol. Jan. 2000;76(1):89-96. X-6. [pmid: 10620447].
661 Horiguchi H, Matsui-Horiguchi M, Fujiwara M, Kaketa M, Kawano M, Ohtsubo-Shimoyamada R, et al. Angiomyofibroblastoma of the vulva: report of a case with immunohistochemical and molecular analysis. Int J Gynecol Pathol. Jul. 2003;22(3):277-84. CASE REPORT. [pmid: 12819396].
662 Horiuchi A, Nikaido T, Yoshizawa T, Itoh K, Kobayashi Y, Toki T, et al. HCG promotes proliferation of uterine leiomyomal cells more strongly than that of myometrial smooth muscle cells in vitro. Mol Hum Reprod. Jun. 2000;6(6):523-8. X-6. [pmid: 10825369].
663 Horowitz E, Dekel A, Feldberg D, Rabinerson D. Massive hemoperitoneum due to rupture of an artery overlying a uterine leiomyoma: a case report. Acta Obstet Gynecol Scand. Apr. 2005;84(4):408-9. CASE REPORT. [pmid: 15762978].
664 Hou Y, Wang J, Zhu X, Tao K, Lu X, Du X, et al. A comparative study of esophageal stromal tumors and smooth muscle tumors. Zhonghua Bing Li Xue Za Zhi. Apr. 2002;31(2):116-9. X-6. [pmid: 12419156].
665 Houck WV, Broderick TJ, Cohen SA, Cohen NM. Benign metastasizing leiomyoma. Surg Endosc. Apr. 2002;16(4):716. CASE REPORT. [pmid: 11972229].
666 Houston KD, Copland JA, Broaddus RR, Gottardis MM, Fischer SM, Walker CL. Inhibition of proliferation and estrogen receptor signaling by peroxisome proliferator-activated receptor gamma ligands in uterine leiomyoma. Cancer Res. Mar 15. 2003;63(6):1221-7. X-6. [pmid: 12649180].
667 Hove MG, Kasiya W. Gastro-intestinal stromal tumours (GISTs): a six year Zimbabwean experience. Cellular differentiation with immunocytochemistry. Cent Afr J Med. Dec. 2000;46(12):314-8. X-4. [pmid: 11486470].
668 Hsieh CH, Lui CC, Huang SC, Ou YC, ChangChien CC, Lan KC, et al. Multiple uterine angioleiomyomas in a woman presenting with severe menorrhagia. Gynecol Oncol. Aug. 2003;90(2):348-52. CASE REPORT. [pmid: 12893198].
669 Hsieh YY, Chan IP, Wang HI, Chang CC, Huang CW, Lin CS. PROGINS Alu sequence insertion is associated with hyperprolactinaemia but not leiomyoma susceptibility. Clin Endocrinol (Oxf). Apr. 2005;62(4):492-7. X-6. [pmid: 15807882].
670 Hsieh YY, Chang CC, Hsu CW, Lin CS. Gene transfections with p53 and p21 inhibit cell proliferation, collagen type I, leukemia inhibitory factor, and tumor necrosis factor-alpha expression in leiomyoma cells. Fertil Steril. Jun. 2004;81(6):1665-70. X-6. [pmid: 15193492].
671 Hsieh YY, Chang CC, Tsai FJ, Lin CC, Tsai CH. T homozygote and allele of epidermal growth factor receptor 2073 gene polymorphism are associated with higher susceptibility to endometriosis and leiomyomas. Fertil Steril. Mar. 2005;83(3):796-9. X-6. [pmid: 15749523].
672 Hsieh YY, Chang CC, Tsai FJ, Lin CC, Yeh LS, Peng CT. Androgen receptor trinucleotide polymorphism in leiomyoma. J Assist Reprod Genet. Dec. 2004;21(12):453-7. X-6. [pmid: 15704521].
673 Hsieh YY, Chang CC, Tsai FJ, Lin CC, Yeh LS, Tsai CH. Tumor necrosis factor-alpha-308 promoter and p53 codon 72 gene polymorphisms in women with leiomyomas. Fertil Steril. Oct. 2004;82(Suppl 3):1177-81. X-6. [pmid: 15474092].
674 Hsieh YY, Chang CC, Tsai FJ, Tsai HD, Yeh LS, Lin CC, et al. Estrogen receptor thymine-adenine dinucleotide repeat polymorphism is associated with susceptibility to leiomyoma. Fertil Steril. Jan. 2003;79(1):96-9. X-6. [pmid: 12524070].
675 Hsu IH, Chang TC, Wu CT, Chen RJ, Chow SN. Angiomyofibroblastoma of the vulva. J Formos Med Assoc. Jun. 2004;103(6):467-71. CASE REPORT. [pmid: 15278193].
676 Hsu YH, Chan T, Yuan SS, Wang SL, Su JH. Retroperitoneal leiomyomas: a rare tumor of the pelvis. Kaohsiung J Med Sci. Dec. 2002;18(12):636-9. CASE REPORT. [pmid: 12670041].
677 Huan Y, Dillon RW, Unger PD. Angiomyolipoma of the bladder. Ann Diagn Pathol. Dec. 2002;6(6):378-80. CASE REPORT. [pmid: 12478489].
678 Huang CT, Chien CY, Su CY, Chen WJ. Leiomyoma of the inferior turbinates. J Otolaryngol. Feb. 2000;29(1):55-6. CASE REPORT. [pmid: 10709174].
679 Huang HW, Lee SC, Ho WM, Lai HC, Juang SE. Complications of fluid overloading with different distention media in hysteroscopy—a report of two cases. Acta Anaesthesiol Sin. Sep. 2003;41(3):149-54. CASE REPORT. [pmid: 14601202].
680 Huang HY, Chen WJ, Sung MT, Huang CC. Atypical leiomyoma of the urinary bladder—a rare tumor occurring in a young female with concurrent breast carcinoma—an influence of sex steroid hormone?. Scand J Urol Nephrol. 2002;36(3):231-3. CASE REPORT. [pmid: 12201943].
681 Huang KC, Chuang LM, Chen CY, Chow SN, Lin RS. Serum leptin and leptin receptor isoforms in omental adipose tissue of nondiabetic women undergoing gynecologic surgery for benign disease. J Formos Med Assoc. Nov. 2000;99(11):839-43. X-4. [pmid: 11155773].
682 Huang LY, Cheng YF, Chang HW, Chang SY, Kung FT, Liang HM, et al. Quantified short-term outcome of uterine artery embolization with gelatin sponge particles and lipiodol for symptomatic myoma. Fertil Steril. May. 2004;81(5):1375-82. X-4. [pmid: 15136105].
683 Huang PC, Chen JT, Chia-Man C, Kwan PC, Ho WL. Benign metastasizing leiomyoma of the lung: a case report. J Formos Med Assoc. Dec. 2000;99(12):948-51. CASE REPORT. [pmid: 11155751].
684 Huang SC, Tang MJ, Cheng YM, Hsu KF, Ho CL, Chou CY. Enhanced polyadenosine diphosphate-ribosylation in gonadotropin-releasing hormone agonist-treated uterine leiomyoma. J Clin Endocrinol Metab. Oct. 2003;88(10):5009-16. X-4. [pmid: 14557488].
685 Huang SC, Tang MJ, Hsu KF, Cheng YM, Chou CY. Fas and its ligand, caspases, and bcl-2 expression in gonadotropin-releasing hormone agonist-treated uterine leiomyoma. J Clin Endocrinol Metab. Oct. 2002;87(10):4580-6. X-4. [pmid: 12364438].
686 Huang XF, Wang CM, Pan BR, Dai XW, Fang L, Yang JJ, et al. Pathological characteristics of gastric leiomyoblastoma. World J Gastroenterol. Nov 1. 2004;10(21):3182-4. X-6. [pmid: 15457569].
687 Hui P, Fedoriw G. Recurrent endometrial stromal tumors with smooth-muscle differentiation and a protracted clinical course. Nat Clin Pract Oncol. Nov. 2005;2(11):588-93. quiz. CASE REPORT. [pmid: 16270099].
688 Huilgol RL, Young CJ, Solomon MJ. The gist of it: Case reports of a gastrointestinal stromal tumour and a leiomyoma of the anorectum. ANZ J Surg. Mar. 2003;73(3):167-9. CASE REPORT. [pmid: 12608988].
689 Hulka CA, Hall DA, McCarthy K, Simeone J. Sonographic findings in patients with adenomyosis: can sonography assist in predicting extent of disease?. AJR Am J Roentgenol. Aug. 2002;179(2):379-83. X-6. [pmid: 12130436].
690 Hummel CW, Geiser AG, Bryant HU, Cohen IR, Dally RD, Fong KC, et al. A selective estrogen receptor modulator designed for the treatment of uterine leiomyoma with unique tissue specificity for uterus and ovaries in rats. J Med Chem. Nov 3. 2005;48(22):6772-5. X-6. [pmid: 16250633].
691 Humphrey R, Carlan SJ, Greenbaum L. Rectus sheath hematoma in pregnancy. J Clin Ultrasound. Jun. 2001;29(5):306-11. CASE REPORT. [pmid: 11486328].
692 Hupuczi P, Papp Z. Postoperative ascites associated with intraperitoneal antiseptic lavage. Obstet Gynecol. May. 2005;105(5 Pt 2):1267-8. CASE REPORT. [pmid: 15863605].
693 Hurford WE, Kratz A. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 23-2004. A 50-year-old woman with low oxygen saturation. N Engl J Med. Jul 22. 2004;351(4):380-7. CASE REPORT. [pmid: 15269319].
694 Hussein-Fikret S, Fuller PJ, Gargett CE. Expression of steroid receptor coactivators in cultured cells from paired myometrial and fibroid tissues. J Soc Gynecol Investig. Sep. 2005;12(6):445-51. X-6.
695 Hwang JL, Seow KM, Tsai YL, Huang LW, Hsieh BC, Lee C. Comparative study of vaginal, laparoscopically assisted vaginal and abdominal hysterectomies for uterine myoma larger than 6 cm in diameter or uterus weighing at least 450 g: a prospective randomized study. Acta Obstet Gynecol Scand. Dec. 2002;81(12):1132-8. X-4. [pmid: 12519109].
696 Iacobellis G. Combined treatment with tranexamic acid and oral contraceptive pill causes coronary ulcerated plaque and acute myocardial infarction. Cardiovasc Drugs Ther. May. 2004;18(3):239-40. X-6. [pmid: 15229393].
697 Ikeda K, Kuroda M, Sakaida N, Maehara M, Ohmura N, Sawada S. Cellular leiomyoma of the nasal cavity: findings of CT and MR imaging. AJNR Am J Neuroradiol. Jun–Jul. 2005;26(6):1336-8. CASE REPORT. [pmid: 15956493].
698 Ikeda R, Suga K, Suzuki K. MRI appearance of a leiomyoma of the female urethra. Clin Radiol. Jan. 2001;56(1):76-9. X-6. [pmid: 11162704].
699 Ikota H, Tanimoto A, Komatsu H, Ozawa Y, Matsushita H. Ureteral leiomyoma causing hydronephrosis in Type 1 multiple endocrine neoplasia. Pathol Int. Jun. 2004;54(6):457-9. CASE REPORT. [pmid: 15144407].
700 Ilbey O, Apaydin E, Gursan A, Cikili N. Bladder leiomyoma: a rare cause of urinary stress incontinence. Arch Ital Urol Androl. Jun. 2000;72(2):85-7. CASE REPORT. [pmid: 10953395].
701 Imai A, Sugiyama M, Furui T, Tamaya T. Treatment of perimenopausal women with uterine myoma: successful use of a depot GnRH agonist leading to a natural menopause. J Obstet Gynaecol. Sep. 2003;23(5):518-20. X-5. [pmid: 12963511].
702 Imai S, Ayabe Y, Iiyama T, Muramatsu H, Matsuo Y, Kudo S. Leiomyoma of the prostate: CT and MR findings. Abdom Imaging. Nov–Dec. 2002;27(6):674-6. CASE REPORT. [pmid: 12395254].
703 Imogie AO. Sustenance of women's health after the age of 45 years at the University of Benin, Benin City, Nigeria. Health Care Women Int. Dec. 2000;21(8):717-26. X-6. [pmid: 11813763].
704 Imoh-Ita F, Morgan P, Rymer J. Which is the appropriate hormone replacement therapy after sub-total hysterectomy?. Climacteric. Mar. 2000;3(1):65-7. X-1. [pmid: 11910612].
705 Inaba F, Maekawa I, Inaba N. Giant myomas of the uterus. Int J Gynaecol Obstet. Mar. 2005;88(3):325-6. CASE REPORT. [pmid: 15733893].
706 Inaba H, Ohnishi Y, Inaba M, Niki H, Yamasaki Y, Morita S, et al. Painless mass of the cheek. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jan. 2003;95(1):3-6. CASE REPORT. [pmid: 12539019].
707 Inagaki N, Ung L, Otani T, Wilkinson D, Lopata A. Uterine cavity matrix metalloproteinases and cytokines in patients with leiomyoma, adenomyosis or endometrial polyp. Eur J Obstet Gynecol Reprod Biol. Dec 10. 2003;111(2):197-203. X-6. [pmid: 14597251].
708 Indman PD. Use of carboprost to facilitate hysteroscopic resection of submucous myomas. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):68-72. X-5. [pmid: 15104835].
709 Infante M, Alloisio M, Massone PB, Ravasi G. Thoracoscopic resection of an esophageal stromal tumor through the left pleural cavity. Surg Laparosc Endosc Percutan Tech. Aug. 2001;11(4):273-6. X-6. [pmid: 11525374].
710 Inki P, Hurskainen R, Palo P, Ekholm E, Grenman S, Kivela A, et al. Comparison of ovarian cyst formation in women using the levonorgestrel-releasing intrauterine system vs. hysterectomy. Ultrasound Obstet Gynecol. Oct. 2002;20(4):381-5. X-5. [pmid: 12383322].
711 Inoue K, Tsukuda S, Kayano H, Tanaka J, Heshiki A. A case of hypervascular renal capsule leiomyoma. Radiat Med. Sep–Oct. 2000;18(5):323-6. CASE REPORT. [pmid: 11128405].
712 Isaacs JS, Jung YJ, Mole DR, Lee S, Torres-Cabala C, Chung YL, et al. HIF overexpression correlates with biallelic loss of fumarate hydratase in renal cancer: novel role of fumarate in regulation of HIF stability. Cancer Cell. Aug. 2005;8(2):143-53. X-6. [pmid: 16098467].
713 Ishihara H, Kitawaki J, Kado N, Koshiba H, Fushiki S, Honjo H. Gonadotropin-releasing hormone agonist and danazol normalize aromatase cytochrome P450 expression in eutopic endometrium from women with endometriosis, adenomyosis, or leiomyomas. Fertil Steril. Mar. 2003;79(Suppl 1):735-42. X-6. [pmid: 12620485].
714 Istre O, Hald K, Qvigstad E. Multiple myomas treated with a temporary, noninvasive, Doppler-directed, transvaginal uterine artery clamp. J Am Assoc Gynecol Laparosc. May. 2004;11(2):273-6. CASE REPORT. [pmid: 15200790].
715 Itani Y, Otsuka Y, Deguchi F, Watanabe S, Masuda Y, Miyazaki A, et al. A case report of intravenous leiomyomatosis extending into the heart. Heart Vessels. 2000;15(6):291-4. CASE REPORT. [pmid: 11766068].
716 Ito F, Kawamura N, Ichimura T, Tsujimura A, Ishiko O, Ogita S. Ultrastructural comparison of uterine leiomyoma cells from the same myoma nodule before and after gonadotropin-releasing hormone agonist treatment. Fertil Steril. Jan. 2001;75(1):125-30. X-6. [pmid: 11163826].
717 Ito M, Yamaoka H, Sano K, Hotchi M. Angiomyofibroblastoma of the male inguinal region. Arch Pathol Lab Med. Nov. 2000;124(11):1679-81. CASE REPORT. [pmid: 11079024].
718 Itoh H, Yanagi M, Setoyama T, Shirao K, Yanagi S, Kataoka H, et al. Solitary fibroleiomyomatous hamartoma of the lung in a patient without a pre-existing smooth-muscle tumor. Pathol Int. Aug. 2001;51(8):661-5. CASE REPORT. [pmid: 11564224].
719 Ivell R, Balvers M, Pohnke Y, Telgmann R, Bartsch O, Milde-Langosch K, et al. Immunoexpression of the relaxin receptor LGR7 in breast and uterine tissues of humans and primates. Reprod Biol Endocrinol. Nov 24. 2003;1:114. X-6. [pmid: 14633277]. [pmcid: 293425].
720 Jaaskelainen J. Non-invasive transcranial high intensity focused ultrasound (HIFUS) under MRI thermometry and guidance in the treatment of brain lesions. Acta Neurochir Suppl. 2003;88:57-60. X-1. [pmid: 14531562].
721 Jabar MF, Prasannan S, Gul YA. Adult intussusception secondary to inflammatory polyps. Asian J Surg. Jan. 2005;28(1):58-61. CASE REPORT. [pmid: 15691802].
722 Jacobs MA, Herskovits EH, Kim HS. Uterine fibroids: diffusion-weighted MR imaging for monitoring therapy with focused ultrasound surgery—preliminary study. Radiology. Jul. 2005;236(1):196-203. X-5. [pmid: 15987974].
723 Jain P, Pradhan P, Cietak KA, Anyanwu L. Acute abdomen following spontaneous variceal rupture overlying uterine leiomyoma. J Obstet Gynaecol. Aug. 2004;24(5):589. CASE REPORT. [pmid: 15369956].
724 Jakiel G, Sobstyl M, Wojtowicz M. Fertility following laparoscopic uterine myomectomy in an infertile patient treated for 10 years. Case report. Ann Univ Mariae Curie Sklodowska [Med]. 2002;57(2):217-21. CASE REPORT.
725 Jakimiuk AJ, Bogusiewicz M, Tarkowski R, Dziduch P, Adamiak A, Wrobel A, et al. Estrogen receptor alpha and beta expression in uterine leiomyomas from premenopausal women. Fertil Steril. Oct. 2004;82(Suppl 3):1244-9. X-6. [pmid: 15474102].
726 Jallo GI, Roonprapunt C, Kothbauer K, Freed D, Allen J, Epstein F. Spinal solitary fibrous tumors: a series of four patients: case report. Neurosurgery. Jul. 2005;57(1):E195. discussion E195. CASE REPORT. [pmid: 15987560].
727 Jankovic SM, Varjacic M, Protic B. Relaxant effect of oxytocin on isolated human oviduct. Croat Med J. Oct. 2001;42(5):511-6. X-6. [pmid: 11593499].
728 Jasonni VM, D'Anna R, Mancuso A, Caruso C, Corrado F, Leonardi I. Randomized double-blind study evaluating the efficacy on uterine fibroids shrinkage and on intra-operative blood loss of different length of leuprolide acetate depot treatment before myomectomy. Acta Obstet Gynecol Scand. Oct. 2001;80(10):956-8. X-5. [pmid: 11580742].
729 Jatoi N. Leiomyosarcoma: a rare malignant change in a leiomyoma. J Coll Physicians Surg Pak. Feb. 2003;13(2):106-7. CASE REPORT. [pmid: 12685956].
730 Jeanty P, Besnard S, Arnold A, Turner C, Crum P. Air-contrast sonohysterography as a first step assessment of tubal patency. J Ultrasound Med. Aug. 2000;19(8):519-27. X-6. [pmid: 10944037].
731 Jeon YK, Cha HJ, Kim NR, Kim CJ, Chi JG. Leiomyoma in the posterior choroid: a case report. J Korean Med Sci. Jun. 2002;17(3):429-33. CASE REPORT. [pmid: 12068155].
732 Jeon YT, Kim JW, Park NH, Song YS, Kang SB, Lee HP. DNA repair gene XRCC1 Arg399Gln polymorphism is associated with increased risk of uterine leiomyoma. Hum Reprod. Jun. 2005;20(6):1586-9. X-4. [pmid: 15760950].
733 Jeschke K, Wakonig J, Winzely M, Henning K. Laparoscopic partial cystectomy for leiomyoma of the bladder wall. J Urol. Nov. 2002;168(5):2115-6. CASE REPORT. [pmid: 12394722].
734 Jha RC, Ascher SM, Imaoka I, Spies JB. Symptomatic fibroleiomyomata: MR imaging of the uterus before and after uterine arterial embolization. Radiology. Oct. 2000;217(1):228-35. X-6. [pmid: 11012449].
735 Jha RC, Takahama J, Imaoka I, Korangy SJ, Spies JB, Cooper C, et al. Adenomyosis: MRI of the uterus treated with uterine artery embolization. AJR Am J Roentgenol. Sep. 2003;181(3):851-6. X-6. [pmid: 12933493].
736 Jiang J, Wu RF, Wang ZH, Sun HC, Xu Z, Xiu HM. Effect of mifepristone on estrogen and progesterone receptors in human endometrial and endometriotic cells in vitro. Fertil Steril. May. 2002;77(5):995-1000. X-6. [pmid: 12009357].
737 Jirecek S, Lee A, Pavo I, Crans G, Eppel W, Wenzl R. Raloxifene prevents the growth of uterine leiomyomas in premenopausal women. Fertil Steril. Jan. 2004;81(1):132-6. X-5. [pmid: 14711556].
738 Joffre F, Tubiana JM, Pelage JP. FEMIC (Fibromes Embolises aux MICrospheres calibrees): uterine fibroid embolization using tris-acryl microspheres. A French multicenter study. Cardiovasc Intervent Radiol. Nov–Dec. 2004;27(6):600-6. X-5. [pmid: 15578135].
739 Johnson N, Fletcher H, Reid M. Depo medroxyprogesterone acetate (DMPA) therapy for uterine myomata prior to surgery. Int J Gynaecol Obstet. May. 2004;85(2):174-6. X-4. [pmid: 15099785].
740 Jones K, Walker WJ, Sutton C. A case of failed fibroid embolisation due to an unusual vascular supply. Bjog. Aug. 2003;110(8):782-3. CASE REPORT. [pmid: 12892694].
741 Joo JG, Inovay J, Silhavy M, Papp Z. Successful enucleation of a necrotizing fibroid causing oligohydramnios and fetal postural deformity in the 25th week of gestation. A case report. J Reprod Med. Oct. 2001;46(10):923-5. CASE REPORT. [pmid: 11725739].
742 Jordan LB, Al-Nafussi A, Beattie G. Cotyledonoid hydropic intravenous leiomyomatosis: a new variant leiomyoma. Histopathology. Mar. 2002;40(3):245-52. X-6. [pmid: 11895490].
743 Jordan RC, Regezi JA. Oral spindle cell neoplasms: a review of 307 cases. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jun. 2003;95(6):717-24. X-6. [pmid: 12789154].
744 Joseph KA, Shutter J, El-Tamer M, Schnabel F. Cutaneous subareolar leiomyoma: a rare clinical entity. Breast J. Nov–Dec. 2005;11(6):501-2. CASE REPORT. [pmid: 16297114].
745 Joseph V, Chacko G, Raghuram L, Rajshekhar V. Benign metastasizing leiomyoma causing spinal cord compression. Surg Neurol. Dec. 2003;60(6):575-7. discussion 577–8. CASE REPORT. [pmid: 14670684].
746 Joyce A, Hessami S, Heller D. Leiomyosarcoma after uterine artery embolization. A case report. J Reprod Med. Mar. 2001;46(3):278-80. CASE REPORT. [pmid: 11304875].
747 Jozwik M, Szajda SD, Skrzydlewski Z, Sulkowski S. The activity of cancer procoagulant in cases of uterine leiomyomas. Eur J Gynaecol Oncol. 2005;26(4):407-10. X-6. [pmid: 16122189].
748 Jun SH, Ginsburg ES, Racowsky C, Wise LA, Hornstein MD. Uterine leiomyomas and their effect on in vitro fertilization outcome: a retrospective study. J Assist Reprod Genet. Mar. 2001;18(3):139-43. X-6. [pmid: 11411428].
749 Jung BH, Bai SW, Chung BC. Endogenous urinary steroids in premenopausal women with uterine leiomyomas. Int J Gynaecol Obstet. Jan. 2004;84(1):55-60. X-6. [pmid: 14698830].
750 Jurcic V, Perkovic T, Pohar-Marinsek Z, Hvala A, Lazar I. Infantile myofibroma in a prematurely born twin: a case report. Pediatr Dermatol. Jul–Aug. 2003;20(4):345-9. CASE REPORT. [pmid: 12869160].
751 Kado N, Kitawaki J, Obayashi H, Ishihara H, Koshiba H, Kusuki I, et al. Association of the CYP17 gene and CYP19 gene polymorphisms with risk of endometriosis in Japanese women. Hum Reprod. Apr. 2002;17(4):897-902. X-6. [pmid: 11925378].
752 Kairi-Vassilatou E, Kontogianni K, Salamalekis M, Sykiotis K, Kondi-Pafitis A. A clinicopathological study of the relationship between adenomyosis and other hormone-dependent uterine lesions. Eur J Gynaecol Oncol. 2004;25(2):222-4. X-6. [pmid: 15032287].
753 Kakarla A, Ash AK. Pregnancy after embolisation of a fibroid: emergency caesarean myomectomy. J Obstet Gynaecol. Apr. 2005;25(3):300-1. CASE REPORT. [pmid: 16147744].
754 Kaleli S, Calay Z, Ceydeli N, Aydynly K, Kosebay D. A huge abdominal mass mimicking ovarian cancer: p53-negative but aneuploid myxoid leiomyosarcoma of the uterus. Eur J Obstet Gynecol Reprod Biol. Dec 10. 2001;100(1):96-9. CASE REPORT. [pmid: 11728667].
755 Kalir T, Wu H, Gordon RE, Gil J. Morphometric and electron microscopic analyses of the effect of gonadotropin-releasing hormone agonist treatment on arteriole size in uterine leiomyomas. Arch Pathol Lab Med. Sep. 2000;124(9):1295-8. X-6. [pmid: 10975924].
756 Kam MH, Tan YH, Wong MY. A 12-year experience in the surgical management of vesicovaginal fistulae. Singapore Med J. Apr. 2003;44(4):181-4. X-6. [pmid: 12952029].
757 Kamat NV, Telkar HB, Ramani SK, Thakker AP. Ruptured degenerated uterine fibroid diagnosed by imaging. Obstet Gynecol. Nov. 2001;98(5 Pt 2):961-3. CASE REPORT. [pmid: 11704222].
758 Kamernitskii AV, Levina IS, Kareva EN, Kirpichnikova NV, Mgdesyan KK, Ovchinnikova EV. Relative binding activity of new antigestagens with progesterone receptors in human hyperplastic endometrium. Bull Exp Biol Med. Nov. 2002;134(5):445-7. X-6. [pmid: 12802447].
759 Kaminski AM, Cameron DC, French MA. Leiomyoma of the oesophagus in an HIV-infected patient. Australas Radiol. Feb. 2001;45(1):49-51. CASE REPORT. [pmid: 11259973].
760 Kamoi S, Ohaki Y, Mori O, Yokoyama M, Kawamoto Y, Kawamura T, et al. Epithelioid trophoblastic tumor of the uterus: cytological and immunohistochemical observation of a case. Pathol Int. Jan. 2002;52(1):75-81. CASE REPORT. [pmid: 11940211].
761 Kanamori T, Takakura K, Mandai M, Kariya M, Fukuhara K, Kusakari T, et al. PEP-19 overexpression in human uterine leiomyoma. Mol Hum Reprod. Nov. 2003;9(11):709-17. X-6. [pmid: 14561813].
762 Kanamori T, Takakura K, Mandai M, Kariya M, Fukuhara K, Sakaguchi M, et al. Increased expression of calcium-binding protein S100 in human uterine smooth muscle tumours. Mol Hum Reprod. Oct. 2004;10(10):735-42. X-6. [pmid: 15322223].
763 Kanaoka Y, Hirai K, Ishiko O. Microwave endometrial ablation for an enlarged uterus. Arch Gynecol Obstet. Nov. 2003;269(1):30-2. X-5. [pmid: 14605820].
764 Kanaoka Y, Hirai K, Ishiko O. Microwave endometrial ablation for menorrhagia caused by large submucous myomas. J Obstet Gynaecol Res. Dec. 2005;31(6):565-70. CASE REPORT. [pmid: 16343261].
765 Kanaoka Y, Hirai K, Ishiko O, Ogita S. Microwave endometrial ablation at a frequency of 2.45 GHz. A pilot study. J Reprod Med. Jun. 2001;46(6):559-63. X-5. [pmid: 11441680].
766 Kanaoka Y, Hirai K, Ishiko O, Ogita S. An intranodal morcellation technique employing loop electrosurgical excision procedure for large prolapsed pedunculated myomas. Oncol Rep. Sep–Oct. 2001;8(5):1149-51. CASE REPORT. [pmid: 11496333].
767 Kanelopoulos N, Dendrinos S, Oikonomou A, Panagopoulos P, Markussis V. Doppler-ultrasound as a predictor of uterine fibroid response to GnRH therapy. Int J Gynaecol Obstet. Jul. 2003;82(1):41-7. X-5. [pmid: 12834940].
768 Kanno T, Yoshikawa D, Tomioka A, Kamijyo T, Yamada K, Goto F. Hydrothorax: an unexpected complication after laparoscopic myomectomy. Br J Anaesth. Sep. 2001;87(3):507-9. CASE REPORT. [pmid: 11517142].
769 Kano H, Kanda H. Cervical endometriosis presented as a polypoid mass of portio cervix uteri. J Obstet Gynaecol. Jan. 2003;23(1):84-5. CASE REPORT. [pmid: 12647713].
770 Kao CH. FDG uptake in a huge uterine myoma. Clin Nucl Med. Mar. 2003;28(3):249. X-6. [pmid: 12592145].
771 Kapur U, Hobbs CM, McDermott E, Mooney EE. Gastric glomus tumor. Ann Diagn Pathol. Feb. 2004;8(1):32-5. CASE REPORT. [pmid: 15129908].
772 Karagama YG, Bridges LR, van Hille PT. Angioleiomyoma of the internal auditory meatus: a rare occurrence in the internal auditory canal. Ear Nose Throat J. Apr. 2005;84(4):216-218. CASE REPORT. [pmid: 15929320].
773 Karamercan A, Kurukahvecioglu O, Yilmaz TU, Aygencel G, Aytac B, Sare M. Adult ileal intussusception: an unusual emergency condition. Adv Ther. Jan–Feb. 2006;23(1):163-8. CASE REPORT. [pmid: 16644617].
774 Karcaaltincaba M, Sudakoff GS. CT of a ruptured pyomyoma. AJR Am J Roentgenol. Nov. 2003;181(5):1375-7. CASE REPORT. [pmid: 14573437].
775 Karci A, Erkin Y. Transient blindness following hysteroscopy. J Int Med Res. Mar–Apr. 2003;31(2):152-5. CASE REPORT. [pmid: 12760320].
776 Karim BO, Burroughs FH, Rosenthal DL, Ali SZ. Endometrial-type cells in cervico-vaginal smears: clinical significance and cytopathologic correlates. Diagn Cytopathol. Feb. 2002;26(2):123-7. X-6. [pmid: 11813332].
777 Karnak I, Akcoren Z, Senocak ME. Endobronchial leiomyoma in children. Eur J Pediatr Surg. Apr. 2000;10(2):136-9. CASE REPORT. [pmid: 10877085].
778 Karuppaswamy J, Tapp A. Leiomyomatosis peritonealis disseminata-is a different approach needed?. J Obstet Gynaecol. Jul. 2002;22(4):446-7. X-1. [pmid: 12521481].
779 Kasai T, Shozu M, Murakami K, Segawa T, Shinohara K, Nomura K, et al. Increased expression of type I 17beta-hydroxysteroid dehydrogenase enhances in situ production of estradiol in uterine leiomyoma. J Clin Endocrinol Metab. Nov. 2004;89(11):5661-8. X-6. [pmid: 15531526].
780 Kasayama S, Miyake S, Samejima Y. Transient thyrotoxicosis and hypothyroidism following administration of the GnRH agonist leuprolide acetate. Endocr J. Dec. 2000;47(6):783-5. CASE REPORT. [pmid: 11228054].
781 Kashyape SS, Bhavsar SK. Solitary intestinal leiomyoma. Indian Pediatr. Nov. 2005;42(11):1170. CASE REPORT. [pmid: 16340064].
782 Kassanos D, Salamalekis E, Vitoratos N, Panayotopoulos N, Loghis C, Creatsas C. The value of transvaginal ultrasonography in diagnosis and management of cervical incompetence. Clin Exp Obstet Gynecol. 2001;28(4):266-8. X-6. [pmid: 11838756].
783 Kassenoff TL, Tabaee A, Kacker A. Myofibroma of the cheek: a case report. Ear Nose Throat J. Jun. 2004;83(6):404-7. CASE REPORT. [pmid: 15266876].
784 Kataoka S, Yamada H, Hoshi N, Kudo M, Hareyama H, Sakuragi N, et al. Cytogenetic analysis of uterine leiomyoma: the size, histopathology and GnRHa-response in relation to chromosome karyotype. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):58-62. X-6. [pmid: 12932873].
785 Kato K, Shiozawa T, Mitsushita J, Toda A, Horiuchi A, Nikaido T, et al. Expression of the mitogen-inducible gene-2 (mig-2) is elevated in human uterine leiomyomas but not in leiomyosarcomas. Hum Pathol. Jan. 2004;35(1):55-60. X-6. [pmid: 14745725].
786 Kato T, Kobayashi T, Ikeda R, Nakamura T, Akakura K, Hikage T, et al. Urethral leiomyoma expressing estrogen receptors. Int J Urol. Jul. 2004;11(7):573-5. CASE REPORT. [pmid: 15242374].
787 Katrak MP, Mehta NN, Sinha AS, Patnaik PS, Khithani AS, Joshi RM. Extraserosal pedunculated leiomyoma of stomach. Indian J Gastroenterol. Sep–Oct. 2002;21(5):200-1. CASE REPORT. [pmid: 12416754].
788 Katsumori T, Akazawa K, Mihara T. Uterine artery embolization for pedunculated subserosal fibroids. AJR Am J Roentgenol. Feb. 2005;184(2):399-402. X-5. [pmid: 15671352].
789 Katsumori T, Bamba M, Kobayashi TK, Moritani S, Urabe M, Nakajima K, et al. Uterine leiomyoma after embolization by means of gelatin sponge particles alone: report of a case with histopathologic features. Ann Diagn Pathol. Oct. 2002;6(5):307-11. CASE REPORT. [pmid: 12376924].
790 Katsumori T, Nakajima K, Mihara T, Tokuhiro M. Uterine artery embolization using gelatin sponge particles alone for symptomatic uterine fibroids: midterm results. AJR Am J Roentgenol. Jan. 2002;178(1):135-9. X-5. [pmid: 11756107].
791 Katsumori T, Nakajima K, Tokuhiro M. Gadolinium-enhanced MR imaging in the evaluation of uterine fibroids treated with uterine artery embolization. AJR Am J Roentgenol. Aug. 2001;177(2):303-7. X-6. [pmid: 11461850].
792 Kausch I, Galle J, Buttner H, Bohle A, Jocham D. Leiomyo-adenomatoid tumor of the epididymis. J Urol. Aug. 2002;168(2):636. CASE REPORT. [pmid: 12131327].
793 Kaushik R, Attri AK, Kaur L, Nada R. Leiomyoma of the vas deferens. J Postgrad Med. Apr–Jun. 2001;47(2):133-4. CASE REPORT. [pmid: 11832607].
794 Kawagishi N, Kashiwagi T, Ibe M, Manabe A, Ishida-Yamamoto A, Hashimoto Y, et al. Pleomorphic angioleiomyoma. Am J Dermatopathol. Jun. 2000;22(3):268-71. CASE REPORT. [pmid: 10871073].
795 Kawahara C, Tanaka Y, Kato H, Watanabe S, Kokubun S. Myolysis of the erector spinae muscles as the cause of scoliosis in osteoid osteoma of the spine. Spine. Jun 15. 2002;27(12):E313-5. CASE REPORT. [pmid: 11805698].
796 Kawamura K, Sekiguchi K, Shibata S, Fukuda J, Kodama H, Tanaka T. Immunohistochemical analysis of adenomatoid tumor of the uterus utilizing of monoclonal antibody HBME-1. Acta Obstet Gynecol Scand. Sep. 2000;79(9):798-9. X-6. [pmid: 10993108].
797 Kawamura N, Ichimura T, Ito F, Shibata S, Takahashi K, Tsujimura A, et al. Transcervical needle biopsy for the differential diagnosis between uterine sarcoma and leiomyoma. Cancer. Mar 15. 2002;94(6):1713-20. X-6. [pmid: 11920533].
798 Kawamura N, Iwanaga N, Hada S, Maeda K, Sumi T, Ishiko O, et al. Transient shrinkage of a uterine leiomyosarcoma treated with GnRH agonist for a presumed uterine leiomyoma: comparison of magnetic resonance imaging finding before and during GnRH agonist treatment. Oncol Rep. Nov–Dec. 2001;8(6):1255-7. CASE REPORT. [pmid: 11605044].
799 Kawate S, Takeyoshi I, Ikota H, Numaga Y, Sunose Y, Morishita Y. Endometrioid adenocarcinoma arising from endometriosis of the mesenterium of the sigmoid colon. Jpn J Clin Oncol. Mar. 2005;35(3):154-7. CASE REPORT. [pmid: 15741306].
800 Kayes AV, Bancroft LW, Tennyson GS, O'Connor MI. Myofibroma of the upper arm in a 52-year-old woman. Skeletal Radiol. Apr. 2002;31(4):240-5. CASE REPORT. [pmid: 11904694].
801 Kaymak O, Ustunyurt E, Okyay RE, Kalyoncu S, Mollamahmutoglu L. Myomectomy during cesarean section. Int J Gynaecol Obstet. May. 2005;89(2):90-3. X-4. [pmid: 15847868].
802 Kayser K, Zink S, Schneider T, Dienemann H, Andre S, Kaltner H, et al. Benign metastasizing leiomyoma of the uterus: documentation of clinical, immunohistochemical and lectin-histochemical data of ten cases. Virchows Arch. Sep. 2000;437(3):284-92. X-6. [pmid: 11037349].
803 Kazandi M, Aksehirli S, Cirpan T, Akercan F. Transvaginal sonography combined with saline contrast sonohysterography to evaluate the uterine cavity in patients with abnormal uterine bleeding and postmenopausal endometrium more than 5 mm. Eur J Gynaecol Oncol. 2003;24(2):185-90. X-6. [pmid: 12701976].
804 Kazsuba A, Vitez A, Gall J, Mathe L, Ludmany E, Krasznai G. Gastric hyalinization as a possible consequence of corrosive injury. Endoscopy. Apr. 2000;32(4):356-8. CASE REPORT. [pmid: 10774977].
805 Kebapci M, Aslan O, Kaya T, Yalcin OT, Ozalp S. Pedunculated uterine leiomyoma associated with pseudo-Meigs' syndrome and elevated CA-125 level: CT features. Eur Radiol. Dec. 2002;12(Suppl 3):S127-9. CASE REPORT. [pmid: 12522621].
806 Kemper MJ, Ganschow R, Helmke K, Muller-Wiefel DE. The child with haematuria and dysphagia. Nephrol Dial Transplant. Oct. 2000;15(10):1694-5. CASE REPORT. [pmid: 11007845].
807 Keogh CF, Torreggiani WC, Gee R, O'Connell JX, Munk PL. Fibroid in the buttock: an unexpected diagnosis. Skeletal Radiol. Aug. 2003;32(8):472-5. CASE REPORT. [pmid: 12802521].
808 Kerlan RK Jr, Coffey JO, Milkman MS, LaBerge JM, Wilson MW, Cea Wolanske KA, et al. Massive vaginal hemorrhage after uterine fibroid embolization. J Vasc Interv Radiol. Nov. 2003;14(11):1465-7. CASE REPORT. [pmid: 14605115].
809 S. Kesavan and N. Q. Walford. Test and teach. Number One hundred and three. Plexiform fibrohistiocytic tumor. Pathology. 2000 Aug;32(3):200–1; 225–6. X-1
810 Keshavarzi A, Vaezy S, Kaczkowski PJ, Keilman G, Martin R, Chi EY, et al. Attenuation coefficient and sound speed in human myometrium and uterine fibroid tumors. J Ultrasound Med. May. 2001;20(5):473-80. X-6. [pmid: 11345104].
811 Kew CC, Putti TC, Razvi K. Malignant mesenchymoma arising from a uterine leiomyoma in the menopause. Gynecol Oncol. Dec. 2004;95(3):712-5. CASE REPORT. [pmid: 15581987].
812 Keyoung JA, Levy EB, Roth AR, Gomez-Jorge J, Chang TC, Spies JB. Intraarterial lidocaine for pain control after uterine artery embolization for leiomyomata. J Vasc Interv Radiol. Sep. 2001;12(9):1065-9. X-6. [pmid: 11535769].
813 Khaitan A, Seth A, Dinda AK, Singh I, Talwar M, Bandhu S. Transurethral resection versus open surgery for leiomyoma of urinary bladder—a report of 2 cases. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(4):270-3. CASE REPORT. [pmid: 12189436].
814 Khanna N, Isles E. An unsuspected case of a degenerating leiomyoma. J Am Board Fam Pract. Jul–Aug. 2000;13(4):305-7. CASE REPORT. [pmid: 10933295].
815 Khaund A, Moss JG, McMillan N, Lumsden MA. Evaluation of the effect of uterine artery embolisation on menstrual blood loss and uterine volume. Bjog. Jul. 2004;111(7):700-5. X-5. [pmid: 15198761].
816 Khayata GM, Thwaini S, Aswad SG. Intravenous leiomyomatosis extending to the heart. Int J Gynaecol Obstet. Jan. 2003;80(1):59-60. CASE REPORT. [pmid: 12527462].
817 Khorram O, Garthwaite M, Golos T. Uterine and ovarian aryl hydrocarbon receptor (AHR) and aryl hydrocarbon receptor nuclear translocator (ARNT) mRNA expression in benign and malignant gynaecological conditions. Mol Hum Reprod. Jan. 2002;8(1):75-80. X-6. [pmid: 11756572].
818 Khorram O, Garthwaite M, Grosen E, Golos T. Human uterine and ovarian expression of growth hormone-releasing hormone messenger RNA in benign and malignant gynecologic conditions. Fertil Steril. Jan. 2001;75(1):174-9. X-6. [pmid: 11163834].
819 Kido A, Monma C, Togashi K, Ueda H, Itoh K, Fujii S, et al. Uterine arterial embolization for the treatment of diffuse leiomyomatosis. J Vasc Interv Radiol. May. 2003;14(5):643-7. X-6. [pmid: 12761320].
820 Kiguli-Malwadde E, Byanyima RK. Structural findings at hysterosalpingography in patients with infertility at two private clinics in Kampala, Uganda. Afr Health Sci. Dec. 2004;4(3):178-81. X-4. [pmid: 15687070].
821 Kilian AK, Ringle T, Waag KL, Duber C, Neff KW. Pre- and postoperative MRI of esophageal and gastric leiomyomatosis in a pediatric patient. AJR Am J Roentgenol. Mar. 2005;184(3 Suppl):S129-31. CASE REPORT. [pmid: 15728005].
822 Kim BY, Cho CH, Song DK, Mun KC, Suh SI, Kim SP, et al. Ciglitizone inhibits cell proliferation in human uterine leiomyoma via activation of store-operated Ca2+ channels. Am J Physiol Cell Physiol. Feb. 2005;288(2):C389-95. X-6. [pmid: 15469956].
823 Kim DH, Lee ES, Park SD. A safer, simpler, classic intrafascial supracervical hysterectomy technique. Jsls. Apr–Jun. 2005;9(2):159-62. X-6. [pmid: 15984702].
824 Kim DI, Lee TK, Lim IS, Kim H, Lee YC, Kim CH. Regulation of IGF-I production and proliferation of human leiomyomal smooth muscle cells by Scutellaria barbata D. Don in vitro: isolation of flavonoids of apigenin and luteolin as acting compounds. Toxicol Appl Pharmacol. Jun 15. 2005;205(3):213-24. X-6. [pmid: 15922007].
825 Kim JC, Kim SS, Park JY. “Bridging vascular sign” in the MR diagnosis of exophytic uterine leiomyoma. J Comput Assist Tomogr. Jan–Feb. 2000;24(1):57-60. X-6. [pmid: 10667660].
826 Kim JG, Kim MH, Kim IS, Moon SY, Kang SB, Lee HP, et al. Decreased expression of mac25 mRNA in uterine leiomyomata compared with adjacent myometrium. Am J Reprod Immunol. Jan. 2000;43(1):53-7. X-6. [pmid: 10698042].
827 Kim MD, Won JW, Lee DY, Ahn CS. Uterine artery embolization for adenomyosis without fibroids. Clin Radiol. Jun. 2004;59(6):520-6. X-6. [pmid: 15145722].
828 Kim MJ, Park YK, Cho JH. Cotyledonoid dissecting leiomyoma of the uterus: a case report and review of the literature. J Korean Med Sci. Dec. 2002;17(6):840-4. CASE REPORT. [pmid: 12483013].
829 Kim MK, Higgins J, Cho EY, Ko YH, Oh YL. Expression of CD34, bcl-2, and kit in inflammatory fibroid polyps of the gastrointestinal tract. Appl Immunohistochem Mol Morphol. Jun. 2000;8(2):147-53. X-6. [pmid: 10937062].
830 Kim NR, Sung CO, Han J. Bizarre leiomyoma of the scrotum. J Korean Med Sci. Jun. 2003;18(3):452-4. CASE REPORT. [pmid: 12808340].
831 Kim SH, Sim JS, Seong CK. Interface vessels on color/power Doppler US and MRI: a clue to differentiate subserosal uterine myomas from extrauterine tumors. J Comput Assist Tomogr. Jan–Feb. 2001;25(1):36-42. X-6. [pmid: 11176291].
832 Kim TI, Park YS, Choi EH, Park SW, Chung JB, Kang JK, et al. Endoscopic resection of a large leiomyoma of the esophagus. Gastrointest Endosc. Jan. 2004;59(1):129-33. CASE REPORT. [pmid: 14722568].
833 Kimura T, Inoue T, Katayama K, Hirose K, Imamura Y, Yamaguchi A. Mesenteric Castleman's disease: report of a case. Surg Today. 2002;32(7):651-4. CASE REPORT. [pmid: 12111527].
834 Kimura T, Kusui C, Matsumura Y, Ogita K, Isaka S, Nakajima A, et al. Effectiveness of hormonal tourniquet by vasopressin during myomectomy through vasopressin V1a receptor ubiquitously expressed in myometrium. Gynecol Obstet Invest. 2002;54(3):125-31. X-5. [pmid: 12571432].
835 Kir G, Cetiner H, Gurbuz A, Eren S. Immunohistochemical profile of intravenous leiomyomatosis. Eur J Gynaecol Oncol. 2004;25(4):481-3. X-6. [pmid: 15285309].
836 Kir G, Cetiner H, Karateke A, Gurbuz A, Bulbul D. Utility of MIB-1 and estrogen and progesterone receptor in distinguishing between endometrial stromal sarcomas and endometrial stromal nodules, highly cellular leiomyomas. Int J Gynecol Cancer. Mar–Apr. 2005;15(2):337-42. X-6. [pmid: 15823122].
837 Kir G, Kir M, Gurbuz A, Karateke A, Aker F. Estrogen and progesterone expression of vessel walls with intravascular leiomyomatosis; discussion of histogenesis. Eur J Gynaecol Oncol. 2004;25(3):362-6. X-6. [pmid: 15171320].
838 Kiran G, Kiran H, Coban YK, Guven AM. Ovarian cortical transplantation may be an alternative to hormone therapy in patients with early climacterium. Fertil Steril. Nov. 2005;84(5):1509. CASE REPORT. [pmid: 16275256].
839 Kiran G, Kiran H, Coban YK, Guven AM, Yuksel M. Fresh autologous transplantation of ovarian cortical strips to the anterior abdominal wall at the pfannenstiel incision site. Fertil Steril. Oct. 2004;82(4):954-6. CASE REPORT. [pmid: 15482779].
840 Kirk VG, McFadden S, Pinto A, Boag G, Sigalet DL. Leiomyoma of the esophagus associated with bronchial obstruction owing to inflammatory pseudotumor in a child. J Pediatr Surg. May. 2000;35(5):771-4. CASE REPORT. [pmid: 10813347].
841 Kitao K, Ohara N, Funakoshi T, Moriyama T, Morita H, Kitazawa S, et al. Consumptive coagulopathy that developed in a pregnant woman with degenerated uterine leiomyoma: case report. Clin Exp Obstet Gynecol. 2005;32(4):250. CASE REPORT. [pmid: 16440826].
842 Kitawaki J, Ishihara H, Koshiba H, Kiyomizu M, Teramoto M, Kitaoka Y, et al. Usefulness and limits of CA-125 in diagnosis of endometriosis without associated ovarian endometriomas. Hum Reprod. Jul. 2005;20(7):1999-2003. X-6. [pmid: 15890727].
843 Kitawaki J, Koshiba H, Ishihara H, Kusuki I, Tsukamoto K, Honjo H. Progesterone induction of 17beta-hydroxysteroid dehydrogenase type 2 during the secretory phase occurs in the endometrium of estrogen-dependent benign diseases but not in normal endometrium. J Clin Endocrinol Metab. Sep. 2000;85(9):3292-6. X-6. [pmid: 10999824].
844 Kitawaki J, Koshiba H, Ishihara H, Kusuki I, Tsukamoto K, Honjo H. Expression of leptin receptor in human endometrium and fluctuation during the menstrual cycle. J Clin Endocrinol Metab. May. 2000;85(5):1946-50. X-6. [pmid: 10843179].
845 Kitawaki J, Obayashi H, Ishihara H, Koshiba H, Kusuki I, Kado N, et al. Oestrogen receptor-alpha gene polymorphism is associated with endometriosis, adenomyosis and leiomyomata. Hum Reprod. Jan. 2001;16(1):51-55. X-6. [pmid: 11139535].
846 Kiuru M, Launonen V, Hietala M, Aittomaki K, Vierimaa O, Salovaara R, et al. Familial cutaneous leiomyomatosis is a two-hit condition associated with renal cell cancer of characteristic histopathology. Am J Pathol. Sep. 2001;159(3):825-9. X-6. [pmid: 11549574]. [pmcid: 1850481].
847 Kiuru M, Lehtonen R, Arola J, Salovaara R, Jarvinen H, Aittomaki K, et al. Few FH mutations in sporadic counterparts of tumor types observed in hereditary leiomyomatosis and renal cell cancer families. Cancer Res. Aug 15. 2002;62(16):4554-7. X-6. [pmid: 12183404].
848 Kiuru M, Lehtonen R, Eerola H, Aittomaki K, Blomqvist C, Nevanlinna H, et al. No germline FH mutations in familial breast cancer patients. Eur J Hum Genet. Apr. 2005;13(4):506-9. X-6. [pmid: 15523491].
849 Klein A, Schwartz ML. Uterine artery embolization for the treatment of uterine fibroids: an outpatient procedure. Am J Obstet Gynecol. Jun. 2001;184(7):1556-60. discussion 1560–3. X-5. [pmid: 11408880].
850 Klemi P, Alanen K, Hietanen S, Grenman S, Varpula M, Salmi T. Response of estrogen receptor-positive intraabdominal fibromatosis to aromatase inhibitor therapy. Obstet Gynecol. Nov. 2003;102(5 Pt 2):1155-8. X-6. [pmid: 14607040].
851 Klijanienko J, Caillaud JM, Lagace R, Vielh P. Fine-needle aspiration of leiomyosarcoma: a correlative cytohistopathological study of 96 tumors in 68 patients. Diagn Cytopathol. Mar. 2003;28(3):119-25. X-6. [pmid: 12619091].
852 Klip H, van Leeuwen FE, Schats R, Burger CW. Risk of benign gynaecological diseases and hormonal disorders according to responsiveness to ovarian stimulation in IVF: a follow-up study of 8714 women. Hum Reprod. Sep. 2003;18(9):1951-8. X-6. [pmid: 12923156].
853 Knoop M, St Friedrichs K, Dierschke J. Surgical management of gastrointestinal stromal tumors of the stomach. Langenbecks Arch Surg. Apr. 2000;385(3):194-8. X-6. [pmid: 10857490].
854 Kobayashi A, Amagasa T, Okada N. Leiomyomatous hamartoma of the tongue: case report. J Oral Maxillofac Surg. Mar. 2001;59(3):337-40. CASE REPORT. [pmid: 11243621].
855 Kocaoglu M, Bulakbasi N, Ugurel MS, Ors F, Tayfun C, Ucoz T. Value of magnetic resonance imaging in the depiction of intravenous leiomyomatosis extending to the heart. J Comput Assist Tomogr. Jul–Aug. 2003;27(4):630-3. X-6. [pmid: 12886157].
856 Koehler F, Kivelitz D. Images in clinical medicine. A calcified pelvic mass. N Engl J Med. Jun 3. 2004;350(23):e21. CASE REPORT. [pmid: 14702424].
857 Koh DM, Burn PR, King DM. Benign metastasizing leiomyoma with intracaval leiomyomatosis. Br J Radiol. Apr. 2000;73(868):435-7. CASE REPORT. [pmid: 10844871].
858 Kohama T, Shinohara K, Takahura M, Inoue M. Large uterine myoma with erythropoietin messenger RNA and erythrocytosis. Obstet Gynecol. Nov. 2000;96(5 Pt 2):826-8. CASE REPORT. [pmid: 11094224].
859 Kohler C, Hasenbein K, Klemm P, Tozzi R, Schneider A. Laparoscopic-assisted vaginal hysterectomy with lateral transsection of the uterine vessels. Surg Endosc. Mar. 2003;17(3):485-90. X-6. [pmid: 12415337].
860 Kojima T, Ishiko O, Ichimura T, Nishimura S, Sumi T, Ueda J, et al. The usefulness and limits of magnetic resonance imaging in the differential diagnosis of pelvic tumors. Oncol Rep. Jul–Aug. 2001;8(4):867-9. X-6. [pmid: 11410800].
861 Kojiro S, Tomioka Y, Takemoto Y, Nishida N, Kamura T, Kojiro M. Primary leiomyoma of the ovary—a report of 2 resected cases. Kurume Med J. 2003;50(34):169-72. CASE REPORT. [pmid: 14768483].
862 Kokawa K, Yamoto M, Yata C, Mabuchi Y, Umesaki N. Postmenopausal intravenous leiomyomatosis with high levels of estradiol and estrogen receptor. Obstet Gynecol. Nov. 2002;100(5 Pt 2):1124-6. CASE REPORT. [pmid: 12423831].
863 Kondera-Anasz Z, Mielczarek-Palacz A, Sikora J. Soluble Fas receptor and soluble Fas ligand in the serum of women with uterine tumors. Apoptosis. Oct. 2005;10(5):1143-9. X-4. [pmid: 16151647].
864 Kondi-Pafiti A, Spanidou-Carvouni H, Dimopoulou C, Kontogianni CI. Endometrioid adenocarcinoma arising in uteri with incomplete fusion of Mullerian ducts. Report of three cases. Eur J Gynaecol Oncol. 2003;24(1):83-4. CASE REPORT. [pmid: 12691326].
865 Konig A, Happle R. Two cases of type 2 segmental manifestation in a family with cutaneous leiomyomatosis. Eur J Dermatol. Dec. 2000;10(8):590-2. CASE REPORT. [pmid: 11125318].
866 Konkle BA, Bauer KA, Weinstein R, Greist A, Holmes HE, Bonfiglio J. Use of recombinant human antithrombin in patients with congenital antithrombin deficiency undergoing surgical procedures. Transfusion. Mar. 2003;43(3):390-4. X-6. [pmid: 12675726].
867 Konstantinidis K, Theodoropoulos GE, Spanomihos G, Sambalis G, Vorias M, Georgiou M, et al. Laparoscopic-assisted small bowel resection of a leiomyoma causing recurrent obscure gastrointestinal bleeding. J Laparoendosc Adv Surg Tech A. Aug. 2005;15(4):396-9. CASE REPORT. [pmid: 16108744].
868 Kopitovic V, Bujas M, Fistes Topalski N, Pjevic M, Ilic D, Kapamadzija A, et al. Clinical efficacy of goserelin (Zoladex) in the treatment of uterine myomas in infertile patients. Med Pregl. Jul–Aug. 2001;54(78):339-46. X-5. [pmid: 11905182].
869 Korman U, Kuruoglu S, Haider S. Rare complication of intestinal Crohn's disease: giant fibroid polyp. Eur Radiol. 2000;10(3):435-7. CASE REPORT. [pmid: 10756991].
870 Koshiyama M, Morita Y, Fujii H, Kobashi Y, Yoshida M. Gynecologic malignancies accompanied by benign hormone-dependent diseases. Menopause. Summer. 2001;8(2):149-50. X-6. [pmid: 11256876].
871 Koshiyama M, Okamoto T, Ueta M. The relationship between endometrial carcinoma and coexistent adenomyosis uteri, endometriosis externa and myoma uteri. Cancer Detect Prev. 2004;28(2):94-8. X-6. [pmid: 15068832].
872 Kovac SR. Hysterectomy outcomes in patients with similar indications. Obstet Gynecol. Jun. 2000;95(6 Pt 1):787-93. X-6. [pmid: 10831967].
873 Kovacs KA, Lengyel F, Kornyei JL, Vertes Z, Szabo I, Sumegi B, et al. Differential expression of Akt/protein kinase B, Bcl-2 and Bax proteins in human leiomyoma and myometrium. J Steroid Biochem Mol Biol. Dec. 2003;87(45):233-40. X-6. [pmid: 14698203].
874 Kovacs KA, Oszter A, Gocze PM, Kornyei JL, Szabo I. Comparative analysis of cyclin D1 and oestrogen receptor (alpha and beta) levels in human leiomyoma and adjacent myometrium. Mol Hum Reprod. Nov. 2001;7(11):1085-91. X-6. [pmid: 11675476].
875 Kovacs P, Stangel JJ, Santoro NF, Lieman H. Successful pregnancy after transient ovarian failure following treatment of symptomatic leiomyomata. Fertil Steril. Jun. 2002;77(6):1292-5. CASE REPORT. [pmid: 12057745].
876 Kriplani A, Agarwal N, Parul D, Bhatla N, Saxena AK. Prolapsed leiomyoma with severe haemorrhage after GnRH analogue therapy. J Obstet Gynaecol. Jul. 2002;22(4):449-51. CASE REPORT. [pmid: 12521484].
877 Kroencke TJ, Gauruder-Burmester A, Enzweiler CN, Taupitz M, Hamm B. Disintegration and stepwise expulsion of a large uterine leiomyoma with restoration of the uterine architecture after successful uterine fibroid embolization: case report. Hum Reprod. Apr. 2003;18(4):863-5. CASE REPORT. [pmid: 12660286].
878 Kruschinski D, Homburg S. Lift-(gasless) laparoscopic surgery under regional anesthesia. Surg Technol Int. 2005;14:193-6. X-6. [pmid: 16525973].
879 Kugelman A, Greif Y, Gershoni-Baruch R, Berkowitz D, Best LA, Guralnik L, et al. Pulmonary presentation of esophageal leiomyomatosis associated with Alport syndrome in childhood. Isr Med Assoc J. Apr. 2003;5(4):293-4. CASE REPORT. [pmid: 14509139].
880 Kugimoto Y, Asami A, Shigematsu M, Hotokebuchi T. Giant vascular leiomyoma with extensive calcification in the forearm. J Orthop Sci. 2004;9(3):310-3. CASE REPORT. [pmid: 15168189].
881 Kulshrestha R, Lakhey M, Rani S. Massive cystic degeneration of a uterine leiomyoma presenting as an ovarian cyst: a case report. Indian J Pathol Microbiol. Jan. 2003;46(1):86-8. CASE REPORT. [pmid: 15027737].
882 Kumru S, Aydin S, Aras A, Gursu MF, Gulcu F. Effects of surgical menopause and estrogen replacement therapy on serum paraoxonase activity and plasma malondialdehyde concentration. Gynecol Obstet Invest. 2005;59(2):108-12. X-6. [pmid: 15591805].
883 Kunimatsu N, Kunimatsu A, Kojima K, Hirabayasi Y, Ohtomo K. A case of renal angioleiomyoma with rapid growing: CT findings with histopathological correlation. Radiat Med. Nov–Dec. 2004;22(6):437-41. CASE REPORT. [pmid: 15648463].
884 Kuo MJ, Yeh HZ, Chen GH, Jan YJ. Diffuse esophageal leiomyomatosis with a pedunculated polyp. J Gastroenterol. Dec. 2004;39(12):1205-9. CASE REPORT. [pmid: 15622487].
885 Kuppermann M, Summitt RL Jr, Varner RE, McNeeley SG, Goodman-Gruen D, Learman LA, et al. Sexual functioning after total compared with supracervical hysterectomy: a randomized trial. Obstet Gynecol. Jun. 2005;105(6):1309-18. X-6. [pmid: 15932822].
886 Kurachi O, Matsuo H, Samoto T, Maruo T. Tumor necrosis factor-alpha expression in human uterine leiomyoma and its down-regulation by progesterone. J Clin Endocrinol Metab. May. 2001;86(5):2275-80. X-6. [pmid: 11344239].
887 Kuriakose R, Koshy RC. Anesthetic management of autoimmune polyglandular syndrome (Schmidt's syndrome)—a case report. Middle East J Anesthesiol. Oct. 2005;18(3):639-46. CASE REPORT. [pmid: 16381269].
888 Kurokawa S, Kojima Y, Tozawa K, Hayashi Y, Sasaki S, Kohri K. Female paraurethral leiomyoma: immunohistochemical approach to the relationship between leiomyoma and ovarian hormones. J Urol. Mar. 2002;167(3):1403-4. X-6. [pmid: 11832751].
889 Kurose K, Mine N, Doi D, Ota Y, Yoneyama K, Konishi H, et al. Novel gene fusion of COX6C at 8q22–23 to HMGIC at 12q15 in a uterine leiomyoma. Genes Chromosomes Cancer. Mar. 2000;27(3):303-7. X-6. [pmid: 10679920].
890 Kurose K, Mine N, Iida A, Nagai H, Harada H, Araki T, et al. Three aberrant splicing variants of the HMGIC gene transcribed in uterine leiomyomas. Genes Chromosomes Cancer. Feb. 2001;30(2):212-7. X-6. [pmid: 11135440].
891 Kusama R, Fujimori M, Hama Y, Shingu K, Ito K, Mochizuki Y, et al. Stromal sarcoma of the breast with leiomyosarcomatous pattern. Pathol Int. Aug. 2002;52(8):534-9. CASE REPORT. [pmid: 12366813].
892 Kutay V, Tuncer M, Harman M, Ekim H, Yakut C. Intracardiac extension of intravenous leiomyoma. Tex Heart Inst J. 2005;32(2):232-4. CASE REPORT. [pmid: 16107124]. [pmcid: 1163482].
893 Kwawukume EY. Myomectomy during cesarean section. Int J Gynaecol Obstet. Feb. 2002;76(2):183-4. X-4. [pmid: 11818118].
894 Kwawukume EY. Caesarean myomectomy. Afr J Reprod Health. Dec. 2002;6(3):38-43. X-4. [pmid: 12685407].
895 Kwon JY, Park KH, Park YN, Cho NH. Effect of cetrorelix acetate on apoptosis and apoptosis regulatory factors in cultured uterine leiomyoma cells. Fertil Steril. Nov. 2005;84(5):1526-8. X-6. [pmid: 16275262].
896 Kwon MS, Lee SS, Ahn GH. Schwannomas of the gastrointestinal tract: clinicopathological features of 12 cases including a case of esophageal tumor compared with those of gastrointestinal stromal tumors and leiomyomas of the gastrointestinal tract. Pathol Res Pract. 2002;198(9):605-13. X-6. [pmid: 12440783].
897 La Fianza A, Alberici E. CT diagnosis of Pseudo-Meigs' syndrome. Clin Radiol. Apr. 2002;57(4):315-7. CASE REPORT. [pmid: 12014881].
898 La Marca A, Carducci Artenisio A, Stabile G, Rivasi F, Volpe A. Evidence for cycle-dependent expression of follicle-stimulating hormone receptor in human endometrium. Gynecol Endocrinol. Dec. 2005;21(6):303-6. X-6. [pmid: 16390776].
899 La Marca A, Giulini S, Vito G, Orvieto R, Volpe A, Jasonni VM. Gestrinone in the treatment of uterine leiomyomata: effects on uterine blood supply. Fertil Steril. Dec. 2004;82(6):1694-6. X-5. [pmid: 15589885].
900 Laato M, Ekfors T, Alanen A, Rajala P, Nurmi M. Leiomyoma of the urinary bladder. Ann Chir Gynaecol. 2001;90(Suppl 215):55-7. CASE REPORT. [pmid: 12041931].
901 Lach B, Benoit BG. Primary composite angiogenic leiomyosarcoma-epithelioid angiosarcoma of the brain. Ultrastruct Pathol. Sep–Oct. 2000;24(5):339-46. CASE REPORT. [pmid: 11071573].
902 LaCoursiere DY, Kennedy J, P C. Retained fragments after total laparoscopic hysterectomy. J Minim Invasive Gynecol. Jan–Feb. 2005;12(1):67-9. CASE REPORT. [pmid: 15904602].
903 Lai AC, Goodwin SC, Bonilla SM, Lai AP, Yegul T, Vott S, et al. Sexual dysfunction after uterine artery embolization. J Vasc Interv Radiol. Jun. 2000;11(6):755-8. CASE REPORT. [pmid: 10877421].
904 Lai CT, Tai MC, Liang CM, Lee HS. Unusual uveal tract tumor: mesectodermal leiomyoma of the ciliary body. Pathol Int. May. 2004;54(5):337-42. CASE REPORT. [pmid: 15086838].
905 Laifer-Narin S, Ragavendra N, Parmenter EK, Grant EG. False-normal appearance of the endometrium on conventional transvaginal sonography: comparison with saline hysterosonography. AJR Am J Roentgenol. Jan. 2002;178(1):129-33. X-6. [pmid: 11756106].
906 Lalor PF, Uribe A, Daum GS. De novo growth of a large preperitoneal lipoleiomyoma of the abdominal wall. Gynecol Oncol. May. 2005;97(2):719-21. CASE REPORT. [pmid: 15863192].
907 Lam PM, Lo KW, Yu MM, Lau TK, Cheung TH. Intravenous leiomyomatosis with atypical histologic features: a case report. Int J Gynecol Cancer. Jan–Feb. 2003;13(1):83-7. CASE REPORT. [pmid: 12631226].
908 Landi S, Fiaccavento A, Zaccoletti R, Barbieri F, Syed R, Minelli L. Pregnancy outcomes and deliveries after laparoscopic myomectomy. J Am Assoc Gynecol Laparosc. May. 2003;10(2):177-81. X-5. [pmid: 12732768].
909 Lang K, Reifenberger J, Ruzicka T, Megahed M. Type 1 segmental cutaneous leiomyomatosis. Clin Exp Dermatol. Nov. 2002;27(8):649-50. CASE REPORT. [pmid: 12472537].
910 Lantsberg S, Rachinsky I, Boguslavsky L, Piura B. Diagnosis of urinary leak following abdominal total hysterectomy using renal scintigraphy. Eur J Obstet Gynecol Reprod Biol. Jul. 2000;91(1):11-3. CASE REPORT. [pmid: 10817871].
911 Larson B, Bremme K, Clyne N, Nordstrom L. Preoperative treatment of anemic women with epoetin beta. Acta Obstet Gynecol Scand. Jun. 2001;80(6):559-62. X-5. [pmid: 11380294].
912 Lasmar RB, Barrozo PR, Dias R, Oliveira MA. Submucous myomas: a new presurgical classification to evaluate the viability of hysteroscopic surgical treatment—preliminary report. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):308-11. X-4. [pmid: 16036188].
913 Launonen V, Vierimaa O, Kiuru M, Isola J, Roth S, Pukkala E, et al. Inherited susceptibility to uterine leiomyomas and renal cell cancer. Proc Natl Acad Sci U S A. Mar 13. 2001;98(6):3387-92. CASE REPORT. [pmid: 11248088]. [pmcid: 30663].
914 Laverge F, D'Angelo A, Davies NJ, Wood A, Amso NN. Spontaneous expulsion of three large fibroids after uterine artery embolization. Fertil Steril. Aug. 2003;80(2):450-2. CASE REPORT. [pmid: 12909514].
915 Lavis R, Igbokwe U, Freeman S, Smith M. Intratesticular angioleiomyoma. Arch Pathol Lab Med. Oct. 2004;128(10):1165-6. CASE REPORT. [pmid: 15387703].
916 Law P, Gedroyc WM, Regan L. Magnetic resonance-guided percutaneous laser ablation of uterine fibroids. J Magn Reson Imaging. Oct. 2000;12(4):565-70. X-5. [pmid: 11042638].
917 Lawson LM, Tiwari P, Filipenko JD. An unusual cause of an incidental lung mass. Can Respir J. Jul–Aug. 2003;10(5):276-7. CASE REPORT. [pmid: 12945004].
918 Layfield LJ, Liu K, Dodge R, Barsky SH. Uterine smooth muscle tumors: utility of classification by proliferation, ploidy, and prognostic markers versus traditional histopathology. Arch Pathol Lab Med. Feb. 2000;124(2):221-7. X-6. [pmid: 10656730].
919 Lazarou S, Herschorn S. Ureteric obstruction requiring nephrectomy after uterine fibroid embolization. Can J Urol. Feb. 2005;12(1):2553-4. CASE REPORT. [pmid: 15777494].
920 Learman LA, Summitt RL Jr, Varner RE, McNeeley SG, Goodman-Gruen D, Richter HE, et al. A randomized comparison of total or supracervical hysterectomy: surgical complications and clinical outcomes. Obstet Gynecol. Sep. 2003;102(3):453-62. X-6. [pmid: 12962924].
921 Lee BS, Nowak RA. Human leiomyoma smooth muscle cells show increased expression of transforming growth factor-beta 3 (TGF beta 3) and altered responses to the antiproliferative effects of TGF beta. J Clin Endocrinol Metab. Feb. 2001;86(2):913-20. X-6. [pmid: 11158066].
922 Lee CL, Huang KG, Wang CJ, Yen CF, Soong YK. Radical laparoscopic surgery for carcinoma of the cervical stump. J Am Assoc Gynecol Laparosc. May. 2000;7(2):241-4. CASE REPORT. [pmid: 10806270].
923 Lee EJ, Kong G, Lee SH, Rho SB, Park CS, Kim BG, et al. Profiling of differentially expressed genes in human uterine leiomyomas. Int J Gynecol Cancer. Jan–Feb. 2005;15(1):146-54. X-6. [pmid: 15670310].
924 Lee H, Morgan K, Abramowsky C, Ricketts RR. Leiomyoma at the site of esophageal atresia repair. J Pediatr Surg. Dec. 2001;36(12):1832-3. CASE REPORT. [pmid: 11733917].
925 Lee JH, Jeong YK, Park JK, Hwang JC. “Ovarian vascular pedicle” sign revealing organ of origin of a pelvic mass lesion on helical CT. AJR Am J Roentgenol. Jul. 2003;181(1):131-7. X-6. [pmid: 12818843].
926 Lee KF, Lin PY, Cheung YC. Leiomyomatosis of mesenteric lymph nodes associated with duodenal adenocarcinoma. Chang Gung Med J. Apr. 2002;25(4):271-4. CASE REPORT. [pmid: 12079162].
927 Lee LH. Thrombotic and haemorrhagic complications in patients with mechanical heart valve prostheses attending the Singapore General Hospital Anticoagulation Clinic. Ann Acad Med Singapore. Jan. 2000;29(1):71-4. X-6. [pmid: 10748969].
928 Lee MW, Choi JH, Sung KJ, Moon KC, Koh JK. Palisaded and verocay body prominent leiomyoma of deep soft tissue. J Dermatol. Mar. 2002;29(3):160-3. CASE REPORT. [pmid: 11990252].
929 Lee SH, Ha HK, Byun JY, Kim AY, Cho KS, Lee YR, et al. Radiological features of leiomyomatous tumors of the colon and rectum. J Comput Assist Tomogr. May–Jun. 2000;24(3):407-12. X-6. [pmid: 10864076].
930 Lee SJ, Paik YH, Lee DK, Lee KS, Lee SI. The diagnostic value of endoprobe for small esophageal leiomyomas derived from the muscularis mucosae. Yonsei Med J. Feb 28. 2005;46(1):61-5. X-6. [pmid: 15744806].
931 Lee SK, Arbini AA, Galloway MT. Angioleiomyoma of the patellar tendon sheath. Case report. Am J Knee Surg. Summer. 2001;14(3):178-80. CASE REPORT. [pmid: 11491429].
932 Lee SY, Hsu HH, Chang CT, Yang CW, Wong YC, Wang LJ. Renal capsular leiomyoma—imaging features on computed tomography and angiography. Nephrol Dial Transplant. Jan. 2006;21(1):228-9. X-6. [pmid: 16204284].
933 Lee TH. By the way, doctor. I went through menopause about 10 years ago and have been taking estrogen therapy ever since. My uterus was removed because of fibroids, so there is no risk of endometrial cancer, which is why I am taking estrogen without progesterone. Should I have a bone density scan? A lot of my friends are having them, but I'm not sure how this test could alter my therapy. Harv Health Lett. Mar. 2000;25(5):7. X-1.
934 Lee TK, Cho HL, Kim DI, Lee YC, Kim CH. Scutellaria barbata D. Don induces c-fos gene expression in human uterine leiomyomal cells by activating beta2-adrenergic receptors. Int J Gynecol Cancer. May–Jun. 2004;14(3):526-31. X-6. [pmid: 15228428].
935 Lee TK, Kim DI, Han JY, Kim CH. Inhibitory effects of Scutellaria barbata D. Don. and Euonymus alatus Sieb. on aromatase activity of human leiomyomal cells. Immunopharmacol Immunotoxicol. Aug. 2004;26(3):315-27. X-6. [pmid: 15518167].
936 Lee TK, Kim DI, Song YL, Lee YC, Kim HM, Kim CH. Differential inhibition of Scutellaria barbata D. Don (Lamiaceae) on HCG-promoted proliferation of cultured uterine leiomyomal and myometrial smooth muscle cells. Immunopharmacol Immunotoxicol. Aug. 2004;26(3):329-42. X-6. [pmid: 15518168].
937 Lee TK, Lee DK, Kim DI, Lee YC, Chang YC, Kim CH. Inhibitory effects of Scutellaria barbata D. Don on human uterine leiomyomal smooth muscle cell proliferation through cell cycle analysis. Int Immunopharmacol. Mar. 2004;4(3):447-54. X-6. [pmid: 15072097].
938 Lee TK, Lee JY, Kim DI, Lee YC, Kim CH. Differential regulation of protein kinase C activity by modulating factors and Euonymus alatus (Thunb.) Sieb in human myometrial and uterine leiomyomal smooth muscle cells. Int J Gynecol Cancer. Mar–Apr. 2005;15(2):349-58. X-6. [pmid: 15823124].
939 Lee YS. Benefits of high epigastric port placement for removing the very large uterus. J Am Assoc Gynecol Laparosc. Aug. 2001;8(3):425-8. X-5. [pmid: 11509786].
940 Lehtonen R, Kiuru M, Vanharanta S, Sjoberg J, Aaltonen LM, Aittomaki K, et al. Biallelic inactivation of fumarate hydratase (FH) occurs in nonsyndromic uterine leiomyomas but is rare in other tumors. Am J Pathol. Jan. 2004;164(1):17-22. X-6. [pmid: 14695314]. [pmcid: 1602244].
941 Leiser AL, Hamid AM, Blanchard R. Recurrence of prolactin-producing endometrial stromal sarcoma with sex-cord stromal component treated with progestin and aromatase inhibitor. Gynecol Oncol. Aug. 2004;94(2):567-71. CASE REPORT. [pmid: 15297205].
942 Leitao MM, Soslow RA, Nonaka D, Olshen AB, Aghajanian C, Sabbatini P, et al. Tissue microarray immunohistochemical expression of estrogen, progesterone, and androgen receptors in uterine leiomyomata and leiomyosarcoma. Cancer. Sep 15. 2004;101(6):1455-62. X-6. [pmid: 15316901].
943 Leng J, Lang J, Liu Z, Huang R. Laparoscopic myomectomy. Chin Med Sci J. Jun. 2001;16(2):111-4. X-5. [pmid: 12901501].
944 Leone FP, Lanzani C, Ferrazzi E. Use of strict sonohysterographic methods for preoperative assessment of submucous myomas. Fertil Steril. Apr. 2003;79(4):998-1002. X-6. [pmid: 12749444].
945 Leonhardt H, Aziz A, Lonn L. Post-embolization syndrome and complete expulsion of a leiomyoma after uterine artery embolization. Acta Obstet Gynecol Scand. Mar. 2005;84(3):303-5. CASE REPORT. [pmid: 15715544].
946 Leon-Villapalos J, Kaniorou-Larai M, Dziewulski P. Full thickness abdominal burn following magnetic resonance guided focused ultrasound therapy. Burns. Dec. 2005;31(8):1054-5. CASE REPORT. [pmid: 15970389].
947 Leppert PC, Baginski T, Prupas C, Catherino WH, Pletcher S, Segars JH. Comparative ultrastructure of collagen fibrils in uterine leiomyomas and normal myometrium. Fertil Steril. Oct. 2004;82(Suppl 3):1182-7. X-6. [pmid: 15474093].
948 Leron E, Stanton SL. Vaginal leiomyoma—an imitator of prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):196-8. CASE REPORT. [pmid: 11484748].
949 Lerwill MF, Sung R, Oliva E, Prat J, Young RH. Smooth muscle tumors of the ovary: a clinicopathologic study of 54 cases emphasizing prognostic criteria, histologic variants, and differential diagnosis. Am J Surg Pathol. Nov. 2004;28(11):1436-51. X-6. [pmid: 15489647].
950 Letterie GS, Catherino WH. A 7.5-MHz finger-grip ultrasound probe for real-time intraoperative guidance during complex reproductive surgical procedures. Am J Obstet Gynecol. Dec. 2002;187(6):1588-90. X-5. [pmid: 12501068].
951 Levens E, Luo X, Ding L, Williams RS, Chegini N. Fibromodulin is expressed in leiomyoma and myometrium and regulated by gonadotropin-releasing hormone analogue therapy and TGF-beta through Smad and MAPK-mediated signalling. Mol Hum Reprod. Jul. 2005;11(7):489-94. X-6. [pmid: 16123076].
952 D. Levenson. Uterine fibroid embolization fares well against hysterectomy, study says. Rep Med Guidel Outcomes Res. 2002 Apr 19;13(8):1–2, 5. X-1
953 Levgur M, Abadi MA, Tucker A. Adenomyosis: symptoms, histology, and pregnancy terminations. Obstet Gynecol. May. 2000;95(5):688-91. X-6. [pmid: 10775730].
954 Levy B, Mukherjee T, Hirschhorn K. Molecular cytogenetic analysis of uterine leiomyoma and leiomyosarcoma by comparative genomic hybridization. Cancer Genet Cytogenet. Aug. 2000;121(1):1-8. X-6. [pmid: 10958933].
955 Li B, Sun M, He B, Yu J, Zhang YD, Zhang YL. Identification of differentially expressed genes in human uterine leiomyomas using differential display. Cell Res. Mar. 2002;12(1):39-45. X-6. [pmid: 11942409].
956 Li B, Zhang YL. Identification of up-regulated genes in human uterine leiomyoma by suppression subtractive hybridization. Cell Res. Sep. 2002;12(34):215-21. X-6. [pmid: 12296380].
957 Li S, Chiang TC, Davis GR, Williams RM, Wilson VP, McLachlan JA. Decreased expression of Wnt7a mRNA is inversely associated with the expression of estrogen receptor-alpha in human uterine leiomyoma. J Clin Endocrinol Metab. Jan. 2001;86(1):454-7. X-6. [pmid: 11232041].
958 Li S, Chiang TC, Richard-Davis G, Barrett JC, McLachlan JA. DNA hypomethylation and imbalanced expression of DNA methyltransferases (DNMT1, 3A, and 3B) in human uterine leiomyoma. Gynecol Oncol. Jul. 2003;90(1):123-30. X-6. [pmid: 12821352].
959 Li W, Brophy DP, Chen Q, Edelman RR, Prasad PV. Semiquantitative assessment of uterine perfusion using first pass dynamic contrast-enhanced MR imaging for patients treated with uterine fibroid embolization. J Magn Reson Imaging. Dec. 2000;12(6):1004-8. X-5. [pmid: 11105042].
960 Liang L, He C, Lei M, Li S, Hao Y, Zhu H, et al. Pathology of guinea pigs experimentally infected with a novel reovirus and coronavirus isolated from SARS patients. DNA Cell Biol. Aug. 2005;24(8):485-90. X-6. [pmid: 16101345].
961 Liapi E, Kamel IR, Bluemke DA, Jacobs MA, Kim HS. Assessment of response of uterine fibroids and myometrium to embolization using diffusion-weighted echoplanar MR imaging. J Comput Assist Tomogr. Jan–Feb. 2005;29(1):83-6. X-6. [pmid: 15665689].
962 Lichtinger M, Burbank F, Hallson L, Herbert S, Uyeno J, Jones M. The time course of myometrial ischemia and reperfusion after laparoscopic uterine artery occlusion—theoretical implications. J Am Assoc Gynecol Laparosc. Nov. 2003;10(4):554-63. quiz 564–6. X-5. [pmid: 14738649].
963 Lichtinger M, Hallson L, Calvo P, Adeboyejo G. Laparoscopic uterine artery occlusion for symptomatic leiomyomas. J Am Assoc Gynecol Laparosc. May. 2002;9(2):191-8. X-5. [pmid: 11960047].
964 Lichtinger M, Herbert S, Memmolo A. Temporary, transvaginal occlusion of the uterine arteries: a feasibility and safety study. J Minim Invasive Gynecol. Jan–Feb. 2005;12(1):40-2. X-5. [pmid: 15904597].
965 Lieng M, Istre O, Langebrekke A. Uterine rupture after laparoscopic myomectomy. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):92-3. CASE REPORT. [pmid: 15104841].
966 Ligon AH, Scott IC, Takahara K, Greenspan DS, Morton CC. PCOLCE deletion and expression analyses in uterine leiomyomata. Cancer Genet Cytogenet. Sep. 2002;137(2):133-7. X-6. [pmid: 12393284].
967 Lim S, Taylor A, Di Spiezio Sardo A, Mastrogamvrakis G, Sharma M, Buck L, et al. Myomectomy can be ‘life saving’—a case of a 36-week fibroid uterus managed conservatively in a 40-year-old nulliparous woman. J Obstet Gynaecol. Sep. 2004;24(6):715-7. CASE REPORT. [pmid: 16147630].
968 Lim ST, Kim MW, Sohn MH. Tc-99m RBC perfusion and blood-pool scintigraphy in the evaluation of vascular leiomyoma of the hand. Ann Nucl Med. Jun. 2002;16(4):293-6. CASE REPORT. [pmid: 12126100].
969 Lim ST, Sohn MH, Park SA. Curious radioactivity in the lower abdomen on bone scintigraphy: displacement of the urinary bladder by an incidentally diagnosed uterine myoma. Clin Nucl Med. Oct. 2000;25(10):824-5. CASE REPORT. [pmid: 11043728].
970 Lin PC, Thyer A, Soules MR. Intraoperative ultrasound during a laparoscopic myomectomy. Fertil Steril. Jun. 2004;81(6):1671-4. CASE REPORT. [pmid: 15193493].
971 Lin SC, Huang MJ, Zeng CY, Wang TI, Liu ZL, Shiay RK. Clinical manifestations and prognostic factors in patients with gastrointestinal stromal tumors. World J Gastroenterol. Dec. 2003;9(12):2809-12. X-6. [pmid: 14669339].
972 Lin YH, Hwang JL, Huang LW, Chen HJ. Pyomyoma after a cesarean section. Acta Obstet Gynecol Scand. Jun. 2002;81(6):571-2. CASE REPORT. [pmid: 12047316].
973 Lindheim SR, Adsuar N, Kushner DM, Pritts EA, Olive DL. Sonohysterography: a valuable tool in evaluating the female pelvis. Obstet Gynecol Surv. Nov. 2003;58(11):770-84. X-1. [pmid: 14581828].
974 Lippman SA, Warner M, Samuels S, Olive D, Vercellini P, Eskenazi B. Uterine fibroids and gynecologic pain symptoms in a population-based study. Fertil Steril. Dec. 2003;80(6):1488-94. X-5. [pmid: 14667888].
975 Litta P, Merlin F, Saccardi C, Pozzan C, Sacco G, Fracas M, et al. Role of hysteroscopy with endometrial biopsy to rule out endometrial cancer in postmenopausal women with abnormal uterine bleeding. Maturitas. Feb 14. 2005;50(2):117-23. X-6. [pmid: 15653009].
976 Litta P, Vasile C, Merlin F, Pozzan C, Sacco G, Gravila P, et al. A new technique of hysteroscopic myomectomy with enucleation in toto. J Am Assoc Gynecol Laparosc. May. 2003;10(2):263-70. X-5. [pmid: 12732782].
977 Liu C, Zhang Y, Zhang X, Yang W, Peng W, Shi D, et al. X-ray diffraction-enhanced imaging of uterine leiomyomas. Med Sci Monit. May. 2005;11(5):MT33-38. X-6. [pmid: 15874903].
978 Liu CJ, Chang KW. “Infantile” myofibroma of the oral cavity: report of case. J Oral Maxillofac Surg. Apr. 2001;59(4):471-2. CASE REPORT. [pmid: 11289185].
979 Liu HL, McDannold N, Hynynen K. Focal beam distortion and treatment planning in abdominal focused ultrasound surgery. Med Phys. May. 2005;32(5):1270-80. X-6. [pmid: 15984679].
980 Liu WM. Laparoscopic bipolar coagulation of uterine vessels to treat symptomatic leiomyomas. J Am Assoc Gynecol Laparosc. Feb. 2000;7(1):125-9. X-5. [pmid: 10648752].
981 Liu WM, Ng HT, Wu YC, Yen YK, Yuan CC. Laparoscopic bipolar coagulation of uterine vessels: a new method for treating symptomatic fibroids. Fertil Steril. Feb. 2001;75(2):417-22. X-5. [pmid: 11172850].
982 Liu WM, Tzeng CR, Yi-Jen C, Wang PH. Combining the uterine depletion procedure and myomectomy may be useful for treating symptomatic fibroids. Fertil Steril. Jul. 2004;82(1):205-10. X-4. [pmid: 15237013].
983 Liu WM, Yen YK, Wu YC, Yuan CC, Ng HT. Vaginal expulsion of submucous myomas after laparoscopic-assisted uterine depletion of the myomas. J Am Assoc Gynecol Laparosc. May. 2001;8(2):267-71. X-4. [pmid: 11342736].
984 Liu Y, Park T, Chun KJ, Freeman LM. Uterine myoma identified on a Tc-99m MAG3 scan of a renal transplant. Clin Nucl Med. Nov. 2002;27(11):801-2. CASE REPORT. [pmid: 12394131].
985 Lloria-Benet M, Bagan JV, Lloria de Miguel E, Borja-Morant A, Alonso S. Oral leiomyoma: a case report. Med Oral. May–Jul. 2003;8(3):215-9. CASE REPORT. [pmid: 12730656].
986 Lo KW, Yuen PM. The role of outpatient diagnostic hysteroscopy in identifying anatomic pathology and histopathology in the endometrial cavity. J Am Assoc Gynecol Laparosc. Aug. 2000;7(3):381-5. X-6. [pmid: 10924633].
987 Loddenkemper C, Mechsner S, Foss HD, Dallenbach FE, Anagnostopoulos I, Ebert AD, et al. Use of oxytocin receptor expression in distinguishing between uterine smooth muscle tumors and endometrial stromal sarcoma. Am J Surg Pathol. Nov. 2003;27(11):1458-62. X-6. [pmid: 14576480].
988 Loertzer H, Krause U, Holzhausen HJ, Hamza A, Fornara P. Development of leiomyosarcoma from primary leiomyoma?. Urol Int. 2004;73(3):276-9. X-6. [pmid: 15539851].
989 Loffer FD. Preliminary experience with the VersaPoint bipolar resectoscope using a vaporizing electrode in a saline distending medium. J Am Assoc Gynecol Laparosc. Nov. 2000;7(4):498-502. X-5. [pmid: 11044500].
990 Loffer FD. Hysteroscopic myomectomy in postmenopausal women. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):323-5. X-5. [pmid: 16036191].
991 Lolis DE, Kalantaridou SN, Makrydimas G, Sotiriadis A, Navrozoglou I, Zikopoulos K, et al. Successful myomectomy during pregnancy. Hum Reprod. Aug. 2003;18(8):1699-702. X-5. [pmid: 12871885].
992 Lone FW, Aziz AB, Khan MN, Pervez S. A case of intramural pregnancy: the importance of differentiation from fibroid uterus. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):337-8. CASE REPORT. [pmid: 11592555].
993 Long CY, Fang JH, Chen WC, Su JH, Hsu SC. Comparison of total laparoscopic hysterectomy and laparoscopically assisted vaginal hysterectomy. Gynecol Obstet Invest. 2002;53(4):214-9. X-4. [pmid: 12186986].
994 Lotfallah H, Farag K, Hassan I, Watson R. One-stop hysteroscopy clinic for postmenopausal bleeding. J Reprod Med. Feb. 2005;50(2):101-7. X-6. [pmid: 15755046].
995 Loverro G, Nappi L, Vicino M, Carriero C, Vimercati A, Selvaggi L. Uterine cavity assessment in infertile women: comparison of transvaginal sonography and hysteroscopy. Eur J Obstet Gynecol Reprod Biol. Dec 10. 2001;100(1):67-71. X-6. [pmid: 11728660].
996 Low SC, Chong CL. A case of cystic leiomyoma mimicking an ovarian malignancy. Ann Acad Med Singapore. May. 2004;33(3):371-4. CASE REPORT. [pmid: 15175784].
997 Low SJ, Smith KM. Bladder leiomyoma—a rare cause of bladder symptoms. J Obstet Gynaecol. Jan. 2003;23(1):89. CASE REPORT. [pmid: 12647717].
998 Loy CJ, Evelyn S, Lim FK, Liu MH, Yong EL. Growth dynamics of human leiomyoma cells and inhibitory effects of the peroxisome proliferator-activated receptor-gamma ligand, pioglitazone. Mol Hum Reprod. Aug. 2005;11(8):561-6. X-6. [pmid: 16051682].
999 Luisi S, Latini G, de Felice C, Sanseverino F, di Pasquale D, Mazzeo P, et al. Low serum concentrations of di-(2-ethylhexyl)phthalate in women with uterine fibromatosis. Gynecol Endocrinol. Feb. 2006;22(2):92-5. X-5. [pmid: 16603434].
1000 Lun KR, Spelman LJ. Multiple piloleiomyomas. Australas J Dermatol. Aug. 2000;41(3):185-6. CASE REPORT. [pmid: 10954993].
1001 Luo X, Ding L, Xu J, Chegini N. Gene expression profiling of leiomyoma and myometrial smooth muscle cells in response to transforming growth factor-beta. Endocrinology. Mar. 2005;146(3):1097-118. X-6. [pmid: 15604209].
1002 Luo X, Ding L, Xu J, Williams RS, Chegini N. Leiomyoma and myometrial gene expression profiles and their responses to gonadotropin-releasing hormone analog therapy. Endocrinology. Mar. 2005;146(3):1074-96. X-6. [pmid: 15604208].
1003 Luoto R, Kaprio J, Rutanen EM, Taipale P, Perola M, Koskenvuo M. Heritability and risk factors of uterine fibroids—the Finnish Twin Cohort study. Maturitas. Nov 30. 2000;37(1):15-26. X-6. [pmid: 11099869].
1004 Luoto R, Rutanen EM, Auvinen A. Fibroids and hypertension. A cross-sectional study of women undergoing hysterectomy. J Reprod Med. Apr. 2001;46(4):359-64. X-6. [pmid: 11354837].
1005 Lurie S, Piper I, Woliovitch I, Glezerman M. Age-related prevalence of sonographicaly confirmed uterine myomas. J Obstet Gynaecol. Jan. 2005;25(1):42-4. X-5. [pmid: 16147693].
1006 Ly JQ. Rare bicornuate uterus with fibroid tumors: hysterosalpingography-MR imaging correlation. AJR Am J Roentgenol. Aug. 2002;179(2):537-8. CASE REPORT. [pmid: 12130475].
1007 Lyons TL, Adolph AJ, Winer WK. Laparoscopic supracervical hysterectomy for the large uterus. J Am Assoc Gynecol Laparosc. May. 2004;11(2):170-4. X-5. [pmid: 15200769].
1008 Macdonald DJ, Popli K, Byrne D, Hanretty K. Small bowel obstruction in a twin pregnancy due to fibroid degeneration. Scott Med J. Nov. 2004;49(4):159-60. CASE REPORT. [pmid: 15648716].
1009 Machan L, Martin M. Uterine artery embolization to treat uterine fibroids. Can Assoc Radiol J. Jun. 2001;52(3):183-7. X-1. [pmid: 11436413].
1010 MacKenzie IZ, Naish C, Rees M, Manek S. 1170 consecutive hysterectomies: indications and pathology. J Br Menopause Soc. Sep. 2004;10(3):108-12. X-6. [pmid: 15494102].
1011 Madan AK, Frantzides CT, Keshavarzian A, Smith C. Laparoscopic wedge resection of gastric leiomyoma. Jsls. Jan–Mar. 2004;8(1):77-80. CASE REPORT. [pmid: 14974670].
1012 Madan R. The bridging vascular sign. Radiology. Jan. 2006;238(1):371-2. CASE REPORT. [pmid: 16373780].
1013 Madan SM, Al-Jufairi ZA. Abnormal uterine bleeding. Diagnostic value of hysteroscopy. Saudi Med J. Feb. 2001;22(2):153-6. X-6. [pmid: 11299412].
1014 Madej P, Madej JA, Plewka A, Kazimierczak W, Dzimira S. Evaluation of nucleolar organizer region (NOR) parameters in the uterine leiomyoma. Pathol Res Pract. 2005;201(89):587-92. X-6. [pmid: 16259112].
1015 Maebayashi T, Imai K, Takekawa Y, Sasaki J, Otsuka H, Katsura Y, et al. Radiologic features of uterine lipoleiomyoma. J Comput Assist Tomogr. Mar–Apr. 2003;27(2):162-5. CASE REPORT. [pmid: 12703006].
1016 Maekawa H, Tanaka N, Hashimoto N, Yamada H, Mitsui H, Ikeda H, et al. Esophageal smooth muscle tumor in a 25-year-old woman with congenital malformations. J Gastroenterol. Oct. 2001;36(10):700-3. CASE REPORT. [pmid: 11686481].
1017 Maeng L, Choi KY, Lee A, Kang CS, Kim KM. Polypoid arteriovenous malformation of colon mimicking inflammatory fibroid polyp. J Gastroenterol. Jun. 2004;39(6):575-8. CASE REPORT. [pmid: 15235876].
1018 Magann EF, Evans S, Hutchinson M, Collins R, Lanneau G, Morrison JC. Postpartum hemorrhage after cesarean delivery: an analysis of risk factors. South Med J. Jul. 2005;98(7):681-5. X-6. [pmid: 16108235].
1019 Magro G, Gurrera A, Bisceglia M. H-caldesmon expression in myofibroblastoma of the breast: evidence supporting the distinction from leiomyoma. Histopathology. Mar. 2003;42(3):233-8. X-6. [pmid: 12605642].
1020 Mahalingam M, Goldberg LJ. Atypical pilar leiomyoma: cutaneous counterpart of uterine symplastic leiomyoma?. Am J Dermatopathol. Aug. 2001;23(4):299-303. X-6. [pmid: 11481520].
1021 Mak CW, Tzeng WS, Chou CK, Chen CY, Chang JM, Tzeng CC. Leiomyoma arising from the tunica albuginea of the testis: sonographic findings. J Clin Ultrasound. Jul–Aug. 2004;32(6):309-11. X-6. [pmid: 15211679].
1022 Makhlouf HR, Sobin LH. Inflammatory myofibroblastic tumors (inflammatory pseudotumors) of the gastrointestinal tract: how closely are they related to inflammatory fibroid polyps?. Hum Pathol. Mar. 2002;33(3):307-15. X-6. [pmid: 11979371].
1023 Makrydimas G, Kaponis A, Skentou C, Lolis D. Short-term safety of celocentesis for the mother and the fetus. Ultrasound Obstet Gynecol. Mar. 2002;19(3):243-5. X-6. [pmid: 11896943].
1024 Malik E, Berg C, Sterzik K, Stoz F, Rossmanith WG. Reproductive outcome of 32 patients with primary or secondary infertility and uterine pathology. Arch Gynecol Obstet. Jul. 2000;264(1):24-6. X-5. [pmid: 10985614].
1025 Malik E, Buchweitz O, Muller-Steinhardt M, Kressin P, Meyhofer-Malik A, Diedrich K. Prospective evaluation of the systemic immune response following abdominal, vaginal, and laparoscopically assisted vaginal hysterectomy. Surg Endosc. May. 2001;15(5):463-6. X-6. [pmid: 11353962].
1026 Malyshkina AI, Posiseeva LV, Sotnikova NY, Antsiferova JS, Suvorkina EE, Arevadze IE. Local immunological markers of different rate of growth of uterine myoma. Russ J Immunol. Apr. 2002;7(1):58-62. X-6. [pmid: 12687267].
1027 Mangioni S, Vigano P, Lattuada D, Abbiati A, Vignali M, Di Blasio AM. Overexpression of the Wnt5b gene in leiomyoma cells: implications for a role of the Wnt signaling pathway in the uterine benign tumor. J Clin Endocrinol Metab. Sep. 2005;90(9):5349-55. X-6. [pmid: 15972578].
1028 Manojlovic S, Aljinovic-Ratkovic N, Kruslin B. Calcified leiomyoma of the lateral pterygoid muscle in an 8-year-old boy. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Feb. 2000;89(2):199-203. CASE REPORT. [pmid: 10673656].
1029 Marchionni M, Fambrini M, Zambelli V, Scarselli G, Susini T. Reproductive performance before and after abdominal myomectomy: a retrospective analysis. Fertil Steril. Jul. 2004;82(1):154-9. quiz 265. X-5. [pmid: 15237005].
1030 Maresca A, Gagliano C, Marcuzzi A. Leiomyoma of the hand: a case report. Chir Main. Jun–Aug. 2005;24(34):193-5. CASE REPORT. [pmid: 16121629].
1031 Marino JL, Eskenazi B, Warner M, Samuels S, Vercellini P, Gavoni N, et al. Uterine leiomyoma and menstrual cycle characteristics in a population-based cohort study. Hum Reprod. Oct. 2004;19(10):2350-5. X-5. [pmid: 15242998].
1032 Marioni G, Marchese-Ragona R, Fernandez S, Bruzon J, Marino F, Staffieri A. Progesterone receptor expression in angioleiomyoma of the nasal cavity. Acta Otolaryngol. Jun. 2002;122(4):408-12. CASE REPORT. [pmid: 12125998].
1033 Markowska A, Rucinski M, Drews K, Malendowicz LK. Further studies on leptin and leptin receptor expression in myometrium and uterine myomas. Eur J Gynaecol Oncol. 2005;26(5):517-25. X-6. [pmid: 16285570].
1034 Marongiu F, Cauli C, Mameli G, Usai B, Mariotti S. Apathetic Graves' disease and acquired hemophilia due to factor VIIIc antibody. J Endocrinol Invest. Mar. 2002;25(3):246-9. CASE REPORT. [pmid: 11936467].
1035 Marrazzo A, Taormina P, Noto A, Cardinale G, Casa L, Lo Gerfo D. Nipple leiomyoma in man: a case report. G Chir. Apr. 2004;25(4):132-3. CASE REPORT. [pmid: 15283404].
1036 Marret H, Alonso AM, Cottier JP, Tranquart F, Herbreteau D, Body G. Leiomyoma recurrence after uterine artery embolization. J Vasc Interv Radiol. Nov. 2003;14(11):1395-9. X-5. [pmid: 14605104].
1037 Marret H, Cottier JP, Alonso AM, Giraudeau B, Body G, Herbreteau D. Predictive factors for fibroids recurrence after uterine artery embolisation. Bjog. Apr. 2005;112(4):461-5. X-5. [pmid: 15777445].
1038 Marret H, Keris Yle B, Acker O, Cottier JP, Herbreteau D. Late leiomyoma expulsion after uterine artery embolization. J Vasc Interv Radiol. Dec. 2004;15(12):1483-5. CASE REPORT. [pmid: 15590809].
1039 Marret H, Tranquart F, Sauget S, Alonso AM, Cottier JP, Herbreteau D. Contrast-enhanced sonography during uterine artery embolization for the treatment of leiomyomas. Ultrasound Obstet Gynecol. Jan. 2004;23(1):77-9. CASE REPORT. [pmid: 14971005].
1040 Martin Chaves EB, Brum IS, Stoll J, Capp E, Corleta HE. Insulin-like growth factor 1 receptor mRNA expression and autophosphorylation in human myometrium and leiomyoma. Gynecol Obstet Invest. 2004;57(4):210-3. X-6. [pmid: 14963370].
1041 Martin SA, Sears DL, Sebo TJ, Lohse CM, Cheville JC. Smooth muscle neoplasms of the urinary bladder: a clinicopathologic comparison of leiomyoma and leiomyosarcoma. Am J Surg Pathol. Mar. 2002;26(3):292-300. X-6. [pmid: 11859200].
1042 Martinez-Mir A, Glaser B, Chuang GS, Horev L, Waldman A, Engler DE, et al. Germline fumarate hydratase mutations in families with multiple cutaneous and uterine leiomyomata. J Invest Dermatol. Oct. 2003;121(4):741-4. X-6. [pmid: 14632190].
1043 Martinez-Mir A, Gordon D, Horev L, Klapholz L, Ott J, Christiano AM, et al. Multiple cutaneous and uterine leiomyomas: refinement of the genetic locus for multiple cutaneous and uterine leiomyomas on chromosome 1q42.3–43. J Invest Dermatol. May. 2002;118(5):876-80. X-6. [pmid: 11982768].
1044 Martin-Lorenzo JG, Torralba-Martinez A, Liron-Ruiz R, Flores-Pastor B, Miguel-Perello J, Aguilar-Jimenez J, et al. Intestinal invagination in adults: preoperative diagnosis and management. Int J Colorectal Dis. Jan. 2004;19(1):68-72. X-6. [pmid: 12838363].
1045 Maruthur NM, Hsiao EC, Lee J, Nivatpumin P. Cases from the Osler medical service at Johns Hopkins University. Am J Med. Apr 1. 2004;116(7):490-2. CASE REPORT. [pmid: 15047040].
1046 Marx M, Wack JP, Baker EL, Stevens SK, Barakos JA. Ovarian protection by occlusion of uteroovarian collateral vessels before uterine fibroid embolization. J Vasc Interv Radiol. Oct. 2003;14(10):1329-32. X-5. [pmid: 14551281].
1047 Maslovsky I, Gemer O, Gefel D, Zimra Y, Lugassy G. Polycythemia as a result of ectopic erythropoietin production in benign cystic leiomyoma of uterus. Acta Obstet Gynecol Scand. 2006;85(7):887-8. CASE REPORT. [pmid: 16817092].
1048 Mason HR, Lake AC, Wubben JE, Nowak RA, Castellot JJ Jr. The growth arrest-specific gene CCN5 is deficient in human leiomyomas and inhibits the proliferation and motility of cultured human uterine smooth muscle cells. Mol Hum Reprod. Mar. 2004;10(3):181-7. X-6. [pmid: 14981145].
1049 Mason HR, Nowak RA, Morton CC, Castellot JJ Jr. Heparin inhibits the motility and proliferation of human myometrial and leiomyoma smooth muscle cells. Am J Pathol. Jun. 2003;162(6):1895-904. X-6. [pmid: 12759246]. [pmcid: 1868134].
1050 Mason TC. Red degeneration of a leiomyoma masquerading as retained products of conception. J Natl Med Assoc. Feb. 2002;94(2):124-6. CASE REPORT. [pmid: 11853046]. [pmcid: 2594119].
1051 Massart F, Becherini L, Gennari L, Facchini V, Genazzani AR, Brandi ML. Genotype distribution of estrogen receptor-alpha gene polymorphisms in Italian women with surgical uterine leiomyomas. Fertil Steril. Mar. 2001;75(3):567-70. X-6. [pmid: 11239543].
1052 Massart F, Becherini L, Marini F, Noci I, Piciocchi L, Del Monte F, et al. Analysis of estrogen receptor (ERalpha and ERbeta) and progesterone receptor (PR) polymorphisms in uterine leiomyomas. Med Sci Monit. Jan. 2003;9(1):BR25-30. X-6. [pmid: 15156607].
1053 Matchar DB, Myers ER, Barber MW, Couchman GM, Datta S, Gray RN, et al. Management of uterine fibroids. Evid Rep Technol Assess (Summ). Jan. 2001;(34):1-6. X-1.
1054 Materia E, Rossi L, Spadea T, Cacciani L, Baglio G, Cesaroni G, et al. Hysterectomy and socioeconomic position in Rome, Italy. J Epidemiol Community Health. Jun. 2002;56(6):461-5. X-6. [pmid: 12011206]. [pmcid: 1732169].
1055 Mathelier AC. Unusual late complications after two previous cesarean deliveries: a case report. Int J Fertil Womens Med. Mar–Apr. 2003;48(2):70-3. CASE REPORT. [pmid: 12779292].
1056 Mathevet P, Valencia P, Cousin C, Mellier G, Dargent D. Operative injuries during vaginal hysterectomy. Eur J Obstet Gynecol Reprod Biol. Jul. 2001;97(1):71-5. X-6. [pmid: 11435013].
1057 Mathew M, Krolikowski A, Al-Haddabi I, Nirmala V. Primary ovarian leiomyoma. Saudi Med J. Feb. 2005;26(2):306-7. CASE REPORT. [pmid: 15770311].
1058 Matson M, Nicholson A, Belli AM. Anastomoses of the ovarian and uterine arteries: a potential pitfall and cause of failure of uterine embolization. Cardiovasc Intervent Radiol. Sep–Oct. 2000;23(5):393-6. X-5. [pmid: 11060372].
1059 Matsumoto H, Nasu K, Nishida M, Ito H, Bing S, Miyakawa I. Regulation of proliferation, motility, and contractility of human endometrial stromal cells by platelet-derived growth factor. J Clin Endocrinol Metab. Jun. 2005;90(6):3560-7. X-6. [pmid: 15755859].
1060 Matsumoto K, Yamamoto T, Hisayoshi T, Asano G. Intravenous leiomyomatosis of the uterus with multiple pulmonary metastases associated with large bullae-like cyst formation. Pathol Int. May. 2001;51(5):396-401. CASE REPORT. [pmid: 11422800].
1061 Matsuoka H, Nishio W, Sakamoto T, Harada H, Sashikata T, Tsubota N. Mediastinal angioleiomyoma. Ann Thorac Surg. May. 2002;73(5):1653-4. CASE REPORT. [pmid: 12022578].
1062 Matsuoka R, Yanaihara A, Saito H, Furusawa Y, Toma Y, Shimizu Y, et al. Regulation of estrogen activity in human endometrium: effect of IL-1beta on steroid sulfatase activity in human endometrial stromal cells. Steroids. Jun. 2002;67(7):655-9. X-6. [pmid: 11996939].
1063 Matsuzaki S, Fukaya T, Uehara S, Murakami T, Sasano H, Yajima A. Characterization of messenger RNA expression of estrogen receptor-alpha and -beta in patients with ovarian endometriosis. Fertil Steril. Jun. 2000;73(6):1219-25. X-6. [pmid: 10856486].
1064 Matthews BD, Walsh RM, Kercher KW, Sing RF, Pratt BL, Answini GA, et al. Laparoscopic vs open resection of gastric stromal tumors. Surg Endosc. May. 2002;16(5):803-7. X-6. [pmid: 11997826].
1065 Matthews JH, Pichardo RO, Hitchcock MG, Leshin B. Cutaneous leiomyoma with cytologic atypia, akin to uterine symplastic leiomyoma. Dermatol Surg. Sep. 2004;30(9):1249-51. discussion 1251. X-6. [pmid: 15355371].
1066 Matyakhina L, Freedman RJ, Bourdeau I, Wei MH, Stergiopoulos SG, Chidakel A, et al. Hereditary leiomyomatosis associated with bilateral, massive, macronodular adrenocortical disease and atypical cushing syndrome: a clinical and molecular genetic investigation. J Clin Endocrinol Metab. Jun. 2005;90(6):3773-9. X-6. [pmid: 15741255].
1067 Mayadeo NM, Tank PD. Non-puerperal incomplete lateral uterine inversion with submucous leiomyoma: a case report. J Obstet Gynaecol Res. Aug. 2003;29(4):243-5. CASE REPORT. [pmid: 12959146].
1068 Mayerhofer K, Lozanov P, Bodner K, Bodner-Adler B, Kimberger O, Czerwenka K. Ki-67 expression in patients with uterine leiomyomas, uterine smooth muscle tumors of uncertain malignant potential (STUMP) and uterine leiomyosarcomas (LMS). Acta Obstet Gynecol Scand. Nov. 2004;83(11):1085-8. X-6. [pmid: 15488127].
1069 McClean G, McCluggage WG. Unusual morphologic features of uterine leiomyomas treated with gonadotropin-releasing hormone agonists: massive lymphoid infiltration and vasculitis. Int J Surg Pathol. Oct. 2003;11(4):339-44. CASE REPORT. [pmid: 14615835].
1070 McCluggage WG, Ellis PK, McClure N, Walker WJ, Jackson PA, Manek S. Pathologic features of uterine leiomyomas following uterine artery embolization. Int J Gynecol Pathol. Oct. 2000;19(4):342-7. X-5. [pmid: 11109163].
1071 McCluggage WG, Hamal P, Traub AI, Walsh MY. Uterine adenolipoleiomyoma: a rare hamartomatous lesion. Int J Gynecol Pathol. Apr. 2000;19(2):183-5. CASE REPORT. [pmid: 10782418].
1072 McKeeby JL, Li X, Zhuang Z, Vortmeyer AO, Huang S, Pirner M, et al. Multiple leiomyomas of the esophagus, lung, and uterus in multiple endocrine neoplasia type 1. Am J Pathol. Sep. 2001;159(3):1121-7. X-6. [pmid: 11549605]. [pmcid: 1850469].
1073 McKelvey A, McKenna D, McManus D, Joyce M. A case of lymphoma occurring in an ovarian teratoma. Gynecol Oncol. Aug. 2003;90(2):474-7. CASE REPORT. [pmid: 12893223].
1074 McLucas B, Adler L. Uterine fibroid embolization compared with myomectomy. Int J Gynaecol Obstet. Sep. 2001;74(3):297-9. X-5. [pmid: 11543757].
1075 McLucas B, Goodwin S, Adler L, Rappaport A, Reed R, Perrella R. Pregnancy following uterine fibroid embolization. Int J Gynaecol Obstet. Jul. 2001;74(1):1-7. X-5. [pmid: 11430934].
1076 McLucas B, Reed RA, Goodwin S, Rappaport A, Adler L, Perrella R, et al. Outcomes following unilateral uterine artery embolisation. Br J Radiol. Feb. 2002;75(890):122-6. X-5. [pmid: 11893635].
1077 Mechanic SA, Maurer JL, Igoe MJ, Kavitsky DM, Nance ST. Anti-Vel reactivity diminished by adsorption with rabbit RBC stroma. Transfusion. Sep. 2002;42(9):1180-3. X-6. [pmid: 12430675].
1078 Mehra R, Huria A, Gupta P, Mohan H. Choriocarcinoma with negative urinary and serum beta human chorionic gonadotropin (betaHCG)—a case report. Indian J Med Sci. Dec. 2005;59(12):538-41. CASE REPORT. [pmid: 16385173].
1079 Mehta H, Sandhu C, Matson M, Belli AM. Review of readmissions due to complications from uterine fibroid embolization. Clin Radiol. Dec. 2002;57(12):1122-4. X-5. [pmid: 12475539].
1080 Melamud O, Eichel L, Turbow B, Shanberg A. Laparoscopic vesicovaginal fistula repair with robotic reconstruction. Urology. Jan. 2005;65(1):163-6. CASE REPORT. [pmid: 15667885].
1081 Melgrati L, Damiani A, Franzoni G, Marziali M, Sesti F. Isobaric (gasless) laparoscopic myomectomy during pregnancy. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):379-81. CASE REPORT. [pmid: 16036205].
1082 Melzer E, Redder I, Bar-Meir S. Images in focus. Gastric inflammatory fibroid polyp: endosonographic features. Endoscopy. Dec. 2000;32(12):S76. X-6. [pmid: 11147961].
1083 Memisoglu E, Agarwal B, Akduman I, Prather C, Collins B, Civelek AC. Multimodality diagnostic imaging of diffuse esophageal leiomyomatosis. J Comput Assist Tomogr. Jan–Feb. 2006;30(1):100-4. CASE REPORT. [pmid: 16365582].
1084 Menchinelli P, De Giovanni L, Capozzoli A, Weir JM, Ronzoni G. Leiomyoma of the female urethra. Arch Ital Urol Androl. Jun. 2003;75(2):124-5. CASE REPORT. [pmid: 12868154].
1085 Meng K, Branam JD, Nghiem HV, Carlos RC. The short-term clinical outcomes after saline infusion sonohysterography in women with postmenopausal bleeding. Acad Radiol. Feb. 2005;12(2):136-41. X-6. [pmid: 15721589].
1086 Meniru GI, Wasdahl D, Onuora CO, Hecht BR, Hopkins MP. Vaginal leiomyoma co-existing with broad ligament and multiple uterine leiomyomas. Arch Gynecol Obstet. May. 2001;265(2):105-7. CASE REPORT. [pmid: 11409472].
1087 Mentzel T, Dei Tos AP, Sapi Z, Kutzner H. Myopericytoma of skin and soft tissues: clinicopathologic and immunohistochemical study of 54 cases. Am J Surg Pathol. Jan. 2006;30(1):104-13. X-5. [pmid: 16330949].
1088 Mentzel T, Kutzner H. Haemorrhagic dermatomyofibroma (plaque-like dermal fibromatosis): clinicopathological and immunohistochemical analysis of three cases resembling plaque-stage Kaposi's sarcoma. Histopathology. Jun. 2003;42(6):594-8. CASE REPORT. [pmid: 12786896].
1089 Merani R, Khannah G, Mann S, Ghabrial R. Orbital leiomyoma: a case report with clinical, radiological and pathological correlation. Clin Experiment Ophthalmol. Aug. 2005;33(4):408-11. CASE REPORT. [pmid: 16033356].
1090 Merchant S, Malpica A, Deavers MT, Czapar C, Gershenson D, Silva EG. Vessels within vessels in the myometrium. Am J Surg Pathol. Feb. 2002;26(2):232-6. X-6. [pmid: 11812945].
1091 Mercorio F, De Simone R, Di Spiezio Sardo A, Cerrota G, Bifulco G, Vanacore F, et al. The effect of a levonorgestrel-releasing intrauterine device in the treatment of myoma-related menorrhagia. Contraception. Apr. 2003;67(4):277-80. X-5. [pmid: 12684148].
1092 Merz H, Lange K, Koch BU, Bauer O, Gaulard P, Feller AC. Primary extranodal CD8 positive epitheliotropic T-cell lymphoma arising in a leiomyoma of the uterus. Bjog. May. 2003;110(5):527-9. CASE REPORT. [pmid: 12742341].
1093 Meshikhes AW, Al-Khalaf EA, Al-Bahar SH. Gastric leiomyoma. Is there an association with Helicobacter pylori?. Saudi Med J. Nov. 2004;25(11):1758-9. X-6. [pmid: 15573227].
1094 Mesia AF, Demopoulos RI. Effects of leuprolide acetate on low-grade endometrial stromal sarcoma. Am J Obstet Gynecol. May. 2000;182(5):1140-1. X-6. [pmid: 10819848].
1095 Messina ML, Bozzini N, Halbe HW, Pinotti JA. Uterine artery embolization for the treatment of uterine leiomyomata. Int J Gynaecol Obstet. Oct. 2002;79(1):11-6. X-5. [pmid: 12399085].
1096 Meston CM. The effects of hysterectomy on sexual arousal in women with a history of benign uterine fibroids. Arch Sex Behav. Feb. 2004;33(1):31-42. X-5. [pmid: 14739688].
1097 Mettler L. Long-term results in the treatment of menorrhagia and hypermenorrhea with a thermal balloon endometrial ablation technique. Jsls. Oct–Dec. 2002;6(4):305-9. X-5. [pmid: 12500827].
1098 Mettler L, Audebert A, Lehmann-Willenbrock E, Jacobs VR, Schive K. New adhesion prevention concept in gynecological surgery. Jsls. Jul–Sep. 2003;7(3):207-9. X-6. [pmid: 14558707].
1099 Mettler L, Audebert A, Lehmann-Willenbrock E, Schive K, Jacobs VR. Prospective clinical trial of SprayGel as a barrier to adhesion formation: an interim analysis. J Am Assoc Gynecol Laparosc. Aug. 2003;10(3):339-44. X-6. [pmid: 14567808].
1100 Michal M, Hes O, Havlicek F. Benign renal angiomyoadenomatous tumor: a previously unreported renal tumor. Ann Diagn Pathol. Oct. 2000;4(5):311-5. CASE REPORT. [pmid: 11073338].
1101 Michal M, Rokyta Z, Mejchar B, Pelikan K, Kummel M, Mukensnabl P. Prolapse of the fallopian tube after hysterectomy associated with exuberant angiomyofibroblastic stroma response: a diagnostic pitfall. Virchows Arch. Oct. 2000;437(4):436-9. CASE REPORT. [pmid: 11097370].
1102 Miettinen M, Furlong M, Sarlomo-Rikala M, Burke A, Sobin LH, Lasota J. Gastrointestinal stromal tumors, intramural leiomyomas, and leiomyosarcomas in the rectum and anus: a clinicopathologic, immunohistochemical, and molecular genetic study of 144 cases. Am J Surg Pathol. Sep. 2001;25(9):1121-33. X-6. [pmid: 11688571].
1103 Miettinen M, Kopczynski J, Makhlouf HR, Sarlomo-Rikala M, Gyorffy H, Burke A, et al. Gastrointestinal stromal tumors, intramural leiomyomas, and leiomyosarcomas in the duodenum: a clinicopathologic, immunohistochemical, and molecular genetic study of 167 cases. Am J Surg Pathol. May. 2003;27(5):625-41. X-6. [pmid: 12717247].
1104 Miettinen M, Sarlomo-Rikala M, Sobin LH. Mesenchymal tumors of muscularis mucosae of colon and rectum are benign leiomyomas that should be separated from gastrointestinal stromal tumors—a clinicopathologic and immunohistochemical study of eighty-eight cases. Mod Pathol. Oct. 2001;14(10):950-6. X-6. [pmid: 11598163].
1105 Miettinen M, Sarlomo-Rikala M, Sobin LH, Lasota J. Gastrointestinal stromal tumors and leiomyosarcomas in the colon: a clinicopathologic, immunohistochemical, and molecular genetic study of 44 cases. Am J Surg Pathol. Oct. 2000;24(10):1339-52. X-6. [pmid: 11023095].
1106 Miettinen M, Sarlomo-Rikala M, Sobin LH, Lasota J. Esophageal stromal tumors: a clinicopathologic, immunohistochemical, and molecular genetic study of 17 cases and comparison with esophageal leiomyomas and leiomyosarcomas. Am J Surg Pathol. Feb. 2000;24(2):211-22. X-6. [pmid: 10680889].
1107 Miettinen M, Sobin LH. Gastrointestinal stromal tumors in the appendix: a clinicopathologic and immunohistochemical study of four cases. Am J Surg Pathol. Nov. 2001;25(11):1433-7. X-6. [pmid: 11684962].
1108 Miettinen M, Sobin LH, Sarlomo-Rikala M. Immunohistochemical spectrum of GISTs at different sites and their differential diagnosis with a reference to CD117 (KIT). Mod Pathol. Oct. 2000;13(10):1134-42. X-6. [pmid: 11048809].
1109 Migishima F, Jobo T, Hata H, Sato R, Ikeda Y, Arai M, et al. Uterine leiomyoma causing massive ascites and left pleural effusion with elevated CA 125: a case report. J Obstet Gynaecol Res. Aug. 2000;26(4):283-7. CASE REPORT. [pmid: 11049239].
1110 Mihssin N, Moorthy K, Sengupta A, Houghton PW. Gastric stromal tumours: a practical approach. Ann R Coll Surg Engl. Nov. 2000;82(6):378-82. X-6. [pmid: 11103152]. [pmcid: 2503480].
1111 Milad MP, Morrison K, Sokol A, Miller D, Kirkpatrick L. A comparison of laparoscopic supracervical hysterectomy vs laparoscopically assisted vaginal hysterectomy. Surg Endosc. Mar. 2001;15(3):286-8. X-6. [pmid: 11344430].
1112 Miller JC. Looking back: the use of radium in the treatment of myoma uteri and myopathic hemorrhages in 1920. J Miss State Med Assoc. Apr. 2003;44(4):116-9. X-1. [pmid: 12807068].
1113 Millward SF, Holley ML. The current status of interventional radiology in Canada: results of a survey by the Canadian Interventional Radiology Association. Can Assoc Radiol J. Apr. 2001;52(2):87-91. X-6. [pmid: 11339151].
1114 Minakuchi K, Hirai K, Kawamura N, Ishiko O, Kanaoka Y, Ogita S. Case of hemorrhagic shock due to hypermenorrhea during anticoagulant therapy. Arch Gynecol Obstet. Sep. 2000;264(2):99-100. CASE REPORT. [pmid: 11045334].
1115 Mine N, Kurose K, Konishi H, Araki T, Nagai H, Emi M. Fusion of a sequence from HEI10 (14q11) to the HMGIC gene at 12q15 in a uterine leiomyoma. Jpn J Cancer Res. Feb. 2001;92(2):135-9. CASE REPORT. [pmid: 11223542].
1116 Mine N, Kurose K, Nagai H, Doi D, Ota Y, Yoneyama K, et al. Gene fusion involving HMGIC is a frequent aberration in uterine leiomyomas. J Hum Genet. 2001;46(7):408-12. X-6. [pmid: 11450849].
1117 Minutti CZ, Zimmerman D. Traumatic hypopituitarism due to maternal uterine leiomyomas. J Endocrinol Invest. Feb. 2002;25(2):158-62. CASE REPORT. [pmid: 11929087].
1118 Misao R, Niwa K, Iwagaki S, Shimokawa K, Tamaya T. Leiomyoma of the fallopian tube. Gynecol Obstet Invest. 2000;49(4):279-80. CASE REPORT. [pmid: 10828715].
1119 Miskry T, Magos A. Randomized, prospective, double-blind comparison of abdominal and vaginal hysterectomy in women without uterovaginal prolapse. Acta Obstet Gynecol Scand. Apr. 2003;82(4):351-8. X-6. [pmid: 12716320].
1120 Misra M, Maziak DE, Shamji FM, Michaud C, Perkins DG, Matzinger F. Esophageal leiomyomatosis. Med Sci Monit. Nov. 2003;9(11):CS98-101. CASE REPORT. [pmid: 14586279].
1121 Misumi S, Irie T, Fukuda K, Tada S, Hosomura Y. A case of deep soft tissue leiomyoma: CT and MRI findings. Radiat Med. Jul–Aug. 2000;18(4):253-6. CASE REPORT. [pmid: 11247002].
1122 Mitropoulou TN, Lamari F, Syrokou A, Hjerpe A, Karamanos NK. Identification of oligomeric domains within dermatan sulfate chains using differential enzymic treatments, derivatization with 2-aminoacridone and capillary electrophoresis. Electrophoresis. Aug. 2001;22(12):2458-63. X-6. [pmid: 11519950].
1123 Mitropoulou TN, Stagiannis KD. Variation in sulfation pattern of galactosaminoglycan containing proteoglycans is associated with the development of uterine leiomyoma. Biomed Chromatogr. Sep. 2004;18(7):411-3. X-6. [pmid: 15340964].
1124 Mitropoulou TN, Theocharis AD, Stagiannis KD, Karamanos NK. Identification, quantification and fine structural characterization of glycosaminoglycans from uterine leiomyoma and normal myometrium. Biochimie. Jun. 2001;83(6):529-36. X-6. [pmid: 11506898].
1125 Mittal K, Demopoulos RI. MIB-1 (Ki-67), p53, estrogen receptor, and progesterone receptor expression in uterine smooth muscle tumors. Hum Pathol. Sep. 2001;32(9):984-7. X-6. [pmid: 11567229].
1126 Mittal K, Popiolek D, Demopoulos RI. Uterine myxoid leiomyosarcoma within a leiomyoma. Hum Pathol. Mar. 2000;31(3):398-400. CASE REPORT. [pmid: 10746687].
1127 Miyata T, Yamamoto H, Kita H, Yano T, Sunada K, Sekine Y, et al. A case of inflammatory fibroid polyp causing small-bowel intussusception in which retrograde double-balloon enteroscopy was useful for the preoperative diagnosis. Endoscopy. Apr. 2004;36(4):344-7. CASE REPORT. [pmid: 15057687].
1128 Mizobuchi S, Kuge K, Matsumoto Y, Yokoyama Y, Ookawauchi K, Tamura S, et al. Co-existence of early esophageal carcinoma and leiomyoma: a case report. Jpn J Clin Oncol. Dec. 2004;34(12):751-4. CASE REPORT. [pmid: 15640507].
1129 Mizuno K, Sasaki S, Tozawa K, Kojima Y, Hayashi Y, Kohri K. Leiomyoma of the urinary bladder during pregnancy. Int J Urol. Jul. 2003;10(7):407-9. CASE REPORT. [pmid: 12823699].
1130 Mizutani T, Sugihara A, Honma H, Komura H, Nakamuro K, Terada N. Effect of steroid add-back therapy on the proliferative activity of uterine leiomyoma cells under gonadotropin-releasing hormone agonist therapy. Gynecol Endocrinol. Feb. 2005;20(2):80-3. X-5. [pmid: 15823826].
1131 Modafferi F. Epithelioid cell's uterine leiomyoma uteri. A case report with immunohistochemical study. J Exp Clin Cancer Res. Jun. 2002;21(2):295-8. CASE REPORT. [pmid: 12148592].
1132 Moen MH, Stokstad T. A long-term follow-up study of women with asymptomatic endometriosis diagnosed incidentally at sterilization. Fertil Steril. Oct. 2002;78(4):773-6. X-6. [pmid: 12372455].
1133 Mogami T, Dohi M, Harada J. A new image navigation system for MR-guided cryosurgery. Magn Reson Med Sci. Dec 15. 2002;1(4):191-7. X-5. [pmid: 16082144].
1134 Mohammed NB, NoorAli R, AnandaKumar C. Uterine fibroid: clinical presentation and relative morbidity of abdominal myomectomy and total abdominal hysterectomy, in a teaching hospital of Karachi, Pakistan. Singapore Med J. Jun. 2002;43(6):289-95. X-4. [pmid: 12380725].
1135 Mohan PC, Tan BS, Kwek BH, Abu J, Koh D, Tay KH, et al. Uterine artery embolisation for symptomatic fibroids in a tertiary hospital in Singapore. Ann Acad Med Singapore. Jan. 2005;34(1):78-83. X-5. [pmid: 15726223].
1136 Monakhov AS, Guljaev AV, Aksenov AV, Hanson KP. Medico-genetic and cytogenetic investigation in family with high predisposition to diffuse intestine polyposis. J Exp Clin Cancer Res. Sep. 2002;21(3):347-9. X-6. [pmid: 12385576].
1137 Monteagudo A, Carreno C, Timor-Tritsch IE. Saline infusion sonohysterography in nonpregnant women with previous cesarean delivery: the “niche” in the scar. J Ultrasound Med. Oct. 2001;20(10):1105-15. X-6. [pmid: 11587017].
1138 Montgomery E, Speight PM, Fisher C. Myofibromas presenting in the oral cavity: a series of 9 cases. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Mar. 2000;89(3):343-8. X-6. [pmid: 10710461].
1139 Moon NS, Rong Zeng W, Premdas P, Santaguida M, Berube G, Nepveu A. Expression of N-terminally truncated isoforms of CDP/CUX is increased in human uterine leiomyomas. Int J Cancer. Aug 1. 2002;100(4):429-32. X-6. [pmid: 12115525].
1140 Moore SD, Herrick SR, Ince TA, Kleinman MS, Cin PD, Morton CC, et al. Uterine leiomyomata with t(10;17) disrupt the histone acetyltransferase MORF. Cancer Res. Aug 15. 2004;64(16):5570-7. X-6. [pmid: 15313893].
1141 Moorjani N, Kuo J, Ashley S, Hughes G. Intravenous uterine leiomyosarcomatosis with intracardial extension. J Card Surg. Jul–Aug. 2005;20(4):382-5. CASE REPORT. [pmid: 15985146].
1142 Morales L, Timmerman D, Neven P, Konstantinovic ML, Carbonez A, Van Huffel S, et al. Third generation aromatase inhibitors may prevent endometrial growth and reverse tamoxifen-induced uterine changes in postmenopausal breast cancer patients. Ann Oncol. Jan. 2005;16(1):70-4. X-6. [pmid: 15598941].
1143 Morice P, Chapelier A, Dartevelle P, Castaigne D, Lhomme C. Late intracaval and intracardiac leiomyomatosis following hysterectomy for benign myomas treated by surgery and GnRH agonist. Gynecol Oncol. Nov. 2001;83(2):422-3. CASE REPORT. [pmid: 11606110].
1144 Morikawa T, Kaji M, Ohtake S, Ueno T, Okushiba S, Kondo S, et al. Video-assisted anatomic mediobasal segmentectomy of lung. Surg Endosc. Oct. 2003;17(10):1678. X-6. [pmid: 14703631].
1145 Morimura M, Ishiko O, Honda KI, Sumi T, Kawamura N, Wakasa K, et al. Metachromasia of the endocervical epithelium in women treated with gonadotropin releasing hormone agonist. Int J Mol Med. Sep. 2001;8(3):319-21. X-6. [pmid: 11494062].
1146 Moritomo H, Murase T, Ebara R, Yoshikawa H. Massive vascular leiomyoma of the hand. Scand J Plast Reconstr Surg Hand Surg. 2003;37(2):125-7. CASE REPORT. [pmid: 12755515].
1147 Morris CD, Wilkinson J, Fox D, Armstrong GR, Attwood SE. Diffuse esophageal leiomyomatosis with localized dense eosinophilic infiltration. Dis Esophagus. 2002;15(1):85-7. CASE REPORT. [pmid: 12060049].
1148 Moss JG. Uterine fibroid embolization: more evidence is required. Cardiovasc Intervent Radiol. Mar–Apr. 2005;28(2):150-2. X-1. [pmid: 15883859].
1149 Mothes H, Heidet L, Arrondel C, Richter KK, Thiele M, Patzer L, et al. Alport syndrome associated with diffuse leiomyomatosis: COL4A5-COL4A6 deletion associated with a mild form of Alport nephropathy. Nephrol Dial Transplant. Jan. 2002;17(1):70-4. X-6. [pmid: 11773466].
1150 Mozzachio K, Linder K, Dixon D. Uterine smooth muscle tumors in potbellied pigs (Sus scrofa) resemble human fibroids: a potential animal model. Toxicol Pathol. Jul–Aug. 2004;32(4):402-7. X-6. [pmid: 15307213].
1151 Mozzetti S, Ferrandina G, Marone M, D'Ingiullo F, Fruscella E, De Pasqua A, et al. Expression of bcl-2, bax-xL, and bcl-xS in endometrial and cervical tissues. Cancer Detect Prev. 2000;24(6):536-41. X-6. [pmid: 11198267].
1152 Muehldorfer SM, Stolte M, Martus P, Hahn EG, Ell C. Diagnostic accuracy of forceps biopsy versus polypectomy for gastric polyps: a prospective multicentre study. Gut. Apr. 2002;50(4):465-70. X-6. [pmid: 11889063]. [pmcid: 1773183].
1153 Muller Vranjes A, Popovic Z, Vlahovic I, Habek D, Kasac Z. Heterotopic trigeminal pregnancy in infertile women after ovulation stimulation and embolisation of a uterine myoma. Fetal Diagn Ther. 2006;21(1):81-3. CASE REPORT. [pmid: 16354982].
1154 Muneyyirci-Delale O, Weisberg GW. Do heavier women benefit from a higher dose of leuprolide acetate for suppression of serum estradiol?. Int J Fertil Womens Med. Nov–Dec. 2000;45(6):368-71. X-6. [pmid: 11140546].
1155 Muniz CJ, Fleischer AC, Donnelly EF, Mazer MJ. Three-dimensional color Doppler sonography and uterine artery arteriography of fibroids: assessment of changes in vascularity before and after embolization. J Ultrasound Med. Feb. 2002;21(2):129-33. X-6. [pmid: 11833868].
1156 Murakami T, Shimizu T, Katahira A, Terada Y, Yokomizo R, Sawada R. Intraoperative injection of prostaglandin F2alpha in a patient undergoing hysteroscopic myomectomy. Fertil Steril. Jun. 2003;79(6):1439-41. CASE REPORT. [pmid: 12798895].
1157 Muramatsu Y, Sugino N, Suzuki T, Totsune K, Takahashi K, Tashiro A, et al. Urocortin and corticotropin-releasing factor receptor expression in normal cycling human ovaries. J Clin Endocrinol Metab. Mar. 2001;86(3):1362-9. X-6. [pmid: 11238533].
1158 Murata Y, Takahashi K, Murakami M, Moriya H. An unusual cause of sciatic pain. J Bone Joint Surg Br. Jan. 2001;83(1):112-3. CASE REPORT. [pmid: 11245516].
1159 Murota T, Komai Y, Danno S, Fujita I, Kawakita M, Matsuda T. Endoscopic partial cystectomy for bladder leiomyoma using retroperitoneoscopic and transurethral procedures. Int J Urol. Mar. 2002;9(3):190-2. CASE REPORT. [pmid: 12010334].
1160 Murphy EK. The presence of sales representatives in the OR. Aorn J. Apr. 2001;73(4):822-4. X-1. [pmid: 11303471].
1161 Murta EF, Oliveira GP, Prado Fde O, De Souza MA, Tavares Murta BM, Adad SJ. Association of uterine leiomyoma and Chagas' disease. Am J Trop Med Hyg. Mar. 2002;66(3):321-4. X-4. [pmid: 12139229].
1162 Nabeshima H, Murakami T, Sato Y, Terada Y, Yaegashi N, Okamura K. Successful pregnancy after myomectomy using preoperative adjuvant uterine artery embolization. Tohoku J Exp Med. Jul. 2003;200(3):145-9. CASE REPORT. [pmid: 14521257].
1163 Nagar AM, Raut AA, Narlawar RS, Bhatgadde VL, Rege S, Thapar V. Giant renal capsular leiomyoma: study of two cases. Br J Radiol. Nov. 2004;77(923):957-8. CASE REPORT. [pmid: 15507423].
1164 Nagi B, Verma V, Vaiphei K, Kochhar R, Bhasin D, Singh K. Primary small bowel tumors: a radiologic-pathologic correlation. Abdom Imaging. Sep–Oct. 2001;26(5):474-80. X-6. [pmid: 11503082].
1165 Nahir B, Eldar-Geva T, Alberton J, Beller U. Symptomatic diaphragmatic endometriosis ten years after total abdominal hysterectomy. Obstet Gynecol. Nov. 2004;104(5 Pt 2):1149-51. CASE REPORT. [pmid: 15516432].
1166 Naito S, Shimizu K, Akino K, Ohtsuru A, Watanabe M, Yamashita S, et al. Autocrine/paracrine involvement of parathyroid hormone-related peptide in vascular leiomyoma. Endocr J. Jun. 2002;49(3):335-41. X-6. [pmid: 12201218].
1167 Nakajo M, Ohkubo K, Fukukura Y, Nandate T, Nakajo M. Embolization of spontaneous rupture of an aneurysm of the ovarian artery supplying the uterus with fibroids. Acta Radiol. Dec. 2005;46(8):887-90. CASE REPORT. [pmid: 16392615].
1168 Nakamura Y, Egami K, Maeda S, Hosone M, Onda M. Primary leiomyoma of the pancreas. Int J Pancreatol. Dec. 2000;28(3):235-8. CASE REPORT. [pmid: 11373063].
1169 Nakase H, Ide M, Yazumi S, Watanabe N, Itoh T, Matsuura M, et al. Rectal leiomyoma with fibromuscular obliteration mimicking adematous lesion. Endoscopy. Mar. 2002;34(3):241. CASE REPORT. [pmid: 11870580].
1170 Nakase H, Mimura J, Kawasaki T, Itani T, Komori H, Hashimoto K, et al. Endoscopic resection of small inflammatory fibroid polyp of the colon. Intern Med. Jan. 2000;39(1):25-7. CASE REPORT. [pmid: 10674844].
1171 Nakayama H, Enzan H, Miyazaki E, Kuroda N, Toi M. Lack of CD34 positive stromal cells within angiomyomas (vascular leiomyomas). J Clin Pathol. May. 2002;55(5):395-6. X-6. [pmid: 11986351]. [pmcid: 1769649].
1172 Nakra R, Mani H, Patkar N, Nema SK. A 40-year-old woman with multiple uterine masses. Stromomyoma—mixed endometrial stromal-smooth muscle tumor of the uterus. Arch Pathol Lab Med. Dec. 2005;129(12):e222-3. CASE REPORT. [pmid: 16329742].
1173 Nanda S, Chadha N, Sen J, Sangwan K. Transvaginal sonography and saline infusion sonohysterography in the evaluation of abnormal uterine bleeding. Aust N Z J Obstet Gynaecol. Nov. 2002;42(5):530-4. X-6. [pmid: 12495102].
1174 Naqvi MM, Naseem A. Obstetrical risks in the older primigravida. J Coll Physicians Surg Pak. May. 2004;14(5):278-81. X-4. [pmid: 15225455].
1175 Narayanan TJ, Chowdary GV, Murthy JM. Contraceptive-related cerebral venous thrombosis with profuse vaginal bleed. Neurocrit Care. 2005;2(3):292-5. CASE REPORT. [pmid: 16159078].
1176 Nardo LG, Iyer L, Reginald PW. Benign pulmonary metastasizing leiomyomatosis in pregnancy: a rare complication after cesarean section. Acta Obstet Gynecol Scand. Aug. 2003;82(8):770-2. CASE REPORT. [pmid: 12848652].
1177 Narita F, Ohara N, Fukunaga K. Myomatous erythrocytosis syndrome. J Obstet Gynaecol. Sep. 2003;23(5):577. CASE REPORT. [pmid: 12963536].
1178 Nasiadek M, Krawczyk T, Sapota A. Tissue levels of cadmium and trace elements in patients with myoma and uterine cancer. Hum Exp Toxicol. Dec. 2005;24(12):623-30. X-6. [pmid: 16408615].
1179 Nass Duce M, Oz U, Ozer C, Yildiz A, Apaydin FD, Cil F. Diagnostic value of sonohysterography in the evaluation of submucosal fibroids and endometrial polyps. Aust N Z J Obstet Gynaecol. Dec. 2003;43(6):448-52. X-6. [pmid: 14712949].
1180 Nassar A, Fleisher SR, Nasuti JF. Value of histiocyte detection in Pap smears for predicting endometrial pathology. An institutional experience. Acta Cytol. Sep–Oct. 2003;47(5):762-7. X-6. [pmid: 14526675].
1181 National Institute for Health and Clinical Excellence. Treatment and care for women with heavy periods. London: National Institute for Health and Clinical Excellence 2007. X-1
1182 Navarro O, Dugougeat F, Daneman A. Sonographic signs that characterize the gastrointestinal origin of abdominal neoplasms in children: 4 case reports. Can Assoc Radiol J. Aug. 2000;51(4):250-3. CASE REPORT. [pmid: 10976247].
1183 Nayar AC, McAleer EP, Tunick PA, Applebaum RM, Colvin SB, Kronzon I. Benign metastasizing leiomyomatosis diagnosed by echocardiography. Echocardiography. Oct. 2002;19(7 Pt 1):571-2. CASE REPORT. [pmid: 12376010].
1184 Nersesyan AK, Adamyan RT. Micronuclei level in exfoliated buccal mucosa cells of patients with benign and malignant tumors of female reproductive organs and breast. Tsitol Genet. May–Jun. 2004;38(3):72-5. X-6.
1185 Nevadunsky NS, Bachmann GA, Nosher J, Yu T. Women's decision-making determinants in choosing uterine artery embolization for symptomatic fibroids. J Reprod Med. Oct. 2001;46(10):870-4. X-6. [pmid: 11725729].
1186 Newman C, Finan MA. Hysterectomy in women with cervical stenosis. Surgical indications and pathology. J Reprod Med. Sep. 2003;48(9):672-6. X-6. [pmid: 14562629].
1187 Ng C, Lam KY, Gupta TS, Ho YH. Inflammatory fibroid polyp of the caecum in a patient with neurofibromatosis. Ann Acad Med Singapore. Nov. 2004;33(6):797-9. CASE REPORT. [pmid: 15608842].
1188 Ng C, Lavery S, Hemingway A, Williamson R, McCarthy A, Trew G, et al. Successful spontaneous pregnancy following surgical removal of a post uterine artery embolized necrotic fibroid capsule: a case report. Hum Reprod. Feb. 2006;21(2):380-3. CASE REPORT. [pmid: 16223787].
1189 Ng EH, Chan CC, Tang OS, Yeung WS, Ho PC. Endometrial and subendometrial blood flow measured by three-dimensional power Doppler ultrasound in patients with small intramural uterine fibroids during IVF treatment. Hum Reprod. Feb. 2005;20(2):501-6. X-6. [pmid: 15576392].
1190 Ng EH, Ho PC. Doppler ultrasound examination of uterine arteries on the day of oocyte retrieval in patients with uterine fibroids undergoing IVF. Hum Reprod. Mar. 2002;17(3):765-70. X-6. [pmid: 11870133].
1191 Ng PH, Mahdy Z, Nik NI. Recurrent leiomyomatosis peritonealis disseminata. J Obstet Gynaecol. Feb. 2004;24(2):188-9. CASE REPORT. [pmid: 14766471].
1192 Ngeh N, Belli AM, Morgan R, Manyonda I. Pre-myomectomy uterine artery embolisation minimises operative blood loss. Bjog. Oct. 2004;111(10):1139-40. X-5. [pmid: 15383118].
1193 Nguyen NT, Alcocer JJ, Luketich JD. Thoracoscopic enucleation of an esophageal leiomyoma. J Clin Gastroenterol. Jul. 2000;31(1):89-90. CASE REPORT. [pmid: 10914787].
1194 Nicholls C, Glover L, Pistrang N. The illness experiences of women with fibroids: an exploratory qualitative study. J Psychosom Obstet Gynaecol. Sep–Dec. 2004;25(34):295-304. X-6. [pmid: 15715028].
1195 Nicholson T. Outcome in patients undergoing unilateral uterine artery embolization for symptomatic fibroids. Clin Radiol. Feb. 2004;59(2):186-91. X-5. [pmid: 14746790].
1196 Nicholson TA, Pelage JP, Ettles DF. Fibroid calcification after uterine artery embolization: ultrasonographic appearance and pathology. J Vasc Interv Radiol. Apr. 2001;12(4):443-6. X-5. [pmid: 11287530].
1197 Nikolaidis P, Siddiqi AJ, Carr JC, Vogelzang RL, Miller FH, Chrisman HB, et al. Incidence of nonviable leiomyomas on contrast material-enhanced pelvic MR imaging in patients referred for uterine artery embolization. J Vasc Interv Radiol. Nov. 2005;16(11):1465-71. X-5. [pmid: 16319152].
1198 Nikolic B, Abbara S, Levy E, Imaoka I, Lundsten ML, Jha RC, et al. Influence of radiographic technique and equipment on absorbed ovarian dose associated with uterine artery embolization. J Vasc Interv Radiol. Oct. 2000;11(9):1173-8. X-5. [pmid: 11041474].
1199 Nikolic B, Kessler CM, Jacobs HM, Abbara S, Ammann AM, Neeman Z, et al. Changes in blood coagulation markers associated with uterine artery embolization for leiomyomata. J Vasc Interv Radiol. Sep. 2003;14(9 Pt 1):1147-53. X-5. [pmid: 14514806].
1200 Nikolic B, Nguyen K, Martin LG, Redd DC, Best I, Silverstein MI. Pyosalpinx developing from a preexisting hydrosalpinx after uterine artery embolization. J Vasc Interv Radiol. Mar. 2004;15(3):297-301. CASE REPORT. [pmid: 15028817].
1201 Nikolic B, Spies JB, Campbell L, Walsh SM, Abbara S, Lundsten MJ. Uterine artery embolization: reduced radiation with refined technique. J Vasc Interv Radiol. Jan. 2001;12(1):39-44. X-5. [pmid: 11200352].
1202 Nikolic B, Spies JB, Lundsten MJ, Abbara S. Patient radiation dose associated with uterine artery embolization. Radiology. Jan. 2000;214(1):121-5. X-5. [pmid: 10644110].
1203 Ninan AC, St Luce S, Kimberl IJ, Petros JA, Issa MM. Endoscopic enucleation of leiomyoma of the bladder. Urol Int. 2005;75(1):8-9. CASE REPORT. [pmid: 16037700].
1204 Nishida M, Nasu K, Fukuda J, Kawano Y, Narahara H, Miyakawa I. Down-regulation of interleukin-1 receptor type 1 expression causes the dysregulated expression of CXC chemokines in endometriotic stromal cells: a possible mechanism for the altered immunological functions in endometriosis. J Clin Endocrinol Metab. Oct. 2004;89(10):5094-100. X-6. [pmid: 15472211].
1205 Nishida N, Nonoshita A, Kojiro S, Takemoto Y, Kojiro M. Intravenous leiomyomatosis with uterine leiomyoma and adenomyosis: a case presentation and brief comment on the histogenesis. Kurume Med J. 2003;50(34):173-5. CASE REPORT. [pmid: 14768484].
1206 Nishikawa H, Ideishi M, Nishimura T, Kawamura A, Kamochi H, Tahara H, et al. Deep venous thrombosis and pulmonary thromboembolism associated with a huge uterine myoma—a case report. Angiology. Feb. 2000;51(2):161-6. CASE REPORT. [pmid: 10701725].
1207 Nishino M, Togashi K, Nakai A, Hayakawa K, Kanao S, Iwasaku K, et al. Uterine contractions evaluated on cine MR imaging in patients with uterine leiomyomas. Eur J Radiol. Jan. 2005;53(1):142-6. X-6. [pmid: 15607866].
1208 Nishio J, Iwasaki H, Ohjimi Y, Ishiguro M, Kobayashi K, Nabeshima K, et al. Chromosomal imbalances in angioleiomyomas by comparative genomic hybridization. Int J Mol Med. Jan. 2004;13(1):13-6. X-6. [pmid: 14654964].
1209 Nishiyama Y, Koyama S, Andoh A, Kishi Y, Yoshikawa K, Ishizuka I, et al. Gastric inflammatory fibroid polyp treated with Helicobacter pylori eradication therapy. Intern Med. Mar. 2003;42(3):263-7. CASE REPORT. [pmid: 12705792].
1210 Nishizawa J, Matsumoto M, Sugita T, Matsuyama K, Tokuda Y, Yoshida K, et al. Intravenous leiomyomatosis extending into the right ventricle associated with pulmonary metastasis and extensive arteriovenous fistula. J Am Coll Surg. May. 2004;198(5):842-3. CASE REPORT. [pmid: 15110820].
1211 Nistal M, Hardisson D, Riestra ML. Multiple pulmonary leiomyomatous hamartomas associated with a bronchogenic cyst in a man. Arch Pathol Lab Med. Apr. 2003;127(4):e194-6. CASE REPORT. [pmid: 12683900].
1212 Noguchi T, Dobashi Y, Minehara H, Itoman M, Kameya T. Involvement of cyclins in cell proliferation and their clinical implications in soft tissue smooth muscle tumors. Am J Pathol. Jun. 2000;156(6):2135-47. X-6. [pmid: 10854234]. [pmcid: 1850071].
1213 Nomura H, Hata F, Yasoshima T, Kuwahara S, Naohara T, Nishimori H, et al. Giant peritoneal loose body in the pelvic cavity: report of a case. Surg Today. 2003;33(10):791-3. CASE REPORT. [pmid: 14513332].
1214 Novi JM, Shaunik A, Mulvihill BH, Morgan MA. Acute urinary retention caused by a uterine leiomyoma: a case report. J Reprod Med. Feb. 2004;49(2):131-2. CASE REPORT. [pmid: 15018444].
1215 Nowak RA. Novel therapeutic strategies for leiomyomas: targeting growth factors and their receptors. Environ Health Perspect. Oct. 2000;108(Suppl 5):849-53. X-6. [pmid: 11035994].
1216 Nowicki M, Adamkiewicz G, Bryc W, Kokot F. The influence of luteinizing hormone-releasing hormone analog on serum leptin and body composition in women with solitary uterine myoma. Am J Obstet Gynecol. Mar. 2002;186(3):340-4. X-5. [pmid: 11904588].
1217 Nozawa S, Iwata T, Yamashita H, Banno K, Kubushiro K, Aoki R, et al. Gonadotropin-releasing hormone analogue therapy for peritoneal inclusion cysts after gynecological surgery. J Obstet Gynaecol Res. Dec. 2000;26(6):389-93. X-6. [pmid: 11152322].
1218 Nozoe T, Nagamatsu A, Funahashi S, Kitamura M, Suehiro T, Matsumata T, et al. Partial resection for leiomyoblastoma of stomach. Hepatogastroenterology. Nov–Dec. 2001;48(42):1806-7. CASE REPORT. [pmid: 11813629].
1219 Nucci MR, O'Connell JT, Huettner PC, Cviko A, Sun D, Quade BJ. h-Caldesmon expression effectively distinguishes endometrial stromal tumors from uterine smooth muscle tumors. Am J Surg Pathol. Apr. 2001;25(4):455-63. X-6. [pmid: 11257619].
1220 Nucci MR, Weremowicz S, Neskey DM, Sornberger K, Tallini G, Morton CC, et al. Chromosomal translocation t(8;12) induces aberrant HMGIC expression in aggressive angiomyxoma of the vulva. Genes Chromosomes Cancer. Oct. 2001;32(2):172-6. X-6. [pmid: 11550285].
1221 Nucci MR, Young RH. Arias-Stella reaction of the endocervix: a report of 18 cases with emphasis on its varied histology and differential diagnosis. Am J Surg Pathol. May. 2004;28(5):608-12. X-6. [pmid: 15105648].
1222 Nuciforo PG, Roncalli M. Pathologic quiz case: a scrotal sac mass incidentally discovered during autopsy. Arch Pathol Lab Med. Feb. 2003;127(2):239-40. X-6. [pmid: 12562245].
1223 Numa F, Hirabayashi K, Kawasaki K, Sakaguchi Y, Sugino N, Suehiro Y, et al. Syndecan-1 expression in cancer of the uterine cervix: association with lymph node metastasis. Int J Oncol. Jan. 2002;20(1):39-43. X-6. [pmid: 11743640].
1224 Ocampo-Candiani J, Vazquez-Martinez O, Regalado-Briz A, Barboza-Quintana O, Mendez-Olvera N. Cutaneous leiomyomatosis and parotid pleomorphic adenoma. J Drugs Dermatol. Sep–Oct. 2005;4(5):642-5. CASE REPORT. [pmid: 16167424].
1225 Oczeretko E, Swiatecka J, Kitlas A, Laudanski T, Pierzynski P. Visualization of synchronization of the uterine contraction signals: running cross-correlation and wavelet running cross-correlation methods. Med Eng Phys. Jan. 2006;28(1):75-81. X-6. [pmid: 15919226].
1226 Odofin O, Nasir N, Satyadas T, Lower AM, Akle C. An unusual case of ectopic or “parasitic” leiomyoma excised by laparoscopic surgery. Int Surg. Jul–Sep. 2004;89(3):161-3. CASE REPORT. [pmid: 15521253].
1227 Oelsner G, Elizur SE, Frenkel Y, Carp H. Giant uterine tumors: two cases with different clinical presentations. Obstet Gynecol. May. 2003;101(5 Pt 2):1088-91. CASE REPORT. [pmid: 12738111].
1228 Ogliari KS, Mohallem SV, Barrozo P, Viscomi F. A uterine cavity-myoma communication after uterine artery embolization: two case reports. Fertil Steril. Jan. 2005;83(1):220-2. CASE REPORT. [pmid: 15652915].
1229 Oh KJ, Kwon BJ, Han MH, Hwang PG, Kim CJ, Na DG, et al. MR imaging findings of uveal leiomyoma: three cases. AJNR Am J Neuroradiol. Jan. 2005;26(1):100-3. CASE REPORT. [pmid: 15661710].
1230 Oh MH, Cho IC, Kang YI, Kim CY, Kim DS, Cho HD, et al. A case of retroperitoneal lipoleiomyoma. J Korean Med Sci. Apr. 2001;16(2):250-2. CASE REPORT. [pmid: 11306758].
1231 O'Hanlon DM, Clarke E, Lennon J, Gorey TF. Leiomyoma of the esophagus. Am J Surg. Aug. 2002;184(2):168-9. CASE REPORT. [pmid: 12169363].
1232 Ohara N. Acute onset of hematometra associated with endometritis and cervical stenosis. A case report. Clin Exp Obstet Gynecol. 2002;29(1):23-4. CASE REPORT. [pmid: 12013085].
1233 Ohkuchi A, Onagawa T, Usui R, Koike T, Hiratsuka M, Izumi A, et al. Effect of maternal age on blood loss during parturition: a retrospective multivariate analysis of 10,053 cases. J Perinat Med. 2003;31(3):209-15. X-6. [pmid: 12825476].
1234 Ohtani T, Tanita M, Tagami H. Resolution of a leg ulcer after hysterectomy for huge uterine myoma. J Dermatol. Jul. 2003;30(7):530-2. CASE REPORT. [pmid: 12928542].
1235 Ojili V, Bapuraj JR, Suri V. Uterine artery embolization for the treatment of symptomatic fibroids. Int J Gynaecol Obstet. Dec. 2004;87(3):249-51. X-4. [pmid: 15548400].
1236 Okada S, Yamauchi H, Ishimori S, Satoh S, Sugawara H, Tanaba Y. Endoscopic surgery with a flexible bronchoscope and argon plasma coagulation for tracheobronchial tumors. J Thorac Cardiovasc Surg. Jan. 2001;121(1):180-2. X-6. [pmid: 11135176].
1237 Okafor PI, Orakwe JC, Mbonu OO. Cyclical haematuria sequel to uterine myomectomy: a case report. West Afr J Med. Oct–Dec. 2002;21(4):341-2. CASE REPORT. [pmid: 12665283].
1238 Okai T, Minamoto T, Ohtsubo K, Minato H, Kurumaya H, Oda Y, et al. Endosonographic evaluation of c-kit-positive gastrointestinal stromal tumor. Abdom Imaging. May–Jun. 2003;28(3):301-7. X-6. [pmid: 12719898].
1239 Okamoto K, Ito J, Takahashi H, Emura I, Mori H, Furusawa T, et al. Solitary myofibromatosis of the skull. Eur Radiol. 2000;10(1):170-4. CASE REPORT. [pmid: 10663739].
1240 Okamoto T, Koshiyama M, Yamamoto K. Treatment of huge uterine tumors thought to be benign in post-menopausal women. Med Sci Monit. Feb. 2004;10(2):CR43-5. X-5. [pmid: 14737041].
1241 Okamoto T, Koshiyama M, Yamamoto K. Rapidly growing leiomyoma in a postmenopausal woman. J Obstet Gynaecol Res. Aug. 2004;30(4):316-8. CASE REPORT. [pmid: 15238109].
1242 Okolo SO, Gentry CC, Perrett CW, Maclean AB. Familial prevalence of uterine fibroids is associated with distinct clinical and molecular features. Hum Reprod. Aug. 2005;20(8):2321-4. X-6. [pmid: 15860490].
1243 Olagundoye V, Jackson S, Manek S. Fatal septicaemia following rupture of a gangrenous fibroid. Bjog. Oct. 2004;111(10):1141-2. CASE REPORT. [pmid: 15383119].
1244 Olayemi O, Adekanle DA, Aimakhu CO, Adeniji AO, Udoh ES, Ogunowo TO. Blood loss at fibroids surgery: myomectomy versus total abdominal hysterectomy. Trop Doct. Jul. 2005;35(3):171-2. X-4. [pmid: 16105348].
1245 Oliva E, Young RH, Amin MB, Clement PB. An immunohistochemical analysis of endometrial stromal and smooth muscle tumors of the uterus: a study of 54 cases emphasizing the importance of using a panel because of overlap in immunoreactivity for individual antibodies. Am J Surg Pathol. Apr. 2002;26(4):403-12. X-6. [pmid: 11914617].
1246 Oliveira FG, Abdelmassih VG, Diamond MP, Dozortsev D, Melo NR, Abdelmassih R. Impact of subserosal and intramural uterine fibroids that do not distort the endometrial cavity on the outcome of in vitro fertilization-intracytoplasmic sperm injection. Fertil Steril. Mar. 2004;81(3):582-7. X-6. [pmid: 15037406].
1247 Oliver RJ, Coulthard P, Carre C, Sloan P. Solitary adult myofibroma of the mandible simulating an odontogenic cyst. Oral Oncol. Sep. 2003;39(6):626-9. CASE REPORT. [pmid: 12798407].
1248 Omary RA, Vasireddy S, Chrisman HB, Ryu RK, Pereles FS, Carr JC, et al. The effect of pelvic MR imaging on the diagnosis and treatment of women with presumed symptomatic uterine fibroids. J Vasc Interv Radiol. Nov. 2002;13(11):1149-53. X-6. [pmid: 12427815].
1249 Omeroglu A, Husain A. Multilocular peritoneal inclusion cyst (benign cystic mesothelioma). Arch Pathol Lab Med. Aug. 2001;125(8):1123-4. CASE REPORT. [pmid: 11473477].
1250 Omodei U, Ferrazzi E, Ramazzotto F, Becorpi A, Grimaldi E, Scarselli G, et al. Endometrial evaluation with transvaginal ultrasound during hormone therapy: a prospective multicenter study. Fertil Steril. Jun. 2004;81(6):1632-7. X-6. [pmid: 15193487].
1251 Onishi S, Hojo N, Sakai I, Matsumoto T, Watanabe A, Miyazaki T, et al. Secondary amyloidosis and eosinophilia in a patient with uterine leiomyosarcoma. Jpn J Clin Oncol. Oct. 2005;35(10):617-21. CASE REPORT. [pmid: 16172171].
1252 Orcy RB, Brum I, da Silva RS, Kucharski LC, Corleta HE, Capp E. Insulin receptor tyrosine kinase activity and substrate 1 (IRS-1) expression in human myometrium and leiomyoma. Eur J Obstet Gynecol Reprod Biol. Nov 1. 2005;123(1):107-10. X-6. [pmid: 16260343].
1253 Orii A, Masutani H, Nikaido T, Zhai YL, Kato K, Kariya M, et al. Altered post-translational modification of redox factor 1 protein in human uterine smooth muscle tumors. J Clin Endocrinol Metab. Aug. 2002;87(8):3754-9. X-6. [pmid: 12161506].
1254 Orji EO, Fasubaa OB, Adeyemi B, Dare FO, Onwudiegwu U, Ogunniyi SO. Mortality and morbidity associated with misdiagnosis of ectopic pregnancy in a defined Nigerian population. J Obstet Gynaecol. Sep. 2002;22(5):548-50. X-4. [pmid: 12521428].
1255 Orsini G, Fioroni M, Rubini C, Piattelli A. Leiomyoma of the lip: report of a case. J Oral Maxillofac Surg. Jan. 2001;59(1):80-3. CASE REPORT. [pmid: 11152195].
1256 Oruc S, Karaer O, Kurtul O. Coexistence of a prolapsed, pedunculated cervical myoma and pregnancy complications: a case report. J Reprod Med. Jul. 2004;49(7):575-7. CASE REPORT. [pmid: 15305833].
1257 O'Shea RT, Cook JR, Seman EI. Total laparoscopic hysterectomy: a new option for removal of the large myomatous uterus. Aust N Z J Obstet Gynaecol. Aug. 2002;42(3):282-4. X-5. [pmid: 12230064].
1258 Ososki AL, Lohr P, Reiff M, Balick MJ, Kronenberg F, Fugh-Berman A, et al. Ethnobotanical literature survey of medicinal plants in the Dominican Republic used for women's health conditions. J Ethnopharmacol. Mar. 2002;79(3):285-98. X-6. [pmid: 11849831].
1259 Osuga Y, Yano T, Kugu K, Koga K, Fukuoka K, Matsumi H, et al. Effects of gonadotropin-releasing hormone analog treatment on skin condition. Gynecol Endocrinol. Feb. 2002;16(1):57-61. X-5. [pmid: 11915583].
1260 Ouchi J, Araki Y, Chijiiwa Y, Kubo H, Hamada S, Ochiai T, et al. Endosonographic probe-guided endoscopic removal of colonic pedunculated leiomyoma. Acta Gastroenterol Belg. Jul–Sep. 2000;63(3):314-6. CASE REPORT. [pmid: 11190001].
1261 Ozer N, Engin H, Akgul E, Sahiner L, Atalar E, Aksoyek S, et al. An unusual case of recurrent mass in the right atrium: intravenous leiomyomatosis. Echocardiography. Jul. 2005;22(6):514-6. CASE REPORT. [pmid: 15966937].
1262 Ozercan IH, Cobanoglu B, Simsek M, Dogan C, Ozercan MR. Epidermoid cyst of the ovary: a case report. Pathologica. Aug. 2000;92(4):284-5. CASE REPORT. [pmid: 11029890].
1263 Ozolek JA, Sasatomi E, Swalsky PA, Rao U, Krasinskas A, Finkelstein SD. Inflammatory fibroid polyps of the gastrointestinal tract: clinical, pathologic, and molecular characteristics. Appl Immunohistochem Mol Morphol. Mar. 2004;12(1):59-66. X-6. [pmid: 15163021].
1264 Ozumba B, Ezegwui H. Intrauterine adhesions in an African population. Int J Gynaecol Obstet. Apr. 2002;77(1):37-8. X-6. [pmid: 11929656].
1265 Paal E, Miettinen M. Retroperitoneal leiomyomas: a clinicopathologic and immunohistochemical study of 56 cases with a comparison to retroperitoneal leiomyosarcomas. Am J Surg Pathol. Nov. 2001;25(11):1355-63. X-6. [pmid: 11684951].
1266 Padhye S, Karki C. Voluntary surgical contraception: a study on level of satisfaction. Nepal Med Coll J. Jun. 2003;5(1):18-21. X-6. [pmid: 16583968].
1267 Pahwa R, Khurana N, Chaturvedi KU. Angiomyoma of the palate—a case report. Indian J Pathol Microbiol. Apr. 2004;47(2):229-30. CASE REPORT. [pmid: 16295479].
1268 Paik SS, Oh YH, Jang KS, Han HX, Cho SH. Uterine leiomyoma with massive lymphoid infiltration: case report and review of the literature. Pathol Int. May. 2004;54(5):343-8. CASE REPORT. [pmid: 15086839].
1269 Palazzo L, Landi B, Cellier C, Cuillerier E, Roseau G, Barbier JP. Endosonographic features predictive of benign and malignant gastrointestinal stromal cell tumours. Gut. Jan. 2000;46(1):88-92. X-6. [pmid: 10601061]. [pmcid: 1727785].
1270 Palomba S, Sena T, Morelli M, Noia R, Zullo F, Mastrantonio P. Effect of different doses of progestin on uterine leiomyomas in postmenopausal women. Eur J Obstet Gynecol Reprod Biol. May 10. 2002;102(2):199-201. X-5. [pmid: 11950491].
1271 Pambuccian CA, Oprea GM, Lakatua DJ. Reduced expression of early growth response-1 gene in leiomyoma as identified by mRNA differential display. Gynecol Oncol. Mar. 2002;84(3):431-6. X-6. [pmid: 11855883].
1272 Panici PB, Zullo MA, Angioli R, Muzii L. Minilaparotomy hysterectomy: a valid option for the treatment of benign uterine pathologies. Eur J Obstet Gynecol Reprod Biol. Apr 1. 2005;119(2):228-31. X-6. [pmid: 15808385].
1273 Pantanowitz L, Antonioli DA, Pinkus GS, Shahsafaei A, Odze RD. Inflammatory fibroid polyps of the gastrointestinal tract: evidence for a dendritic cell origin. Am J Surg Pathol. Jan. 2004;28(1):107-14. X-6. [pmid: 14707872].
1274 Parasi A, Triantafillidis JK, Barbatzas C, Karakosta A, Condilis N, Sotiriou H. Coexistence of Crohn's disease and inflammatory fibroid polyp of the small bowel. Report of a case and review of the literature. Ann Ital Chir. Jul–Aug. 2005;76(4):395-9. CASE REPORT. [pmid: 16550878].
1275 Parazzini F. Left:right side ratio of endometriotic implants in the pelvis. Eur J Obstet Gynecol Reprod Biol. Nov 10. 2003;111(1):65-7. X-6. [pmid: 14557014].
1276 Parazzini F, Chiaffarino F, Polverino G, Chiantera V, Surace M, La Vecchia C. Uterine fibroids risk and history of selected medical conditions linked with female hormones. Eur J Epidemiol. 2004;19(3):249-53. X-6. [pmid: 15117118].
1277 Parikh P, Chan TY, Epstein JI, Argani P. Incidental stromal-predominant mixed epithelial-stromal tumors of the kidney: a mimic of intraparenchymal renal leiomyoma. Arch Pathol Lab Med. Jul. 2005;129(7):910-4. X-6. [pmid: 15974815].
1278 Park HR, Kim MD, Kim NK, Kim HJ, Yoon SW, Park WK, et al. Uterine restoration after repeated sloughing of fibroids or vaginal expulsion following uterine artery embolization. Eur Radiol. Sep. 2005;15(9):1850-4. X-4. [pmid: 15729564].
1279 Park KH, Kim JY, Shin JS, Kwon JY, Koo JS, Jeong KA, et al. Treatment outcomes of uterine artery embolization and laparoscopic uterine artery ligation for uterine myoma. Yonsei Med J. Aug 30. 2003;44(4):694-702. X-4. [pmid: 12950127].
1280 Park SH, Lee JH, Chae YS, Kim CH. Recurrent mesectodermal leiomyoma of the ciliary body: a case report. J Korean Med Sci. Aug. 2003;18(4):614-7. CASE REPORT. [pmid: 12923346].
1281 Parkar RB, Thagana NG. Hysteroscopic surgery at the Aga Khan Hospital, Nairobi. East Afr Med J. Jul. 2004;81(7):336-40. X-4. [pmid: 15490704].
1282 Parker RL, Young RH, Clement PB. Skeletal muscle-like and rhabdoid cells in uterine leiomyomas. Int J Gynecol Pathol. Oct. 2005;24(4):319-25. X-5. [pmid: 16175075].
1283 Parker WH, Broder MS, Liu Z, Shoupe D, Farquhar C, Berek JS. Ovarian conservation at the time of hysterectomy for benign disease. Obstet Gynecol. Aug. 2005;106(2):219-26. X-6. [pmid: 16055568].
1284 Pasrija S, Trivedi SS, Narula MK. Prospective study of saline infusion sonohysterography in evaluation of perimenopausal and postmenopausal women with abnormal uterine bleeding. J Obstet Gynaecol Res. Feb. 2004;30(1):27-33. X-4. [pmid: 14718017].
1285 Passaro MD, Piquion J, Mullen N, Sutherland D, Zhai S, Figg WD, et al. Luteal phase dose-response relationships of the antiprogestin CDB-2914 in normally cycling women. Hum Reprod. Sep. 2003;18(9):1820-7. X-6. [pmid: 12923133].
1286 Pathan SK, Kapila K, Haji BE, Mallik MK, Al-Ansary TA, George SS, et al. Cytomorphological spectrum in scar endometriosis: a study of eight cases. Cytopathology. Apr. 2005;16(2):94-9. X-6. [pmid: 15787652].
1287 Patrikis MI, Bryan EJ, Thomas NA, Rice GE, Quinn MA, Baker MS, et al. Mutation analysis of CDP, TP53, and KRAS in uterine leiomyomas. Mol Carcinog. Jun. 2003;37(2):61-4. X-6. [pmid: 12766905].
1288 Patton KT, Cheng L, Papavero V, Blum MG, Yeldandi AV, Adley BP, et al. Benign metastasizing leiomyoma: clonality, telomere length and clinicopathologic analysis. Mod Pathol. Jan. 2006;19(1):130-40. X-6. [pmid: 16357844].
1289 Pavlica P, Bartolone A, Gaudiano C, Barozzi L. Female paraurethral leiomyoma: ultrasonographic and magnetic resonance imaging findings. Acta Radiol. Nov. 2004;45(7):796-8. CASE REPORT. [pmid: 15624526].
1290 Pavlovich SV, Volkov NI, Burlev VA. Proliferative activity and level of steroid hormone receptors in the myometrium and myoma nodes in different phases of menstrual cycle. Bull Exp Biol Med. Oct. 2003;136(4):396-8. X-6. [pmid: 14714093].
1291 Payne JF, Haney AF. Serious complications of uterine artery embolization for conservative treatment of fibroids. Fertil Steril. Jan. 2003;79(1):128-31. CASE REPORT. [pmid: 12524075].
1292 Payne JF, Robboy SJ, Haney AF. Embolic microspheres within ovarian arterial vasculature after uterine artery embolization. Obstet Gynecol. Nov. 2002;100(5 Pt 1):883-6. CASE REPORT. [pmid: 12423846].
1293 Pedeutour F, Quade BJ, Sornberger K, Tallini G, Ligon AH, Weremowicz S, et al. Dysregulation of HMGIC in a uterine lipoleiomyoma with a complex rearrangement including chromosomes 7, 12, and 14. Genes Chromosomes Cancer. Feb. 2000;27(2):209-15. X-6. [pmid: 10612811].
1294 Pei M, Yu C, Qu M. Expression of collagen type I, II and III in loose body of osteoarthritis. J Orthop Sci. 2000;5(3):288-93. X-6. [pmid: 10982671].
1295 Pekindil G, Tuncyurek O, Orguc S, Inceboz U, Kandiloglu AR, Caglar H. A case of endometrial stromal sarcoma with curvilinear calcification. Gynecol Oncol. Aug. 2005;98(2):318-21. CASE REPORT. [pmid: 15963554].
1296 Pelage JP, Guaou NG, Jha RC, Ascher SM, Spies JB. Uterine fibroid tumors: long-term MR imaging outcome after embolization. Radiology. Mar. 2004;230(3):803-9. X-5. [pmid: 14990844].
1297 Pelage JP, Jacob D, Fazel A, Namur J, Laurent A, Rymer R, et al. Midterm results of uterine artery embolization for symptomatic adenomyosis: initial experience. Radiology. Mar. 2005;234(3):948-53. X-6. [pmid: 15681687].
1298 Pelage JP, Le Dref O, Beregi JP, Nonent M, Robert Y, Cosson M, et al. Limited uterine artery embolization with tris-acryl gelatin microspheres for uterine fibroids. J Vasc Interv Radiol. Jan. 2003;14(1):15-20. X-5. [pmid: 12525582].
1299 Pelage JP, Le Dref O, Soyer P, Kardache M, Dahan H, Abitbol M, et al. Fibroid-related menorrhagia: treatment with superselective embolization of the uterine arteries and midterm follow-up. Radiology. May. 2000;215(2):428-31. X-5. [pmid: 10796920].
1300 Pelage JP, Walker WJ, Le Dref O, Rymer R. Ovarian artery: angiographic appearance, embolization and relevance to uterine fibroid embolization. Cardiovasc Intervent Radiol. May–Jun. 2003;26(3):227-33. X-6. [pmid: 14562969].
1301 Pellicano M, Bramante S, Cirillo D, Palomba S, Bifulco G, Zullo F, et al. Effectiveness of autocrosslinked hyaluronic acid gel after laparoscopic myomectomy in infertile patients: a prospective, randomized, controlled study. Fertil Steril. Aug. 2003;80(2):441-4. X-5. [pmid: 12909511].
1302 Pellicano M, Guida M, Bramante S, Acunzo G, Di Spiezio Sardo A, Tommaselli GA, et al. Reproductive outcome after autocrosslinked hyaluronic acid gel application in infertile patients who underwent laparoscopic myomectomy. Fertil Steril. Feb. 2005;83(2):498-500. X-5. [pmid: 15705404].
1303 Pelosi MA 2nd, Pelosi MA 3rd. A new nonabsorbable adhesion barrier for myomectomy. Am J Surg. Nov. 2002;184(5):428-32. X-5. [pmid: 12433607].
1304 Pelosi MA, Pelosi MA 3rd, Eim J. Hand-assisted laparoscopy for megamyomectomy. A case report. J Reprod Med. Jun. 2000;45(6):519-25. CASE REPORT. [pmid: 10900591].
1305 Pereira SG, Davies RJ, Ballantyne GH, Duperier T. Laparoscopic wedge resection of a gastric leiomyoma. Surg Endosc. Aug. 2001;15(8):896-7. X-6. [pmid: 11443434].
1306 Perera ND, Senanayake L, Vithana VH, Fernando R. An unusual presentation of female urethral leiomyoma. Ceylon Med J. Mar. 2005;50(1):31-3. CASE REPORT. [pmid: 15881563].
1307 Perez-Medina T, Bajo JM, Martinez-Cortes L, Castellanos P, Perez de Avila I. Six thousand office diagnostic-operative hysteroscopies. Int J Gynaecol Obstet. Oct. 2000;71(1):33-8. X-6. [pmid: 11044539].
1308 Perimenis P, Speakman M. Incidental presentation of leiomyoma of bladder with carincoma of the prostate. Int Urol Nephrol. 2000;32(2):279-80. CASE REPORT. [pmid: 11229649].
1309 Perri P, Paduano B, Incorvaia C, Costagliola C, Parmeggiani F, Rossi S, et al. Mesectodermal leiomyoma exclusively involving the posterior choroid. Am J Ophthalmol. Sep. 2002;134(3):451-4. CASE REPORT. [pmid: 12208265].
1310 Perrone G, DeAngelis C, Critelli C, Capri O, Galoppi P, Santoro G, et al. Hysteroscopic findings in postmenopausal abnormal uterine bleeding: a comparison between HRT users and non-users. Maturitas. Dec 10. 2002;43(4):251-5. X-5. [pmid: 12468133].
1311 Peterson WA, Bates MC, Chauhan S, Lee JC, Hernandez DP. Team approach with gynecologists taking the lead role in selecting patients for uterine artery embolization. W V Med J. Sep–Oct. 2004;100(5):182-4. X-6. [pmid: 15617462].
1312 Peyton-Jones B, Fiadjoe P, Fox R. Massive uterine leiomyomas and successful pregnancy. J Obstet Gynaecol. Sep. 2003;23(5):569-70. CASE REPORT. [pmid: 12963528].
1313 Philippoussis F, Gagne D, Hugo P, Gosselin D. Concentrations of alpha-fetoprotein, insulin-like growth factor binding protein-3, c-erbB-2, and epidermal growth factor in serum of patients with endometriosis. J Soc Gynecol Investig. Apr. 2004;11(3):175-81. X-6.
1314 Phupong V, Tresukosol D, Taneepanichskul S, Boonkasemsanti W. Unilateral deep vein thrombosis associated with a large myoma uteri. A case report. J Reprod Med. Jun. 2001;46(6):618-20. CASE REPORT. [pmid: 11441692].
1315 Pietura R, Jakiel G, Swatowski D, Semczuk M, Szczerbo-Trojanowska M. Pregnancy 4 months after uterine artery embolization. Cardiovasc Intervent Radiol. Jan–Feb. 2005;28(1):117-9. CASE REPORT. [pmid: 15772730].
1316 Pillay K, R Chetty. Test and teach. A uterine tumour causing a diagnostic dilemma. Low-grade endometrial stromal sarcoma with extensive endometrioid glandular differentiation. Pathology. Aug. 2003;35(4):344-6. X-6. [pmid: 12959770].
1317 Pimentel JR, de Almeida AL, Aymore IL, Pinto EP, Osthoff L, Smith J. Metastatic skeletal leiomyomatosis (leiomyomatosis ossea). Skeletal Radiol. Jan. 2002;31(1):30-4. CASE REPORT. [pmid: 11807590].
1318 Pinto I, Chimeno P, Romo A, Paul L, Haya J, de la Cal MA, et al. Uterine fibroids: uterine artery embolization versus abdominal hysterectomy for treatment—a prospective, randomized, and controlled clinical trial. Radiology. Feb. 2003;226(2):425-31. X-5. [pmid: 12563136].
1319 Pistorius GA, Hegenauer K, Pahl S, Feifel G. Intrathoracic diverticulum caused by a leiomyoma: a rare case of spontaneous oesophageal rupture. Eur J Surg. May. 2000;166(5):426-8. CASE REPORT. [pmid: 10881960].
1320 Pitukkijronnakorn S, Leelachaikul P, Chittacharoen A. Labial leiomyoma: a case report. J Med Assoc Thai. Jan. 2005;88(1):118-9. CASE REPORT. [pmid: 15960230].
1321 Polan ML, Warrington JA, Chen B, Mahadevappa M, Wang H, Wen Y. Bench to bedside: clinical opportunities for microarray analysis. Fertil Steril. Aug. 2003;80(2):291-2. X-6. [pmid: 12909488].
1322 Pollard P, Wortham N, Barclay E, Alam A, Elia G, Manek S, et al. Evidence of increased microvessel density and activation of the hypoxia pathway in tumours from the hereditary leiomyomatosis and renal cell cancer syndrome. J Pathol. Jan. 2005;205(1):41-9. X-6. [pmid: 15586379].
1323 Pollard PJ, Briere JJ, Alam NA, Barwell J, Barclay E, Wortham NC, et al. Accumulation of Krebs cycle intermediates and over-expression of HIF1alpha in tumours which result from germline FH and SDH mutations. Hum Mol Genet. Aug 1. 2005;14(15):2231-9. X-6. [pmid: 15987702].
1324 Pollard RR, Goldberg JM. Prolapsed cervical myoma after uterine artery embolization. A case report. J Reprod Med. May. 2001;46(5):499-500. CASE REPORT. [pmid: 11396381].
1325 Pollio F, Staibano S, Mansueto G, De Rosa G, Persico F, De Falco M, et al. Erythropoietin and erythropoietin receptor system in a large uterine myoma of a patient with myomatous erythrocytosis syndrome: possible relationship with the pathogenesis of unusual tumor size. Hum Pathol. Jan. 2005;36(1):120-7. CASE REPORT. [pmid: 15712191].
1326 Pollock J, Morgan D, Denobile J, Williams J. Adjuvant radiotherapy for gastrointestinal stromal tumor of the rectum. Dig Dis Sci. Feb. 2001;46(2):268-72. X-6. [pmid: 11281173].
1327 Poncelet C, Fauvet R, Feldmann G, Walker F, Madelenat P, Darai E. Prognostic value of von Willebrand factor, CD34, CD31, and vascular endothelial growth factor expression in women with uterine leiomyosarcomas. J Surg Oncol. May 1. 2004;86(2):84-90. X-6. [pmid: 15112250].
1328 Poncelet C, Madelenat P, Feldmann G, Walker F, Darai E. Expression of von Willebrand's factor, CD34, CD31, and vascular endothelial growth factor in uterine leiomyomas. Fertil Steril. Sep. 2002;78(3):581-6. X-6. [pmid: 12215337].
1329 Poncelet C, Walker F, Madelenat P, Bringuier AF, Scoazec JY, Feldmann G, et al. Expression of CD44 standard and isoforms V3 and V6 in uterine smooth muscle tumors: a possible diagnostic tool for the diagnosis of leiomyosarcoma. Hum Pathol. Nov. 2001;32(11):1190-6. X-6. [pmid: 11727257].
1330 Porpora MG, Picarelli A, Prosperi Porta R, Di Tola M, D'Elia C, Cosmi EV. Celiac disease as a cause of chronic pelvic pain, dysmenorrhea, and deep dyspareunia. Obstet Gynecol. May. 2002;99(5 Pt 2):937-9. CASE REPORT. [pmid: 11975966].
1331 Pourbagher A, Pourbagher MA, Bal N, Oguzkurt L, Ezer A. Leiomyoma of the breast parenchyma. AJR Am J Roentgenol. Dec. 2005;185(6):1595-7. CASE REPORT. [pmid: 16304020].
1332 Pournaras CC, Comacle P, Moulonguet I, Cavelier-Balloy B, Dubertret L, Basset-Seguin N. Multiple painful cutaneous nodules. Arch Dermatol. May. 2005;141(5):633-8. CASE REPORT. [pmid: 15897394].
1333 Powell LH, Meyer P, Weiss G, Matthews KA, Santoro N, Randolph JF Jr, et al. Ethnic differences in past hysterectomy for benign conditions. Womens Health Issues. Jul–Aug. 2005;15(4):179-86. X-6. [pmid: 16051109].
1334 Preutthipan S, Herabutya Y. Vaginal misoprostol for cervical priming before operative hysteroscopy: a randomized controlled trial. Obstet Gynecol. Dec. 2000;96(6):890-4. X-6. [pmid: 11084173].
1335 Price N, Nakade K, Kehoe ST. A rapidly growing uterine fibroid postpartum. Bjog. May. 2004;111(5):503-5. CASE REPORT. [pmid: 15104619].
1336 Prieto A, Crespo C, Pardo A, Docal I, Calzada J, Alonso P. Uterine lipoleiomyomas: US and CT findings. Abdom Imaging. Nov–Dec. 2000;25(6):655-7. X-6. [pmid: 11029102].
1337 Pritts EA. Fibroids and infertility: a systematic review of the evidence. Obstet Gynecol Surv. Aug. 2001;56(8):483-91. X-1. [pmid: 11496160].
1338 Prollius A, de Vries C, Loggenberg E, du Plessis A, Nel M, Wessels PH. Uterine artery embolisation for symptomatic fibroids: the effect of the large uterus on outcome. Bjog. Mar. 2004;111(3):239-42. X-4. [pmid: 14961885].
1339 Prollius A, de Vries C, Loggenberg E, Nel M, du Plessis A, Van Rensburg DJ, et al. Uterine artery embolization for symptomatic fibroids. Int J Gynaecol Obstet. Mar. 2004;84(3):236-40. X-4. [pmid: 15001371].
1340 Prollius A, du Plessis A, Nel M. Uterine artery embolization in HIV positive patients. Int J Gynaecol Obstet. Jan. 2005;88(1):67-8. X-4. [pmid: 15617714].
1341 Pron G, Mocarski E, Bennett J, Vilos G, Common A, Vanderburgh L. Pregnancy after uterine artery embolization for leiomyomata: the Ontario multicenter trial. Obstet Gynecol. Jan. 2005;105(1):67-76. X-5. [pmid: 15625144].
1342 K. E. Puca and H. H. Wu. Pathologic quiz case. An incidental endometrial tumor masked by large leiomyoma. Arch Pathol Lab Med. 2002 Jul;126(7):864, 865–6. CASE REPORT
1343 Pujol J, Pares D, Mora L, Sans M, Jaurrieta E. Diagnosis and management of diffuse leiomyomatosis of the oesophagus. Dis Esophagus. 2000;13(2):169-71. X-6. [pmid: 14601911].
1344 Pulle C, Sturlese E. Clinical trial comparing the activity and efficacy of ibuprofen isobutanolammonium vs Benzydamine hydrochloride, applied as vaginal irrigations, in patients with vaginitis. Clin Exp Obstet Gynecol. 2002;29(3):173-9. X-6. [pmid: 12519036].
1345 Qidwai GI, Caughey AB, Jacoby AF. Obstetric outcomes in women with sonographically identified uterine leiomyomata. Obstet Gynecol. Feb. 2006;107(2 Pt 1):376-82. X-6. [pmid: 16449127].
1346 Quade BJ, Dal Cin P, Neskey DM, Weremowicz S, Morton CC. Intravenous leiomyomatosis: molecular and cytogenetic analysis of a case. Mod Pathol. Mar. 2002;15(3):351-6. X-6. [pmid: 11904348].
1347 Quade BJ, Wang TY, Sornberger K, Dal Cin P, Mutter GL, Morton CC. Molecular pathogenesis of uterine smooth muscle tumors from transcriptional profiling. Genes Chromosomes Cancer. Jun. 2004;40(2):97-108. X-6. [pmid: 15101043].
1348 Quade BJ, Weremowicz S, Neskey DM, Vanni R, Ladd C, Dal Cin P, et al. Fusion transcripts involving HMGA2 are not a common molecular mechanism in uterine leiomyomata with rearrangements in 12q15. Cancer Res. Mar 15. 2003;63(6):1351-8. X-6. [pmid: 12649198].
1349 Rabinovici J, Inbar Y, Eylon SC, Schiff E, Hananel A, Freundlich D. Pregnancy and live birth after focused ultrasound surgery for symptomatic focal adenomyosis: a case report. Hum Reprod. May. 2006;21(5):1255-9. CASE REPORT. [pmid: 16410334].
1350 Rahili A, D'Amata G, Avallone S, Piche M, Benchimol D. Concomitant leiomyoma and leiomyosarcoma of the oesophagus. J Exp Clin Cancer Res. Sep. 2005;24(3):487-91. CASE REPORT. [pmid: 16270537].
1351 Rai VM, Balachandran C, Kudva R. Multiple painful nodules. Indian J Dermatol Venereol Leprol. Nov–Dec. 2005;71(6):449-51. CASE REPORT. [pmid: 16394498].
1352 Rajab KE, Aradi AN, Datta BN. Postmenopausal leimyomatosis peritonealis disseminata. Int J Gynaecol Obstet. Mar. 2000;68(3):271-2. CASE REPORT. [pmid: 10699204].
1353 Ramachandran S, Song MQ, Lowe E, Dominguez CE, Parthasarathy S, Murphy AA. RU486 inhibits expression of lysophosphatidic acid induced glycodelin. Am J Obstet Gynecol. Apr. 2005;192(4):1285-93. discussion 1293–4. X-6. [pmid: 15846221].
1354 Ramazan D, Orhan U, Bulent K, Nagehan O, Cem T. A urachal leiomyoma misdiagnosed as an ovarian tumor. Eur J Obstet Gynecol Reprod Biol. Dec 10. 2001;100(1):94-5. CASE REPORT. [pmid: 11728666].
1355 Ramesh L, Edozien L. Not all disseminated intra-abdominal lesions are malignant: a case of leiomyomatosis peritonealis disseminata. J Obstet Gynaecol. May. 2005;25(4):409. CASE REPORT. [pmid: 16091343].
1356 Rao VS, Naik R, Nayak KS. Leiomyoma of the kidney—report of two cases. Indian J Pathol Microbiol. Jul. 2001;44(3):343-4. CASE REPORT. [pmid: 12024929].
1357 Rattray CA, Parris CN, Chisholm G, Coard KC. Complete non-puerperial uterine inversion as a result of a uterine sarcoma. West Indian Med J. Sep. 2000;49(3):245-7. CASE REPORT. [pmid: 11076223].
1358 Razavi MK, Wolanske KA, Hwang GL, Sze DY, Kee ST, Dake MD. Angiographic classification of ovarian artery-to-uterine artery anastomoses: initial observations in uterine fibroid embolization. Radiology. Sep. 2002;224(3):707-12. X-5. [pmid: 12202703].
1359 Redan JA, Gardner JC, Tylutki FJ. Hand-assisted laparoscopy for the removal of an esophageal leiomyoma. Jsls. Apr–Jun. 2001;5(2):167-9. CASE REPORT. [pmid: 11394430].
1360 Reddy BV, Lee J, Cunningham PL. Giant uterine leiomyoma with air-fluid levels. J Am Coll Surg. May. 2004;198(5):844-5. CASE REPORT. [pmid: 15132153].
1361 Reddy NM, Jain KA, Gerscovich EO. A degenerating cystic uterine fibroid mimicking an endometrioma on sonography. J Ultrasound Med. Sep. 2003;22(9):973-6. CASE REPORT. [pmid: 14510270].
1362 Redman JF, Liang X, Ferguson MA, Savell VH. Leiomyoma of the glans penis in a child. J Urol. Sep. 2000;164(3 Pt 1):791. CASE REPORT. [pmid: 10953157].
1363 Reekers JA. Uterine artery embolization: what the others say. Cardiovasc Intervent Radiol. Jul–Aug. 2004;27(4):305-6. X-1. [pmid: 15366216].
1364 Regidor PA, Engel K, Regidor M, Grummer R, Traub O, Winterhager E, et al. Expression of the gap junction connexins Cx43, Cx45 and Cx26 in human uterine leiomyomata. Gynecol Endocrinol. Apr. 2001;15(2):113-22. X-6. [pmid: 11379007].
1365 Ren RL, Wu HH. Pathologic quiz case: a 40-year-old woman with an unusual uterine tumor. Uterine angiolipoleiomyoma with focal atypical leiomyoma. Arch Pathol Lab Med. Feb. 2004;128(2):e31-2. CASE REPORT. [pmid: 14736266].
1366 Reron A, Huras H. Influence of the operative treatment of leiomyomas on lipid profile. Neuro Endocrinol Lett. Dec. 2004;25(6):429-34. X-4. [pmid: 15665805].
1367 Reslova T, M Resl. The coincidence of pure lipoma, leiomyoma, and endometrial cancer. A case report of the uterine tumor triplicity. Acta Medica (Hradec Kralove). 2003;46(3):129-30. CASE REPORT. [pmid: 14677724].
1368 Reubi JC, Laderach U, Waser B, Gebbers JO, Robberecht P, Laissue JA. Vasoactive intestinal peptide/pituitary adenylate cyclase-activating peptide receptor subtypes in human tumors and their tissues of origin. Cancer Res. Jun 1. 2000;60(11):3105-12. X-6. [pmid: 10850463].
1369 Reyad MM, Gazvani MR, Khine MM. A rare case of primary leiomyoma of the vulva. J Obstet Gynaecol. Jan. 2006;26(1):73-4. CASE REPORT. [pmid: 16390721].
1370 Rha SE, Sohn KM, Lee SY, Jung HS, Park SM, Kim KM. Pedunculated exogastric leiomyoblastoma presenting as a wandering abdominal mass. Abdom Imaging. Sep–Oct. 2000;25(5):545-7. CASE REPORT. [pmid: 10931995].
1371 Ribeiro SC, Ribeiro RM, Santos NC, Pinotti JA. A randomized study of total abdominal, vaginal and laparoscopic hysterectomy. Int J Gynaecol Obstet. Oct. 2003;83(1):37-43. X-4. [pmid: 14511870].
1372 Rice DC, Bakaeen F, Farley DR, Unni KK, van Heerden JA. Surgical management of duodenal leiomyomas. World J Surg. May. 2001;25(5):562-6. X-6. [pmid: 11369980].
1373 Rich DA, Stokes IM. Uterine torsion due to a fibroid, emergency myomectomy and transverse upper segment caesarean section. Bjog. Jan. 2002;109(1):105-6. CASE REPORT. [pmid: 11843369].
1374 Richlin SS, Ramachandran S, Shanti A, Murphy AA, Parthasarathy S. Glycodelin levels in uterine flushings and in plasma of patients with leiomyomas and polyps: implications for implantation. Hum Reprod. Oct. 2002;17(10):2742-7. X-6. [pmid: 12351556].
1375 Rim Nam H, Jae Huh S, Taik Park C, Kim B, Ahn G. A case of invasive squamous cell carcinoma on the surface of pedunculated cervical leiomyoma presenting an exophytic cervical cancer. Gynecol Oncol. Apr. 2005;97(1):253-5. CASE REPORT. [pmid: 15790470].
1376 Ringold S. FDA approves ultrasound fibroid therapy. Jama. Dec 15. 2004;292(23):2826. X-1. [pmid: 15598901].
1377 Rivier JE, Hoeger C, Erchegyi J, Gulyas J, DeBoard R, Craig AG, et al. Potent somatostatin undecapeptide agonists selective for somatostatin receptor 1 (sst1). J Med Chem. Jun 21. 2001;44(13):2238-46. X-6. [pmid: 11405660].
1378 Roan CJ, Chuang JH, Hsu TY, Tsai HY, Pan LL, Cheng JT. Estrogen receptor beta is not increasingly expressed in leiomyoma nodules which show no progressive enlargement in premenopausal women. J Formos Med Assoc. Dec. 2005;104(12):920-6. X-5. [pmid: 16607449].
1379 Robb-Nicholson C. By the way, doctor. I am 59 years old, in good health, and have been on HRT (estrogen and progesterone) for about 10 years. I have tried several different preparations, but despite this, have developed a uterine fibroid, experienced indigestion, gained 20 pounds, and had one abnormal mammogram (with, thankfully, a negative biopsy). Because there is heart disease in my family, my doctor wants me to stay on HRT for the rest of my life. Can you suggest any alternatives?. Harv Womens Health Watch. Jan. 2000;7(5):8. X-1.
1380 Robb-Nicholson C. By the way, doctor. What can I do about irregular bleeding during perimenopause?. Harv Womens Health Watch. Apr. 2003;10(8):8. X-1.
1381 Robles-Frias A, Severin CE, Robles-Frias MJ, Garrido JL. Diffuse uterine leiomyomatosis with ovarian and parametrial involvement. Obstet Gynecol. May. 2001;97(5 Pt 2):834-5. CASE REPORT. [pmid: 11336772].
1382 Rogerson L, Bates J, Weston M, Duffy S. A comparison of outpatient hysteroscopy with saline infusion hysterosonography. Bjog. Jul. 2002;109(7):800-4. X-6. [pmid: 12135217].
1383 Rohatgi A, Singh KK. Laparoendoscopic management of gastrointestinal stromal tumors. J Laparoendosc Adv Surg Tech A. Feb. 2003;13(1):37-40. CASE REPORT. [pmid: 12676020].
1384 Romer T, Schwesinger G. Chance finding of a leiomyosarcoma in hysteroscopic resection of a myoma. Acta Obstet Gynecol Scand. Nov. 2002;81(11):1078-9. CASE REPORT. [pmid: 12421178].
1385 Romero FR, Kohanim S, Lima G, Permpongkosol S, Fine SW, Kavoussi LR. Leiomyomas of the kidney: emphasis on conservative diagnosis and treatment. Urology. Dec. 2005;66(6):1319. CASE REPORT.
1386 Roques F, Sanchez B, Bucher B, Lariviere J. Role of pre-operative assessment in the surgical management of leiomyoma extended to the right heart chambers: a compendium of information from isolated reports. Eur J Cardiothorac Surg. Apr. 2001;19(4):522-4. CASE REPORT. [pmid: 11306327].
1387 Rosenbaum SP, Fried M, Munro MG. Endometrial hydrothermablation: a comparison of short-term clinical effectiveness in patients with normal endometrial cavities and those with intracavitary pathology. J Minim Invasive Gynecol. Mar–Apr. 2005;12(2):144-9. X-5. [pmid: 15904618].
1388 Rossetti A, Sizzi O, Soranna L, Mancuso S, Lanzone A. Fertility outcome: long-term results after laparoscopic myomectomy. Gynecol Endocrinol. Apr. 2001;15(2):129-34. X-5. [pmid: 11379009].
1389 Rossi G, Valli R, Bertolini F, Marchioni A, Cavazza A, Mucciarini C, et al. PDGFR expression in differential diagnosis between KIT-negative gastrointestinal stromal tumours and other primary soft-tissue tumours of the gastrointestinal tract. Histopathology. May. 2005;46(5):522-31. X-6. [pmid: 15842634].
1390 Roth AR, Spies JB, Walsh SM, Wood BJ, Gomez-Jorge J, Levy EB. Pain after uterine artery embolization for leiomyomata: can its severity be predicted and does severity predict outcome?. J Vasc Interv Radiol. Sep. 2000;11(8):1047-52. X-5. [pmid: 10997469].
1391 Roth LM, Reed RJ. Cotyledonoid leiomyoma of the uterus: report of a case. Int J Gynecol Pathol. Jul. 2000;19(3):272-5. CASE REPORT. [pmid: 10907177].
1392 Rothlin M, Schob O. Laparoscopic wedge resection for benign gastric tumors. Surg Endosc. Aug. 2001;15(8):893-5. X-6. [pmid: 11443418].
1393 Rouzi AA, Al-Noury AI, Shobokshi AS, Jamal HS, Abduljabbar HS. Abdominal myomectomy versus abdominal hysterectomy for symptomatic and big uterine fibroids. Saudi Med J. Nov. 2001;22(11):984-6. X-4. [pmid: 11744970].
1394 Roy C, Bierry G, Ghali SE, Buy X, Rossini A. Acute torsion of uterine leiomyoma: CT features. Abdom Imaging. Jan–Feb. 2005;30(1):120-3. CASE REPORT. [pmid: 15647881].
1395 Roy MK, Joarder RH, Suruzzaman M, Kundu KK, Hossain MA, Alam MM, et al. Leiomyoma of the urinary bladder. Mymensingh Med J. Jul. 2005;14(2):209-11. CASE REPORT. [pmid: 16056215].
1396 Rupp CC, Nagel TC, Swanlund DJ, Bischof JC, Coad JE. Cryothermic and hyperthermic treatments of human leiomyomata and adjacent myometrium and their implications for laparoscopic surgery. J Am Assoc Gynecol Laparosc. Feb. 2003;10(1):90-8. X-6. [pmid: 12555001].
1397 Rush DS, Tan J, Baergen RN, Soslow RA. h-Caldesmon, a novel smooth muscle-specific antibody, distinguishes between cellular leiomyoma and endometrial stromal sarcoma. Am J Surg Pathol. Feb. 2001;25(2):253-8. X-6. [pmid: 11176075].
1398 Rusher AH, Davis K, Phillips D, Wiggins L. Open versus thoracoscopic removal of left-sided mid-esophageal leiomyoma. J Ark Med Soc. Jan. 2001;97(7):247-9. X-6. [pmid: 11189104].
1399 Rustin P. Mitochondria, from cell death to proliferation. Nat Genet. Apr. 2002;30(4):352-3. X-6. [pmid: 11925557].
1400 Rutanen E, Hurskainen R, Finne P, Nokelainen K. Induction of endometrial plasminogen activator-inhibitor 1: a possible mechanism contributing to the effect of intrauterine levonorgestrel in the treatment of menorrhagia. Fertil Steril. May. 2000;73(5):1020-4. X-6. [pmid: 10785231].
1401 Ryu RK. Uterine artery embolization: current implications of embolic agent choice. J Vasc Interv Radiol. Nov. 2005;16(11):1419-22. X-1. [pmid: 16319145].
1402 Ryu RK, Chrisman HB, Omary RA, Miljkovic S, Nemcek AA Jr, Saker MB, et al. The vascular impact of uterine artery embolization: prospective sonographic assessment of ovarian arterial circulation. J Vasc Interv Radiol. Sep. 2001;12(9):1071-4. X-5. [pmid: 11535770].
1403 Ryu RK, Siddiqi A, Omary RA, Chrisman HB, Nemcek AA Jr, Sichlau MJ, et al. Sonography of delayed effects of uterine artery embolization on ovarian arterial perfusion and function. AJR Am J Roentgenol. Jul. 2003;181(1):89-92. X-5. [pmid: 12818835].
1404 Saad AG, Kaouk JH, Kaspar HG, Khauli RB. Leiomyoma of the urethra: report of 3 cases of a rare entity. Int J Surg Pathol. Apr. 2003;11(2):123-6. CASE REPORT. [pmid: 12754634].
1405 Sabatini L, Atiomo W, Magos A. Successful myomectomy following infected ischaemic necrosis of uterine fibroids after uterine artery embolisation. Bjog. Jul. 2003;110(7):704-6. CASE REPORT. [pmid: 12842064].
1406 Sabatini R, Ferreri R, Distante G, Loizzi V, Loizzi P. Benign metastasizing leiomyoma in the lung: a case report. Eur J Gynaecol Oncol. 2002;23(5):445-6. CASE REPORT. [pmid: 12440822].
1407 Sadan O, Ginath S, Sofer D, Rotmensch S, Debby A, Glezerman M, et al. The role of tamoxifen in the treatment of symptomatic uterine leiomyomata — a pilot study. Eur J Obstet Gynecol Reprod Biol. Jun. 2001;96(2):183-6. X-5. [pmid: 11384804].
1408 Saez F, Urresola A, Larena JA, Martin JI, Pijuan JI, Schneider J, et al. Endometrial carcinoma: assessment of myometrial invasion with plain and gadolinium-enhanced MR imaging. J Magn Reson Imaging. Sep. 2000;12(3):460-6. X-6. [pmid: 10992314].
1409 Saglam A, Guler G, Taskin M, Ayhan A, Uner AH. Uterine leiomyoma with prominent lymphoid infiltrate. Int J Gynecol Cancer. Jan–Feb. 2005;15(1):167-70. CASE REPORT. [pmid: 15670313].
1410 Sah SP, Agrawal CS, Rani S. Inflammatory fibroid polyp of the jejunum presenting as intussusception. Indian J Pathol Microbiol. Jan. 2002;45(1):119-21. CASE REPORT. [pmid: 12593579].
1411 Saha R, Sharma M, Padhye S, Karki U, Pandey S, Thapa J. Hysterectomy: an analysis of perioperative and post operative complication. Kathmandu Univ Med J (KUMJ). Apr–Jun. 2003;1(2):124-7. X-4. [pmid: 16388212].
1412 Sahlin L, Wang H, Lindblom B, Eriksson H, Holmgren A, Blanck A. Thioredoxin expression in human myometrium and fibroids. Mol Hum Reprod. Jan. 2000;6(1):60-7. X-6. [pmid: 10611262].
1413 Sahoo B, Radotra BD, Kaur I, Kumar B. Zosteriform pilar leiomyoma. J Dermatol. Dec. 2001;28(12):759-61. CASE REPORT. [pmid: 11804075].
1414 Saint M, Gildengorin G, Sawaya GF. Current cervical neoplasia screening practices of obstetrician/gynecologists in the US. Am J Obstet Gynecol. Feb. 2005;192(2):414-21. X-6. [pmid: 15695980].
1415 Saito E, Okamoto A, Saito M, Shinozaki H, Takakura S, Yanaihara N, et al. Genes associated with the genesis of leiomyoma of the uterus in a commonly deleted chromosomal region at 7q22. Oncol Rep. Mar. 2005;13(3):469-72. X-6. [pmid: 15706419].
1416 Saitoh M, Hayasaka T, Nakahara K, Ohmichi M, Shimazaki Y, Kurachi H. Intravenous leiomyomatosis with cardiac extension. Gynecol Obstet Invest. 2004;58(3):168-70. CASE REPORT. [pmid: 15249745].
1417 Sakamoto H, Jikuya T, Sasaki A, Satoh M, Sakakibara Y. Severely calcified intravenous leiomyomatosis with cardiac extension. Jpn J Thorac Cardiovasc Surg. Mar. 2004;52(3):148-51. CASE REPORT. [pmid: 15077850].
1418 Sakamoto K, Ohmori T, Takei H. Catamenial pneumothorax caused by endometriosis in the visceral pleura. Ann Thorac Surg. Jul. 2003;76(1):290-1. CASE REPORT. [pmid: 12842566].
1419 Sakamoto T, Kato H, Okabe T, Ohya T, Iesato H, Yokomori T, et al. A large inflammatory fibroid polyp of the colon treated by endoclip-assisted endoscopic polypectomy: A case report. Dig Liver Dis. Dec. 2005;37(12):968-72. CASE REPORT. [pmid: 16243012].
1420 Sakellariou P, Protopapas A, Kyritsis N, Voulgaris Z, Papaspirou E, Diakomanolis E. Intramural leiomyoma of the bladder. Eur Radiol. 2000;10(6):906-8. CASE REPORT. [pmid: 10879700].
1421 Sakhel K, Khalil A, Kaspar H, Azar G, Mansour A, Nassar A. Placental site trophoblastic tumor in a patient with secondary infertility and radiological findings consistent with a leiomyoma: a case report. Int J Gynecol Cancer. Jul–Aug. 2004;14(4):694-6. CASE REPORT. [pmid: 15304170].
1422 Salerno MG, Masciullo V, Naldini A, Zannoni GF, Vellone V, Scambia G. Endometrioid adenocarcinoma with squamous differentiation arising from ureteral endometriosis in a patient with no history of gonadal endometriosis. Gynecol Oncol. Dec. 2005;99(3):749-52. CASE REPORT. [pmid: 16226301].
1423 Salim R, Lee C, Davies A, Jolaoso B, Ofuasia E, Jurkovic D. A comparative study of three-dimensional saline infusion sonohysterography and diagnostic hysteroscopy for the classification of submucous fibroids. Hum Reprod. Jan. 2005;20(1):253-7. X-6. [pmid: 15498782].
1424 Salvador E, Bienstock J, Blakemore KJ, Pressman E. Leiomyomata uteri, genetic amniocentesis, and the risk of second-trimester spontaneous abortion. Am J Obstet Gynecol. May. 2002;186(5):913-5. X-6. [pmid: 12015511].
1425 Salvig JD, Petersen KR, Moller BR. Acute abdominal pain caused by torsion of an enlarged non-pregnant uterus. J Obstet Gynaecol. Jan. 2005;25(1):81-2. CASE REPORT. [pmid: 16147712].
1426 Samaiya A, Chumber S, Vashishth S, Karak AK. Oesophageal leiomyoma presenting as a mediastinal mass. Trop Gastroenterol. Oct–Dec. 2000;21(4):204-6. CASE REPORT. [pmid: 11194589].
1427 Sampath D, Zhu Y, Winneker RC, Zhang Z. Aberrant expression of Cyr61, a member of the CCN (CTGF/Cyr61/Cef10/NOVH) family, and dysregulation by 17 beta-estradiol and basic fibroblast growth factor in human uterine leiomyomas. J Clin Endocrinol Metab. Apr. 2001;86(4):1707-15. X-6. [pmid: 11297607].
1428 Sandhu AK, Hassan WY. Uterine fibroid embolization: is there a role?. Saudi Med J. May. 2004;25(5):669-70. X-1. [pmid: 15138541].
1429 Sang H. Clinical and experimental research into treatment of hysteromyoma with promoting qi flow and blood circulation, softening and resolving hard lump. J Tradit Chin Med. Dec. 2004;24(4):274-9. X-4. [pmid: 15688694].
1430 Sano K, Kobayashi M, Sakaguchi N, Ito M, Hotchi M, Matsumoto K. A rat model of hypereosinophilic syndrome. Pathol Int. Feb. 2001;51(2):82-8. X-6. [pmid: 11169145].
1431 Santos Gda C, Alves VA, Wakamatsu A, Zucoloto S. Inflammatory fibroid polyp: an immunohistochemical study. Arq Gastroenterol. Apr–Jun. 2004;41(2):104-7. X-6. [pmid: 15543383].
1432 Sapmaz E, Celik H, Altungul A. Bilateral ascending uterine artery ligation vs. tourniquet use for hemostasis in cesarean myomectomy. A comparison. J Reprod Med. Dec. 2003;48(12):950-4. X-4. [pmid: 14738022].
1433 Saraiya PV, Chang TC, Pelage JP, Spies JB. Uterine artery replacement by the round ligament artery: an anatomic variant discovered during uterine artery embolization for leiomyomata. J Vasc Interv Radiol. Sep. 2002;13(9 Pt 1):939-41. CASE REPORT. [pmid: 12354830].
1434 Sarlomo-Rikala M, Tsujimura T, Lendahl U, Miettinen M. Patterns of nestin and other intermediate filament expression distinguish between gastrointestinal stromal tumors, leiomyomas and schwannomas. Apmis. Jun. 2002;110(6):499-507. X-6. [pmid: 12193211].
1435 Sato F, Miyake H, Nishi M, Kudo R. Fertility and uterine size among Asian women undergoing hysterectomy for leiomyomas. Int J Fertil Womens Med. Jan–Feb. 2000;45(1):34-7. X-5. [pmid: 10721742].
1436 Sato F, Miyake H, Nishi M, Mori M, Kudo R. Early normal menstrual cycle pattern and the development of uterine leiomyomas. J Womens Health Gend Based Med. Apr. 2000;9(3):299-302. X-5. [pmid: 10787225].
1437 Sato F, Mori M, Nishi M, Kudo R, Miyake H. Familial aggregation of uterine myomas in Japanese women. J Epidemiol. May. 2002;12(3):249-53. X-5. [pmid: 12164328].
1438 Satyanarayana S, Jawed KZ, Sikri V, Kaur B, Singh P. Myxoid leiomyoma of tunica vaginalis testis. Indian J Pathol Microbiol. Jul. 2001;44(3):373-4. CASE REPORT. [pmid: 12024941].
1439 Saunders RN, Pattenden C, Agarawal PK. Heavy rectal bleeding secondary to the passage of a rectal leiomyoma per anus. Ann R Coll Surg Engl. Nov. 2004;86(6):W44-6. CASE REPORT. [pmid: 15005947]. [pmcid: 1964010].
1440 Savargaonkar P, Morgenstern N, Bhuiya T. Inflammatory fibroid polyp of the ileum causing intussusception: report of two cases with emphasis on cytologic diagnosis. Diagn Cytopathol. Apr. 2003;28(4):217-21. CASE REPORT. [pmid: 12672099].
1441 Sayer RA, Amundsen CL. Giant pelvic retroperitoneal leiomyoma arising from the rectal wall. Obstet Gynecol. May. 2003;101(5 Pt 2):1132-4. CASE REPORT. [pmid: 12738127].
1442 Scapinelli R, Iacobellis C, Taglialavoro G, Blandamura S, Baggio ME. Vascular leiomyoma of the limbs. Chir Organi Mov. Apr–Jun. 2001;86(2):143-52. CASE REPORT. [pmid: 12025046].
1443 Schindl M, Birner P, Losch A, Breitenecker G, Joura EA. Preperitoneal lipoleiomyoma of the abdominal wall in a postmenopausal woman. Maturitas. Nov 30. 2000;37(1):33-6. CASE REPORT. [pmid: 11099871].
1444 Schlotzer-Schrehardt U, Junemann A, Naumann GO. Mitochondria-rich epithelioid leiomyoma of the ciliary body. Arch Ophthalmol. Jan. 2002;120(1):77-82. X-6. [pmid: 11786062].
1445 Schmidt CS, Bentz ML. Congenital smooth muscle hamartoma: the importance of differentiation from melanocytic nevi. J Craniofac Surg. Sep. 2005;16(5):926-9. X-6. [pmid: 16192884].
1446 Schmidt-Rohlfing B, Tietze L, Siebert CH, Staatz G. Deep soft-tissue leiomyoma of the popliteal fossa in a 14-year-old girl. Arch Orthop Trauma Surg. Nov. 2001;121(10):604-6. CASE REPORT. [pmid: 11768646].
1447 Schwartz SM. Invited commentary: Studying the epidemiology of uterine leiomyomata—past, present, and future. Am J Epidemiol. Jan 1. 2001;153(1):27-9. discussion 30. X-1. [pmid: 11159142].
1448 Schwesinger WH, Sirinek KR, Gaskill HV 3rd, Velez JP, Corea JJ, Strodel WE. Jejunoileal causes of overt gastrointestinal bleeding: diagnosis, management, and outcome. Am Surg. Apr. 2001;67(4):383-7. X-6. [pmid: 11308010].
1449 Scialli AR, Levi AJ. Intermittent leuprolide acetate for the nonsurgical management of women with leiomyomata uteri. Fertil Steril. Sep. 2000;74(3):540-6. X-5. [pmid: 10973652].
1450 Sclabas GM, Maurer CA, Wente MN, Zimmermann A, Buchler MW. Case report: hepatic leiomyoma in a renal transplant recipient. Transplant Proc. Dec. 2002;34(8):3200-2. CASE REPORT. [pmid: 12493419].
1451 Scurry J, Kerdemelidis P, Fortune D. Small atypical leiomyomas: report of two cases. Pathology. Aug. 2001;33(3):319-21. CASE REPORT. [pmid: 11523933].
1452 Seckin NC, Turhan NO, Kopal S, Inegol I. Acardiac twin: a misdiagnosed, mismanaged case. Eur J Obstet Gynecol Reprod Biol. Apr 25. 2003;107(2):212-3. CASE REPORT. [pmid: 12648873].
1453 Seidman DS, Nezhat CH, Nezhat F, Nezhat C. The role of laparoscopic-assisted myomectomy (LAM). Jsls. Oct–Dec. 2001;5(4):299-303. X-1. [pmid: 11719974].
1454 Seiji M, Shinnichi I, Motojyuku M, Akieda K, Yamamoto I, Inokuchi S. Traumatic avulsion of the uterine myoma. J Trauma. Dec. 2005;59(6):1532. CASE REPORT. [pmid: 16394937].
1455 Seinera P, Farina C, Todros T. Laparoscopic myomectomy and subsequent pregnancy: results in 54 patients. Hum Reprod. Sep. 2000;15(9):1993-6. X-5. [pmid: 10967002].
1456 Seki H, Takizawa Y, Sodemoto T. Epidural analgesia for painful myomas refractory to medical therapy during pregnancy. Int J Gynaecol Obstet. Dec. 2003;83(3):303-4. CASE REPORT. [pmid: 14643043].
1457 Sekulic SR, Vuleta PD, Vuleta DP. Breech presentation and tossing a coin: heads or tails. Med Hypotheses. Feb. 2003;60(2):218-24. X-6. [pmid: 12606239].
1458 Sell SM, Patel S, Stracner D, Meloni A. Allelic loss analysis by capillary electrophoresis: an accurate, automated method for detection of deletions in solid tumors. Genet Test. Fall. 2001;5(3):267-8. X-6. [pmid: 11788095].
1459 Sell SM, Tullis C, Stracner D, Song CY, Gewin J. Minimal interval defined on 7q in uterine leiomyoma. Cancer Genet Cytogenet. Feb. 2005;157(1):67-9. X-6. [pmid: 15676150].
1460 Sena-Martins M, Roteli-Martins CM, Tadini V, de Souza GA, Kisilevzky N, Lazar F Junior. Uterine artery embolization for the treatment of symptomatic myomas in Brazilian women. Sao Paulo Med J. Sep 1. 2003;121(5):185-90. X-4. [pmid: 14666289].
1461 Sentilhes L, Sergent F, Verspyck E, Gravier A, Roman H, Marpeau L. Laparoscopic myomectomy during pregnancy resulting in septic necrosis of the myometrium. Bjog. Sep. 2003;110(9):876-8. CASE REPORT. [pmid: 14511975].
1462 Senturk LM, Sozen I, Gutierrez L, Arici A. Interleukin 8 production and interleukin 8 receptor expression in human myometrium and leiomyoma. Am J Obstet Gynecol. Mar. 2001;184(4):559-66. X-6. [pmid: 11262453].
1463 Seoud MA, Nassar AH, Usta IM, Melhem Z, Kazma A, Khalil AM. Impact of advanced maternal age on pregnancy outcome. Am J Perinatol. Jan. 2002;19(1):1-8. X-6. [pmid: 11857090].
1464 Sepilian V, Della Badia C. Iatrogenic endometriosis caused by uterine morcellation during a supracervical hysterectomy. Obstet Gynecol. Nov. 2003;102(5 Pt 2):1125-7. CASE REPORT. [pmid: 14607029].
1465 Seracchioli R, Bagnoli A, Colombo FM, Missiroli S, Venturoli S. Conservative treatment of recurrent ovarian fibromas in a young patient affected by Gorlin syndrome. Hum Reprod. Jun. 2001;16(6):1261-3. CASE REPORT. [pmid: 11387302].
1466 Seracchioli R, Colombo FM, Bagnoli A, Govoni F, Missiroli S, Venturoli S. Laparoscopic myomectomy for fibroids penetrating the uterine cavity: is it a safe procedure?. Bjog. Mar. 2003;110(3):236-40. X-5. [pmid: 12628260].
1467 Sesti F, La Marca L, Pietropolli A, Piccione E. Multiple leiomyomas of the vagina in a premenopausal woman. Arch Gynecol Obstet. Sep. 2004;270(2):131-2. CASE REPORT. [pmid: 12827387].
1468 Settnes A, Andreasen AH, Jorgensen T. Hypertension is associated with an increased risk for hysterectomy: a Danish cohort study. Eur J Obstet Gynecol Reprod Biol. Oct 1. 2005;122(2):218-24. X-6. [pmid: 16219523].
1469 Sewell PE, Arriola RM, Robinette L, Cowan BD. Real-time I-MR-imaging—guided cryoablation of uterine fibroids. J Vasc Interv Radiol. Jul. 2001;12(7):891-3. X-5. [pmid: 11435548].
1470 Shadbolt CL, Coakley FV, Qayyum A, Donat SM. MRI of vaginal leiomyomas. J Comput Assist Tomogr. May–Jun. 2001;25(3):355-7. X-6. [pmid: 11351183].
1471 Shah AN, Olah KS. Cervical stump carcinoma following subtotal hysterectomy. J Obstet Gynaecol. Nov. 2002;22(6):701. CASE REPORT. [pmid: 12554282].
1472 Shalom A, Wasserman I, Segal M, Orda R. Inflammatory fibroid polyp and Helicobacter pylori. Aetiology or coincidence?. Eur J Surg. Jan. 2000;166(1):54-7. X-6. [pmid: 10688218].
1473 Shamonki MI, Ziegler WF, Badger GJ, Sites CK. Prediction of endometrial ablation success according to perioperative findings. Am J Obstet Gynecol. May. 2000;182(5):1005-7. X-5. [pmid: 10819809].
1474 Shan H, Huang MS, Guan SH, Jiang ZB, Zhu KS, Li ZR. Superselective uterine arterial embolization with pingyangmycin-lipiodol emulsion for management of symptomatic uterine leiomyoma. Chin Med J (Engl). Jan. 2004;117(1):75-8. X-4. [pmid: 14733778].
1475 Shao JB, Wong F. Factors influencing the choice of hysterectomy. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):303-6. X-6. [pmid: 11592545].
1476 Shapiro A, Ferenczy A, Turcotte R, Bruchim I, Gotlieb WH. Uterine smooth-muscle tumor of uncertain malignant potential metastasizing to the humerus as a high-grade leiomyosarcoma. Gynecol Oncol. Sep. 2004;94(3):818-20. CASE REPORT. [pmid: 15350379].
1477 Sharma B, Preston J, Ray C. Microwave endometrial ablation for menorrhagia: outcome at 2 years—experience of a district general hospital. J Obstet Gynaecol. Nov. 2004;24(8):916-9. X-6. [pmid: 16147652].
1478 Sharma JB, Wadhwa L, Malhotra M, Arora R, Garg A, Singh S. Huge localized vaginal neurofibromatosis: an unusual cause of postmenopausal bleeding. J Obstet Gynaecol Res. Apr. 2004;30(2):96-9. CASE REPORT. [pmid: 15009610].
1479 Sharma P, Chaturvedi KU, Gupta R, Nigam S. Leiomyomatosis peritonealis disseminata with malignant change in a post-menopausal woman. Gynecol Oncol. Dec. 2004;95(3):742-5. CASE REPORT. [pmid: 15581996].
1480 Shashoua AR, Stringer NH, Pearlman JB, Behmaram B, Stringer EA. Ischemic uterine rupture and hysterectomy 3 months after uterine artery embolization. J Am Assoc Gynecol Laparosc. May. 2002;9(2):217-20. CASE REPORT. [pmid: 11960052].
1481 Shee JJ, Huang ST, Chang PL, Hsieh ML, Wang TM. Leiomyoma of the epididymis: case report. Chang Gung Med J. Mar. 2000;23(3):175-9. CASE REPORT. [pmid: 15641222].
1482 Sheiner E, Bashiri A, Levy A, Hershkovitz R, Katz M, Mazor M. Obstetric characteristics and perinatal outcome of pregnancies with uterine leiomyomas. J Reprod Med. Mar. 2004;49(3):182-6. X-6. [pmid: 15098887].
1483 Sheiner E, Biderman-Madar T, Katz M, Levy A, Hadar A, Mazor M. Higher rates of tachysystole among patients with clinically apparent uterine leiomyomas. Am J Obstet Gynecol. Sep. 2004;191(3):945-8. X-6. [pmid: 15467569].
1484 Shenoy MU, Singh SJ, Robson K, Stewart RJ. Gastrointestinal stromal tumor: a rare cause of neonatal intestinal obstruction. Med Pediatr Oncol. Jan. 2000;34(1):70-1. CASE REPORT. [pmid: 10611593].
1485 Sherer DM, Maitland CY, Levine NF, Eisenberg C, Abulafia O. Prenatal magnetic resonance imaging assisting in differentiating between large degenerating intramural leiomyoma and complex adnexal mass during pregnancy. J Matern Fetal Med. May–Jun. 2000;9(3):186-9. CASE REPORT. [pmid: 10914629].
1486 S. K. Shergill, H. K. Shergill, M. Gupta and S. Kaur. Clinicopathological study of hysterectomies. J Indian Med Assoc. 2002 Apr;100(4):238–9, 246. X-4
1487 Shetty SC, Kini U, D'Cruz MN, Hasan S. Angioleiomyoma in the tonsil: an uncommon tumour in a rare site. Br J Oral Maxillofac Surg. Apr. 2002;40(2):169-71. CASE REPORT. [pmid: 12180214].
1488 Shetty SM, Kalokhe S, Rathi P, Desai N, Sethna KS, Rajyadhyaksha G, et al. Duodenal leiomyoma—a rare cause of haematemesis. J Assoc Physicians India. Nov. 2001;49:1114-5. CASE REPORT. [pmid: 11868869].
1489 Shiau CS, Chang MY, Chiang CH, Hsieh CC, Hsieh TT. Ovarian endometrioma associated with very high serum CA-125 levels. Chang Gung Med J. Sep. 2003;26(9):695-9. X-6. [pmid: 14651169].
1490 Shimada K, Ohashi I, Kasahara I, Miyasaka N, Shibuya H. Triple-phase dynamic MRI of intratumoral vessel density and hyalinization grade in uterine leiomyomas. AJR Am J Roentgenol. Apr. 2004;182(4):1043-50. X-6. [pmid: 15039185].
1491 Shimada K, Ohashi I, Kasahara I, Watanabe H, Ohta S, Miyasaka N, et al. Differentiation between completely hyalinized uterine leiomyomas and ordinary leiomyomas: three-phase dynamic magnetic resonance imaging (MRI) vs. diffusion-weighted MRI with very small b-factors. J Magn Reson Imaging. Jul. 2004;20(1):97-104. X-6. [pmid: 15221814].
1492 Shimada K, Ohashi I, Shibuya H, Tanabe F, Akashi T. MR imaging of an atypical vaginal leiomyoma. AJR Am J Roentgenol. Mar. 2002;178(3):752-4. CASE REPORT. [pmid: 11856713].
1493 Shime H, Kariya M, Orii A, Momma C, Kanamori T, Fukuhara K, et al. Tranilast inhibits the proliferation of uterine leiomyoma cells in vitro through G1 arrest associated with the induction of p21(waf1) and p53. J Clin Endocrinol Metab. Dec. 2002;87(12):5610-7. X-6. [pmid: 12466360].
1494 Shinojima N, Ohta K, Yano S, Nakamura H, Kochi M, Ishimaru Y, et al. Myofibroblastoma in the suprasellar region. Case report. J Neurosurg. Nov. 2002;97(5):1203-7. CASE REPORT. [pmid: 12450045].
1495 Shirvani AR, Winters JC. Vaginal leiomyoma presenting as a urethral diverticulum. J Urol. Jun. 2000;163(6):1869. CASE REPORT. [pmid: 10799207].
1496 Shivkumar PV, Barick RD, Shambharkar C. Fundal leiomyoma presenting as acute on chronic uterine inversion. J Obstet Gynaecol. Nov. 2005;25(8):832-3. CASE REPORT. [pmid: 16368606].
1497 Shlansky-Goldberg R, Cope C. A new twist on the Waltman loop for uterine fibroid embolization. J Vasc Interv Radiol. Aug. 2001;12(8):997-1000. X-6. [pmid: 11487683].
1498 Shojaie M, Abbas Z, Sultan N, Kazi J. Gastrointestinal stromal tumours: a case report and recent concepts. J Pak Med Assoc. May. 2004;54(5):278-80. CASE REPORT. [pmid: 15270191].
1499 Shozu M, Murakami K, Segawa T, Kasai T, Inoue M. Successful treatment of a symptomatic uterine leiomyoma in a perimenopausal woman with a nonsteroidal aromatase inhibitor. Fertil Steril. Mar. 2003;79(3):628-31. CASE REPORT. [pmid: 12620453].
1500 Shozu M, Murakami K, Segawa T, Kasai T, Ishikawa H, Shinohara K, et al. Decreased expression of early growth response-1 and its role in uterine leiomyoma growth. Cancer Res. Jul 1. 2004;64(13):4677-84. X-6. [pmid: 15231681].
1501 Shozu M, Sumitani H, Segawa T, Yang HJ, Murakami K, Inoue M. Inhibition of in situ expression of aromatase P450 in leiomyoma of the uterus by leuprorelin acetate. J Clin Endocrinol Metab. Nov. 2001;86(11):5405-11. X-6. [pmid: 11701714].
1502 Shozu M, Sumitani H, Segawa T, Yang HJ, Murakami K, Kasai T, et al. Overexpression of aromatase P450 in leiomyoma tissue is driven primarily through promoter I.4 of the aromatase P450 gene (CYP19). J Clin Endocrinol Metab. Jun. 2002;87(6):2540-8. X-6. [pmid: 12050211].
1503 Shushan A, Protopapas A, Hart R, Magos AL. Diagnostic and therapeutic advantages of hysteroscopic surgery in management of intrauterine lesions in postmenopausal women. J Am Assoc Gynecol Laparosc. Feb. 2001;8(1):87-91. X-5. [pmid: 11172120].
1504 Shushan A, Revel A, Laufer N, Rojansky N. Hysteroscopic treatment of intrauterine lesions in premenopausal and postmenopausal women. J Am Assoc Gynecol Laparosc. May. 2002;9(2):209-13. X-5. [pmid: 11960050].
1505 Shushan A, Rojansky N, Laufer N, Klein BY, Shlomai Z, Levitzki R, et al. The AG1478 tyrosine kinase inhibitor is an effective suppressor of leiomyoma cell growth. Hum Reprod. Sep. 2004;19(9):1957-67. X-6. [pmid: 15205403].
1506 Shyamkumar NK, Sadhu RD, Nayak S, Kamath S. Soft-tissue case 51. Gossypiboma. Can J Surg. Jun. 2003;46(3):207-228. CASE REPORT. [pmid: 12812246].
1507 Siddiqui NH, Khan SB, Husain AN. Pathologic quiz case: a 76-year-old woman with bilateral pulmonary nodules. Arch Pathol Lab Med. Apr. 2003;127(4):501-2. CASE REPORT. [pmid: 12683887].
1508 Sidhu R, Sood BP, Kalra N, Vajpae K, Joshi K, Gupta NM, et al. Imaging features of esophageal leiomyomatosis: a case report. Clin Imaging. Sep–Oct. 2002;26(5):293-5. CASE REPORT. [pmid: 12213358].
1509 Sieunarine K, Cowie AS, Bartlett JD, Lindsay I, Smith JR. A novel approach in the management of a recurrent adenomatoid tumor of the uterus utilizing a Strassman technique. Int J Gynecol Cancer. Jul–Aug. 2005;15(4):671-5. X-6. [pmid: 16014122].
1510 Signorile PG. Laparoscopic-ultraminilaparotomic myomectomy (LUM)-laparoscopic-ultraminilaparotomic embolized myomectomy (LUEM). Surgical techniques. Clin Exp Obstet Gynecol. 2002;29(4):277-80. X-5. [pmid: 12635745].
1511 Silver MA, Raghuvir R, Fedirko B, Elser D. Systemic hypertension among women with uterine leiomyomata: potential final common pathways of target end-organ remodeling. J Clin Hypertens (Greenwich). Nov. 2005;7(11):664-8. X-6. [pmid: 16278524].
1512 Simsek T, Karakus C, Trak B. Impact of different hormone replacement therapy regimens on the size of myoma uteri in postmenopausal period: tibolone versus transdermal hormonal replacement system. Maturitas. Jul 25. 2002;42(3):243-6. X-4. [pmid: 12161049].
1513 Simsir A, Thorner K, Waisman J, Cangiarella J. Endometriosis in abdominal scars: a report of three cases diagnosed by fine-needle aspiration biopsy. Am Surg. Oct. 2001;67(10):984-6. CASE REPORT. [pmid: 11603558].
1514 Sinawat S, Chiyabutra T, Kleabkaew P. Endometrial abnormalities in postmenopausal breast cancer patients. J Med Assoc Thai. Jun. 2004;87(6):636-40. X-6. [pmid: 15279341].
1515 Sinawat S, Seejorn K. Pseudo-Meigs' syndrome secondary to subserous myoma uteri: a case report. J Med Assoc Thai. Nov. 2002;85(11):1240-3. CASE REPORT. [pmid: 12546324].
1516 Sinclair D, Gaither K, Mason TC. Fertility outcomes following myomectomy in an urban hospital setting. J Natl Med Assoc. Oct. 2005;97(10):1346-8. X-5. [pmid: 16353656]. [pmcid: 2594713].
1517 Singh I, Seth A. Pedunculated prolapsing bladder hematoma (pseudotumor) mimicking an anterior vaginal polyp—a clinical curiosity and rare complication of transurethral resection of bladder tumor. Int Urol Nephrol. 2001;33(3):467-8. CASE REPORT. [pmid: 12230273].
1518 Singla SL, Rattan KN, Kaushik N. Mesenteric leiomyoma in infancy. Indian J Pediatr. Nov. 2000;67(11):857-8. CASE REPORT. [pmid: 11216391].
1519 Sinha R, Hegde A, Warty N, Bhat P, Singhal T. Laparoscopic removal of large multiple myomas with cumulative weight of 2.3 kg. J Am Assoc Gynecol Laparosc. Aug. 2003;10(3):403-6. CASE REPORT. [pmid: 14567823].
1520 Sinha R, Hegde A, Warty N, Mahajan C. Laparoscopic myomectomy: enucleation of the myoma by morcellation while it is attached to the uterus. J Minim Invasive Gynecol. May–Jun. 2005;12(3):284-9. X-4. [pmid: 15922988].
1521 Sinha R, Hegde A, Warty N, Patil N. Laparoscopic excision of very large myomas. J Am Assoc Gynecol Laparosc. Nov. 2003;10(4):461-8. X-5. [pmid: 14738629].
1522 Sinha RY, Hegde A, Warty N, Jain R. Laparoscopic devascularization of uterine myomata followed by enucleation of the myomas by direct morcellation. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):99-102. X-5. [pmid: 15104844].
1523 Sinkre P, Hoang MP, Albores-Saavedra J. Mullerianosis of inguinal lymph nodes: report of a case. Int J Gynecol Pathol. Jan. 2002;21(1):60-4. CASE REPORT. [pmid: 11781525].
1524 Sinkre P, Miller DS, Milchgrub S, Hameed A. Adenomyofibroma of the endometrium with skeletal muscle differentiation. Int J Gynecol Pathol. Jul. 2000;19(3):280-3. CASE REPORT. [pmid: 10907179].
1525 Siskin GP, Stainken BF, Dowling K, Meo P, Ahn J, Dolen EG. Outpatient uterine artery embolization for symptomatic uterine fibroids: experience in 49 patients. J Vasc Interv Radiol. Mar. 2000;11(3):305-11. X-5. [pmid: 10735424].
1526 Siskin GP, Tublin ME, Stainken BF, Dowling K, Dolen EG. Uterine artery embolization for the treatment of adenomyosis: clinical response and evaluation with MR imaging. AJR Am J Roentgenol. Aug. 2001;177(2):297-302. X-6. [pmid: 11461849].
1527 Sit AS, Modugno F, Hill LM, Martin J, Weissfeld JL. Transvaginal ultrasound measurement of endometrial thickness as a biomarker for estrogen exposure. Cancer Epidemiol Biomarkers Prev. Sep. 2004;13(9):1459-65. X-6. [pmid: 15342446].
1528 Skandalakis JE. Musculature of the alimentary tract. World J Surg. Apr. 2000;24(4):391-4. X-6. [pmid: 10706910].
1529 Skinner GN, Louden KA. Non-puerperal uterine inversion associated with an atypical leiomyoma. Aust N Z J Obstet Gynaecol. Feb. 2001;41(1):100-1. CASE REPORT. [pmid: 11284635].
1530 Skubitz KM, Skubitz AP. Differential gene expression in uterine leiomyoma. J Lab Clin Med. May. 2003;141(5):297-308. X-6. [pmid: 12761473].
1531 Skubitz KM, Skubitz AP. Differential gene expression in leiomyosarcoma. Cancer. Sep 1. 2003;98(5):1029-38. X-6. [pmid: 12942572].
1532 Smart OC, Hindley JT, Regan L, Gedroyc WG. Gonadotrophin-releasing hormone and magnetic-resonance-guided ultrasound surgery for uterine leiomyomata. Obstet Gynecol. Jul. 2006;108(1):49-54. X-5. [pmid: 16816055].
1533 Smith AK, Coakley FV, Jackson R, Gordon RL. CT and MRI of retroperitoneal edema associated with large uterine leiomyomas. J Comput Assist Tomogr. May–Jun. 2002;26(3):459-61. CASE REPORT. [pmid: 12016381].
1534 Smith C, Sabet L, Izawa JI. Management of endosalpingiosis of urinary bladder. Urology. Nov. 2004;64(5):1031. CASE REPORT. [pmid: 15533512].
1535 Smith GS, Isaacson JR, Dempsey MB, Falk GL. Laparoscopic excision of esophageal leiomyoma through an anterior esophagotomy. Dis Esophagus. 2001;14(34):278-9. CASE REPORT. [pmid: 11869340].
1536 Smith WJ, Upton E, Shuster EJ, Klein AJ, Schwartz ML. Patient satisfaction and disease specific quality of life after uterine artery embolization. Am J Obstet Gynecol. Jun. 2004;190(6):1697-703. discussion 1703–6. X-5. [pmid: 15284774].
1537 Sobande AA, Eskandar M, Archibong EI, Damole IO. Elective hysterectomy: a clinicopathological review from Abha catchment area of Saudi Arabia. West Afr J Med. Jan–Mar. 2005;24(1):31-5. X-4. [pmid: 15909707].
1538 Song YS, Kang JS, Park MH. Fallopian tube prolapse misdiagnosed as vault granulation tissue: a report of three cases. Pathol Res Pract. 2005;201(12):819-22. CASE REPORT. [pmid: 16308107].
1539 Soon MS, Lin OS. Inflammatory fibroid polyp of the duodenum. Surg Endosc. Jan. 2000;14(1):86. CASE REPORT. [pmid: 10854512].
1540 Sotoudehmanesh R, Ghafoori A, Mikaeli J, Tavangar SM, Moghaddam HM. Esophageal leiomyomatosis diagnosed by endoscopic ultrasound. Endoscopy. Mar. 2005;37(3):281. CASE REPORT. [pmid: 15731952].
1541 Soweid AM. Endosonographic features predictive of benign and malignant gastrointestinal stromal cell tumors. Gastrointest Endosc. Jun. 2001;53(7):836-8. X-6. [pmid: 11414241].
1542 Soysal ME, Soysal SK, Vicdan K. Thermal balloon ablation in myoma-induced menorrhagia under local anesthesia. Gynecol Obstet Invest. 2001;51(2):128-33. X-4. [pmid: 11223708].
1543 Soysal S, Soysal ME. The efficacy of levonorgestrel-releasing intrauterine device in selected cases of myoma-related menorrhagia: a prospective controlled trial. Gynecol Obstet Invest. 2005;59(1):29-35. X-4. [pmid: 15377823].
1544 Sozen I, Senturk LM, Arici A. Effect of gonadotropin-releasing hormone agonists on monocyte chemotactic protein-1 production and macrophage infiltration in leiomyomatous uterus. Fertil Steril. Oct. 2001;76(4):792-6. X-6. [pmid: 11591415].
1545 N. A. Spangler. Using sonohysterography to evaluate uterine bleeding. Jaapa. 2002 Aug;15(8):37–42, 44. X-6
1546 Speert H. Memorable medical mentors: VI. Thomas S. Cullen (1868-1953). Obstet Gynecol Surv. Aug. 2004;59(8):557-63. X-1. [pmid: 15277874].
1547 Spies JB. Uterine artery embolization for fibroids: understanding the technical causes of failure. J Vasc Interv Radiol. Jan. 2003;14(1):11-4. X-1. [pmid: 12525581].
1548 Spies JB. Recovery after uterine artery embolization: understanding and managing short-term outcomes. J Vasc Interv Radiol. Oct. 2003;14(10):1219-22. X-1. [pmid: 14551266].
1549 Spies JB, Allison S, Flick P, Cramp M, Bruno J, Jha RC, et al. Spherical polyvinyl alcohol versus tris-acryl gelatin microspheres for uterine artery embolization for leiomyomas: results of a limited randomized comparative study. J Vasc Interv Radiol. Nov. 2005;16(11):1431-7. X-5. [pmid: 16319148].
1550 Spies JB, Benenati JF, Worthington-Kirsch RL, Pelage JP. Initial experience with use of tris-acryl gelatin microspheres for uterine artery embolization for leiomyomata. J Vasc Interv Radiol. Sep. 2001;12(9):1059-63. X-5. [pmid: 11535768].
1551 Spies JB, Coyne K, Guaou Guaou N, Boyle D, Skyrnarz-Murphy K, Gonzalves SM. The UFS-QOL, a new disease-specific symptom and health-related quality of life questionnaire for leiomyomata. Obstet Gynecol. Feb. 2002;99(2):290-300. X-6. [pmid: 11814511].
1552 Spies JB, Roth AR, Gonsalves SM, Murphy-Skrzyniarz KM. Ovarian function after uterine artery embolization for leiomyomata: assessment with use of serum follicle stimulating hormone assay. J Vasc Interv Radiol. Apr. 2001;12(4):437-42. X-5. [pmid: 11287529].
1553 Spies JB, Sacks D. Credentials for uterine artery embolization. J Vasc Interv Radiol. Feb. 2004;15(2 Pt 1):111-3. X-1. [pmid: 14963175].
1554 Sprague RA, Hayes CS, Advincula AP. Integration of robot-assisted laparoscopy in the minimally invasive management of symptomatic uterine fibroids. Biomed Instrum Technol. 2005;(Suppl):55-60. X-1.
1555 Sreekumar KP, Moorthy S, Prabhu NK, Pillai AK. Intra-arterial contrast-enhanced spiral CT: adjunct to angiography for localizing obscure gastrointestinal bleed. Indian J Gastroenterol. Nov–Dec. 2002;21(6):230-1. CASE REPORT. [pmid: 12546178].
1556 Sriram PV, Rao GV, Reddy DN. Wireless capsule endoscopy: experience in a tropical country. J Gastroenterol Hepatol. Jan. 2004;19(1):63-7. X-6. [pmid: 14675244].
1557 Srisombut C, Weerakiet S. Laparoscopic hysterectomy using laparosonic coagulating shears: experience of 15 cases. J Med Assoc Thai. Aug. 2000;83(8):915-20. X-5. [pmid: 10998846].
1558 M. A. St John, E. G. Maghami, S. Bhuta, R. B. Lufkin and E. Abemayor. Radiology quiz case 1. Vascular leiomyoma of the larynx. Arch Otolaryngol Head Neck Surg. 2002 Nov;128(11):1330, 1332–3. CASE REPORT
1559 Stanko CM, Severson MA 2nd, Molpus KL. Deep venous thrombosis associated with large leiomyomata uteri. A case report. J Reprod Med. Apr. 2001;46(4):405-7. CASE REPORT. [pmid: 11354847].
1560 Stein LA, Valenti D. Soft-tissue case 36. Ischemic necrosis of a large uterine fibroid after embolization. Can J Surg. Dec. 2000;43(6):410-467. CASE REPORT. [pmid: 11129827].
1561 Steiner SJ, Davis MM, Corkins MR. Clinical quiz. Leiomyoma. J Pediatr Gastroenterol Nutr. Oct. 2003;37(4):461-521. CASE REPORT. [pmid: 14582475].
1562 Stephens LC, Katz SG. Phentermine and anaesthesia. Anaesth Intensive Care. Aug. 2005;33(4):525-7. CASE REPORT. [pmid: 16119498].
1563 Stern V. Operations: spinal versus general anaesthetics- a patient's view. Bmj. Dec 23–30. 2000;321(7276):1606-7. X-6. [pmid: 11124198]. [pmcid: 1119274].
1564 Stewart EA, Faur AV, Wise LA, Reilly RJ, Harlow BL. Predictors of subsequent surgery for uterine leiomyomata after abdominal myomectomy. Obstet Gynecol. Mar. 2002;99(3):426-32. X-5. [pmid: 11864669].
1565 Stewart EA, Gedroyc WM, Tempany CM, Quade BJ, Inbar Y, Ehrenstein T, et al. Focused ultrasound treatment of uterine fibroid tumors: safety and feasibility of a noninvasive thermoablative technique. Am J Obstet Gynecol. Jul. 2003;189(1):48-54. X-5. [pmid: 12861137].
1566 Stojsic Z, Bacetic D, Radevic B, Vasiljevic JD. A well-differentiated liposarcoma co-existent with leiomyoma. Vojnosanit Pregl. Sep–Oct. 2004;61(5):565-8. CASE REPORT. [pmid: 15551811].
1567 Stolk MF, de Jong AE, van Ramshorst B, Biemans JM, Blomjous FJ, Timmer R. Intestinal bleeding due to a stromal tumor in a Meckel's diverticulum. Gastrointest Endosc. Jul. 2002;56(1):147-9. CASE REPORT. [pmid: 12085058].
1568 Stone JA, Morrison AL. Piloleiomyoma mistaken for postacne scarring. Cutis. May. 2004;73(5):335-7. CASE REPORT. [pmid: 15186049].
1569 Stotz M, Lampart A, Kochli OR, Schneider M. Intraabdominal bleeding masked by hemodilution after hysteroscopy. Anesthesiology. Aug. 2000;93(2):569-70. CASE REPORT. [pmid: 10910510].
1570 Strang A, Lisson SW, Petrou SP. Ureteral endometriosis and coexistent urethral leiomyoma in a postmenopausal woman. Int Braz J Urol. Nov–Dec. 2004;30(6):496-8. CASE REPORT. [pmid: 15663808].
1571 Stringer NH, DeWhite A, Park J, Ghodsizadeh A, Edwards M, Kumari NV, et al. Laparoscopic myomectomy after failure of uterine artery embolization. J Am Assoc Gynecol Laparosc. Nov. 2001;8(4):583-6. CASE REPORT. [pmid: 11677341].
1572 Stringer NH, Grant T, Park J, Oldham L. Ovarian failure after uterine artery embolization for treatment of myomas. J Am Assoc Gynecol Laparosc. Aug. 2000;7(3):395-400. CASE REPORT. [pmid: 10924636].
1573 Stringer NH, Strassner HT, Lawson L, Oldham L, Estes C, Edwards M, et al. Pregnancy outcomes after laparoscopic myomectomy with ultrasonic energy and laparoscopic suturing of the endometrial cavity. J Am Assoc Gynecol Laparosc. Feb. 2001;8(1):129-36. X-5. [pmid: 11172128].
1574 Strinic T, Kuzmic-Prusac I, Eterovic D, Jakic J, Scukanec M. Leiomyomatosis peritonealis disseminata in a postmenopausal woman. Arch Gynecol Obstet. Sep. 2000;264(2):97-8. CASE REPORT. [pmid: 11045333].
1575 Strinic T, Vulic M, Bukovic D, Maskovic J, Hauptman D, Jelincic Z. Uterine artery embolization for the treatment of uterine fibroids. Coll Antropol. Dec. 2004;28(2):793-7. X-5. [pmid: 15666613].
1576 Strohmer H, Roehlich M, Hafner E, Maier U. Leiomyoma of the vesicovaginal septum. Arch Gynecol Obstet. May. 2001;265(2):94-5. CASE REPORT. [pmid: 11409484].
1577 Stutterecker D, Umek W, Tunn R, Sulzbacher I, Kainz C. Leiomyoma in the space of Retzius: a report of 2 cases. Am J Obstet Gynecol. Jul. 2001;185(1):248-9. CASE REPORT. [pmid: 11483940].
1578 Su WH, Wang PH, Chang SP, Su MC. Preoperational diagnosis of a uterine lipoleiomyoma using ultrasound and computed tomography images: a case report. Eur J Gynaecol Oncol. 2001;22(6):439-40. CASE REPORT. [pmid: 11874076].
1579 Subramanian S, Spies JB. Uterine artery embolization for leiomyomata: resource use and cost estimation. J Vasc Interv Radiol. May. 2001;12(5):571-4. X-5. [pmid: 11340134].
1580 Sugimoto K, Yanagida H, Yagi K, Kuwajima H, Okada M, Takemura T. A Japanese family with Alport syndrome associated with esophageal leiomyomatosis: genetic analysis of COL4A5 to COL4A6 and immunostaining for type IV collagen subtypes. Clin Nephrol. Aug. 2005;64(2):144-50. CASE REPORT. [pmid: 16114791].
1581 Sugimura H, Yamaguchi K, Furukoji E, Tamura S, Sakae T, Koga H, et al. Comparison of conventional fast spin echo, single-shot two-dimensional and three-dimensional half-fourier RARE for T2-weighted female pelvic imaging. J Magn Reson Imaging. Mar. 2004;19(3):349-55. X-6. [pmid: 14994304].
1582 Sugino N, Suzuki T, Kashida S, Karube A, Takiguchi S, Kato H. Expression of Bcl-2 and Bax in the human corpus luteum during the menstrual cycle and in early pregnancy: regulation by human chorionic gonadotropin. J Clin Endocrinol Metab. Nov. 2000;85(11):4379-86. X-6. [pmid: 11095483].
1583 Sugita Y, Shigemori M, Harada H, Wada Y, Hayashi I, Morimastu M, et al. Primary meningeal sarcomas with leiomyoblastic differentiation: a proposal for a new subtype of primary meningeal sarcomas. Am J Surg Pathol. Sep. 2000;24(9):1273-8. X-6. [pmid: 10976702].
1584 Sulaiman S, Khaund A, McMillan N, Moss J, Lumsden MA. Uterine fibroids—do size and location determine menstrual blood loss?. Eur J Obstet Gynecol Reprod Biol. Jul 15. 2004;115(1):85-9. X-5. [pmid: 15223171].
1585 Sule AZ. Traumatic rupture of uterine fibroid: an uncommon cause of post traumatic haemoperitoneum. West Afr J Med. Apr–Jun. 2000;19(2):158-9. CASE REPORT. [pmid: 11070755].
1586 Sultana CJ, Goldberg J, Aizenman L, Chon JK. Vesicouterine fistula after uterine artery embolization: a case report. Am J Obstet Gynecol. Dec. 2002;187(6):1726-7. CASE REPORT. [pmid: 12501095].
1587 Sumathi VP, Al-Hussaini M, Connolly LE, Fullerton L, McCluggage WG. Endometrial stromal neoplasms are immunoreactive with WT-1 antibody. Int J Gynecol Pathol. Jul. 2004;23(3):241-7. X-6. [pmid: 15213600].
1588 Sumi T, Ishiko O, Ueda K, Wakasa K, Ogita S. Magnetic resonance imaging diagnosis of a deep soft tissue leiomyoma under the rectus muscle. Gynecol Obstet Invest. 2002;53(4):231-3. CASE REPORT. [pmid: 12186989].
1589 Sumitani H, Shozu M, Segawa T, Murakami K, Yang HJ, Shimada K, et al. In situ estrogen synthesized by aromatase P450 in uterine leiomyoma cells promotes cell growth probably via an autocrine/intracrine mechanism. Endocrinology. Oct. 2000;141(10):3852-61. X-6. [pmid: 11014242].
1590 Sun S, Jin Y, Chang G, Wang C, Li X, Wang Z. Endoscopic band ligation without electrosurgery: a new technique for excision of small upper-GI leiomyoma. Gastrointest Endosc. Aug. 2004;60(2):218-22. X-6. [pmid: 15278048].
1591 Sun WS, Fujimoto J, Tamaya T. Clinical implications of coexpression of growth arrest-specific gene 6 and receptor tyrosine kinases Axl and Sky in human uterine leiomyoma. Mol Hum Reprod. Nov. 2003;9(11):701-7. X-6. [pmid: 14561812].
1592 Sun Y, Tawfiqul B, Valderrama E, Kline G, Kahn LB. Pulmonary crystal-storing histiocytosis and extranodal marginal zone B-cell lymphoma associated with a fibroleiomyomatous hamartoma. Ann Diagn Pathol. Feb. 2003;7(1):47-53. X-6. [pmid: 12616474].
1593 Suneja A, Taneja A, Guleria K, Yadav P, Agarwal N. Incarcerated procidentia due to cervical fibroid: an unusual presentation. Aust N Z J Obstet Gynaecol. Jun. 2003;43(3):252-3. CASE REPORT. [pmid: 14712998].
1594 Surrey ES, Lietz AK, Schoolcraft WB. Impact of intramural leiomyomata in patients with a normal endometrial cavity on in vitro fertilization-embryo transfer cycle outcome. Fertil Steril. Feb. 2001;75(2):405-10. X-5. [pmid: 11172848].
1595 Sutton CJ. Historical curiosities in the surgical management of myomas. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):4-7. X-1. [pmid: 15104824].
1596 Suzuki M, Takamizawa S, Nomaguchi K, Suzu S, Yamada M, Igarashi T, et al. Erythropoietin synthesis by tumour tissues in a patient with uterine myoma and erythrocytosis. Br J Haematol. Apr. 2001;113(1):49-51. CASE REPORT. [pmid: 11328280].
1597 Suzuki M, Usui N, Furugen Y, Mitsuhasi N. Pyrimidine nucleoside phosphorylase activity in normal tissues of the uterus and ovary and in benign and malignant lesions of these organs. Int J Clin Oncol. Feb. 2001;6(1):19-24. X-6. [pmid: 11706522].
1598 Swartz CD, Afshari CA, Yu L, Hall KE, Dixon D. Estrogen-induced changes in IGF-I, Myb family and MAP kinase pathway genes in human uterine leiomyoma and normal uterine smooth muscle cell lines. Mol Hum Reprod. Jun. 2005;11(6):441-50. X-6. [pmid: 15879465].
1599 Sylvestre C, Child TJ, Tulandi T, Tan SL. A prospective study to evaluate the efficacy of two- and three-dimensional sonohysterography in women with intrauterine lesions. Fertil Steril. May. 2003;79(5):1222-5. X-6. [pmid: 12738522].
1600 Szabo I, Szantho A, Csabay L, Csapo Z, Szirmai K, Papp Z. Color Doppler ultrasonography in the differentiation of uterine sarcomas from uterine leiomyomas. Eur J Gynaecol Oncol. 2002;23(1):29-34. X-6. [pmid: 11876388].
1601 Szlosarek PW, Lofts FJ, Pettengell R, Carter P, Young M, Harmer C. Effective treatment of a patient with a high-grade endometrial stromal sarcoma with an accelerated regimen of carboplatin and paclitaxel. Anticancer Drugs. Apr. 2000;11(4):275-8. CASE REPORT. [pmid: 10898543].
1602 Szumilo J, Kotarska M, Chroscicki A, Korobowicz E. Leiomyoma of the cervical esophagus: a case report. Ann Univ Mariae Curie Sklodowska [Med]. 2003;58(2):22-4. CASE REPORT.
1603 Tagaya N, Kasama K, Suzuki N, Taketsuka S, Horie K, Kubota K. Simultaneous laparoscopic treatment for diseases of the gallbladder, stomach, and colon. Surg Laparosc Endosc Percutan Tech. Jun. 2005;15(3):169-71. CASE REPORT. [pmid: 15956904].
1604 Tagaya N, Kita J, Kogure H, Kubota K. Laparoscopic intragastric resection of gastric leiomyoma using needlescopic instruments. Case report. Surg Endosc. Apr. 2001;15(4):414. CASE REPORT. [pmid: 11409411].
1605 Tai CT, Lin WC, Chang WC, Chiu TH, Chen GT. Classical cadherin and catenin expression in normal myometrial tissues and uterine leiomyomas. Mol Reprod Dev. Feb. 2003;64(2):172-8. X-6. [pmid: 12506349].
1606 Takahashi K, Kawamura N, Ishiko O, Ogita S. Shrinkage effect of gonadotropin releasing hormone agonist treatment on uterine leiomyomas and t(12;14). Int J Oncol. Feb. 2002;20(2):279-83. X-6. [pmid: 11788889].
1607 Takahashi K, Kawamura N, Tsujimura A, Ichimura T, Ito F, Ishiko O, et al. Association of the shrinkage of uterine leiomyoma treated with GnRH agonist and deletion of long arm of chromosome 7. Int J Oncol. Jun. 2001;18(6):1259-63. X-6. [pmid: 11351260].
1608 Takahashi K, Okada M, Imaoka I, Sugimura K, Miyazaki K. Value of magnetic resonance imaging in predicting efficacy of GnRH analogue treatment for uterine leiomyoma. Hum Reprod. Sep. 2001;16(9):1989-94. X-6. [pmid: 11527910].
1609 Takahashi T, Nagai N, Oda H, Ohama K, Kamada N, Miyagawa K. Evidence for RAD51L1/HMGIC fusion in the pathogenesis of uterine leiomyoma. Genes Chromosomes Cancer. Feb. 2001;30(2):196-201. X-6. [pmid: 11135437].
1610 Takamura M, Murakami T, Kurachi H, Kim T, Enomoto T, Narumi Y, et al. MR imaging of mesenteric hemangioma: a case report. Radiat Med. Jan–Feb. 2000;18(1):67-9. CASE REPORT. [pmid: 10852659].
1611 Takebayashi K, Aso Y, Tayama K, Takemura Y, Inukai T. Primary antiphospholipid syndrome associated with acute adrenal failure. Am J Med Sci. Jan. 2003;325(1):41-4. CASE REPORT. [pmid: 12544085].
1612 Takeda A, Manabe S, Hosono S, Nakamura H. Preoperative evaluation of submucosal myoma by virtual hysteroscopy. J Am Assoc Gynecol Laparosc. Aug. 2004;11(3):404-9. X-5. [pmid: 15559356].
1613 Takeda T, Osuga K, Morishige K, Khankan AA, Tasaka K, Murata Y. A case of generalised oedema secondary to uterine artery embolisation for leiomyomata. Bjog. Feb. 2004;111(2):179-80. CASE REPORT. [pmid: 14723759].
1614 Takeda T, Osuga K, Morishige K, Tasaka K, Nakamura H, Murata Y. Changes of plasma vascular endothelial growth factor level after uterine artery embolisation for leiomyomata. Bjog. Oct. 2005;112(10):1437-9. X-6. [pmid: 16167953].
1615 Takeda Y, Satoh M, Nakamura S, Matsumoto D. Congenital leiomyomatous epulis: a case report with immunohistochemical study. Pathol Int. Dec. 2000;50(12):999-1002. CASE REPORT. [pmid: 11123769].
1616 Takeuchi H, Kinoshita K. Evaluation of adhesion formation after laparoscopic myomectomy by systematic second-look microlaparoscopy. J Am Assoc Gynecol Laparosc. Nov. 2002;9(4):442-6. X-5. [pmid: 12386353].
1617 Takeuchi H, Kobori H, Kikuchi I, Sato Y, Mitsuhashi N. A prospective randomized study comparing endocrinological and clinical effects of two types of GnRH agonists in cases of uterine leiomyomas or endometriosis. J Obstet Gynaecol Res. Oct. 2000;26(5):325-31. X-5. [pmid: 11147718].
1618 Takeuchi H, Kuwatsuru R. The indications, surgical techniques, and limitations of laparoscopic myomectomy. Jsls. Apr–Jun. 2003;7(2):89-95. X-5. [pmid: 12856836].
1619 Tallini G, Vanni R, Manfioletti G, Kazmierczak B, Faa G, Pauwels P, et al. HMGI-C and HMGI(Y) immunoreactivity correlates with cytogenetic abnormalities in lipomas, pulmonary chondroid hamartomas, endometrial polyps, and uterine leiomyomas and is compatible with rearrangement of the HMGI-C and HMGI(Y) genes. Lab Invest. Mar. 2000;80(3):359-69. X-6. [pmid: 10744071].
1620 Tamura M, Murata T, Kurumaya H, Ohta Y. Leiomyoma of an accessory tracheal bronchus. Ann Thorac Surg. Dec. 2004;78(6):2163-5. CASE REPORT. [pmid: 15561062].
1621 Tan TL, Rafla N. Retained calcified fibroid fragments after uterine artery embolization for fibroids. Fertil Steril. Apr. 2004;81(4):1145-7. CASE REPORT. [pmid: 15066481].
1622 Tanaka H, Umekawa T, Kikukawa T, Nakamura M, Toyoda N. Venous thromboembolic diseases associated with uterine myomas diagnosed before hysterectomy: a report of two cases. J Obstet Gynaecol Res. Dec. 2002;28(6):300-3. X-5. [pmid: 12512926].
1623 Tanaka R, Sanada S, Suzuki M, Kobayashi T, Matsui T, Inoue H, et al. Breathing chest radiography using a dynamic flat-panel detector combined with computer analysis. Med Phys. Aug. 2004;31(8):2254-62. X-6. [pmid: 15377092].
1624 Tanaka T. Effects of herbal medicines on menopausal symptoms induced by gonadotropin-releasing hormone agonist therapy. Clin Exp Obstet Gynecol. 2001;28(1):20-3. X-6. [pmid: 11332582].
1625 Tanaka YO, Jikuya T, Iijima T, Sakakibara Y, Itai Y. Intravenous leiomyomatosis diagnosed by plain radiographs. Clin Radiol. Nov. 2002;57(11):1037-40. CASE REPORT. [pmid: 12409117].
1626 Tanaka YO, Nishida M, Tsunoda H, Okamoto Y, Yoshikawa H. Smooth muscle tumors of uncertain malignant potential and leiomyosarcomas of the uterus: MR findings. J Magn Reson Imaging. Dec. 2004;20(6):998-1007. X-6. [pmid: 15558559].
1627 Taniguchi F, Harada T, Iwabe T, Yoshida S, Mitsunari M, Terakawa N. Use of the LAP DISK (abdominal wall sealing device) in laparoscopically assisted myomectomy. Fertil Steril. Apr. 2004;81(4):1120-4. X-5. [pmid: 15066473].
1628 Tarim E, Killicadag E, Kayaselcuk F, Bagis T, Yilmaz Z. Submucosal leiomyoma of the uterus incorporated into the fetal membranes and mimicking a placental neoplasm: a case report. Placenta. Jul. 2003;24(6):706-9. CASE REPORT. [pmid: 12828929].
1629 Tasdelen A, Mercan AS, Sezgin A, Karapinar K, Yaveri A, Aslamaci S. Two discrete masses of leiomyomatosis in a patient, one extending to the right atrium. Thorac Cardiovasc Surg. Jun. 2000;48(3):161-3. CASE REPORT. [pmid: 10903064].
1630 Taskin O, Sadik S, Onoglu A, Gokdeniz R, Erturan E, Burak F, et al. Role of endometrial suppression on the frequency of intrauterine adhesions after resectoscopic surgery. J Am Assoc Gynecol Laparosc. Aug. 2000;7(3):351-4. X-4. [pmid: 10924629].
1631 Taylor A, Blackmore S, Tsirkas P, Magos A. Color Doppler evaluation of changes in uterine perfusion induced by the use of an absorbable cervical tourniquet during open myomectomy. J Clin Ultrasound. Oct. 2005;33(8):390-3. X-5. [pmid: 16240429].
1632 Taylor A, Sharma M, Tsirkas P, Arora R, Di Spiezio Sardo A, Mastrogamvrakis G, et al. Surgical and radiological management of uterine fibroids—a UK survey of current consultant practice. Acta Obstet Gynecol Scand. May. 2005;84(5):478-82. X-6. [pmid: 15842213].
1633 Taylor A, Sharma M, Tsirkas P, Di Spiezio Sardo A, Setchell M, Magos A. Reducing blood loss at open myomectomy using triple tourniquets: a randomised controlled trial. Bjog. Mar. 2005;112(3):340-5. X-5. [pmid: 15713151].
1634 Tchelepi H, Daneshmand S, Yanle Z, Ralls PW. Sonography of spermatic cord leiomyoma: case report and review of the literature. J Ultrasound Med. Apr. 2004;23(4):569-71. CASE REPORT. [pmid: 15098879].
1635 Teixeira AB, Etchebehere CS, Carvalho DC, Sousa MC, Santos AO, Lima MC, et al. Tc-99m MDP uptake in uterine leiomyoma. Clin Nucl Med. Jun. 2000;25(6):484. CASE REPORT. [pmid: 10836706].
1636 Tempany CM, Stewart EA, McDannold N, Quade BJ, Jolesz FA, Hynynen K. MR imaging-guided focused ultrasound surgery of uterine leiomyomas: a feasibility study. Radiology. Mar. 2003;226(3):897-905. X-5. [pmid: 12616023].
1637 Testa AC, Pomini F, Fattorossi A, Battaglia A, Ferrandina G, Mansueto D, et al. Doppler velocimetry and cytofluorimetric analysis in uterine myomas. Gynecol Obstet Invest. 2003;56(3):139-42. X-6. [pmid: 14530613].
1638 Theodoridis TD, Zepiridis L, Grimbizis G, Bontis J. Laparoscopic management of broad ligament leiomyoma. J Minim Invasive Gynecol. Nov–Dec. 2005;12(6):469. CASE REPORT. [pmid: 16337571].
1639 Thielen BK, Barker DF, Nelson RD, Zhou J, Kren SM, Segal Y. Deletion mapping in Alport syndrome and Alport syndrome-diffuse leiomyomatosis reveals potential mechanisms of visceral smooth muscle overgrowth. Hum Mutat. Nov. 2003;22(5):419. X-6.
1640 Thienpont E, Geens S, Nelen G. Angioleiomyoma of the knee. A case report. Acta Orthop Belg. Feb. 2002;68(1):76-8. CASE REPORT. [pmid: 11915464].
1641 Thomas LA, Balaratnam N, Richards DG, Duane PD. Diffuse esophageal leiomyomatosis: another cause of pseudoachalasia. Dis Esophagus. 2000;13(2):165-8. CASE REPORT. [pmid: 14601910].
1642 Thorpe-Beeston JG, Sebire NJ. Spontaneous expulsion of submucous fibroid after preterm labour. Bjog. Jun. 2002;109(6):726-7. CASE REPORT. [pmid: 12118657].
1643 Thukkani N, Ravichandran PS, Das A, Slater MS. Leiomyomatosis metastatic to the tricuspid valve complicated by pelvic hemorrhage. Ann Thorac Surg. Feb. 2005;79(2):707-9. CASE REPORT. [pmid: 15680873].
1644 Tietze L, Gunther K, Horbe A, Pawlik C, Klosterhalfen B, Handt S, et al. Benign metastasizing leiomyoma: a cytogenetically balanced but clonal disease. Hum Pathol. Jan. 2000;31(1):126-8. X-6. [pmid: 10665925].
1645 Toh CH, Wu CH, Tsay PK, Yeow KM, Pan KT, Tseng JH, et al. Uterine artery embolization for symptomatic uterine leiomyoma and adenomyosis. J Formos Med Assoc. Oct. 2003;102(10):701-6. X-5. [pmid: 14691595].
1646 Tomlinson IP, Alam NA, Rowan AJ, Barclay E, Jaeger EE, Kelsell D, et al. Germline mutations in FH predispose to dominantly inherited uterine fibroids, skin leiomyomata and papillary renal cell cancer. Nat Genet. Apr. 2002;30(4):406-10. X-6. [pmid: 11865300].
1647 Tong GX, Hernandez O, Yee HT, Zheng SH, Yang GC. Human T-lymphotropic virus type-1 related adult T-cell leukemia/lymphoma presenting as a parotid mass diagnosed by fine-needle aspiration biopsy. Diagn Cytopathol. Nov. 2004;31(5):333-7. CASE REPORT. [pmid: 15468115].
1648 Topfer LA, Hailey D. Uterine artery embolization for the treatment of fibroids. Issues Emerg Health Technol. Aug. 2002;(36):1-6. X-1.
1649 Topolovec Z, Mrcela M, Milojkovic M, Sijanovic S, Topolovec J, Curzik D, et al. Pleomorphic vulvar leiomyoma with local invasive behavior. Coll Antropol. Dec. 2002;26(2):571-5. CASE REPORT. [pmid: 12528283].
1650 Torigian DA, Siegelman ES, Terhune KP, Butts SF, Blasco L, Shlansky-Goldberg RD. MRI of uterine necrosis after uterine artery embolization for treatment of uterine leiomyomata. AJR Am J Roentgenol. Feb. 2005;184(2):555-9. CASE REPORT. [pmid: 15671379].
1651 Toro JR, Nickerson ML, Wei MH, Warren MB, Glenn GM, Turner ML, et al. Mutations in the fumarate hydratase gene cause hereditary leiomyomatosis and renal cell cancer in families in North America. Am J Hum Genet. Jul. 2003;73(1):95-106. X-6. [pmid: 12772087]. [pmcid: 1180594].
1652 Torreggiani W, Zwirewich C, Lyburn I, Harris A, Davis JE, Wilkie D, et al. Translabial sonography of vaginal fibroids: report of 2 cases and review of the literature. J Ultrasound Med. Aug. 2001;20(8):909-13. X-5. [pmid: 11503927].
1653 Toscani GK, Chaves EM, Cervi FL, Tavares MB, Silva IS, von Eye Corleta H, et al. Gene expression and tyrosine kinase activity of insulin receptor in uterine leiomyoma and matched myometrium. Arch Gynecol Obstet. Nov. 2004;270(3):170-3. X-6. [pmid: 12937923].
1654 Toyoshima M, Akahira J, Moriya T, Hayakawa S, Yaegashi N. Primary vaginal adenosarcoma with sarcomatous overgrowth. Gynecol Oncol. Dec. 2004;95(3):759-61. CASE REPORT. [pmid: 15582000].
1655 Trampe BS, Pryde PG, Stewart KS, Droste S, Zieher S, Kay HH. Color Doppler ultrasonography for distinguishing myomas from uterine contractions in pregnancy. J Reprod Med. Sep. 2001;46(9):791-4. X-6. [pmid: 11584478].
1656 Tranquart F, Brunereau L, Cottier JP, Marret H, Gallas S, Lebrun JL, et al. Prospective sonographic assessment of uterine artery embolization for the treatment of fibroids. Ultrasound Obstet Gynecol. Jan. 2002;19(1):81-7. X-5. [pmid: 11851974].
1657 Traynor L, Levy E, Choi JJ, Cleary K, Zeng J, Lindisch D. Software development for registration of digital subtraction angiography (DSA) images in uterine fibroid embolization. Stud Health Technol Inform. 2000;70:350-5. X-6. [pmid: 10977570].
1658 Tricarico A, Cione G, Sozio M, Di Palo P, Bottino V, Martino A, et al. Digestive hemorrhages of obscure origin. Surg Endosc. Apr. 2002;16(4):711-3. X-6. [pmid: 11972222].
1659 Tringali S, Tiffet O, Berger JL, Cuilleret J. Bronchial artery aneurysm disguised as a leiomyoma of the esophagus. Ann Thorac Surg. Feb. 2002;73(2):632-3. CASE REPORT. [pmid: 11845886].
1660 Tripathi R, Sharma B, Chaturvedi KU, Khurana N, Mala YM. Granulocytic sarcoma of the female genital tract: report of a case with an unusual presentation. Gynecol Obstet Invest. 2005;59(4):189-91. CASE REPORT. [pmid: 15920828].
1661 Tropeano G, Di Stasi C, Litwicka K, Romano D, Draisci G, Mancuso S. Uterine artery embolization for fibroids does not have adverse effects on ovarian reserve in regularly cycling women younger than 40 years. Fertil Steril. Apr. 2004;81(4):1055-61. X-5. [pmid: 15066463].
1662 Tropeano G, Litwicka K, Di Stasi C, Romano D, Mancuso S. Permanent amenorrhea associated with endometrial atrophy after uterine artery embolization for symptomatic uterine fibroids. Fertil Steril. Jan. 2003;79(1):132-5. CASE REPORT. [pmid: 12524076].
1663 Tsai EM, Chen HS, Long CY, Yang CH, Hsu SC, Wu CH, et al. Laparoscopically assisted vaginal hysterectomy versus total abdominal hysterectomy: a study of 100 cases on light-endorsed transvaginal section. Gynecol Obstet Invest. 2003;55(2):105-9. X-4. [pmid: 12771457].
1664 Tsai HJ, Tsou MY, Ho CM, Tsai SK. Epidural analgesia associated with a fatal outcome in a patient with an unrecognized brain tumour. Anaesth Intensive Care. Dec. 2004;32(6):832-4. CASE REPORT. [pmid: 15648998].
1665 Tsai SJ, Lin SJ, Cheng YM, Chen HM, Wing LY. Expression and functional analysis of pituitary tumor transforming gene-1 [corrected] in uterine leiomyomas. J Clin Endocrinol Metab. Jun. 2005;90(6):3715-23. X-6. [pmid: 15769981].
1666 Tsai TL, Changchien CS, Hu TH, Hsiaw CM, Hsieh KC. Differentiation of benign and malignant gastric stromal tumors using endoscopic ultrasonography. Chang Gung Med J. Mar. 2001;24(3):167-73. X-6. [pmid: 11355084].
1667 Tseng LJ, Jao YT, Mo LR. Leiomyoma of the major papilla. Gastrointest Endosc. May. 2003;57(6):717-8. CASE REPORT. [pmid: 12709703].
1668 Tsibris JC, Maas S, Segars JH, Nicosia SV, Enkemann SA, O'Brien WF, et al. New potential regulators of uterine leiomyomata from DNA arrays: the ionotropic glutamate receptor GluR2. Biochem Biophys Res Commun. Dec 5. 2003;312(1):249-54. X-6. [pmid: 14630051].
1669 Tsibris JC, Segars J, Coppola D, Mane S, Wilbanks GD, O'Brien WF, et al. Insights from gene arrays on the development and growth regulation of uterine leiomyomata. Fertil Steril. Jul. 2002;78(1):114-21. X-6. [pmid: 12095500].
1670 Tsibris JC, Segars J, Enkemann S, Coppola D, Wilbanks GD, O'Brien WF, et al. New and old regulators of uterine leiomyoma growth from screening with DNA arrays. Fertil Steril. Aug. 2003;80(2):279-81. X-6. [pmid: 12909486].
1671 Tsin DA. Culdolaparoscopy: a preliminary report. Jsls. Jan–Mar. 2001;5(1):69-71. X-5. [pmid: 11303998].
1672 Tsin DA, Waters TK, Granato RC. Laparoscopic myomectomy in a patient with Mayer-Rokitansky-Kuster-Hauser syndrome. J Am Assoc Gynecol Laparosc. Aug. 2000;7(3):411-3. CASE REPORT. [pmid: 10924639].
1673 Tsoitis G, Kanitakis J, Papadimitriou C, Hatzibougias Y, Asvesti K, Happle R. Cutaneous leiomyomatosis with type 2 segmental involvement. J Dermatol. May. 2001;28(5):251-5. CASE REPORT. [pmid: 11436362].
1674 Tsujimura A, Kawamura N, Ichimura T, Honda K, Ishiko O, Ogita S. Telomerase activity in needle biopsied uterine myoma-like tumors: differential diagnosis between uterine sarcomas and leiomyomas. Int J Oncol. Feb. 2002;20(2):361-5. X-6. [pmid: 11788902].
1675 Tsujino T, Ohara N, Yoshida S, Kennedy S, Takemura N, Deguchi M, et al. The CYP17 MspA1 polymorphism is not associated with an increased risk of uterine leiomyomas in a Japanese population. Gynecol Endocrinol. Feb. 2006;22(2):87-91. X-6. [pmid: 16603433].
1676 Tueche SG, Trono M, Guiramand J, Cesari J. A bizarre giant leiomyoma. Ann Med Interne (Paris). Mar. 2001;152(2):137-8. CASE REPORT. [pmid: 11357051].
1677 Tulandi T, Sammour A, Valenti D, Stein L. Images in endoscopy: uterine artery embolization and utero-ovarian collateral. J Am Assoc Gynecol Laparosc. Nov. 2001;8(4):474. X-6. [pmid: 11677322].
1678 Tuncay YA, Ozturk D, Tok B, Demirdoven G, Omurcan C. Intestinal leiomyoma presenting as a pelvic mass: two case reports. Aust N Z J Obstet Gynaecol. Aug. 2003;43(4):331-3. CASE REPORT. [pmid: 14714724].
1679 Turner CR, Russell KY, Dorje P. Variable systolic pressure variation and dynamic hyperinflation due to an intrabronchial tumor. J Clin Anesth. Nov. 2004;16(7):533-6. CASE REPORT. [pmid: 15590258].
1680 Tyreus PD, Nau WH, Diederich CJ. Effect of applicator diameter on lesion size from high temperature interstitial ultrasound thermal therapy. Med Phys. Jul. 2003;30(7):1855-63. X-6. [pmid: 12906204].
1681 Tzafettas JM. Current and potential application of GnRH agonists in gynecologic practice. Ann N Y Acad Sci. 2000;900:435-43. X-1. [pmid: 10818434].
1682 Uchikoshi F, Ito T, Nishida T, Kitagawa T, Endo S, Matsuda H. Laparoscopic intragastric resection of gastric stromal tumor located at the esophago-cardiac junction. Surg Laparosc Endosc Percutan Tech. Feb. 2004;14(1):1-4. X-6. [pmid: 15259576].
1683 Udawat H, Nuwal P, Solanki RL. Leiomyoma of urinary bladder—a case report. Indian J Pathol Microbiol. Jul. 2001;44(3):347-8. CASE REPORT. [pmid: 12024931].
1684 Ueda M, Otsuka M, Hatakenaka M, Torii Y. Uterine endometrial stromal sarcoma located in uterine myometrium: MRI appearance. Eur Radiol. 2000;10(5):780-2. CASE REPORT. [pmid: 10823633].
1685 Ulaner GA, Hu JF, Vu TH, Oruganti H, Giudice LC, Hoffman AR. Regulation of telomerase by alternate splicing of human telomerase reverse transcriptase (hTERT) in normal and neoplastic ovary, endometrium and myometrium. Int J Cancer. Feb 1. 2000;85(3):330-5. X-6. [pmid: 10652422].
1686 Uma R, Olah KS. Transvaginal caesarean hysterectomy: an unusual complication of a fibroid gravid uterus. Bjog. Oct. 2002;109(10):1192-4. CASE REPORT. [pmid: 12387479].
1687 Uner A, Tiras MB, Kilic D, Dursun A, Dilek U. Uterine lipoleiomyoma containing metastatic breast carcinoma: a case with two unusual pathologies. Eur J Obstet Gynecol Reprod Biol. Jan 10. 2003;106(1):76-8. CASE REPORT. [pmid: 12475587].
1688 Usta IM, Hobeika EM, Nassar AH. A tale of 2 pedunculated myomas. Am J Obstet Gynecol. Nov. 2005;193(5):1753-5. CASE REPORT. [pmid: 16260224].
1689 Usubutun A, Karaman N, Ayhan A, Kucukali T. Atypical endometrial stromal cells related with a polypoid leiomyoma with bizarre nuclei: a case report. Int J Gynecol Pathol. Oct. 2005;24(4):352-4. CASE REPORT. [pmid: 16175081].
1690 Val-Bernal JF, Pinto J, Garijo MF, Gomez MS. Pagetoid dyskeratosis of the cervix: an incidental histologic finding in uterine prolapse. Am J Surg Pathol. Nov. 2000;24(11):1518-23. X-6. [pmid: 11075853].
1691 Valenzano MM, Lijoi D, Mistrangelo E, Fortunato T, Costantini S, Ragni N. The value of sonohysterography in detecting intracavitary benign abnormalities. Arch Gynecol Obstet. Oct. 2005;272(4):265-8. X-6. [pmid: 16001198].
1692 Valverde K, Henderson M, Smith CR, Tallett S, Chan HS. Typical and atypical Carney's triad presenting with malignant hypertension and papilledema. J Pediatr Hematol Oncol. Nov. 2001;23(8):519-24. X-6. [pmid: 11878780].
1693 van de Ven J, Donker TH, Blankenstein MA, Thijssen JH. Differential effect of gonadotropin-releasing hormone analogue treatment on estrogen levels and sulfatase activity in uterine leiomyoma and myometrium. Fertil Steril. Jun. 2002;77(6):1227-32. X-6. [pmid: 12057733].
1694 van de Ven J, Sprong M, Donker GH, Thijssen JH, Mak-Kregar S, Blankenstein MA. Levels of estrogen and progesterone receptors in the myometrium and leiomyoma tissue after suppression of estrogens with gonadotropin releasing hormone analogs. Gynecol Endocrinol. Dec. 2001;15(Suppl 6):61-8. X-6. [pmid: 12227888].
1695 van den Broek PP, de Faber JT, Kliffen M, Paridaens D. Anterior orbital leiomyoma: possible pulley smooth muscle tissue tumor. Arch Ophthalmol. Nov. 2005;123(11):1614. CASE REPORT. [pmid: 16286632].
1696 van der Peet DL, Berends FJ, Klinkenberg-Knol EC, Cuesta MA. Endoscopic treatment of benign esophageal tumors: case report of three patients. Surg Endosc. Dec. 2001;15(12):1489. CASE REPORT.
1697 van Dillen J, van der Honing A. Primary amenorrhoea: three cases from a semi-rural Namibian hospital. Trop Doct. Jul. 2005;35(3):186-8. CASE REPORT. [pmid: 16105357].
1698 van Rijn AB, van Kralingen KW, Koelma IA. Angioleiomyoma of the diaphragm. Ann Thorac Surg. Jun. 2000;69(6):1928-9. CASE REPORT. [pmid: 10892949].
1699 Van Voorhis BJ, Romitti PA, Jones MP. Family history as a risk factor for development of uterine leiomyomas. Results of a pilot study. J Reprod Med. Aug. 2002;47(8):663-9. X-6. [pmid: 12216434].
1700 VanderBrink BA, Munver R, Tash JA, Sosa RE. Renal angiomyolipoma with contrast-enhancing elements mimicking renal malignancy: radiographic and pathologic evaluation. Urology. Mar. 2004;63(3):584-6. CASE REPORT.
1701 Vang R, Medeiros LJ, Samoszuk M, Deavers MT. Uterine leiomyomas with Eosinophils: a clinicopathologic study of 3 cases. Int J Gynecol Pathol. Jul. 2001;20(3):239-43. X-5. [pmid: 11444199].
1702 Vanharanta S, Wortham NC, Laiho P, Sjoberg J, Aittomaki K, Arola J, et al. 7q deletion mapping and expression profiling in uterine fibroids. Oncogene. Sep 29. 2005;24(43):6545-54. X-6. [pmid: 15940248].
1703 Varner RE, Ireland CC, Summitt RL Jr, Richter HE, Learman LA, Vittinghoff E, et al. Medicine or Surgery (Ms): a randomized clinical trial comparing hysterectomy and medical treatment in premenopausal women with abnormal uterine bleeding. Control Clin Trials. Feb. 2004;25(1):104-18. X-6. [pmid: 14980755].
1704 Varol N, Healey M, Tang P, Sheehan P, Maher P, Hill D. Ten-year review of hysterectomy morbidity and mortality: can we change direction?. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):295-302. X-6. [pmid: 11592544].
1705 Varras M, Antoniou S, Samara C, Frakala S, Angelidou-Manika Z, Paissios P. Intraperitoneal haemorrhage secondary to perforation of uterine fibroid after cystic degeneration. Unusual CT findings resembling malignant pelvic tumor: case report. Eur J Gynaecol Oncol. 2002;23(6):565-8. CASE REPORT. [pmid: 12556108].
1706 Vashisht A, Studd JW, Carey AH, McCall J, Burn PR, Healy JC, et al. Fibroid embolisation: a technique not without significant complications. Bjog. Sep. 2000;107(9):1166-70. X-5. [pmid: 11002964].
1707 Venkatachalam S, Bagratee JS, Moodley J. Medical management of uterine fibroids with medroxyprogesterone acetate (Depo Provera): a pilot study. J Obstet Gynaecol. Oct. 2004;24(7):798-800. X-5. [pmid: 15763792].
1708 Vereczkei A, Illenyi L, Arany A, Szabo Z, Toth L, Horvath OP. Transvaginal extraction of the laparoscopically removed spleen. Surg Endosc. Jan. 2003;17(1):157. X-6. [pmid: 12399871].
1709 Verhulst D, Vanwyck R, Wouters K. Stromal tumor of the small intestine. Jbr-Btr. May–Jun. 2004;87(3):162-3. X-6. [pmid: 15293693].
1710 Vetter S, Schultz FW, Strecker EP, Zoetelief J. Patient radiation exposure in uterine artery embolization of leiomyomata: calculation of organ doses and effective dose. Eur Radiol. May. 2004;14(5):842-8. X-6. [pmid: 14551727].
1711 Vicente LF, Maia AP, Carvalho MJ, Sa e Melo P, Magalhaes C, Torrezao I, et al. A benign leiomyoma causing paraparesis: a case report and histopathogenesis. Acta Obstet Gynecol Scand. Jul. 2005;84(7):704-6. CASE REPORT. [pmid: 15954885].
1712 Vigano P, Bonacina P, Strada GR. Leiomyoma of the seminal vesicles. Arch Ital Urol Androl. Dec. 2003;75(4):230-1. CASE REPORT. [pmid: 15005501].
1713 Vijayaraghavan R, Sujatha Y, Santosh KV, Belagavi CS. Inflammatory fibroid polyp of jejunum causing jejuno-jejunal intussusception. Indian J Gastroenterol. Sep–Oct. 2004;23(5):190-2. CASE REPORT. [pmid: 15599009].
1714 Vilos GA, Vilos EC, Romano W, Abu-Rafea B. Temporary uterine artery occlusion for treatment of menorrhagia and uterine fibroids using an incisionless Doppler-guided transvaginal clamp: case report. Hum Reprod. Jan. 2006;21(1):269-71. CASE REPORT. [pmid: 16155072].
1715 Virdis A, Ghiadoni L, Pinto S, Lombardo M, Petraglia F, Gennazzani A, et al. Mechanisms responsible for endothelial dysfunction associated with acute estrogen deprivation in normotensive women. Circulation. May 16. 2000;101(19):2258-63. X-6. [pmid: 10811592].
1716 Visvanathan D, Connell R, Hall-Craggs MA, Cutner AS, Bown SG. Interstitial laser photocoagulation for uterine myomas. Am J Obstet Gynecol. Aug. 2002;187(2):382-4. X-5. [pmid: 12193929].
1717 Vlahos NF. Hysteroscopic resection of a large submucosal fibroid using intermittent bimanual uterine massage and a bipolar resectoscope: a case report. J Reprod Med. Jul. 2005;50(7):543-6. CASE REPORT. [pmid: 16130854].
1718 Voeller DM, Parr A, Allegra CJ. Development of human anti-thymidine kinase antibodies. Anticancer Drugs. Jul. 2001;12(6):555-9. X-6. [pmid: 11460003].
1719 Vott S, Bonilla SM, Goodwin SC, Chen G, Wong GC, Lai A, et al. CT findings after uterine artery embolization. J Comput Assist Tomogr. Nov–Dec. 2000;24(6):846-8. X-5. [pmid: 11105698].
1720 Vrtik M, Larbalestier RI, Cameron D, Gupta A, Sinniah R. Giant superior mediastinal angioleiomyoma. J Thorac Cardiovasc Surg. Nov. 2004;128(5):786-8. X-6. [pmid: 15514620].
1721 Wahab M, Thompson J, Al-Azzawim F. The effect of submucous fibroids on the dose-dependent modulation of uterine bleeding by trimegestone in postmenopausal women treated with hormone replacement therapy. Bjog. Mar. 2000;107(3):329-34. X-6. [pmid: 10740328].
1722 Wakiyama H, Sugimoto T, Ataka K, Yamashita C, Tsuji Y, Nakagiri K, et al. Intravenous leiomyomatosis extending into the right ventricular cavity: one-stage radical operation using cardiopulmonary bypass—a case report. Angiology. Jun. 2000;51(6):505-9. CASE REPORT. [pmid: 10870860].
1723 Walker CL, Burroughs KD, Davis B, Sowell K, Everitt JI, Fuchs-Young R. Preclinical evidence for therapeutic efficacy of selective estrogen receptor modulators for uterine leiomyoma. J Soc Gynecol Investig. Jul–Aug. 2000;7(4):249-56. X-6.
1724 Walker WJ, Carpenter TT, Kent AS. Persistent vaginal discharge after uterine artery embolization for fibroid tumors: cause of the condition, magnetic resonance imaging appearance, and surgical treatment. Am J Obstet Gynecol. May. 2004;190(5):1230-3. X-5. [pmid: 15167823].
1725 Wallace MB, Hoffman BJ, Sahai AS, Inoue H, Van Velse A, Hawes RH. Imaging of esophageal tumors with a water-filled condom and a catheter US probe. Gastrointest Endosc. May. 2000;51(5):597-600. X-6. [pmid: 10805852].
1726 Walocha JA, Litwin JA, Miodonski AJ. Vascular system of intramural leiomyomata revealed by corrosion casting and scanning electron microscopy. Hum Reprod. May. 2003;18(5):1088-93. X-6. [pmid: 12721189].
1727 Walocha JA, Miodonski AJ, Szczepanski W, Skrzat J, Stachura J. Two types of vascularisation of intramural uterine leiomyomata revealed by corrosion casting and immunohistochemical study. Folia Morphol (Warsz). Feb. 2004;63(1):37-41. X-6. [pmid: 15039897].
1728 Walocha JA, Szczepanski W, Miodonski AJ, Gorczyca J, Skrzat J, Bereza T, et al. Application of acrylic emulsion Liquitex R (Binney and Smith) for the preparation of injection specimens and immunohistochemical studies—an observation. Folia Morphol (Warsz). May. 2003;62(2):157-61. X-6. [pmid: 12866677].
1729 Walsh RM, Heniford BT. Laparoendoscopic treatment of gastric stromal tumors. Semin Laparosc Surg. Sep. 2001;8(3):189-94. X-6. [pmid: 11588769].
1730 Wang CJ, Yen CF, Lee CL, Soong YK. Laparoscopic-assisted vaginal myomectomy. J Am Assoc Gynecol Laparosc. Nov. 2000;7(4):510-4. X-5. [pmid: 11044502].
1731 Wang CJ, Yen CF, Lee CL, Soong YK. Laparoscopic uterine artery ligation for treatment of symptomatic adenomyosis. J Am Assoc Gynecol Laparosc. Aug. 2002;9(3):293-6. X-6. [pmid: 12101325].
1732 Wang CJ, Yuen LT, Yen CF, Lee CL, Soong YK. A simplified method to decrease operative blood loss in laparoscopic-assisted vaginal hysterectomy for the large uterus. J Am Assoc Gynecol Laparosc. Aug. 2004;11(3):370-3. X-4. [pmid: 15559351].
1733 Wang CP, Chang YL, Sheen TS. Vascular leiomyoma of the head and neck. Laryngoscope. Apr. 2004;114(4):661-5. X-6. [pmid: 15064620].
1734 Wang H, Mahadevappa M, Yamamoto K, Wen Y, Chen B, Warrington JA, et al. Distinctive proliferative phase differences in gene expression in human myometrium and leiomyomata. Fertil Steril. Aug. 2003;80(2):266-76. X-6. [pmid: 12909484].
1735 Wang H, Wu X, Englund K, Masironi B, Eriksson H, Sahlin L. Different expression of estrogen receptors alpha and beta in human myometrium and leiomyoma during the proliferative phase of the menstrual cycle and after GnRHa treatment. Gynecol Endocrinol. Dec. 2001;15(6):443-52. X-6. [pmid: 11826769].
1736 Wang J, Ohara N, Takekida S, Xu Q, Maruo T. Comparative effects of heparin-binding epidermal growth factor-like growth factor on the growth of cultured human uterine leiomyoma cells and myometrial cells. Hum Reprod. Jun. 2005;20(6):1456-65. X-6. [pmid: 15760954].
1737 Wang J, Sheng W, Tu X, Shi D, Zhu X, Zhang R. Clinicopathologic analysis of angiomyofibroblastoma of the female genital tract. Chin Med J (Engl). Nov. 2000;113(11):1036-9. X-6. [pmid: 11776120].
1738 Wang J, Zhang G, Shi H, Feng Y, Wang W, Wang Y, et al. Dextran uterine artery embolization to treat fibroids. Chin Med J (Engl). Aug. 2002;115(8):1132-6. X-5. [pmid: 12215276].
1739 Wang KC, Lee WL, Yuan CC, Wang PH. Major hemorrhage in a patient with multiple submucous leiomyomata during the treatment of long-acting gonadotropin-releasing hormone agonist. Kaohsiung J Med Sci. Feb. 2000;16(2):103-7. CASE REPORT. [pmid: 10816995].
1740 Wang L, Vargas H, French SW. Cellular origin of gastrointestinal stromal tumors: a study of 27 cases. Arch Pathol Lab Med. Oct. 2000;124(10):1471-5. X-6. [pmid: 11035578].
1741 Wang MC, Shiao AS. Auricle angioleiomyoma. Zhonghua Yi Xue Za Zhi (Taipei). Apr. 2002;65(4):180-2. CASE REPORT. [pmid: 12135197].
1742 Wang MH, Wu CT, Hung CC, Liang JD, Chen PJ. Hepatic leiomyomatous neoplasm associated with Epstein Barr virus infection in an adult with acquired immunodeficiency syndrome. J Formos Med Assoc. Nov. 2000;99(11):873-5. CASE REPORT. [pmid: 11155782].
1743 Wang PH, Lee WL, Yuan CC, Chao HT, Liu WM, Yu KJ, et al. Major complications of operative and diagnostic laparoscopy for gynecologic disease. J Am Assoc Gynecol Laparosc. Feb. 2001;8(1):68-73. X-6. [pmid: 11172117].
1744 Wang S, Su Q, Zhu S, Liu J, Hu L, Li D. Clonality of multiple uterine leiomyomas. Zhonghua Bing Li Xue Za Zhi. Apr. 2002;31(2):107-11. X-6. [pmid: 12419154].
1745 Wang W, Check JH. Effect of corporal fibroids on outcome following embryo transfer in donor-oocyte recipients. Clin Exp Obstet Gynecol. 2004;31(4):263-4. X-5. [pmid: 15672960].
1746 Wang W, Check JH, Dietterich C, Lurie D. Effect of fibroids on cumulative probability of pregnancy in women taking follicle maturing drugs without assisted reproductive technology. Clin Exp Obstet Gynecol. 2001;28(2):86-8. X-6. [pmid: 11491381].
1747 Wang Y, Matsuo H, Kurachi O, Maruo T. Down-regulation of proliferation and up-regulation of apoptosis by gonadotropin-releasing hormone agonist in cultured uterine leiomyoma cells. Eur J Endocrinol. Mar. 2002;146(3):447-56. X-6. [pmid: 11888853].
1748 Wang Y, Zhang R, Ouyang Z, Zhang D, Wang L. Diagnosis and surgical treatment of esophageal leiomyoma. Zhonghua Zhong Liu Za Zhi. Jul. 2002;24(4):394-6. X-6. [pmid: 12408774].
1749 Watabe B, Jayaraman M, Ramos D. Images in medicine. A torsed uterine fibroid presenting as a radiologic challenge. Med Health R I. Jan. 2003;86(1):21. CASE REPORT. [pmid: 12633017].
1750 Watanabe K, Ogura G, Suzuki T. Leiomyoblastoma of the uterus: an immunohistochemical and electron microscopic study of distinctive tumours with immature smooth muscle cell differentiation mimicking fetal uterine myocytes. Histopathology. Apr. 2003;42(4):379-86. X-6. [pmid: 12653950].
1751 Wattiez A, Soriano D, Cohen SB, Nervo P, Canis M, Botchorishvili R, et al. The learning curve of total laparoscopic hysterectomy: comparative analysis of 1647 cases. J Am Assoc Gynecol Laparosc. Aug. 2002;9(3):339-45. X-6. [pmid: 12101332].
1752 Weaver F, Hynes D, Goldberg JM, Khuri S, Daley J, Henderson W. Hysterectomy in Veterans Affairs Medical Centers. Obstet Gynecol. Jun. 2001;97(6):880-4. X-6. [pmid: 11384689].
1753 Weeks AD, Duffy SR, Walker JJ. A double-blind randomised trial of leuprorelin acetate prior to hysterectomy for dysfunctional uterine bleeding. Bjog. Mar. 2000;107(3):323-8. X-6. [pmid: 10740327].
1754 Wegienka G, Baird DD, Hertz-Picciotto I, Harlow SD, Steege JF, Hill MC, et al. Self-reported heavy bleeding associated with uterine leiomyomata. Obstet Gynecol. Mar. 2003;101(3):431-7. X-6. [pmid: 12636944].
1755 Wei EX, Albores-Saavedra J, Fowler MR. Plexiform neurofibroma of the uterine cervix: a case report and review of the literature. Arch Pathol Lab Med. Jun. 2005;129(6):783-6. CASE REPORT. [pmid: 15913429].
1756 Wei J, Chiriboga L, Mizuguchi M, Yee H, Mittal K. Expression profile of tuberin and some potential tumorigenic factors in 60 patients with uterine leiomyomata. Mod Pathol. Feb. 2005;18(2):179-88. X-6. [pmid: 15467714].
1757 Wei JJ, Chiriboga L, Arslan AA, Melamed J, Yee H, Mittal K. Ethnic differences in expression of the dysregulated proteins in uterine leiomyomata. Hum Reprod. Jan. 2006;21(1):57-67. X-6. [pmid: 16172143].
1758 Wei JJ, Chiriboga L, Mittal K. Expression profile of the tumorigenic factors associated with tumor size and sex steroid hormone status in uterine leiomyomata. Fertil Steril. Aug. 2005;84(2):474-84. X-6. [pmid: 16084893].
1759 Wei JJ, Zhang XM, Chiriboga L, Yee H, Perle MA, Mittal K. Spatial differences in biologic activity of large uterine leiomyomata. Fertil Steril. Jan. 2006;85(1):179-87. X-6. [pmid: 16412751].
1760 Weichert W, Denkert C, Gauruder-Burmester A, Kurzeja R, Hamm B, Dietel M, et al. Uterine arterial embolization with tris-acryl gelatin microspheres: a histopathologic evaluation. Am J Surg Pathol. Jul. 2005;29(7):955-61. X-5. [pmid: 15958862].
1761 Weinrach DM, Wang KL, Keh P, Sambasiva Rao M. Pathologic quiz case: a 40-year-old woman with a large pelvic mass, ascites, massive right hydrothorax, and elevated CA 125. Uterine symplastic leiomyoma associated with pseudo-Meigs syndrome and elevated CA 125. Arch Pathol Lab Med. Aug. 2004;128(8):933-4. CASE REPORT. [pmid: 15270600].
1762 Weintraub JL, Romano WJ, Kirsch MJ, Sampaleanu DM, Madrazo BL. Uterine artery embolization: sonographic imaging findings. J Ultrasound Med. Jun. 2002;21(6):633-7. quiz 639–40. X-6. [pmid: 12054299].
1763 Weissman AM, Hartz AJ, Hansen MD, Johnson SR. The natural history of primary dysmenorrhoea: a longitudinal study. Bjog. Apr. 2004;111(4):345-52. X-6. [pmid: 15008771].
1764 West S, Ruiz R, Parker WH. Abdominal myomectomy in women with very large uterine size. Fertil Steril. Jan. 2006;85(1):36-9. X-5. [pmid: 16412723].
1765 Westfall AC, Mansoor A, Sullivan SA, Wilson DJ, Dailey RA. Orbital and periorbital myofibromas in childhood: two case reports. Ophthalmology. Oct. 2003;110(10):2000-5. CASE REPORT. [pmid: 14522779].
1766 Westhof G, Bader W, Greiner-Mai E, Hatzmann W. Comparison of cytosolic p53 protein levels in the female genital tract and breast, and their tumors. Tumour Biol. May–Jun. 2000;21(3):123-34. X-6. [pmid: 10754462].
1767 Weston G, Trajstman AC, Gargett CE, Manuelpillai U, Vollenhoven BJ, Rogers PA. Fibroids display an anti-angiogenic gene expression profile when compared with adjacent myometrium. Mol Hum Reprod. Sep. 2003;9(9):541-9. X-6. [pmid: 12900513].
1768 Whale CI, Johnson SR, Phillips KG, Newton SA, Lewis SA, Tattersfield AE. Lymphangioleiomyomatosis: a case-control study of perinatal and early life events. Thorax. Nov. 2003;58(11):979-82. X-6. [pmid: 14586053]. [pmcid: 1746512].
1769 Wildemeersch D, Schacht E. Contraception with a novel ‘frameless’ intrauterine levonorgestrel-releasing drug delivery system: a pilot study. Eur J Contracept Reprod Health Care. Dec. 2000;5(4):234-40. X-5. [pmid: 11245550].
1770 Wildemeersch D, Schacht E. The effect on menstrual blood loss in women with uterine fibroids of a novel “frameless” intrauterine levonorgestrel-releasing drug delivery system: a pilot study. Eur J Obstet Gynecol Reprod Biol. Apr 10. 2002;102(1):74-9. X-5. [pmid: 12039094].
1771 Wildemeersch D, Schacht E, Wildemeersch P. Treatment of primary and secondary dysmenorrhea with a novel 'frameless' intrauterine levonorgestrel-releasing drug delivery system: a pilot study. Eur J Contracept Reprod Health Care. Dec. 2001;6(4):192-8. X-5. [pmid: 11848648].
1772 Wildemeersch D, Schacht E, Wildemeersch P. Contraception and treatment in the perimenopause with a novel “frameless” intrauterine levonorgestrel-releasing drug delivery system: an extended pilot study. Contraception. Aug. 2002;66(2):93-9. X-5. [pmid: 12204781].
1773 Wildemeersch D, Schacht E, Wildemeersch P. Performance and acceptability of intrauterine release of levonorgestrel with a miniature delivery system for hormonal substitution therapy, contraception and treatment in peri and postmenopausal women. Maturitas. Mar 28. 2003;44(3):237-45. X-5. [pmid: 12648887].
1774 Williams NP, Williams E, Fletcher H. Smooth muscle tumours of the vulva in Jamaica. West Indian Med J. Dec. 2002;51(4):228-31. X-6. [pmid: 12632638].
1775 Wise LA, Palmer JR, Harlow BL, Spiegelman D, Stewart EA, Adams-Campbell LL, et al. Risk of uterine leiomyomata in relation to tobacco, alcohol and caffeine consumption in the Black Women's Health Study. Hum Reprod. Aug. 2004;19(8):1746-54. X-6. [pmid: 15218005]. [pmcid: 1876785].
1776 Wise LA, Palmer JR, Rowlings K, Kaufman RH, Herbst AL, Noller KL, et al. Risk of benign gynecologic tumors in relation to prenatal diethylstilbestrol exposure. Obstet Gynecol. Jan. 2005;105(1):167-73. X-6. [pmid: 15625159].
1777 Wise LA, Palmer JR, Spiegelman D, Harlow BL, Stewart EA, Adams-Campbell LL, et al. Influence of body size and body fat distribution on risk of uterine leiomyomata in U.S. black women. Epidemiology. May. 2005;16(3):346-54. X-6. [pmid: 15824551]. [pmcid: 1847589].
1778 Wise LA, Palmer JR, Stewart EA, Rosenberg L. Age-specific incidence rates for self-reported uterine leiomyomata in the Black Women's Health Study. Obstet Gynecol. Mar. 2005;105(3):563-8. X-6. [pmid: 15738025]. [pmcid: 1847590].
1779 Wittich AC, Salminen ER, Yancey MK, Markenson GR. Myomectomy during early pregnancy. Mil Med. Feb. 2000;165(2):162-4. CASE REPORT. [pmid: 10709382].
1780 Wolanska M, Bankowski E. An accumulation of insulin-like growth factor I (IGF-I) in human myometrium and uterine leiomyomas in various stages of tumour growth. Eur Cytokine Netw. Oct–Dec. 2004;15(4):359-63. X-6. [pmid: 15627646].
1781 Wolanska M, Bankowski E. Fibroblast growth factors (FGF) in human myometrium and uterine leiomyomas in various stages of tumour growth. Biochimie. Feb. 2006;88(2):141-6. X-6. [pmid: 16139411].
1782 Wolanska M, Sobolewski K, Bankowski E, Jaworski S. Matrix metalloproteinases of human leiomyoma in various stages of tumor growth. Gynecol Obstet Invest. 2004;58(1):14-8. X-5. [pmid: 15004438].
1783 Wolanska M, Sobolewski K, Cechowska-Pasko M, Jaworski S. The activities of some glycosaminoglycan-degrading enzymes in uterine leiomyomas. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):73-8. X-6. [pmid: 12932876].
1784 Wolanske KA, Gordon RL, Kerlan RK Jr, Wilson MW, LaBerge JM, Jacoby AF. Reversal of flow in the ovarian artery during uterine artery embolization. J Vasc Interv Radiol. Jun. 2003;14(6):785-7. CASE REPORT. [pmid: 12817047].
1785 Wolanske KA, Gordon RL, Wilson MW, Kerlan RK Jr, LaBerge JM, Jacoby AF. Coil embolization of a tuboovarian anastomosis before uterine artery embolization to prevent nontarget particle embolization of the ovary. J Vasc Interv Radiol. Oct. 2003;14(10):1333-8. CASE REPORT. [pmid: 14551282].
1786 Wong C. A uterine fibroid presenting as an incarcerated umbilical hernia during pregnancy. Hernia. Oct. 2005;9(3):298-9. CASE REPORT. [pmid: 16007370].
1787 Wong L, Ching TW, Kok TL, Koon TH. Spontaneous hemoperitoneum from a uterine leiomyoma in pregnancy. Acta Obstet Gynecol Scand. Dec. 2005;84(12):1208-9. CASE REPORT. [pmid: 16305710].
1788 Wong NA, Young R, Malcomson RD, Nayar AG, Jamieson LA, Save VE, et al. Prognostic indicators for gastrointestinal stromal tumours: a clinicopathological and immunohistochemical study of 108 resected cases of the stomach. Histopathology. Aug. 2003;43(2):118-26. X-6. [pmid: 12877726].
1789 Wong SK, Ahuja A, Chow J, King WW. Angioleiomyoma in the submandibular region: an unusual tumor in an unusual site. Otolaryngol Head Neck Surg. Jan. 2000;122(1):144-5. CASE REPORT. [pmid: 10629503].
1790 Woodruff BE, Mack K. Colonic leiomyoma in a 12-year-old patient with tuberous sclerosis: a case report and brief review. J Pediatr Gastroenterol Nutr. Apr. 2001;32(4):499-500. CASE REPORT. [pmid: 11396824].
1791 Worthington-Kirsch RL. Uterine artery embolization for fibroid disease is not experimental. Cardiovasc Intervent Radiol. Mar–Apr. 2005;28(2):148-9. X-1. [pmid: 15719184].
1792 Worthington-Kirsch RL, Hutchins FL Jr. Retained myoma fragment after LASH procedure. Clin Radiol. Sep. 2001;56(9):777-8. CASE REPORT. [pmid: 11585402].
1793 Worthington-Kirsch RL, Koller NE. Time course of pain after uterine artery embolization for fibroid disease. Medscape Womens Health. Mar–Apr. 2002;7(2):4. X-5. [pmid: 12142860].
1794 Wrede J, Helmke B, Hartmann M, Voelcker HE, Dithmar S. Successful hormone treatment of orbital leiomyoma. Ophthalmology. Jul. 2005;112(7):1316-8. CASE REPORT. [pmid: 15921744].
1795 Wright-Pascoe R, Bishop K. Chronic iron deficiency anaemia. West Indian Med J. Sep. 2000;49(3):249-53. X-6. [pmid: 11076224].
1796 Wu SM, Chao Yu YM, Yang CF, Che HL. Decision-making tree for women considering hysterectomy. J Adv Nurs. Aug. 2005;51(4):361-8. X-4. [pmid: 16086805].
1797 Wu X, Blanck A, Norstedt G, Sahlin L, Flores-Morales A. Identification of genes with higher expression in human uterine leiomyomas than in the corresponding myometrium. Mol Hum Reprod. Mar. 2002;8(3):246-54. X-6. [pmid: 11870232].
1798 Wu X, Blanck A, Olovsson M, Henriksen R, Lindblom B. Expression of Bcl-2, Bcl-x, Mcl-1, Bax and Bak in human uterine leiomyomas and myometrium during the menstrual cycle and after menopause. J Steroid Biochem Mol Biol. Jan. 2002;80(1):77-83. X-6. [pmid: 11867266].
1799 Wu X, Blanck A, Olovsson M, Moller B, Favini R, Lindblom B. Apoptosis, cellular proliferation and expression of p53 in human uterine leiomyomas and myometrium during the menstrual cycle and after menopause. Acta Obstet Gynecol Scand. May. 2000;79(5):397-404. X-6. [pmid: 10830768].
1800 Wu X, Blanck A, Olovsson M, Moller B, Lindblom B. Expression of basic fibroblast growth factor (bFGF), FGF receptor 1 and FGF receptor 2 in uterine leiomyomas and myometrium during the menstrual cycle, after menopause and GnRHa treatment. Acta Obstet Gynecol Scand. Jun. 2001;80(6):497-504. X-6. [pmid: 11380284].
1801 Wu X, Englund K, Lindblom B, Blanck A. mRNA-expression of often used house-keeping genes and the relation between RNA and DNA are sex steroid-dependent parameters in human myometrium and fibroids. Gynecol Obstet Invest. 2003;55(4):225-30. X-6. [pmid: 12904697].
1802 Wu X, Wang H, Englund K, Blanck A, Lindblom B, Sahlin L. Expression of progesterone receptors A and B and insulin-like growth factor-I in human myometrium and fibroids after treatment with a gonadotropin-releasing hormone analogue. Fertil Steril. Nov. 2002;78(5):985-93. X-6. [pmid: 12413982].
1803 Xiaogang Z, Huasheng W, Xingtao J. Carinal leiomyoma: report of a case treated by carinal resection and reconstruction. Thorac Cardiovasc Surg. Aug. 2001;49(4):235-7. CASE REPORT. [pmid: 11505322].
1804 Xu GQ, Li YW, Han YM, Li YM, Chen WX, Ji F, et al. Miniature ultrasonic probes for diagnosis and treatment of digestive tract diseases. World J Gastroenterol. Jul 1. 2004;10(13):1948-53. X-6. [pmid: 15222043].
1805 Xu GQ, Zhang BL, Li YM, Chen LH, Ji F, Chen WX, et al. Diagnostic value of endoscopic ultrasonography for gastrointestinal leiomyoma. World J Gastroenterol. Sep. 2003;9(9):2088-91. X-6. [pmid: 12970912].
1806 Xu J, Luo X, Chegini N. Differential expression, regulation, and induction of Smads, transforming growth factor-beta signal transduction pathway in leiomyoma, and myometrial smooth muscle cells and alteration by gonadotropin-releasing hormone analog. J Clin Endocrinol Metab. Mar. 2003;88(3):1350-61. X-6. [pmid: 12629129].
1807 Xu Q, Takekida S, Ohara N, Chen W, Sitruk-Ware R, Johansson ED, et al. Progesterone receptor modulator CDB-2914 down-regulates proliferative cell nuclear antigen and Bcl-2 protein expression and up-regulates caspase-3 and poly(adenosine 5'-diphosphate-ribose) polymerase expression in cultured human uterine leiomyoma cells. J Clin Endocrinol Metab. Feb. 2005;90(2):953-61. X-6. [pmid: 15572421].
1808 Xu Y, Lacouture M, Petronic-Rosic V, Soltani K, Shea CR. Ossified soft tissue leiomyoma in a patient with sickle cell anemia. J Cutan Pathol. Nov. 2005;32(10):696-9. CASE REPORT. [pmid: 16293183].
1809 Yadav D, Levy MJ, Schwartz D, Jondal ML, Clain J, Wiersema MJ. EUS-guided trucut biopsy for diagnosis of an esophageal stromal tumor: case report. Gastrointest Endosc. Sep. 2003;58(3):457-60. CASE REPORT. [pmid: 14528231].
1810 Yamada N, Uchida R, Fuchida S, Okano A, Okamoto M, Ochiai N, et al. CD5+ Epstein-Barr virus-positive intravascular large B-cell lymphoma in the uterus co-existing with huge myoma. Am J Hematol. Mar. 2005;78(3):221-4. CASE REPORT. [pmid: 15726593].
1811 Yamada T, Nakago S, Kurachi O, Wang J, Takekida S, Matsuo H, et al. Progesterone down-regulates insulin-like growth factor-I expression in cultured human uterine leiomyoma cells. Hum Reprod. Apr. 2004;19(4):815-21. X-6. [pmid: 15033949].
1812 Yamamoto H, Sato H, Shibata S, Murata M, Fukuda J, Tanaka T. Involvement of annexin V in the antiproliferative effect of GnRH agonist on cultured human uterine leiomyoma cells. Mol Hum Reprod. Feb. 2001;7(2):169-73. X-6. [pmid: 11160843].
1813 Yaman C, Jesacher K, Polz W. Accuracy of three-dimensional transvaginal ultrasound in uterus volume measurements; comparison with two-dimensional ultrasound. Ultrasound Med Biol. Dec. 2003;29(12):1681-4. X-6. [pmid: 14698334].
1814 Yamasaki H, Douchi T, Yamamoto S, Oki T, Kuwahata R, Nagata Y. Body fat distribution and body composition during GnRH agonist therapy. Obstet Gynecol. Mar. 2001;97(3):338-42. X-5. [pmid: 11239633].
1815 Yamazaki K. CD10- and CD34-positive periglandular stromal cells in pulmonary benign metastasizing leiomyoma with metaplastic adenomyomatous glands: an ultrastructural and immunohistochemical study. Virchows Arch. Mar. 2005;446(3):270-7. X-6. [pmid: 15688167].
1816 Yan CM, Mok KM. Uterine fibroids and adenomyosis in a woman with Rokitansky-Kuster-Hauser syndrome. J Obstet Gynaecol. Sep. 2002;22(5):561-2. CASE REPORT. [pmid: 12521437].
1817 Yan J, Wu Z, Li Y, Feng G, Zhang H. Angioleiomyoma of the ciliary body: a case report. Yan Ke Xue Bao. Mar. 2004;20(1):19-22. CASE REPORT. [pmid: 15124528].
1818 Yanai-Inbar I, Silverberg SG. Mucosal epithelial proliferation of the fallopian tube: prevalence, clinical associations, and optimal strategy for histopathologic assessment. Int J Gynecol Pathol. Apr. 2000;19(2):139-44. X-6. [pmid: 10782410].
1819 Yang CC, Tseng JY, Chen P, Wang PH. Uterus didelphys with cervical agenesis associated with adenomyosis, a leiomyoma and ovarian endometriosis. A case report. J Reprod Med. Nov. 2002;47(11):936-8. CASE REPORT. [pmid: 12497685].
1820 Yang CH, Lee JN, Hsu SC, Kuo CH, Tsai EM. Effect of hormone replacement therapy on uterine fibroids in postmenopausal women—a 3-year study. Maturitas. Sep 30. 2002;43(1):35-9. X-5. [pmid: 12270580].
1821 Yang JH, Chen MJ, Chen HF, Lee TH, Ho HN, Yang YS. Decreased expression of killer cell inhibitory receptors on natural killer cells in eutopic endometrium in women with adenomyosis. Hum Reprod. Sep. 2004;19(9):1974-8. X-6. [pmid: 15217996].
1822 Yang JH, Lin BL. Changes in myometrial thickness during hysteroscopic resection of deeply invasive submucous myomas. J Am Assoc Gynecol Laparosc. Nov. 2001;8(4):501-5. X-5. [pmid: 11677327].
1823 Yang JM, Huang WC. Sonographic findings of acute urinary retention secondary to an impacted pelvic mass. J Ultrasound Med. Oct. 2002;21(10):1165-9. CASE REPORT. [pmid: 12369672].
1824 Yang PS, Lee KS, Lee SJ, Kim TS, Choo IW, Shim YM, et al. Esophageal leiomyoma: radiologic findings in 12 patients. Korean J Radiol. Jul–Sep. 2001;2(3):132-7. X-6. [pmid: 11752983].
1825 Yang WE, Hsueh S, Chen CH, Lee ZL, Chen WJ. Leiomyoma of the hand mimicking a pearl ganglion. Chang Gung Med J. Feb. 2004;27(2):134-7. CASE REPORT. [pmid: 15095959].
1826 Yarali H, Bukulmez O. The effect of intramural and subserous uterine fibroids on implantation and clinical pregnancy rates in patients having intracytoplasmic sperm injection. Arch Gynecol Obstet. Jan. 2002;266(1):30-3. X-4. [pmid: 11998961].
1827 Yaris N, Cakir M, Cobanoglu U, Yayla S, Imamoglu M. Leiomyoma of the diaphragm in a child with Klippel Trenaunay syndrome. Pediatr Int. Feb. 2004;46(1):94-6. CASE REPORT. [pmid: 15043675].
1828 Yasuda K, Okumura T, Okada H, Nakajima T, Aoki J, Arai H, et al. Platelet-activating factor acetylhydrolase isoforms I and II in human uterus. Comparisons with pregnant uterus and myoma. Biol Reprod. Jan. 2001;64(1):339-44. X-6. [pmid: 11133692].
1829 Yasuoka R, Sakakura C, Shimomura K, Fujita Y, Nakanishi M, Aragane H, et al. Mutations in exon 11 of the c-kit gene in a myogenic tumor and a neurogenic tumor as well as in gastrointestinal stromal tumors. Utility of c-kit mutation as a prognostic biomarker for gastrointestinal mesenchymal tumor. Dig Surg. 2003;20(3):183-91. X-6. [pmid: 12759497].
1830 Yates BJ. Angioleiomyoma: clinical presentation and surgical management. Foot Ankle Int. Aug. 2001;22(8):670-4. X-6. [pmid: 11527030].
1831 Yavuz E, Gulluoglu MG, Akbas N, Tuzlali S, Ilhan R, Iplikci A, et al. The values of intratumoral mast cell count and Ki-67 immunoreactivity index in differential diagnosis of uterine smooth muscle neoplasms. Pathol Int. Dec. 2001;51(12):938-41. X-6. [pmid: 11844066].
1832 Yeagley TJ, Goldberg J, Klein TA, Bonn J. Labial necrosis after uterine artery embolization for leiomyomata. Obstet Gynecol. Nov. 2002;100(5 Pt 1):881-2. CASE REPORT. [pmid: 12423845].
1833 Yen YK, Liu WM, Lai CR, Yuan CC, Ng HT. Rapid enlargement of uterine myomas after laparoscopic bipolar coagulation of uterine vessels. J Am Assoc Gynecol Laparosc. Feb. 2002;9(1):93-7. CASE REPORT. [pmid: 11821615].
1834 Yen YK, Liu WM, Yuan CC, Ng HT. Laparoscopic bipolar coagulation of uterine vessels to treat symptomatic myomas in women with elevated Ca 125. J Am Assoc Gynecol Laparosc. May. 2001;8(2):241-6. X-4. [pmid: 11342731].
1835 Yen YK, Liu WM, Yuan CC, Ng HT. Addition of laparoscopic uterine nerve ablation to laparoscopic bipolar coagulation of uterine vessels for women with uterine myomas and dysmenorrhea. J Am Assoc Gynecol Laparosc. Nov. 2001;8(4):573-8. X-4. [pmid: 11677339].
1836 Yen YK, Liu WM, Yuan CC, Ng HT. Comparison of two procedures for laparoscopic-assisted vaginal hysterectomy of large myomatous uteri. J Am Assoc Gynecol Laparosc. Feb. 2002;9(1):63-9. X-4. [pmid: 11821608].
1837 Yilmaz E, Bozdogan O, Atasoy P, Altan Y. Epididymal leiomyoma associated with leydig cell hyperplasia: a case report and immunohistochemical study. Int Urol Nephrol. 2002;34(2):215-8. CASE REPORT. [pmid: 12775098].
1838 Yin H, Mittal K. Incidental findings in uterine prolapse specimen: frequency and implications. Int J Gynecol Pathol. Jan. 2004;23(1):26-8. X-5. [pmid: 14668546].
1839 Yogesh K, Amita M, Rajendra K, Raju A, Rekha W, Hemant T. Vaginal leiomyoma developing after hysterectomy - case report and literature review. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):96-7. CASE REPORT. [pmid: 15730381].
1840 Yohannes P, Schaefer J. Urinary retention during the second trimester of pregnancy: a rare cause. Urology. Jun. 2002;59(6):946. CASE REPORT. [pmid: 12031388].
1841 Yokoyama T, Setoguchi Y, Ohta K, Sugiyama N, Nagate A, Nagao T, et al. Endobronchial minute leiomyoma in a patient with malignant lymphoma. Intern Med. Jul. 2005;44(7):769-70. CASE REPORT. [pmid: 16093608].
1842 Yokoyama Y, Shinohara A, Hirokawa M, Maeda N. Erythrocytosis due to an erythropoietin-producing large uterine leiomyoma. Gynecol Obstet Invest. 2003;56(4):179-83. CASE REPORT. [pmid: 14564105].
1843 Yoshikawa K, Yamaguti T, Nakamura M, Hirabayasi K, Hazano K, Utida M, et al. The role of dual-phase enhanced helical computed tomography in difficult intestinal bleeding. J Clin Gastroenterol. Jul. 2000;31(1):83-4. CASE REPORT. [pmid: 10914785].
1844 Yoshimitsu N, Douchi T, Nagata Y. Perioperative changes in circulating leptin levels in women undergoing total abdominal hysterectomy. Endocr J. Aug. 2001;48(4):509-13. X-5. [pmid: 11603576].
1845 Yoshimura K, Okubo K, Ichioka K, Terada N, Matsuta Y, Arai Y. Laparoscopic partial nephrectomy with a microwave tissue coagulator for small renal tumor. J Urol. Jun. 2001;165(6 Pt 1):1893-6. X-6. [pmid: 11371875].
1846 Yoshitake T, Asayama Y, Yoshimitsu K, Irie H, Aibe H, Tajima T, et al. Bilateral ovarian leiomyomas: CT and MRI features. Abdom Imaging. Jan–Feb. 2005;30(1):117-9. CASE REPORT. [pmid: 15185019].
1847 Yoshizaki A, Nakayama T, Naito S, Sekine I. Expressions of parathyroid hormone-related protein (PTHrP) and PTH/PTHrP-receptor (PTH/PTHrP-R) in gastrointestinal stromal tumours (GISTs), leiomyomas and schwannomas. Scand J Gastroenterol. Feb. 2004;39(2):133-7. X-6. [pmid: 15000274].
1848 Young RH. Dusting off old books: comments on classic gynecologic pathology books of yesteryear. Int J Gynecol Pathol. Jan. 2000;19(1):67-84. X-1. [pmid: 10638454].
1849 Yu KJ, Lai CR, Sheu MH. Spontaneous expulsion of a uterine submucosal leiomyoma after administration of a gonadotropin-releasing hormone agonist. Eur J Obstet Gynecol Reprod Biol. Jun. 2001;96(2):223-5. CASE REPORT. [pmid: 11384814].
1850 Yuddandi N, Gleeson R, Gillan J, Geary M. Management of a massive caseous fibroid at caesarean section. J Obstet Gynaecol. Jun. 2004;24(4):455-6. CASE REPORT. [pmid: 15203593].
1851 Yun AJ, Daniel SM. Sympathetic and T helper (Th)2 bias may ameliorate uterine fibroids, independent of sex steroids. Med Hypotheses. 2005;65(6):1172-5. X-6. [pmid: 16213989].
1852 Yusim IE, Neulander EZ, Eidelberg I, Lismer LJ, Kaneti J. Leiomyoma of the genitourinary tract. Scand J Urol Nephrol. Sep. 2001;35(4):295-9. X-6. [pmid: 11676355].
1853 Zahid MA, Waqar SH, Shamsuddin S, Ahmed I, Dar FS. Leiomyoma of oesophagus. J Coll Physicians Surg Pak. Jun. 2003;13(6):347-9. CASE REPORT. [pmid: 12814536].
1854 Zaslawski R, Surowiak P, Dziegiel P, Pretnik L, Zabel M. Analysis of the expression of estrogen and progesteron receptors, and of PCNA and Ki67 proliferation antigens, in uterine myomata cells in relation to the phase of the menstrual cycle. Med Sci Monit. Sep–Oct. 2001;7(5):908-13. X-6. [pmid: 11535933].
1855 Zheng WW, Zhou KR, Chen ZW, Shen JZ, Chen CZ, Zhang SJ. Characterization of focal hepatic lesions with SPIO-enhanced MRI. World J Gastroenterol. Feb. 2002;8(1):82-6. X-6. [pmid: 11833077].
1856 Zhong YQ, Huang HR, Zhu ZH, Chen QK, Zhan J, Xing LC. Effects of sulfasalazine on biopsy mucosal pathologies and histological grading of patients with active ulcerative colitis. World J Gastroenterol. Jul 28. 2005;11(28):4435-8. X-6. [pmid: 16038049].
1857 Zhou PH, Yao LQ, Zhong YS, He GJ, Xu MD, Qin XY. Role of endoscopic miniprobe ultrasonography in diagnosis of submucosal tumor of large intestine. World J Gastroenterol. Aug 15. 2004;10(16):2444-6. X-6. [pmid: 15285040].
1858 Zhu XQ, Shi YF, Cheng XD, Zhao CL, Wu YZ. Immunohistochemical markers in differential diagnosis of endometrial stromal sarcoma and cellular leiomyoma. Gynecol Oncol. Jan. 2004;92(1):71-9. X-6. [pmid: 14751141].
1859 Zikria BA, Radevic MR, Jormark SC, Huvos AG, Yang SS. Intraosseous leiomyoma of the ulna. A case report. J Bone Joint Surg Am. Nov. 2004;86-A(11):2522-5. CASE REPORT. [pmid: 15523029].
1860 Zinkiewicz K, Zgodzinski W, Dabrowski A, Szumilo J, Cwik G, Wallner G. Recurrent inflammatory fibroid polyp of cardia: a case report. World J Gastroenterol. Mar 1. 2004;10(5):767-8. CASE REPORT. [pmid: 14991958].
1861 Zompatori M, Sciascia N, Di Scioscio V, Bergonzini R. Big, but good-natured. Radiol Med (Torino). Mar. 2003;105(3):254-6. CASE REPORT. [pmid: 12835652].
1862 Zondervan KT, Cardon LR, Kennedy SH, Martin NG, Treloar SA. Multivariate genetic analysis of chronic pelvic pain and associated phenotypes. Behav Genet. Mar. 2005;35(2):177-88. X-6. [pmid: 15685430].
1863 Zorlu CG, Akar ME, Seker-Ari E, Yilmaz S, Sindel T. Uterine artery embolization to control bleeding after myomectomy. Acta Obstet Gynecol Scand. Jun. 2005;84(6):606-7. CASE REPORT. [pmid: 15901277].
1864 Zorn KC, Daigle S, Belzile F, Tu le M. Embolization of a massive retropubic hemorrhage following a tension-free vaginal tape (TVT) procedure: case report and literature review. Can J Urol. Feb. 2005;12(1):2560-3. CASE REPORT. [pmid: 15777497].
1865 Zupi E, Marconi D, Sbracia M, Exacoustos C, Piredda A, Sorrenti G, et al. Directed laparoscopic cryomyolysis for symptomatic leiomyomata: one-year follow up. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):343-6. X-5. [pmid: 16036195].
1866 Zupi E, Piredda A, Marconi D, Townsend D, Exacoustos C, Arduini D, et al. Directed laparoscopic cryomyolysis: a possible alternative to myomectomy and/or hysterectomy for symptomatic leiomyomas. Am J Obstet Gynecol. Mar. 2004;190(3):639-43. X-5. [pmid: 15041993].
1867 Zupi E, Pocek M, Dauri M, Marconi D, Sbracia M, Piccione E, et al. Selective uterine artery embolization in the management of uterine myomas. Fertil Steril. Jan. 2003;79(1):107-11. X-5. [pmid: 12524072].