# Appendix C. Evidence Tables

Glossary

AOR | adjusted odds ratio
AUB | abnormal uterine bleeding
bFGF | basic fibroblast growth factor
BMD | body mineral density
BMI | body mass index
CA | cyproterone acetate
cc | cubic centimeter
CI | confidence interval
Cm | centimeter
Cm/s | centimeters per second
Cm^2^ | centimeters squared
cm^3^ | cubic centimeters
COPD | chronic obstructive pulmonary disease
CPT-4 | Current Procedural Terminology, Fourth Edition
C-section | cesarean section
d | day
E_2_ | estradiol
EBL | estimated blood loss
ER | emergency room
ET | embryo transfer
EV | estradiol valerate
EZ | estradiol
FSH | follicle-stimulating hormone
g | gram
g/dl | grams per deciliter
GIFT | gamete intrafallopian transfer
gm | grams
GnRH | Gonadotropin releasing hormone
GnRHa/GnRH-a | Gonadotropin releasing hormone agonist/analogue
gyn | gynecologic
HDL-C | high-density lipoprotein cholesterol
Hct | hematocrit
Hgb | Hemoglobin
hrs | hours
ICD-9-CM | International Classification of Diseases, Ninth Revision, Clinical Modification
im | intramuscular
IM | intramuscular
IQR | interquartile range
IU | international units
IU/L | international units per liter
IUI | intrauterine insemination
IVF | invitro fertilization
kg | kilograms
LA | leuprorelin
LA-MLT | laparoscopically assisted minilaparotomy
LAVH | laparoscopically assisted vaginal hysterectomy
lb | pound
LDL-C | low-density lipoprotein cholesterol
LH | luteinizing hormone
LM | laprascopic myomectomy
LT | laparotomy
mg | milligram
mg/d | milligrams per day
mg/dL | milligram per deciliter
min | minute(s)
ml | millileter
MLT | minilaparotomy
mlU/mL | milli-international units per million
mm | millimeter
mmol/L | millimoles per liter
mos | months
MPA | Medroxyprogesterone Acetate
MR | magnetic resonance
MRgFUS | magnetic resonance guided focused ultrasound
MRI | magnetic resonance imaging
N | number
NA | not applicable
ng/ml | nanogram/milliliter
nmol/l | nanomoles per liter
NR | not reported
NRS | numeric rating scale
NS | not significant
NSAIDs | non-steroidal anti-inflammatory drugs
OCP | oral contraceptive pill
OR | odds ratio
PID | Pelvic Inflammatory Disease
pmol/L | picomoles per liter
po | per oral (by mouth)
PROM | premature rupture of membranes
q28d | every 28 days
RCT | randomized controlled trial
rHuEPO | recombinant human erythropoietin
RR | relative risk
sc | subcutaneous
SC | subcutaneous
SD | standard deviation
SEM | standard error of mean
SLL | second-look laparoscopy
SSS | symptom severity scale
TAH | total abdominal hysterectomy
TC | total cholesterol
TCR | transcervical resection
TCRE | transcervical resection of endometrium
TCRM | transcervical resection of submucous fibroids
TG | triglycerides
u/s | ultrasound
UAE | Uterine artery embolization
UFE | uterine fibroid embolization
UFS-QOL | uterine fibroid symptoms - quality-of-life
UK | United Kingdom
US | United States
VAS | visual analog scale
vs. | versus
WHR | waist-to-hip ratio
wk(s) | week(s)
wt | weight
yr(s) | year(s)
ZIFT | zygote intrafallopian transfer

Evidence Table 1. KQ 1

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria and Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Cumulative incidence by race: | Quality:
Baird et al., 2003 | Prospective cohort | - Age 35 to 49 yr | NR | OR = 2.9; 95% CI, 2.5–3.4 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | P < 0.001 | INTERNAL VALIDITY: fair
US, Community | NA | - Not a member of health plan at Washington, DC site; - No telephone; - Non-English speaking | NR | Age at fibroid diagnosis (mean): | Random: +
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | G1: 33 | Methods and blinding: NA
NR | G1: Black women | NA | NR | G2: 36 | Pt selection criteria: ++
Funding: | G2: White women | Preoperative therapy: | Type of fibroid: | P < 0.001 | Loss to follow-up: 10–20%
NIEHS | N at enrollment: | NA | NR | Multiple fibroids, %: | Drop-out rates: NA
| G1: 840 | Additional procedures: | | G1: 73 | Statistical issues: ++
| G2: 524 | NA | | G2: 45 | EXTERNAL VALIDITY: good
| N at follow-up: | | | Hysterectomy with previous fibroid diagnosis, %: | Age: +, reported
| NA | | | G1: 12 | Race: +, reported
| Age, %: | | | G2: 5 | Pregnancy history: -, NR
| 35 to 39 yr: | | | Premenopausal women previously diagnosed, %: | Surgical history: -, NR
| G1: 33 | | | G1: 45 | Fibroid/uterine size: NA
| G2: 31 | | | G2: 21 | Number of fibroids: NA
| 40 to 44 yr: | | | Fibroids detected by ultrasound in women previously diagnosed, %: | Location of fibroids: NA
| G1: 34 | | | G1: 87 | Baseline characteristics: +, reported
| G2: 32 | | | G2: 78 | Length of follow-up: ++
| ≥ 45 yr: | | | Fibroids detected by ultrasound in premenopausal women not previously diagnosed, %: | Measurement methods: +
| G1: 33 | | | G1: 59 | Measurement reliability: +
| G2: 38 | | | G2: 43 | Clinical care: NA
| Race/ethnicity: | | | Modifiers:
| See groups | | | NR
| Parity, at age 35, (%):
| 0:
| G1: 186 (23)
| G2: 332 (66)
| 1:
| G1: 194 (24)
| G2: 87 (17)
| 2:
| G1: 251 (31)
| G2: 68 (13)
| ≥ 3:
| G1: 187 (23)
| G2: 17 (3)
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | New cases of UF: | Quality:
Wise et al., 2004 | Prospective cohort | - Premenopausal women with intact uteri; - Age: 21 to 69 yrs; - Subscribers of Essence magazine, member of Black professional organizations, and friends and relatives of respondents | NR | 2,279 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Age at menarche, IRR (95% CI): | INTERNAL VALIDITY: good
US, National survey | NA | - Natural or medical menopause; - Hysterectomy; - Bilateral oophorectomy; - Unknown menopausal status; - Diagnosis of leiomyomata before 1997; - Did not complete 1999 and 2001 follow-up questionnaires; - No information about year of diagnosis or confirmation type; - Women with incomplete exposure or covariate information | NR | < 11: 1.0 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | 11: 0.9 (0.8–1.1) | Methods and blinding: NA
03/1997 to 03/2001 | Ultrasound confirmed fibroids: 2,006 Hysterectomy confirmed fibroids: 273 | NR | NR | 12 to 13: 0.8 (0.7–0.9) | Pt selection criteria: ++
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | 14: 0.8 (0.6–0.9) | Loss to follow-up: <10%
Grant from National Cancer Institute | 22,895 | NR | NR | > 14: 0.6 (0.5–0.8) | Drop-out rates: NA
| N at follow-up: | Associated procedure(s): | | P < 0.001 | Statistical issues: ++
| NR | NR | | Nulliparous, IRR: | EXTERNAL VALIDITY: fair (1)
| Age: | | | 1.0 | Age: +, reported
| Median 34 | | | Parity, IRR (95% CI): | Race: +, reported
| Race/ethnicity, %: | | | 0.7 (0.6–0.7) | Pregnancy history: NA
| African-American: 100 | | | Age at first birth, IRR (95% CI): | Surgical history: NA
| Parity, parous, %: | | | <20: 1.0 | Fibroid/uterine size: NA
| 57 (average of 2 births) | | | 20–24: 0.9 (0.8–1.1) | Number of fibroids: NA
| Baseline Hgb/Hct: | | | 25–29: 0.7 (0.6–0.9) | Location of fibroids: NA
| NR | | | >29: 0.5 (0.4–0.9) | Baseline characteristics: +, reported
| | | | P = 0.002 | Length of follow-up: ++
| | | | Current use of hormonal contraceptive, IRR (95% CI): | Measurement methods: +
| | | | Progestin-only injectables: 0.5 (0.4–0.9) | Measurement reliability: -
| | | | Progestin-only implants: 0.4 (0.2–1.5) | Clinical care: NA
| | | | Progestin-only OCP: 0.8 (0.4–3.0)
| | | | Combined OCP: 1.0 (0.9–1.1)
| | | | Years since last birth, IRR (95% CI):
| | | | < 5: 1.0 (referent)
| | | | 5–9: 2.2 (1.6–2.5)
| | | | 10 to 14: 3.5 (2.2–3.7)
| | | | 15 to 19: 3.5 (1.9–3.5)
| | | | > 19: 3.4 (1.4–3.2)
| | | | P < 0.001

Evidence Table 2. KQ2 Expectant management

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Hgb, after therapy, g/dL ± SD: | Quality:
Di Lieto, De Falco, Pollio et al., 2005 | Prospective cohort | - Pre-menopausal; - Symptomatic fibroids | G1: 725.6 ± 193.5 | G1: 12.8 ± 0.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 762.7 ± 201.2 | G2: NA | INTERNAL VALIDITY: good
Italy, Academic medical center | Medical management followed by uterine surgery | - Malignant neoplasm | Number of fibroids: | Hgb, after surgery, g/dL ± SD: | Random: NA
Enrollment period: | Groups: | In last 12 months: | NR | G1: 11.3 ± 0.5 | Methods and blinding: NA
NR | G1: Leuprolide acetate depot injections for 3 months | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | G2: 6.5 ± 0.8 | Pt selection criteria: +
Funding: | G2: No pre-treatment | Indications: | NR | Uterine volume, cm^3^± SD: | Loss to follow-up: <10%
Italian Ministry of University and Scientific Research | N at enrollment: | NR | Type of fibroid: | G1: 492.7±134.2 | Drop-out rates: <5%
| G1: 31 | Preoperative therapy: | NR | G2: N/A | Statistical issues: +
| G2: 55 | See Groups | | Modifiers: | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Additional procedures: | | NR | Age: +, reported
| NR | NR | | | Race: NA, not US study
| Age, yrs ± SD: | | | | Pregnancy history: +, reported
| G1: 37.5 ± 3.9 | | | | Surgical history: +, reported
| G2: 38.1 ± 3.5 | | | | Fibroid/uterine size: +
| Race/ethnicity: | | | | Number of fibroids: -
| NR | | | | Location of fibroids: -
| Parity, mean ± SD: | | | | Baseline characteristics: +, reported
| G1: 2.2 ± 1.4 | | | | Length of follow-up: +
| G2: 2.1 ± 1.6 | | | | Measurement methods: +
| Baseline Hgb, g/dL ± SD: | | | | Measurement reliability: +
| G1: 7.6 ± 0.3 | | | | Clinical care: -
| G2: 7.8 ± 0.5
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine size: | Quality:
Di Lieto, De Falco, Staibano et al., 2003 | Prospective cohort | - Pre-menopausal; - Fibroids present | G1: 774.5 ± 203.1 | G1: 484.9 ± 144.5 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 804.7 ± 233.7 | G2: N/A | INTERNAL VALIDITY: good
Italy, Academic medical center | Monthly subcutaneous leuprorelin acetate depot 3.75 mg for 3 cycles prior to myomectomy or hysterectomy | - Malignant neoplasm | Number of fibroids: | P < 0.05 | Random: NA
Enrollment period: | Groups: | In last 12 mos: | NR | “Quickscore”* for bFGF: | Methods and blinding: NA
NR | G1: Leuprorelin acetate depot 3.75 mg | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | G1: 7.96 ± 2.22 | Pt selection criteria: +
Funding: | G2: No medical intervention women | | NR | G2: 9.61 ± 2.54 | Loss to follow-up: <10%
NR | N at enrollment: | | Type of fibroid: | P < 0.05 | Drop-out rates: <5%
| G1: 25 | Indications: | NR | Modifiers: | Statistical issues: +
| G2: 46 | NR | | NR | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Preoperative therapy: | | | Age: +, reported
| G1: 25 | See Groups | | | Race: NA, not US study
| G2: 46 | Additional procedures: | | | Pregnancy history: +, reported
| Age, yrs ± SD: | NR | | | Surgical history: +, reported
| G1: 38.4 ± 4.3 | | | | Fibroid/uterine size: +
| G2: 37.9 ± 3.5 | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: +, reported
| Parity, mean ± SD: | | | | Length of follow-up: +
| G1: 2.3 ± 1.4 | | | | Measurement methods: +
| G2: 1.9 ± 1.5 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: -
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine Size, cm^3^± SD: | Quality:
Di Lieto, De Rosa et al., 2002 | Prospective cohort | - Pre-menopausal; - Symptomatic fibroids | G1: 571.3 ± 266.7 | G1: 413.4 ± 217 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 540.4 ± 250.8 | G2: 601.1 ± 241.3 | INTERNAL VALIDITY: good
Italy, Academic medical center | Monthly subcutaneous leuprorelin acetate depot 3.75 mg for 3 cycles prior to myomectomy | - Malignant neoplasm | Number of fibroids: | Modifiers: | Random: NA
Enrollment period: | Groups: | In last 12 months: | NR | NR | Methods and blinding: NA
NR | G1: Leuprorelin acetate depot 3.75 mg | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | | Pt selection criteria: +
Funding: | G2: No medical intervention | Indications: | NR | | Loss to follow-up: <10%
NR | N at enrollment: | NR | Type of fibroid: | | Drop-out rates: <5%
| G1: 39 | Preoperative therapy: | NR | | Statistical issues: +
| G2: 31 | See Groups | | | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | Additional procedures: | | | Age: +, reported
| G1: 39 | NR | | | Race: NA, not US study
| G2: 31 | | | | Pregnancy history: +, reported
| Age, mean yrs ± SD: | | | | Surgical history: NA
| G1: 36.1 ± 3.2 | | | | Fibroid/uterine size: +
| G2: 37.3 ± 3.7 | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: -, NR
| Parity, mean ± SD: | | | | Length of follow-up: +
| G1: 2.2 ± 1.8 | | | | Measurement methods: +
| G2: 1.9 ± 1.8 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: -
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine volume, cm^3^± SD: | Quality:
Di Lieto, Iannotti et al., 2003 | Prospective cohort | - Pre-menopausal; - Symptomatic fibroids | G1: 675.8 ± 176 | G1: 466.6 ± 113.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 646.9 ± 191.4 | G2: NR | INTERNAL VALIDITY: good
Italy, Academic medical center | Monthly subcutaneous leuprorelin acetate depot 3.75 mg for 3 cycles prior to myomectomy | - Malignant neoplasm | Number of fibroids: | P < 0.05 | Random: NA
Enrollment period: | Groups: | In last 12 months: | NR | Modifiers: | Methods and blinding: NA
NR | G1: Leuprorelin acetate depot 3.75 mg | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | NR | Pt selection criteria: +
Funding: | G2: No medical intervention | Indications: | NR | | Loss to follow-up: NR
NR | N at enrollment: | NR | Type of fibroid: | | Drop-out rates: NR
| G1: 48 | Preoperative therapy: | NR | | Statistical issues: +
| G2: 41 | See Groups | | | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Additional procedures: | | | Age: +, reported
| G1: 48 | NR | | | Race: NA, not US study
| G2: 41 | | | | Pregnancy history: +, reported
| Age, yrs ± SD: | | | | Surgical history: +, reported
| G1: 38 ± 4 | | | | Fibroid/uterine size: +
| G2: 38.8 ± 3.7 | | | | Number of fibroids: -
| Race/Ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: +, reported
| Parity, mean ± SD: | | | | Length of follow-up: +
| G1: 2.2 ± 1.8 | | | | Measurement methods: +
| G2: 1.5 ± 1.3 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: -
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size cm^3^± SD: | Fibroid volume: | Quality:
Donnez et al., 2003 | RCT | - Pre-menopausal; - Uterine fibroids requiring hysterectomy; - Willing to use barrier contraception for 4 weeks before and during presurgical stage of trial; - Not involved in night-shift work | Numerical values not reported | G1 vs. G5: P = 0.833 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2 vs. G5: P = 0.938 | INTERNAL VALIDITY: poor
Multi-national, Academic medical centers | Medical management with anti-estrogen and GnRH-a followed by hysterectomy | - Previously received >3mos GnRHa; - Completed GnRHa treatment within 3 mos of study; - Received sex-hormone therapy, used OCP, or danazol within 4 weeks of study; - History of disease affecting bone or steroid metabolism; - Change in menstrual frequency or changes related to onset of menopause | NR | G3 vs. G5: P = 0.506 | Random: -
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | G1 vs. G4: P = 0.001 | Methods and blinding: -
NR | G1: Fulvestrant 50 mg IM injection monthly × 3 | NR | NR | G2 vs. G4: P = 0.0002 | Pt selection criteria: +
Funding: | G2: Fulvestrant 125 mg IM monthly × 3 | Preoperative therapy: | Type of fibroid: | G3 vs. G4: P = 0.023 | Loss to follow-up: <10%
AstraZeneca Pharma-ceuticals | G3: Fulvestrant 250 mg IM monthly × 3 | NR | NR | Endometrial thickness: | Drop-out rates: 5–10%
| G4: Goserelin 3.6 mg SC × 3 | Associated procedure(s): | | G1 vs. G5: P = 0.468 | Statistical issues: +
| G5: No treatment | NR | | G2 vs. G5: P = 0.868 | EXTERNAL VALIDITY: poor (5)
| N at enrollment: | | | G3 vs. G5: P = 0.755 | Age: +, reported
| G1: 59 | | | G1 vs. G4: P = 0.025 | Race: NA, not US study
| G2: 66 | | | G2 vs. G4: P = 0.002 | Pregnancy history: -, NR
| G3: 62 | | | G3 vs. G4: P = 0.009 | Surgical history: NA
| G4: 66 | | | Uterine Volume: | Fibroid/uterine size: +
| G5: 60 | | | Numerical values not reported | Number of fibroids: -
| N at follow-up: | | | G3/G4 superior, | Location of fibroids: -
| G1: 55 | | | G4 > G3 | Baseline characteristics: -, NR
| G2: 63 | | | Modifiers: | Length of follow-up: +
| G3: 61 | | | NR | Measurement methods: +
| G4: 62 | | | | Measurement reliability: +
| G5: 60 | | | | Clinical care: -
| Age, yrs ± SD:
| G1: 44.0 ± 4.0
| G2: 44.0 ± 4.4
| G3: 44.0 ± 4.5
| G4: 44.0 ± 4.0
| G5: 44.0 ± 5.1
| Race/ethnicity:
| NR
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Estimated blood loss, ml ± SD: | Quality:
Dousias et al., 2003 | RCT | - No major medical illness; - Age: 30 to 60 yrs; - Hgb: ≥ 9 and < 12 g/dl; - Weight: 50 to 80 kg; - Ferritin > 50 ng/ml; - Uterine fibroids by ultrasound | NR | G1: 645 ± 116 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 593 ± 130 | INTERNAL VALIDITY: good
Greece, Academic medical center | Preoperative recombinant human erythropoietin (rHuEPO) | NR | NR | Length of stay, days ± SD: | Random: +
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | G1: 7.6 ± 0.5 | Methods and blinding: +
NR | G1: Iron 200 mg/day and rHuEPO 600 U/ml SC once weekly for 3 weeks | NR | NR | G2: 7.8 ± 0.9 | Pt selection criteria: +
Funding: | G2: Iron 200 mg/d | Preoperative therapy: | Type of fibroid: | Mean Hgb on Day 7, g/dL ± SD: | Loss to follow-up: NR
NR | N at enrollment: | None | NR | G1: 11.2 ± 0.7 | Drop-out rates: NR
| G1: 23 | Additional procedures: | | G2: 10.5 ± 0.6 | Statistical issues: +
| G2: 27 | NR | | 95% CI, 0.3–1.1 | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | | | Mean Hgb on Day 0, g/dL ± SD: | Age: +, reported
| G1: 23 | | | G1: 11.9 ± 0.7 | Race: NA, not US study
| G2: 27 | | | G2: 10.7 ± 0.7 | Pregnancy history: -, NR
| Age, yrs ± SD: | | | 95% CI, 0.8–1.6 | Surgical history: NA
| G1: 48.2 ± 4.1 | | | Mean Hgb on Day +3, g/dL ± SD: | Fibroid/uterine size: -
| G2: 49.2 ± 4.7 | | | G1: 10.3 ± 0.8 | Number of fibroids: -
| Race: | | | G2: 8.8 ± 0.7 | Location of fibroids: -
| NR | | | 95% CI, 1.9–2.0 | Baseline characteristics: -, NR
| Parity: | | | Mean Hgb on Day +7, g/dL ± SD: | Length of follow-up: +
| NR | | | G1: 10.7 ± 0.8 | Measurement methods: +
| Baseline Hgb/Hct, g/dL ± SD: | | | G2: 8.8 ± 0.7 | Measurement reliability: +
| G1:10.3 ± 4.1 | | | 95% CI, 1.4–2.3 | Clinical care: +
| G2:10.4 ± 4.6 | | | Mean Hgb on Day +14, g/dL ± SD:
| | | | G1: 10.8 ± 0.2
| | | | G2: 9.1 ± 0.7
| | | | 95% CI, 1.3–2.1
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Mean size change, cm: | Quality:
Mehl-Madrona, 2002 | Prospective cohort | - Pre-menopausal; - Intact uterus of ≥ 6 to 8 week size with palpable fibroids; - Fibroids 2 to 3 cm in diameter | NR | G1: -0.8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: +1.9 | INTERNAL VALIDITY: fair
US, Academic medical center | Traditional Chinese medical approach | - Fibroids growing ≥ 6 cm/year; - Hgb < 8g/dL; - Hydronephrosis; - Taking hormonal contraceptives | NR | Size and/or rate of growth of fibroids, 6 mos, mean change in size (cm): | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Cured (gone) | Methods and blinding: NA
NR | G1: Traditional Chinese Medicine with combination of weekly acupuncture, Chinese herbs, and nutritional therapy | - Palpable fibroids; - Fibroids 2 to 3 cm in diameter | NR | G1: 3 | Pt selection criteria: +
Funding: | G2: Matched controls medically managed with any medical treatment | Pre-operative therapy: | Type of fibroid: | G2: 0 | Loss to follow-up: <10%
NR | N at enrollment: | NA | NR | Reduced size (>2cm) | Drop-out rates: <5%
| G1: 37 | Associated procedure(s): | | G1: 11 | Statistical issues: -
| G2: 37 | NA | | G2: 1 | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | | | Stopped growing | Age: +, reported
| G1: 37 | | | (± 1cm) | Race: -, NR
| G2: 37 | | | G1: 8 | Pregnancy history: -, NR
| Age: | | | G2: 2 ) | Surgical history: NA
| Mode: 36 (24 to 45) | | | Decreased rate of growth (change >1cm) | Fibroid/uterine size: +
| Race/ethnicity: | | | G1: 10 (+1.1) | Number of fibroids: -
| NR | | | G2: 9 (+0.9) | Location of fibroids: -
| Parity: | | | Total improved*: | Baseline characteristics: -, NR
| NR | | | G1: 32 | Length of follow-up: +
| Baseline Hgb/Hct: | | | G2: 13 | Measurement methods: +
| NR | | | P < 0.001 | Measurement reliability: +
| | | | No change | Clinical care: +
| | | | G1: 3 (+0.9)
| | | | G2: 20 (+1.9)
| | | | Increased rate of growth (change >1cm)
| | | | G1: 2 (+9.2)
| | | | G2: 4 (+7.0)
| | | | Total unimproved:
| | | | G1: 5
| | | | G2: 24
| | | | P < 0.001
| | | | Symptom change, N:
| | | | Heavy menstrual bleeding, before treatment:
| | | | G1: 20
| | | | G2: 20
| | | | Heavy menstrual bleeding, 6 mos:
| | | | G1: 9
| | | | G2: 11
| | | | Prolonged menstrual bleeding, before treatment:
| | | | G1: 9
| | | | G2: 9
| | | | Prolonged menstrual bleeding, 6 mos:
| | | | G1: 5
| | | | G2: 5
| | | | Dysmenorrhea before treatment, N:
| | | | G1: 9
| | | | G2: 9
| | | | Dysmenorrhea, 6 mos:
| | | | G1: 5
| | | | G2: 7
| | | | Decreased exercise/activity tolerance, before treatment:
| | | | G1: 2
| | | | G2: 2
| | | | Decreased exercise/activity tolerance, before treatment:
| | | | G1: 2
| | | | G2: 2
| | | | Decreased exercise/activity tolerance, 6 mos:
| | | | G1: 1
| | | | G2: 1
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Change in BMD, %: | Quality:
Palomba, Morelli, Di Carlo et al., 2002 | RCT | - Age >52 years; - No hormone therapy after menopause | NR | G1: 5.7^a^ | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 6.4^a^ | INTERNAL VALIDITY: fair
Italy, Academic medical center | Leuprolide acetate plus tibolone for 12 mos vs. hysterectomy with bilateral oophorectomy | - BMD <1.0 SD; - Medical illnesses with impact calcium metabolism; - Treatment with drugs for or interfering with bone metabolism; - BMI<18 or >30; - Cigarette use >20/day; - Alcohol > 3 drinks/day | NR | G3: 3.4^a,b^ | Random: +
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Change in Bone Alkaline Phosphatase, %: | Methods and blinding: -
NR | G1: Symptomatic fibroids treated with leuprolide acetate plus tibolone | NR | NR | G1: 33.5^a^ | Pt selection criteria: ++
Funding: | G2: Symptomatic fibroids treated with laparoscopic or laparotomic hysterectomy with bilateral oophorectomy | Preoperative therapy: | Type of fibroid: | G2: 36.7^a^ | Loss to follow-up: <10%
NR | G3: Non randomized comparison group of naturally postmenopausal women | See groups | NR | G3: 21.2^a,b^ | Drop-out rates: <5%
| N at enrollment: | Associated procedure(s): | | ^a^P < 0.05 vs baseline | Statistical issues: ++
| G1: 60 | NR | | ^b^P < 0.05 vs. G1&2 | EXTERNAL VALIDITY: fair (2)
| G2: 60 | | | No significant | Age: +, reported
| N at followup: | | | difference in BMD or in bone turnover markers was | Race: NA, not US study
| G1: 56 | | | detected between G1 and G2. | Pregnancy history: +, reported
| G2: 54 | | | The decrease in BMD and in bone turnover markers was statistically | Surgical history: -, NR
| Age, yrs ± SD: | | | significant (P < .05) when G1 & G2 were compared to G3. | Fibroid/uterine size: +
| G1: 53.9 ± 1.6 | | | Modifier: | Number of fibroids: NA
| G2: 53.1 ± 1.5 | | | NR | Location of fibroids: NA
| G3: 54.2 ± 1.8 | | | | Baseline characteristics: -, NR
| Race/Ethnicity: | | | | Length of follow-up: ++
| NR | | | | Measurement methods: +
| Parity (mean ± SD): | | | | Measurement reliability: +
| G1: 2.1 ± 1.6 | | | | Clinical care: +
| G2: 1.9 ± 1.9
| G3: 2.0 ± 1.7
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine size at 3 mos, cm^3^± SD: | Quality:
Palomba, Orio, Russo, et al., 2005 | RCT | - Natural menopause for 1 to 2 yrs; - 1 to 2 fibroids with at least 1 > 2 cm | G1: 313.1 ± 87.9 | G1: 274.9 ± 71.9 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 327.7 ± 89.8 | G2: 327.5 ± 90.7 | INTERNAL VALIDITY: good
Italy, Academic medical center | Raloxifene vs. placebo | - Neoplastic, metabolic, or infectious diseases; - Vascular thrombosis or coagulation abnormality; - BMI >30; - Use of hormone therapy in previous 6 mos; - Moderate or severe vasomotor symptoms | Number of fibroids: | G1 vs baseline: | Random: +
Enrollment period: | Groups: | Indications, N (%): | NR | P < 0.001 | Methods and blinding: +
NR | G1: 180 mg/day orally for 3 cycles of 28 days | Uterine prolapse: | Baseline fibroid size, cm^3^± SD: | G2 vs baseline: | Pt selection criteria: ++
Funding: | G2: 3 placebo tablets/day for 3 cycles of 28 days | G1: 16 (80) | G1: 141.7 ± 37.8 | P = 0.824 | Loss to follow-up: <10%
NR | N at enrollment: | G2: 17 (85.9) | G2: 150.3 ± 58.7 | G1 vs G2: | Drop-out rates: <5%
| G1: 20 | Complex endometrial hyperplasia: | Type of fibroid: | P = 0.048 | Statistical issues: ++
| G2: 20 | G1: 2 (10) | All intramural | Fibroid size at 3 mos, cm^3^± SD: | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | G2: 2 (10) | | G1: 116.3±27.4 | Age: +, reported
| NR | High-grade intrasquamous lesion: | | G2: 150.4±58.0 | Race: NA, not US study
| Age, yrs ± SD: | G1: 2 (10) | | G1 vs baseline: | Pregnancy history: +, reported
| G1: 53.4 ± 4.1 | G2: 1 (5) | | P < 0.001 | Surgical history: -, NR
| G2: 52.2 ± 4.0 | Preoperative therapy: | | G2 vs baseline: | Fibroid/uterine size: +
| Race/ethnicity: | NR | | P = 0.993 | Number of fibroids: -
| NR | Associated procedure(s): | | G1 vs G2: | Location of fibroids: -
| Parity, mean ± SD: | NR | | P = 0.022 | Baseline characteristics: +, reported
| G1: 2.2 ± 1.3 | | | Modifiers: | Length of follow-up: ++
| G2: 2.1 ± 1.2 | | | NR | Measurement methods: +
| Baseline Hgb/Hct: | | | | Measurement reliability: +
| NR | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine volume*: | Quality:
Palomba, Orio et al., 2002 | RCT | - Premenopausal women; - Symptomatic fibroids | G1: 473 ± 113 | G1 vs. baseline: | Overall quality score: fair
Palomba, Russo, Orio, Tauchmanova et al., 2002 | Intervention: | Exclusion criteria: | G2: 446 ± 105 | P < 0.05 | INTERNAL VALIDITY: good
Palomba, Orio, Russo, Falbo et al., 2004 | Leuprolide acetate depot and raloxifene hydrochloride vs. placebo | - Serious medical illness; - Vascular thrombosis; - BMD < 1 SD from mean peak value; - BMI <18 or >30; - Smoking >20 cigarettes/day; - Alcohol>3 drinks/day; - WHR > 0.8; - Hyper androgenemia; - Serum folate > 12.5 nmol/l; - Hyperhomo-cystenaemia | Number of fibroids: | G2 vs. baseline: | Random: +
Palomba, Russo et al., 2004 | Groups: | Indications, N: | NR | P < 0.05 | Methods and blinding: +
Country and setting: | G1: Leuprolide acetate depot 3.75 mg every 28 days and raloxifene hydrochloride 60 mg/d | - Menorrhagia: 50; - Pelvic pressure: 44; - Pelvic pain: 36; - Urinary frequency: 31; - Constipation: 11 | Baseline fibroid size, cm^3^± SD: | Fibroid volume*: | Pt selection criteria: ++
Italy, Academic medical center | G2: Leuprolide acetate depot 3.75 mg every 28 days and placebo each day | Preoperative therapy: | G1: 197 ± 61 | G1 vs. baseline: | Loss to follow-up: <10%
Enrollment period: | N at enrollment: | NA | G2: 189 ± 154 | P < 0.05 | Drop-out rates: <5%
06/2000 to 01/2001 | G1: 50 | Associated procedure(s): | Type of fibroid: | G2 vs. baseline: | Statistical issues: ++
Funding: | G2: 50 | NR | NR | P < 0.05 | EXTERNAL VALIDITY: poor (4)
NR | N at follow-up: | | | Menorrhagia, N %: | Age: +, reported
| NR | | | G1: 0(0)^a^ | Race: NA, not US study
| Age, yrs ± SD: | | | G2: 0(0)^a^ | Pregnancy history: +, reported
| G1: 49.1 ± 4.2 | | | Pelvic pressure, N %: | Surgical history: -, NR
| G2: 48.6 ± 3.9 | | | G1: 3 (6.7)^a^ | Fibroid/uterine size: +
| Race/ethnicity: | | | G2: 3 (6.5)^a^ | Number of fibroids: -
| NR | | | Pelvic pain, N %: | Location of fibroids: -
| Parity (mean ± SD): | | | G1: 2 (4.4)^a^ | Baseline characteristics: -, NR
| G1: 1.8 ± 1.4 | | | G2: 3 (6.5)^a^ | Length of follow-up: ++
| G2: 1.7 ± 1.3 | | | Urinary frequency, N %: | Measurement methods: +
| Baseline Hgb/Hct: | | | G1: 3 (6.7)^a^ | Measurement reliability: +
| NR | | | G2: 2 (4.3)^a^ | Clinical care: +
| | | | Constipation:
| | | | G1: 0 (0)^a^
| | | | G2: 0 (0)^a^
| | | | Change in BMD, Lumbar spine*:
| | | | G2 vs. baseline/G1:
| | | | P < 0.05
| | | | Change in BMD, Trochanter*:
| | | | G2 vs. baseline/G1:
| | | | P < 0.05
| | | | Change in BMD, Femoral Neck*:
| | | | G2 vs. baseline/G1:
| | | | P < 0.05
| | | | Change in TC (mmol/l)*:
| | | | G1: 0.26^a,b^
| | | | G2: 0.47^a^
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Operative time, min ± SD: | Quality:
Palomba, Pellicano et al., 2001 | RCT | - Infertility >3 years; - Recurrent miscarriage; - Increased vaginal bleeding; - Pelvic pressure and pain; - Urinary frequency; - Constipation; - Largest Intramural fibroid 400 to 500 cm^3^; - ≤ 3 fibroids | G1: 528 ± 83 | G1: 99.8 ± 22.7 | Overall quality score: fair
Palomba, Morelli, Noia, et al., 2002 | Intervention: | Exclusion criteria: | G2: 504 ± 92 | G2: 91.5 ± 17.6 | INTERNAL VALIDITY: good
Country and setting: | Leuprolide acetate, tibolone and iron vs. leuprolide acetate and iron vs. placebo prior to myomectomy | - Serious medical illnesses; - Submucosal fibroids; - Abnormal endometrial biopsy; - Abnormal pap smear; - Pregnant; - Calcification or hyperechoic fibroids | G3: 496 ± 99 | G3: 117.6 ± 16.1 | Random: +
Italy, Academic medical center | Groups: | Indications: | Number of fibroids, mean ± SD: | G1/G2 vs. G3: | Methods and blinding: +
Enrollment period: | G1: IM leuprolide acetate 3.75 mg q28d; iron 2 tablets daily; tibolone oral 2.5mg/d | NR | G1: 1.90 ± 0.9 | P < 0.05 | Pt selection criteria: ++
NR | G2: IM leuprolide acetate 3.75 mg q28d; iron 2 tablets daily; | Preoperative therapy: | G2: 2.0 ± 0.9 | G1 vs. G2: | Loss to follow-up: <10%
Funding: | G3: Iron tablets, 2 orally daily | See groups | G3: 1.9 ± 0.9 | P = NS | Drop-out rates: <5%
NR | N at enrollment: | Associated procedure(s): | Baseline fibroid size, cm^3^± SD: | Estimated blood loss, ml ± SD: | Statistical issues: ++
| G1: 22 | NR | G1: 179 ± 48 | G1: 186.8 ± 62.2 | EXTERNAL VALIDITY: fair (2)
| G2: 22 | | G2: 167 ± 41 | G2: 171.2 ± 64.3 | Age: +, reported
| G3: 22 | | G3: 163 ± 38 | G3: 245.8 ± 53.0 | Race: NA, not US study
| N at follow-up: | | Type of fibroid: | G1/G2 vs. G3: | Pregnancy history: +, reported
| G1: 20 | | All intramural | P < 0.05 | Surgical history: -, NR
| G2: 20 | | | G1 vs. G2: | Fibroid/uterine size: +
| G3: 21 | | | P = NS | Number of fibroids: +
| Age, yrs ± SD: | | | Hgb, Visit 2, g/dL ± SD: | Location of fibroids: -
| G1: 24.9 ± 3.9 | | | G1: 13.6 ± 0.9^a^ | Baseline characteristics: +, reported
| G2: 27.0 ± 3.3 | | | G2: 13.5 ± 0.9^a^ | Length of follow-up: ++
| G3: 26.6 ± 4.1 | | | G3: 12.1 ± 1.5^c^ | Measurement methods: +
| Race/ethnicity: | | | Hgb, Visit 3, g/dL ± SD: | Measurement reliability: +
| NR | | | G1: 12.0 ± 0.8^b^ | Clinical care: +
| Parity: | | | G2: 12.2 ± 0.8^b^
| NR | | | G3: 10.7 ± 1.1^b,c^
| Baseline Hgb, g/dL ± SD: | | | Uterine volume, Visit 2, cm^3^± SD:
| G1: 12.2 ± 1.6 | | | G1: 373 ± 51^a^
| G2: 11.9 ± 1.5 | | | G2: 337 ± 50^a^
| G3: 12.4 ± 1.7 | | | G3: 498 ± 97^c^
| | | | Uterine volume, Visit 3, cm^3^± SD:
| | | | G1: 198 ± 27^a,b^
| | | | G2: 193 ± 18^a,b^
| | | | G3: 201 ± 19^a,b^
| | | | Fibroid Volume, Visit 2, cm^3^± SD:
| | | | G1: 130 ± 31^a^
| | | | G2:113 ± 23^a^
| | | | G3:164 ± 39^c^
| | | | ^a^P < 0.05 vs. Visit 1
| | | | ^b^P < 0.05 vs. Visit 2
| | | | ^c^P < 0.05 vs. G1 &
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine and fibroid size: | Quality:
Palomba, Sammartino et al., 2001 | RCT | - Natural menopause for 1 to 2 yrs; - 1 to 2 fibroids with at least 1 > 2 cm | G1: 295.6 ± 81.0 | After 6, 9, and 12 cycles of treatment a reduction in mean uterine and fibroid size was observed in comparison to baseline and between groups | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 316.6 ± 113.7 | (P < 0.05)* | INTERNAL VALIDITY: good
Italy, Academic medical center | Raloxifene vs. placebo | - Neoplastic, metabolic or infectious disease; - Vascular thrombosis or coagulation abnormality; - BMI >30; - Hormone therapy in prior 6 mons; - Moderate or severe vasomotor symptoms | Number of fibroids: | Amenorrhea | Random: +
Enrollment period: | Groups: | Indications: | NR | 3 mo, %: | Methods and blinding: +
NR | G1: 60 mg/day × 12 cycles | NR | Baseline fibroid size, cm^3^± SD: | G1: 83.9 | Pt selection criteria: ++
Funding: | G2: 60 mg/day placebo × 12 cycles | Preoperative therapy: | G1: 127.1 ± 38.2 | G2: 82.8 | Loss to follow-up: <10%
NR | N at enrollment: | NR | G2: 138.5 ± 55.7 | P = NS | Drop-out rates: 5–10%
| G1: 35 | Associated procedure(s): | Type of fibroid: | 6 mo, %: | Statistical issues: ++
| G2: 35 | NR | NR | G1: 84.9 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | | | G2: 84.9 | Age: +, reported
| G1: 31 | | | P = NS | Race: NA, not US study
| G2: 31 | | | 9 mo, %: | Pregnancy history: +, reported
| Age, yrs ± SD: | | | G1: 82.8 | Surgical history: -, NR
| G1: 54.2±4.9 | | | G2: 83.9 | Fibroid/uterine size: +
| G2: 51.2±3.9 | | | P = NS | Number of fibroids: -
| Race/ethnicity: | | | 12 mo, %: | Location of fibroids: -
| NR | | | G1: 88.1 | Baseline characteristics: +, reported
| Parity, mean ± SD: | | | G2: 86.0 | Length of follow-up: ++
| G1: 2.0 ± 1.5 | | | P = NS | Measurement methods: +
| G2: 2.1 ± 1.7 | | | AUB episodes, mean ± SD: | Measurement reliability: +
| Baseline Hgb/Hct: | | | At 3 mos | Clinical care: +
| NR | | | G1: 1.40 ± 0.63
| | | | G2: 1.40 ± 0.63
| | | | P =NS
| | | | At 6 mos
| | | | G1: 1.29 ± 0.47
| | | | G2: 1.38 ± 0.62
| | | | P =NS
| | | | At 9 mos
| | | | G1: 1.13 ± 0.34
| | | | G2: 1.20 ± 0.41
| | | | P =NS
| | | | AUB episodes, mean ± SD:
| | | | At 12 months
| | | | G1: 1.18 ± 0.41
| | | | G2: 1.15 ± 0.38
| | | | P =NS
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Fibroid size | Quality:
Palomba, Sena, et al., 2001 | Prospective cohort | - Natural menopause for 1 to 2 yrs; - 1 to 2 intramural or subserosal uterine fibroids, with at least one >2 cm | G1: 313.1 ± 83.9 | 3rd cycle, cm^3^ ± SD: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 327.7 ± 89.9 | G1: 143.9±38.8 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Transdermal estradiol (E_2_) and Medroxyprogest-erone Acetate (MPA) | - Neoplastic, metabolic or infectious diseases; - Vascular thrombosis; - BMI > 30; - Hormonal therapy in prior 6 mos; - Endometrial abnormalities by ultrasound; - Endometrial thickness > 5 mm; - Hypoechoic or calcified fibroids | G3: NA | G2: 153.1±62.1 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids: | P = NS | Methods and blinding: NA
NR | G1: women with fibroids, 50 μg/day transdermal E_2_ + 2.5 mg/day MPA X 12 cycles | NR | NR | 6th cycle, cm^3^ ± SD: | Pt selection criteria: ++
Funding: | G2: women with fibroids, 1 tablet calcium carbonate per day X 12 cycles | Preoperative therapy: | Baseline fibroid size, cm^3^± SD: | G1: 146.6±45.5 | Loss to follow-up: <10%
NR | G3: women without fibroids, 50 μg/day transdermal E_2_ + 2.5 mg/day MPA X 12 cycles | NR | G1: 141.7 ± 37.8 | G2: 155.3±64.7 | Drop-out rates: 5–10%
| N at enrollment: | Associated procedure(s): | G2: 150.3 ± 58.7 | P = NS | Statistical issues: +
| G1: 35 | NR | G3: NA | 9th cycle, cm^3^ ± SD: | EXTERNAL VALIDITY: fair (3)
| G2: 35 | | Type of fibroid: | G1: 147.1±49.1 | Age: +, reported
| G3: 35 | | NR | G2: 155.4±68.6 | Race: NA, not US study
| N at follow-up: | | | P = NS | Pregnancy history: +, reported
| G1: 31 | | | 12th cycle, cm^3^ ± SD: | Surgical history: -, NR
| G2: 31 | | | G1: 147.5±53.3 | Fibroid/uterine size: +
| G3: 30 | | | G2: 156.0±72.5 | Number of fibroids: -
| Age, yrs ± SD: | | | P = NS | Location of fibroids: -
| G1: 53.8 ± 3.8 | | | No significant difference in bleeding patterns between G1 and G2 | Baseline characteristics: +, reported
| G2: 52.4 ± 3.7 | | | Amenorrhea, at cycle 3, G1 and G3 less prevalent that G2 (P < 0.05) | Length of follow-up: ++
| G3: 54 ± 3.8 | | | Abnormal uterine bleeding episodes at cycle 3, G1 and G3 more severe than G2 | Measurement methods: +
| Race/ethnicity: | | | (P < 0.05) | Measurement reliability: +
| NR | | | By 6th, 9th, and 12th treatment cycles bleeding pattern was not significantly different between 3 groups | Clinical care: +
| Parity. mean ± SD: | | | Modifiers:
| G1: 2.1 ± 1.7 | | | NR
| G2: 2.2 ± 1.6
| G3: 2.1 ± 1.7
| Baseline Hgb/Hct:
| NR

a P < 0.005 vs. baseline

b P <0.05 versus Group 2

* Tabular data only

* Graphs, not quantitative data provided

Evidence Table 3. KQ 2 Pharmaceutical management

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size, mm ± SD: | Operative time, min ± SD: | Quality:
Campo et al., 2005 | Retrospective cohort | - Premenopausal; - Undergoing myomectomy; - Diagnosis by transvaginal ultrasound and confirmed by diagnostic hysteroscopy | NR | G1: 57.65 ± 29.61 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed, mean ± SD: | G2: 40 ± 18.06 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Two month pretreatment with triptorelin, Decapeptyl 3.75 mg followed by resectoscopic myomectomy | NR | G1: 1.09 ± 0.29 | P = 0.002 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 1.1 ± 0.53 | Hemorrhage, N: | Methods and blinding: NA
NR | G1: Triptorelin 3.75 mg | Abnormal uterine bleeding: | Baseline fibroid size: | G1: 0 | Pt selection criteria: +
Funding: | G2: No pretreatment | G1: 30 (79) | G1: 29.73 ± 14.47 | G2: 0 | Loss to follow-up: <10%
NR | N at enrollment: | G2: 33 (79) | G2: 28.72 ± 11.57 | Uterine perforation, N: | Drop-out rates: NA
| G1: 38 | Pre-operative therapy: | Type of fibroid, N: | G1: 0 | Statistical issues: -
| G2: 42 | See groups | Completely intracavitary: | G2: 1 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | Associated procedure(s): | G1: 15 | P = NS | Age: +, reported
| G1: 38 | NR | G2: 16 | Length of stay, days ± SD: | Race: NA, not US study
| G2: 42 | | Intramural extension < 50%: | G1: 1.15 ± 0.44 | Pregnancy history: +, reported
| Age, yrs ± SD: | | G1: 20 | G2: 1.05 ± 0.22 | Surgical history: -, NR
| G1: 38.97 ± 7.46 | | G2: 23 | P = NS | Fibroid/uterine size: +
| G2: 38.8 ± 5.39 | | Intramural extension ≥ 50%: | Fibroid recurrence in 24 mos, N (%): | Number of fibroids: +
| Race/Ethnicity: | | G1: 7 | G1: 2 (5.26) | Location of fibroids: +
| NR | | G2: 9 | G2: 3 (7.1) | Baseline characteristics: +, reported
| Parity, parous, N (%): | | | P = 0.908 | Length of follow-up: ++
| G1: 26 (68.4) | | | Recurrence of abnormal uterine bleeding, N (%): | Measurement methods: +
| G2: 28 (66) | | | G1: 8/30 (26.6) | Measurement reliability: +
| Baseline Hgb/Hct: | | | G2: 12/33 (36.3) | Clinical care: +
| NR | | | P = 0.57
| | | | Repeat hysteroscopy, N:
| | | | G1/G2: 2
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine Size, cm^3^± SD: | Quality:
Di Lieto, De Falco, Mansueto et al., 2005 | RCT | - Pre-menopausal women; - Symptomatic fibroids | G1: 992.7 ± 115.9 | G1: 584 ± 87.3 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 977.1 ± 104.7 | G2: 569 ± 84.8 | INTERNAL VALIDITY: poor
Italy, Academic medical center | Medical management with GnRH-a (Leuprorelin acetate 3.75 mg subcutaneously every month) | - Hormonal therapy; - Delivery; - Uterine surgery within 12 mos prior to study | G3: NR | G3: NR | Random: -
Enrollment period: | Groups: | Indications: | Number of fibroids: | G1 vs G2: | Methods and blinding: +
NR | G1: GnRH-a plus tibolone | NR | NR | P > 0.05 | Pt selection criteria: +
Funding: | G2: GnRH-a | Pre-operative therapy: | Baseline fibroid size: | Hgb, g/dL ± SD: | Loss to follow-up: <10%
NR | G3: Control | See groups | NR | G1: 12.4 ± 1.6 | Drop-out rates: <5%
| N at enrollment: | Associated procedure(s): | Type of fibroid: | G2: 9.1 ± 1.2 | Statistical issues: +
| G1: 22 | Myomectomy, hysterectomy or hysteroscopic resection | NR | G3: NR | EXTERNAL VALIDITY: poor (5)
| G2: 23 | | | G1 vs. G2: | Age: +, reported
| G3: 28 | | | P > 0.05 | Race: NA, not US study
| N at follow-up: | | | Menorrhagia, using VAS at baseline: | Pregnancy history: -, NR
| 70 | | | G1: 6.9 ± 1.1 | Surgical history: +, reported
| Age: | | | G2: 7.2 ± 1.3 | Fibroid/uterine size: +
| G1: 36.8 ± 4.1 | | | P > 0.05 | Number of fibroids: -
| G2: 37.2 ± 3.9 | | | No menorrhagic at followup | Location of fibroids: -
| G3: NR | | | Pelvic pain, using VAS at baseline: | Baseline characteristics: -, NR
| Race/ethnicity: | | | G1: 3.9 ± 1.2 | Length of follow-up: +
| NR | | | G2: 4.1 ± 1.5 | Measurement methods: +
| Parity: | | | P > 0.05 | Measurement reliability: +
| NR | | | No pelvic pain at followup | Clinical care: -
| Baseline Hgb, g/dL ± SD: | | | Hot flashes (data presented graphically)
| G1: 9.1 ± 1.2 | | | G1: No change
| G2: 9.5 ± 0.9 | | | G2: Increase over time
| G3: NR | | | P significant value NR
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Hgb, after therapy, g/dL ± SD: | Quality:
Di Lieto, De Falco, Pollio et al., 2005 | Prospective cohort | - Pre-menopausal; - Symptomatic fibroids | G1: 725.6 ± 193.5 | G1: 12.8 ± 0.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 762.7 ± 201.2 | G2: NA | INTERNAL VALIDITY: good
Italy, Academic medical center | Medical management followed by uterine surgery | - Malignant neoplasm | Number of fibroids: | Hgb, after surgery, g/dL ± SD: | Random: NA
Enrollment period: | Groups: | In last 12 mos: | NR | G1: 11.3 ± 0.5 | Methods and blinding: NA
NR | G1: Leuprolide acetate depot injections for 3 mos | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | G2: 6.5 ± 0.8 | Pt selection criteria: +
Funding: | G2: No pretreatment | Indications: | NR | Uterine volume, cm^3^± SD: | Loss to follow-up: <10%
Italian Ministry of University and Scientific Research | N at enrollment: | NR | Type of fibroid: | G1: 492.7±134.2 | Drop-out rates: <5%
| G1: 31 | Preoperative therapy: | NR | G2: N/A | Statistical issues: +
| G2: 55 | See Groups | | Modifiers: | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Additional procedures: | | NR | Age: +, reported
| NR | NR | | | Race: NA, not US study
| Age, yrs ± SD: | | | | Pregnancy history: +, reported
| G1: 37.5 ± 3.9 | | | | Surgical history: +, reported
| G2: 38.1 ± 3.5 | | | | Fibroid/uterine size: +
| Race/ethnicity: | | | | Number of fibroids: -
| NR | | | | Location of fibroids: -
| Parity, mean ± SD: | | | | Baseline characteristics: +, reported
| G1: 2.2 ± 1.4 | | | | Length of follow-up: +
| G2: 2.1 ± 1.6 | | | | Measurement methods: +
| Baseline Hgb, g/dL ± SD: | | | | Measurement reliability: +
| G1: 7.6 ± 0.3 | | | | Clinical care: -
| G2: 7.8 ± 0.5
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine size: | Quality:
Di Lieto, De Falco, Staibano et al., 2003 | Prospective cohort | - Pre-menopausal; - Fibroids present | G1: 774.5 ± 203.1 | G1: 484.9 ± 144.5 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 804.7 ± 233.7 | G2: N/A | INTERNAL VALIDITY: good
Italy, Academic medical center | Monthly subcutaneous leuprorelin acetate depot 3.75 mg for 3 cycles prior to myomectomy or hysterectomy | - Malignant neoplasm | Number of fibroids: | P < 0.05 | Random: NA
Enrollment period: | Groups: | In last 12 mos: | NR | “Quickscore”* for bFGF: | Methods and blinding: NA
NR | G1: Leuprorelin acetate depot 3.75 mg | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | G1: 7.96 ± 2.22 | Pt selection criteria: +
Funding: | G2: No medical intervention women | Indications: | NR | G2: 9.61 ± 2.54 | Loss to follow-up: <10%
NR | N at enrollment: | NR | Type of fibroid: | P < 0.05 | Drop-out rates: <5%
| G1: 25 | Preoperative therapy: | NR | Modifiers: | Statistical issues: +
| G2: 46 | See Groups | | NR | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Additional procedures: | | | Age: +, reported
| G1: 25 | NR | | | Race: NA, not US study
| G2: 46 | | | | Pregnancy history: +, reported
| Age, yrs ± SD: | | | | Surgical history: +, reported
| G1: 38.4 ± 4.3 | | | | Fibroid/uterine size: +
| G2: 37.9 ± 3.5 | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: +, reported
| Parity, mean ± SD: | | | | Length of follow-up: +
| G1: 2.3 ± 1.4 | | | | Measurement methods: +
| G2: 1.9 ± 1.5 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: -
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine Size, cm^3^± SD: | Quality:
Di Lieto, De Rosa et al., 2002 | Prospective cohort | - Pre-menopausal; - Symptomatic fibroids | G1: 571.3 ± 266.7 | G1: 413.4 ± 217 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 540.4 ± 250.8 | G2: 601.1 ± 241.3 | INTERNAL VALIDITY: good
Italy, Academic medical center | Monthly subcutaneous leuprorelin acetate depot 3.75 mg for 3 cycles prior to myomectomy | - Malignant neoplasm | Number of fibroids: | Modifiers: | Random: NA
Enrollment period: | Groups: | In last 12 mos: | NR | NR | Methods and blinding: NA
NR | G1: Leuprorelin acetate depot 3.75 mg | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | | Pt selection criteria: +
Funding: | G2: No medical intervention | Indications: | NR | | Loss to follow-up: <10%
NR | N at enrollment: | NR | Type of fibroid: | | Drop-out rates: <5%
| G1: 39 | Preoperative therapy: | NR | | Statistical issues: +
| G2: 31 | See Groups | | | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | Additional procedures: | | | Age: +, reported
| G1: 39 | NR | | | Race: NA, not US study
| G2: 31 | | | | Pregnancy history: +, reported
| Age, yrs ± SD: | | | | Surgical history: NA
| G1: 36.1 ± 3.2 | | | | Fibroid/uterine size: +
| G2: 37.3 ± 3.7 | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: -, NR
| Parity, mean ± SD: | | | | Length of follow-up: +
| G1: 2.2 ± 1.8 | | | | Measurement methods: +
| G2: 1.9 ± 1.8 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: -
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine volume, cm^3^± SD: | Quality:
Di Lieto, Iannotti et al., 2003 | Prospective cohort | - Pre-menopausal; - Symptomatic fibroids | G1: 675.8 ± 176 | G1: 466.6 ± 113.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 646.9 ± 191.4 | G2: NR | INTERNAL VALIDITY: good
Italy, Academic medical center | Monthly subcutaneous leuprorelin acetate depot 3.75 mg for 3 cycles prior to myomectomy | - Malignant neoplasm | Number of fibroids: | P < 0.05 | Random: NA
Enrollment period: | Groups: | In last 12 mos: | NR | Modifiers: | Methods and blinding: NA
NR | G1: Leuprorelin acetate depot 3.75 mg | - Received hormonal therapy; - Delivered; - Underwent uterine surgery | Baseline fibroid size: | NR | Pt selection criteria: +
Funding: | G2: No medical intervention | Indications: | NR | | Loss to follow-up: NR
NR | N at enrollment: | NR | Type of fibroid: | | Drop-out rates: NR
| G1: 48 | Preoperative therapy: | NR | | Statistical issues: +
| G2: 41 | See Groups | | | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Additional procedures: | | | Age: +, reported
| G1: 48 | NR | | | Race: NA, not US study
| G2: 41 | | | | Pregnancy history: +, reported
| Age, yrs ± SD: | | | | Surgical history: +, reported
| G1: 38 ± 4 | | | | Fibroid/uterine size: +
| G2: 38.8 ± 3.7 | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: +, reported
| Parity, mean ± SD: | | | | Length of follow-up: +
| G1: 2.2 ± 1.8 | | | | Measurement methods: +
| G2: 1.5 ± 1.3 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: -
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Fibroid volume: | Quality:
Donnez et al., 2003 | RCT | - Pre-menopausal; - Uterine fibroids requiring hysterectomy; - Willing to use barrier contraception for 4 weeks before and during presurgical stage of trial; - Not involved in night-shift work | Numerical values not reported | G1 vs. G5: P = 0.833 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2 vs. G5: P = 0.938 | INTERNAL VALIDITY: poor
Multinational, Academic medical centers | Medical management with anti-estrogen and GnRH-a followed by hysterectomy | - Previously received >3mos GnRHa; - Completed GnRHa treatment within 3 mos of study; - Received sex-hormone therapy, used OCP, or danazol within 4 weeks of study; - History of disease affecting bone or steroid metabolism; - Change in menstrual frequency or changes related to onset of menopause | NR | G3 vs. G5: P = 0.506 | Random: -
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | G1 vs. G4: P = 0.001 | Methods and blinding: -
NR | G1: Fulvestrant 50 mg IM injection monthly × 3 | NR | NR | G2 vs. G4: P = 0.0002 | Pt selection criteria: +
Funding: | G2: Fulvestrant 125 mg IM monthly × 3 | Preoperative therapy: | Type of fibroid: | G3 vs. G4: P = 0.023 | Loss to follow-up: <10%
AstraZeneca Pharmaceuticals | G3: Fulvestrant 250 mg IM monthly × 3 | NR | NR | Endometrial thickness: | Drop-out rates: 5–10%
| G4: Goserelin 3.6 mg SC × 3 | Associated procedure(s): | | G1 vs. G5: P = 0.468 | Statistical issues: +
| G5: No treatment | NR | | G2 vs. G5: P = 0.868 | EXTERNAL VALIDITY: poor (5)
| N at enrollment: | | | G3 vs. G5: P = 0.755 | Age: +, reported
| G1: 59 | | | G1 vs. G4: P = 0.025 | Race: NA, not US study
| G2: 66 | | | G2 vs. G4: P = 0.002 | Pregnancy history: -, NR
| G3: 62 | | | G3 vs. G4: P = 0.009 | Surgical history: NA
| G4: 66 | | | Uterine Volume: | Fibroid/uterine size: +
| G5: 60 | | | Numerical values not reported | Number of fibroids: -
| N at follow-up: | | | G3/G4 superior, G4 > G3 | Location of fibroids: -
| G1: 55 | | | Modifiers: | Baseline characteristics: -, NR
| G2: 63 | | | NR | Length of follow-up: +
| G3: 61 | | | | Measurement methods: +
| G4: 62 | | | | Measurement reliability: +
| G5: 60 | | | | Clinical care: -
| Age, yrs ± SD:
| G1: 44.0 ± 4.0
| G2: 44.0 ± 4.4
| G3: 44.0 ± 4.5
| G4: 44.0 ± 4.0
| G5: 44.0 ± 5.1
| Race/ethnicity:
| NR
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cc ± SD: | Outcomes at 2 mos: | Quality:
Eisinger et al., 2003 | RCT | - Premenopausal; - Symptomatic fibroid(s); - Uterine volume ≥ 300 cc by U/S; - Use non-hormonal contraception; - Indications for hysterectomy | G1: 832 ± 443 | Uterine volume, cc: | Overall quality score: fair
Eisinger et al., 2005 | Intervention: | Exclusion criteria: | G2: 850 ± 380 | G1: 660 | INTERNAL VALIDITY: fair
Country and setting: | Oral mifepristone daily | - Pregnancy or attempting pregnancy; - FSH > 11.6 mIU/mL; - Breast-feeding; - Adnexal masses; - Abnormal vaginal bleeding; - Suspected/ diagnosed gynecologic cancer; - Contraindications to mifepristone; - Anticoagulants; - Herbals or botanicals with hormonal effects; - Oral contraception, hormone replacement therapy, GnRH analogues, or depomedroxyprogesterone in prior 6 mos | Number of fibroids: | G2: 640 | Random: +
US, Community | Groups: | Indications: | NR | P comparison to baseline: | Methods and blinding: -
Enrollment period: | G1: 5 mg/day po mifepristone | NR | Baseline fibroid size: | G1: 0.003 | Pt selection criteria: ++
10/2000 to 04/2001 | G2: 10 mg/day po mifepristone | Preoperative therapy: | NR | G2: <0.001 | Loss to follow-up: <10%
Funding: | N at enrollment: | NR | Type of fibroid: | Outcomes at 4 mos: | Drop-out rates: <5%
David and Lucille Packard Foundation and the Abortion Rights Mobilization | G1: 20 | Associated procedure(s): | NR | Uterine volume, cc: | Statistical issues: ++
| G2: 20 | NR | | G1: 498 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | | | G2: 539 | Age: +, reported
| 6 mos: | | | P comparison to baseline: | Race: +, reported
| G1: 18 | | | G1:<0.001 | Pregnancy history: +, reported
| G2: 20 | | | G2:<0.001 | Surgical history: -, NR
| 12 mos: | | | Outcomes at 6 mos: | Fibroid/uterine size: +
| G1: 8 | | | Uterine volume, mean cc: | Number of fibroids: -
| G2: 10 | | | G1: 435 | Location of fibroids: -
| Age, yrs ± SD: | | | G2: 438 | Baseline characteristics: +, reported
| G1: 43.9 ± 5.1 | | | Decrease in volume, mean cc: | Length of follow-up: +
| G2: 41.1 ± 5.3 | | | G1: -400 | Measurement methods: +
| Race/ethnicity, N (%): | | | G2: -416 | Measurement reliability: +
| White: | | | P comparison to baseline: | Clinical care: +
| G1: 13 (65) | | | G1: < 0.001
| G2: 12 (60) | | | G2: < 0.001
| Black: | | | Amenorrhea:
| G1: 5 (25) | | | G1: 61%
| G2: 8 (40) | | | G2: 65%
| Hispanic: | | | Menstrual blood loss index score, mean:
| G1: 1 (5) | | | G1: 10.9
| G2: 0 | | | (95% CI, 5.8–15.9)
| Asian: | | | G2: 5.9
| G1: 1 (5) | | | (95% CI, 1.0–10.7)
| G2: 0 | | | P NS, value NR
| Parity, mean ± SD: | | | Simple hyperplasia on biopsy:
| G1: 0.4 ± 0.8 | | | G1: 0
| G2: 0.4 ± 0.7 | | | G2: 5
| Baseline Hgb, g/dL: | | | Outcomes at 12 mos:
| G1: 12 ± 2.3 | | | Change in uterine volume, cc:
| G2: 12.2 ± 2.1 | | | All: -439
| | | | (95% CI, -563 – 316)
| | | | Amenorrhea,%:
| | | | G1: 40%
| | | | G2: 70%
| | | | Simple hyperplasia on biopsy, N:
| | | | G1: 0
| | | | G2: 1
| | | | (No atypia in any biopsies)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Litta et al., 2005 | Retrospective cohort | - Reproductive age; - Single fibroid ≤ 4cm; - Undergoing laparoscopic myomectomy | NR | G1: 96.0 ± 38.5 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed, N: | G2: 103.9 ± 33.8 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Treatment with GnRH analog for 3 months prior to laparoscopic myomectomy | - Intrauterine lesions | G1: 30 | P = NS | Random: NA
Enrollment period: | Groups: | Indications: | G2: 30 | Mean estimated blood loss, ml ± SD: | Methods and blinding: NA
01/2000 to 9/2003 | G1: GnRH analog for 3 months | NR | Baseline fibroid size, ml ± SD: | G1: 201.7 ± 209.4 | Pt selection criteria: +
Funding: | G2: No treatment prior to myomectomy | Pre-operative therapy: | G1: 494.4 ± 488.7 | G2: 203.8 ± 193.9 | Loss to follow-up: NA
NR | N at enrollment: | See groups | G2: NR | P = NS | Drop-out rates: NA
| G1: 30 | Associated procedure(s): | Type of fibroid: | Conversion to laparotomy, N (%): | Statistical issues: -
| G2: 30 | NR | NR | G1: 1 (3.3) | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | G2: 0 | Age: +, reported
| G1: 30 | | | Length of stay, days ± SD: | Race: NA, not US study
| G2: 30 | | | G1: 1.6 ±1.3 | Pregnancy history: -, NR
| Age, yrs ± SD: | | | G2: 1.7 ± 1.6 | Surgical history: -, NR
| G1: 39.2 ± 6.1 | | | P = NS | Fibroid/uterine size: +
| G2: 38.9 ± 5.4 | | | Fever > 38°C, N (%): | Number of fibroids: -
| Race/Ethnicity: | | | G1: 2 (6.6) | Location of fibroids: -
| NR | | | G2: 1 (3.3) | Baseline characteristics: -, NR
| Parity: | | | Fibroid volume vs. baseline, ml ± SD: | Length of follow-up: NA
| NR | | | G1: 369.2 ± 358.9 | Measurement methods: +
| Baseline Hgb/Hct: | | | G2: 397.7 ± 409.2 | Measurement reliability: +
| NR | | | P < 0.001 | Clinical care: -
| | | | Decrease in fibroid volume, ml ± SD:
| | | | G1: 125.2 ± 159.8
| | | | G2: NR
| | | | Modifiers:
| | | | Increasing fibroid volume and weight associated with blood loss, and operating time within and across groups
| | | | (P < 0.0001).
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Change in BMD, %: | Quality:
Palomba, Morelli, Di Carlo et al., 2002 | RCT | - Age > 52 yr; - No hormone therapy after menopause | NR | G1: 5.7^a^ | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 6.4^a^ | INTERNAL VALIDITY: fair
Italy, Academic medical center | Leuprolide acetate plus tibolone for 12 mos vs. hysterectomy with bilateral oophorectomy | - BMD <1.0 SD; - Medical illnesses with impact calcium metabolism; - Treatment with drugs for or interfering with bone metabolism; - BMI < 18 or >30; - Cigarette use >20/day; - Alcohol > 3 drinks/day | NR | G3: 3.4^a,b^ | Random: +
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Change in Bone Alkaline Phosphatase, %: | Methods and blinding: -
NR | G1: Symptomatic fibroids treated with leuprolide acetate plus tibolone | NR | NR | G1: 33.5^a^ | Pt selection criteria: ++
Funding: | G2: Symptomatic fibroids treated with laparoscopic or laparotomic hysterectomy with bilateral oophorectomy | Preoperative therapy: | Type of fibroid: | G2: 36.7^a^ | Loss to follow-up: <10%
NR | G3: Non randomized comparison group of naturally postmenopausal women | See groups | NR | G3: 21.2^a,b^ | Drop-out rates: <5%
| N at enrollment: | Associated procedure(s): | | ^a^P < 0.05 vs. baseline | Statistical issues: ++
| G1: 60 | NR | | ^b^P < 0.05 vs. G1&2 | EXTERNAL VALIDITY: fair (2)
| G2: 60 | | | Modifiers: | Age: +, reported
| N at followup: | | | No significant | Race: NA, not US study
| G1: 56 | | | difference in BMD or in bone turnover markers was detected between G1 and G2 | Pregnancy history: +, reported
| G2: 54 | | | The decrease in BMD and in bone turnover markers was statistically significant | Surgical history: -, NR
| Age, yrs ± SD: | | | (P < .05) when G1 & G2 were compared to G3 | Fibroid/uterine size: +
| G1: 53.9 ± 1.6 | | | | Number of fibroids: NA
| G2: 53.1 ± 1.5 | | | | Location of fibroids: NA
| G3: 54.2 ± 1.8 | | | | Baseline characteristics: -, NR
| Race/ethnicity: | | | | Length of follow-up: ++
| NR | | | | Measurement methods: +
| Parity, mean ± SD: | | | | Measurement reliability: +
| G1: 2.1 ± 1.6 | | | | Clinical care: +
| G2: 1.9 ± 1.9
| G3: 2.0 ± 1.7
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Operative time, min ± SD: | Quality:
Palomba, Pellicano et al., 2001 | RCT | - Infertility >3 years; - Recurrent miscarriage; - Increased vaginal bleeding; - Pelvic pressure and pain; - Urinary frequency; - Constipation; - Largest Intramural fibroid 400 to 500 cm^3^; - ≤ 3 fibroids | G1: 528 ± 83 | G1: 99.8 ± 22.7 | Overall quality score: fair
Palomba, Morelli, Noia, et al., 2002 | Intervention: | Exclusion criteria: | G2: 504 ± 92 | G2: 91.5 ± 17.6 | INTERNAL VALIDITY: good
Country and setting: | Leuprolide acetate, tibolone and iron vs. leuprolide acetate and iron vs. placebo prior to myomectomy | - Serious medical illnesses; - Submucosal fibroids; - Abnormal endometrial biopsy; - Abnormal pap smear; - Pregnant; - Calcification or hyperechoic fibroids | G3: 496 ± 99 | G3: 117.6 ± 16.1 | Random: +
Italy, Academic medical center | Groups: | Indications: | Number of fibroids, mean ± SD: | G1/G2 vs. G3: | Methods and blinding: +
Enrollment period: | G1: IM leuprolide acetate 3.75 mg q28d; iron 2 tablets daily; tibolone oral 2.5mg/d | NR | G1: 1.90 ± 0.9 | P < 0.05 | Pt selection criteria: ++
NR | G2: IM leuprolide acetate 3.75 mg q28d; iron 2 tablets daily; | Preoperative therapy: | G2: 2.0 ± 0.9 | G1 vs. G2: | Loss to follow-up: <10%
Funding: | G3: Iron tablets, 2 orally daily | See groups | G3: 1.9 ± 0.9 | P = NS | Drop-out rates: <5%
NR | N at enrollment: | Associated procedure(s): | Baseline fibroid size, cm^3^± SD: | Estimated blood loss, ml ± SD: | Statistical issues: ++
| G1: 22 | NR | G1: 179 ± 48 | G1: 186.8 ± 62.2 | EXTERNAL VALIDITY: fair (2)
| G2: 22 | | G2: 167 ± 41 | G2: 171.2 ± 64.3 | Age: +, reported
| G3: 22 | | G3: 163 ± 38 | G3: 245.8 ± 53.0 | Race: NA, not US study
| N at follow-up: | | Type of fibroid: | G1/G2 vs. G3: | Pregnancy history: +, reported
| G1: 20 | | All intramural | P < 0.05 | Surgical history: -, NR
| G2: 20 | | | G1 vs. G2: | Fibroid/uterine size: +
| G3: 21 | | | P = NS | Number of fibroids: +
| Age, yrs ± SD: | | | Hgb, Visit 2, g/dL ± SD: | Location of fibroids: -
| G1: 24.9 ± 3.9 | | | G1: 13.6 ± 0.9^a^ | Baseline characteristics: +, reported
| G2: 27.0 ± 3.3 | | | G2: 13.5 ± 0.9^a^ | Length of follow-up: ++
| G3: 26.6 ± 4.1 | | | G3: 12.1 ± 1.5^c^ | Measurement methods: +
| Race/ethnicity: | | | Hgb, Visit 3, g/dL ± SD: | Measurement reliability: +
| NR | | | G1: 12.0 ± 0.8^b^ | Clinical care: +
| Parity: | | | G2: 12.2 ± 0.8^b^
| NR | | | G3: 10.7 ± 1.1^b,c^
| Baseline Hgb, g/dL ± SD: | | | Uterine volume, Visit 2, cm^3^± SD:
| G1: 12.2 ± 1.6 | | | G1: 373 ± 51^a^
| G2: 11.9 ± 1.5 | | | G2: 337 ± 50^a^
| G3: 12.4 ± 1.7 | | | G3: 498 ± 97^c^
| | | | Uterine volume, Visit 3, cm^3^± SD:
| | | | G1: 198 ± 27^a,b^
| | | | G2: 193 ± 18^a,b^
| | | | G3: 201 ± 19^a,b^
| | | | Fibroid Volume, Visit 2, cm^3^± SD:
| | | | G1: 130 ± 31^a^
| | | | G2:113 ± 23^a^
| | | | G3:164 ± 39^c^
| | | | ^a^P < 0.05 vs. Visit 1
| | | | ^b^P < 0.05 vs. Visit 2
| | | | ^c^P < 0.05 vs. G1 & G2
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine volume*: | Quality:
Palomba, Orio et al., 2002 | RCT | - Premenopausal women; - Symptomatic fibroids | G1: 473 ± 113 | G1 vs. baseline: | Overall quality score: fair
Palomba, Russo, Orio, Tauchmanova et al., 2002 | Intervention: | Exclusion criteria: | G2: 446 ± 105 | P < 0.05 | INTERNAL VALIDITY: good
Palomba, Orio, Russo, Falbo et al., 2004 | Leuprolide acetate depot and raloxifene hydrochloride vs. placebo | - Serious medical illness; - Vascular thrombosis; - BMD < 1 SD from mean peak value; - BMI <18 or >30; - Smoking >20 cigarettes/day; - Alcohol >3 drinks/day; - WHR > 0.8; - Hyper androgenemia; - Serum folate > 12.5 nmol/l; - Hyperhomocystenaemia | Number of fibroids: | G2 vs. baseline: | Random: +
Palomba, Russo et al., 2004 | Groups: | Indications, N: | NR | P < 0.05 | Methods and blinding: +
Country and setting: | G1: Leuprolide acetate depot 3.75 mg every 28 days and raloxifene hydrochloride 60 mg/d | - Menorrhagia: 50; - Pelvic pressure: 44; - Pelvic pain: 36; - Urinary frequency: 31; - Constipation: 11 | Baseline fibroid size, cm^3^± SD: | Fibroid volume*: | Pt selection criteria: ++
Italy, Academic medical center | G2: Leuprolide acetate depot 3.75 mg every 28 days and placebo each day | Preoperative therapy: | G1: 197 ± 61 | G1 vs. baseline: | Loss to follow-up: <10%
Enrollment period: | N at enrollment: | NA | G2: 189 ± 154 | P < 0.05 | Drop-out rates: <5%
06/2000 to 01/2001 | G1: 50 | Associated procedure(s): | Type of fibroid: | G2 vs. baseline: | Statistical issues: ++
Funding: | G2: 50 | NR | NR | P < 0.05 | EXTERNAL VALIDITY: poor (4)
NR | N at follow-up: | | | Menorrhagia, N %: | Age: +, reported
| NR | | | G1: 0(0)^a^ | Race: NA, not US study
| Age, yrs ± SD: | | | G2: 0(0)^a^ | Pregnancy history: +, reported
| G1: 49.1 ± 4.2 | | | Pelvic pressure, N %: | Surgical history: -, NR
| G2: 48.6 ± 3.9 | | | G1: 3 (6.7)^a^ | Fibroid/uterine size: +
| Race/ethnicity: | | | G2: 3 (6.5)^a^ | Number of fibroids: -
| NR | | | Pelvic pain, N %: | Location of fibroids: -
| Parity, mean ± SD: | | | G1: 2 (4.4)^a^ | Baseline characteristics: -, NR
| G1: 1.8 ± 1.4 | | | G2: 3 (6.5)^a^ | Length of follow-up: ++
| G2: 1.7 ± 1.3 | | | Urinary frequency, N %: | Measurement methods: +
| Baseline Hgb/Hct: | | | G1: 3 (6.7)^a^ | Measurement reliability: +
| NR | | | G2: 2 (4.3)^a^ | Clinical care: +
| | | | Constipation:
| | | | G1: 0 (0)^a^
| | | | G2: 0 (0)^a^
| | | | Change in BMD, Lumbar spine*:
| | | | G2 vs. baseline/G1:
| | | | P < 0.05
| | | | Change in BMD, Trochanter*:
| | | | G2 vs. baseline/G1:
| | | | P < 0.05
| | | | Change in BMD, Femoral Neck*:
| | | | G2 vs. baseline/G1:
| | | | P < 0.05
| | | | Change in TC, mmol/l*:
| | | | G1: 0.26^a,b^
| | | | G2: 0.47^a^
| | | | Change in HDL-C, mmol/l*:
| | | | G1: 0.09^a^
| | | | G2: 0.10^a^ Change in LDL-C, mmol/l*:
| | | | G1: 0.02 ^b^
| | | | G2: 0.23 ^a^
| | | | Change in TG, mmol/l*:
| | | | G1: 0.10 ^a^
| | | | G2: 0.13 ^a^
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine size, 3^rd^ cycle, cm^3^± SD: | Quality:
Palomba, Orio, Morelli, Russo et al., 2002 | RCT | - Healthy pre-menopausal women; - Ovulatory cycles from 26–30d; - ≤ 2 asymptomatic fibroids < 20mm | G1: 203.9 ± 58.4 | G1: 205.5 ± 58.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 206.7 ± 61.0 | G2: 207.5 ± 62.3 | INTERNAL VALIDITY: good
Italy | Raloxifene vs. placebo | - Neoplastic disease; - Serious medical illnesses; - Vascular thrombosis/coagulation disorder; - BMI >30; - Hormone therapy in prior 6 mos; - Moderate to severe vasomotor symptoms | G3: 195.9 ± 56.5 | G3: 197.3 ± 54.1 | Random: +
Academic medical center | Groups: | Indications: | Number of fibroids: | P = NS | Methods and blinding: +
Enrollment period: | G1: Raloxifene 60 mg/d plus polyvitamins for 6×28d cycles | NR | NR | Uterine size, 6th cycle, cm^3^± SD: | Pt selection criteria: ++
NR | G2: Raloxifene 180 mg/d plus polyvitamins for 6×28d cycles | Preoperative therapy: | Baseline fibroid size, cm^3^± SD: | G1: 209.5 ± 59.3 | Loss to follow-up: <10%
Funding: | G3: Polyvitamins | NR | G1: 51.7±18.9 | G2: 207.5 ± 64.4 | Drop-out rates: <5%
NR | N at enrollment: | Associated procedure(s): | G2: 47.4±16.3 | G3: 202.0 ± 52.6 | Statistical issues: ++
| G1: 30 | NR | G3: 49.0±14.9 | G1/G3 vs. baseline: P < 0.05 | EXTERNAL VALIDITY: fair (3)
| G2: 30 | | Type of fibroid: | Fibroid size, 3rd cycle, cm^3^± SD: | Age: +, reported
| G3: 30 | | NR | G1: 53.3 ± 19.7 | Race: NA, not US study
| N at follow-up: | | | G2: 47.6 ± 18.1 | Pregnancy history: +, reported
| G1: 29 | | | G3: 50.6 ± 14.9 | Surgical history: -, NR
| G2: 30 | | | P < 0.05 vs. baseline | Fibroid/uterine size: +
| G3: 29 | | | P = NS | Number of fibroids: -
| Age, yrs ± SD: | | | Fibroid size, 6th cycle, cm^3^± SD: | Location of fibroids: -
| G1: 36.3 ± 5.4 | | | G1: 57.4±23.7 | Baseline characteristics: +, reported
| G2: 35.9 ± 6.1 | | | G2: 47.7±21.8 | Length of follow-up: +
| G3: 37.2 ± 5.8 | | | G3: 55.3±17.9 | Measurement methods: +
| Race/ethnicity: | | | G1/G3 vs. baseline: P < 0.05 | Measurement reliability: +
| NR | | | Modifiers: | Clinical care: +
| Parity, mean ± SD: | | | NR
| G1: 1.1 ± 1.0
| G2: 1.2 ± 1.1
| G3: 1.2 ± 1.1
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine size at 3 mos, cm^3^± SD: | Quality:
Palomba, Orio, Russo et al., 2005 | RCT | - Natural menopause for 1 to 2 yrs; - 1 to 2 fibroids with at least 1 > 2 cm | G1: 313.1 ± 87.9 | G1: 274.9 ± 71.9 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 327.7 ± 89.8 | G2: 327.5 ± 90.7 | INTERNAL VALIDITY: good
Italy, Academic medical center | Raloxifene vs. placebo | - Neoplastic, metabolic, or infectious diseases; - Vascular thrombosis or coagulation abnormality; - BMI >30; - Use of hormone therapy in previous 6 mos; - Moderate or severe vasomotor symptoms | Number of fibroids: | G1 vs. baseline: | Random: +
Enrollment period: | Groups: | Indications, N (%): | NR | P < 0.001 | Methods and blinding: +
NR | G1: 180 mg/day orally for 3 cycles of 28 days | Uterine prolapse: | Baseline fibroid size, cm^3^± SD: | G2 vs. baseline: | Pt selection criteria: ++
Funding: | G2: 3 placebo tablets/day for 3 cycles of 28 days | G1: 16 (80) | G1: 141.7 ± 37.8 | P = 0.824 | Loss to follow-up: <10%
NR | N at enrollment: | G2: 17 (85.9) | G2: 150.3 ± 58.7 | G1 vs. G2: | Drop-out rates: <5%
| G1: 20 | Complex endometrial hyperplasia: | Type of fibroid: | P = 0.048 | Statistical issues: ++
| G2: 20 | G1: 2 (10) | All intramural | Fibroid size at 3 mos, cm^3^± SD: | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | G2: 2 (10) | | G1: 116.3±27.4 | Age: +, reported
| NR | High-grade intrasquamous lesion: | | G2: 150.4±58.0 | Race: NA, not US study
| Age, yrs ± SD: | G1: 2 (10) | | G1 vs. baseline: | Pregnancy history: +, reported
| G1: 53.4 ± 4.1 | G2: 1 (5) | | P < 0.001 | Surgical history: -, NR
| G2: 52.2 ± 4.0 | Preoperative therapy: | | G2 vs. baseline: | Fibroid/uterine size: +
| Race/ethnicity: | NR | | P = 0.993 | Number of fibroids: -
| NR | Associated procedure(s): | | G1 vs. G2: | Location of fibroids: -
| Parity, mean ± SD: | NR | | P = 0.022 | Baseline characteristics: +, reported
| G1: 2.2 ± 1.3 | | | Modifiers: | Length of follow-up: ++
| G2: 2.1 ± 1.2 | | | NR | Measurement methods: +
| Baseline Hgb/Hct: | | | | Measurement reliability: +
| NR | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Uterine and fibroid size: | Quality:
Palomba, Sammartino et al., 2001 | RCT | - Natural menopause for 1 to 2 yrs; - 1 to 2 fibroids with at least 1 > 2 cm | G1: 295.6 ± 81.0 | After 6, 9, and 12 cycles of treatment a reduction in mean uterine and fibroid size was observed in comparison to baseline and between groups | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 316.6 ± 113.7 | (P < 0.05)* | INTERNAL VALIDITY: good
Italy, Academic medical center | Raloxifene vs. placebo | - Neoplastic, metabolic or infectious disease; - Vascular thrombosis or coagulation abnormality; - BMI >30; - Hormone therapy in prior 6 mos; - Moderate or severe vasomotor symptoms | Number of fibroids: | Amenorrhea | Random: +
Enrollment period: | Groups: | Indications: | NR | 3 mo, %: | Methods and blinding: +
NR | G1: 60 mg/day × 12 cycles | NR | Baseline fibroid size, cm^3^± SD: | G1: 83.9 | Pt selection criteria: ++
Funding: | G2: 60 mg/day placebo × 12 cycles | Preoperative therapy: | G1: 127.1 ± 38.2 | G2: 82.8 | Loss to follow-up: <10%
NR | N at enrollment: | NR | G2: 138.5 ± 55.7 | P = NS | Drop-out rates: 5–10%
| G1: 35 | Associated procedure(s): | Type of fibroid: | 6 mo, %: | Statistical issues: ++
| G2: 35 | NR | NR | G1: 84.9 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | | | G2: 84.9 | Age: +, reported
| G1: 31 | | | P = NS | Race: NA, not US study
| G2: 31 | | | 9 mo, %: | Pregnancy history: +, reported
| Age, yrs ± SD: | | | G1: 82.8 | Surgical history: -, NR
| G1: 54.2±4.9 | | | G2: 83.9 | Fibroid/uterine size: +
| G2: 51.2±3.9 | | | P = NS | Number of fibroids: -
| Race/ethnicity: | | | 12 mo, %: | Location of fibroids: -
| NR | | | G1: 88.1 | Baseline characteristics: +, reported
| Parity, mean ± SD: | | | G2: 86.0 | Length of follow-up: ++
| G1: 2.0 ± 1.5 | | | P = NS | Measurement methods: +
| G2: 2.1 ± 1.7 | | | AUB episodes | Measurement reliability: +
| Baseline Hgb/Hct: | | | 3 mo (mean ± SD): | Clinical care: +
| NR | | | G1: 1.40 ± 0.63
| | | | G2: 1.40 ± 0.63
| | | | P =NS
| | | | 6 mo (mean ± SD):
| | | | G1: 1.29 ± 0.47
| | | | G2: 1.38 ± 0.62
| | | | P =NS
| | | | 9 mo (mean ± SD):
| | | | G1: 1.13 ± 0.34
| | | | G2: 1.20 ± 0.41
| | | | P =NS
| | | | AUB episodes, mean ± SD:
| | | | At 12 months
| | | | G1: 1.18 ± 0.41
| | | | G2: 1.15 ± 0.38
| | | | P =NS
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine volume (ml ± SD): | Operative time, min ± SD: | Quality:
Seracchioli et al., 2003 | RCT | - Uterine volume 16–20 wks; - Absence of pelvic pathology; - No prior therapy with GnRHa, progestational agents, or danazol in past 6 mos; - Mobile uterus with mean volume 380–680 ml; - Regular vaginal accessibility | G1: 528 ± 275 | G1: 85.3 ± 29.1 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 579 ± 337 | G2: 115.3 ± 38.2 | INTERNAL VALIDITY: poor
Italy, Academic medical center | Triptorelin depot IM injection 11.25 mg 3 mos prior to laparoscopic hysterectomy | - Diseases requiring hospital monitoring; - Prior longitudinal laparotomy; - Contraindications to laparoscopy | Preoperative uterine volume (ml ± SD): | P < 0.001 | Random: -
Enrollment period: | Groups: | Indications, N (%): | G1: 388 ± 193 | Conversion to laparotomy, N: | Methods and blinding: -
NR | G1: Triptorelin depot injection 11.25 mg 3 mos prior to surgery starting in midluteal phase | - Uterine bleeding: 54 (87); - Pelvic pain/pressure: 35 (56); - Recurrent urinary disorder: 23 (37) | G2: 587 ± 341 | G1: 0 | Pt selection criteria: ++
Funding: | G2: No therapy | Pre-operative therapy: | P < 0.005 | G2: 3 | Loss to follow-up: NR
NR | N at enrollment: | see Groups | Number of fibroids: | Decrease in Hgb, g/dl ± SD: | Drop-out rates: NR
| G1: 31 | Associated procedure(s): | NR | G1: 1.2 ± 0.8 | Statistical issues: +
| G2: 31 | Bilateral salpinooophorectomy: | Baseline fibroid size: | G2: 1.9 ± 1.0 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | G1: 7 (22.6) | NR | P < 0.005 | Age: +, reported
| NR | G2: 8 (25.8) | Type of fibroid: | Transfusion, N: | Race: NA, not US study
| Age, yrs ± SD: | | NR | G1: 0 | Pregnancy history: -, NR
| G1: 47.6 ± 3.5 | | | G2: 3 | Surgical history: NA
| G2: 48.4 ± 4.6 | | | Length of stay, hrs ± SD: | Fibroid/uterine size: +
| Race/ethnicity: | | | G1: 76.3 ± 24.4 | Number of fibroids: -
| NR | | | G2: 80.4 ± 26.5 | Location of fibroids: -
| Parity: | | | Modifiers: | Baseline characteristics: +, reported
| NR | | | NR | Length of follow-up: +
| Baseline Hgb, g/dl ± SD: | | | | Measurement methods: +
| G1:11.2 ± 1.3 | | | | Measurement reliability: +
| G2:11.6 ± 1.4 | | | | Clinical care: +
| Preoperative Hgb, g/dl ± SD:
| G1: 12.3 ± 1.4
| G2: 11.4 ± 1.4
| P < 0.02
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Change in fibroid volume, %: | Quality:
Somekawa et al., 2001 | RCT | - Appropriate for leuprolide treatment; - Normal cyclic menses | NR | G1: 52.9 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 49.8 | INTERNAL VALIDITY: poor
Japan, Academic medical center | GnRH analog | - Performing excessive exercise; - Heavy smokers; - Alcoholics; - Clinically diagnosed with serious medical illnesses; - History of carcinoma | NR | P = NS | Random: -
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Change in LDL-C, 6 mos, %: | Methods and blinding: -
NR | G1: | NR | NR | G1: 8.4 | Pt selection criteria: -
Funding: | Leuprolide acetate 1.88 mg IM monthly plus Ipriflavone 600 mg/day po for 6 mos | Pre-operative therapy: | Type of fibroid: | G2: 22.6 | Loss to follow-up: NR
NR | G2: | See groups | NR | P<0.01 | Drop-out rates: NR
| Leuprolide acetate 1.88 mg IM monthly for 6 mos | Associated procedure(s): | | Modifiers: | Statistical issues: +
| N at enrollment: | NR | | NR | EXTERNAL VALIDITY: poor (5)
| G1: 51 | | | | Age: +, reported
| G2: 51 | | | | Race: NA, not US study
| N at follow-up: | | | | Pregnancy history: +, reported
| NR | | | | Surgical history: NA
| Age, yrs ± SD: | | | | Fibroid/uterine size: -
| G1: 45 ± 1 | | | | Number of fibroids: -
| G2: 46 ± 1 | | | | Location of fibroids: -
| Race/ethnicity: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: +
| Parity, mean ± SD: | | | | Measurement methods: +
| G1: 1.7 ± 0.1 | | | | Measurement reliability: +
| G2: 1.7 ± 0.1 | | | | Clinical care: -
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Operative time, min ± SD: | Quality:
Vercellini et al., 2003 | RCT | - Pre-menopausal; - Age: 18 to 40 yrs; - FSH < 30 mIU/mL | G1: 343 ± 130 | G1: 93 ± 32 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 338 ± 148 | G2: 90 ± 32 | INTERNAL VALIDITY: fair
Italy, Academic medical center | GnRH analog treatment prior to myomectomy | - Predominantly intracavitary fibroids; - Previous pelvic surgery for gyn pathology; - GnRHa use in last 6 mos; - Ultrasonographic signs of uterine calcifications; - Coagulation disorders; - Unstable general conditions; - Hgb <10 g/dL | Baseline uterine size, wks gestation ± SD: | Mean estimated blood loss, ml ± SD: | Random: +
Enrollment period: | Groups: | Indications: | G1: 12 ± 2 | G1: 265 ± 181 | Methods and blinding: -
NR | G1: Triptorelin 3.75 mg IM q28days × 2 prior to myomectomy surgery | - Menorrhagia; - Pelvic compression; - Infertility | G2: 12 ± 2 | G2: 296 ± 204 | Pt selection criteria: ++
Funding: | G2: Immediate myomectomy | Pre-operative therapy: | Number of fibroids removed, mean ± SD: | Hgb, 6 hrs after surgery, g/dL ± SD: | Loss to follow-up: <10%
NR | N at enrollment: | Triptorelin as per intervention | G1: 3 ± 3 | G1: 12.1 ± 1.2 | Drop-out rates: <5%
| G1: 50 | Associated procedure(s): | G2: 3 ± 3 | G2: 11.8 ± 1.2 | Statistical issues: ++
| G2: 50 | None | Baseline largest fibroid size, mm ± SD: | Hct, 6 hrs after surgery, % ± SD: | EXTERNAL VALIDITY: fair (2)
| N at followup: | | G1: 69 ± 25 | G1: 35.2 ± 3.1 | Age: +, reported
| 97 | | G2: 66 ± 23 | G2: 34.5 ± 3.3 | Race: NA, not US study
| Age, yrs ± SD: | | Type of fibroid: | Hgb, 24 hrs after surgery, g/dL ± SD: | Pregnancy history: +, reported
| G1: 34 ± 4 | | NR | G1: 11.4 ± 1.0 | Surgical history: +, reported
| G2: 33 ± 4 | | | G2: 11.0 ± 1.4 | Fibroid/uterine size: +
| Race/ethnicity: | | | Hct, 24 hrs after surgery, % ± SD: | Number of fibroids: -
| NR | | | G1: 34.1 ± 2.9 | Location of fibroids: -
| Parity, parous, %: | | | G2: 33.1 ± 3.9 | Baseline characteristics: +, reported
| G1: 15 (31) | | | P = NR | Length of follow-up: NA
| G2: 18 (37) | | | Modifiers: | Measurement methods: +
| Baseline Hgb, g/dL ± SD: | | | NR | Measurement reliability: +
| G1: 12.7 ± 1.2 | | | | Clinical care: +
| G2: 12.3 ± 1.1
| Baseline Hct (% ± SD):
| G1: 38.4 ± 3.4
| G2: 37.6 ± 3.3
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Decrease in fibroid size (mm ± SD): | Quality:
Verspyck et al., 2000 | RCT | - Symptomatic uterine fibroids; - ≥ 1 fibroids ≥ 5 cm by ultrasound; - Any size submucous fibroid | NR | G1: 20.93 ± 4.17 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids (mean ± SD): | G2: 5 ± 3.01 | INTERNAL VALIDITY: poor
France, Multi-site, NR | Leuprorelin vs. lynestrenol prior to surgery | - Amenorrhea; - Calcified fibroids; - GnRHa therapy in last 6 mos | G1: 2.59 ± 0.31 | P = 0.01 | Random: +
Enrollment period: | Groups: | Indications, N (%), | G2: 2.04 ± 0.42 | Hgb, at 16 wks, g/dL ± SD: | Methods and blinding: NA
3 yr | G1: SC injections of LA 3.75 mg every 28 days for 16 weeks prior to surgery | Infertility: | Baseline fibroid size (mm ± SD): | G1: 13.38 ± 0.21 | Pt selection criteria: +
Funding: | G2: Lynestrenol 10 mg po per day days 5 to 25 of each menstrual cycle for 16 weeks prior to surgery | G1: 1 (3) | G1: 78.69 ± 4.99 | G2: 13.56 ± 0.32 | Loss to follow-up: <10%
NR | N at enrollment: | G2: 2 (8.7) | G2: 65.55 ± 4.72 | P = NR | Drop-out rates: >10%
| G1: 33 | Pre-operative therapy: | Type of fibroid: | Modifiers: | Statistical issues: +
| G2: 23 | See groups | ≥ 5 cm as determined by ultrasound OR any size submucous fibroid | NR | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Associated procedure(s): | | | Age: +, reported
| G1: 28 | Myomectomy and hysterectomy | | | Race: NA, not US study
| G2: 18 | | | | Pregnancy history: +, reported
| Age, yrs ± SD: | | | | Surgical history: NA
| G1: 42.24 ± 1.27 | | | | Fibroid/uterine size: +
| G2: 40.17 ± 1.69 | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| Caucasian: 91% | | | | Baseline characteristics: +, reported
| Parity (reported as gravidity): | | | | Length of follow-up: +
| G1: 1.97 ± 0.29 | | | | Measurement methods: +
| G2: 2.35 ± 0.42 | | | | Measurement reliability: +
| Baseline Hgb, g/dL ± SD: | | | | Clinical care: -
| G1: 12.54 ± 0.31
| G2: 12.43 ± 0.33

a P <0.005 vs. baseline

b P <0.05 versus Group 2

* Tabular data only

* Graphs, not quantitative data provided

Evidence Table 4. KQ 2 UAE

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Number of fibroids: | Further invasive therapy (hysterectomy, myomectomy, or UAE), N (%): | Quality:
Broder et al., 2002 | Retrospective cohort (survey) | Patients having bilateral uterine artery embolization or abdominal myomectomy at a single institution | NR | G1: 51 (29) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Baseline fibroid size: | G2: 1 (3) | INTERNAL VALIDITY: poor
US, Academic medical center | Uterine artery embolization or abdominal myomectomy | NA | NR | P = 0.004 | Random: NA
Enrollment period: | Groups: | Elapsed time from procedure to survey (mean mos, range): | Type of fibroid: | (AOR: 12.5; 95%CI: 1.4, 110.1) | Methods and blinding: NA
02/1996 to 08/1997 | G1: Uterine artery embolization | G1: 46 (41 to 59) | NR | No improvement/worsening of symptoms, N (%): | Pt selection criteria: -
Funding: | G2: Abdominal myomectomy | G2: 49 (37 to 59) | | G1: 3 (8) | Loss to follow-up: 10–20%
Partial support form NIH (NICHD) BIRCWH Grant | N at procedure: | Indications: | | G2: 3 (10) | Drop-out rates: NA
| G1: 59 | NR | | P = 0.78 | Statistical issues: +
| G2: 38 | Preoperative therapy: | | Somewhat/very dissatisfied, N (%): | EXTERNAL VALIDITY: poor (5)
| N contacted: | NR | | G1: 2 (6) | Age: +, reported
| G1: 53 | Additional procedures: | | G2: 6 (21) | Race: +, reported
| G2: 32 | NR | | P = 0.06 | Pregnancy history: -, NR
| N respondents: | | | Clinical failure (a priori definition as combination of three above outcomes), N (%): | Surgical history: +, reported
| G1: 51 of 59 | | | G1: 20 (39) | Fibroid/uterine size: -
| G2: 30 of 38 | | | G2: 9 (30) | Number of fibroids: -
| Age, mean yrs: | | | P = 0.40 | Location of fibroids: -
| G1: 43.5 (27 to 66) | | | Modifiers: | Baseline characteristics: +, reported
| G2: 37.6 (28 to 45) | | | NR | Length of follow-up: ++
| P = 0.03 | | | (in multivariate models, months elapsed total and between procedure and survey did not predict failure) | Measurement methods: +
| Race/ethnicity, N (%): | | | | Measurement reliability: -
| G1: | | | | Clinical care: +
| White: 23 (45)
| Black: 17 (33)
| Hispanic: 3 (6)
| Asian: 1 (2)
| Other: 7 (14)
| G2:
| White: 14 (47)
| Black: 7 (23)
| Hispanic: 2 (7)
| Asian: 3 (10)
| Other: 4 (13)
| Parity:
| NR
| Baseline uterine size:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Clinical failure, N (%): | Quality:
Chrisman, West et al., 2005 | Prospective case series | Patients who underwent technically successful UAE | NR | 11 (10%) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Continued symptoms, N (%): | INTERNAL VALIDITY: poor
US, Academic medical center | UAE | - Not interested in treatment option; - History of severe reaction to iodinated contrast agent; - Other pathologic process (adenomyosis, infarcted leiomyomas, or other nonuterine disease) | NR | Menorrhagia: | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | 5 (45) | Methods and blinding: NA
11/2000 to 09/2001 | Patients who underwent primary UAE | - Significant uterine bleeding; - Bulk-related symptoms; - Pain | NR | Bulk symptoms: | Pt selection criteria: -
Funding: | N at enrollment: | Pre-operative therapy: | Type of fibroid: | 3 (27) | Loss to follow-up: <10%
NR | 111 | No | NR | Both: | Drop-out rates: <5%
| N at follow-up: | Associated procedure(s): | | 3 (27) | Statistical issues: -
| 111 | NR | | Persistent contrast enhancement: | EXTERNAL VALIDITY: poor (7)
| Age: | | | 8 (73) | Age: +, reported
| NR | | | Complete tumor necrosis: | Race: -, NR
| Race/ethnicity: | | | 3 (27) | Pregnancy history: -, NR
| NR | | | Offered repeat UAE: | Surgical history: -, NR
| Parity: | | | 8 (73) | Fibroid/uterine size: -
| NR | | | 2 refused and sought alternate care | Number of fibroids: -
| Baseline Hgb/Hct: | | | Modifiers: | Location of fibroids: -
| NR | | | NR | Baseline characteristics: +, reported
| | | | | Length of follow-up: +
| | | | | Measurement methods: -
| | | | | Measurement reliability: -
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Primary hemostasis, N (%): | Quality:
Chrisman, Liu et al., 2005 | Prospective case series | - Patients undergoing UAE for symptomatic fibroids | NR | 320 (97) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Device failure, N (%): | INTERNAL VALIDITY: fair
US, Academic medical center | UAE and percutaneous closure device | NR | NR | 8 (2.4) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | (99% CI; 0.2%, 4.6%) | Methods and blinding: NA
01/2001 to 09/2003 | NA | NR | NR | Minor complications, N (%): | Pt selection criteria: ++
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | 72 (22) | Loss to follow-up: <10%
NR | 342 | NR | NR | (99% CI; 16–28) | Drop-out rates: <5%
| N at follow-up: | Associated procedure(s): | | Major complications, N: | Statistical issues: -
| 328 | NR | | 0 | EXTERNAL VALIDITY: poor (8)
| Age, mean range: | | | Modifiers: | Age: -, NR
| Overall: 45 (32 to 54) | | | NR | Race: -, NR
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Parity: | | | | Fibroid/uterine size: -
| NR | | | | Number of fibroids: -
| Baseline Hgb/Hct: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: -, NR
| | | | | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^: | At least 1 adverse event, N (%): | Quality:
Goodwin et al., 2006 | Prospective cohort | - Symptomatic fibroids confirmed on MRI; - ≥ 30 yr old; - Regular menses; - Normal Pap smear; - Able to complete follow-up requirements | G1: 658.4 | G1: 33 (22.1) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 590.6 | G2: 24 (40) | INTERNAL VALIDITY: good
US, Academic medical centers | UAE vs. myomectomy | - Hysteroscopically resectable fibroids; - Pelvic infection; - Gynecologic malignancy; - Undiagnosed pelvic mass outside of uterus; - Unexplained abnormal menstrual bleeding; - Infection; - Coagulopathy; - History of pelvic irradiation; - ASA score ≥ 4; - FSH level > 40 IU/L; - Participation in any other Investigational device or drug study; - Desire to become pregnant; - Abnormal serum creatinine level; - Uterine arteriovenous fistula; - Severe contrast allergy; - Pedunculated subserosal fibroid | P > 0.05 | P < 0.01 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Number of fibroids N (%): | Major adverse event, N: | Methods and blinding: NA
NR | G1: UAE | Abnormal bleeding | 0 | G1: 6 | Pt selection criteria: ++
Funding: | G2: Myomectomy | G1: 77 (51.7) | G1: 2 (1.3) | G2: 1 | Loss to follow-up: 10–20%
Boston Scientific Corporation | N at enrollment: | G2: 20 (33.3) | G2: 1 (1.7) | P > 0.05 | Drop-out rates: <5%
| G1: 149 | P = 0.02 | 1 | Length of stay, mean hrs: | Statistical issues: ++
| G2: 60 | Bulk/pressure | G1: 9 (6.0) | G1: 23.8 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | G1: 38 (25.5) | G2: 5 (8.3) | G2: 61.6 | Age: +, reported
| G1: 121 | G2: 16 (26.7) | 2 | P < 0.0001 | Race: -, NR
| G2: 45 | Pelvic pain | G1: 10 (6.7) | Dominant fibroid volume, 3 mos or 6 mos: | Pregnancy history: +, reported
| Age, mean yrs: | G1: 29 (19.5) | G2: 4 (6.7) | P = NS | Surgical history: -, NR
| G1: 43.9 | G2: 18 (30.0) | 3 | Quality-of-life assessments, 6 mos: | Fibroid/uterine size: +
| G2: 38.2 | Infertility | G1: 10 (6.7) | P = NS | Number of fibroids: +
| P < 0.0001 | G1: 0 (0.0) | G2: 8 (13.3) | Menstrual bleeding score, 3 mos or 6 mos: | Location of fibroids: +
| Race: | G2: 2 (3.3) | 4 | P = NS | Baseline characteristics: +, reported
| NR | Other | G1: 10 (6.7) | Return to normal activities, mean days: | Length of follow-up: ++
| Parity, parous,%: | G1: 5 (3.4) | G2: 7 (11.7) | G1: 14.6 | Measurement methods: +
| G1: 75.2 | G2: 4 (6.7) | 5 | G2: 44.4 | Measurement reliability: +
| G2: 48.3 | Preoperative therapy: | G1: 6 (4.0) | P < 0.05 | Clinical care: -
| P < 0.0001 | NR | G2: 2 (3.3) | Missed workdays:
| Baseline Hgb/Hct: | Additional procedures: | 6–10 | G1: 9.9
| NR | NR | G1: 27 (18.1) | G2: 37.0
| | | G2: 14 (23.3) | P < 0.001
| | | >10 | Modifiers:
| | | G1: 75 (50.3) | NR
| | | G2: 13 (21.7)
| | | P = 0.0001
| | | Baseline dominant fibroid size, cm^3^:
| | | G1: 182.12
| | | G2: 226.92
| | | P = 0.081
| | | Type of fibroid, N (%):
| | | Intramural
| | | G1: 88 (59.1)
| | | G2: 26 (43.3)
| | | Submucosal
| | | G1: 1 (0.007)
| | | G2: 3 (5.0)
| | | Submucosal pedunculated
| | | G1: 17 (11.4)
| | | G2: 2 (3.3)
| | | Sebserosal
| | | G1: 8 (5.4)
| | | G2: 8 (13.3)
| | | Subserosal pedunculated
| | | G1: 31 (20.8)
| | | G2: 13 (21.7)
| | | Other
| | | G1: 0 (0.0)
| | | G2: 1 (1.7)
| | | Cannot determine
| | | G1: 2 (1.3)
| | | G2: 0 (0.0)
| | | Missing
| | | G1: 2 (1.3)
| | | G2: 7 (11.7)
Author: | Design: | Inclusion criteria: | Baseline uterine volume (ml ± SD): | Decrease in size of dominant fibroid, N (%): | Quality:
Hald et al; 2004 | Prospective cohort | - Pre-menopausal | G1: 833 ± 469 | Measured by U/S: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 665 ± 376 | G1: 28 (54) | INTERNAL VALIDITY: fair
Norway, Academic medical center | Laparoscopic occlusion of uterine vessels vs. embolization of uterine arteries | - Currently pregnant; - Breastfeeding; - Current or recent PID; - Abnormal Pap; - Endometriosis; - Breast cancer; - Previous history of DVT, thromboembolism or liver disease; - Hormone therapy in 3 mos prior to study | Number of fibroids: | G2: 27 (45) | Random: NA
Enrollment period: | Groups: | Indications, N (%): | NR | P = NS | Methods and blinding: NA
NR | G1: Radiologic embolization | - Bulk symptoms: 6 (13); - Bulk symptoms and menorrhagia: 29 (63); - Menorrhagia only: 11 (24) | Baseline dominant fibroid size by ultrasound, ml ± SD: | Measured fibroid by MRI: | Pt selection criteria: ++
Funding: | G2: Laparoscopic closure of uterine arteries | Pre-operative therapy: | G1: 263 ± 196 | G1: 27 (45) | Loss to follow-up: 10–20%
NR | N at enrollment: | NR | G2: 187 ± 141 | G2: 30 (36) | Drop-out rates: <5%
| G1: 24 | Associated procedure(s): | Baseline dominant fibroid size by MRI, ml ± SD: | P = NS | Statistical issues: ++
| G2: 22 | NR | G1: 293 ± 245 | Decreased in uterine volume, measured by MRI: | EXTERNAL VALIDITY: fair (2)
| N at follow-up: | | G2: 232 ± 157 | G1: 19 (40) | Age: +, reported
| 32 | | Type of fibroid: | G2: 17 (36) | Race: +, reported
| Age, mean, yrs: | | NR | P = NS | Pregnancy history: +, reported
| G1: 41 | | | Pictorial blood loss assessment score: | Surgical history: +, reported
| G2: 44 | | | G1: 28 (66) | Fibroid/uterine size: +
| P = 0.08 | | | G2: 33 (50) | Number of fibroids: -
| Race/ethnicity, N: | | | Postoperative pain, cm (SD): | Location of fibroids: -
| White: 41 | | | 43 patients | Baseline characteristics: +, reported
| African: 2 | | | G1: 1.9 (1.8) | Length of follow-up: +
| Arabic: 1 | | | G2: 1.4 (1.4) | Measurement methods: +
| Indian: 2 | | | P = 0.40 | Measurement reliability: +
| Parity, parous, %: | | | Pain relief (ketobemidon), mg (SD): | Clinical care: +
| Nulliparous | | | G1: 38 (19.6)
| G1: 79 | | | G2: 16 (13.0)
| G2: 45 | | | P = 0.00
| Baseline Hgb/Hct: | | | Modifiers:
| NR | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Fibroid volume, 3 mos, ml ± SD: | Quality:
Healey et al., 2004 | Prospective cohort | - Healthy premenopausal women; - Age: 39 to 50; - Symptomatic uterine fibroids; - Regular menstrual cycles; - Day 3 serum FSH levels < 40 IU/L | G1: 538 ± 50 | G1: 434.1 ± 51.5 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids (%): | G2: NA | INTERNAL VALIDITY: poor
Canada, Academic medical center | UAE vs. hysterectomy | See inclusion criteria | 1: | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | G1: 11 (16.3) | (95% CI, 6–201) | Methods and blinding: NA
08/2000 to 04/2003 | G1: UAE | Bleeding: | G2: NA | Fibroid volume, 6 mos, ml ± SD: | Pt selection criteria: ++
Funding: | G2: Hysterectomy | G1: 42 (61.8) | ≥ 2: | G1: 361.0 ± 38.4 | Loss to follow-up: >20%
NR | N at enrollment: | G2: 16 (100) | 57 (83.8) | G2: NA | Drop-out rates: <5%
| G1: 68 | Pain/pressure: | G2: NA | P < 0.01 | Statistical issues: +
| G2: 16 | G1: 5 (7.4) | Baseline (dominant) fibroid size, ml ± SD: | (95% CI, 44–241) | EXTERNAL VALIDITY: good
| N at follow-up: | G2: 0 | G1: 154 ± 19.9 | Hormone measures at 6 mos | Age: +, reported
| G1: 48 | Urinary symptoms: | G2: NA | FSH (IU/L ± SEM): | Race: +, reported
| G2: 13 | G1: 3 (4.4) | Type of fibroid, N (%): | G1: 9.9 ± 1.0 | Pregnancy history: +, reported
| Age, yrs ± SD: | G2: 0 | Submucosal: | 95% CI, -1.7–1.2 | Surgical history: +, reported
| G1: 44.9 ± 3.8 | Multiple symptoms: | G1: 10 (14.7) | G2: 7.8 ± 1.8 | Fibroid/uterine size: +
| G2: 43.7 ± 3.6 | G1: 14 (20.1) | G2: NA | 95% CI, -0.2–4.0 | Number of fibroids: +
| Race/ethnicity: | G2: 0 | Intramural or subserosal: | LH (IU/L ± SEM): | Location of fibroids: +
| NR | Preoperative therapy: | G1: 58 (85.3) | G1: 7.0 ± 1.1 | Baseline characteristics: +, reported
| Parity, parous (%): | NR | G2: NA | 95% CI, -1.2–0.8 | Length of follow-up: +
| Nulliparous: | Associated procedure(s): | | G2: 11.2 ± 5 | Measurement methods: +
| G1: 11 (22.0) | NR | | 95% CI, -1.91–3.3 | Measurement reliability: +
| G2: 0 | | | E2 (pmol/L ± SEM): | Clinical care: +
| Baseline Hgb/Hct: | | | G1: 214 ± 34.9
| NR | | | 95% CI, -52–36
| | | | G2: 326 ± 79.2
| | | | 95% CI, -39.8–212.6
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine volume, median cm^3^ (range): | Procedure time, min: | Quality:
Hehenkamp et al., 2005 | RCT | - Ultrasound confirmation uterine fibroids; - Menorrhagia; - Premenopausal scheduled for hysterectomy | G1: 321 (31 to 3,005) | G1: 79.0 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 313 (58 to 3,617) | G2: 95.4 | INTERNAL VALIDITY: good
The Netherlands, Hospitals | UAE versus hysterectomy | - Other treatment options available; - Future pregnancy desired; - Renal failure; - Active pelvic infection or clotting disorders; - Allergic to contrast material; - Uterine malignancy suspected; - Submucosal fibroids with 50% of diameter within uterine cavity or Dominant pedunculated serosal fibroids | Number of fibroids (%): | P = 0.007 | Random: +
Enrollment period: | Groups: | Indications, N (%): | 1 fibroid: | Mean estimated blood loss, ml ± SD: | Methods and blinding: NA
03/2002 to 02/2004 | G1: UAE | Dysmenorrhea: | G1: 35 (39.8) | G1: 30.9 ± 23.8 | Pt selection criteria: ++
Funding: | G2: Hysterectomy (abdominal, vaginal, laparoscopically assisted vaginal, and laparoscopic) | G1: 47 (53.4) | G2: 25 (28.1) | G2: 436.1 ± 474.5 | Loss to follow-up: <10%
Netherlands Organisation for Health Research and Development and Boston Scientific Corporation | N at enrollment: | G2: 50 (56.2) | 2 fibroids: | P < 0.001 | Drop-out rates: <5%
| G1: 88 | Pressure/Pain: | G1: 13 (14.8) | Length of stay, days ± SD: | Statistical issues: ++
| G2: 89 | G1: 38 (43.1) | G2: 16 (18.0) | G1: 2.0 ± 2.1 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | G2: 39 (43.8) | 3 fibroids: | G2: 5.1 ± SD1.3 | Age: +, reported
| G1: 81 | Bladder/Bowel symptoms: | G1: 17 (19.3) | P < 0.001 | Race: +, reported
| G2: 75 | G1: 18 (20.5) | G2: 25 (25.8) | Readmissions, N: | Pregnancy history: +, reported
| Age, yrs ± SD: | G2: 25 (28.1) | >3 fibroids: | G1: 9 | Surgical history: +, reported
| G1: 44.6 ± 4.8 | Anemia: | G1: 18 (20.5) | G2: 0 | Fibroid/uterine size: +
| G2: 45.4 ± 4.2 | G1: 43 (48.9) | G2: 14 (15.7) | P = 0.0032 | Number of fibroids: +
| Race/ethnicity, N (%): | G2: 42 (47.2) | Baseline dominant fibroid volume, median cm^3^ (range): | Minor complications at surgery, complications/ patients: | Location of fibroids: -
| Black: | Other symptoms: | G1: 59 (1–673) | G1: 23/18 | Baseline characteristics: +, reported
| G1: 24 (27.3) | G1: 6 (6.8) | G2: 87 (4–1641) | G2: 26/23 | Length of follow-up: +
| G2: 20 (22.5) | G2: 11 (12.4) | Type of fibroid: | (RR = 0.72; 95% CI, 0.43–1.23) | Measurement methods: +
| White: | Preoperative therapy: | NR | P = 0.23 | Measurement reliability: +
| G1: 54 (61.4) | NR | | Minor complications at 6 weeks, complications/ patients: | Clinical care: +
| G2: 57 (64.0) | Additional procedures, N: | | G1: 68/47
| Other: | Hysterectomy: | | G2: 34/30
| G1: 10 (11.4) | G1: 4 | | (RR = 1.45; 95% CI, 1.04–2.02)
| G2: 12 (13.5) | G2: NA | | P = 0.024
| Parity, N (%): | Removal of hydrosalpinx: | | Major complications at surgery, complications/ patients:
| 0: | G1: 0 | | G1:1/1
| G1: 30 (34.1) | G2: 1 | | G2: 1/1
| G2: 20 (22.5) | Adhesiolysis: | | (RR = 0.93; 95% CI, 0.06–14.54)
| ≥1: | G1: 1 | | P = 0.99
| G1: 58 (65.9) | G2: 0 | | Major complications at 6 weeks, complications/ patients:
| G2: 69 (77.5) | Unilateral salpingo-oophorectomy: | | G1: 3/3 pts
| Baseline Hgb/Hct: | G1: 1 | | G2: 1/1 pts
| NR | G2: 2 | | (RR = 2.78; 95% CI, 0.30–26.13)
| | Bilateral salpingo-oophorectomy: | | P = 0.62
| | G1: 0 | | Unscheduled doctor visits, surgery to 6 wks, visits/pts:
| | G2: 1 | | G1: 45/24
| | | | G2: 30/19
| | | | (RR = 1.45; 95% CI, 0.90–2.37)
| | | | P = 0.12)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^: | UAE Failure | Quality:
Huang et al. 2006 | Retrospective case series | - Consecutive UAE patients | 531.5 | (persistent or recurrent bleeding, pain, or bulk systems with repeat UAE, myomectomy, and/or hysterectomy), | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | N (%): | INTERNAL VALIDITY: poor
Canada, Academic medical center | UAE | NR | NR | Total: 22 (9.4) | Random: NA
Enrollment period: | N at enrollment: | Indications, N: | Baseline dominant fibroid size, cm^3^: | Hysterectomy: 16 (6.9) | Methods and blinding: NA
11/1997 to 02/2004 | 233 | - Menorrhagia: 125; - Abdominal distension: 59; - Abdominal/pelvic pain: 38 | 201.4 | Myomectomy: 6 (2.6) | Pt selection criteria: -
Funding: | N at follow-up: | Preoperative therapy: | Type of fibroid: | Modifiers: | Loss to follow-up: NA
NR | 233 | NR | NR | Baseline fibroid size (cm^3^): | Drop-out rates: NA
| Age: | Associated procedure(s): | | Failed: 355.2 | Statistical issues: -
| NR | NR | | Succeeded: 183.8 | EXTERNAL VALIDITY: poor (5)
| Race/ethnicity: | | | P = NS | Age: +, reported
| NR | | | Baseline uterine size, cm^3^: | Race: -, NR
| Parity: | | | Failed: 590.2 | Pregnancy history: -, NR
| NR | | | Succeeded: 525.3 | Surgical history: +, reported
| Baseline Hgb/Hct: | | | P = NS | Fibroid/uterine size: +
| NR | | | Prior myomectomy Failed: 13% vs. | Number of fibroids: -
| | | | Succeeded: 2.4%, | Location of fibroids: -
| | | | P < 0.05 | Baseline characteristics: +, reported
| | | | Fibroid volume reduction at 6 mos, % | Length of follow-up: +
| | | | Failed: 54.4 | Measurement methods: +
| | | | Succeeded: 36.0 | Measurement reliability: -
| | | | P < 0.05 | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Procedure time, min ± SD: | Quality:
Katsumori et al., 2003 | Retrospective case series | - Pre-menopausal; - At least 1 clinical symptom uncontrolled by medication | G1: 1,380 ± 500 | G1: 55.3 ± 15.8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 684 ± 337 | G2: 46.6 ± 14.3 | INTERNAL VALIDITY: fair
Japan, Community | UAE | - Desire future pregnancy; - Refused major surgery | P < 0.001 | Length of stay, days ± SD: | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids: | G1: 4.0 ± 1.6 | Methods and blinding: NA
2002 | G1: Fibroid ≥ 10 cm | Symptomatic fibroids | NR | G2: 3.8 ± 0.8 | Pt selection criteria: ++
Funding: | G2: Fibroid < 10 cm | Pre-operative therapy: | Baseline fibroid size, diameter of largest, cm ± SD: | Minor complications, N (%): | Loss to follow-up: NA
NR | N at enrollment: | NR | G1: 12.4 ± 2.2 | G1: 9 (19.1) | Drop-out rates: <5%
| G1: 47 | Associated procedure(s): | G2: 6.8 ± 2.0 | G2: 16 (15.2) | Statistical issues: -
| G2: 105 | NR | P < 0.001 | P = 0.637 | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | | Largest fibroid volume (ml ± SD): | Major complications, N (%): | Age: +, reported
| 30 days: 152 | | G1: 701 ± 336 | G1: 3 (6.4) | Race: NA, not US study
| > 4 mos: 134 | | G2: 154 ± 107 | G2: 2 (1.9) | Pregnancy history: -, NR
| > 12 mos: 96 | | P < 0.001 | P = 0.172 | Surgical history: -, NR
| > 24 mos: 49 | | Type of fibroid: | Increased care, prolonged hospitalization, N (%): | Fibroid/uterine size: +
| Age: | | NR | G1: 2 (4.3) | Number of fibroids: -
| 42.5 (31 to 52) | | | G2: 2 (1.9) | Location of fibroids: -
| Race/ethnicity: | | | Symptom control, mean score ± SD: | Baseline characteristics: +, reported
| NR | | | Menorrhagia at 4 mos: | Length of follow-up: ++
| Parity: | | | G1: 3.36 ± 0.99 | Measurement methods: +
| NR | | | G2: 3.79 ± 0.55 | Measurement reliability: +
| Baseline Hgb/Hct: | | | P = 0.003 | Clinical care: +
| NR | | | Menorrhagia at 1 yr:
| | | | G1: 3.58 ± 0.50
| | | | G2: 3.79 ± 0.56
| | | | P = 0.022
| | | | Patient satisfaction at 4 mos:
| | | | G1: 1.80 ± 0.46
| | | | G2: 1.97 ± 0.18
| | | | P = 0.004
| | | | Complete devascularization at 1 week, N (%):
| | | | G1: 34 (72)
| | | | G2: 94 (90)
| | | | P = 0.007
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | UAE, N (%): | Quality:
Lohle et al., 2006 | Prospective case series | - Presence of uterine fibroid; - Symptoms including: heavy menstrual bleeding, pain, and/or bulk-related symptoms unresolved by previous treatment | 532 ± 375 | Bilateral: 152 (96) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Unilateral: 6 (4) | INTERNAL VALIDITY: poor
Netherlands, Academic medical center | UAE | - Postmenopausal; - Malignancy; - Pedunculated fibroids; - Pregnancy | NR | Amenorrhea, N (%): | Random: NA
Enrollment period: | Groups: | Indications: | Baseline dominant fibroid size, cm^3^± SD: | Permanent: 17 (11) | Methods and blinding: NA
02/2001 to 02/2004 | NA | See inclusion criteria | 201 ± 249 | Transient: 20 (13) | Pt selection criteria: -
Funding: | N at enrollment: | Pre-operative therapy: | Type of fibroid: | Fibroid expulsion, N (%): | Loss to follow-up: <10%
NR | 158 | NR | NR | 16 (10) | Drop-out rates: NA
| N at follow-up, 12 months: | Associated procedure(s): | | Additional procedures, N: | Statistical issues: -
| 126 (MRI) | NR | | Second UAE: 9 | EXTERNAL VALIDITY: poor (4)
| 142 (survey) | | | Hysterectomy: 3 | Age: +, reported
| Age, mean yrs (range): | | | Dominant fibroid size, 12 mos, cm^3^± SD: | Race: +, reported
| 42.3 (23–53 | | | 78 ± 100 | Pregnancy history: -, NR
| Race/Ethnicity, N: | | | Dominant fibroid volume reduction, % ± SD: | Surgical history: -, NR
| White: 142 | | | 60 ± 40 | Fibroid/uterine size: +
| Afro-Caribbean: 11 | | | P<0.0001 | Number of fibroids: -
| Asian: 5 | | | Uterine volume reduction, % ± SD: | Location of fibroids: -
| Parity: | | | 47 ± 34 | Baseline characteristics: +, reported
| NR | | | P<0.0001 | Length of follow-up: +
| Baseline Hgb/Hct: | | | Symptom resolution, N (%): | Measurement methods: +
| NR | | | Heavy bleeding: 113/126 (91) | Measurement reliability: +
| | | | Pain: 80/91 (92) | Clinical care: +
| | | | Bulk symptoms: 70/81 (92)
| | | | Satisfaction, N (%):
| | | | Very satisfied: 81 (57)
| | | | Satisfied: 51 (36)
| | | | Not satisfied: 10 (7)
| | | | Modifiers:
| | | | Embosphere vs Embogold:
| | | | Embogold: similar volume reduction, satisfaction, and fibroid expulsion
| | | | P=NS
| | | | Embogold: greater risk of skin rash (P = 0.031); slower return to usual activities (P = 0.004)
Author: | Design: | Inclusion criteria: | Number of fibroids: | Improvement or stabilization of symptoms 6 mos after UFE: | Quality:
McLucas et al., 2001 | Prospective cohort | - Menorrhagia or postmenopausal bleeding secondary to uterine myomata | NR | 88% | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Baseline fibroid size: (cm) (range): | Total uterine volume decreased: | INTERNAL VALIDITY: poor
US, Academic center | UAE | - Contraindications to angiography and embolization, such as coagulopathy, pelvic inflammatory disease, diabetes mellitus, or vasculitis | 7.8 (1.5 to 16.3) | 52% (N = 46) | Random: NA
Enrollment period: | Groups: | Indications: | Type of fibroid: | Treatment failures, N (%): | Methods and blinding: NA
04/1997 to 08/1999 | NA | NR | NR | 21/167 (13) | Pt selection criteria: ++
Funding: | N at enrollment: | Preoperative therapy: | | Post UFE complications, %: | Loss to follow-up: >20%
NR | 167 | NR | | - Fever: 7; - Nausea/vomiting: 1; - Passage of submucosus myoma: 5; - Premature menopause: 2.4; - Hysterectomy: 3.5 | Drop-out rates: <5%
| N at follow-up (12 mos): | Associated procedure(s): | | Other modifiers: | Statistical issues: +
| 46 | NR | | Lupron use | EXTERNAL VALIDITY: fair (3)
| Age (range): | | | Earlier pelvic surgery - more likely to fail UFE: | Age: +, reported
| 43 (29 to 63) | | | P = 0.012 | Race: -, NR
| Race/ethnicity: | | | Age, parity, menopausal status, uterine characterics, procedure characteristics (partial size and partial load), and post-procedure complications unrelated to UAE falure | Pregnancy history: +, reported
| NR | | | | Surgical history: +, reported
| Parity*: | | | | Fibroid/uterine size: +
| 0.7 | | | | Number of fibroids: -
| Baseline uterine size: | | | | Location of fibroids: -
| Without lupron: 155 (1,389 mL) | | | | Baseline characteristics: +, reported
| With lupron: 12 (1,404 mL) | | | | Length of follow-up: ++
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size*: | Peak systolic velocity positively correlated with volume of embolization particles | Quality:
McLucas, et al., 2002 | Prospective case series | NR | NR | P = 0.05 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Higher baseline peak systolic velocity correlated with decrease in myoma and uterine volume | INTERNAL VALIDITY: poor
US, Academic medical center | UAE | NR | NR | P = 0.001 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | High peak systolic velocity (> 64 cm/s) significant predictor of failure | Methods and blinding: NA
04/1996 to 05/1999 | NA | NR | NR | P = 0.02 | Pt selection criteria: -
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | Other modifiers: | Loss to follow-up: 10–20%
NR | 227 | NR | NR | NR | Drop-out rates: NA
| N at follow-up (6 mos): | Associated procedure(s): | | | Statistical issues: +
| 188 | NR | | | EXTERNAL VALIDITY: poor (9)
| Age*: | | | | Age: -, NR
| NR | | | | Race: -, NR
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Parity*: | | | | Fibroid/uterine size: -
| NR | | | | Number of fibroids: -
| Baseline Hgb/Hct: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: -, NR
| | | | | Length of follow-up: +
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^, N (%): | Procedure time, min (median): | Quality:
Pron, Bennett, Common, Sniderman et al., 2003 | Prospective case series | - Symptomatic, ultrasound documented fibroids | 0 to 250: 106 (22) | 61 (55) | Overall quality score: fair
Pron, Bennett, Common, Wall et al., 2003 | Intervention: | Exclusion criteria: | 251 to 500: 131 (37) | (95% CI, 58–63) | INTERNAL VALIDITY: fair
Pron, Cohen, Soucie et al., 2003 | UAE | - Active PID; - Renal insufficiency; - Endometrial carcinoma; - Undiagnosed pelvic mass; - Pregnancy | 501 to 1,000: 149 (31) | Fluoroscopy time, mean min: | Random: NA
Pron, Mocarski, Bennett et al., 2003 | Groups: | Indications, %: | ≥1,001: 102 (21) | 18.9 | Methods and blinding: NA
Pron, Mocarski, Cohen, et al., 2003 | NA | - Menorrhagia: 17; - Menorrhagia/ dysmenorrhea: 63; - Pelvic pain: 13; - Bulk effects: 8 | Number of fibroids, N (%): | (95% CI, 18.0–19.8) | Pt selection criteria: ++
Country and setting: | N at enrollment: | Pre-operative therapy: | 1: 150 (30) | Complications, N (%): | Loss to follow-up: <10%
Canada, Academic medical centers | 555 | NR | 2 to 4: 220 (44) | 30 (5.3) | Drop-out rates: <5%
Enrollment period: | N at follow-up: | Associated procedure(s): | ≥ 5: 125 (26) | (95% CI, 3.6%ndash;7.4%) | Statistical issues: -
11/98 to 11/00 | 548 (98%) at 2 wks | NR | Baseline fibroid size mean cm^3^: | Major complications, N: | EXTERNAL VALIDITY: good
Funding: | 464 (83.6%) at 3 mos ultrasound | | 293 | 3 | Age: +, reported
NR | Age, mean (yrs): | | (95% CI, 259–327) | Intra-procedural pain, N (%): | Race: +, reported
| 43 (18 to 59) | | Type of fibroid, N (%): | None: 386 (70) | Pregnancy history: +, reported
| Race/ethnicity: | | - Intramural: 285 (60); - Intramural and subserosal/ submucosal: 63 (13); - Subserosal: 92 (19); - Submucosal: 33 (7) | Minor/tolerable: 162 (30) | Surgical history: +, reported
| White: 66% | | | Uncomfortable: 54 (10) | Fibroid/uterine size: +
| Black: 23% | | | Very uncomfortable: 50 (9) | Number of fibroids: +
| Other: 11% | | | Unbearable: 23 (4) | Location of fibroids: +
| Parity, parous, %: | | | NRS (1 to 10)- mean (median): 6.3 (6.0) | Baseline characteristics: +, reported
| Nulliparous: 50 | | | Ineffective analgesia: 24 (4%) | Length of follow-up: +
| Baseline Hgb/Hct: | | | Postprocedural pain, N (%): | Measurement methods: +
| NR | | | None: 44 (8) | Measurement reliability: +
| | | | Minor/tolerable: 86 (18) | Clinical care: +
| | | | Uncomfortable: 103 (19)
| | | | Very uncomfortable: 188 (35)
| | | | Unbearable: 116 (22)
| | | | NRS (1 to 10)- mean (median): 7.0 (7.5)
| | | | Ineffective pain management: 57 (10%)
| | | | Prescription pain medication use, days(median):
| | | | 6.8 (6.0)
| | | | Fever, N (%);
| | | | 157 (29)
| | | | Length of stay, nights (range):
| | | | 1.3 (0 to 11)
| | | | Infection rate, %:
| | | | 2.4 (95% CI, 1.3–4.0)
| | | | Fibroid expulsion, N (%):
| | | | 19 (3)
| | | | Readmission, N (%):
| | | | 16 (3)
| | | | Mean change in dominant fibroid volume:
| | | | 33% (95% CI, 28–38)
| | | | Mean change in uterine volume:
| | | | 27% (95% CI, 23–32)
| | | | Improvement in menorrhagia, N (%):
| | | | 358/429 (83)
| | | | (95% CI, 80–87)
| | | | Improvement in dysmenorrhea, N (%):
| | | | 249/322 (77)
| | | | (95% CI, 72–82)
| | | | Improvement in bulk related symptoms, N (%):
| | | | 388/464 (84)
| | | | (95% CI, 80–87)
| | | | Improvement in urinary urgency/ frequency, N (%):
| | | | 263/306 (86)
| | | | (95% CI, 82–90)
| | | | Duration of menstrual flow, mean days:
| | | | Pre UAE: 7.6
| | | | Post UAE: 5.4
| | | | P < 0.001
| | | | Pad count for day heaviest flow, median:
| | | | Pre UAE: 9
| | | | Post UAE: 4
| | | | P < 0.0001
| | | | Satisfactory intra-procedural care, %:
| | | | 97
| | | | Satisfactory post-procedural ward care, %:
| | | | 87
| | | | Median life-impact score (higher = greater impact):
| | | | Pre UAE: 8
| | | | Post UAE: 3
| | | | P < 0.001
| | | | Overall satisfaction, (%:
| | | | 91 (95% CI, 89–94)
| | | | Strong dissatisfaction, N (%):
| | | | 32/487 (7)
| | | | Would repeat UAE, N (%):
| | | | 414/487 (85)
| | | | Time until recovery, days, (median):
| | | | 13.1 (10.0)
| | | | Subsequent hysterectomy, N (%):
| | | | 8 (1.5)
| | | | Modifiers:
| | | | Larger fibroids were more likely to have significant volume decrease
Author: | Design: | Inclusion criteria: | Baseline uterine size: | All complications, N (%): | Quality:
Rajan et al., 2004 | Retrospective case series | - UAE for symptomatic fibroids | NR | 25 (6.1) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Minor complications, N (%): | INTERNAL VALIDITY: good
Canada, Community | UAE | - Pregnancy; - Gynecologic malignancy or pre-malignancy; - Adenomyosis with no fibroids; - Severe renal insufficiency; - Acute vasculitis; - Any acute or chronic infection; - Active pelvic infection or history of pelvic inflammatory disease; - Uncorrectable coagulopathy | NR | 14 (3.4) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size (cm ± SD): | Major complications, N(%): | Methods and blinding: NA
01/2000 to 07/2003 | NA | NR | 7.7 ± 3.2 | 11 (2.7) | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid, N (%): | Intrauterine infection (requiring intravenous antibiotic therapy and/or surgery), N (%): | Loss to follow-up: NA
NR | 410 | NR | Submucosal: 148 (36.1) | 5 (1.2%) | Drop-out rates: <5%
| N at follow-up: | Additional procedures: | Nonsubmucosal: 262 (63.9) | Modifiers: | Statistical issues: +
| NA | NR | | Intrauterine infection more common in submucosal than nonsubmucosal | EXTERNAL VALIDITY: poor (4)
| Age, yrs ± SD: | | | In univariate analysis | Age: +, reported
| 42.8 ± 5.8 | | | P = 0.006; logistic regression not significant | Race: +, reported
| Race/ethnicity: | | | (P = 0.079) | Pregnancy history: -, NR
| White: 66% | | | | Surgical history: -, NR
| Asian: 11% | | | | Fibroid/uterine size: +
| Afro-Caribbean: 23% | | | | Number of fibroids: -
| Parity: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: +, reported
| Baseline Hgb/Hct: | | | | Length of follow-up: +
| NR | | | | Measurement methods: +
| | | | | Measurement reliability: -
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Length of stay: | Quality:
Rasuli et al., 2004 | Prospective cohort | - UAE; - Premenopausal | NR | All discharged within 6 hours of UAE | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Return for pain management, N (%): | INTERNAL VALIDITY: poor
Canada, Academic medical center | UAE with superior hypogastric nerve block | - Pregnancy; - Desire for future pregnancy; - PID; - Endometriosis; - Adenomyosis; - Uterine malignancy; - Fibroid volume > 780 cm^3^ | NR | G1: 6 (6.0) | Random: +
Enrollment period: | Groups: | Indications, N (%): | Baseline fibroid size: | G2: 1 (2.6) | Methods and blinding: NA
04/1998 to 01/2004 | G1: Short-acting morphine tablets and indomethacin suppositories | - Menorrhagia: 16 (11.5); - Pressure: 8 (5.8); - Dysmenorrhea: 1 (0.7); - Menorrhagia/pressure: 20 (14.4); - Menorrhagia/dysmenorrhea: 9 (6.5); - Dysmenorrhea/pressure: 1 (0.7); - Three symptoms: 84 (60.4) | NR | P = NS | Pt selection criteria: +
Funding: | G2: Long-acting morphine tablets with short-acting morphine tablets for breakthrough pain, and naproxen suppositories | Preoperative therapy: | Type of fibroid: | Mean peak pain score, 5 days post-UAE (SD): | Loss to follow-up: 10–20%
NR | N at enrollment: | NR | NR | G1: 5.7 ± 2.2 | Drop-out rates: NA
| G1: 100 | Associated procedure(s): | | G2: 2.7 ± 2.5 | Statistical issues: -
| G2: 39 | NR | | P < 0 .01 | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | No pain, N (%): | Age: +, reported
| Post-op: | | | G1: 5 (5.0) | Race: -, NR
| G1: 100 | | | G2: 12 (30.8) | Pregnancy history: -, NR
| G2: 39 | | | P < 0.001 | Surgical history: -, NR
| 6 mos: | | | Nausea and Vomiting, N (%): | Fibroid/uterine size: -
| Total: 125 | | | G1: 20 (20.0) | Number of fibroids: -
| Age, mean yrs (range): | | | G2: 1 (2.6) | Location of fibroids: -
| 43.3 (28 to 53) | | | P < 0.01 | Baseline characteristics: +, reported
| Race/ethnicity: | | | Satisfaction with UAE, at 6 mos, N (%): | Length of follow-up: ++
| NR | | | - Completely satisfied: 118/125 (94.4); - Partially satisfied: 3/125 (2.4); - Unsatisfied: 4/125 (3.2%) | Measurement methods: +
| Parity: | | | Modifiers: | Measurement reliability: +
| NR | | | NR | Clinical care: -
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Pain medication use (days): | Quality:
Razavi et al., 2003 | Retrospective cohort | - Abdominal myomectomy; - Uterine fibroid embolization | NR | G1: 5.1 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 8.7 | INTERNAL VALIDITY: fair
US, Academic medical center | Myomectomy and UFE | - Planned laparoscopic myomectomy within 3 mos of UFE; - Primary reason for surgery was the treatment of infertility without other symptoms | NR | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Length of stay, days: | Methods and blinding: NA
07/1998 to 12/2000 | G1: UFE | NR | NR | G1: 0 | Pt selection criteria: +
Funding: | G2: Abdominal myomectomy | Preoperative therapy: | Type of fibroid: | G2: 2.9 | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P < 0.05 | Drop-out rates: NA
| G1: 62 | Associated procedure(s): | | Complications, N (%): | Statistical issues: -
| G2: 40 | NR | | G1: 7 (11) | EXTERNAL VALIDITY: poor (9)
| N at follow-up: | | | G2: 10 (25) | Age: +, reported
| NA | | | P < 0.05 | Race: -, NR
| Age, mean yrs (range): | | | Menorrhagia relief, N (%): | Pregnancy history: -, NR
| G1: 37.7 (28 to 48) | | | G1: 48 (92) | Surgical history: -, NR
| G2: 44.2 (31 to 56) | | | G2:14 (64) | Fibroid/uterine size: -
| Race/ethnicity: | | | P < 0.05 | Number of fibroids: -
| NR | | | Pain relief, N (%): | Location of fibroids: -
| Parity: | | | G1: 25 (74) | Baseline characteristics: -, NR
| NR | | | G2: 14 (54) | Length of follow-up: NA
| Baseline uterine size: | | | P = NS | Measurement methods: +
| NR | | | Mass effect, N (%): | Measurement reliability: -
| Baseline Hct, %: | | | G1: 28 (76) | Clinical care: -
| G1: 35.5 | | | G2: 21 (91)
| G2: 36 | | | P < 0.05
| | | | Time to resume normal activities (days):
| | | | G1: 8
| | | | G2: 36
| | | | P < 0.05
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline fibroid size: | Embolic volume, cc ± SD: | Quality:
Ryu et al., 2003 | Retrospective cohort | Consecutive UAE patients | NR | G1: 4.86 ± 3.01 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 3.52 ± 1.63 | INTERNAL VALIDITY: poor
US, Academic medical centers | UAE | NR | NR | P = 0.05 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Baseline fibroid size: | Morphine dose, 5 mg, N ± SD: | Methods and blinding: NA
03/1997 to 12/1999 | G1: Tri-acryl gelatin microspheres | Menorrhagia: | NR | G1: 37.2 ± 23.5 | Pt selection criteria: -
Funding: | G2: Polyvinyl alcohol particles | G1: 14 (48) | Type of fibroid: | G2: 47.1± 26.8 | Loss to follow-up: >20%
NR | N at enrollment: | G2: 6 (23) | NR | P > 0.15 | Drop-out rates: <5%
| G1: 36 | Bulk symptoms: | | Subjective pain score, (mean ± SD: | Statistical issues: +
| G2: 36 | G1: 2 (7) | | G1: 5.07 ± 2.99 | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | G2: 2 (8) | | G2: 5.58 ± 2.77 | Age: +, reported
| G1: 29 | Both: | | P > 0.5 | Race: +, reported
| G2: 26 | G1: 13 (45) | | Technical success | Pregnancy history: -, NR
| Age, mean yrs: | G2: 16 (620 | | (successful superselective bilateral UAE), N (%): | Surgical history: -, NR
| G1: 44 (29 to 59) | Preoperative therapy: | | G1: 29/29 (100) | Fibroid/uterine size: -
| G2: 44 (35 to 51) | NR | | G2: 26/26 (100) | Number of fibroids: -
| Race/ethnicity, N (%): | Associated procedure(s): | | G1: 28/29 (96) | Clinical success
| African American: | NR | | (complete/ significant improvement of symptoms), N (%): | Baseline characteristics: +, reported
| G1: 11/29 (38) | | | Location of fibroids: - | Length of follow-up: +
| G2: 9/26 (35) | | | G2: 25/26 (96) | Measurement methods: +
| Parity: | | | Modifiers: | Measurement reliability: +
| NR | | | NR | Clinical care: +
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, mean ml: | Outcomes at 3 mos: | Quality:
Spies, Ascher et al., 2001 | Prospective case series | At least 1 of the following: | 717 | Subsequent intervention, N (%): | Overall quality score: good
Spies, Roth, et al., 2002 | Intervention: | - Heavy menstrual bleeding ± anemia; - Pelvic pain or pressure; back, flank, or leg pain; - Urinary frequency or other bladder symptoms; - Hydronephrosis; - Failed, refused, or not suitable for medical therapy | (95% CI, 648.8–785.2) | Hyst/D&C: 6 (3) (95% CI, 1–6) | INTERNAL VALIDITY: good
Spies, Bruno, et al., 2005 | Bilateral uterine artery embolization | Patients 1 to 50: | Number of fibroids,N (%): | Hysterectomy: 1 (1) (95% CI, 0–3) | Random: NA
Country and setting: | Groups: | - Age: <35 yrs or wished to maintain fertility required to exhaust all therapies | 1: 28 (14.8) | Repeat UAE: 0 | Methods and blinding: NA
US, Academic medical center | NA | Patients 51 to 200: | 2 to 5: 138 (73.0) | Myomectomy: 0 | Pt selection criteria: ++
Enrollment period: | N at enrollment: | - Age: <35 yrs if failed medical therapy and only remaining option extensive myomectomy, repeat myomectomy, or hysterectomy | >5: 23 (12.2) | Improved symptoms, N (%): | Loss to follow-up: <10%
07/1997 to 12/1999 | 200 | Exclusion criteria: | Missing: 11 | At 3 mos | Drop-out rates: <5%
Funding: | N at follow-up: | - Pregnancy; - Suspicion of uterine, ovarian, or cervical cancer; - Pedunculated fibroids; - Hystero-scopically resectable fibroids; - Uterus >24 wks | Baseline dominant fibroid size (mean ml): | Yes: 180 (93) (95% CI, 89–96) | Statistical issues: ++
NR | 3 mo: 193 | Indications: | 240 | No: 9 (5) (95% CI, 2–9) | EXTERNAL VALIDITY: good
| 12 mo: 190 | NR | (95% CI, 200.8–279.3) | At 5 yrs | Age: +, reported
| 24 mo: 161 | Preoperative therapy: | Type of fibroid, N (%): | 143 (73) | Race: +, reported
| 36 mo: 183 | NR | - Intramural: 108 (54); - Submucosal: 35 (17.5); - Subserosal: 39 (19.5); - Missing: 18 | Bleeding, N (%): | Pregnancy history: +, reported
| 48 mo: 180 | Associated procedure(s): | | Amenorrhea: 14, (8) (95% CI, 4–12) | Surgical history: +, reported
| 60 mo: 182 | NR | | Mean change in bleeding score: 3.33 (95% CI, 3.04–3.61) | Fibroid/uterine size: +
| Age, mean yrs: | | | Pain: | Number of fibroids: +
| 43.1 (95% CI, 42.4–43.7) | | | Mean change pain score: 3.47 (95% CI, 3.17–3.78) | Location of fibroids: +
| Race/ethnicity, %: | | | Outcomes at 60 mos: | Baseline characteristics: +, reported
| Black: 50% | | | Improved symptoms, N (%): | Length of follow-up: ++
| White: 45% | | | Yes: 133 (73) (95% CI, 66–79) | Measurement methods: +
| Asian: 2.5% | | | No:10 (5) (95% CI, 3–10) | Measurement reliability: +
| Hispanic: 1.5% | | | Bleeding, N (%): | Clinical care: +
| Other: 1.0% | | | Amenorrhea: 42 (29) (95% CI, 21–37)
| Parity: | | | Mean change in bleeding score: 3.98 (95% CI, 3.67–4.28)
| NR | | | Pain:
| Baseline Hgb/Hct: | | | Mean change in pain score: 3.72 (95% CI, 3.34–4.10)
| NR | | | Subsequent interventions, (Years1 to 5), (%):
| | | | - Hysteroscopy/ D&C: 19; - Hysterectomy: 25; - Myomectomy: 6; - Repeat UAE: 3; - Failed or recurred: 46 (25); - Continued relief: 133 (73)
| | | | Modifiers:
| | | | Baseline imaging variables not associated with failure at 12 mos
| | | | Age, race, baseline leiomyoma volume, baseline uterine volume, and subsequent interventions were not associated with satisfaction
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Procedure time, min: | Quality:
Spies, Cooper, Worthington-Kirsch et al., 2004 | Prospective cohort | - Age: 30 to 50 yrs; - Symptomatic fibroids | G1: 689.4 ± 466.1 | G1: 57.9 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 389.2 ± 521.2 | G2: 93.6 | INTERNAL VALIDITY: poor
US, Community and academic medical centers | UAE and hysterectomy | - Submucosal fibroids with > 50% diameter within uterine cavity; - Dominant pedunculated serosal fibroid | P < 0.001 | P < 0.001 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids N (%): | At least 1 complication, N (%): | Methods and blinding: NA
NR | G1: UAE | NR | 1 fibroid: | G1: 28 (27.5%; 95% CI, 19.1–37.2) | Pt selection criteria: +
Funding: | G2: Hysterectomy | Preoperative therapy: | G1: 27 (26) | G2: 25 (50%; 95% CI, 35.5–64.5) | Loss to follow-up: >20%
Biosphere Medical Inc. | N at enrollment: | NR | G2: 20 (40) | P = 0.01 | Drop-out rates: NR
| G1: 102 | Additional procedures: | 2 fibroids: | Complications within 30 days, %: | Statistical issues: +
| G2: 50 | NR | G1: 33 (32) | G1: 17.6 | EXTERNAL VALIDITY: good
| (40 TAH, 2 LAVH, and 8 LH) | | G2: 19 (38) | G2: 28 | Age: +, reported
| N at follow-up, 12 months: | | ≥3 fibroids: | P = 0.15 | Race: +, reported
| G1: 76 | | G1: 42 (41) | Complications after 30 days, %: | Pregnancy history: +, reported
| G2: 30 | | G2: 10 (20) | G1: 12.7 | Surgical history: +, reported
| Age, yrs ± SD: | | P = 0.021 | G2: 32 | Fibroid/uterine size: +
| G1: 42.6 ± 4.0 | | Baseline dominant fibroid size (ml ± SD): | P=0.01 | Number of fibroids: +
| G2: 41.6 ± 5.3 | | G1: 146.8 ± 158.5 | Major complications, N (%): | Location of fibroids: +
| P = 0.264 | | G2: 90.6 ± 354.8 | G1: 4 (3.9) | Baseline characteristics: +, reported
| Race/ethnicity, N (%): | | P = 0.330 | G2: 6 (12) | Length of follow-up: ++
| Asian/Pacific Island: | | Type of fibroid, N (%): | P = 0.08 | Measurement methods: +
| G1:1 (1) | | Intramural: | Life threatening Complications, %: | Measurement reliability: +
| G2: 2 (4) | | G1: 61 (60) | G1: 0 | Clinical care: +
| Black: | | G2: 32 (64) | G2: 0
| G1: 61 (60) | | P = 0.724 | Overall morbidity N (%):
| G2: 9 (18) | | Subserosal: | G1: 15 (14.7)
| Hispanic: | | G1: 19 (19) | G2: 17 (34.0)
| G1: 7 (7) | | G2: 8 (16) | P = 0.01
| G2: 8 (16) | | P = 0.823 | Hemorrhage, N (%):
| White: | | Submucosal: | G1: 0 (0)
| G1: 31 (30) | | G1: 17 (17) | G2: 4 (8)
| G2: 31 (62) | | G2: 13 (26) | P = 0.01
| Other: | | P = 0.197 | Febrile morbidity, N (%):
| G1: 2 (2) | | Transmural: | G1: 13 (12.7)
| G2: 0 (0) | | G1: 11 (11) | G2: 12 (24.0)
| P < 0.001 | | G2: 1 (2) | P = 0.10
| Parity, N (%): | | P = 0.108 | Length of stay, days:
| Nulliparous: | | Pedunculated: | G1: 0.83
| G1: 44 (43) | | G1: 2 (2) | G2: 2.3
| G2: 11 (22) | | G2: 4 (8) | P < 0.001
| Para 1: | | P=0.072 | Readmission, N (%):
| G1: 20 (20) | | | G1: 3 (2.9)
| G2: 10 (20) | | | 4 (8)
| Multiparous: | | | P = 0.22
| G1: 38 (37) | | | Satisfaction with symptom outcome:
| G2: 29 (58) | | | P = NS
| P = 0.025 | | | Mean time to return to work, days:
| Baseline Hgb, (%): | | | G1: 10.7
| <12 g/dL: | | | G2: 32.5
| G1: 59 (58) | | | P < 0.001
| G2: 19 (38) | | | Unintended surgery, N (%):
| ≥12 g/dL: | | | G1: 2 (2)
| G1: 43 (42) | | | G2: 4 (8)
| G2: 31 (63) | | | P = 0.09
| P = 0.025 | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Subsequent care, 12 mos, N (%): | Quality:
Spies, Myers, Worthington-Kirsch et al., 2005 | Prospective case series | - Undergoing UAE for fibroid treatment; - Entered into Fibroid Registry for Outcomes Data | NR | - Medical treatment: 121 (7); - Gyn interventions: 77 (6); - Hysterectomy: 27 (1.6); - Unplanned ER care: 52 (3) | Overall quality score: fair
[See evidence table for Spies, Spector, Roth, et al., 2002] | Intervention: | Exclusion criteria: | Number of fibroids: | Symptom Score change, 12 mos: | INTERNAL VALIDITY: fair
Country and setting: | UAE | NR | NR | -38.94 ± 24.79 | Random: NA
US, Academic medical centers | Groups: | Indications: | Baseline fibroid size: | P < 0.001 | Methods and blinding: NA
Enrollment period: | NA | - Heavy bleeding; - Bulk related symptoms; - Pain | NR | HRQOL score change, 12 mos: | Pt selection criteria: ++
12/2000 to 12/2002 | N at enrollment: | Pre-operative therapy: | Type of fibroid: | 39.67 ± 25.28 | Loss to follow-up: 10–20%
Funding: | 2,112 | NR | NR | P < 0.001 | Drop-out rates: <5%
Society for Interventional Radiology Foundation | N at follow-up: | Associated procedure(s): | | Modifiers: | Statistical issues: ++
| 6 mos: 1,797 | NR | | NR | EXTERNAL VALIDITY: good
| 1 year: 1,701 | | | | Age: +, reported
| Age: | | | | Race: +, reported
| NR | | | | Pregnancy history: +, reported
| Race/ethnicity, %: | | | | Surgical history: +, reported
| White: 47.2% | | | | Fibroid/uterine size: +
| Parity: | | | | Number of fibroids: +
| NR | | | | Location of fibroids: +
| Baseline Hgb/Hct: | | | | Baseline characteristics: +, reported
| NR | | | | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | All complications, N (%): | Quality:
Spies, Spector, Roth, et al., 2002 | Prospective case series | Symptomatic fibroids | NR | 42 (10.5) | Overall quality score: fair
[See evidence tables for Spies, Ascher, Roth, et al., 2001; Spies, Roth, Jha, et al., 2002; and Spies, Bruno, et al., 2005] | Intervention: | Exclusion criteria: | Number of fibroids: | (95% CI, 7.7–13.9) | INTERNAL VALIDITY: good
Country and setting: | UAE | - Pregnant; - Infertility due to fibroids; - Desire for pregnancy with fibroids that could be removed by myomectomy; - Pedunculated submucosal fibroids that are hystero-scopically respectable; - Uterus > 24 wks | NR | Perioperative complications, %: | Random: NA
US, Academic medical center | Groups: | Indications: | Baseline fibroid size: | 8.5% | Methods and blinding: NA
Enrollment period: | NA | Reported in {481} | NR | (95% CI, 6.0–11.7). | Pt selection criteria: ++
07/1997 to 04/2001 | N at enrollment: | Preoperative therapy: | Type of fibroid: | Hemorrhage, N (%): | Loss to follow-up: <10%
Funding: | 400 | NR | NR | 3 (0.75) | Drop-out rates: <5%
NR | N at follow-up: | Associated procedure(s): | | (95% CI, 0.2–2.2) | Statistical issues: +
| 391 | NR | | Fever, N (%): | EXTERNAL VALIDITY: fair (4)
| Age, mean yrs (range): | | | 8 (2) | Age: +, reported
| 43 (27 to 57) | | | (95% CI, 0.9–3.9) | Race: +, reported
| Race/ethnicity: | | | Readmission, N (%): | Pregnancy history: -, NR
| Black: 53% | | | 14 (3.5) | Surgical history: -, NR
| White: 43% | | | (95% CI, 1.9–5.8) | Fibroid/uterine size: -
| Hispanic: 1.8% | | | Unintended procedure, N (%): | Number of fibroids: -
| Other: 1.5% | | | 10 (2.5) | Location of fibroids: -
| Parity: | | | (95% CI, 1.2–4.5) | Baseline characteristics: +, reported
| NR | | | Life threatening events, N (%): | Length of follow-up: ++
| Baseline Hgb/Hct: | | | 2 (0.5) | Measurement methods: +
| NR | | | (95% CI, 0.1–1.8) | Measurement reliability: +
| | | | Overall morbidity, N (%): | Clinical care: +
| | | | 20 (5)
| | | | (95% CI, 3.1–7.7)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cc ± SD: | Pregnancy, N (%): | Quality:
Walker and Pelage, 2002 | Prospective case series | - Women receiving UAE for symptomatic fibroids | 787 ± 648 | 10/24 attempting (41.7) and 3 unexpected | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Miscarriage, N (%): | INTERNAL VALIDITY: poor
UK, Community | UAE | NR | NR | 2/13 (15.4) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size (cc ± SD): | Live births, N (%): | Methods and blinding: NA
12/1996 to 10/2001 | NA | NR | 248 ± 354 | 9/13 (69.2) | Pt selection criteria: -
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | Median uterine and dominant fibroid volumes: | Loss to follow-up: >20%
NR | 400 | NR | NR | 255 and 19 cc | Drop-out rates: <5%
| N at follow-up: | Associated procedure(s): | | P = 0.0001 | Statistical issues: -
| Questionnaire: 383 | NR | | compared to baseline
| 6 week questionnaire: 262 | | | Time until no pain, days ± SD: | EXTERNAL VALIDITY: fair (3)
| > 1 yr: 252 | | | 17.2 ± 14.0 | Age: +, reported
| > 2 yrs: 131 | | | Improved menstrual bleeding, %: | Race: +, reported
| Age, yrs ± SD: | | | 84 | Pregnancy history: -, NR
| 43.2 ± 6.6 | | | Improved menstrual pain, N (%): | Surgical history: -, NR
| Race/ethnicity, %: | | | 383 (79) | Fibroid/uterine size: +
| Caucasian: 81% | | | Satisfaction, %: | Number of fibroids: -
| Afro-Caribbean: 12% | | | 97 | Location of fibroids: +
| Indian: 1% | | | Time to resume normal activity, days ± SD: | Baseline characteristics: +, reported
| Chinese: 1% | | | 13.6 ± 9.8 | Length of follow-up: +
| Other: 5% | | | Time to back at work, days ± SD: | Measurement methods: +
| Parity: | | | 16.6 ± 10.8 | Measurement reliability: +
| NR | | | Clinical failure or recurrence, N (%): | Clinical care: +
| Baseline Hgb/Hct: | | | 23 (6)
| NR | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Median fibroid reduction: | Quality:
Watson and Walker, 2002 | Prospective case series | - Patients receiving UAE and had magnetic resonance scans at 6 mos | NR | 58% | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, %: | Symptom relief, %: | INTERNAL VALIDITY: poor
UK, Community | UAE | NR | 1 to 3: 64% | - No symptoms: 38; - Improved symptoms: 53; - No symptom change: 8; - Worse symptoms: 2 | Random: NA
Enrollment period: | Groups: | Indications: | 4 to 10: 12% | Modifiers: | Methods and blinding: NA
NR | NA | NR | > 10: 24% | NR | Pt selection criteria: -
Funding: | N at enrollment: | Preoperative therapy: | Baseline largest size in cm, %: | | Loss to follow-up: <10%
NR | 114 | NR | < 8.5 cm: 89% | | Drop-out rates: NA
| N at follow-up: | Associated procedure(s): | ≥ 8.5 cm: 56% | | Statistical issues: -
| 6mos: 105 | NR | Type of fibroid, %: | | EXTERNAL VALIDITY: fair (3)
| Age, mean yrs: | | - Complex fibroid mass: 45; - Interstitial: 33; - Submucosal: 29; - Subserousal: 26; - Pedunculated subserousal: 6; - Peduncalated submucosal: 5 | | Age: +, reported
| 42 | | | | Race: -, NR
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: +, reported
| Parity: | | | | Fibroid/uterine size: +
| NR | | | | Number of fibroids: +
| Baseline Hgb/Hct: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: -, NR
| | | | | Length of follow-up: +
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Length of stay, days: | Quality:
Worthington-Kirsch et al., 2005 | Prospective case series | - Women undergoing uterine embolization for fibroids at 1 of 72 sites of FIBROID Registry | 677.7 ± 520.4 | 1.68 | Overall quality score: fair
Myers et al., 2005 | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | (95% CI, 1.21–2.15) | INTERNAL VALIDITY: fair
Country and setting: | UAE | NR | 1 to 2: 1249 (43.4) | AE, during hospitalization, N (%): | Random: NA
US, Varied sites (72) | Groups: | Indications (predominant symptom), N (%): | 3 to 4: 690 (24.1) | 94 in 90 (3) | Methods and blinding: NA
Enrollment period: | NA | - Heavy menstrual bleeding: 1,932 (64.7)); - Pelvic pain: 314 (10.5); - Bulk symptoms: 694 (23.3); - Other symptoms: 45 (1.5) | ≥ 5: 936 (32.6) | AE between discharge and 30 days, N (%): | Pt selection criteria: ++
12/2000 to 12/2002 | N at enrollment:* | Preoperative therapy, N (%): | Baseline fibroid size: | 710 (26) | Loss to follow-up: 10–20%
Funding: | 3,041 (30-day follow-up eligible) | GnRH agonist: 133 (4.4) | NR | Major events, N (%): | Drop-out rates: <5%
Society of Interventional Radiology Foundation through unrestricted grants from Biosphere Medical, Boston Scientific Corporation, COOK, Inc., and Cordis Endovascular | 2,112 (1-year follow-up eligible) | Additional procedures: | Type of fibroid, N (%): | 111 (4) | Statistical issues: ++
| N at follow-up: | NR | - Intramural: 1231 (42.8); - Transmural: 585 (20.3); - Subserosal: 410 (14.3); - Submucosal: 376 (13.1); - Pedunculated: subserosal: 64 (2.2); - Pedunculated: submucosal: 9 (0.3) | Recurrent pain, N (%): | EXTERNAL VALIDITY: good
| 2,729 (30 days) | | | 65 (2.1) | Age: +, reported
| 1,797 (1 year) | | | Possible infection, N (%): | Race: +, reported
| Age, yrs ± SD: | | | 19 (0.62) | Pregnancy history: +, reported
| 43.5 ± 5.6 | | | Minor events, N (%): | Surgical history: +, reported
| Race/ethnicity, %: | | | 610 (22) | Fibroid/uterine size: +
| African American: 48 | | | Hot flushes, N (%): | Number of fibroids: +
| White: 44.4 | | | 156 (5.7) | Location of fibroids: +
| Hispanic: 3.6 | | | Pain, N (%): | Baseline characteristics: +, reported
| Asian/Pacific Islander: 2.8 | | | 264 (9.6) | Length of follow-up: ++
| Other: 1.3 | | | Mean lost work days: | Measurement methods: +
| Parity, %: | | | 9.63 | Measurement reliability: +
| Nulliparous: 44.1 | | | (95% CI, 9.38–9.88) | Clinical care: +
| Baseline Hgb/Hct: | | | Modifiers:
| NR | | | Increased risk of AEs in hospital:
| | | | Univariate:
| | | | Length of procedure:
| | | | OR = 1.012; 95% CI, 1.005–1.019
| | | | Core site status:
| | | | OR = 0.334; 95% CI, 0.15–0.76
| | | | Size of fibroid:
| | | | OR = 1.073; 95% CI, 1.013–1.138
| | | | Multivariate:
| | | | Length of procedure:
| | | | OR = 1.10; 95% CI, 1.005–1.01
| | | | Size of fibroid:
| | | | OR = 1.11; 95% CI, 1.028–1.20
| | | | Uterine volume:
| | | | OR 0.999; 95% CI, 0.998–0.999
| | | | Increased risk of AE at 30 days:
| | | | Univariate:
| | | | Prior procedures or medical therapy:
| | | | OR = 1.242; 95% CI, 1.113–1.38)
| | | | P < 0.001
| | | | African American:
| | | | OR = 1.158; 95% CI, 1.048–1.28
| | | | P = 0.004
| | | | Smoking status:
| | | | OR = 1.139; 95% CI, 1.009–1.286
| | | | P = 0.035
| | | | Multivariate:
| | | | Smoking status:
| | | | OR = 1.141; 95% CI, 1.007–1.293
| | | | P = 0.039
| | | | African American:
| | | | OR = 1.129; 95% CI, 1.019–1.251
| | | | P = 0.021
| | | | Prior procedures:
| | | | OR = 1.235; 95% CI, 1.103–1.383
| | | | P < 0.001
| | | | Duration of procedure:
| | | | OR = 1.004; 95% CI, 1.001–1.006
| | | | P = 0.009
| | | | DVT prophylaxis:
| | | | OR = 0.757; 95% CI, 0.622–0.919

* Included in models but not reported

* Registry without complete overlap

Evidence Table 5. KQ 2 Endometrial ablation

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Bleeding controlled, N (%): | Quality:
Loffer, 2005 | Retrospective cohort | - All hysteroscopic myomectomies by a single surgeon for premenopausal women with menorrhagia/ menometrorrhagia | NR | G1: 70 (95.9) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 84 (80.8) | INTERNAL VALIDITY: fair
US, Academic medical center | Endometrial ablation at time of hysteroscopic myomectomy for submucosal fibroids | - Procedures done by author outside US or for which follow-up information was unavailable | G1: 1.5 ± 1.1 | P = 0.003 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 1.5 ± 1.1 | (OR = 0.18; 95%CI, 0.05–0.63) | Methods and blinding: NA
08/1984 to 08/2003 | G1: Endometrial ablation | - Menorrahagia and/or metrorrhagia | P = 0.96 | Success (no recurrence of bleeding problems or hysterectomy): | Pt selection criteria: +
Funding: | G2: Without endometrial ablation | Pre-operative therapy, N (%): | Baseline fibroid size, cm ± SD: | Log Rank = 5.3; | Loss to follow-up: <10%
NR | N at enrollment: | Endometrial suppression: | G1: 3.0 ± 1.1 | P = 0.02 | Drop-out rates: NA
| G1: 73 | G1: 58 (79.5) | G2: 3.4 ± 1.5 | (Kaplan-Meier survival analysis) | Statistical issues: -
| G2: 104 | G2: 22 (27.5) | P = 0.06 | Modifiers: | EXTERNAL VALIDITY: poor (4)
| N at follow-up (12 mos): | Associated Procedure(s): | Type of fibroid, %: | Complete vs. incomplete removal of fibroids | Age: +, reported
| G1: 72 | NR | Type 0: | Success (defined above), N (%): | Race: -, NR
| G2: 103 | | G1: 30.1 | G1 with complete removal: 58 of 60 (96.7) | Pregnancy history: -, NR
| Age, yrs ± SD: | | G2: 33.7 | G1 with incomplete removal: 12 of 13 (92.3) | Surgical history: -, NR
| G1: 44.0 ± 4.7 | | Type I: | G2 with complete removal: 65 of 77 (84.4) | Fibroid/uterine size: +
| G2: 37.6 ± 6.0 | | G1: 49.3 | G2 with incomplete removal: 19 of 27 (70.4) | Number of fibroids: +
| P < 0.001 | | G2: 36.5 | Hysterectomy, N (%): | Location of fibroids: +
| Race/ethnicity: | | Type II: | G1 with complete removal: 11 (18.3) | Baseline characteristics: -, NR
| NR | | G1: 20.5 | G1 with incomplete removal: 2 (15.4) | Length of follow-up: ++
| Parity: | | G2: 29.8 | G2 with complete removal: 13 (16.9) | Measurement methods: +
| NR | | | G2 with incomplete removal: 10 (37) | Measurement reliability: +
| (15 infertile, no ablations in this group) | | | | Clinical care: +
| Baseline Hgb/Hct:
| NR

Evidence Table 6. KQ2 in situ destructive techniques (MRI-guided focused ultrasound and cryotherapy)

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria and Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm ^ 3 ^ ± SD: | Pain, N (%): | Quality:
Hindley, et. al., 2004 | Prospective case series | - ≥ 18 yr old; - No desire future childbearing; - Clinically significant uterine fibroids | 595 ± 362 | None: 79 (75) | Overall quality score: fair
Stewart et al., 2006 | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | Mild: 19 (18) | INTERNAL VALIDITY: short term: fair
Country and setting: | MRI guided focused ultrasound surgery | - Pelvic or uncontrolled systemic disease; - Postmenopausal; - Weight > 250 lb (113 kg); - Unable to communicate during treatment; - Unsuitable for MRI; - Change of OCP's or NSAID's 1 to 3 mos pretreatment; - Extensive or treatment blocking abdominal scars; - Fibroids > 10 cm; - Uterus > 24 wks | 2.3 ± 2.0 | Moderate: 7 (7) | long term: poor
US, Israel, UK, Germany, Academic medical centers | Groups: | Indications: | Baseline fibroid size, dominant fibroid, cm ^ 3 ^ ± SD: | Severe: 1 (1) | Random: NA
Enrollment period: | NA | Symptomatic fibroids normally treated by conventional surgical therapy | 372 ± 235 | Fibroid volume, 6 mos, mean ± SD: | Methods and blinding: NA
NR | N at enrollment: | Preoperative therapy: | Type of fibroid, %: | -13.5% ± 32 | Pt selection criteria: ++
Funding: | 176 | NR | - Submucosal: 22%; - Intramural: 57%; - Subserosal: 21% | Transfusion, 6 mos: | Loss to follow-up: <10%/>20%
Insightec, Ltd., manufacturer of MR guided focused ultrasound system | N at follow-up: | Additional procedures: | | 3% | Drop-out rates: <5%
| 6 mos: 109 | NR | | Rehospitalization, 6 mos: | Statistical issues: ++
| 12 mos: 82 | | | 7% | EXTERNAL VALIDITY: good
| Age, yrs ± SD: | | | Skin burns after MRgFUS, %: | Age: +, reported
| 44.8 ± 4.9 | | | 5% | Race: +, reported
| Race/ethnicity, %: | | | Skin ulceration, N: | Pregnancy history: -, NR
| Caucasian: 81 | | | 1 | Surgical history: +, reported
| Black:11 | | | Sciatic nerve palsy, N: | Fibroid/uterine size: +
| American Indian/ Alaskan Native: 0 | | | 1 | Number of fibroids: +
| Asian: 3 | | | Improvement rated by decrease of ≥10 points of questionnaire, N (%): | Location of fibroids: +
| Hispanic: 0 | | | 82 (79.3) | Baseline characteristics: +, reported
| Other: 5 | | | P < 0.0001 | Length of follow-up: ++
| Parity: | | | Symptom severity score, mean (range): | Measurement methods: +
| NR | | | - 27.3 points (18.75 to 81.25) | Measurement reliability: +
| Baseline Hgb/Hct: | | | P < 0.0001 | Clinical care: +
| NR | | | Improvement 1 to 3 mos:
| | | | -24.1 points
| | | | Mass effect:
| | | | -32.7 points
| | | | Bleeding symptoms:
| | | | -34.8 points
| | | | Heavy menses requiring blood transfusion, N (%):
| | | | 5 (5)
| | | | 10-point improvement in transformed symptom severity scale (SSS) of Uterine Fibroid Symptoms Quality-of-Life questionnaire (UFS-QOL) at 6 mos, (%):
| | | | 77/109 (70.6)
| | | | P < 0.0001
| | | | After 12 mos:
| | | | 42/82 (51.2)
| | | | Modifiers:
| | | | NR

Evidence Table 7. KQ 2 Myomectomy

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Hemorrhage, N: | Quality:
Agostini, Cravello, Bretelle, et al., 2002 | Prospective case series | NR | NR | 3 | Overall quality score: poor
Agostini, Cravello, Desbriere, et al., 2002 | Intervention: | Exclusion criteria: | Number of fibroids: | P= 0.01 | INTERNAL VALIDITY: poor
Agostini, Cravello, Shojai, et al., 2002 | Hysteroscopy | NR | NR | (RR for fibroid resection vs. synechiolysis = 6.55; 95% CI, 1.58–27.17) | Random: NA
Country and setting: | Groups: | Indications: | Baseline fibroid size: | Uterine perforation, N: | Methods and blinding: NA
France, Community | NA | NR | NR | 9 | Pt selection criteria: -
Enrollment period: | N at enrollment: | Preoperative therapy: | Type of fibroid: | P < 0.0001 | Loss to follow-up: NR
01/1990 to 01/2000 | 782 | NR | NR | (RR for fibroid resection vs. synechiolysis = 7; 95% CI, 2.83–17.62) | Drop-out rates: NR
Funding: | (There were 2,116 surgical hysteroscopies performed and reported on 1,952 women; 782 were for fibroid resection) | Additional procedure(s): | | Early-onset endometritis, N: | Statistical issues: -
NR | N at follow-up: | NR | | 4 | EXTERNAL VALIDITY: poor (9)
| NA | | | P = 0.0066 | Age: -, NR
| Age, yrs ± SD: | | | (RR for fibroid resection vs. synechiolysis = 5.89; 95% CI, 1.68–20.69) | Race: NA, not US study
| 46.2 ± 4.2 | | | Modifiers: | Pregnancy history: -, NR
| Race/ethnicity: | | | NR | Surgical history: -, NR
| NR | | | | Fibroid/uterine size: -
| Parity: | | | | Number of fibroids: -
| NR | | | | Location of fibroids: -
| Baseline Hgb/Hct: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: -
| | | | | Measurement methods: +
| | | | | Measurement reliability: -
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Agostini et al., 2005 | RCT | - Need myomectomy | NR | G1: 90 ± 12 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 86 ± 15 | INTERNAL VALIDITY: poor
France, Academic medical center | Intravenous oxytocin during abdominal or vaginal myomectomy | - Preoperative embolization; - Preoperative administration of GnRH agonists | NR | P = 0.16 | Random: -
Enrollment period: | Groups: | Indications: | Baseline fibroid size (gm ± SD): | Mean estimated blood loss, ml ± S): | Methods and blinding: +
10/1998 to 05/2002 | G1: 15 IU oxytocin in “physiologic serum” over 30 min at uterine incision | Bleeding, N (%): | G1: 286 ± 206 | G1: 508 ± 558 | Pt selection criteria: +
Funding: | G2: 125 cc of “physiologic serum” over 30 min at uterine incision | G1: 24 (51) | G2: 268 ± 253 | G2: 451 ± 336 | Loss to follow-up: <10%
NR | N at enrollment: | G2: 21 (44.7) | P = 0.71 | P = 0.55 | Drop-out rates: NA
| G1: 47 | Pelvic pain, N (%): | Type of fibroid: | Decrease in Hgb, g/dl ± SD: | Statistical issues: ++
| G2: 47 | G1: 27 (36.2) | NR | G1: 1.89 ± 1.26 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | G2: 20 (42.5) | | G2: 1.93 ± 1.20 | Age: +, reported
| G1: 47 | Fertility, N (%): | | P = 0.87 | Race: NA, not US study
| G2: 47 | G1: 6 (12.8) | | Autotransfusion, N (%): | Pregnancy history: -, NR
| Age, yrs ± SD: | G2: 6 (12.8) | | G1: 19 (40.4) | Surgical history: -, NR
| G1: 40 ± 5.2 | Preoperative therapy: | | G2: 16 (34.0) | Fibroid/uterine size: +
| G2: 39 ± 4.3 | NR | | P = 0.5 | Number of fibroids: -
| Race/ethnicity: | Additional procedures: | | Blood transfusion, N (%): | Location of fibroids: -
| NR | Surgical route, N (%): | | G1: 7 (14.9) | Baseline characteristics: +, reported
| Parity: | Laparotomy: | | G2: 2 (4.2) | Length of follow-up: NA
| NR | G1: 32 (68.1) | | P = 0.09 | Measurement methods: +
| Baseline Hgb, g/dl ± SD: | G2: 31 (66) | | Modifiers: | Measurement reliability: +
| G1: 12 ± 1.3 | Vaginal: | | NR | Clinical care: +
| G2: 11.95 ± 1.82 | G1: 15 (31.9)
| | G2: 16 (34)
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, median min (IQR): | Quality:
Benassi, et al., 2000 | RCT | - Symptomatic fibroids, including menorrhagia, pelvic pain, and compression | NR | G1: 70 (40–100) | Overall quality score: good
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, median (IQR): | G2: 90 (40–120) | INTERNAL VALIDITY: good
Italy, Academic medical center | Myomectomy | - Use of hormone in past 6 months; - Previous uterine surgery; - PID | G1: 9 (2–17) | P < 0.05 | Random: +
Enrollment period: | Groups: | Indications: | G2: 6 (2–11) | Complications, N: | Methods and blinding: NA
02/1997 to 10/1998 | G1: Myomectomy using sodium-2-mercaptoethane sulfonate (mesna) | NR | Baseline largest fibroid size, median (IQR) mL: | G1: 1 | Pt selection criteria: ++
Funding: | G2: Myomectomy using saline solution | Pre-operative therapy: | G1: 67.96 (7.98–334.72) | G2: 6 | Loss to follow-up: NA
NR | N at enrollment: | None | G2: 45.88 (2.78–234.3) | Length of stay, days (range): | Drop-out rates: NA
| G1: 29 | Associated procedure(s): | Type of fibroid: | G1: 2 (2–3) | Statistical issues: +
| G2: 29 | NR | NR | G2: 3 (3–4) | EXTERNAL VALIDITY: good
| N at follow-up: | | | Decrease in Hgb, 24hr, g/dL: | Age: +, reported
| G1: 29 | | | G1: 0.9 (-0.1–2.1) | Race: NA, not US study
| G2: 29 | | | G2: 1.7 (0.1–2.9) | Pregnancy history: +, reported
| Age, median yrs (IQR): | | | P < 0.006 | Surgical history: +, reported
| G1: 34 (25 to 43) | | | Decrease in Hct 24hr, %: | Fibroid/uterine size: +
| G2: 35 (25 to 45) | | | G1: -0.4 (-5.3 to 3.8) | Number of fibroids: +
| Race/Ethnicity: | | | G2: 3.0 (-1.9 to 6.8) | Location of fibroids: +
| NR | | | P < 0.01 | Baseline characteristics: +, reported
| Parity, parous, N (%): | | | Modifiers: | Length of follow-up: NA
| G1: 6 (20.7) | | | NR | Measurement methods: +
| G2: 8 (27.6) | | | | Measurement reliability: +
| Baseline Hgb, median g/dL (IQR): | | | | Clinical care: +
| G1: 11.1 (10–11.9)
| G2: 11.4 (10–12.7)
| Baseline Hct, median% (IQR):
| G1: 34.3 (31.5–36.3)
| G2: 35.7 (33–37.5)
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Boe Engelsen et al., 2006 | Retrospective cohort | - All TCR procedures; - Uterus size < 12 wks on bimanual examination; - Uterine cavity depth less than 12 cm; - Submucous fibroids < 5 cm on vaginal ultrasound | NR | G1: 42.8 ± 20.6 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 31.4 ± 13.7 | INTERNAL VALIDITY: poor
Norway, Academic medical center | TCRE or TCRM | NR | NR | P < 0.001 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Baseline fibroid size: | Fluid absorption, ml ± SD: | Methods and blinding: NA
01/1992 to 12/1998 | G1: TCRM and TCRE or TCRM only | - Menorrhagia: 380/ 386 (98.4); - Dysmenorrhea: 95/380 (25)*; - Postmenopausal bleeding: 6/386 (1.6) | NR | G1: 292 ± 518 | Pt selection criteria: ++
Funding: | G2: TCRE only | Pre-operative therapy, %: | Type of fibroid, N: | G2: 186 ± 385 | Loss to follow-up: 10–20%
NR | N at enrollment: | - Gestagens: 54.1; - GnRHa: 4.9; - No pretreatment: 41 | Submucous: 149 | P < 0.05 | Drop-out rates: NA
| G1: 149 | Associated procedure(s): | | Uterine perforation, N (%): | Statistical issues: -
| G2: 241 | NR | | G1: 16 (10.7) | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | | | G2: 15 (6.2)* | Age: +, reported
| - 320 underwent examinations at 3 mos; - 327 completed questionnaire 4–10 yr after 1st procedure | | | Tissue resected, gm ± SD: | Race: NA, not US study
| Age, mean yrs (range): | | | G1: 21.5 ± 14.2 | Pregnancy history: +, reported
| 44.4 (23 to 68) | | | G2: 9.5 ± 4.7 | Surgical history: -, NR
| Race/ethnicity: | | | P < 0.001 | Fibroid/uterine size: -
| NR | | | Decrease in Hgb, g/dl ± SD: | Number of fibroids: -
| Parity, parous (range): | | | G1: 1.4 ± 1.1 | Location of fibroids: -
| 2.5 (0 to 6) | | | G2: 1.1 ± 0.9 | Baseline characteristics: +, reported
| Baseline Hgb/Hct: | | | P < 0.01 | Length of follow-up: ++
| NR | | | Modifiers: | Measurement methods: +
| | | | NR | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Cumulative pregnancy rate, N (%): | Quality:
Bulletti et al., 2004 | Prospective cohort | - Nulliparity; - Age 25 to 39; - ≥ 1 fibroid > 5 cm with tubal occlusion | NR | G1: 28 (33) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 13 (15) | INTERNAL VALIDITY: poor
Italy, Academic medical center | Myomectomy before IVF | - Male factor infertility; - Bilateral tubal occlusion; - Submucous fibroid(s); - Diagnosis with increased abortion risk other than fibroid(s) | NR | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Miscarriage rate, N (%): | Methods and blinding: NA
1997 to 2003 | G1: Myomectomy before IVF | - Infertility: 100% | NR | G1: 8 (7) | Pt selection criteria: ++
Funding: | G2: No myomectomy before IVF | Pre-operative therapy: | Type of fibroid: | G2: 3 (4) | Loss to follow-up: 10–20%
NR | N at enrollment: | NR | NR | P = NS | Drop-out rates: >10%
| G1: 84 | Associated procedure(s): | | Delivery rate, N (%): | Statistical issues: -
| G2: 84 | NR | | G1: 21 (25) | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | G2: 10 (12) | Age: +, reported
| - 193 enrolled; - 143 completed the study; - 25 replaced to reach 168; - Followup interval: NR | | | P < 0.05 | Race: NA, not US study
| Age, yrs ± SD: | | | Modifiers: | Pregnancy history: -, NR
| All: 33.04 ± 4.76 | | | NR | Surgical history: -, NR
| G1: 32.83 ± 4.12 | | | | Fibroid/uterine size: -
| G2: NR | | | | Number of fibroids: -
| Race/ethnicity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: -, NR
| Parity, parous, %: | | | | Length of follow-up: +
| G1: 0 | | | | Measurement methods: +
| G2: 0 | | | | Measurement reliability: +
| Baseline Hgb/Hct: | | | | Clinical care: +
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SEM: | Quality:
Cagnacci et al., 2003 | RCT | - Symptomatic fibroids or fibroids with associated infertility; - < 5 total intramural or subserous fibroids; - Diameter between 5 and 15 cm | NR | G1: 92.6 ± 4.4 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 85.9 ± 7.2 | INTERNAL VALIDITY: good
Italy, Specialty treatment center | Laparotomy, minilaparotomy, and laparoscopically-assisted minilaparotomy for myomectomy | - Pedunculated fibroids | G1: 1.18 ± 0.4 | G3: 91.3 ± 7.2 | Random: +
Enrollment period: | Groups: | Indications: | G2: 1.87 ± 0.3 | G1 vs. G2 vs. G3: | Methods and blinding: +
01/2001 to 07/2002 | G1: Laparoscopically-assisted minilaparotomy for myomectomy | NR | G3: 1.58 ± 0.7 | P < 0.01 vs. G3 | Pt selection criteria: ++
Funding: | G2: Minilaparotomy | Pre-operative therapy: | Baseline fibroid size, max cm diameter): | Decrease in Hgb, mg/dl ± SEM: | Loss to follow-up: NA
NR | G3: Laparotomy | NR | G1: 7.1 ± 0.7 | G1: 1.8 ± 0.15 | Drop-out rates: NA
| N at enrollment: | Associated procedure(s): | G2: 6.8 ± 0.7 | G2: 2.4 ± 0.4 | Statistical issues: ++
| G1: 17 | NR | G3: 5.8 ± 0.4 | G3: 3.07 ± 0.3 | EXTERNAL VALIDITY: fair (3)
| G2: 17 | | Type of fibroid: | G1 vs. G2 vs. G3: P < 0.025 | Age: +, reported
| G3: 17 | | NR | Fever >38C, N (%): | Race: NA, not US study
| N at follow-up: | | | G1: 4 (23.5) | Pregnancy history: -, NR
| G1: 17 | | | G2: 4 (23.5) | Surgical history: -, NR
| G2: 17 | | | G3: 4 (23.5) | Fibroid/uterine size: +
| G3: 17 | | | Length of stay, hrs ± SEM: | Number of fibroids: +
| Age, yrs ± SEM: | | | G1: 81.5 ± 8.2 | Location of fibroids: -
| G1: 37.6 ± 1.9 | | | G2: 119.3 ± 9.6 | Baseline characteristics: +, reported
| G2: 39.4 ± 1.6 | | | G3: 141.6 ± 5.2 | Length of follow-up: NA
| G3: 37.7 ± 0.9 | | | G1 vs. G2 vs. G3: P < 0.01 | Measurement methods: +
| Race/ethnicity: | | | G3 vs. G2: | Measurement reliability: +
| NR | | | P < 0.05 | Clinical care: +
| Parity: | | | Ileus, hrs ± SEM:
| NR | | | G1: 33.4 ± 3.4**
| Baseline Hgb/Hct: | | | G2: 41.8 ± 3.9*
| NR | | | G3: 55.0 ± 4.5
| | | | * P < 0.05
| | | | ** P < 0.01 vs. G3
| | | | Pain scores by 10 cm VAS
| | | | Abdominal pain at 7 days:
| | | | G1: 0.9 ± 0.4*
| | | | G2: 0.5 ± 0.2*
| | | | G3: 3.0 ± 0.6
| | | | *P < 0.05 vs. G3
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Transfusion, N (%): | Quality:
Cobellis et al., 2002 | Retrospective case series | - Women submitted to myomectomy during cesarean | NR | 34 (11%) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, %: | Length of stay, %: | INTERNAL VALIDITY: fair
Italy, Academic medical center | Myomectomy during cesarean section | NR | One: 63% | 4 to 5 days: 100 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Modifiers: | Methods and blinding: NA
NR | NA | Cesarean, %: | Subserosal ≤ 4 cm: 71% | NR | Pt selection criteria: -
Funding: | N at enrollment: | - Anomalous presentation: 33; - Previous C-section: 26; - Prolonged labor/ cardiotocography anomalies: 15; - Hypertensive disorders: 12; - Fetopelvic disproportion: 11; - Other: 3 | Type of fibroid, %: | | Loss to follow-up: <10%
NR | 322 | Pre-operative therapy: | - Subserosal: 71; - Subserosal/ intramural: 17; - Intramural: 8; - Intraligamen-tous associated/ another location: 4 | | Drop-out rates: NA
| N at follow-up: | NR | | | Statistical issues: -
| NA | Associated procedure(s): | | | EXTERNAL VALIDITY: poor (5)
| Age (mean): | NR | | | Age: -, NR
| 33.5 | | | | Race: NA, not US study
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Parity, parous, %: | | | | Fibroid/uterine size: -
| Nulliparous: 65 | | | | Number of fibroids: -
| Baseline Hgb/Hct: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: +, reported
| | | | | Length of follow-up: NA
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min (range): | Quality:
Damiani et al., 2003 | Prospective case series | - ≥ 1 symptomatic subserosal or intramural fibroid; - Fibroid > 30 mm | NR | 73 (35 to 145) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, (range): | Mean estimated blood loss, ml (range): | INTERNAL VALIDITY: fair
Italy; Academic medical center | Gasless laparoscopic myomectomy | NR | 3.1 (1 to 8) | 102 (40 to 320) | Random: NA
Enrollment period: | Groups: | Indications: | 21.1% had multiple fibroids | Fever >° 38C, N: | Methods and blinding: NA
04/1997 to 10/2001 | NA | NR | Baseline fibroid size, cm (range): | 3 | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy, N (%): | 5.9 cm (3–12 cm) | Length of stay, days (range): | Loss to follow-up: NA
NR | 279 | GnRHa: 48 (16.8) | Type of fibroid, N (%): | 2.6 (2 to 5) | Drop-out rates: NA
| N at follow-up: | Additional procedures: | - Intramural: 118 (42.3); - Subserosal: 161 (57.7); - Anterior: 71; - Fundal: 106; - Posterior: 102 | Modifiers: | Statistical issues: -
| NA | NR | | NR | EXTERNAL VALIDITY: fair (3)
| Age, yrs (range): | | | | Age: +, reported
| 35.2 (22 to 48) | | | | Race: NA, not US study
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Parity: | | | | Fibroid/uterine size: +
| NR | | | | Number of fibroids: +
| Baseline Hgb/Hct: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: -, NR
| | | | | Length of follow-up: NA
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Dessolle et al., 2001 | Prospective case series | - Age 18 to 43 yrs; - Infertility ≥ 24 mos; - Intramural or subserous fibroids > 3 cm in diameter; - < 4 myomas, and largest myoma < 10 cm | NR | G1: 150 ± 60 | Overall quality score: fair
Soriano et al., 2003 | Intervention: | Exclusion criteria: | Number of fibroids (mean ± SD): | G2: 148 ± 47 | INTERNAL VALIDITY: fair
Country and setting: | Laparoscopic myomectomy | - Anesthetic contraindications; - Only submucous fibroids | G1: 1.7 ± 0.6 | Complications, N: | Random: NA
France, Community | Groups: | Indications, N (%): | G2: 1.6 ± 0.6 | G1: 4* | Methods and blinding: NA
Enrollment period: | G1: Laparoscopic myomectomy | Primary infertility: | P = NS | G2: 2 | Pt selection criteria: ++
01/1990 to 10/1988 | G2: Laparoconversion for myomectomy | G1: 28 (31.8) | Baseline size of largest fibroid (cm ± SD): | Length of stay, days ± SD: | Loss to follow-up: NA
Funding: | N at enrollment: | G2: 6 (33.4) | G1: 6.2 ± 1.8 | G1: 3.0 ± 1 | Drop-out rates: NA
NR | G1: 88 | Pre-operative therapy: | G2: 8.1 ± 1.4 | G2: 5.5 ± 1 | Statistical issues: -
| G2: 18 | None | P < 0.001 | P < 0.001 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Associated procedure(s): | Type of fibroid, N (%): | Pregnancy rate, N (%): | Age: +, reported
| NR | NR | Subserosal: | G1: 42 (48) | Race: NA, not US study
| Age, yrs ± SD: | | G1: 31 (35) | G2: 10 (56) | Pregnancy history: -, NR
| G1: 36.1 ± 2.1 | | G2: 0 | P = NS | Surgical history: -, NR
| G2: 34.7 ± 2.4 | | Intramural: | Pregnancies, N: | Fibroid/uterine size: +
| Race/ethnicity: | | G1: 57 (65) | G1: 44 | Number of fibroids: +
| NR | | G2: 18 (100) | G2: 10 | Location of fibroids: +
| Parity: | | | P = NS | Baseline characteristics: +, reported
| NR | | | Spontaneous pregnancy, N (%): | Length of follow-up: ++
| Baseline Hgb/Hct: | | | G1: 36/44 (82) | Measurement methods: +
| NR | | | G2: 8/10 (80) | Measurement reliability: -
| | | | P = NS | Clinical care: +
| | | | Ovulation induction + IUI, N (%):
| | | | G1: 2 (5)
| | | | G2: 1 (10)
| | | | IVF + ET, N (%):
| | | | G1: 6 (13)
| | | | G2: 1 (10)
| | | | First-trimester miscarriage, N:
| | | | G1: 6
| | | | G2: 3
| | | | Abortion, N:
| | | | G1: 2
| | | | G2: 2
| | | | Dehiscence of uterine scar, N:
| | | | G1: 0
| | | | G2: 0
| | | | Vaginal delivery, N (%):
| | | | G1:26/34 (77)
| | | | G2: 2/4 (50)
| | | | Cesarean delivery, N (%):
| | | | G1: 8/34 (24)
| | | | G2: 2/4 (50)
| | | | Ectopic pregnancy, N:
| | | | G1: 1
| | | | G2: 0
| | | | Live newborn, N (%):
| | | | G1: 36/44 (41)
| | | | G2: 4/10 (40)
| | | | Premature delivery, N:
| | | | G1: 0
| | | | G2: 1
| | | | Time to conception, mos ± SD:
| | | | G1: 7.5 ± 2.6
| | | | G2: 15.1 ± 2.4
| | | | P < 0.001
| | | | Patients with unexplained infertility, N (%):
| | | | G1: 32/42 (76)
| | | | G2: 8/9 (89)
| | | | P = NS
| | | | Patients with minor infertility factors, N (%):
| | | | G1: 10/42 (24)
| | | | G2: 2/9 (22)
| | | | P = NS
| | | | Patients with primary infertility, N (%):
| | | | G1: 14/28 (50)
| | | | G2: 2/6 (33)
| | | | P = NS
| | | | Patients with secondary infertility, N (%):
| | | | G1: 28/60 (47)
| | | | G2: 8/12 (66)
| | | | P = NS
| | | | Adhesions, N (%):
| | | | G1: 12/16 (75)
| | | | G2: 4/4 (100)
| | | | Recurrence N (%):
| | | | G1: 6/66 (9)*
| | | | G2: 2/12 (17)
| | | | Re-operation (%):
| | | | G1: 0
| | | | G2: 2
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time range in min: | Quality:
Di Gregorio et al., 2001 | Retrospective case series | - Women who received myomectomy for symptomatic fibroids, infertility, or “size and/or number of fibroids required surgical treatment”; - Fibroid size ≥ 10 mm | NR | 30 to 140 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids N (range): | Conversion to laparotomy, N: | INTERNAL VALIDITY: fair
Italy, Specialty fibroid treatment center | Laparoscopic myomectomy | NR | 1 to 9 | 2/635 | Random: NA
Enrollment period: | Groups: | Indications, N: | Baseline fibroid size (mm): | Adhesions at second look, N (%): | Methods and blinding: NA
03/1988 to 04/2001 | NA | - Infertility: 445 | < 20: 633 (54%) | 2/121 (1.6) | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | 21 to 39: 357 (30.5%) | Modifiers: | Loss to follow-up: NA
NR | 635 patients | NR | 40 to 59: 123 (10.5%) | NR | Drop-out rates: NA
| (1,170 fibroids) | Additional procedures, N: | > 60: 57 (4.9%) | | Statistical issues: -
| N at follow-up: | - Adhesiolysis: 118; - Ovarian cystectomy: 89; - Coagulation of endometriotic lesions: 157; - Salpingectomy for ectopic pregnancy: 5; - Appendectomy: 5 | Type of fibroid, N (%): | | EXTERNAL VALIDITY: fair (3)
| 121 second look surgeries | | - Subserous: 630 (53.8); - Intramural: 412 (35.2); - Pedunculated: 128 (10.9) | | Age: -, NR
| Age, mean yrs (range): | | | | Race: NA, not US study
| 34.5 (24 to 51) | | | | Pregnancy history: +, reported
| Race/ethnicity: | | | | Surgical history: -, NR
| NR | | | | Fibroid/uterine size: +
| Parity, parous, N (%): | | | | Number of fibroids: +
| Overall: 278 (43.8) | | | | Location of fibroids: +
| Baseline Hgb/Hct: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: NA
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Recurrence rate, N (%): | Quality:
Doridot et al., 2001 | Retrospective case series | - Women undergoing laparoscopic myomectomy | NR | 45 (22.9%) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | Mean recurrence time, mos ± SD: | INTERNAL VALIDITY: fair
France, Academic medical center | Laparoscopic myomectomy | NR | 1: 114 (58.1) | 42 ± 22 (4–95) | Random: NA
Enrollment period: | Groups: | Indications, N (%): | 2: 36 (18.4) | Recurrence requiring surgery, N (%): | Methods and blinding: NA
03/1989 to 12/1996 | NA | - Pain: 51 (26); - Menometrorrhagia: 45 (23); - Infertility: 63 (32.1); - Size: 32 (16.3); - Pressure: 3 (1.5); - Recurrent miscarriage: 2 (1) | ≥ 3: 46 (23.5) | 8 (4.6) | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy: | Baseline fibroid size (mm), (%): | Second operative procedures, N: | Loss to follow-up: 10–20%
NR | 196 | - GnRH agonist, (%):; - No: 122 (70.5); - Yes: 51 (29.5) | < 50: 86 (43.9) | LM: 3 | Drop-out rates: NA
| N at follow-up: | Associated procedure(s): | 50 to 70: 67 (34.2) | Myomectomy by laparotomy: 1 | Statistical issues: +
| 173 | NR | ≥ 70: 43 (21.9) | Hysterectomy by laparotomy: 4 | EXTERNAL VALIDITY: good
| Age, yrs ± SD (range): | | Type of fibroid, N (%): | Cumulative risk of recurrence: | Age: +, reported
| 36.6 ± 6.6 (18 to 54) | | - Intramural: 74 (37.8); - Subserous: 97 (49.5); - Pedunculated: 25 (12.8) | At 2 yr: 12.7% | Race: NA, not US study
| Race/ethnicity: | | | At 5 yr: 16.7% | Pregnancy history: +, reported
| NR | | | Modifiers: | Surgical history: -, NR
| Parity, N (%): | | | Nulliparity, %: | Fibroid/uterine size: +
| 0: 143 (72.9) | | | At 2 yr: 12.8% | Number of fibroids: +
| 1: 40 (20.4) | | | At 5 yr: 47.6% P = 0.0025 | Location of fibroids: +
| 2: 10 (5.1) | | | Multivariate analysis of recurrence risk: | Baseline characteristics: +, reported
| 3: 3 (1.5) | | | - Nulliparity: P = 0.004; 95% CI, 1.4–8.7; - > 1 fibroid: P = 0.05; 95% CI, 0.27–0.98 | Length of follow-up: ++
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Dubuisson et al., 2001 | Retrospective case series | - Underwent LM at institution; - Subserous or intramural fibroid >20 mm in diameter; - Adequate ultrasound examination | NR | 129 ± 57 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids (mean ± SD): | Successful laparoscopic myomectomy: | INTERNAL VALIDITY: good
France, Academic medical center | Laparoscopic myomectomy | NR | 2.2 ± 1.8 | 378/426 (88.7) | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Baseline fibroid size (mm ± SD): | Conversion to laparoscopic-assisted myomectomy: | Methods and blinding: NA
03/1989 to 10/1999 | N at enrollment: | Meno-metrorrhagia: 123 (28.9) | 56 ± 22 | 33/426 (7.8) | Pt selection criteria: +
Funding: | 426 | Infertility/recurrent spontaneous abortion: 132 (32) | Type of largest fibroid, N (%)*: | Conversion to laparotomy: | Loss to follow-up: <10%
NR | N at follow-up: | Pain: 146 (34.3) | Intramural: 147 (55.5) | 15/426 (3.5) | Drop-out rates: NA
| 265 (with adequate preoperative ultrasound) | Pressure: 52 (12.2) | Subserous: 92 (34.7) | Modifiers: | Statistical issues: ++
| Age, yrs ± SD: | Size/rapid growth: 53 (12.4) | Pedunculated: 26 (9.8) | NR | EXTERNAL VALIDITY: fair (1)
| 37.8 ± 7.3 | Pre-operative therapy | | | Age: +, reported
| Race/ethnicity: | No: | | | Race: NA, not US study
| NR | Associated procedure(s), N: | | | Pregnancy history: -, NR
| Parity: | 3 (procedure not reported) | | | Surgical history: +, reported
| NR | | | | Fibroid/uterine size: +
| Baseline Hgb/Hct: | | | | Number of fibroids: +
| NR | | | | Location of fibroids: +
| | | | | Baseline characteristics: +, reported
| | | | | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, weeks gestation: | Mean EBL, ml: | Quality:
Elliot et al., 2005 | Retrospective cohort | - Open myomectomy cases logged in operating room logbooks | G1: 17 | G1: 705 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 18 | G3: 795 | INTERNAL VALIDITY: poor
UK, Academic medical center | Intra-operative uterine tourniquet during multiple myomectomy | NR | P = 0.55 | P = 0.10 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids: | Mean EBL/fibroid volume, ml/cm^3^: | Methods and blinding: NA
NR | G1: Tourniquet used | NR | NR | G1: 4.6 | Pt selection criteria: -
Funding: | G2: No tourniquet used | Pre-operative therapy: | Baseline fibroid size, cm^3^: | G2: 4.7 | Loss to follow-up: NA
NR | N at enrollment: | NR | G1: 603 | P = 0.83 | Drop-out rates: NA
| G1: 20 | Associated procedure(s): | G2: 395 | Mean EBL/uterine size (units not given): | Statistical issues: -
| G2: 37 | NR | P = 0.7 | G1: 38.1 | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | Type of fibroid: | G2: 40.6 | Age: +, reported
| NA | | NR | P = 0.84 | Race: +, reported
| Age (mean): | | | Mean fall in Hgb, g/dL: | Pregnancy history: -, NR
| G1: 35.9 | | | G1: 2.80 | Surgical history: -, NR
| G2: 35.8 | | | G2: 2.33 | Fibroid/uterine size: +
| Race/ethnicity, N (%): | | | P = 0.16 | Number of fibroids: -
| Afro-Caribbean: 44 (77.2) | | | Mean fall in Hgb/fibroid volume, g/dL/cm^3^: | Location of fibroids: -
| Parity: | | | G1: 0.02 | Baseline characteristics: -, NR
| NR | | | G2: 0.02 | Length of follow-up: NA
| Baseline Hgb/Hct: | | | P = 0.65 | Measurement methods: +
| NR | | | Intra-operative transfusion, N (range of units): | Measurement reliability: +
| | | | G1: 4 (1–3) | Clinical care: -
| | | | G2: 1 (2)
| | | | P > 0.1
| | | | Post-operative transfusion, N (range of units):
| | | | G1: 8 (1–3)
| | | | G2: 5 (1–7)
| | | | P > 0.1
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min: | Quality:
Fanfani et al., 2005 | Prospective cohort | - Symptomatic or infertility-associated fibroids; - < 5 intramural or subserosal fibroids with ≤10 cm diameter; - Age < 45 yrs | NR | G1: 61.6 (40 to 90) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed: | G2: 62.3 (45 to 80) | INTERNAL VALIDITY: good
Italy, Academic medical center | Laparoscopy and minilaparotomy myomectomy | - Submucosal and/or pedunculated fibroids; - Prior suprapubic longitudinal laparotomy | G1: 1.4 (1 to 3) | P = NS | Random: NA
Enrollment period: | Groups: | Indications: | G2: 2.9 (1 to 5) | Median estimated blood loss, ml: | Methods and blinding: NA
01/2003 to 12/2004 | G1: Laparoscopy | Infertility, N (%): | P < 0.05 | G1: 270 (100 to 420) | Pt selection criteria: ++
Funding: | G2: Mini-laparotomy | G1: 19 (20.5) | Baseline fibroid size, by largest fibroid removed (cm): | G2: 315 (150 to 400) | Loss to follow-up: <10%
NR | N at enrollment: | G2: 34 (28.4) | G1: 5.6 (4 to 9) | P = NS | Drop-out rates: <5%
| G1: 93 | AUB, N (%): | G2: 5.4 (4 to 9) | Intra-operative complications, N (%): | Statistical issues: +
| G2: 120 | G1: 30 (32.2) | Type of fibroid, N (%): | G1: 0 (0) | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | G2: 43 (35.8) | Intramural: | G2: 0 (0) | Age: +, reported
| G1: 93 | Pelvic pain, N (%): | G1: 79 (60.7) | P = NS | Race: NA, not US study
| G2: 120 | G1: 24 (25.8) | G2: 224 (64.3) | Postoperative anemia, N (%): | Pregnancy history: -, NR
| Age, mean yrs: | G2: 28 (23.3) | Subserosal: | G1: 0 (0) | Surgical history: +, reported
| G1: 34.4 (26 to 40) | Pre-operative therapy: | G1: 51 (39.3) | G2: 2 (1.7) | Fibroid/uterine size: +
| G2: 33.6 (24 to 39) | NR | G2: 124 (35.7) | P = NS | Number of fibroids: +
| Race/ethnicity: | Associated procedure(s): | | Fever > 38°C, N (%): | Location of fibroids: +
| NR | NR | | G1: 4 (4.3) | Baseline characteristics: +, reported
| Parity: | | | G2: 4 (3.3) | Length of follow-up: +
| NR | | | P = NS | Measurement methods: +
| Baseline Hgb/Hct: | | | Length of stay, days (range): | Measurement reliability: +
| NR | | | G1: 2.3 (2 to 3) | Clinical care: +
| | | | G2: 2.8 (2 to 3)
| | | | P = NS
| | | | Ileus, days:
| | | | G1: 1.4 (1 to 2)
| | | | G2: 1.3 (1 to 2)
| | | | P = NS
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, mean min (range): | Quality:
Glasser, 2005 | Retrospective case series | - Myomectomy | NR | 110 (55 to 260)* | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Mean estimated blood loss (range): | INTERNAL VALIDITY: fair
US, Community | Minilaparotomy myomectomy | - Laparoscopic myomectomy alone; - Abdominal incision > 6 cm | NR | 330 (50 to 2,000) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size, mean gm (range): | Length of stay, hrs (range): | Methods and blinding: NA
01/1995 to 12/2003 | NA | NR | 285.6 (30 to 925) | 13.6 (4 to 48) | Pt selection criteria: ++
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | Modifiers: | Loss to follow-up: NA
NR | 139 | GnRHa: 70/139 | NR | None | Drop-out rates: NA
| N at follow-up: | Additional procedures: | | | Statistical issues: -
| NA | NR | | | EXTERNAL VALIDITY: poor (7)
| Age, mean yrs: | | | | Age: +, reported
| 38.9 (23 to 56) | | | | Race: -, NR
| Race: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Parity: | | | | Fibroid/uterine size: +
| NR | | | | Number of fibroids: -
| Baseline Hgb/Hct: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: +, reported
| | | | | Length of follow-up: +
| | | | | Measurement methods: -
| | | | | Measurement reliability: -
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^: | At least 1 adverse event, N (%): | Quality:
Goodwin et al., 2006 | Prospective cohort | - Symptomatic fibroids confirmed on MRI; - ≥ 30 yr old; - Regular menses; - Normal Pap smear; - Able to complete follow-up requirements | G1: 658.4 | G1: 33 (22.1) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 590.6 | G2: 24 (40) | INTERNAL VALIDITY: good
US, Academic medical centers | UAE vs. myomectomy | - Hysteroscopically resectable fibroids; - Pelvic infection; - Gynecologic malignancy; - Undiagnosed pelvic mass outside of uterus; - Unexplained abnormal menstrual bleeding; - Infection; - Coagulopathy; - History of pelvic irradiation; - ASA score ≥ 4; - FSH level > 40 IU/L; - Participation in any other investigational device or drug study; - Desire to become pregnant; - Abnormal serum creatinine level; - Uterine arteriovenous fistula; - Severe contrast allergy; - Pedunculated subserosal fibroid | P > 0.05 | P < 0.01 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Number of fibroids N (%): | Major adverse event, N: | Methods and blinding: NA
NR | G1: UAE | Abnormal bleeding | 0 | G1: 6. | Pt selection criteria: ++
Funding: | G2: Myomectomy | G1: 77 (51.7) | G1: 2 (1.3) | G2: 1 | Loss to follow-up: 10–20%
Boston Scientific Corporation | N at enrollment: | G2: 20 (33.3) | G2: 1 (1.7) | P < 0.05 | Drop-out rates: <5%
| G1: 149 | P = 0.02 | 1 | Length of stay, mean hrs: | Statistical issues: ++
| G2: 60 | Bulk/pressure | G1: 9 (6.0) | G1: 23.8 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | G1: 38 (25.5) | G2: 5 (8.3) | G2: 61.6 | Age: +, reported
| G1: 12o (1 yr) | G2: 16 (26.7) | 2 | P < 0.0001 | Race: -, NR
| G2: 54 (6 mos) | Pelvic pain | G1: 10 (6.7) | Dominant fibroid volume, 3 mos or 6 mos: | Pregnancy history: +, reported
| Age, mean yrs: | G1: 29 (19.5) | G2: 4 (6.7) | P = NS | Surgical history: -, NR
| G1: 43.9 | G2: 18 (30.0) | 3 | Quality-of-life assessments, 6 mos: | Fibroid/uterine size: +
| G2: 38.2 | Infertility | G1: 10 (6.7) | P = NS | Number of fibroids: +
| P < 0.0001 | G1: 0 (0.0) | G2: 8 (13.3) | Menstrual bleeding score, 3 mos or 6 mos: | Location of fibroids: +
| Race: | G2: 2 (3.3) | 4 | P = NS | Baseline characteristics: +, reported
| NR | Other | G1: 10 (6.7) | Return to normal activities, mean days: | Length of follow-up: ++
| Parity, parous (%): | G1: 5 (3.4) | G2: 7 (11.7) | G1: 14.6 | Measurement methods: +
| G1: 75.2 | G2: 4 (6.7) | 5 | G2: 44.4 | Measurement reliability: +
| G2: 48.3 | Preoperative therapy: | G1: 6 (4.0) | P < 0.05 | Clinical care: -
| P < 0.0001 | NR | G2: 2 (3.3) | Missed workdays:
| Baseline Hgb/Hct: | Additional procedures: | 6–10 | G1: 9.9
| NR | NR | G1: 27 (18.1) | G2: 37.0
| | | G2: 14 (23.3) | P < 0.001
| | | >10 | Modifiers:
| | | G1: 75 (50.3) | NR
| | | G2: 13 (21.7)
| | | P = 0.0001
| | | Baseline dominant fibroid size, cm^3^:
| | | G1: 182.12
| | | G2: 226.92
| | | P = 0.081
| | | Type of fibroid, N (%):
| | | Intramural
| | | G1: 88 (59.1)
| | | G2: 26 (43.3)
| | | Submucosal
| | | G1: 1 (0.007)
| | | G2: 3 (5.0)
| | | Submucosal pedunculated
| | | G1: 17 (11.4)
| | | G2: 2 (3.3)
| | | Sebserosal
| | | G1: 8 (5.4)
| | | G2: 8 (13.3)
| | | Subserosal pedunculated
| | | G1: 31 (20.8)
| | | G2: 13 (21.7)
| | | Other
| | | G1: 0 (0.0)
| | | G2: 1 (1.7)
| | | Cannot determine
| | | G1: 2 (1.3)
| | | G2: 0 (0.0)
| | | Missing
| | | G1: 2 (1.3)
| | | G2: 7 (11.7)
Author: | Design: | Inclusion criteria: | Baseline uterine size, median: | 5 year cumulative probability: | Quality:
Hanafi, 2005 | Retrospective case series | NR | 10 gestational weeks | Fibroid recurrence: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | 62% | INTERNAL VALIDITY: fair
US, Community | Myomectomy by exploratory laporotomy | NR | 1: 37 (26) | Any surgery for recurrence: | Random: NA
Enrollment period: | Groups: | Indications, %: | > 1: 108 (74) | 17% | Methods and blinding: NA
01/1992 to 10/2002 | NA | - Menometrorrhagia: 91; - Dysmenorrhea: 82; - Dyspareunia: 41; - Noncyclic pelvic pain: 22; - Anemia: 3; - Infertility: 30; - No symptoms: 3 | Baseline fibroid size, median gm (range): | Major surgery for recurrence: | Pt selection criteria: -
Funding: | N at enrollment: | Preoperative therapy: | 103 (8–590) | 9% | Loss to follow-up: <10%
NR | 154 | None | (N=28) | Modifiers of fibroid recurrence: | Drop-out rates: <5%
| N at follow-up: | Associated procedure(s): | Type of fibroid, N (%): | Number of fibroids: | Statistical issues: +
| 132 | NR | - Subserous: 34 (23); - Intramural or intramural/ subserous: 98 (68); - Submucous or intramural/ submucosal: 6 (4); - All locations: 7 (5) | 1 fibroid: 11% | EXTERNAL VALIDITY: fair (3)
| Age, median yr: | | | > 1 fibroid: 74% | Age: +, reported
| 36 (24 to 49) | | | P = 0.011 | Race: +, reported
| Race/ethnicity: | | | Uterine size: | Pregnancy history: +, reported
| NR | | | ≤ 10 weeks: 46% | Surgical history: -, NR
| Parity, median: | | | > 10 weeks: 82% | Fibroid/uterine size: +
| 1 (0 to 6), 89% had not completed families | | | P = 0.03 | Number of fibroids: +
| Baseline Hgb/Hct: | | | Subsequent parity: 26% | Location of fibroids: -
| NR | | | Without subsequent parity: 76% | Baseline characteristics: +, reported
| | | | P = 0.010 | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Repeat resection among women with fibroids, N (%): | Quality:
Istre and Langebrekke, 2003 | Retrospective cohort | - Failed conservative medical treatment, including hormone therapy | NR | 33/188 (17) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Hysterectomy after repeat resection, N (%): | INTERNAL VALIDITY: poor
Norway, National registry and hospital database | Follow-up women who failed conservative medical treatment for fibroids | NR | NR | 12/33 (36) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Modifiers: | Methods and blinding: NA
1989 to 1996 | Patients with fibroid resection | NR | NR | NR | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | | Loss to follow-up: 10–20%
NR | 188 | NA | NR | | Drop-out rates: <5%
| N at follow-up (“at least 4 yr”): | Additional procedures: | | | Statistical issues: -
| 188 | NR | | | EXTERNAL VALIDITY: poor (5)
| Age: | | | | Age: -, NR
| NR | | | | Race: NA, not US study
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: +, reported
| Parity: | | | | Fibroid/uterine size: -
| NR | | | | Number of fibroids: -
| Baseline Hgb/Hct: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics:+, reported
| | | | | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Kumakiri et al., 2005 | Retrospective case series | - Menorrhagia and abdominal fullness; - Infertility; - Fibroids ≥ 5 cm; - Wishing to have children; - Largest fibroid ≤ 12 cm; - Uterus size ≤ 14 weeks gestation | NR | Pregnancy: 105.3 ± 45.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids enucleated, mean ± SD: | No pregnancy: 106.0 ± 51.5 | INTERNAL VALIDITY: fair
Japan, Academic medical center | Laparoscopic myomectomy | See inclusion criteria | Pregnancy: 3.2 ± 2.7 | P =0.75 | Random: NA
Enrollment period: | Groups: | Indications, N: | No pregnancy: 3.7 ± 3.6 | Mean estimated blood loss, ml ± SD: | Metods and blinding: NA
01/1998 to 12/2002 | NA | Infertility: 59 | P = 0.04 | Pregnancy: 85.2 ± 105.8 | Pt selection criteria: +
Funding: | N at enrollment: | Menorrhagia: 20 | Baseline largest fibroid size mm ± SD: | No pregnancy: 120.3 ± 174.5 | Loss to follow-up: <10%
NR | 108 | Dysmenorrhea: 17 | Pregnancy: 67.5 ± 16.9 | P =0.53 | Drop-out rates: NA
| N at follow-up: | Lower abdominal pain: 6 | No pregnancy: 62.3 ± 16.3 | Pregnancy success rate, N (%): | Statistical issues: -
| NA | Other: 6 | P = 0.004 | 40/108 (37) | EXTERNAL VALIDIT: fair (2)
| Age, yrs ± SD: | Pre-operative therapy, N (%): | Type of fibroid: | Spontaneous pregnancies, N (%): | Age: +, reported
| 35.5 ± 3.5 | GnRH: 86 (79.6) | NR | 40/47 (85.1) | Race: NA, not US study
| Race/Ethnicity: | Associated procedure(s): | | ART pregnancies, N (%); | Pregnancy history: -, NR
| NA | NR | | 7/47 (14.9) | Surgical history: -, NR
| Parity, parous (N): | | | Miscarriages, N (%): | Fibroid/uterine size: +
| Multiparous: 10 | | | 11/47 (23.4) | Number of fibroids: +
| Baseline Hgb/Hct: | | | Ectopic, N: | Location of fibroids: +
| NR | | | 1/47 (2.1) | Baseline characteristics: +, reported
| | | | Live births, N (%): | Length of follow-up: +
| | | | 32/47 (68.1) | Measurement methods: +
| | | | Elective Cesarean delivery, N (%): | Measurement reliability: +
| | | | 9/32 (28.1) | Clinical care: +
| | | | VBALM failure, N (%):
| | | | 4/23 (17.4)
| | | | Modifiers:
| | | | Pregnancy rate correlated positively with diameter of largest fibroid:
| | | | OR =1.06; 95% CI, 1.02–1.10
| | | | P = 0.004
| | | | Modifiers:
| | | | Pregnancy rate correlated negatively with age at myomectomy:
| | | | OR = 0.88; 95% CI, 0.80–0.98
| | | | P = 0.02
| | | | Pregnancy rate correlated negatively with number of enucleated fibroids:
| | | | OR =1.17; 95% CI, 1.01–1.37
| | | | P = 0.04
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Landi et al., 2001 | Prospective case series | - Healthy; - Non-pregnant; - Undergoing laparoscopic myomectomy | NR | 100.7 ± 43.8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, %: | Mean estimated blood loss, ml ± SD: | INTERNAL VALIDITY: poor
Italy, Academic medical center | Laparoscopic myomectomy | - Pre-operative medical therapy with GnRH agonists | One: 52.3 | 381.4 ± 324.8 | Random: NA
Enrollment period: | Groups: | Indications, %: | Two: 18.9 | Estimated blood loss < 100 ml, N: | Methods and blinding: NA
05/1997 to 09/1999 | NA | - Pelvic mass: 170 (46.2); - AUB: 82 (22.3); - Pelvic pain: 69 (18.8); - Primary infertility: 16 (4.3) | Three: 11.6 | 63 | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | Four: 6.6 | Conversion to laparotomy, N %: | Loss to follow-up: >20%
NR | 368 | None | ≥ Five: 10.0 | 8 (2.1) | Drop-out rates: NA
| N at follow-up, 1 mo: | Additional procedures, N, (%): | (totals to 99.4%) | Any operative complications | Statistical issues: -
| 282 | - Endometrial biopsy: 151 (41); - Adhesiolysis: 108 (29.3); - Chromoperturbation: 55 (14.9); - Coagulation of endometriosis: 50 (13.5); - Ovarian cystectomy: 44 (11.9) | Baseline diameter of largest fibroid, (mm ± SD): | (major vessel, ureteral, bladder, bowel injury, needle breaks, uterine manipulator and sound injuries), N %: | EXTERNAL VALIDITY: fair (2)
| Age, yr ± SD: | | 56.9 ± 27.6 | 12 (3.3) | Age: +, reported
| 37.1 ± 6.9 | | Type of fibroids, %: | Decrease in Hgb, g/100 ml ± SD: | Race: NA, not US study
| Race/ethnicity: | | Subserous: 37.2 | 1.38 ± 0.93 | Pregnancy history: -, NR
| NR | | Intramural: 41.4 | Transfusion, N: | Surgical history: -, NR
| Parity: | | Pedunculated: 16.5 | 4 | Fibroid/uterine size: +
| NR | | Intraligamentous: 4.8 | Fever > 38°C, N %: | Number of fibroids: +
| Baseline Hgb/Hct: | | (N = 768) | 12 (3.3) | Location of fibroids: +
| NR | | | Intermittent pelvic pain, N: | Baseline characteristics: +, reported
| | | | 5 | Length of follow-up: +
| | | | Length of stay, days ± SD: | Measurement methods: +
| | | | 2.89 ± 1.30 | Measurement reliability: +
| | | | Any cuff hematoma, pelvic hematoma, wound infection, antibiotic treatment, wound dehiscence, N: | Clinical care: +
| | | | 18
| | | | Time to subjective well-being, days ± SD:
| | | | 10.58 ± 6.68
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Bleeding controlled, N (%): | Quality:
Loffer, 2005 | Retrospective cohort | - All hysteroscopic myomectomies by a single surgeon for premenopausal women with menorrhagia/ menometrorrhagia | NR | G1: 70 (95.9) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 84 (80.8) | INTERNAL VALIDITY: fair
US, Academic medical center | Endometrial ablation at time of hysteroscopic myomectomy for submucosal fibroids | - Procedures done by author outside US or for which follow-up information was unavailable | G1: 1.5 ± 1.1 | P = 0.003 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 1.5 ± 1.1 | (OR = 0.18; 95%CI, 0.05–0.63) | Methods and blinding: NA
08/1984 to 08/2003 | G1: Endometrial ablation | - Menorrahagia and/or metrorrhagia | P = 0.96 | Success (no recurrence of bleeding problems or hysterectomy): | Pt selection criteria: +
Funding: | G2: Without endometrial ablation | Pre-operative therapy, N (%): | Baseline fibroid size, cm ± SD: | Log Rank = 5.3; | Loss to follow-up: <10%
NR | N at enrollment: | Endometrial suppression: | G1: 3.0 ± 1.1 | P = 0.02 | Drop-out rates: NA
| G1: 73 | G1: 58 (79.5) | G2: 3.4 ± 1.5 | (Kaplan-Meier survival analysis) | Statistical issues: -
| G2: 104 | G2: 22 (27.5) | P = 0.06 | Modifiers: | EXTERNAL VALIDITY: poor (4)
| N at follow-up (12 mos): | Associated Procedure(s): | Type of fibroid, %: | Complete vs. incomplete removal of fibroids | Age: +, reported
| G1: 72 | NR | Type 0: | Success (defined above), N (%): | Race: -, NR
| G2: 103 | | G1: 30.1 | G1 with complete removal: 58 of 60 (96.7) | Pregnancy history: -, NR
| Age, yrs ± SD: | | G2: 33.7 | G1 with incomplete removal: 12 of 13 (92.3) | Surgical history: -, NR
| G1: 44.0 ± 4.7 | | Type I: | G2 with complete removal: 65 of 77 (84.4) | Fibroid/uterine size: +
| G2: 37.6 ± 6.0 | | G1: 49.3 | G2 with incomplete removal: 19 of 27 | Number of fibroids: +
| P < 0.001 | | G2: 36.5 | (70.4) | Location of fibroids: +
| Race/ethnicity: | | Type II: | Hysterectomy, N (%): | Baseline characteristics: -, NR
| NR | | G1: 20.5 | G1 with complete removal: 11 (18.3) | Length of follow-up: ++
| Parity: | | G2: 29.8 | G1 with incomplete removal: 2 (15.4) | Measurement methods: +
| NR | | | G2 with complete removal: 13 (16.9) | Measurement reliability: +
| (15 infertile, no ablations in this group) | | | G2 with incomplete removal: 10 (37) | Clinical care: +
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, mean min (range): | Quality:
Malzoni et al., 2003 | Retrospective case series | - Undergoing laparoscopic myomectomy | NR | 85 (58 to 180) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Fibroids removed, N (%): | Conversion to laparotomy, N (%): | INTERNAL VALIDITY: fair
Italy, Community | Laparoscopic myomectomy for fibroids ≥ 5cm | NR | 1: 84 (58.33) | 2 (1.39) | Random: NA
Enrollment period: | Groups: | Indications, N (%): | 2: 35 (24.3) | Transfusion, N (%): | Methods and blinding: NA
01/1997 to 07/1999 | NA | - Infertility: 102 (70.8); - Abnormal bleeding: 98 (68); - Pain: 64 (44.4); - More than 1 symptom: 81 (56.2) | 3: 17 (11.8) | 1 (0.69) | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy: | 4: 6 (4.17) | Length of stay, days (range): | Loss to follow-up: NA
NR | 144 | None | Baseline dominant fibroid size, mean cm (range): | 2.6 (2 to 5) | Drop-out rates: NA
| N at follow-up: | Associated procedure(s), N (%): | 7.8 (5 to 18) | Intramural hematoma, N (%): | Statistical issues: -
| NR | - Lysis: 24 (16.6); - Tubal plasty: 6 (4.16); - Appendectomy: 5 (3.47); - Ovarian cystectomy: 4 (2.77); - Coagulation of endometriosis: 3 (2.08) | Type of fibroid, N (%): | 1 day post-op: 108 (75) | EXTERNAL VALIDITY: fair (1)
| Age, mean yrs: | | - Interstitial submucous: 108 (75); - Subserous sessile: 15 (10.4); - Pedunculated: 7 (4.86); - Intraligamen-tous: 14 (9.7) | 2 day post-op: 14 (9.7) | Age: +, reported
| 33.7 (22 to 41) | | | Pregnancy rate N (%)*: | Race: NA, not US study
| Race/ethnicity: | | | 26 in 21 patients (25%) | Pregnancy history: +, reported
| NR | | | Spontaneous: 20 | Surgical history: -, NR
| Parity, parous, N (%): | | | After IVF: 1 | Fibroid/uterine size: +
| Nulligravida: 98 (60.5) | | | Live birth, N: | Number of fibroids: +
| Baseline Hgb/Hct: | | | 21 | Location of fibroids: +
| NR | | | Cesarean delivery, N: | Baseline characteristics: +, reported
| | | | 12/21 | Length of follow-up: +
| | | | Vaginal delivery, N: | Measurement methods: +
| | | | 9/21 | Measurement reliability: +
| | | | Uterine rupture, N: | Clinical care: +
| | | | 0
| | | | Miscarriage, N:
| | | | 4/26
| | | | Ectopic pregnancy, N:
| | | | 1/26
| | | | Pregnancy rate, 1997, N (%):
| | | | 6-mon: 13/38 (34.21)
| | | | 12-mon: 21/38 (55.26)
| | | | Adhesions at 2nd-look, N (%):
| | | | 6/18 (33)
| | | | Severity of adhesions, N (%):
| | | | Type 1: 4 (22.2)
| | | | Type 2: 2 (11.1)
| | | | Type 3: 0
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Risk of laparoconversion, multivariate: | Quality:
Marret et al., 2006 | Retrospective case series | - Planned laparoscopic myomectomy | NR | Increase in largest fibroid size of 1 mm: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | OR = 1.06 | INTERNAL VALIDITY: good
France, Academic medical center and Community | Myomectomy | - Missing medical record data | G1: 2.4 ± 2.5 | (95% CI, 1.03–1.09) | Random: NA
Enrollment period: | Groups: | Indications: | G2: 1.7 ± 1.8 | P < 0.001 | Methods and blinding: NA
01/1996 to 12/2000 | G1: Conversion to laparotomy | - Pelvic pain: 41%; - Infertility: 38%; - Bleeding: 14% | Baseline largest fibroid size, mm ± SD: | Dominant fibroid intramural: | Pt selection criteria: +
Funding: | G2: Laparoscopy | Pre-operative therapy: | G1: 67.9 ± 18.2 | OR = 3.24 | Loss to follow-up: NA
NR | N at enrollment: | GnRHa: | G2: 47.8 ± 18.6 | (95% CI, 1.11–10.21) | Drop-out rates: NA
| G1: 33 | G1: 1 (3.0) | Type of fibroid, N (%): | P = 0.036 | Statistical issues: +
| G2: 83 | G2: 2 (2.4) | Subserous: | Surgeon's experience (senior vs. junior): | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | P = NS | G1: 19 (57.6) | OR = 0.15 | Age: -, NR
| NA | Associated procedure(s): | G2: 61 (73.5) | (95% CI, 0.04–0.46) | Race: -, NR
| Age: | NR | Intramural: | P = 0.001 | Pregnancy history: -, NR
| NR | | G1: 15 (45.5) | | Surgical history: -, NR
| Race/ethnicity: | | G2: 21 (25.3) | | Fibroid/uterine size: +
| NR | | | | Number of fibroids: +
| Parity: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: +, reported
| Baseline Hgb/Hct: | | | | Length of follow-up: NA
| NR | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Marret et al., 2004 | Retrospective cohort | NR | NR | G1: 89 ± 33 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, median (range): | G2a: 89 ± 45 | INTERNAL VALIDITY: poor
France, Community and Academic medical centers | Myomectomy (abdominal vs. laporoscopic) | NR | G1: 1 (1 to 18) | G2b: 98 ± 30 | Random: NA
Enrollment period: | Groups: | Indications, %: | G2: 1 (1 to 15) | G1 vs. G2a: | Methods and blinding: NA
01/1996 to 01/2000 | G1: Abdominal myomectomy | Pain: | P = 0.010 | P = 0.963 | Pt selection criteria: -
Funding: | G2: Laparoscopic myomectomy | G1: 35 | Baseline largest fibroid size, mm ± SD: | G2a vs. G2b: | Loss to follow-up: <10%
French Society of Gynaecology and Obstetrics West Group | G2a: Laparoscopy | G2: 41 | G1: 81.4±39.7 | P = 0.248 | Drop-out rates: NA
| G2b: Laparoconversion | Infertility: | G2: 53.7±20.4 | Mean estimated blood loss, ml ± SD: | Statistical issues: -
| N at enrollment: | G1: 35 | P < 0.001 | G1: 504 ± 542 | EXTERNAL VALIDITY: poor (6)
| G1: 176 | G2: 38 | Type of fibroid N (%): | G2a: 226 ± 320 | Age: -, NR
| G2: 126 | Bleeding: | Subserous: | G2b: 643 ± 999 | Race: -, NR
| G2a: 89 | G1: 30 | G1: 83 (47.4) | G1 vs. G2a: | Pregnancy history: -, NR
| G2b: 37 | G2: 14 | G2: 85 (69.7) | P = 0.039 | Surgical history: -, NR
| N at follow-up, 2 yr: | Preoperative therapy, %: | P < 0.001 | G2a vs. G2b: | Fibroid/uterine size: +
| G1: 176 | GnRH agonists | Intramural: | P = 0.114 | Number of fibroids: +
| G2: 126 | G1: 16 | G1: 89 (51.1) | Decrease in Hgb, g/dL ± SD: | Location of fibroids: +
| G2a: 89 | G2: 3 | G2: 36 (29.5) | G1: 2.6 ± 1.6 | Baseline characteristics: +, reported
| G2b: 37 | Additional procedures: | P < 0.001 | G2a: 1.6 ± 1.4 | Length of follow-up: +
| Age: | NR | | G2b: 2.6 ± 1.4 | Measurement methods: +
| NR | | | G1 vs. G2a: | Measurement reliability: -
| Race/ethnicity: | | | P < 0.001 | Clinical care: -
| NR | | | G2a vs. G2b:
| Parity: | | | P = 0.005
| NR | | | Transfusions, N (%):
| Baseline Hgb/Hct: | | | G1: 9/173 (5.2)
| NR | | | G2a: 0/88 (0.0)
| | | | G2b: 2/35 (5.7)
| | | | G1 vs. G2a:
| | | | P = 0.031
| | | | G2a vs. G2b:
| | | | P = 0.079
| | | | Fever, N (%):
| | | | G1: 28 (15.9) G2a: 1/88 (1.1)
| | | | G2b: 2/35 (5.7)
| | | | G1 vs. G2a:
| | | | P < 0.001
| | | | G2a vs. G2b:
| | | | P = 0.195
| | | | Length of stay, days ± SD:
| | | | G1: 6.9 ± 2.0
| | | | G2a: 3.6 ± 1.3
| | | | G2b: 6.5 ± 1.8
| | | | G1 vs. G2a:
| | | | P < 0.001
| | | | G2a vs. G2b:
| | | | P < 0.001
| | | | Uterine cavity opening, N (%):
| | | | G1: 58/173 (33.5)
| | | | G2a: 7 (7.9)
| | | | G2b: 7/36 (19.4)
| | | | G1 vs. G2a:
| | | | P < 0.001
| | | | G2a vs. G2b:
| | | | P = 0.113
| | | | Complications or injuries, N (%):
| | | | G1: 4/176 (2.3)
| | | | G2a: 2/89 (2.2)
| | | | G2b: 2/35 (5.7)
| | | | G1 vs. G2a:
| | | | P = 1.000
| | | | G2a vs. G2b:
| | | | P = 0.316
| | | | Wound hematoma, N (%):
| | | | G1: 10 (5.7)
| | | | G2a: 1 (1.1)
| | | | G2b: 3/35 (8.6)
| | | | G1 vs. G2a:
| | | | P = 0.106
| | | | G2a vs. G2b:
| | | | P = 0.068
| | | | Wound infection, N (%):
| | | | G1: 1 (0.6)
| | | | G2a: 0 (0.0)
| | | | G2b: 0 (0.0)
| | | | G1 vs. G2a:
| | | | P = 1.000
| | | | Endometritis, N (%):
| | | | G1: 1 (0.6)
| | | | G2a: 0 (0.0)
| | | | G2b: 0 (0.0)
| | | | G1 vs. G2a:
| | | | P = 1.000
| | | | Deep vein thrombosis, N (%):
| | | | G1: 0 (0.0)
| | | | G2a: 0 (0.0)
| | | | G2b: 0 (0.0)
| | | | G1 vs. G2a:
| | | | P = 1.000
| | | | Urinary tract infection, N (%):
| | | | G1: 7 (4.0)
| | | | G2a: 0 (0.0)
| | | | G2b: 0 (0.0)
| | | | G1 vs. G2a:
| | | | P = 1.000
| | | | Surgeon's experience (consultant/ fellow), N (%):
| | | | G2a: 69/82 (84.1)
| | | | G2b: 18/32 (56.2)
| | | | G2a vs. G2b:
| | | | P < 0.001
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Conversion to open myomectomy, N: | Quality:
Marziani et al., 2005 | Prospective case series | - Excessive uterine bleeding defined by history with Hgb < 10 g/dl and Hct < 37; - Infertility; - Fibroids defined by transvaginal ultrasound and diagnostic hysteroscopy | NR | 3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean (range): | Conversion to hysterectomy, N: | INTERNAL VALIDITY: fair
Italy, Academic medical center | Hysteroscopic myomectomy | - Myoma size ≥ 3 cm; - Intramural fibroid with < 5 mm of myometrium between fibroid and serosa; - Adnexal pathology; - Abnormal endometrial biopsy | 1.5 (1 to 3) | 2 | Random: NA
Enrollment period: | Groups: | Indications, N (%) | Baseline fibroid size, cm^3^± SD: | Uterine perforation, N: | Methods and blinding: NA
01/1997 to 12/2001 | G1: Women with submucous uterine fibroids | - Abnormal uterine bleeding: 84 (78.5); - Infertility: 23 (21.5) | Type 0: 22 ± 9 | 0 | Pt selection criteria: ++
Funding: | N at enrollment: | Pre-operative therapy: | Type 1: 25 ± 9 | Post-operative hemorrhage, N: | Loss to follow-up: <10%
NR | 107 | GnRH to reduce size of fibroid if ≥ 3 cm or desired by surgeon | Type 2: 23 ± 10 | 3 | Drop-out rates: NA
| N at follow-up, 36 mos: | Associated procedure(s): | Type of fibroid, N (%): | Number of procedures, N (%): | Statistical issues: -
| G1: 104 | NR | Type 0: 51 (47.7) | One: 91 (85) | EXTERNAL VALIDITY: fair (3)
| Age, mean yrs: | | Type 1: 43 (40.2) | Two: 16 (15) | Age: +, reported
| G1: 35 (30 to 46) | | Type 2: 13 (12.1) | Control of menorrhagia, N (%): | Race: NA, not US study
| Race/ethnicity: | | | - One procedure: 68 (81.0); - Two procedures: 11 (13.1); - Not controlled: 5 (4.7) | Pregnancy history: -, NR
| NR | | | Modifiers: | Surgical history: -, NR
| Parity: | | | Number of fibroids and control of menorrhagia after one procedure: | Fibroid/uterine size: +
| NR | | | - 1 fibroid: 46 of 46 (100%); - 2 fibroids: 21 of 24 (87.5%); - 3 fibroids: 12 of 14 (85.7%) | Number of fibroids: +
| Baseline Hgb/Hct: | | | P < 0.05 | Location of fibroids: +
| G1: 10.33 g/dL | | | | Baseline characteristics: +, reported
| | | | | Length of follow-up: -
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | No adhesions on 2nd look, N (%): | Quality:
Mettler et al., 2004 | RCT | - Age ≥ 18; - Candidates for myomectomy via laparoscope or laparotomy; “thought to benefit from second-look laparoscopy within 16 weeks of surgery” | NR | G1: 7 of 22 (31.8) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Baseline fibroid size: | G2: 2 of 18 (11.1) | INTERNAL VALIDITY: poor
Germany and France, Academic medical center and specialty fibroid treatment center | Sprayable adhesion barrier after myomectomy | NR | NR | P = NS | Random: -
Enrollment period: | (SprayGel; Confluent Surgical, Waltham, MA) | Indications, N (%): | Number of fibroids removed, mean ± SD: | Severity of adhesions (tenacity score: 0 = none; 1 = filmy, avascular; 2 = vascular, dense; 3 = cohesive): | Methods and blinding: +
NR | Groups: | Infertility: | G1: 2.6 ± 3.2 | G1: 1.0 | Pt selection criteria: ++
Funding: | G1: Myomectomy plus adhesion barrier | G1: 11 (32.4) | G2: 2.6 ± 3.2 | G2: 1.9 | Loss to follow-up: >20%
Confluent Surgical | G2: Myomectomy alone | G2: 9 (30) | Weight of fibroids removed, gm ± SD: | P = 0.002 | Drop-out rates: 5–10%
(Phase III Trial) | N at enrollment: | Pain: | G1: 115.0 ± 121 | Extent of adhesions, median area of uterus involved in cm^2^: | Statistical issues: -
| G1: 34 | G1: 16 (47.1) | G2: 101.0 ± 104 | G1: 7.4 | EXTERNAL VALIDITY: poor (5)
| G2: 30 | G2: 16 (53.3) | Type of fibroid, N (%) | G2: 7.8 | Age: +, reported
| N at follow-up: | Other: | Intramural: | P = NS | Race: NA, not US study
| G1: 34 | G1: 7 (20.6) | G1: 29 (84.4) | Increased incidence of adhesions: | Pregnancy history: -, NR
| G2: 30 | Other: 5 (16.7) | G2: 27 (89.7) | G1: 0.64 | Surgical history: -, NR
| N at second look, N (%): | Pre-operative therapy: | Number of uterine incisions, mean ± SD: | G2: 1.22 | Fibroid/uterine size: -
| G1: 22 (64.7) | NR | G1: 1.9 ± 1.5 | P = 0.035 | Number of fibroids: -
| G2: 18 (60.0) | Associated procedure(s): | G2: 1.5 ± 1.2 | Increased adhesion area from baseline, median increase in area of uterus involved cm^2^: | Location of fibroids: +
| Age, yrs ± SD: | Myomectomy by laparotomy: | Length of uterine incisions, mean cm ± SD: | G1: 4.5 | Baseline characteristics: +, reported
| G1: 34.9 ± 5.2 | G1: 6 | G1: 7.4 ± 4.9 | G2: 7.2 | Length of follow-up: -
| G2: 35.0 ± 5.9 | G2: 7 | G2: 7.0 ± 4.6 | P = NS | Measurement methods: +
| Race/ethnicity: | | | Modifiers: | Measurement reliability: +
| NR | | | NR | Clinical care: +
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time (median mins): | Quality:
Munoz et al., 2003 | Retrospective case series | - Symptomatic fibroid or infertility; - Desire for uterine preservation; - Fibroid <6cm; - Less than 50% of endometrial surface affected | NR | 32.5 (10–105) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Uterine perforation: | INTERNAL VALIDITY: fair
Spain, Academic medical center | Hysteroscopic myomectomy | - Labastida's Type V fibroid; - Pathology that contraindicates procedure | NR | N = 1 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Baseline fibroid size, cm (%): | Hemorrhage: | Methods and blinding: NA
01/1992 to 12/1999 | NA | - AUB: 101 (84.1); - Infertility: 14 (11.6); - Pain: 7 (5.8%) | 1: 5 (4.1) | N = 1 | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy, N (%) | 2: 31 (25.8) | Unable to complete procedure: | Loss to follow-up: <10%
NR | 120 | - None: 39 (32.5); - Danazol: 9 (7.5); - GnRHa: 72 (60) | 3: 63 (52.5) | N = 22 | Drop-out rates: NA
| N at follow-up: | Associated procedure(s), N (%): | 4: 19 (15.9) | Length of stay, N (%): | Statistical issues: -
| 120 | 37 (30.8) | 5: 2 (1.7) | 12 hrs: 15 (47.5) | EXTERNAL VALIDITY: fair (3)
| Age (median yrs): | | Type of fibroid, N (%): | 24 hrs: 33 (27.5) | Age: +, reported
| 44.8 (23 to 74) | | Type 0: 52 (43.3) | 36 hrs: 5 (4.3) | Race: NA, not US study
| Race/ethnicity: | | Type I: 51 (42.5) | 48 hrs: 17 (14.1) | Pregnancy history: +, reported
| NR | | Type II: 17 (14.1) | 72 hrs: 7 (5.8) | Surgical history: -, NR
| Parity (range): | | | > 72 hrs: 1 (0.8) | Fibroid/uterine size: +
| 1.6 (0 to 6) | | | Infection, N: | Number of fibroids: -
| Nulliparous: 25.8% | | | N = 1 | Location of fibroids: +
| Baseline Hgb/Hct: | | | Excess glycine, N: | Baseline characteristics: +, reported
| NR | | | N = 1 | Length of follow-up: -
| | | | Later interventions, N (%): | Measurement methods: +
| | | | - 107 (89.1); - Hysterectomy: 3; - Myomectomy: 9 | Measurement reliability: +
| | | | Glycine retention, median: | Clinical care: +
| | | | 281 ml
| | | | Modifiers:
| | | | Operative time modified by size, median mins (range):
| | | | < 3cm: 26.5 (10 to 45)
| | | | > 3cm: 36.3 (10 to 105)
| | | | Glycine retention by modified by complexity, median:
| | | | Simple procedure:
| | | | 270 ml
| | | | Combined procedures:
| | | | 302 ml
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Estimated blood loss >500ml, N (%): | Quality:
Olufowobi et al., 2004 | Retrospective case series | - Reproductive age; - Myomectomy during study period | NR | 34 (31) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed, mean (range): | Conversion to laparotomy, %: | INTERNAL VALIDITY: fair
UK, Community | Myomectomy | NR | 5 (1–27) | 32 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Baseline removed fibroid size, mean cm: | Conversion to hysterectomy, N (%): | Methods and blinding: NA
1996 to 2001 | NR | - Menstrual disorder only: 20 (18); - Menstrual disorder and pain: 23 (21); - Menstrual disorder and infertility: 26 (24); - Menstrual disorder and mass: 7 (6); - Abdominal/pelvic pain only: 3 (3); - Abdominal/pelvic pain and infertility: 14 (13); - Abdominal/pelvic pain and mass: 10 (9); - Abdominal mass only: 4 (4); - Abdominal mass and infertility: 11 (10); - Infertility alone: 16 (15) | 8.2 (2–30) | 4 (4) | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | Length of stay, days ± SD: | Loss to follow-up: NA
NR | 109 | Medical management (NSAIDS or GnRHa): 48% | NR | 4.8 ± 1.8 | Drop-out rates: NA
| N at follow-up: | Associated procedure(s): | | Fever, %: | Statistical issues: -
| NA | NR | | 38% | EXTERNAL VALIDITY: poor (5)
| Age, yrs ± SD: | | | Transfusion, N (%): | Age: +, reported
| 36 ± 4.7 | | | 23 (21) | Race: NA, not US study
| Race/ethnicity: | | | Wound infection, N, (%): | Pregnancy history: -, NR
| NR | | | 5 (5) | Surgical history: -, NR
| Parity: | | | Improved symptoms (excluding infertility), N (%): | Fibroid/uterine size: -
| NR | | | 34/50 (68) | Number of fibroids: -
| Baseline Hgb/Hct: | | | Improved symptoms with infertility, N (%): | Location of fibroids: -
| NR | | | 21/59 (36) | Baseline characteristics: +, reported
| | | | IVF conception, N (%): | Length of follow-up: +
| | | | 2/17 (14) | Measurement methods: +
| | | | Natural conception, N (%): | Measurement reliability: +
| | | | 13/28 (46) | Clinical care: -
| | | | Modifier:
| | | | NA
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min: | Quality:
Ou et al., 2002 | Retrospective cohort study | - Women undergoing myomectomy for UF | NR | G1: 144 (110–260) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids (median removed): | G2: 168 (140–244) | INTERNAL VALIDITY: fair
US and Taiwan, Community | Colpotomy and harmonic scalpel | NA | G1: 7 | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | G2: 4 | Mean estimated blood loss (ml): | Methods and blinding: NA
01/1992 to 01/2002 | G1: Colpotomy | - Primary infertility: 62 (37); - Secondary infertility: 28 (17); - Menometrorrhagia: 52 (32); - Dysmenorrhea: 25 (15); - Mass on ultrasound: 121 (72) | Overall mean: 5.6 | Harmonic scalpel: 243 (150–350) | Pt selection criteria: +
Funding: | G2: Morcellation | Preoperative therapy: | Baseline fibroid size (gm): | Unipolar cautery: 378 (203–800) | Loss to follow-up: NA
NR | N at enrollment: | NA | G1: 103.4 | P < 0.01 | Drop-out rates: NA
| G1: 143 | Associated procedure(s), N (%): | G2: 92.4 | Modifier: | Statistical issues: -
| G2: 22 | Tuboplasty or adhesion lysis: 17 (10.3) | Type of fibroid: | NA | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | Myolysis: 11 (6.7) | NR | | Age: +, reported
| NA | | | | Race: -, NR
| Age, mean yrs: | | | | Pregnancy history: -, NR
| 31.6 (18–44) | | | | Surgical history: -, NR
| Race/ethnicity: | | | | Fibroid/uterine size: -
| NR | | | | Number of fibroids: -
| Parity: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: +, reported
| Baseline Hgb/Hct: | | | | Length of follow-up: NA
| NR | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Pain medication use, days: | Quality:
Razavi et al., 2003 | Retrospective cohort | - Abdominal myomectomy; - Uterine fibroid embolization | NR | G1: 5.1 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 8.7 | INTERNAL VALIDITY: fair
US, Academic medical center | Myomectomy and UFE | - Planned laparoscopic myomectomy within 3 mos of UFE; - Primary reason for surgery was the treatment of infertility without other symptoms | NR | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Length of stay, days: | Methods and blinding: NA
07/1998 to 12/2000 | G1: UFE | NR | NR | G1: 0 | Pt selection criteria: +
Funding: | G2: Abdominal myomectomy | Preoperative therapy: | Type of fibroid: | G2: 2.9 | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P < 0.05 | Drop-out rates: NA
| G1: 62 | Associated procedure(s): | | Complications, N (%): | Statistical issues: -
| G2: 40 | NR | | G1: 7 (11) | EXTERNAL VALIDITY: poor (9)
| N at follow-up: | | | G2: 10 (25) | Age: +, reported
| NA | | | P < 0.05 | Race: -, NR
| Age, mean yrs (range): | | | Menorrhagia relief, N (%): | Pregnancy history: -, NR
| G1: 37.7 (28 to 48) | | | G1: 48 (92) | Surgical history: -, NR
| G2: 44.2 (31 to 56) | | | G2:14 (64) | Fibroid/uterine size: -
| Race/ethnicity: | | | P < 0.05 | Number of fibroids: -
| NR | | | Pain relief, N (%): | Location of fibroids: -
| Parity: | | | G1: 25 (74) | Baseline characteristics: -, NR
| NR | | | G2: 14 (54) | Length of follow-up: NA
| Baseline uterine size: | | | P = NS | Measurement methods: +
| NR | | | Mass effect, N (%): | Measurement reliability: -
| Baseline Hct, %: | | | G1: 28 (76) | Clinical care: -
| G1: 35.5 | | | G2: 21 (91)
| G2: 36 | | | P < 0.05
| | | | Time to resume normal activities, days:
| | | | G1: 8
| | | | G2: 36
| | | | P < 0.05
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, mins: | Quality:
Rossetti et al., 2001 | RCT | - Age < 42; - At least one symptomatic fibroid > 3 cm; - ≤ 7 fibroids; - No submucous fibroids that could be removed by hysteroscope | NR | G1/G2: 40 to 240 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids N (range): | Conversion to laparotomy, N: | INTERNAL VALIDITY: good
Italy, Academic medical center | Myomectomy method | NR | G1: 2.2 (1 to 7) | G1: 2 | Random: +
Enrollment period: | Groups: | Indications, (%): | G2: 2.3 (1 to 7) | G2: NA | Methods and blinding: NA
01/1991 to 06/1998 | G1: Laparoscopic | G1: | Baseline fibroid volume (cm^3^± SD): | G3: NR | Pt selection criteria: ++
Funding: | G2: Abdominal | Pelvic Pain: 29% | G1: 92.5 ± 108.5 | Decrease in Hgb, mg/dL ± SD: | Loss to follow-up: <10%
NR | G3: Laparoscopic (non-randomized comparison) | G1: 29 | G2: 152 ± 137.0 | G1/G2: 1.3 ± 0.9 | Drop-out rates: NA
| N at enrollment: | G2: 30 | Type of fibroid: | Transfusion: | Statistical issues: +
| G1: 41 | Infertility: | NR (submucous excluded) | 0 | EXTERNAL VALIDITY: fair (3)
| G2: 40 | G1: 34 | | Major or late complications: | Age: +, reported
| G3: 84 | G2: 35 | | 0 | Race: -, NR
| N at follow-up: | Menorrhagia: | | Fibroid recurrence, 40 mos N (%): | Pregnancy history: +, reported
| G1: 41 | G1: 31 | | G1: 11 (27) | Surgical history: -, NR
| G2: 40 | G2: 29 | | G2: 9 (23) P = NS | Fibroid/uterine size: +
| G3: 78 | Pelvic Mass: | | G3: 17 (22) | Number of fibroids: +
| Age (yrs ± SD): | G1: 6 | | Fibroid recurrence in cohort: | Location of fibroids: -
| G1: 35 ± 5 | G2: 6 | | Age, pre- and post-operative gravidity, parity, size, number, depth of fibroids | Baseline characteristics: +, reported
| G2: 35 ± 3 | Pre-operative therapy: | | P = NS | Length of follow-up: ++
| G3 (median): 36 (25 to 42) | G3: 30.7% received 3 mos course of GnRH agonist | | Pre-operative GnRH agonist use (independent of number of fibroids): | Measurement methods: +
| Race/ethnicity: | Associated procedure(s): | | Without: 8 of 54 (14.8%) | Measurement reliability: +
| NR | NR | | P < 0.02 | Clinical care: +
| Parity: | | | Recurrence with GnRHa: 9 of 24 treated (37.5%)
| NR | | | Modifier:
| Baseline Hgb/Hct: | | | NR
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Complications, %: | Quality:
Roth et al., 2003 | Retrospective case series | - Abdominal myomectomy; - Black or white race | NR | 29% | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed, %: | G2 vs. G1 | INTERNAL VALIDITY: fair
US, Academic medical center | Abdominal myomectomy | NR | 1 fibroid: | OR = 1.36; 95%CI, 0.56–3.15 | Random: NA
Enrollment period: | Groups: | Indications: | G1: 36.5 | Urinary retention or bladder injury, %: | Methods and blinding: NA
07/1992 to 06/1998 | G1: White | NR | G2: 10 | 0.7 | Pt selection criteria: -
Funding: | G2: Black | Preoperative therapy: | 2 to 3 fibroids: | Transfusion, %: | Loss to follow-up: NA
AHRQ | N at enrollment: | NR | G1: 23.5 | 20 | Drop-out rates: NA
| G1: 107 | Associated procedure(s): | G2: 25 | G2 vs. G1 | Statistical issues: +
| G2: 118 | NR | ≥ 4 fibroids: | OR = 0.9; 95%CI, 0.27, 2.76 | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | G1: 40 | Fever, %: | Age: +, reported
| G1: 107 | | G2: 65 | 2.9 | Race: +, reported
| G2: 118 | | P = 0.001 | Ileus, %: | Pregnancy history: -, NR
| Age, yrs ± SD: | | Baseline fibroid size (wk gestation), %: | 2.4 | Surgical history: -, NR
| G1: 35.6 ± 6.9 | | <12 wks: | Disruption of wound, %: | Fibroid/uterine size: +
| G2: 34.8 ± 5.0 | | G1: 28.8 | 1.0 | Number of fibroids: -
| P = 0.021 | | G2: 13.8 | Infection, %: | Location of fibroids: -
| Race/ethnicity: | | 12 to 16 wks: | 2.0 | Baseline characteristics: -, NR
| NA - see groups | | G1: 27.3 | Respiratory complications, %: | Length of follow-up: +
| Parity: | | G2: 37.9 | 1.0 | Measurement methods: +
| NR | | 16 to 20 wks: | Modifiers: | Measurement reliability: +
| Baseline Hct (mean ± SD): | | G1: 19.7 | Uterine size | Clinical care: -
| G1: 37.3 ± 4.0 | | G2: 29.9 | (OR = 6.3; 95%CI, 3.18–12.4) and number of fibroids (OR = 2.6; 95% CI, 1.25–5.44) predicted transfusion
| G2: 36.4 ± 3.8 | | >20 wks: | Uterine size
| P = 0.232 | | G1: 9.1 | (OR = 1.86; 95%CI: 1.3–2.67), number of fibroids (OR = 1.83; 95% CI, 1.1–3.14), and co-morbidities (OR = 2.77; 95% CI, 1.1–7.69) predicted complications
| | | G2: 12.6 | Prior abdominal surgery, BMI, adhesions, and pre-op diagnoses not associated with complications or transfusion
| | | P = 0.12
| | | Type of fibroid:
| | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Seracchioli et al., 2000 | RCT | - Fibroid(s) ≥ 5 cm; - Infertility | NR | G1: 88.85 ± 26.91 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 100.23 ± 38.34 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Myomectomy | - Pedunculated fibroids; - Uterine size above umbilicus; - > 3 fibroids of > 5 cm size; - Other causes of infertility | G1: 2.75 ± 1.98 | Conversion to laparotomy, N (%): | Random: +
Enrollment period: | Groups: | Indications for LM, N (%): | G2: 2.94 ± 1.53 | G1: NA | Methods and blinding: NA
01/1993 to 01/1998 | G1: Abdominal myomectomy | - Primary infertility: 87 (66.4); - Secondary infertility: 44 (33.6) | Baseline size of largest fibroid (cm ± SD): | G2: 3 (4.3) | Pt selection criteria: ++
Funding: | G2: Laparoscopic myomectomy | Preoperative therapy: | G1: 7.47 ± 2.60 | Intra-operative complications: | Loss to follow-up: 10–20%
NR | N at enrollment: | None | G2: 7.07 ± 2.54 | None | Drop-out rates: NA
| G1: 65 | Associated procedure(s): | Type of fibroid, N (%): | Decrease in Hgb: | Statistical issues: +
| G2: 66 | NR | Subserosal: | G1: 2.17 ± 1.57 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | | G1: 19 (44.2) | G2: 1.33 ± 1.23 | Age: +, reported
| G1: 59 | | G2: 24 (55.8) | P < 0.001 | Race: NA, not US study
| G2: 56 | | Intramural: | Transfusion, N: | Pregnancy history: +, reported
| Age, yrs ± SD: | | G1: 54 (52.9) | G1: 3 | Surgical history: -, NR
| G1: 33.97 ± 4.79 | | G2: 48 (47.1) | G2: 0 | Fibroid/uterine size: +
| G2: 34.00 ± 4.11 | | “Reaching Cavity”: | Fever > 38° C, N (%): | Number of fibroids: +
| Race/ethnicity: | | G1: 5 (9.2) | G1: 17 (26.2) | Location of fibroids: +
| NR | | G2: 2 (4.1) | G2: 8 (12.1) | Baseline characteristics: +, reported
| Parity: | | | Length of stay, hrs ± SD: | Length of follow-up: +
| See fertility status | | | G1: 142.80 ± 34.60 | Measurement methods: +
| Baseline Hgb/Hct: | | | G2: 75.61 ± 37.09 | Measurement reliability: +
| NR | | | Antibiotic Rx, N (%): | Clinical care: +
| | | | G1: 17 (26.2)
| | | | G2: 8 (12.1)
| | | | Pregnancy rate, N (%):
| | | | G1: 33/59 (55.9)
| | | | G2: 30/56 (53.6)
| | | | Miscarriage, N (%):
| | | | G1: 4 (12.1)
| | | | G2: 6 (20.0)
| | | | Ectopic:
| | | | G1: 0
| | | | G2: 1
| | | | Births:
| | | | G1: 27/59
| | | | G2: 20/56
| | | | Preterm births, N (%):
| | | | G1: 2 (7.4)
| | | | G2: 1 (5.0)
| | | | Cesarean rate, N (%):
| | | | G1: 21 (77.8)
| | | | G2: 13 (65.0)
| | | | Uterine Rupture:
| | | | 0
| | | | Fibroid recurrence, by US every 6 mos, N (%):
| | | | G1: 12 (20.3)
| | | | G2: 12 (21.4)
| | | | Subsequent treatment, N:
| | | | G1:
| | | | Myomectomy: 3
| | | | Hysterectomy: 1
| | | | G2: 0
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, median cm^3^: | Operative time, median min (25%, 75%) | Quality:
Silva et al., 2000 | Prospective case series with historical comparison group | - Eligible to consent; - Age ≥ 18 yr; - Uterus ≥ 14 wk size | G1: 526 | G1: 222.5 (192.5, 270) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 828 | G2: 180(160, 220) | INTERNAL VALIDITY: good
US, Academic medical center | Myomectomy | - Prior myomectomy; - Concurrent hysteroscopic myomectomy; - History of bleeding diathesis; - Fibroid > 8cm diameter; > 4 intramural fibroids > 3cm diameter by ultrasound; - Malignant/pre-malignant condition; - Pregnancy; - Lactation | Number of fibroids: | EBL (median ml, 25%, 75%) | Random: NA
Enrollment period: | Groups: | Historic controls: | G1: NR | G1: 300 (100, 550) | Methods and blinding: NA
Prospective: | G1: Laparoscopic (complete and assisted) | Inclusion criteria*: | G2: NR | G2: 200 (150, 375) | Pt selection criteria: ++
10/96-10/97 | G2: Abdominal | - Abdominal myomectomy in correct time frame; - Frequency matched within 100 gm of fibroid weight | Baseline fibroid size (median gm; 25%, 75%): | EBL > 1200ml: | Loss to follow-up: <10%
Historical comparison group: | N at enrollment: | Indications: | G1: 151 (31, 262) | G1: 0 | Drop-out rates: <5%
1/90-10/97 | G1: 25 | NR | G2: 170 (81, 285 | G2: 1 | Statistical issues: ++
(14 prospective; 37 historical) | G2: 51 | Preoperative therapy: | Type of fibroid: | Hemorrhage: | EXTERNAL VALIDITY: poor (5)
Funding: | N at follow-up: | NR | NR (submucosal excluded) | G1: 0 | Age: +, reported
Cleveland Clinic Foundation | G1: 25 | Additional procedures, (%): | | G2: 3 | Race: -, NR
| G2: 51 | G1: 16 (64) | | Bladder injury: | Pregnancy history: +, reported
| Age (median yrs): | G2: 33 (65) | | G1: 0 | Surgical history: -, NR
| G1: 37 | | | G2: 1 | Fibroid/uterine size: +
| G2: 37 | | | Fever ≥ 38.0, N (%): | Number of fibroids: -
| Race/ethnicity: | | | G1: 4 (16) | Location of fibroids: -
| NR | | | G2: 13 (26) | Baseline characteristics: -, NR
| Parity (median): | | | Length of stay, median hours (1^st^ Quartile, 3^rd^ Quartile) | Length of follow-up: +
| G1: 0 | | | G1: 30.5 (25, 52.5) | Measurement methods: +
| G2: 0 | | | G2: 65 (45, 76) | Measurement reliability: +
| Baseline Hgb/Hct: | | | Ileus, N (%): | Clinical care: +
| NR | | | G1: 1 (4)
| | | | G2: 1 (2)
| | | | Urinary tract infection, N (%):
| | | | G1: 1 (4)
| | | | G2: 1 (2)
| | | | Anemia (Hct < 28%):
| | | | G1: 2 (8)
| | | | G2: 10 (20)
| | | | Anemia requiring transfusion, N (%):
| | | | G1: 2 (8)
| | | | G2: 6 (12)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Ongoing pregnancy rate, %: | Quality:
Surrey et al., 2005 | Retrospective cohort | - Early follicular phase serum FSH level of < 12 mIU/mL; - At least six resting antral follicles 2 to 10 mm | NR | G1: 61 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 86.7 | INTERNAL VALIDITY: fair
US, Fertility treatment center | - Precycle hysteroscopic or abdominal myomectomy and fresh IVF-ET or oocyte donation | NR | G1: 1.3 ± 0.2 | G3: 52 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 1.2 ± 0.2 | G4: 84.6 | Methods and blinding: NA
2 yr | G1: Submucosal fibroids, hystero-scopic resection, fresh IVF-ET | - Submucosal or intramural leiomyomata that distorted or abutted endometrial cavity with < 2 mm of intervening normal myometrium | G3: 2.3 ± 0.3 | G5: 53 | Pt selection criteria: +
Funding: | G2: Submucosal fibroids, hystero-scopic resection, donor IVF-ET | Pre-operative therapy: | G4: 3.5 ± 0.6 | G6: 77 | Loss to follow-up: <10%
NR | G3: Myomectomy and fresh IVF-ET | NR | G1 vs. G3: | Biochemical pregnancy rate, %: | Drop-out rates: NA
| G4: Myomectomy and donor IVF-ET | Associated procedure(s): | P < 0.01 | G1: 16 | Statistical issues: -
| G5: No fibroids, fresh IVF-ET | None | G2 vs. G4: | G2: 13.3 | EXTERNAL VALIDITY: fair
| G6: No fibroids, donor IVF-ET | | P < 0.01 | G3: 20 | Age: +, reported
| N at enrollment: | | Baseline fibroid size (cm ± SD): | G4: 8.3 | Race: -, NR
| G1: 31 | | G1: 1.7 ± 0.3 | G5: 14 | Pregnancy history: -, NR
| G2: 15 | | G2: 1.4 ± 0.2 | G6: 13.1 | Surgical history: -, NR
| G3: 29 | | G3: 6.1 ± 0.8 | Implantation rate, %: | Fibroid/uterine size: +
| G4: 26 | | G4: 6.8 ± 0.8 | G1: 24 | Number of fibroids: +
| G5: 896 | | G1 vs. G3: | G2: 57.8 | Location of fibroids: +
| G6: 552 | | P < 0.01 | G3: 26 | Baseline characteristics: +, reported
| N at follow-up: | | G2 vs. G4: | G4: 55.2 | Length of follow-up: +
| NA | | P < 0.01 | G5: 23 | Measurement methods: +
| Age, yrs ± SD: | | Type of fibroid, %: | G6: 49.1 | Measurement reliability: +
| G1: 38.8 ± 0.9 | | Submucosal only: | No statistical differences were noted in ongoing pregnancy, biochemical pregnancy, or implantation rates among the groups undergoing each procedure | Clinical care:+
| G2: 40.3 ± 1.2 | | G1: 67.7% | Modifier:
| G3: 37.5 ± 0.5 | | G2: 73.3% | NR
| G4: 42.2 ± 0.8 | | G3: 0.0%
| G5: 38 ± 0.1 | | G4: 0.0%
| G6: 40.0 ± 0.2 | | Intramural only:
| G4 vs. G6: | | G1: 25.8%
| P < 0.05 | | G2: 28.0%
| Race/ethnicity: | | G3: 93.1%
| NR | | G4: 92.3%
| Parity: | | Intramural and submucosal:
| NR | | G2: 6.7%
| Baseline Hgb/Hct: | | G4: 7.7%
| NR | | G1: 6.5%
| | | G3: 6.9%
| | | G1 vs. G3:
| | | P < 0.01
| | | G2 vs. G4:
| | | P < 0.01
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Adhesion formation per patient, %: | Quality:
Takeuchi et al., 2005 | RCT | At enrollment: | NR | G1: 10 (34.5) | Overall quality score: fair
Country and setting: | Intervention: | - Symptomatic uterine fibroids | Number of fibroids, mean ± SD: | G2: 20 (67.7) | INTERNAL VALIDITY: good
Japan, Academic medical center | Laparoscopic myomectomy with anti-adhesion therapy | At follow-up: | G1: 3.6 ± 4.0 | G3: 20 (62.5) | Random: +
Enrollment period: | Groups: | - Underwent SLL because desired children and were not pregnant | G2: 4.7 ± 4.0 | G1/G3: P < 0.05 | Methods and blinding: +
01/2001 to 06/2002 | G1: Fibrin gel | Exclusion criteria: | G3: 4.5 ± 4.4 | Modifiers: | Pt selection criteria: ++
Funding: | G2: Fibrin sheet | - Diameter of largest fibroid < 5 cm; - Largest fibroid pedunculated; - Additional procedures (cystectomy, adnexal adhesiolysis, cul-de-sac opening) | Baseline fibroid size(wt extracted fibroid), gm ± SD: | NR | Loss to follow-up: NA
NR | G3: Control | Indications: | G1: 188 ± 93.7 | | Drop-out rates: NA
| N at enrollment: | Infertility: | G2: 212 ± 118 | | Statistical issues: +
| G1: 68 | G1: 10 (34.5) | G3: 201 ± 114 | | EXTERNAL VALIDITY: poor (5)
| G2: 68 | G2: 11 (36.7) | Type of fibroid, %: | | Age: +, reported
| G3: 69 | G3: 11 (34.4) | Submucosal: | | Race: NA, not US study
| N at follow-up: | Preoperative therapy: | G1: 2 (2.9) | | Pregnancy history: -, NR
| G1: 29 | GnRH agonist: | G2: 3 (2.1) | | Surgical history: -, NR
| G2: 30 | G1: 25 (86.2) | G3: 3 (2.1) | | Fibroid/uterine size: +
| G3: 32 | G2: 25 (83.3) | Intramural: | | Number of fibroids: +
| Age, yrs ± SD: | G3: 28 (87.5) | G1: 57 (54.8) | | Location of fibroids: +
| G1: 35.3 ± 4.7 | Additional procedures: | G2: 59 (42.2) | | Baseline characteristics: -, NR
| G2: 35.7 ± 3.8 | None | G3: 60 (41.7) | | Length of follow-up: -
| G3: 35.0 ± 4.1 | | Subserosal: | | Measurement methods: +
| Race/ethnicity: | | G1: 44 (42.3) | | Measurement reliability: +
| NR | | G2: 78 (55.7) | | Clinical care: +
| Parity: | | G3: 81 (56.2)
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Tsuji et al., 2005 | Prospective cohort | Diagnosed with uterine fibroids alone | NR | G1: 103 ± 25 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 94 ± 23 | INTERNAL VALIDITY: fair
Japan, Academic medical center | Anti-adhesion treatment during myomectomy | Additional procedures | G1: 4.5 ± 3.7 | G3: 99 ± 41 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 2.8 ± 2.6 | G4: 105 ± 36 | Methods and blinding: NA
12/1999 to 12/2003 | G1: Hyaluronic acid carboxy-methylcellulose film implants (Seprafilm^®^ Genzyme Corp.) | NR | G3: 2.7 ± 2.5 | Mean estimated blood loss (ml ± SD): | Pt selection criteria: ++
Funding: | G2: Irrigation with 250 ml of Dextran 40 (10% Dextran 40 Low Injection^®^, Nichi-iko Pharmaceutical Corp.) | Preoperative therapy: NR | G4: 2.2 ± 1.0 | G1: 123 ± 97 | Loss to follow-up: <10%
NR | G3: Factor 13 with fibrinogen (Beriplast^®^, Aventis Behring Corp.) | Additional procedures: | Baseline dominant size (cm ± SD): | G2: 136 ± 56 | Drop-out rates: <5%
| G4: No treatment | None | G1: 7.7 ± 3.6 | G3: 125 ± 82 | Statistical issues: -
| N at enrollment: | | G2: 6.4 ± 2.9 | G4: 134 ± 89 | EXTERNAL VALIDITY: poor (4)
| G1: 21 | | G3: 6.1 ± 1.6 | Uterine adhesion, %: | Age: +, reported
| G2: 17 | | G4: 7.5 ± 2.7 | G1: 3 (14.3) | Race: NA, not US study
| G3: 12 | | Type of fibroid: | G2: 12 (70.6) | Pregnancy history: -, NR
| G4: 13 | | NR | G3: 9 (75.0) | Surgical history: -, NR
| N at follow-up, 7 days: | | | G4: 10 (76.9) | Fibroid/uterine size: +
| G1: 21 | | | G1/G2:P = 0.0004 | Number of fibroids: +
| G2: 17 | | | G1/G3: P = 0.0005 | Location of fibroids: +
| G3: 12 | | | G1/G4: P = 0.0003 | Baseline characteristics: -, NR
| G4: 13 | | | G2/G3: P = 0.7928 | Length of follow-up: -
| Age, yrs ± SD: | | | G2/G4: P = 0.6974 | Measurement methods: +
| G1: 33.0 ± 4.4 | | | G3/G4: P = 0.9105 | Measurement reliability: +
| G2: 34.7 ± 3.8 | | | Adnexal adhesion, %: | Clinical care: +
| G3: 34.8 ± 3.6 | | | G1: 3 (14.3)
| G4: 33.0 ± 4.7 | | | G2: 9 (52.9)
| Race: | | | G3: 2 (16.7)
| NR | | | G4: 12 (92.3)
| Parity: | | | G1/G2:P = 0.0098
| NR | | | G1/G3: P = 0.855
| Baseline Hgb/Hct: | | | G1/G4: P < 0.0001
| NR | | | G2/G3: P = 0.041
| | | | G2/G4: P = 0.0136
| | | | G3/G4: P < 0.0001
| | | | Peritoneal adhesion, %:
| | | | G1: 3 (14.3)
| | | | G2: 5 (29.4)
| | | | G3: 5 (41.6)
| | | | G4: 9 (69.2)
| | | | G1/G2:P = 0.2557
| | | | G1/G3: P = 0.0818
| | | | G1/G4: P = 0.001
| | | | G2/G3: P = 0.4953
| | | | G2/G4: P = 0.0283
| | | | G3/G4: P < 0.1654
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Fever >38° C, N (%): | Quality:
Vavilis et al., 2005 | Retrospective cohort | - Undergoing abdominal myomectomy or hysterectomy | NR | G1: 17 (16.63) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 14 (13.72) | INTERNAL VALIDITY: fair
Greece, Academic medical center | Abdominal myomectomy vs. abdominal hysterectomy | NR | NR | P = NS | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Fever lasting > 24 hrs, N (%): | Methods and blinding: NA
01/2000 to 01/2003 | G1: Abdominal myomectomy | NR | NR | G1: 4 (3.92) | Pt selection criteria: -
Funding: | G2: Abdominal hysterectomy | Pre-operative therapy: | Type of fibroid: | G2: 5 (4.9) | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P = NS | Drop-out rates: NA
| G1: 102 | Associated procedure(s): | | Modifiers: | Statistical issues: +
| G2: 102 | NR | | NR | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | | Age: +, reported
| NA | | | | Race: NA, not US study
| Age, yrs ± SD: | | | | Pregnancy history: -, NR
| G1: 35 ± 5.8 | | | | Surgical history: -, NR
| G2: 45 ± 3.4 | | | | Fibroid/uterine size: -
| Race/ethnicity: | | | | Number of fibroids: -
| NR | | | | Location of fibroids: -
| Parity: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: NA
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Operative time, min ± SD: | Quality:
Zullo et al., 2004 | RCT | - Infertility > 3 yr; - Recurrent first trimester miscarriages; - Increased vaginal bleeding; - Pelvic pressure and pain; - Urinary frequency; - Constipation | G1: 272.9 ± 36.3 | G1: 78.7 ± 13.1 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 265.4 ± 29.9 | G2: 109.2 ± 15.2 | INTERNAL VALIDITY: good
Italy, Academic medical center | Intraoperative injection of bupivacaine plus epinephrine vs. saline solution during laparoscopic myomectomy | - Serious medical illnesses or malignancy; - Largest intramural fibroid on ultrasound < 3 cm or > 5 cm; - >2 fibroids; - Calcified fibroids; - Submucosal fibroids; - Pregnancy; - Abnormal pap smear or endometrial biopsy; - Anemia; - Treatment with GnRHa within 2 mos of surgery | Number of fibroids, mean ± SD: | P < 0.001 | Random: +
Enrollment period: | Groups: | Indications: | G1: 1.3 ± 0.4 | Mean estimated blood loss, ml ± SD: | Methods and blinding: +
03/2002 to 12/002 | G1: Bupivacaine | See inclusion criteria | G2: 1.2 ± 0.3 | G1: 143.9 ± 48.1 | Pt selection criteria: ++
Funding: | G2: Saline | Pre-operative therapy: | Baseline largest fibroid size, cm^3^± SD: | G2: 212.5 ± 51.0 | Loss to follow-up: <10%
NR | N at enrollment: | None | G1: 80.5 ± 24.1 | P < 0.001 | Drop-out rates: <5%
| G1: 30 | Associated procedure(s): | G2: 73.5 ± 19.7 | Decrease in Hgb: | Statistical issues: ++
| G2: 30 | None | Type of fibroid: | P < 0.05 | EXTERNAL VALIDITY: fair (2)
| N at follow-up: | | None submucosal | Value of VAS significantly lower in group A than in group B was observed 24 hours after surgery, but not at any other time point measured | Age: +, reported
| 56 | | | Pain medication use, number of vials: | Race: NA, not US study
| Age, yrs ± SD: | | | G1: 4.0 ± 0.9 | Pregnancy history: +, reported
| G1: 28.2 ± 3.1 | | | G2: 7.6 ± 1.3 | Surgical history: -, NR
| G2: 27.1 ± 2.9 | | | P < 0.001 | Fibroid/uterine size: +
| Race/ethnicity: | | | Modifiers: | Number of fibroids: +
| NR | | | NR | Location of fibroids: -
| Parity, mean ± SD: | | | | Baseline characteristics: +, reported
| G1: 1.1 ± 0.8 | | | | Length of follow-up: NA
| G2: 1.0 ± 0.7 | | | | Measurement methods: +
| Baseline Hgb/Hct: | | | | Measurement reliability: +
| NR | | | | Clinical care: +

* Numbers and percentages in text do not agree

* Calculated by reviewer.

* Discrepancy in paper

* Pregnancy rate was only calculated for patients who had LM in 1997

* Additional detail not provided

Evidence Table 8. KQ 2 Hysterectomy

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria and Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Benassi et al., 2002 | RCT | - Women with large symptomatic uteri necessitating hysterectomy | G1: 380 ± 165 | G1: 86 ± 25.32 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 436 ± 171 | G2: 102 ± 31.02 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Vaginal or abdominal hysterectomy | - Prolapse; - Uterine/adnexial neoplasm; - Pelvic inflammation; - Vaginal stenosis; - Previous pelvic/ vaginal procedures; - Hormone treatment 6 mos before surgery | P = 0.072 | P < 0.001 | Random: +
Enrollment period: | Groups: | Indications: | Number of fibroids: | Transfusions, N (%): | Methods and blinding: NA
01/1997 to 12/2000 | G1: Vaginal hysterectomy | NR | NR | G1: 2 (3.3) | Pt selection criteria: ++
Funding: | G2: Abdominal hysterectomy | Preoperative therapy: | Baseline fibroid size: | G2: 4 (6.7) | Loss to follow-up: <10%
NR | N at enrollment: | Antithrombotic and antibiotic prophylaxis | NR | Fever > 38°C, N (%): | Drop-out rates: NA
| G1: 60 | Additional procedures: | Type of fibroid: | G1: 10 (16.6) | Statistical issues: +
| G2: 59 | Adnexectomy, N (%): | NR | G2: 18 (30.5) | EXTERNAL VALIDITY: fair (3)
| N at follow-up, 1 month: | G1: 38 (63) | | P < 0.05 | Age: +, reported
| G1: 60 | G2: 41 (69.4) | | Postoperative complications, N (%): | Race: +, reported
| G2: 59 | | | G1: 2 (3.3) | Pregnancy history: +, reported
| Age, yrs ± SD: | | | G2: 6 (10.1) | Surgical history: -, NR
| G1: 48 ± 5.3 | | | P = 0.136 | Fibroid/uterine size: +
| G2: 47 ± 5.1 | | | Pain medication use, N (%): | Number of fibroids: -
| P = 0.403 | | | G1: 40 (66.6) | Location of fibroids: -
| Race/ethnicity, %: | | | G2: 51 (86.4) | Baseline characteristics: +, reported
| White: 100% | | | P < 0.05 | Length of follow-up: NA
| Parity, mean ± SD: | | | Length of stay, days ± SD: | Measurement methods: +
| G1: 1.38 ± 0.58 | | | G1: 3.4 ± 0.7 | Measurement reliability: +
| G2: 1.42 ± 0.69 | | | G2: 4.3 ± 1.5 | Clinical care: +
| P = 0.966 | | | P < 0.001
| Baseline Hgb, g/dL ± SD: | | | Treatment satisfaction, N (%):
| G1: 12.7 ± 1.6 | | | Good/very good,:
| G2: 12.5 ± 2.02 | | | G1: 50 (83.4)
| P = 0.840 | | | G2: 19 (32.1)
| | | | Normal:
| | | | G1: 8 (13.3)
| | | | G2: 35 (59.3)
| | | | Bad/very bad:
| | | | G1: 2 (3.3)
| | | | G2: 5 (7.3)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Darai et al., 2001 | RCT | - Uterine size >280 gm; - Previous pelvic surgery; - History of pelvic inflammatory disease; - Moderate or severe endometriosis; - Adnexal masses; - Adnexectomy | G1: 424 ± 211 | G1: 108 ± 35 | Overall quality score: fair
Soriano et al., 2001 | Intervention: | Exclusion criteria: | G2: 513 ± 360 | G2: 160 ± 50 | INTERNAL VALIDITY: good
Country and setting: | Hysterectomy (laparoscopic vaginal, vaginal [laparoscopic vaginal, vaginal hysterectomy [LAVH]) | - Anesthetic contraindications; - Suspicious adnexal mass; - Vagina < than two fingers wide; - Immobile uterus without descent and lateral mobilization | Number of fibroids: | P <0.001 | Random: +
France, Community | Groups: | Indications: | NR | Conversion to laparotomy, N (%): | Methods and blinding: +
Enrollment period: | G1: Vaginal hysterectomy | Menorrhagia, N (%): | Baseline fibroid size: | G1: 0 | Pt selection criteria: ++
01/1999 to 12/1999 | G2: LAVH | G1: 16 (40) | NR | G2: 3 (7.5) | Loss to follow-up: <10%
Funding: | N at enrollment: | G2: 14 (35) | Type of fibroid: | P < 0.05 | Drop-out rates: NA
NR | G1: 40 | Fibroids, N (%): | NR | Hemorrhage, N (%): | Statistical issues: ++
| G2: 40 | G1: 40 (100) | | G1: 1 (2.5) | EXTERNAL VALIDITY: fair (3)
| N at follow-up, 6 to 8 wks: | G2: 40 (100) | | G2: 1 (2.5) | Age: +, reported
| G1: 40 | Dysmenorrhea, N (%): | | Bladder injury, N (%): | Race: +, reported
| G2: 40 | G1: 16 (40) | | G1: 0 | Pregnancy history: +, reported
| N at follow-up, pain assessment: | G2: 15 (37.5) | | G2: 1 (2.5) | Surgical history: -, NR
| G1: 40 | Preoperative therapy: | | Decrease in Hgb, g/dl ± SD: | Fibroid/uterine size: +
| G2: 37 (3 laparotomy patients excluded) | None | | G1: 2.0 ±1.2 | Number of fibroids: -
| Age, mean yrs ± SD: | Additional procedures: | | G2: 2.1 ± 1.4 | Location of fibroids: -
| G1: 49.1 ± 4.7 | NR | | Post-operative transfusion, N (%): | Baseline characteristics: +, reported
| G2: 50.2 ± 6.8 | | | G1: 1 (2.5) | Length of follow-up: NA
| Race/ethnicity: | | | G2: 1 (2.5) | Measurement methods: +
| NR | | | Fever > 38°C, N (%): | Measurement reliability: +
| Parity, mean ± SD: | | | G1: 2 (5.0) | Clinical care: +
| G1: 2.7 ± 2.6 | | | G2: 3 (7.5)
| G2: 1.6 ± 1.1 | | | Length of stay, days ± SD:
| Baseline Hgb/Hct: | | | G1: 5.3 ± 2.1
| NR | | | G2: 5.7 ± 3.0
| | | | Abdominal wall hematoma, N (%):
| | | | G1: 0
| | | | G2: 2 (5.0)
| | | | Vaginal cuff hematoma, N (%):
| | | | G1: 2 (5.0)
| | | | G2: 1 (2.5)
| | | | Vaginal cuff infection, N (%):
| | | | G1: 1 (2.5)
| | | | G2: 2 (5.0)
| | | | Abdominal wall infection, N (%):
| | | | G1: 0
| | | | G2: 1 (2.5)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Dessole et al., 2000 | RCT | Uterine fibroids | G1: 305 ± 91 | G1: 121 ± 32 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 330 ± 85 | G2: 90 ± 15 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Bipolar electrocautery scissors | NR | Number of fibroids: | P < 0.01 | Random: +
Enrollment period: | Groups: | Indications: | NR | Ligations, mean ± SD: | Methods and blinding: +
NR | G1: Abdominal hysterectomy with conventional technique | NR | Baseline fibroid size: | G1: 14 ± 4 | Pt selection criteria: -
Funding: | G2: Abdominal hysterectomy with bipolar electrocautery scissors | Preoperative therapy: | NR | G2: 6 ± 2 | Loss to follow-up: NA
Ethicon | N at enrollment: | NR | Type of fibroid: | P < 0.01 | Drop-out rates: NR
| G1: 25 | Additional procedures: | NR | Hgb, Day 5 post-op, g/dL ± SD: | Statistical issues: ++
| G2: 25 | NR | | G1: 10.0 ± 1.4 | EXTERNAL VALIDITY: poor (5)
| N at follow-up, 5 days: | | | G2: 10.4 ± 1.1 | Age: +, reported
| G1: 25 | | | P < 0.001 | Race: NA, not US study
| G2: 25 | | | Hct, Day 5 post-op, mean ± SD: | Pregnancy history: -, NR
| Age, mean yrs ± SD: | | | G1: 32.5 ± 3.3 | Surgical history: -, NR
| G1: 51.2 ± 10 | | | G2: 34.0 ± 3.1 | Fibroid/uterine size: +
| G2: 48.5 ± 5.6 | | | P < 0.001 | Number of fibroids: -
| P = NS | | | Modifiers: | Location of fibroids: -
| Race/ethnicity: | | | NR | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: NA
| Parity: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| Baseline Hgb, g/dL ± SD: | | | | Clinical care: -
| G1: 12.4 ± 1.9
| G2: 11.6 ± 1.7
| P = NS
| Baseline Hct, mean ± SD:
| G1: 39.5 ± 4.6
| G2: 37.5 ± 4.8
| P = NS
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Estimated blood loss, ml ± SD: | Quality:
Dousias et al., 2003 | RCT | - No major medical illness; - Age: 30 to 60 yrs; - Hgb: ≥ 9 and < 12 g/dl; - Weight: 50 to 80 kg; - Ferritin > 50 ng/ml; - Uterine fibroids by ultrasound | NR | G1: 645 ± 116 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 593 ± 130 | INTERNAL VALIDITY: good
Greece, Academic medical center | Preoperative recombinant human erythropoietin (rHuEPO) | NR | NR | Length of stay, days ± SD: | Random: +
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | G1: 7.6 ± 0.5 | Methods and blinding: +
NR | G1: Iron 200 mg/day and rHuEPO 600 U/ml SC once weekly for 3 weeks | NR | NR | G2: 7.8 ± 0.9 | Pt selection criteria: +
Funding: | G2: Iron 200 mg/d | Preoperative therapy: | Type of fibroid: | Mean Hgb on Day 7, g/dL ± SD: | Loss to follow-up: NR
NR | N at enrollment: | None | NR | G1: 11.2 ± 0.7 | Drop-out rates: NR
| G1: 23 | Additional procedures: | | G2: 10.5 ± 0.6 | Statistical issues: +
| G2: 27 | NR | | 95% CI, 0.3–1.1 | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | | | Mean Hgb on Day 0, g/dL ± SD: | Age: +, reported
| G1: 23 | | | G1: 11.9 ± 0.7 | Race: NA, not US study
| G2: 27 | | | G2: 10.7 ± 0.7 | Pregnancy history: -, NR
| Age, yrs ± SD: | | | 95% CI, 0.8–1.6 | Surgical history: NA
| G1: 48.2 ± 4.1 | | | Mean Hgb on Day +3, g/dL ± SD: | Fibroid/uterine size: -
| G2: 49.2 ± 4.7 | | | G1: 10.3 ± 0.8 | Number of fibroids: -
| Race: | | | G2: 8.8 ± 0.7 | Location of fibroids: -
| NR | | | 95% CI, 1.9–2.0 | Baseline characteristics: -, NR
| Parity: | | | Mean Hgb on Day +7, g/dL ± SD: | Length of follow-up: +
| NR | | | G1: 10.7 ± 0.8 | Measurement methods: +
| Baseline Hgb/Hct, g/dL ± SD: | | | G2: 8.8 ± 0.7 | Measurement reliability: +
| G1:10.3 ± 4.1 | | | 95% CI, 1.4–2.3 | Clinical care: +
| G2:10.4 ± 4.6 | | | Mean Hgb on Day +14, g/dL ± SD:
| | | | G1: 10.8 ± 0.2
| | | | G2: 9.1 ± 0.7
| | | | 95% CI, 1.3–2.1
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Myocardial infarction: | Quality:
Falkeborn et al., 2000 | Retrospective case-control (controls chosen randomly) | - Lived in Uppsala Health Care Region; - Underwent hysterectomy and/or oophorectomy 1965-1983 | NR | Relative risk of myocardial infarction NS for women with only fibroids compared to other indications: RR = 1.1; 95% CI, 0.7–1.7 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Relative risk of myocardial infarction significant for naturally menopausal women with fibroids compared with all other women: RR = 6.2; 95% CI, 1.9–20 | INTERNAL VALIDITY: good
Sweden, Inpatient Registry | Hysterectomy and/or oophorectomy | - Cancer other than cervical cancer in situ (n = 4,456);; - Malignancy diagnosed ≤ 90 days of surgery (n = 232); - Emigrated (n = 43); - Had more than 1 of any procedures (n = 238); - Myocardial infarction before surgery (n = 26) | NR | Modifiers: | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | NR | Methods and blinding: NA
1965 to 1983 | NA | NR | NR | | Pt selection criteria:c+
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | | Loss to follow-up: NA
The Faculty of Medicine, University of Uppsala, the Swedish Society of Medicine and the Swedish Medical Research Council | 75% of 16,455 cases with hysterectomy for all causes had fibroids, actual N NR | NR | NR | | Drop-out rates: NA
| Age, mean yrs: | Additional procedures: | | | Statistical issues:c+
| 45.9 | NR | | | EXTERNAL VALIDITY: poor (7)
| Race/ethnicity: | | | | Age: +, reported
| NR | | | | Race: NA, not US study
| Parity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Baseline Hgb/Hct: | | | | Fibroid/uterine size: -
| NR | | | | Number of fibroids: -
| | | | | Location of fibroids: -
| | | | | Baseline characteristics: -, NR
| | | | | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size, mean ml (range): | Operative time, mean min (range): | Quality:
Ferrari et al., 2000 | RCT | NR | G1: 388 (257 to 520) | G1: 135 (115–173) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 370 (243 to 463) | G2: 120 (98–123) | INTERNAL VALIDITY: poor
Italy, Academic medical center | Hysterectomy | NR | Number of fibroids: | P = 0.001 | Random: +
Enrollment period: | Groups: | Indications: | NR | Conversion to laparotomy, N: | Methods and blinding: -
NR | G1: Laparoscopically assisted vaginal hysterectomy | NR | Baseline fibroid size: | G1: 3 | Pt selection criteria: -
Funding: | G1a: Uterus ≤ 500 g | Preoperative therapy: | NR | G2: NA | Loss to follow-up: NA
NR | G1b: Uterus > 500 g | NR | Type of fibroid: | Decrease in Hgb, mean g/dL: | Drop-out rates: <5%
| G2: Total abdominal hysterectomy | Additional procedures: | NR | G1: 1.1 (0.8–1.9) | Statistical issues: +
| G2a: Uterus ≤ 500 g | Bilateral salpingo-oophorectomy, N (%) | | G2: 1.8 (0.7–2.5) | EXTERNAL VALIDITY: fair (3)
| G2b: Uterus > 500 g | G1: 19 (61) | | P = NS | Age: +, reported
| N at enrollment: | G2: 21 (68) | | Transfusions, N (%): | Race: NA, not US study
| G1: 31 | | | G1: 0 | Pregnancy history: +, reported
| G2: 31 | | | G2: 1 (3) | Surgical history: +, reported
| N at follow-up: | | | P = NS | Fibroid/uterine size: +
| G1: 31 | | | Febrile morbidity (not defined), N (%): | Number of fibroids: -
| G1a: 20 | | | G1: 1 (3) | Location of fibroids: -
| G1b: 11 | | | G2: 5 (16) | Baseline characteristics: -, NR
| G2: 31 | | | P = NS | Length of follow-up: NA
| G2a: 21 | | | Pain medication use, N (%): | Measurement methods: +
| G2b: 10 | | | G1: 7 (23) | Measurement reliability: +
| Age (mean, range): | | | G2: 24 (77) | Clinical care: +
| G1: 48 (46 to 49) | | | P < 0.001
| G2: 46 (43 to 50) | | | Length of stay, mean days (range):
| Race Ethnicity: | | | G1: 3.8 (34 to 4.0)
| NR | | | G2: 5.8 (5.3 to 6.3)
| Parity, parous, N (%): | | | P < 0.001
| Nulliparous: | | | Uterine weight, mean gm (range):
| G1: 5 (16) | | | G1: 400 (263 to 590)
| G2: 7 (23) | | | G2: 400 (255 to 556)
| Baseline Hgb/Hct: | | | P = NS
| NR | | | Operating time, mean min, (range):
| | | | G1b: 150 (125 to 173)
| | | | G2b: 108 (83 to 120)
| | | | P = 0.002
| | | | Pain medication use, N (%):
| | | | G1a: 1 (5)
| | | | G2a: 16 (76)
| | | | P = 0.0001
| | | | Length of stay, days (range):
| | | | G1a: 3.4 (3.2 to 4.0)
| | | | G2a: 5.8 (5.0 to 6.4)
| | | | P = 0.0001
| | | | Length of stay, days (range):
| | | | G1b: 4.0 (3.9 to 5.8)
| | | | G2b: 6.0 (5.8 to 6.0)
| | | | P = 0.03
| | | | Modifier:
| | | | Conversion to laparotomy:
| | | | G1a: 0/20
| | | | G1b: 3/11
| | | | P = 0.04
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Harmanli et al., 2004 | Retrospective cohort | - Uterus ≥ 250g; - Surgical indication for hysterectomy | G1: 500.9 ± 277.4 | G1: 114.3 ± 46.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 737.4 ± 637.8 | G2: 137.4 ± 69.8 | INTERNAL VALIDITY: good
US, Academic medical center | Hysterectomy (vaginal vs. abdominal) | - Pelvic malignancies; - Hysterectomy with any other major pelvic or abdominal surgery | P = 0.0006 | P = NS | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Number of fibroids: | Hemorrhage, N (%): | Methods and blinding: NA
03/1990 to 09/2000 | G1: Vaginal hysterectomy | Uterine fibroids | NR | G1: 8 (9.2) | Pt selection criteria: +
Funding: | G2: Abdominal hysterectomy | G1: 84 (95.5) | Baseline fibroid size: | G2: 23 (11.5) | Loss to follow-up: NR
NR | N at enrollment: | G2:188 (94.0) | NR | P = NS | Drop-out rates: NR
| G1: 88 | P = NS | Type of fibroid: | Bladder injury, N (%): | Statistical issues: +
| G2: 200 | Menometrorrhagia | NR | G1: 1 (1.1) | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | G1: 3 (3.4) | | G2: 3 (1.5) | Age: +, reported
| NA | G2: 6 (3.0) | | P = NS | Race: -, NR
| Age, yrs ± SD: | P = NS | | Ureteral injury, N (%): | Pregnancy history: +, reported
| G1: 44.0 ± 4.7 | Pelvic pain, endometriosis, or adenomyosis | | G1: 1 (1.1) | Surgical history: -, NR
| G2: 44.1 ± 6.2 | G1: 1 (1.1) | | G2: 1 (0.5) | Fibroid/uterine size: +
| P = NS | G2: 5 (2.5) | | P = NS | Number of fibroids: -
| Race/ethnicity: | P = NS | | Change in Hgb, g/dL ± SD: | Location of fibroids: -
| NR | Other | | G1: 1.9±1.2 | Baseline characteristics: +, reported
| Parity, parous, mean ± SD: | G1: 0 | | G2: 1.6±1.4 | Length of follow-up: NA
| G1: 2.4 ± 1.3 | G2: 1 (0.5) | | P = 0.03 | Measurement methods: +
| G2: 2.3 ± 1.5 | P = NS | | Febrile morbidity N (%): | Measurement reliability: -
| P = NS | Preoperative therapy: | | G1: 18 (20.5) | Clinical care: +
| Baseline Hgb/Hct: | None | | G2: 28 (14)
| NR | Additional procedures: | | P = NS
| | None | | Length of stay, days ± SD:
| | | | G1: 1.9±0.9
| | | | G2: 3.7±1.3
| | | | P < 0.0001
| | | | Ileus, N (%):
| | | | G1: 1 (1.1)
| | | | G2: 21 (10.5)
| | | | P = 0.006
| | | | Hematoma, N (%):
| | | | G1: 2 (2.3)
| | | | G2: 5 (2.5)
| | | | P = NS
| | | | Venous thromboembolism:
| | | | G1: 0
| | | | G2: 0
| | | | P = NS
| | | | Urinary tract infection, N (%):
| | | | G1: 5 (5.4)
| | | | G2: 13 (6.5)
| | | | P = NS
| | | | Readmission, N (%):
| | | | G1: 3 (3.4)
| | | | G2: 6 (3.0)
| | | | P = NS
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Fibroid volume, 3 mos, ml ± SD: | Quality:
Healey et al., 2004 | Prospective cohort | - Healthy premenopausal women; - Age: 39 to 50; - Symptomatic uterine fibroids; - Regular menstrual cycles; - Day 3 serum FSH levels < 40 IU/L | G1: 538 ± 50 | G1: 434.1 ± 51.5 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | G2: NA | INTERNAL VALIDITY: poor
Canada, Academic medical center | UAE vs. hysterectomy | See inclusion criteria | 1: | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | G1: 11 (16.3) | (95% CI, 6–201) | Methods and blinding: NA
08/2000 to 04/2003 | G1: UAE | Bleeding: | G2: NA | Fibroid volume, 6 mos, ml ± SD: | Pt selection criteria: ++
Funding: | G2: Hysterectomy | G1: 42 (61.8) | ≥ 2: | G1: 361.0 ± 38.4 | Loss to follow-up: >20%
NR | N at enrollment: | G2: 16 (100) | G1: 57 (83.8) | G2: NA | Drop-out rates: <5%
| G1: 68 | Pain/pressure: | G2: NA | P < 0.01 | Statistical issues: +
| G2: 16 | G1: 5 (7.4) | Baseline (dominant) fibroid size, ml ± SD: | (95% CI, 44–241) | EXTERNAL VALIDITY: good
| N at follow-up: | G2: 0 | G1: 154 ± 19.9 | Hormone measures at 6 mos | Age: +, reported
| G1: 48 | Urinary symptoms: | G2: NA | FSH (IU/L ± SEM): | Race: +, reported
| G2: 13 | G1: 3 (4.4) | Type of fibroid, N (%): | G1: 9.9 ± 1.0 | Pregnancy history: +, reported
| Age, yrs ± SD: | G2: 0 | Submucosal: | 95% CI, -1.7–1.2 | Surgical history: +, reported
| G1: 44.9 ± 3.8 | Multiple symptoms: | G1: 10 (14.7) | G2: 7.8 ± 1.8 | Fibroid/uterine size: +
| G2: 43.7 ± 3.6 | G1: 14 (20.1) | G2: NA | 95% CI, -0.2–4.0 | Number of fibroids: +
| Race/ethnicity: | G2: 0 | Intramural or subserosal: | LH (IU/L ± SEM): | Location of fibroids: +
| NR | Preoperative therapy: | G1: 58 (85.3) | G1: 7.0 ± 1.1 | Baseline characteristics: +, reported
| Parity, parous (%): | NR | G2: NA | 95% CI, -1.2–0.8 | Length of follow-up: +
| Nulliparous: | Associated procedure(s): | | G2: 11.2 ± 5 | Measurement methods: +
| G1: 11 (22.0) | NR | | 95% CI, -1.91–3.3 | Measurement reliability: +
| G2: 0 | | | E2 (pmol/L ± SEM): | Clinical care: +
| Baseline Hgb/Hct: | | | G1: 214 ± 34.9
| NR | | | 95% CI, -52–36
| | | | G2: 326 ± 79.2
| | | | 95% CI, -39.8–212.6
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine volume, median cm^3^ (range): | Procedure time, min: | Quality:
Hehenkamp et al., 2005 | RCT | - Ultrasound confirmation uterine fibroids; - Menorrhagia; - Premenopausal scheduled for hysterectomy | G1: 321 (31 to 3,005) | G1: 79.0 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 313 (58 to 3,617) | G2: 95.4 | INTERNAL VALIDITY: good
The Netherlands, Hospitals | UAE versus hysterectomy | - Other treatment options available; - Future pregnancy desired; - Renal failure; - Active pelvic infection or clotting disorders; - Allergic to contrast material; - Uterine malignancy suspected; - Submucosal fibroids with 50% of diameter within uterine cavity or dominant pedunculated serosal fibroids | Number of fibroids, N (%): | P = 0.007 | Random: +
Enrollment period: | Groups: | Indications, N (%): | 1 fibroid: | Mean estimated blood loss, ml ± SD: | Methods and blinding: NA
03/2002 to 02/2004 | G1: UAE | Dysmenorrhea: | G1: 35 (39.8) | G1: 30.9 ± 23.8 | Pt selection criteria: ++
Funding: | G2: Hysterectomy (abdominal, vaginal, laparoscopically assisted vaginal, and laparoscopic) | G1: 47 (53.4) | G2: 25 (28.1) | G2: 436.1 ± 474.5 | Loss to follow-up: <10%
Netherlands Organisation for Health Research and Development and Boston Scientific Corporation | N at enrollment: | G2: 50 (56.2) | 2 fibroids: | P < 0.001 | Drop-out rates: <5%
| G1: 88 | Pressure/Pain: | G1: 13 (14.8) | Length of stay, days ± SD: | Statistical issues: ++
| G2: 89 | G1: 38 (43.1) | G2: 16 (18.0) | G1: 2.0 ± 2.1 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | G2: 39 (43.8) | 3 fibroids: | G2: 5.1 ± SD1.3 | Age: +, reported
| G1: 81 | Bladder/Bowel symptoms: | G1: 17 (19.3) | P < 0.001 | Race: +, reported
| G2: 75 | G1: 18 (20.5) | G2: 25 (25.8) | Readmissions, N: | Pregnancy history: +, reported
| Age, yrs ± SD: | G2: 25 (28.1) | >3 fibroids: | G1: 9 | Surgical history: +, reported
| G1: 44.6 ± 4.8 | Anemia: | G1: 18 (20.5) | G2: 0 | Fibroid/uterine size: +
| G2: 45.4 ± 4.2 | G1: 43 (48.9) | G2: 14 (15.7) | P = 0.0032 | Number of fibroids: +
| Race/ethnicity, N (%): | G2: 42 (47.2) | Baseline dominant fibroid volume, median cm^3^ (range): | Minor complications at surgery, complications/ patients: | Location of fibroids: -
| Black: | Other symptoms: | G1: 59 (1–673) | G1: 23/18 | Baseline characteristics: +, reported
| G1: 24 (27.3) | G1: 6 (6.8) | G2: 87 (4–1641) | G2: 26/23 | Length of follow-up: +
| G2: 20 (22.5) | G2: 11 (12.4) | Type of fibroid: | (RR = 0.72; 95% CI, 0.43–1.23) | Measurement methods: +
| White: | Preoperative therapy: | NR | P = 0.23 | Measurement reliability: +
| G1: 54 (61.4) | NR | | Minor complications at 6 weeks, complications/ patients: | Clinical care: +
| G2: 57 (64.0) | Additional procedures, N: | | G1: 68/47
| Other: | Hysterectomy: | | G2: 34/30
| G1: 10 (11.4) | G1: 4 | | (RR = 1.45; 95% CI, 1.04–2.02)
| G2: 12 (13.5) | G2: NA | | P = 0.024
| Parity, N (%): | Removal of hydrosalpinx: | | Major complications at surgery, complications/ patients:
| 0: | G1: 0 | | G1:1/1
| G1: 30 (34.1) | G2: 1 | | G2: 1/1
| G2: 20 (22.5) | Adhesiolysis: | | (RR = 0.93; 95% CI, 0.06–14.54)
| ≥1: | G1: 1 | | P = 0.99
| G1: 58 (65.9) | G2: 0 | | Major complications at 6 weeks, complications/ patients:
| G2: 69 (77.5) | Unilateral salpingo-oophorectomy: | | G1: 3/3 pts
| Baseline Hgb/Hct: | G1: 1 | | G2: 1/1 pts
| NR | G2: 2 | | (RR = 2.78; 95% CI, 0.30–26.13)
| | Bilateral salpingo-oophorectomy: | | P = 0.62
| | G1: 0 | | Unscheduled doctor visits, surgery to 6 wks, visits/pts:
| | G2: 1 | | G1: 45/24
| | | | G2: 30/19
| | | | (RR = 1.45; 95% CI, 0.90–2.37)
| | | | P = 0.12)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Overall severe operative complications: | Quality:
McPherson et al., 2004 | Prospective case series | - Hysterectomy | NR | 3% | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Severe complications in women with fibroids, N (%): | INTERNAL VALIDITY: poor
UK, Community | Hysterectomy (abdominal, vaginal, laparoscopic) | - Cancer; - Postpartum hysterectomies | NR | 291 (4.4) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Severe postoperative complications in women with fibroids, N (%): | Methods and blinding: NA
10/1994 to 09/1995 | NA | NR | NR | 82 (1.2) | Pt selection criteria: -
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid: | Modifiers: | Loss to follow-up: NR
Department of Health, BUPA Foundation | 37,295 | NR | NR | NR | Drop-out rates: NR
| N at follow-up, 6 wks: | Additional procedures: | | | Statistical issues: -
| G1: 26,973 | NR | | | EXTERNAL VALIDITY: poor (10)
| Age, median: | | | | Age: -, NR
| 45 (12 to 95) | | | | Race: -, NR
| Race/ethnicity: | | | | Pregnancy history: -, NR
| NR | | | | Surgical history: -, NR
| Parity: | | | | Fibroid/uterine size: -
| NR | | | | Number of fibroids: -
| Baseline Hgb/Hct: | | | | Location of fibroids: -
| NR | | | | Baseline characteristics: -, NR
| | | | | Length of follow-up: +
| | | | | Measurement methods: -
| | | | | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size, wks ± SD: | Operative time, min ± SD: | Quality:
Okin et al., 2001 | RCT | - Age ≥ 18 yr; - Diagnosed with fibroids; - Scheduled for TAH with or without bilateral salpingo-oophorectomy | G1: 13.8 ± 4.5 | G1: 54 ± 24 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 13.45 ± 3.15 | G2: 59 ± 19 | INTERNAL VALIDITY: poor
US, Community | Abdominal hysterectomy | - Angina; - Myocardial infarction; - Cardiomyopathy; - Congestive heart failure; - Uncontrolled hypertension; - Migraine; - Asthma; - Severe COPD; - Known or suspected malignancy of pelvic organ; - Major concomitant surgical repair except bilateral salpingo-oophorectomy | P = 0.74 | P = 0.35 | Random: +
Enrollment period: | Groups: | Indications, N: | Number of fibroids: | Mean estimated blood loss, ml ± SD: | Methods and blinding: +
04/1999 to 05/2000 | G1: Abdominal hysterectomy with vasopressin | Menorrhagia/ metrorrhagia: | NR | G1: 445.41 ± 239.99 | Pt selection criteria: ++
Funding: | G2: Abdominal hysterectomy with placebo | G1: 16 | Baseline fibroid size: | G2: 748.42 ± 296.97 | Loss to follow-up: 10–20%
Department of Obstetrics, Gynecology, and Reproductive Sciences | N at randomization: | G2: 14 | NR | P = 0.001 | Drop-out rates: >10%
| G1: 30 | Preoperative therapy, N: | Type of fibroid: | Hysterectomy-related estimated blood loss, ml ± SD: | Statistical issues: ++
| G2: 27 | GnRH agonist: | NR | G1: 410.63 ± 227.76 | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | G1: 5 | | G2: 690.21 ± 294.76 | Age: +, reported
| G1: 27 | G2: 4 | | P = 0.001 | Race: +, reported
| G2: 24 | P = 1.0 | | Intra-operative transfusion, N: | Pregnancy history: -, NR
| Age, yrs ± SD: | Additional procedures, N: | | G1: 1 | Surgical history: -, NR
| G1: 44.22 ± 4.92 | Bilateral salpingo-oopherectomy: | | G2: 1 | Fibroid/uterine size: +
| G2: 44.71 ± 5.36 | G1: 13 | | P = 01.0 | Number of fibroids: -
| P=0.74 | G2: 13 | | Decrease in Hgb, g/dL ± SD: | Location of fibroids: -
| Race/ethnicity, N: | P = 0.78 | | G1: 2.1±1.1 | Baseline characteristics: +, reported
| White: | Left or right salpingo-oopherectomy | | G2: 2.0±1.4 | Length of follow-up: NA
| G1: 26 | G1: 2 | | P = 0.95 | Measurement methods: +
| G2: 15 | G2: 2 | | Postoperative hemoglobin, g/dL ± SD: | Measurement reliability: +
| Black | P = 1.0 | | G1: 10.9±1.4 | Clinical care: +
| G1: 0 | Lysis of adhesions | | G2: 10.7±1.1
| G2: 9 | G1: 4 | | P = 0.65
| Asian | G2: 4 | | Length of stay ≥ 4 days, N:
| G1: 1 | P = 1.0 | | G1: 0
| G2: 0 | Other procedures: | | G2: 3
| Parity: | G1: 5 | | P = 0.10
| NR | G2: 5 | | Modifiers:
| Baseline Hgb, g/dL ± SD: | P = 1.0 | | NR
| G1: 12.9 ± 1.9
| G2: 12.7 ± 1.5
| P=0.71
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, mean min: | Quality:
Paparella et al., 2004 | Prospective case series | - Enlarged uterus 280 to 2,000 gm; - One or more contraindications to vaginal surgery | 427.74 ± 254.75 | G1: 61.59 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G1a: 68.00 | INTERNAL VALIDITY: good
Italy, Community | Vaginal hysterectomy | - Pelvic prolapse or relaxation or uteri < 280 gm | NR | G1b: 55.62 | Random: NA
Enrollment period: | Groups: | Indications, (%): | Baseline fibroid size: | G1c: 52.50 | Methods and blinding: NA
11/1999 to 12/2001 | G1: Vaginal hysterectomy in generally considered contraindications to vaginal surgery | Fibroids: 112 (54.9) | NR | G1d: 62.52 | Pt selection criteria: +
Funding: | G1a: Large uterus | Fibroids and AUB or menorrhagia: | Type of fibroid: | G1e: 71.00 | Loss to follow-up: NR
NR | G1b: Adnexal pathology | 64 (31.4) | NR | P = NS | Drop-out rates: NR
| G1c: Nulliparity | Fibroids and adnexal pathology: 28 (13.7) | | Conversion to laparotomy, N (%): | Statistical issues: +
| G1d: Previous pelvic surgery | Preoperative therapy: | | G1: 10 (4.9) | EXTERNAL VALIDITY: fair (3)
| G1e: More than 1 contraindication | None | | G1a: 0 | Age: +, reported
| N at enrollment: | Additional procedures: | | G1b: 0 | Race: NA, not US study
| G1: 204 | NR | | G1c: 2 (11.1) | Pregnancy history: +, reported
| G1a: 128 | | | G1d: 8 (6.45) | Surgical history: +, reported
| G1b: 28 | | | G1e: 0 | Fibroid/uterine size: +
| G1c: 16 | | | Change in Hgb, g/dL: | Number of fibroids: -
| G1d: 16 | | | G1: 1.36 | Location of fibroids: -
| G1e: 18 | | | G1a: 1.02 | Baseline characteristics: +, reported
| N at follow-up: | | | G1b: 0.73 | Length of follow-up: NA
| NR | | | G1c: 1.2 | Measurement methods: +
| Age, yrs ± SD: | | | G1d: 1.45 | Measurement reliability: +
| 46.96 ± 4.8 | | | G1e: 1.87 | Clinical care: -
| Race/ethnicity: | | | P = NS
| NR | | | Pain medication use (mean days):
| Parity, parous, N (%): | | | G1: 0.74
| Mean: 1.94±0 | | | G1a: 0.57
| Nulliparous: 34 (16.7) | | | G1b: 0.6
| Multiparous: 174 (83.3) | | | G1c: 0.9
| Baseline Hgb/Hct: | | | G1d: 0.7
| NR | | | G1e: 0.66
| | | | P = NS
| | | | Length of stay, mean days:
| | | | G1: 2.94
| | | | G1a: 3.36
| | | | G1b: 3.13
| | | | G1c: 2.67
| | | | G1d: 2.90
| | | | G1e: 2.67
| | | | P NS
| | | | Complications, N (%):
| | | | G1: 20 (9.8)
| | | | G1a: 2 (7.1)
| | | | G1b: 2 (12.5)
| | | | G1c: 0
| | | | G1d: 14 (11.3)
| | | | G1e: 2 (11.1)
| | | | P = NS
| | | | Postoperative complications, N (%):
| | | | G1: 18 (8.8)
| | | | G1a: 2 (7.1)
| | | | G1b: 2 (12.5)
| | | | G1c: 0
| | | | G1d: 14 (11.3)
| | | | G1e: 0
| | | | P = NS
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Seracchioli et al., 2002 | RCT | - Uterus >14 wks caused by fibroids; - Uterine weight ≥ 300 gm | G1: 411.8 ± 175 | G1: 95.2 ± 32.4 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 429.6 ± 125 | G2: 88.6 ± 29.3 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Hysterectomy method | - Endometrial malignancy; - Medical conditions requiring hospital monitoring; - Previous abdominal surgery with longitudinal laparotomy; - Contraindications to laporotomy | P NS | P NS | Random: +
Enrollment period: | Groups: | Indications: | Number of fibroids, mean ± SD: | Mean estimated blood loss (ml ± SD): | Methods and blinding: -
01/1997 to 01/2001 | G1: Total laparoscopic hysterectomy | NR | G1: 3.3 ± 3.2 | G1: 311.6 ± 182 | Pt selection criteria: +
Funding: | G2: Total abdominal hysterectomy | Preoperative therapy: | G2: 2.9 ± 2.6 | G2: 376.9 ± 225 | Loss to follow-up: NA
NR | N at enrollment: | NR | P NS | P NS | Drop-out rates: <5%
| G1: 60 | Additional procedures: | Baseline fibroid size (cm ± SD): | Conversion to laparotomy, N: | Statistical issues: +
| G2: 62 | NR | G1: 4.2 ± 3.1 | G1: 1 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | | G2: 4.9 ± 2.8 | G2: 0 | Age: +, reported
| G1: 60 | | P NS | P NS | Race: NA, not US study
| G2: 62 | | Type of fibroid: | Decrease in Hgb, g/100ml ± SD: | Pregnancy history: +, reported
| Age, yrs ± SD: | | NR | G1: 1.8 ± 1.1 | Surgical history: +, reported
| G1: 46.3 ± 3.5 | | | G2: 2.3 ± 1.8 | Fibroid/uterine size: +
| G2: 47.4 ± 4.9 | | | P NS | Number of fibroids: +
| Race/ethnicity: | | | Transfusion, N: | Location of fibroids: -
| NA | | | G1: 0 | Baseline characteristics: +, reported
| Parity, (parous, %): | | | G2: 1 | Length of follow-up: +
| G1: 86.7 | | | P < NS | Measurement methods: +
| G2: 78.1 | | | Fever >38°C, N (%): | Measurement reliability: +
| Baseline Hgb/Hct: | | | G1: 8 (13.3) | Clinical care: +
| NR | | | G2: 18 (29)
| | | | P < 0.05
| | | | Length of stay, hrs ± SD:
| | | | G1: 76.4 ± 30.4
| | | | G2: 121.8 ± 41.8
| | | | P < 0.001
| | | | Wound infection, N:
| | | | G1: 0
| | | | G2: 6
| | | | P NS
| | | | Convalescence, days ± SD:
| | | | G1: 22.0 ± 11.3
| | | | G2: 36.0 ± 12.1
| | | | P < 0.001
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Procedure time, min): | Quality:
Spies, Cooper, Worthington-Kirsch et al., 2004 | Prospective cohort | - Age: 30 to 50 yrs; - Symptomatic fibroids | G1: 689.4 ± 466.1 | G1: 57.9 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 389.2 ± 521.2 | G2: 93.6 | INTERNAL VALIDITY: poor
US, Community and academic medical centers | UAE and hysterectomy | - Submucosal fibroids with > 50% diameter within uterine cavity; - Dominant pedunculated serosal fibroid | P < 0.001 | P < 0.001 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids, N (%): | At least 1 complication, N (%): | Methods and blinding: NA
NR | G1: UAE | NR | 1 fibroid: | G1: 28 (27.5%; 95% CI, 19.1–37.2) | Pt selection criteria: +
Funding: | G2: Hysterectomy | Preoperative therapy: | G1: 27 (26) | G2: 25 (50%; 95% CI, 35.5–64.5) | Loss to follow-up: >20%
Biosphere Medical Inc. | N at enrollment: | NR | G2: 20 (40) | P = 0.01 | Drop-out rates: NR
| G1: 102 | Additional procedures: | 2 fibroids: | Complications within 30 days, %: | Statistical issues: +
| G2: 50 | NR | G1: 33 (32) | G1: 17.6 | EXTERNAL VALIDITY: good
| (40 TAH, 2 LAVH, and 8 LH) | | G2: 19 (38) | G2: 28 | Age: +, reported
| N at follow-up, 12 months: | | ≥3 fibroids: | P = 0.15 | Race: +, reported
| G1: 76 | | G1: 42 (41) | Complications after 30 days, %: | Pregnancy history: +, reported
| G2: 30 | | G2: 10 (20) | G1: 12.7 | Surgical history: +, reported
| Age, yrs ± SD: | | P = 0.021 | G2: 32 | Fibroid/uterine size: +
| G1: 42.6 ± 4.0 | | Baseline dominant fibroid size (ml ± SD): | P=0.01 | Number of fibroids: +
| G2: 41.6 ± 5.3 | | G1: 146.8 ± 158.5 | Major complications, N (%): | Location of fibroids: +
| P = 0.264 | | G2: 90.6 ± 354.8 | G1: 4 (3.9) | Baseline characteristics: +, reported
| Race/ethnicity, N (%): | | P = 0.330 | G2: 6 (12) | Length of follow-up: ++
| Asian/Pacific Island: | | Type of fibroid, N (%): | P = 0.08 | Measurement methods: +
| G1:1 (1) | | Intramural: | Life threatening Complications, N: | Measurement reliability: +
| G2: 2 (4) | | G1: 61 (60) | G1: 0 | Clinical care: +
| Black: | | G2: 32 (64) | G2: 0
| G1: 61 (60) | | P = 0.724 | Overall morbidity N (%):
| G2: 9 (18) | | Subserosal: | G1: 15 (14.7)
| Hispanic: | | G1: 19 (19) | G2: 17 (34.0)
| G1: 7 (7) | | G2: 8 (16) | P = 0.01
| G2: 8 (16) | | P = 0.823 | Hemorrhage, N (%):
| White: | | Submucosal: | G1: 0 (0)
| G1: 31 (30) | | G1: 17 (17) | G2: 4 (8)
| G2: 31 (62) | | G2: 13 (26) | P = 0.01
| Other: | | P = 0.197 | Febrile morbidity, N (%):
| G1: 2 (2) | | Transmural: | G1: 13 (12.7)
| G2: 0 (0) | | G1: 11 (11) | G2: 12 (24.0)
| P < 0.001 | | G2: 1 (2) | P = 0.10
| Parity, N (%): | | P = 0.108 | Length of stay, days:
| Nulliparous: | | Pedunculated: | G1: 0.83
| G1: 44 (43) | | G1: 2 (2) | G2: 2.3
| G2: 11 (22) | | G2: 4 (8) | P < 0.001
| Para 1: | | P=0.072 | Readmission, N (%):
| G1: 20 (20) | | | G1: 3 (2.9)
| G2: 10 (20) | | | 4 (8)
| Multiparous: | | | P = 0.22
| G1: 38 (37) | | | Satisfaction with symptom outcome:
| G2: 29 (58) | | | P = NS
| P = 0.025 | | | Mean time to return to work, days:
| Baseline Hgb, (%): | | | G1: 10.7
| <12 g/dL: | | | G2: 32.5
| G1: 59 (58) | | | P < 0.001
| G2: 19 (38) | | | Unintended surgery, N (%):
| ≥12 g/dL: | | | G1: 2 (2)
| G1: 43 (42) | | | G2: 4 (8)
| G2: 31 (63) | | | P = 0.09
| P = 0.025 | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Taylor et al., 2003 | Retrospective cohort | - Vaginal or abdominal hysterectomy for uterine fibroids; - No known malignancy | G1: 211 ± 114 | G1: 172 ± 70.0 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 431 ± 236 | G2: 173 ± 66.6 | INTERNAL VALIDITY: fair
US, Academic medical center | Hysterectomy | Uterine weight >982 g | P < 0.001 | P = 0.88 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids: | Intraoperative transfusion, N: | Methods and blinding: NA
08/1990 to 07/2001 | G1: Vaginal hysterectomy with morcellation | - Symptomatic fibroids; - Dysfunctional bleeding; - Pelvic relaxation | NR | G1: 4 | Pt selection criteria: +
Funding: | G2: Abdominal hysterectomy | Pre-operative therapy: | Baseline fibroid size: | G2: 6 | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P = 1.00 | Drop-out rates: NA
| G1: 139 | Additional procedures, (%): | Type of fibroid: | (OR = 1.0; 95% CI, 0.3–3.6) | Statistical issues: -
| G2: 208 | Oophorectomy: | NR | Conversion to laparotomy, N: | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | G1: 31 | | G1: 2 | Age: +, reported
| NA | G2: 53 | | G2: 0 | Race: +, reported
| Age, yrs ± SD: | P < 0.001 | | P = 1.00 | Pregnancy history: -, NR
| G1: 43.4 ± 7.6 | Anterior repair: | | Intraoperative complications, N: | Surgical history: -, NR
| G2: 42.2 ± 6.3 | G1: 30 (21.6) | | G1: 8 | Fibroid/uterine size: +
| P = 0.11 | Posterior repair: | | G2: 16 | Number of fibroids: -
| Race/ethnicity, N: | G1: 23 (16.5) | | P = 0.53 | Location of fibroids: -
| White: | Vaginal urethropexy: | | (OR = 1.4; 95% CI, 0.6–3.3) | Baseline characteristics: +, reported
| G1: 51 | G1: 16 (11.5) | | Bowel injury, N: | Length of follow-up: NA
| G2: 72 | Retropubic urethropexy: | | G1: 1 | Measurement methods: +
| Hispanic: | G2: 18 (8.7) | | G2: 3 | Measurement reliability: -
| G1: 63 | Concurrent surgeries in G1 vs. G2: P > .05 | | P = 0.65 | Clinical care: +
| G2: 88 | | | (OR = 2.0; 95% CI, 0.2–19.6)
| American Indian: | | | Bladder injury, N:
| G1: 16 | | | G1: 3
| G2: 16 | | | G2: 7
| Other: | | | P = 0.75
| G1: 6 | | | (OR = 1.6; 95% CI, 0.4–6.2)
| G2: 20 | | | Ureteral injury, N:
| P = 0.2 | | | G1: 1
| Parity, mean ± SD: | | | G2: 4
| G1: 2.6 ± 1.5 | | | P = 0.65
| G2: 2.3 ± 1.9 | | | (OR = 2.7; 95% CI 0.3–24.5)
| P = 0.1 | | | Decrease in Hct, mean ± SD:
| Baseline Hgb/Hct: | | | G1: 7.5 ± 4.6
| NR | | | G2: 8.3 ± 5.9
| | | | P = 0.18
| | | | Postoperative transfusion, N:
| | | | G1: 4
| | | | G2: 9
| | | | P = 0.57
| | | | (OR = 1.5; 95% CI, 0.5–5.1)
| | | | Fever > 38°C, N:
| | | | G1: 4
| | | | G2: 34
| | | | P < 0.001
| | | | (OR = 6.6; 95% CI, 2.2–19.0)
| | | | Length of stay, days ± SD:
| | | | G1: 2.6 ± 1.5
| | | | G2: 3.9 ± 2.6
| | | | P < 0.001
| | | | Postoperative complications, N:
| | | | G1: 10
| | | | G2: 48
| | | | P < 0.001
| | | | (OR = 3.9; 95% CI, 1.9–7.9)
| | | | Pelvic hematoma, N:
| | | | G1: 2
| | | | G2: 5
| | | | P = 0.71
| | | | (OR = 1.7; 95% CI, 0.3_8.8)
| | | | Reoperation, N:
| | | | G1: 0
| | | | G2: 5
| | | | P = 0.09
| | | | Other complications, N:
| | | | G1: 1
| | | | G2: 7
| | | | P = 0.15
| | | | (OR = 4.8; 95% CI, 0.6–39.5)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, gm ± SD: | Operative time, min ± SD: | Quality:
Unger et al., 2002 | Retrospective case series | - Abdominal hysterectomy for benign disease | G1: 227.7± 129.6 | G1: 122.6 ± 41.7 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 729.3 ± 120.3 | G2: 129.5 ± 40.7 | INTERNAL VALIDITY: fair
US, Academic medical center | Abdominal hysterectomy | Concurrent anterior-posterior colporraphy or retropubic urethropexy | G3: 1658.8 ± 793.5 | G3: 124.0 ± 30.6 | Random: NA
Enrollment period: | Groups: | Indications: | P < 0.001 | P = 0.49 | Methods and blinding: NA
1997 to 2000 | G1: Uterus <500gm | G1: 100% “gynecological problems” (bleeding and pain) | Number of fibroids: | Mean estimated blood loss, ml ± SD: | Pt selection criteria: -
Funding: | G2: Uterus 500–999gm | G2: 3.7% asymptomatic | NR | G1: 387.6 ± 281.4 | Loss to follow-up: NA
NR | G3: Uterus ≥1000gm | G3: 17.5% asymptomatic | Baseline fibroid size: | G2: 464.3 ± 285.2 | Drop-out rates: NA
| N at enrollment: | Preoperative therapy: | NR | G3: 555.9 ± 386.5 | Statistical issues: +
| G1: 208 | NR | Type of fibroid: | P = 0.032 | EXTERNAL VALIDITY: fair (3)
| G2: 63 | Additional procedures: | NR | Estimated blood loss > 500 ml, N (%): | Age: +, reported
| G3: 47 | NR | | G1: 53 (25.5) | Race: +, reported
| N at follow-up: | | | G2: 26 (41.3) | Pregnancy history: +, reported
| NA | | | G3: 26 (55.3) | Surgical history: NA
| Age, yrs ± SD: | | | P = 0.004 | Fibroid/uterine size: +
| G1: 41.0 ± 8.7 | | | (AOR for G3 vs. G1 = 3.42; 95% CI, 1.63–7.19) | Number of fibroids: -
| G2: 42.8 ± 6.0 | | | (AOR for G3 vs. G2 = 1.96; 95% CI 0.85–4.5) | Location of fibroids: -
| G3: 45.1 ± 5.5 | | | Transfusion, N (%): | Baseline characteristics: +, reported
| P = 0.034 | | | G1: 6 (2.9) | Length of follow-up: +
| Race/ethnicity, N (%): | | | G2: 4 (6.4) | Measurement methods: +
| Black: | | | G3: 4 (8.5) | Measurement reliability: +
| G1: 131(63.0) | | | P = 0.14 | Clinical care: -
| G2: 59 (93.6) | | | At least one complication, N (%):
| G2: 44 (93.6) | | | G1: 68 (32.7)
| P < 0.001 | | | G2: 26 (41.3)
| Parity, mean ± SD: | | | G3: 29 (61.7)
| G1: 2.5 ± 1.6 | | | P = 0.006
| G2: 2.6 ± 1.8 | | | (AOR for G3 vs. G1 = 3.42; 95% CI, 1.63–7.25)
| G3: 2.2 ± 1.6 | | | (AOR for G3 vs. G2 = 2.64; 95% CI 1.14–6.13)
| Baseline Hgb/Hct: | | | Length of stay, days ± SD:
| NR | | | G1: 2.9 ± 0.9
| | | | G2: 2.8 ± 1.0
| | | | G3: 2.9 ± 0.8
| | | | P = 0.72
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Fever >38° C, N (%): | Quality:
Vavilis et al., 2005 | Retrospective cohort | - Undergoing abdominal myomectomy or hysterectomy | NR | G1: 17 (16.63) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 14 (13.72) | INTERNAL VALIDITY: fair
Greece, Academic medical center | Abdominal myomectomy vs. abdominal hysterectomy | NR | NR | P = NS | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Fever lasting > 24 hrs, N (%): | Methods and blinding: NA
01/2000 to 01/2003 | G1: Abdominal myomectomy | NR | NR | G1: 4 (3.92) | Pt selection criteria: -
Funding: | G2: Abdominal hysterectomy | Pre-operative therapy: | Type of fibroid: | G2: 5 (4.9) | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P = NS | Drop-out rates: NA
| G1: 102 | Associated procedure(s): | | Modifiers: | Statistical issues: +
| G2: 102 | NR | | NR | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | | Age: +, reported
| NA | | | | Race: NA, not US study
| Age, yrs ± SD: | | | | Pregnancy history: -, NR
| G1: 35 ± 5.8 | | | | Surgical history: -, NR
| G2: 45 ± 3.4 | | | | Fibroid/uterine size: -
| Race/ethnicity: | | | | Number of fibroids: -
| NR | | | | Location of fibroids: -
| Parity: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: NA
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +

Evidence Table 9. KQ2 Complementary and alternative medicine

Study Description | Study Design, Interventions, and Patient Population | Inclusion/Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Mean size change, cm: | Quality:
Mehl-Madrona, 2002 | Prospective cohort | - Pre-menopausal; - Intact uterus of ≥ 6 to 8 week size with palpable fibroids; - Fibroids 2 to 3 cm in diameter | NR | G1: -0.8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: +1.9 | INTERNAL VALIDITY: fair
US, Academic medical center | Traditional Chinese medical approach | - Fibroids growing > 6 cm/year; - Hgb < 8g/dL; - Hydronephrosis; - Taking hormonal contraceptives | NR | P < 0.001 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Size and/or rate of growth of fibroids, 6 mos, mean change in size, cm: | Methods and blinding: NA
NR | G1: Traditional Chinese Medicine with combination of weekly acupuncture, Chinese herbs, and nutritional therapy | - Palpable fibroids; - Fibroids 2 to 3 cm in diameter | NR | Cured (gone) | Pt selection criteria: +
Funding: | G2: Progestational agents to stop excessive uterine bleeding, or 4 contraceptive agents to control menstrual bleeding, and NSAIDS for pain | Pre-operative therapy: | Type of fibroid: | G1: 3 | Loss to follow-up: <10%
NR | N at enrollment: | NA | NR | G2: 0 | Drop-out rates: <5%
| G1: 37 | Associated procedure(s): | | Reduced size (>2cm) | Statistical issues: -
| G2: 37 | NA | | G1: 11 | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | | | G2: 1 | Age: +, reported
| G1: 37 | | | Stopped growing (± 1cm) | Race: -, NR
| G2: 37 | | | G1: 8 | Pregnancy history: -, NR
| Age: | | | G2: 2 ) | Surgical history: NA
| Mode: 36 (24 to 45) | | | Decreased rate of growth (change >1cm) | Fibroid/uterine size: +
| Race/ethnicity: | | | G1: 10 (+1.1) | Number of fibroids: -
| NR | | | G2: 9 (+0.9) | Location of fibroids: -
| Parity: | | | Total improved*: | Baseline characteristics: -, NR
| NR | | | G1: 32 | Length of follow-up: +
| Baseline Hgb/Hct: | | | G2: 13 | Measurement methods: +
| NR | | | P < 0.001 | Measurement reliability: +
| | | | No change | Clinical care: +
| | | | G1: 3 (+0.9)
| | | | G2: 20 (+1.9)
| | | | Increased rate of growth (change >1cm)
| | | | G1: 2 (+9.2)
| | | | G2: 4 (+7.0)
| | | | Total unimproved:
| | | | G1: 5
| | | | G2: 24
| | | | P < 0.001
| | | | Symptom change, N:
| | | | Heavy menstrual bleeding, before treatment:
| | | | G1: 20
| | | | G2: 20
| | | | Heavy menstrual bleeding, 6 mos:
| | | | G1: 9
| | | | G2: 11
| | | | Prolonged menstrual bleeding, before treatment:
| | | | G1: 9
| | | | G2: 9
| | | | Prolonged menstrual bleeding, 6 mos:
| | | | G1: 5
| | | | G2: 5
| | | | Dysmenorrhea before treatment, N:
| | | | G1: 9
| | | | G2: 9
| | | | Dysmenorrhea, 6 mos:
| | | | G1: 5
| | | | G2: 7
| | | | Decreased exercise/activity tolerance, before treatment:
| | | | G1: 2
| | | | G2: 2
| | | | Decreased exercise/activity tolerance, before treatment:
| | | | G1: 2
| | | | G2: 2
| | | | Decreased exercise/activity tolerance, 6 mos:
| | | | G1: 1
| | | | G2: 1
| | | | Modifiers:
| | | | NR

Evidence Table 10. KQ 3 Reproductive outcomes

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria and Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Cumulative pregnancy rate, N (%): | Quality:
Bulletti et al., 2004 | Prospective cohort | - Nulliparity; - Age 25 to 39; - ≥1 fibroid > 5 cm with tubal occlusion | NR | G1: 28 (33) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 13 (15) | INTERNAL VALIDITY: poor
Italy, Academic medical center | Myomectomy before IVF | - Male factor infertility; - Bilateral tubal occlusion; - Submucous fibroid(s); - Diagnosis with increased abortion risk other than fibroid(s) | NR | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Miscarriage rate, N (%): | Methods and blinding: NA
1997 to 2003 | G1: Myomectomy before IVF | - Infertility: 100% | NR | G1: 8 (7) | Pt selection criteria: ++
Funding: | G2: No myomectomy before IVF | Pre-operative therapy: | Type of fibroid: | G2: 3 (4) | Loss to follow-up: 10–20%
NR | N at enrollment: | NR | NR | P = NS | Drop-out rates: >10%
| G1: 84 | Associated procedure(s): | | Delivery rate, N (%): | Statistical issues: -
| G2: 84 | NR | | G1: 21 (25) | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | G2: 10 (12) | Age: +, reported
| 193 enrolled | | | P < 0.05 | Race: NA, not US study
| 143 completed the study | | | Modifiers: | Pregnancy history: -, NR
| 25 replaced to reach 168 | | | NR | Surgical history: -, NR
| Followup interval: NR | | | | Fibroid/uterine size: -
| Age, yrs ± SD: | | | | Number of fibroids: -
| All: 33.04 ± 4.76 | | | | Location of fibroids: -
| G1: 32.83 ± 4.12 | | | | Baseline characteristics: -, NR
| G2: NR | | | | Length of follow-up: +
| Race/ethnicity: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| Parity, parous, N: | | | | Clinical care: +
| G1: 0
| G2: 0
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine volume: | Pregnancy rate, %: | Quality:
Casini et al., 2006 | RCT | - Infertility ≥ 1yr; - No other explanation for infertility; - Age < 35; - One fibroid; - ≤ 40mm diameter | NR | G1: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Submucosal: 43.3* | INTERNAL VALIDITY: good
Italy, Academic medical center | Myomectomy for unexplained infertility | - ≥ 2 fibroids; - Size ≥ 40 mm; - Body wt. > 20% above normal; - Use of hormones within 8 wks | One | Intramural: 56.5 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Subserosal: no surgeries | Methods and blinding: NA
01/1998 to 04/2005 | G1: Hysteroscopic or laparoscopic surgery | Unexplained infertility | NR | Intramural-subserosal: 35.3 | Pt selection criteria: +
Funding: | G2: No surgery | Pre-operative therapy: | Type of fibroid: | Submucosal-intramural: 36.4* | Loss to follow-up: NR
NR | N at enrollment: | None | As per groups | G2: | Drop-out rates: NR
| G1: | Associated procedure(s): | | Submucosal: 27.2* | Statistical issues: +
| Submucosal: 30 | NR | | Intramural: 40.9 | EXTERNAL VALIDITY: poor (4)
| Intramural: 23 | | | Subserosal: 63.6 | Age: +, reported
| Subserosal: no surgeries | | | Intramural-subserosal: 21.4 | Race: NA, not US study
| Intramural-subserosal: 17 | | | Submucosal-intramural: 15.0* | Pregnancy history: +, reported
| Submucosal-intramural: 22 | | | *P < 0.05 | Surgical history: -, NR
| G2: | | | Miscarriage rate, % , | Fibroid/uterine size: -
| Submucosal: 22 | | | G1: | Number of fibroids: -
| Intramural: 22 | | | Submucosal: 38.5 | Location of fibroids: +
| Subserosal: 11 | | | Intramural: 30.8 | Baseline characteristics: +, reported
| Intramural-subserosal: 14 | | | Subserosal: no surgeries | Length of follow-up: -
| Submucosal-intramural: 20 | | | Intramural-subserosal: 33.3 | Measurement methods: +
| N at follow-up: | | | Submucosal-intramural: 50.0 | Measurement reliability: +
| NR | | | G2: | Clinical care: +
| Age, yrs ± SD: | | | Submucosal: 50.0
| NR by group; by fibroid type: | | | Intramural: 33.3
| Submucosal: 31.4 ± 2.5 | | | Subserosal: 0
| Intramural: 32.2 ± 1.9 | | | Intramural-subserosal: 66.6
| Subserosal: 32.4 ± 2.1 | | | Submucosal-intramural: 66.6
| Intramural-subserosal: 29.9 ± 1.6 | | | P = NR
| Submucosal-intramural: 32.2 ± 2.5 | | | Modifiers:
| Race/ethnicity: | | | NR
| NR
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Dessolle et al., 2001 | Prospective case series | - Age 18 to 43 yrs; - Infertility ≥ 24 mos; - Intramural or subserous fibroids > 3 cm in diameter; - < 4 myomas, and largest myoma < 10 cm | NR | G1: 150 ± 60 | Overall quality score: fair
Soriano et al., 2003 | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 148 ± 47 | INTERNAL VALIDITY: fair
Country and setting: | Laparoscopic myomectomy | - Anesthetic contraindications; - Only submucous fibroids | G1: 1.7 ± 0.6 | Complications, N: | Random: NA
France, Community | Groups: | Indications, N (%): | G2: 1.6 ± 0.6 | G1: 4* | Methods and blinding: NA
Enrollment period: | G1: Laparoscopic myomectomy | Primary infertility: | P = NS | G2: 2 | Pt selection criteria: ++
01/1990 to 10/1988 | G2: Laparoconversion for myomectomy | G1: 28 (31.8) | Baseline size of largest fibroid (cm ± SD): | Length of stay, days ± SD: | Loss to follow-up: NA
Funding: | N at enrollment: | G2: 6 (33.4) | G1: 6.2 ± 1.8 | G1: 3.0 ± 1 | Drop-out rates: NA
NR | G1: 88 | Pre-operative therapy: | G2: 8.1 ± 1.4 | G2: 5.5 ± 1 | Statistical issues: -
| G2: 18 | None | P < 0.001 | P < 0.001 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | Associated procedure(s): | Type of fibroid, N (%): | Pregnancy rate, N (%): | Age: +, reported
| NR | NR | Subserosal: | G1: 42 (48) | Race: NA, not US study
| Age, yrs ± SD: | | G1: 31 (35) | G2: 10 (56) | Pregnancy history: -, NR
| G1: 36.1 ± 2.1 | | G2: 0 | P = NS | Surgical history: -, NR
| G2: 34.7 ± 2.4 | | Intramural: | Pregnancies, N: | Fibroid/uterine size: +
| Race/ethnicity: | | G1: 57 (65) | G1: 44 | Number of fibroids: +
| NR | | G2: 18 (100) | G2: 10 | Location of fibroids: +
| Parity: | | | P = NS | Baseline characteristics: +, reported
| NR | | | Spontaneous pregnancy, N (%): | Length of follow-up: ++
| Baseline Hgb/Hct: | | | G1: 36/44 (82) | Measurement methods: +
| NR | | | G2: 8/10 (80) | Measurement reliability: -
| | | | P = NS | Clinical care: +
| | | | Ovulation induction + IUI, N (%):
| | | | G1: 2 (5)
| | | | G2: 1 (10)
| | | | IVF + ET, N (%):
| | | | G1: 6 (13)
| | | | G2: 1 (10)
| | | | First-trimester miscarriage, N:
| | | | G1: 6
| | | | G2: 3
| | | | Abortion, N:
| | | | G1: 2
| | | | G2: 2
| | | | Dehiscence of uterine scar, N:
| | | | G1: 0
| | | | G2: 0
| | | | Vaginal delivery, N (%):
| | | | G1:26/34 (77)
| | | | G2: 2/4 (50)
| | | | Cesarean delivery, N (%):
| | | | G1: 8/34 (24)
| | | | G2: 2/4 (50)
| | | | Ectopic pregnancy, N:
| | | | G1: 1
| | | | G2: 0
| | | | Live newborn, N (%):
| | | | G1: 36/44 (41)
| | | | G2: 4/10 (40)
| | | | Premature delivery, N:
| | | | G1: 0
| | | | G2: 1
| | | | Time to conception, mos ± SD:
| | | | G1: 7.5 ± 2.6
| | | | G2: 15.1 ± 2.4
| | | | P < 0.001
| | | | Patients with unexplained infertility, N (%):
| | | | G1: 32/42 (76)
| | | | G2: 8/9 (89)
| | | | P = NS
| | | | Patients with minor infertility factors, N (%):
| | | | G1: 10/42 (24)
| | | | G2: 2/9 (22)
| | | | P = NS
| | | | Patients with primary infertility, N (%):
| | | | G1: 14/28 (50)
| | | | G2: 2/6 (33)
| | | | P = NS
| | | | Patients with secondary infertility, N (%):
| | | | G1: 28/60 (47)
| | | | G2: 8/12 (66)
| | | | P = NS
| | | | Adhesions, N (%):
| | | | G1: 12/16 (75)
| | | | G2: 4/4 (100)
| | | | Recurrence N (%):
| | | | G1: 6/66 (9)*
| | | | G2: 2/12 (17)
| | | | Re-operation (%):
| | | | G1: 0
| | | | G2: 2
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time range in min: | Quality:
Di Gregorio et al., 2001 | Retrospective case series | - Women who received myomectomy for symptomatic fibroids, infertility, or “size and/or number of fibroids required surgical treatment”; - Fibroid size ≥ 10 mm | NR | 30 to 140 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, range: | Conversion to laparotomy, N: | INTERNAL VALIDITY: fair
Italy, Specialty fibroid treatment center | Laparoscopic myomectomy | NR | 1 to 9 | 2/635 | Random: NA
Enrollment period: | Groups: | Indications, N: | Baseline fibroid size (mm): | Adhesions at second look, N (%): | Methods and blinding: NA
03/1988 to 04/2001 | NA | - Infertility: 445 | < 20: 633 (54%) | 2/121 (1.6) | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | 21 to 39: 357 (30.5%) | Modifiers: | Loss to follow-up: NA
NR | 635 patients | NR | 40 to 59: 123 (10.5%) | NR | Drop-out rates: NA
| (1,170 fibroids) | Additional procedures, N: | > 60: 57 (4.9%) | | Statistical issues: -
| N at follow-up: | - Adhesiolysis: 118; - Ovarian cystectomy: 89; - Coagulation of endometriotic lesions: 157; - Salpingectomy for ectopic pregnancy: 5; - Appendectomy: 5 | Type of fibroid, N (%): | | EXTERNAL VALIDITY: fair (3)
| 121 second look surgeries | | - Subserous: 630 (53.8); - Intramural: 412 (35.2); - Pedunculated: 128 (10.9) | | Age: -, NR
| Age, mean yrs (range): | | | | Race: NA, not US study
| 34.5 (24 to 51) | | | | Pregnancy history: +, reported
| Race/ethnicity: | | | | Surgical history: -, NR
| NR | | | | Fibroid/uterine size: +
| Parity, parous (%): | | | | Number of fibroids: +
| Overall: 278 (43.8) | | | | Location of fibroids: +
| Baseline Hgb/Hct: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: NA
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Neonates, N (%): | Quality:
Dubuisson et al., 2000 | Retrospective case series | - Age < 45 years; - Underwent LM; - ≥1 subserous or intramural myoma >20 mm in diameter | NR | 100 of 145 (69%) delivered viable neonates | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, (%): | Mode of delivery, N (%): | INTERNAL VALIDITY: poor
France, Academic medical center | Laparoscopic myomectomy | NR | 1: 60 (61) | Spontaneous vaginal delivery: | Random: NA
Enrollment period: | Groups: | Indications, N (%): | 2: 18 (18) | 36 (36) | Methods and blinding: NA
03/1989 to 12/1996 | NA | - Infertility/recurrent spontaneous abortion: 53 (54); - Pain/pressure: 29 (29.6); - Abnormal bleeding: 16 (16.3); - Rapidly growing myoma: 14 (14.3) | ≥3: 20 (21) | Forceps delivery: 22 (22) | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy: | Baseline largest fibroid size, mm ± SD: | C-section during labor: 14 (14) | Loss to follow-up: 10–20%
NR | 263 | NR | 47.8 ± 20.6 | C-section before labor: 28 (28) | Drop-out rates: NA
| Number of women at follow-up, N (%): | Associated procedure(s): | Type of largest fibroid, (%): | Gestational age, weeks ± SD: | Statistical issues: -
| 98 (37.2) | NR | Intramural: 32 (32.6) | 36.5 ± 2.7 | EXTERNAL VALIDITY: poor (4)
| 145 pregnancies/ 100 delivered viable neonates; | | Subserous: 41 (41.8) | Birth weight, kg ± SD: | Age: +, reported
| Data presented here is on 100 neonates | | Pedunculated: 25 (25.6) | 3.2 ± .06 | Race: NA, not US study
| No pregnancy during follow-up after LM: | | | 1-min Apgar score, SD: | Pregnancy history: +, reported
| 128 (48.7) | | | 8.9 ±2.0 | Surgical history: -, NR
| Lost to follow-up | | | Premature delivery, N (%): | Fibroid/uterine size: -
| 37 (14.1) | | | 14 (14) | Number of fibroids: -
| Age, yrs ± SD: | | | Indications for C-section after LM, N (%): | Location of fibroids: -
| 33.2 ± 4.0 | | | Elective C-section of uterine scar: 16/42 (38.1) | Baseline characteristics: +, reported
| Race/Ethnicity: | | | Failed trial of labor,: 14 (33.3) | Length of follow-up: ++
| NR | | | Maternal/fetal pathology: 6 (14.3) | Measurement methods: +
| Parity, parous, N (%): | | | Breech presentation: 3 (7.1) | Measurement reliability: +
| Nullipara: 78 (79) | | | Suspected uterine rupture: 3 (7.1) | Clinical care: +
| Primipara: 9 (9) | | | Uterine rupture on LM scar, N (%):
| Multipara: 11 (12) | | | 1 (2.4)
| Baseline Hgb/Hct: | | | Uterine rupture away form LM scar, N (%):
| NR | | | 2 (4.8)
| | | | Obstetric complications, N (%):
| | | | Uterine rupture: 3 (3)
| | | | Uterine rupture related to LM: 1 (1)
| | | | Postpartum hemorrhage: 3 (3)
| | | | Rate of uterine rupture: 1.0% (95% CI 0.0–5.5)
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Kumakiri et al., 2005 | Retrospective case series | - Menorrhagia and abdominal fullness; - Infertility; - Fibroids ≥ 5 cm; - Wishing to have children; - Largest fibroid ≤ 12 cm; - Uterus size ≤ 14 weeks gestation | NR | Pregnancy: 105.3 ± 45.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids enucleated, mean ± SD: | No pregnancy: 106.0 ± 51.5 | INTERNAL VALIDITY: fair
Japan, Academic medical center | Laparoscopic myomectomy | See inclusion criteria | Pregnancy: 3.2 ± 2.7 | P =0.75 | Random: NA
Enrollment period: | Groups: | Indications, N: | No pregnancy: 3.7 ± 3.6 | Mean estimated blood loss, ml ± SD: | Metods and blinding: NA
01/1998 to 12/2002 | NA | Infertility: 59 | P = 0.04 | Pregnancy: 85.2 ± 105.8 | Pt selection criteria: +
Funding: | N at enrollment: | Menorrhagia: 20 | Baseline largest fibroid size mm ± SD: | No pregnancy: 120.3 ± 174.5 | Loss to follow-up: <10%
NR | 108 | Dysmenorrhea: 17 | Pregnancy: 67.5 ± 16.9 | P =0.53 | Drop-out rates: NA
| N at follow-up: | Lower abdominal pain: 6 | No pregnancy: 62.3 ± 16.3 | Pregnancy success rate, N (%): | Statistical issues: -
| NA | Other: 6 | P = 0.004 | 40/108 (37%) | EXTERNAL VALIDIT: fair (2)
| Age, yrs ± SD: | Pre-operative therapy (%): | Type of fibroid: | Spontaneous pregnancies, N (%): | Age: +, reported
| 35.5 ± 3.5 | GnRH: 86 (79.6) | NR | 40/47 (85.1) | Race: NA, not US study
| Race/Ethnicity: | Associated procedure(s): | | ART pregnancies, N (%); | Pregnancy history: -, NR
| NA | NR | | 7/47 (14.9) | Surgical history: -, NR
| Parity, parous (N): | | | Miscarriages, N (%): | Fibroid/uterine size: +
| Multiparous: 10 | | | 11/47 (23.4) | Number of fibroids: +
| Baseline Hgb/Hct: | | | Ectopic, N: | Location of fibroids: +
| NR | | | 1/47 (2.1) | Baseline characteristics: +, reported
| | | | Live births, N (%): | Length of follow-up: +
| | | | 32/47 (68.1) | Measurement methods: +
| | | | Elective Cesarean delivery, N (%): | Measurement reliability: +
| | | | 9/32 (28.1) | Clinical care: +
| | | | VBALM failure, N (%):
| | | | 4/23 (17.4)
| | | | Modifiers:
| | | | Pregnancy rate correlated positively with diameter of largest fibroid:
| | | | OR =1.06; 95% CI, 1.02–1.10
| | | | P = 0.004
| | | | Modifiers:
| | | | Pregnancy rate correlated negatively with age at myomectomy:
| | | | OR = 0.88; 95% CI, 0.80–0.98
| | | | P = 0.02
| | | | Pregnancy rate correlated negatively with number of enucleated fibroids:
| | | | OR =1.17; 95% CI, 1.01–1.37
| | | | P = 0.04
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, mean min (range): | Quality:
Malzoni et al., 2003 | Retrospective case series | - Undergoing laparoscopic myomectomy | NR | 85 (58 to 180) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Fibroids removed, N (%): | Conversion to laparotomy, N (%): | INTERNAL VALIDITY: fair
Italy, Community | Laparoscopic myomectomy for fibroids ≥ 5cm | NR | 1: 84 (58.33) | 2 (1.39) | Random: NA
Enrollment period: | Groups: | Indications, N (%): | 2: 35 (24.3) | Transfusion, N (%): | Methods and blinding: NA
01/1997 to 07/1999 | NA | - Infertility: 102 (70.8); - Abnormal bleeding: 98 (68); - Pain: 64 (44.4); - More than 1 symptom: 81 (56.2) | 3: 17 (11.8) | 1 (0.69) | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy: | 4: 6 (4.17) | Length of stay, days (range): | Loss to follow-up: NA
NR | 144 | None | Baseline dominant fibroid size, mean cm (range): | 2.6 (2 to 5) | Drop-out rates: NA
| N at follow-up: | Associated procedure(s), N (%): | 7.8 (5 to 18) | Intramural hematoma, N (%): | Statistical issues: -
| NR | - Lysis: 24 (16.6); - Tubal plasty: 6 (4.16); - Appendectomy: 5 (3.47); - Ovarian cystectomy: 4 (2.77); - Coagulation of endometriosis: 3 (2.08) | Type of fibroid, N (%): | 1 day post-op: 108 (75) | EXTERNAL VALIDITY: fair (1)
| Age, mean yrs: | | - Interstitial submucous: 108 (75); - Subserous sessile: 15 (10.4); - Pedunculated: 7 (4.86); - Intraligamentous: 14 (9.7) | 2 day post-op: 14 (9.7) | Age: +, reported
| 33.7 (22 to 41) | | | Pregnancy rate N (%)*: | Race: NA, not US study
| Race/ethnicity: | | | 26 in 21 patients (25%) | Pregnancy history: +, reported
| NR | | | Spontaneous: 20 | Surgical history: -, NR
| Parity, parous, N (%): | | | After IVF: 1 | Fibroid/uterine size: +
| Nulligravida: 98 (60.5) | | | Live birth, N: | Number of fibroids: +
| Baseline Hgb/Hct: | | | 21 | Location of fibroids: +
| NR | | | Cesarean delivery, N: | Baseline characteristics: +, reported
| | | | 12/21 | Length of follow-up: +
| | | | Vaginal delivery, N: | Measurement methods: +
| | | | 9/21 | Measurement reliability: +
| | | | Uterine rupture, N: | Clinical care: +
| | | | 0
| | | | Miscarriage, N:
| | | | 4/26
| | | | Ectopic pregnancy, N:
| | | | 1/26
| | | | Pregnancy rate, 1997, N (%):
| | | | 6-mon: 13/38 (34.21)
| | | | 12-mon: 21/38 (55.26)
| | | | Adhesions at 2nd-look, N (%):
| | | | 6/18 (33)
| | | | Severity of adhesions, N (%):
| | | | Type 1: 4 (22.2)
| | | | Type 2: 2 (11.1)
| | | | Type 3: 0
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Seracchioli et al., 2000 | RCT | - Fibroid(s) ≥ 5 cm; - Infertility | NR | G1: 88.85 ± 26.91 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | G2: 100.23 ± 38.34 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Myomectomy | - Pedunculated fibroids; - Uterine size above umbilicus; - > 3 fibroids of > 5 cm size; - Other causes of infertility | G1: 2.75 ± 1.98 | Conversion to laparotomy, N (%): | Random: +
Enrollment period: | Groups: | Indications for LM, N (%): | G2: 2.94 ± 1.53 | G1: NA | Methods and blinding: NA
01/1993 to 01/1998 | G1: Abdominal myomectomy | - Primary infertility: 87 (66.4); - Secondary infertility: 44 (33.6) | Baseline size of largest fibroid (cm ± SD): | G2: 3 (4.3) | Pt selection criteria: ++
Funding: | G2: Laparoscopic myomectomy | Preoperative therapy: | G1: 7.47 ± 2.60 | Intra-operative complications: | Loss to follow-up: 10–20%
NR | N at enrollment: | None | G2: 7.07 ± 2.54 | None | Drop-out rates: NA
| G1: 65 | Associated procedure(s): | Type of fibroid, N (%): | Decrease in Hgb: | Statistical issues: +
| G2: 66 | NR | Subserosal: | G1: 2.17 ± 1.57 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | | G1: 19 (44.2) | G2: 1.33 ± 1.23 | Age: +, reported
| G1: 59 | | G2: 24 (55.8) | P < 0.001 | Race: NA, not US study
| G2: 56 | | Intramural: | Transfusion, N: | Pregnancy history: +, reported
| Age, yrs ± SD: | | G1: 54 (52.9) | G1: 3 | Surgical history: -, NR
| G1: 33.97 ± 4.79 | | G2: 48 (47.1) | G2: 0 | Fibroid/uterine size: +
| G2: 34.00 ± 4.11 | | “Reaching Cavity”: | Fever > 38° C, N (%): | Number of fibroids: +
| Race/ethnicity: | | G1: 5 (9.2) | G1: 17 (26.2) | Location of fibroids: +
| NR | | G2: 2 (4.1) | G2: 8 (12.1) | Baseline characteristics: +, reported
| Parity: | | | Length of stay, hrs ± SD: | Length of follow-up: +
| See fertility status | | | G1: 142.80 ± 34.60 | Measurement methods: +
| Baseline Hgb/Hct: | | | G2: 75.61 ± 37.09 | Measurement reliability: +
| NR | | | Antibiotic Rx, N (%): | Clinical care: +
| | | | G1: 17 (26.2)
| | | | G2: 8 (12.1)
| | | | Pregnancy rate, N (%):
| | | | G1: 33/59 (55.9)
| | | | G2: 30/56 (53.6)
| | | | Miscarriage, N (%):
| | | | G1: 4 (12.1)
| | | | G2: 6 (20.0)
| | | | Ectopic:
| | | | G1: 0
| | | | G2: 1
| | | | Births:
| | | | G1: 27/59
| | | | G2: 20/56
| | | | Preterm births, N (%):
| | | | G1: 2 (7.4)
| | | | G2: 1 (5.0)
| | | | Cesarean rate, N (%):
| | | | G1: 21 (77.8)
| | | | G2: 13 (65.0)
| | | | Uterine Rupture:
| | | | 0
| | | | Fibroid recurrence, by US every 6 mos, N (%):
| | | | G1: 12 (20.3)
| | | | G2: 12 (21.4)
| | | | Subsequent treatment, N:
| | | | G1:
| | | | Myomectomy: 3
| | | | Hysterectomy: 1
| | | | G2: 0
| | | | Modifiers:
| | | | NR

* Calculated by reviewer.

Evidence Table 11. KQ3 Preventing further growth

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Fibroid size at 1 year, cm ^ 3 ^ ± SD: | Quality:
Colacurci et al., 2000 | Prospective cohort | - <57 yr; - Amenorrheic 12–36 mos; - Subserosal or intramural fibroid; - Menopausal status confirmed by FSH > 30 IU/l and estradiol < 30 pg/ml; - No previous HRT | NR | G1/G2: 28.81 ± 30.02 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Modifiers: | INTERNAL VALIDITY: fair
Italy, Academic medical center | Hormone therapy | - Submucosal fibroid; - Liver disease; - Heart disease; - Hypercholesterolemia; - Severe hypertension; - Estrogen dependent/ breast cancer; - High alcohol intake; - Cigarette smoking > 20/day; - BMI >28 | See Groups | NR | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size (cm^3^± SD): | | Methods and blinding: NA
01/1995 to 01/1998 | G1: Single asymptomatic fibroid < 3 cm/14 cm^3^; | NR | G1/G2: 24.14 ± 20.02 | | Pt selection criteria: ++
Funding: | G2: Single asymptomatic fibroid > 3 cm/14 cm^3^ | Preoperative therapy: | G3: NA | | Loss to follow-up: 10–20%
NR | G3: No uterine fibroids | NR | Type of fibroid, N: | | Drop-out rates: NR
| N at enrollment: | Associated procedure(s): | Subserosal: 26 | | Statistical issues: +
| G1: 20 | NR | Intramural: 14 | | EXTERNAL VALIDITY: fair (2)
| G2: 20 | | | | Age: +, reported
| G3: 20 | | | | Race: NA, not US study
| N at follow-up: | | | | Pregnancy history: -, NR
| G1: 15 | | | | Surgical history: NA
| G2: 18 | | | | Fibroid/uterine size: +
| G3: 20 | | | | Number of fibroids: +
| Age, yrs ± SD: | | | | Location of fibroids: +
| G1: 51.4 ± 2.87 | | | | Baseline characteristics: -, NR
| G2: 51.3 ± 2.59 | | | | Length of follow-up: ++
| G3: 51.2 ± 2.26 | | | | Measurement methods: +
| Race/ethnicity: | | | | Measurement reliability: +
| NR | | | | Clinical care: +
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | No change in fibroid volume, N (%): | Quality:
Gregoriou et al., 2001 | Prospective cohort | - Age ≤ 54 yrs; - No menses ≥ 18 mos; - No contraindication for HRT; - Endometrial thickness ≤ 4 cm; - No other medication for at least 6 mos prior to recruitment; - Alcohol intake < 5 units/week; - Non-smoker; - BMI < 28 | NR | G1: 21 (91.3) | Overall quality score: good
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 20 (86.9) | INTERNAL VALIDITY: good
Greece, Academic medical center | Administration of Tibolone in postmenopausal women | NR | NR | Increase in fibroid volume, N (%): | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size, mean volume ± SD: | G1: 2 (8.7) | Methods and blinding: NA
04/1996 to 04/1997 | G1: Asymptomatic, intramural or subserous fibroid with diameter ≤ 2cm | NR | G1: 15.8 ± 1.4 | G2: 3 (13.1) | Pt selection criteria: ++
Funding: | G2: Asymptomatic, intramural or subserous fibroid with diameter >2cm to ≤ 5cm | Pre-operative therapy: | G2: 28.2 ± 1.6 | Percent increase in fibroid volume, 12 mos: | Loss to follow-up: <10%
NR | G3: Women without any detectable fibroids | NA | Type of fibroid: | G1: 5.2% | Drop-out rates: <5%
| N at enrollment: | Associated procedure(s): | NR | G2: 9.2% | Statistical issues: +
| G1: 23 | NR | | Percent increase in fibroid volume, 24 mos: | EXTERNAL VALIDITY: good
| G2: 23 | | | G1: 6.1% | Age: +, reported
| G3: 20 | | | G2: 10.3% | Race: NA, not US study
| N at follow-up: | | | Modifiers: | Pregnancy history: +, reported
| G1: 23 | | | NR | Surgical history: NA
| G2: 23 | | | | Fibroid/uterine size: +
| G3: 20 | | | | Number of fibroids: +
| Age, yrs ± SD: | | | | Location of fibroids: +
| G1: 51.1 ± 2.84 | | | | Baseline characteristics: +, reported
| G2: 50.2 ± 2.32 | | | | Length of follow-up: ++
| G3: 50.5 ± 2.61 | | | | Measurement methods: +
| Race/ethnicity: | | | | Measurement reliability: +
| NR | | | | Clinical care: +
| Parity, parous, %:
| G1: 84.3%
| G2: 85%
| G3: 85%
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^± SD: | Fibroid size | Quality:
Palomba, Sena, et al., 2001 | Prospective cohort | - Natural menopause for 1 to 2 yrs; - 1 to 2 intramural or subserosal uterine fibroids, with at least one >2 cm | G1: 313.1 ± 83.9 | 3rd cycle, cm^3^ ± SD: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 327.7 ± 89.9 | G1: 143.9±38.8 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Transdermal estradiol (E_2_) and Medroxyprogesterone Acetate (MPA) | - Neoplastic, metabolic or infectious diseases; - Vascular thrombosis; - BMI > 30; - Hormonal therapy in prior 6 mos; - Endometrial abnormalities by ultrasound; - Endometrial thickness > 5 mm; - Hypoechoic or calcified fibroids | G3: NA | G2: 153.1±62.1 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids: | P = NS | Methods and blinding: NA
NR | G1: women with fibroids, 50 μg/day transdermal E_2_ + 2.5 mg/day MPA X 12 cycles | NR | NR | 6th cycle, cm^3^ ± SD: | Pt selection criteria: ++
Funding: | G2: women with fibroids, 1 tablet calcium carbonate per day X 12 cycles | Preoperative therapy: | Baseline fibroid size, cm^3^± SD: | G1: 146.6±45.5 | Loss to follow-up: <10%
NR | G3: women without fibroids, 50 μg/day transdermal E_2_ + 2.5 mg/day MPA X 12 cycles | NR | G1: 141.7 ± 37.8 | G2: 155.3±64.7 | Drop-out rates: 5–10%
| N at enrollment: | Associated procedure(s): | G2: 150.3 ± 58.7 | P = NS | Statistical issues: +
| G1: 35 | NR | G3: NA | 9th cycle, cm^3^ ± SD: | EXTERNAL VALIDITY: fair (3)
| G2: 35 | | Type of fibroid: | G1: 147.1±49.1 | Age: +, reported
| G3: 35 | | NR | G2: 155.4±68.6 | Race: NA, not US study
| N at follow-up: | | | P = NS | Pregnancy history: +, reported
| G1: 31 | | | 12th cycle, cm^3^ ± SD: | Surgical history: -, NR
| G2: 31 | | | G1: 147.5±53.3 | Fibroid/uterine size: +
| G3: 30 | | | G2: 156.0±72.5 | Number of fibroids: -
| Age, yrs ± SD: | | | P = NS | Location of fibroids: -
| G1: 53.8 ± 3.8 | | | No significant difference in bleeding patterns between G1 and G2 | Baseline characteristics: +, reported
| G2: 52.4 ± 3.7 | | | Amenorrhea, at cycle 3, G1 and G3 less prevalent that G2 (P < 0.05) | Length of follow-up: ++
| G3: 54 ± 3.8 | | | Abnormal uterine bleeding episodes at cycle 3, G1 and G3 more severe than G2 (P < 0.05) | Measurement methods: +
| Race/ethnicity: | | | By 6th, 9th, and 12th treatment cycles bleeding pattern was not significantly different between 3 groups | Measurement reliability: +
| NR | | | Modifiers: | Clinical care: +
| Parity. mean ± SD: | | | NR
| G1: 2.1 ± 1.7
| G2: 2.2 ± 1.6
| G3: 2.1 ± 1.7
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm ^ 3 ^ ± SD: | Uterine volume at 12 mos, cm^3^± SD: | Quality:
Polatti et al., 2000 | RCT | - Menopause > 12 mos; - 49 to 54 yrs of age; - No prior hormonal therapy in 12 mos; - No contraindications to HRT; - Endometrial thickness ≤ 4mm | G1: 60 ± 10 | G1: 66 ± 8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 64 ± 9 | G2: 70 ± 9 | INTERNAL VALIDITY: poor
Italy, Academic medical center | Hormonal therapy in postmenopausal women | NR | G3: 64 ± 10 | G3: 68 ± 9 | Random: +
Enrollment period: | Groups: | Indications: | G4: 62 ± 9 | G4: 69 ± 7 | Methods and blinding: -
01/1996 to 01/1997 | G1: No fibroids - oral combination of EV 2 mg and CA 1 mg 21 days | NR | Number of fibroids: | Uterine volume at 24 mos, cm^3^± SD: | Pt selection criteria: +
Funding: | G2: No fibroids - transdermal E_2_ 50μg 21 days and oral MPA 10 mg/day days 10–21 | Pre-operative therapy: | NR | G1: 66 ± 7 | Loss to follow-up: <10%
NR | G3: With fibroids - oral combination of EV 2 mg and CA 1 mg 21 days | NA | Baseline fibroid size(cm^3^± SD): | G2: 71 ± 8 | Drop-out rates: >10%
| G4: With fibroids - transdermal E_2_ 50μg 21 days and oral MPA 10 mg/day days 10–21 | Associated procedure(s): | G1: NA | G3: 69 ± 7 | Statistical issues: +
| N at enrollment: | NA | G2: NA | G4: 70 ± 8 | EXTERNAL VALIDITY: poor (4)
| G1: 80 | | G3: 18.6 ± 1.4 | Fibroid Volume at 12 mos, cm^3^± SD: | Age: +, reported
| G2: 80 | | G4: 19.3 ± 1.3 | G1: NA | Race: NA, not US study
| G3: 40 | | Type of fibroid: | G2: 25.4 ± 1.2* | Pregnancy history: -, NR
| G4: 40 | | NR | G3: 19.2±1.1 | Surgical history: NA
| N at follow-up: | | | G4: 23.8±0.9, P < 0.01 | Fibroid/uterine size: +
| G1: 76 | | | Fibroid Volume at 24 mos, cm^3^± SD: | Number of fibroids: -
| G2: 74 | | | G1: NA | Location of fibroids: -
| G3: 38 | | | G2: 26.2 ± 1.1* | Baseline characteristics: -, NR
| G4: 36 | | | G3:19.5±1.1 | Length of follow-up: ++
| Age, yrs ± SD: | | | G4:24.2±0.8, P < 0.01 | Measurement methods: +
| G1: 51 ± 1.8 | | | *Four women in G2 developed fibroids | Measurement reliability: +
| G2: 52 ± 1.4 | | | Modifiers: | Clinical care: +
| G3: 51 ± 1.6 | | | NR
| G4: 52 ± 1.5
| Race/ethnicity:
| NR
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Estrogen and progestogen therapy use > 5 yr was associated with a 1.7-fold increased risk of leiomyomas (95% CI; 0.9–3.3). | Quality:
Reed et al., 2004 | Retrospective case control | - No history of uterine fibroids; - Myomectomy; - Hysterectomy; - Age: 40 to 59 yrs | NR | Statistically significant associations with estrogen and progestogen therapy use were only present among women with a body mass index less than 24 kg/m^2^; OR (ever-use), 2.3 (95% CI, 1.2–4.3); and OR (≥ 5 yr use), 4.0 (95% CI, 1.6–10.3) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Other Modifiers: | INTERNAL VALIDITY: poor
US, Community | NA | - Having menstrual periods; - Using unopposed postmenopausal estrogen therapy for at least 3 mos in the preceding 5 yr; - Unopposed progestin use for at least 3 mos in past 5 yr | NR | NR | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | | Methods and blinding: NA
03/1994 to 06/1998 | G1: Fibroids | NA | NR | | Pt selection criteria: +
Funding: | G2: No fibroids | Pre-operative therapy: | Type of fibroid: | | Loss to follow-up: >20%
NR | N at enrollment: | None | NR | | Drop-out rates: >10%
| G1: 256 | Associated procedure(s): | | | Statistical issues: +
| G2: 276 | N/A | | | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | | Age: +, reported
| NA | | | | Race: +, reported
| Age, N (%): | | | | Pregnancy history: +, reported
| G1: | | | | Surgical history: NA
| 40 to 44: 43 (16.8) | | | | Fibroid/uterine size: +
| 45 to 49: 98 (38.3) | | | | Number of fibroids: -
| 50 to 54: 75 (29.3) | | | | Location of fibroids: -
| 55 to 59: 40 (15.6) | | | | Baseline characteristics: -, NR
| G2: | | | | Length of follow-up: NA
| 40 to 44: 39 (14.1) | | | | Measurement methods: -
| 45 to 49: 107 (38.8) | | | | Measurement reliability: -
| 50 to 54: 92 (33.3) | | | | Clinical care: -
| 55 to 59: 38 (13.8)
| Race/ethnicity, N (%):
| G1:
| White: 210 (82)
| Black: 15 (5.9)
| Hispanic: 14 (5.5)
| Asian: 13 (5.1)
| Other: 4 (1.5)
| G2:
| White: 233 (84.4)
| Black: 7 (2.5)
| Hispanic: 9 (3.3)
| Asian: 25 (8.3)
| Other: 4 (1.5)
| Parity, N (%):
| G1:
| 0: 54 (21.1)
| 1: 48 (18.8)
| 2: 91 (35.6)
| 3+: 63 (24.5)
| G2:
| 0: 55 (19)
| 1: 49 (17.9)
| 2: 106 (38.4)
| 3+: 66 (23.8)
| Baseline Hgb/Hct:
| NR

Evidence Table 12. KQ 4 Costs

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria and Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Total professional costs, (N): | Quality:
Baker et al., 2002 | Retrospective cohort | - Women > age 21 yr; - Had UAE or myomectomy in 2001 for symptomatic fibroids | NR | G1: $2,220 (19) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: $1,611 (9) | INTERNAL VALIDITY: poor
US, Academic medical center | UAE and abdominal myomectomy | NR | NR | P < 0.002 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Total hospital costs, (N): | Methods and blinding: NA
2001 | G1: UAE | NA | NR | G1: $3,193 (16) | Pt selection criteria: -
Funding: | G2: Abdominal myomectomy | Preoperative therapy: | Type of fibroid: | G2: $5,598 (16) | Loss to follow-up: NA
NR | N at enrollment: | NA | NR | P < 0.0001 | Drop-out rates: NA
| G1: 23 | Additional procedures: | | Total costs without imaging, (N): | Statistical issues: -
| G2: 17 | NA | | G1: $5,371 (12) | EXTERNAL VALIDITY: poor (8)
| N at follow-up: | | | G2: $7,401 (8) | Age: +, reported
| NA | | | P < 0.0001 | Race: -, NR
| Age, yrs ± SD: | | | Total costs with imaging, (N): | Pregnancy history: -, NR
| G1: 42.6 ± 4.4 | | | G1: $6,708 (12) | Surgical history: -, NR
| G2: 35.5 ± 4.6 | | | G2: $7,630 (8) | Fibroid/uterine size: -
| P < 0.001 | | | P = 0.086 | Number of fibroids: -
| Race/ethnicity: | | | Modifiers: | Location of fibroids: -
| NR | | | NR | Baseline characteristics: -, NR
| Parity: | | | | Length of follow-up: NA
| NR | | | | Measurement methods: +
| Baseline Hgb/Hct: | | | | Measurement reliability: +
| NR | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Complications, N (%): | Quality:
Beinfeld et al., 2002 | Retrospective cohort | - Patients with principal diagnosis of uterine fibroids; - Principle procedure of hysterectomy based on ICD-9 codes | NR | G1: 2 (3.9) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N ± SD: | G2: 12 (4.8) | INTERNAL VALIDITY: poor
US, Academic medical center | UAE vs. hysterectomy | - Patients whose costs were > 3 SD above mean hospital costs | G1: 2.8 ± 1.4 | P = 1.0 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 2.0 ± 1.1 | Length of stay, days ± SD: | Methods and blinding: NA
10/1998 to 03/2001 | G1: UAE | NR | P < 0.0001 | G1: 0.95 ± 0.4 | Pt selection criteria: -
Funding: | G2: Hysterectomy | Preoperative therapy: | Baseline largest fibroid size, cm ± SD: | G2: 2.6 ± 1.0 | Loss to follow-up: NA
NR | N at enrollment: | NR | G1: 8.0 ± 3.0 | P < 0.0001 | Drop-out rates: NA
| G1: 57 | Additional procedures: | G2: 6.3 ± 3.2 | Cost, $ ± SD: | Statistical issues: -
| G2: 300 | NR | P = 0.001 | G1: $8,223 ± 1,834 | EXTERNAL VALIDITY:poor (5)
| N at follow-up: | | Type of largest fibroid, N (%): | G2: $6,046 ± 1,589 | Age: +, reported
| NA | | Intramural: | P < 0.0001 | Race: +, reported
| Age, yrs ± SD: | | G1: 32 (72.3) | Modifiers: | Pregnancy history: -, NR
| G1: 43.1 ± 4.9 | | G2: 171 (62.0) | NR | Surgical history: -, NR
| G2: 47.0 ± 6.8 | | Submucosal: | | Fibroid/uterine size: +
| P < 0.0001 | | G1: 9 (19.2) | | Number of fibroids: +
| Race/ethnicity, %: | | G2: 52 (18.9) | | Location of fibroids: +
| White | | Subserosal: | | Baseline characteristics: -, NR
| G1: 69.6 | | G1: 4 (8.5) | | Length of follow-up: NA
| G2: 77.0 | | G2: 53 (19.2) | | Measurement methods: +
| Black | | P = 0.18 | | Measurement reliability: +
| G1: 28.6 | | | | Clinical care: -
| G2: 14.2
| Hispanic
| G1: 0
| G2: 7.0
| Asian
| G1: 1.8
| G2: 1.7
| P = 0.01
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Conversion to open myomectomy, %: | Quality:
Subramanian et al., 2001 | Retrospective cohort | - Inpatient and outpatient claims containing Current Procedural Terminology, 4th edition (CPT-4) codes for hysteroscopic (56354, 58145), laparoscopic (56309), or abdominal (58140) myomectomies or the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM) procedure code for all types of myomectomies (68.29) | NR | G1: 7.4 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 13.3 | INTERNAL VALIDITY: poor
US, Database | Myomectomy | - Hysterectomy conversion | NR | G3: NA | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Conversion to hysterectomy, %: | Methods and blinding: NA
1995 to 1997 | G1: Hysteroscopy | NR | NR | G1: 1.5 | Pt selection criteria: -
Funding: | G2: Laparoscopy | Preoperative therapy: | Type of fibroid: | G2: 2.8 | Loss to follow-up: NA
NR | G3: Abdominal | NR | NR | G3: 3.7 | Drop-out rates: >10%
| N at enrollment: | Type of fibroid: | | Length of stay, mean days: | Statistical issues: -
| 4394 | NR | | G1: 2.20 | EXTERNAL VALIDITY: poor (8)
| N at follow-up: | | | G2: 2.25 | Age: +, reported
| 1 year: 820 | | | G3: 2.91 | Race: -, NR
| 2 yr: 236 | | | Reoperation, 1 year, %: | Pregnancy history: -, NR
| Age, mean yrs: | | | G1: 14.4 | Surgical history: -, NR
| 42 | | | G2: 12.3 | Fibroid/uterine size: -
| In/Outpatient: | | | G3: 7.2 | Number of fibroids: -
| G1: 42.8/43.6 | | | Cost ($) | Location of fibroids: -
| G2: 39.5/36.9 | | | In/Outpatient: | Baseline characteristics: -, NR
| G3: 37.0/N/A | | | G1: 7,704/4,291 | Length of follow-up: NA
| Race: | | | G2: 8,018/7,357 | Measurement methods: +
| NR | | | G3: 8,860/N/A | Measurement reliability: -
| Parity: | | | Modifiers: | Clinical care: -
| NR | | | NR
| Baseline Hgb/Hct:
| NR

Evidence Table 13. KQ 5 Modifiers of outcomes

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Recurrence rate, N (%): | Quality:
Doridot et al., 2001 | Retrospective case series | - Women undergoing laparoscopic myomectomy | NR | 45 (22.9%) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | Mean recurrence time, mos ± SD: | INTERNAL VALIDITY: fair
France, Academic medical center | Laparoscopic myomectomy | NR | 1: 114 (58.1) | 42 ± 22 (4–95) | Random: NA
Enrollment period: | Groups: | Indications, N (%): | 2: 36 (18.4) | Recurrence requiring surgery, N (%): | Methods and blinding: NA
03/1989 to 12/1996 | NA | - Pain: 51 (26); - Menometrorrhagia: 45 (23); - Infertility: 63 (32.1); - Size: 32 (16.3); - Pressure: 3 (1.5); - Recurrent miscarriage: 2 (1) | ≥ 3: 46 (23.5) | 8 (4.6) | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy: | Baseline fibroid size (mm), N (%): | Second operative procedures, N: | Loss to follow-up: 10–20%
NR | 196 | GnRH agonist, N (%): | < 50: 86 (43.9) | LM: 3 | Drop-out rates: NA
| N at follow-up: | - No: 122 (70.5); - Yes: 51 (29.5) | 50 to 70: 67 (34.2) | Myomectomy by laparotomy: 1 | Statistical issues: +
| 173 | Associated procedure(s): | ≥ 70: 43 (21.9) | Hysterectomy by laparotomy: 4 | EXTERNAL VALIDITY: good
| Age, yrs ± SD (range): | NR | Type of fibroid, N (%): | Cumulative risk of recurrence: | Age: +, reported
| 36.6 ± 6.6 (18 to 54) | | - Intramural: 74 (37.8); - Subserous: 97 (49.5); - Pedunculated: 25 (12.8) | At 2 yr: 12.7% | Race: NA, not US study
| Race/ethnicity: | | | At 5 yr: 16.7% | Pregnancy history: +, reported
| NR | | | Modifiers: | Surgical history: -, NR
| Parity, N (%): | | | Nulliparity, %: | Fibroid/uterine size: +
| 0: 143 (72.9) | | | At 2 yr: 12.8% | Number of fibroids: +
| 1: 40 (20.4) | | | At 5 yr: 47.6% P = 0.0025 | Location of fibroids: +
| 2: 10 (5.1) | | | Multivariate analysis of recurrence risk: | Baseline characteristics: +, reported
| 3: 3 (1.5) | | | - Nulliparity: P = 0.004; 95% CI, 1.4–8.7; - > 1 fibroid: P = 0.05; 95% CI, 0.27–0.98 | Length of follow-up: ++
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, mean ml (range): | Operative time, mean min: | Quality:
Ferrari et al., 2000 | RCT | NR | G1: 388 (257 to 520) | G1: 135 (115–173) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 370 (243 to 463) | G2: 120 (98–123) | INTERNAL VALIDITY: poor
Italy, Academic medical center | Hysterectomy | NR | Number of fibroids: | P = 0.001 | Random: +
Enrollment period: | Groups: | Indications: | NR | Conversion to laparotomy, N: | Methods and blinding: -
NR | G1: Laparoscopically assisted vaginal hysterectomy | NR | Baseline fibroid size: | G1: 3 | Pt selection criteria: -
Funding: | G1a: Uterus ≤ 500 g | Preoperative therapy: | NR | G2: NA | Loss to follow-up: NA
NR | G1b: Uterus > 500 g | NR | Type of fibroid: | Decrease in Hgb, mean g/dL: | Drop-out rates: <5%
| G2: Total abdominal hysterectomy | Additional procedures: | NR | G1: 1.1 (0.8–1.9) | Statistical issues: +
| G2a: Uterus ≤ 500 g | Bilateral salpingooophorectomy, N (%) | | G2: 1.8 (0.7–2.5) | EXTERNAL VALIDITY: fair (3)
| G2b: Uterus > 500 g | G1: 19 (61) | | P = NS | Age: +, reported
| N at enrollment: | G2: 21 (68) | | Transfusions, N (%): | Race: NA, not US study
| G1: 31 | | | G1: 0 | Pregnancy history: +, reported
| G2: 31 | | | G2: 1 (3) | Surgical history: +, reported
| N at follow-up: | | | P = NS | Fibroid/uterine size: +
| G1: 31 | | | Febrile morbidity (not defined), N (%): | Number of fibroids: -
| G1a: 20 | | | G1: 1 (3) | Location of fibroids: -
| G1b: 11 | | | G2: 5 (16) | Baseline characteristics: -, NR
| G2: 31 | | | P = NS | Length of follow-up: NA
| G2a: 21 | | | Pain medication use, N (%): | Measurement methods: +
| G2b: 10 | | | G1: 7 (23) | Measurement reliability: +
| Age (mean, range): | | | G2: 24 (77) | Clinical care: +
| G1: 48 (46 to 49) | | | P < 0.001
| G2: 46 (43 to 50) | | | Length of stay, mean days (range):
| Race Ethnicity: | | | G1: 3.8 (34 to 4.0)
| NR | | | G2: 5.8 (5.3 to 6.3)
| Parity, parous, N (%): | | | P < 0.001
| Nulliparous: | | | Uterine weight, mean gm (range):
| G1: 5 (16) | | | G1: 400 (263 to 590)
| G2: 7 (23) | | | G2: 400 (255 to 556)
| Baseline Hgb/Hct: | | | P = NS
| NR | | | Operating (mean min, range):
| | | | G1b: 150 (125 to 173)
| | | | G2b: 108 (83 to 120)
| | | | P = 0.002
Author: | Design: | Inclusion criteria: | Baseline uterine size, median: | 5 year cumulative probability: | Quality:
Hanafi, 2005 | Retrospective case series | NR | 10 gestational weeks | Fibroid recurrence: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | 62% | INTERNAL VALIDITY: fair
US, Community | Myomectomy by exploratory laporotomy | NR | 1: 37 (26) | Any surgery for recurrence: | Random: NA
Enrollment period: | Groups: | Indications, %: | > 1: 108 (74) | 17% | Methods and blinding: NA
01/1992 to 10/2002 | NA | - Menometrorrhagia: 91; - Dysmenorrhea: 82; - Dyspareunia: 41; - Noncyclic pelvic pain: 22; - Anemia: 3; - Infertility: 30; - No symptoms: 3 | Baseline fibroid size, median gm (range): | Major surgery for recurrence: | Pt selection criteria: -
Funding: | N at enrollment: | Preoperative therapy: | 103 (8–590) | 9% | Loss to follow-up: <10%
NR | 154 | None | (N=28) | Modifiers of fibroid recurrence: | Drop-out rates: <5%
| N at follow-up: | Associated procedure(s): | Type of fibroid, N (%): | Number of fibroids, %: | Statistical issues: +
| 132 | NR | - Subserous: 34 (23); - Intramural or intramural/ subserous: 98 (68); - Submucous or intramural/ submucosal: 6 (4); - All locations: 7 (5) | 1 fibroid: 11 | EXTERNAL VALIDITY: fair (3)
| Age, median yr: | | | > 1 fibroid: 74 | Age: +, reported
| 36 (24 to 49) | | | P = 0.011 | Race: +, reported
| Race/ethnicity: | | | Uterine size, %: | Pregnancy history: +, reported
| NR | | | ≤ 10 weeks: 46 | Surgical history: -, NR
| Parity, median: | | | > 10 weeks: 82 | Fibroid/uterine size: +
| 1 (0 to 6), 89% had not completed families | | | P = 0.03 | Number of fibroids: +
| Baseline Hgb/Hct: | | | Subsequent parity, %: | Location of fibroids: -
| NR | | | 26 | Baseline characteristics: +, reported
| | | | Without subsequent parity, %: | Length of follow-up: ++
| | | | 76 | Measurement methods: +
| | | | P = 0.010 | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^: | UAE Failure (persistent or recurrent bleeding, pain, or bulk systems with repeat UAE, myomectomy, and/or hysterectomy), N (%): | Quality:
Huang et al. 2006 | Retrospective case series | - Consecutive UAE patients | 531.5 | Total: 22 (9.4) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Hysterectomy: 16 (6.9) | INTERNAL VALIDITY: poor
Canada, Academic medical center | UAE | NR | NR | Myomectomy: 6 (2.6) | Random: NA
Enrollment period: | N at enrollment: | Indications, N: | Baseline dominant fibroid size, cm^3^: | Modifiers: | Methods and blinding: NA
11/1997 to 02/2004 | 233 | - Menorrhagia: 125; - Abdominal distension: 59; - Abdominal/pelvic pain: 38 | 201.4 | Baseline fibroid size (cm^3^): | Pt selection criteria: -
Funding: | N at follow-up: | Preoperative therapy: | Type of fibroid: | Failed: 355.2 | Loss to follow-up: NA
NR | 233 | NR | NR | Succeeded: 183.8 | Drop-out rates: NA
| Age: | Associated procedure(s): | | P = NS | Statistical issues: -
| NR | NR | | Baseline uterine size, cm^3^: | EXTERNAL VALIDITY: poor (5)
| Race/ethnicity: | | | Failed: 590.2 | Age: +, reported
| NR | | | Succeeded: 525.3 | Race: -, NR
| Parity: | | | P = NS | Pregnancy history: -, NR
| NR | | | Prior myomectomy Failed: 13% vs. Succeeded: 2.4%, P < 0.05 | Surgical history: +, reported
| Baseline Hgb/Hct: | | | Fibroid volume reduction at 6 mos, %: | Fibroid/uterine size: +
| NR | | | Failed: 54.4 | Number of fibroids: -
| | | | Succeeded: 36.0 | Location of fibroids: -
| | | | P < 0.05 | Baseline characteristics: +, reported
| | | | | Length of follow-up: +
| | | | | Measurement methods: +
| | | | | Measurement reliability: -
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Procedure time, min ± SD: | Quality:
Katsumori et al., 2003 | Retrospective case series | - Pre-menopausal; - At least 1 clinical symptom uncontrolled by medication | G1: 1,380 ± 500 | G1: 55.3 ± 15.8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | G2: 684 ± 337 | G2: 46.6 ± 14.3 | INTERNAL VALIDITY: fair
Japan, Community | UAE | - Desire future pregnancy; - Refused major surgery | P < 0.001 | Length of stay, days ± SD: | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids: | G1: 4.0 ± 1.6 | Methods and blinding: NA
2002 | G1: Fibroid ≥ 10 cm | Symptomatic fibroids | NR | G2: 3.8 ± 0.8 | Pt selection criteria: ++
Funding: | G2: Fibroid < 10 cm | Pre-operative therapy: | Baseline fibroid size, diameter of largest, cm ± SD: | Minor complications N (%): | Loss to follow-up: NA
NR | N at enrollment: | NR | G1: 12.4 ± 2.2 | G1: 9 (19.1) | Drop-out rates: <5%
| G1: 47 | Associated procedure(s): | G2: 6.8 ± 2.0 | G2: 16 (15.2) | Statistical issues: -
| G2: 105 | NR | P < 0.001 | P = 0.637 | EXTERNAL VALIDITY: poor (4)
| N at follow-up: | | Largest fibroid volume (ml ± SD): | Major complications N (%): | Age: +, reported
| 30 days: 152 | | G1: 701 ± 336 | G1: 3 (6.4) | Race: NA, not US study
| > 4 mos: 134 | | G2: 154 ± 107 | G2: 2 (1.9) | Pregnancy history: -, NR
| > 12 mos: 96 | | P < 0.001 | P = 0.172 | Surgical history: -, NR
| > 24 mos: 49 | | Type of fibroid: | Increased care, prolonged hospitalization, N (%): | Fibroid/uterine size: +
| Age: | | NR | G1: 2 (4.3) | Number of fibroids: -
| 42.5 (31 to 52) | | | G2: 2 (1.9) | Location of fibroids: -
| Race/ethnicity: | | | Symptom control, mean score ± SD: | Baseline characteristics: +, reported
| NR | | | Menorrhagia at 4 mos: | Length of follow-up: ++
| Parity: | | | G1: 3.36 ± 0.99 | Measurement methods: +
| NR | | | G2: 3.79 ± 0.55 | Measurement reliability: +
| Baseline Hgb/Hct: | | | P = 0.003 | Clinical care: +
| NR | | | Menorrhagia at 1 yr:
| | | | G1: 3.58 ± 0.50
| | | | G2: 3.79 ± 0.56
| | | | P = 0.022
| | | | Patient satisfaction at 4 mos:
| | | | G1: 1.80 ± 0.46
| | | | G2: 1.97 ± 0.18
| | | | P = 0.004
| | | | Complete devascularization at 1 week, N (%):
| | | | G1: 34 (72)
| | | | G2: 94 (90)
| | | | P = 0.007
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Kumakiri et al., 2005 | Retrospective case series | - Menorrhagia and abdominal fullness; - Infertility; - Fibroids ≥ 5 cm; - Wishing to have children; - Largest fibroid ≤ 12 cm; - Uterus size ≤ 14 weeks gestation | NR | Pregnancy: 105.3 ± 45.3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids enucleated, mean ± SD: | No pregnancy: 106.0 ± 51.5 | INTERNAL VALIDITY: fair
Japan, Academic medical center | Laparoscopic myomectomy | See inclusion criteria | Pregnancy: 3.2 ± 2.7 | P =0.75 | Random: NA
Enrollment period: | Groups: | Indications, N: | No pregnancy: 3.7 ± 3.6 | Mean estimated blood loss, ml ± SD: | Metods and blinding: NA
01/1998 to 12/2002 | NA | Infertility: 59 | P = 0.04 | Pregnancy: 85.2 ± 105.8 | Pt selection criteria: +
Funding: | N at enrollment: | Menorrhagia: 20 | Baseline largest fibroid size mm ± SD: | No pregnancy: 120.3 ± 174.5 | Loss to follow-up: <10%
NR | 108 | Dysmenorrhea: 17 | Pregnancy: 67.5 ± 16.9 | P =0.53 | Drop-out rates: NA
| N at follow-up: | Lower abdominal pain: 6 | No pregnancy: 62.3 ± 16.3 | Pregnancy success rate, N (%): | Statistical issues: -
| NA | Other: 6 | P = 0.004 | 40/108 (37) | EXTERNAL VALIDIT: fair (2)
| Age, yrs ± SD: | Pre-operative therapy, N (%): | Type of fibroid: | Spontaneous pregnancies, N (%): | Age: +, reported
| 35.5 ± 3.5 | GnRH: 86 (79.6) | NR | 40/47 (85.1) | Race: NA, not US study
| Race/Ethnicity: | Associated procedure(s): | | ART pregnancies, N (%); | Pregnancy history: -, NR
| NA | NR | | 7/47 (14.9) | Surgical history: -, NR
| Parity, parous (N): | | | Miscarriages, N (%): | Fibroid/uterine size: +
| Multiparous: 10 | | | 11/47 (23.4) | Number of fibroids: +
| Baseline Hgb/Hct: | | | Ectopic, N: | Location of fibroids: +
| NR | | | 1/47 (2.1) | Baseline characteristics: +, reported
| | | | Live births, N (%): | Length of follow-up: +
| | | | 32/47 (68.1) | Measurement methods: +
| | | | Elective Cesarean delivery, N (%): | Measurement reliability: +
| | | | 9/32 (28.1) | Clinical care: +
| | | | VBALM failure, N (%):
| | | | 4/23 (17.4)
| | | | Modifiers:
| | | | Pregnancy rate correlated positively with diameter of largest fibroid:
| | | | OR =1.06; 95% CI, 1.02–1.10
| | | | P = 0.004
| | | | Modifiers:
| | | | Pregnancy rate correlated negatively with age at myomectomy:
| | | | OR = 0.88; 95% CI, 0.80–0.98
| | | | P = 0.02
| | | | Pregnancy rate correlated negatively with number of enucleated fibroids:
| | | | OR = 1.17; 95% CI, 1.01–1.37
| | | | P = 0.04
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, min ± SD: | Quality:
Litta et al., 2005 | Retrospective cohort | - Reproductive age; - Single fibroid ≤ 4cm; - Undergoing laparoscopic myomectomy | NR | G1: 96.0 ± 38.5 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed, N: | G2: 103.9 ± 33.8 | INTERNAL VALIDITY: fair
Italy, Academic medical center | Treatment with GnRH analog for 3 months prior to laparoscopic myomectomy | - Intrauterine lesions | G1: 30 | P = NS | Random: NA
Enrollment period: | Groups: | Indications: | G2: 30 | Mean estimated blood loss, ml ± SD: | Methods and blinding: NA
01/2000 to 9/2003 | G1: GnRH analog for 3 months | NR | Baseline fibroid size, ml ± SD: | G1: 201.7 ± 209.4 | Pt selection criteria: +
Funding: | G2: No treatment prior to myomectomy | Pre-operative therapy: | G1: 494.4 ± 488.7 | G2: 203.8 ± 193.9 | Loss to follow-up: NA
NR | N at enrollment: | See groups | G2: NR | P = NS | Drop-out rates: NA
| G1: 30 | Associated procedure(s): | Type of fibroid: | Conversion to laparotomy, N (%): | Statistical issues: -
| G2: 30 | NR | NR | G1: 1 (3.3) | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | G2: 0 | Age: +, reported
| G1: 30 | | | Length of stay, days ± SD: | Race: NA, not US study
| G2: 30 | | | G1: 1.6 ±1.3 | Pregnancy history: -, NR
| Age, yrs ± SD: | | | G2: 1.7 ± 1.6 | Surgical history: -, NR
| G1: 39.2 ± 6.1 | | | P = NS | Fibroid/uterine size: +
| G2: 38.9 ± 5.4 | | | Fever > 38°C, N (%): | Number of fibroids: -
| Race/Ethnicity: | | | G1: 2 (6.6) | Location of fibroids: -
| NR | | | G2: 1 (3.3) | Baseline characteristics: -, NR
| Parity: | | | Fibroid volume vs. baseline, ml ± SD: | Length of follow-up: NA
| NR | | | G1: 369.2 ± 358.9 | Measurement methods: +
| Baseline Hgb/Hct: | | | G2: 397.7 ± 409.2 | Measurement reliability: +
| NR | | | P < 0.001 | Clinical care: -
| | | | Decrease in fibroid volume, ml ± SD:
| | | | G1: 125.2 ± 159.8
| | | | G2: NR
| | | | Modifiers:
| | | | Increasing fibroid volume and weight associated with blood loss, and operating time within and across groups (P < 0.0001).
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | UAE, N (%): | Quality:
Lohle et al., 2006 | Prospective case series | - Presence of uterine fibroid; - Symptoms including: heavy menstrual bleeding, pain, and/or bulk-related symptoms unresolved by previous treatment | 532 ± 375 | Bilateral: 152 (96) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Unilateral: 6 (4) | INTERNAL VALIDITY: poor
Netherlands, Academic medical center | UAE | - Postmenopausal; - Malignancy; - Pedunculated fibroids; - Pregnancy | NR | Amenorrhea, N (%): | Random: NA
Enrollment period: | Groups: | Indications: | Baseline dominant fibroid size, cm ^ 3 ^ ± SD: | Permanent: 17 (11) | Methods and blinding: NA
02/2001 to 02/2004 | NA | See inclusion criteria | 201 ± 249 | Transient: 20 (13) | Pt selection criteria: -
Funding: | N at enrollment: | Pre-operative therapy: | Type of fibroid: | Fibroid expulsion, N (%): 16 (10) | Loss to follow-up: <10%
NR | 158 | NR | NR | Additional procedures, N: | Drop-out rates: NA
| N at follow-up, 12 months: | Associated procedure(s): | | Second UAE: 9 | Statistical issues: -
| 126 (MRI) | NR | | Hysterectomy: 3 | EXTERNAL VALIDITY: poor (4)
| 142 (survey) | | | Dominant fibroid size, 12 mos, cm ^ 3 ^ ± SD: | Age: +, reported
| Age, mean yrs (range): | | | 78 ± 100 | Race: +, reported
| 42.3 (23–53 | | | Dominant fibroid volume reduction, % ± SD: | Pregnancy history: -, NR
| Race/Ethnicity, N: | | | 60 ± 40 | Surgical history: -, NR
| White: 142 | | | P<0.0001 | Fibroid/uterine size: +
| Afro-Caribbean: 11 | | | Uterine volume reduction, % ± SD: | Number of fibroids: -
| Asian: 5 | | | 47 ± 34 | Location of fibroids: -
| Parity: | | | P<0.0001 | Baseline characteristics: +, reported
| NR | | | Symptom resolution, N (%): | Length of follow-up: +
| Baseline Hgb/Hct: | | | Heavy bleeding: 113/126 (91) | Measurement methods: +
| NR | | | Pain: 80/91 (92) | Measurement reliability: +
| | | | Bulk symptoms: 70/81 (92) | Clinical care: +
| | | | Satisfaction, N (%):
| | | | Very satisfied: 81 (57)
| | | | Satisfied: 51 (36)
| | | | Not satisfied: 10 (7)
| | | | Modifiers:
| | | | Embosphere vs Embogold:
| | | | Embogold: similar volume reduction, satisfaction, and fibroid expulsion P=NS
| | | | Embogold: greater risk of skin rash (P = 0.031); slower return to usual activities (P = 0.004)
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Risk of laparoconversion, multivariate: | Quality:
Marret et al., 2006 | Retrospective case series | - Planned laparoscopic myomectomy | NR | Increase in largest fibroid size of 1 mm: | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean ± SD: | OR = 1.06 | INTERNAL VALIDITY: good
France, Academic medical center and Community | Myomectomy | - Missing medical record data | G1: 2.4 ± 2.5 | (95% CI, 1.03–1.09) | Random: NA
Enrollment period: | Groups: | Indications: | G2: 1.7 ± 1.8 | P < 0.001 | Methods and blinding: NA
01/1996 to 12/2000 | G1: Conversion to laparotomy | - Pelvic pain: 41%; - Infertility: 38%; - Bleeding: 14% | Baseline largest fibroid size, mm ± SD: | Dominant fibroid intramural: | Pt selection criteria: +
Funding: | G2: Laparoscopy | Pre-operative therapy: | G1: 67.9 ± 18.2 | OR = 3.24 | Loss to follow-up: NA
NR | N at enrollment: | GnRHa: | G2: 47.8 ± 18.6 | (95% CI, 1.11–10.21) | Drop-out rates: NA
| G1: 33 | G1: 1 (3.0) | Type of fibroid, N (%): | P = 0.036 | Statistical issues: +
| G2: 83 | G2: 2 (2.4) | Subserous: | Surgeon's experience (senior vs. junior): | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | P = NS | G1: 19 (57.6) | OR = 0.15 | Age: -, NR
| NA | Associated procedure(s): | G2: 61 (73.5) | (95% CI, 0.04–0.46) | Race: -, NR
| Age: | NR | Intramural: | P = 0.001 | Pregnancy history: -, NR
| NR | | G1: 15 (45.5) | | Surgical history: -, NR
| Race/ethnicity: | | G2: 21 (25.3) | | Fibroid/uterine size: +
| NR | | | | Number of fibroids: +
| Parity: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: +, reported
| Baseline Hgb/Hct: | | | | Length of follow-up: NA
| NR | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Conversion to open myomectomy, N: | Quality:
Marziani et al., 2005 | Prospective case series | - Excessive uterine bleeding defined by history with Hgb < 10 g/dl and Hct < 37; - Infertility; - Fibroids defined by transvaginal ultrasound and diagnostic hysteroscopy | NR | 3 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, mean: | Conversion to hysterectomy, N: | INTERNAL VALIDITY: fair
Italy, Academic medical center | Hysteroscopic myomectomy | - Myoma size ≥ 3 cm; - Intramural fibroid with < 5 mm of myometrium between fibroid and serosa; - Adnexal pathology; - Abnormal endometrial biopsy | 1.5 (1 to 3) | 2 | Random: NA
Enrollment period: | Groups: | Indications, N (%) | Baseline fibroid size, cm ^ 3 ^ ± SD: | Uterine perforation, N: | Methods and blinding: NA
01/1997 to 12/2001 | G1: Women with submucous uterine fibroids | - Abnormal uterine bleeding: 84 (78.5); - Infertility: 23 (21.5) | Type 0: 22 ± 9 | 0 | Pt selection criteria: ++
Funding: | N at enrollment: | Pre-operative therapy: | Type 1: 25 ± 9 | Post-operative hemorrhage, N: | Loss to follow-up: <10%
NR | 107 | GnRH to reduce size of fibroid if ≥ 3 cm or desired by surgeon | Type 2: 23 ± 10 | 3 | Drop-out rates: NA
| N at follow-up, 36 mos: | Associated procedure(s): | Type of fibroid, N (%): | Number of procedures, N (%): | Statistical issues: -
| G1: 104 | NR | Type 0: 51 (47.7) | One: 91 (85) | EXTERNAL VALIDITY: fair (3)
| Age, mean yrs: | | Type 1: 43 (40.2) | Two: 16 (15) | Age: +, reported
| G1: 35 (30 to 46) | | Type 2: 13 (12.1) | Control of menorrhagia, N (%): | Race: NA, not US study
| Race/ethnicity: | | | - One procedure: 68 (81.0); - Two procedures: 11 (13.1); - Not controlled: 5 (4.7) | Pregnancy history: -, NR
| NR | | | Modifiers: | Surgical history: -, NR
| Parity: | | | Number of fibroids and control of menorrhagia after one procedure: | Fibroid/uterine size: +
| NR | | | - 1 fibroid: 46 of 46 (100%); - 2 fibroids: 21 of 24 (87.5%); - 3 fibroids: 12 of 14 (85.7%) | Number of fibroids: +
| Baseline Hgb/Hct: | | | P < 0.05 | Location of fibroids: +
| G1: 10.33 g/dL | | | | Baseline characteristics: +, reported
| | | | | Length of follow-up: -
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Number of fibroids: | Improvement or stabilization of symptoms 6 mos after UFE, %: | Quality:
McLucas et al., 2001 | Prospective cohort | - Menorrhagia or postmenopausal bleeding secondary to uterine myomata | NR | 88 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Baseline fibroid size: (cm) (range): | Total uterine volume decreased, N (%): | INTERNAL VALIDITY: poor
US, Academic center | UAE | - Contraindications to angiography and embolization, such as coagulopathy, pelvic inflammatory disease, diabetes mellitus, or vasculitis | 7.8 (1.5 to 16.3) | 46 (52) | Random: NA
Enrollment period: | Medical Groups: | Indications: | Type of fibroid: | Treatment failures, N (%): | Methods and blinding: NA
04/1997 to 08/1999 | NA | NR | NR | 21/167 (13) | Pt selection criteria: ++
Funding: | N at enrollment: | Preoperative therapy: | | Post UFE complications, %: | Loss to follow-up: >20%
NR | 167 | NR | | - Fever: 7; - Nausea/vomiting: 1; - Passage of submucosus myoma: 5; - Premature menopause: 2.4; - Hysterectomy: 3.5 | Drop-out rates: <5%
| N at follow-up (12 mos): | Associated procedure(s): | | Other modifiers: | Statistical issues: +
| 46 | NR | | Lupron use | EXTERNAL VALIDITY: fair (3)
| Age (range): | | | Earlier pelvic surgery - more likely to fail UFE: | Age: +, reported
| 43 (29 to 63) | | | P = 0.012 | Race: -, NR
| Race/ethnicity: | | | Age, parity, menopausal status, uterine characterics, procedure characteristics (partial size and partial load), and post-procedure complications unrelated to UAE falure | Pregnancy history: +, reported
| NR | | | | Surgical history: +, reported
| Parity*: | | | | Fibroid/uterine size: +
| 0.7 | | | | Number of fibroids: -
| Baseline uterine size: | | | | Location of fibroids: -
| Without lupron: 155 (1,389 mL) | | | | Baseline characteristics: +, reported
| With lupron: 12 (1,404 mL) | | | | Length of follow-up: ++
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Operative time, median mins, (range): | Quality:
Munoz et al., 2003 | Retrospective case series | - Symptomatic fibroid or infertility; - Desire for uterine preservation; - Fibroid <6cm; - Less than 50% of endometrial surface affected | NR | 32.5 (10–105) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Uterine perforation: | INTERNAL VALIDITY: fair
Spain, Academic medical center | Hysteroscopic myomectomy | - Labastida's Type V fibroid; - Pathology that contraindicates procedure | NR | N = 1 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | Baseline fibroid size, cm (%): | Hemorrhage: | Methods and blinding: NA
01/1992 to 12/1999 | NA | - AUB: 101 (84.1); - Infertility: 14 (11.6); - Pain: 7 (5.8%) | 1: 5 (4.1) | N = 1 | Pt selection criteria: +
Funding: | N at enrollment: | Pre-operative therapy, N (%) | 2: 31 (25.8) | Unable to complete procedure: | Loss to follow-up: <10%
NR | 120 | - None: 39 (32.5); - Danazol: 9 (7.5); - GnRHa: 72 (60) | 3: 63 (52.5) | N = 22 | Drop-out rates: NA
| N at follow-up: | Associated procedure(s), N (%): | 4: 19 (15.9) | Length of stay, N (%): | Statistical issues: -
| 120 | 37 (30.8) | 5: 2 (1.7) | 12 hrs: 15 (47.5) | EXTERNAL VALIDITY: fair (3)
| Age (median yrs): | | Type of fibroid, N (%): | 24 hrs: 33 (27.5) | Age: +, reported
| 44.8 (23 to 74) | | Type 0: 52 (43.3) | 36 hrs: 5 (4.3) | Race: NA, not US study
| Race/ethnicity: | | Type I: 51 (42.5) | 48 hrs: 17 (14.1) | Pregnancy history: +, reported
| NR | | Type II: 17 (14.1) | 72 hrs: 7 (5.8) | Surgical history: -, NR
| Parity (range): | | | > 72 hrs: 1 (0.8) | Fibroid/uterine size: +
| 1.6 (0 to 6) | | | Infection, N: | Number of fibroids: -
| Nulliparous: 25.8% | | | N = 1 | Location of fibroids: +
| Baseline Hgb/Hct: | | | Excess glycine, N: | Baseline characteristics: +, reported
| NR | | | 1 | Length of follow-up: -
| | | | Later interventions, N (%): | Measurement methods: +
| | | | - 107 (89.1); - Hysterectomy: 3; - Myomectomy: 9 | Measurement reliability: +
| | | | Glycine retention, median: | Clinical care: +
| | | | 281 ml
| | | | Modifiers:
| | | | Operative time modified by size, median mins (range):
| | | | < 3cm: 26.5 (10 to 45)
| | | | > 3cm: 36.3 (10 to 105)
| | | | Glycine retention by modified by complexity, median:
| | | | Simple procedure:
| | | | 270 ml
| | | | Combined procedures:
| | | | 302 ml
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm ^ 3 ^ (%): | Procedure time, min (median): | Quality:
Pron, Bennett, Common, Sniderman et al., 2003 | Prospective case series | - Symptomatic, ultrasound documented fibroids | 0 to 250: 106 (22) | 61 (55) | Overall quality score: fair
Pron, Bennett, Common, Wall et al., 2003 | Intervention: | Exclusion criteria: | 251 to 500: 131 (37) | (95% CI, 58–63) | INTERNAL VALIDITY: fair
Pron, Cohen, Soucie et al., 2003 | UAE | - Active PID; - Renal insufficiency; - Endometrial carcinoma; - Undiagnosed pelvic mass; - Pregnancy | 501 to 1,000: 149 (31) | Fluoroscopy time, mean min: | Random: NA
Pron, Mocarski, Bennett et al., 2003 | Groups: | Indications, %: | ≥1,001: 102 (21) | 18.9 | Methods and blinding: NA
Pron, Mocarski, Cohen, et al., 2003 | NA | - Menorrhagia: 17; - Menorrhagia/ dysmenorrhea: 63; - Pelvic pain: 13; - Bulk effects: 8 | Number of fibroids, N (%): | (95% CI, 18.0–19.8) | Pt selection criteria: ++
Country and setting: | N at enrollment: | Pre-operative therapy: | 1: 150 (30) | Complications, N (%): | Loss to follow-up: <10%
Canada, Academic medical centers | 555 | NR | 2 to 4: 220 (44) | 30 (5.3) | Drop-out rates: <5%
Enrollment period: | N at follow-up: | Associated procedure(s): | ≥ 5: 125 (26) | (95% CI, 3.6%–7.4%) | Statistical issues: -
11/98 to 11/00 | 548 (98%) at 2 wks | NR | Baseline fibroid size mean cm^3^: | Major complications, N: | EXTERNAL VALIDITY: good
Funding: | 464 (83.6%) at 3 mos ultrasound | | 293 | 3 | Age: +, reported
NR | Age, mean (yrs): | | (95% CI, 259–327) | Intra-procedural pain, N (%): | Race: +, reported
| 43 (18 to 59) | | Type of fibroid, N (%): | None: 386 (70) | Pregnancy history: +, reported
| Race/ethnicity: | | - Intramural: 285 (60); - Intramural and subserosal/ submucosal: 63 (13); - Subserosal: 92 (19); - Submucosal: 33 (7) | Minor/tolerable: 162 (30) | Surgical history: +, reported
| White: 66% | | | Uncomfortable: 54 (10) | Fibroid/uterine size: +
| Black: 23% | | | Very uncomfortable: 50 (9) | Number of fibroids: +
| Other: 11% | | | Unbearable: 23 (4) | Location of fibroids: +
| Parity, parous (%): | | | NRS (1 to 10)- mean (median): 6.3 (6.0) | Baseline characteristics: +, reported
| Nulliparous: 50 | | | Ineffective analgesia: 24 (4%) | Length of follow-up: +
| Baseline Hgb/Hct: | | | Postprocedural pain, N (%): | Measurement methods: +
| NR | | | None: 44 (8) | Measurement reliability: +
| | | | Minor/tolerable: 86 (18) | Clinical care: +
| | | | Uncomfortable: 103 (19)
| | | | Very uncomfortable: 188 (35)
| | | | Unbearable: 116 (22)
| | | | NRS (1 to 10)- mean (median): 7.0 (7.5)
| | | | Ineffective pain management: 57 (10%)
| | | | Prescription pain medication use, days(median):
| | | | 6.8 (6.0)
| | | | Fever, N (%);
| | | | 157 (29)
| | | | Length of stay, nights (range):
| | | | 1.3 (0 to 11)
| | | | Infection rate, %:
| | | | 2.4 (95% CI, 1.3–4.0)
| | | | Fibroid expulsion, N (%):
| | | | 19 (3)
| | | | Readmission, N (%):
| | | | 16 (3)
| | | | Mean change in dominant fibroid volume, %:
| | | | 33 (95% CI, 28–38)
| | | | Mean change in uterine volume, %:
| | | | 27 (95% CI, 23–32)
| | | | Improvement in menorrhagia, N (%):
| | | | 358/429 (83)
| | | | (95% CI, 80–87)
| | | | Improvement in dysmenorrhea, N (%):
| | | | 249/322 (77)
| | | | (95% CI, 72–82)
| | | | Improvement in bulk related symptoms, N (%):
| | | | 388/464 (84)
| | | | (95% CI, 80–87)
| | | | Improvement in urinary urgency/ frequency, N (%):
| | | | 263/306 (86)
| | | | (95% CI, 82–90)
| | | | Duration of menstrual flow (mean days):
| | | | Pre UAE: 7.6
| | | | Post UAE: 5.4
| | | | P < 0.001
| | | | Pad count for day heaviest flow (median):
| | | | Pre UAE: 9
| | | | Post UAE: 4
| | | | P < 0.0001
| | | | Satisfactory intra-procedural care:
| | | | 97%
| | | | Satisfactory post-procedural ward care:
| | | | 87%
| | | | Median life-impact score (higher = greater impact):
| | | | Pre UAE: 8
| | | | Post UAE: 3
| | | | P < 0.001
| | | | Overall satisfaction, %:
| | | | 91 (95% CI, 89–94)
| | | | Strong dissatisfaction, N (%):
| | | | 32/487 (7)
| | | | Would repeat UAE, N (%):
| | | | 414/487 (85)
| | | | Time until recovery, days, (median):
| | | | 13.1 (10.0)
| | | | Subsequent hysterectomy, N (%):
| | | | 8 (1.5)
| | | | Modifiers:
| | | | Larger fibroids were more likely to have significant volume decrease
Author: | Design: | Inclusion criteria: | Baseline uterine size: | All complications, N (%): | Quality:
Rajan et al., 2004 | Retrospective case series | - UAE for symptomatic fibroids | NR | 25 (6.1) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Minor complications, N (%): | INTERNAL VALIDITY: good
Canada, Community | UAE | - Pregnancy; - Gynecologic malignancy or pre-malignancy; - Adenomyosis with no fibroids; - Severe renal insufficiency; - Acute vasculitis; - Any acute or chronic infection; - Active pelvic infection or history of pelvic inflammatory disease; - Uncorrectable coagulopathy | NR | 14 (3.4) | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size (cm ± SD): | Major complications, N (%): | Methods and blinding: NA
01/2000 to 07/2003 | NA | NR | 7.7 ± 3.2 | 11 (2.7) | Pt selection criteria: +
Funding: | N at enrollment: | Preoperative therapy: | Type of fibroid, N (%): | Intrauterine infection (requiring intravenous antibiotic therapy and/or surgery): | Loss to follow-up: NA
NR | 410 | NR | Submucosal: 148 (36.1) | 5 (1.2%) | Drop-out rates: <5%
| N at follow-up: | Additional procedures: | Non-submucosal: 262 (63.9) | Modifiers: | Statistical issues: +
| NA | NR | | Intrauterine infection more common in submucosal than nonsubmucosal | EXTERNAL VALIDITY: poor (4)
| Age, yrs ± SD: | | | In univariate analysis P = 0.006; logistic regression not significant | Age: +, reported
| 42.8 ± 5.8 | | | (P = 0.079) | Race: +, reported
| Race/ethnicity: | | | | Pregnancy history: -, NR
| White: 66% | | | | Surgical history: -, NR
| Asian: 11% | | | | Fibroid/uterine size: +
| Afro-Caribbean: 23% | | | | Number of fibroids: -
| Parity: | | | | Location of fibroids: +
| NR | | | | Baseline characteristics: +, reported
| Baseline Hgb/Hct: | | | | Length of follow-up: +
| NR | | | | Measurement methods: +
| | | | | Measurement reliability: -
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Complications, %: | Quality:
Roth et al., 2003 | Retrospective case series | - Abdominal myomectomy; - Black or white race | NR | 29 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids removed, %: | G2 vs. G1 | INTERNAL VALIDITY: fair
US, Academic medical center | Abdominal myomectomy | NR | 1 fibroid: | OR = 1.36; 95%CI, 0.56–3.15 | Random: NA
Enrollment period: | Groups: | Indications: | G1: 36.5 | Urinary retention or bladder injury, %: | Methods and blinding: NA
07/1992 to 06/1998 | G1: White | NR | G2: 10 | 0.7 | Pt selection criteria: -
Funding: | G2: Black | Preoperative therapy: | 2 to 3 fibroids: | Transfusion, %: | Loss to follow-up: NA
AHRQ | N at enrollment: | NR | G1: 23.5 | 20 | Drop-out rates: NA
| G1: 107 | Associated procedure(s): | G2: 25 | G2 vs. G1 | Statistical issues: +
| G2: 118 | NR | ≥ 4 fibroids: | OR = 0.9; 95%CI, 0.27, 2.76 | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | G1: 40 | Fever, %: | Age: +, reported
| G1: 107 | | G2: 65 | 2.9 | Race: +, reported
| G2: 118 | | P = 0.001 | Ileus, %: | Pregnancy history: -, NR
| Age, yrs ± SD: | | Baseline fibroid size (wk gestation), %: | 2.4 | Surgical history: -, NR
| G1: 35.6 ± 6.9 | | <12 wks: | Disruption of wound, %: | Fibroid/uterine size: +
| G2: 34.8 ± 5.0 | | G1: 28.8 | 1 | Number of fibroids: -
| P = 0.021 | | G2: 13.8 | Infection, %: | Location of fibroids: -
| Race/ethnicity: | | 12 to 16 wks: | 2 | Baseline characteristics: -, NR
| NA - see groups | | G1: 27.3 | Respiratory complications, %: | Length of follow-up: +
| Parity: | | G2: 37.9 | 1 | Measurement methods: +
| NR | | 16 to 20 wks: | Modifiers: | Measurement reliability: +
| Baseline Hct (mean ± SD): | | G1: 19.7 | Uterine size | Clinical care: -
| G1: 37.3 ± 4.0 | | G2: 29.9 | (OR = 6.3; 95%CI, 3.18–12.4) and number of fibroids (OR = 2.6; 95% CI, 1.25–5.44) predicted transfusion
| G2: 36.4 ± 3.8 | | >20 wks: | Uterine size
| P = 0.232 | | G1: 9.1 | (OR = 1.86; 95%CI: 1.3–2.67), number of fibroids (OR = 1.83; 95% CI, 1.1–3.14), and co-morbidities (OR = 2.77; 95% CI, 1.1–7.69) predicted complications
| | | G2: 12.6 | Prior abdominal surgery, BMI, adhesions, and pre-op diagnoses not associated with complications or transfusion
| | | P = 0.12
| | | Type of fibroid:
| | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Subsequent care, 12 mos, N (%): | Quality:
Spies, Myers, Worthington-Kirsch et al., 2005 | Prospective case series | - Undergoing UAE for fibroid treatment; - Entered into Fibroid Registry for Outcomes Data | NR | - Medical treatment: 121 (7); - Gyn interventions: 77 (6); - Hysterectomy: 27 (1.6); - Unplanned ER care: 52 (3) | Overall quality score: fair
[See evidence table for Spies, Spector, Roth, et al., 2002] | Intervention: | Exclusion criteria: | Number of fibroids: | Symptom Score change, 12 mos: | INTERNAL VALIDITY: fair
Country and setting: | UAE | NR | NR | -38.94 ± 24.79 | Random: NA
US, Academic medical centers | Groups: | Indications: | Baseline fibroid size: | P < 0.001 | Methods and blinding: NA
Enrollment period: | NA | - Heavy bleeding; - Bulk related symptoms; - Pain | NR | HRQOL score change, 12 mos: | Pt selection criteria: ++
12/2000 to 12/2002 | N at enrollment: | Pre-operative therapy: | Type of fibroid: | 39.67 ± 25.28 | Loss to follow-up: 10–20%
Funding: | 2,112 | NR | NR | P < 0.001 | Drop-out rates: <5%
Society for Interventional Radiology Foundation | N at follow-up: | Associated procedure(s): | | Modifiers: | Statistical issues: ++
| 6 mos: 1,797 | NR | | NR | EXTERNAL VALIDITY: good
| 1 year: 1,701 | | | | Age: +, reported
| Age: | | | | Race: +, reported
| NR | | | | Pregnancy history: +, reported
| Race/ethnicity, %: | | | | Surgical history: +, reported
| White: 47.2% | | | | Fibroid/uterine size: +
| Parity: | | | | Number of fibroids: +
| NR | | | | Location of fibroids: +
| Baseline Hgb/Hct: | | | | Baseline characteristics: +, reported
| NR | | | | Length of follow-up: ++
| | | | | Measurement methods: +
| | | | | Measurement reliability: +
| | | | | Clinical care: +
Author: | Design: | Inclusion criteria: | Baseline uterine size, mean ml: | Subsequent intervention, at 3 mos, N (%): | Quality:
Spies, Ascher et al., 2001 | Prospective case series | At least 1 of the following: | 717.0 | Hyst/D&C: 6 (3) (95% CI, 1–6) | Overall quality score: good
Spies, Roth, et al., 2002 | Intervention: | - Heavy menstrual bleeding ± anemia; - Pelvic pain or pressure; back, flank, or leg pain; - Urinary frequency or other bladder symptoms; - Hydronephrosis; - Failed, refused, or not suitable for medical therapy | (95% CI, 648.8–785.2) | Hysterectomy: 1 (1) (95% CI, 0–3) | INTERNAL VALIDITY: good
Spies, Bruno, et al., 2005 | Bilateral uterine artery embolization | Patients 1 to 50: | Number of fibroids, N (%): | Repeat UAE: 0 | Random: NA
Country and setting: | Groups: | - Age: <35 yrs or wished to maintain fertility required to exhaust all therapies | 1: 28 (14.8) | Myomectomy: 0 | Methods and blinding: NA
US, Academic medical center | NA | Patients 51 to 200: | 2 to 5: 138 (73.0) | Improved symptoms, at 3 mos, N (%): | Pt selection criteria: ++
Enrollment period: | N at enrollment: | - Age: <35 yrs if failed medical therapy and only remaining option extensive myomectomy, repeat myomectomy, or hysterectomy | >5: 23 (12.2) | Yes: 180 (93) (95% CI, 89–96) | Loss to follow-up: <10%
07/1997 to 12/1999 | 200 | Exclusion criteria: | Missing: 11 | No: 9 (5) (95% CI, 2–9) | Drop-out rates: <5%
Funding: | N at follow-up: | - Pregnancy; - Suspicion of uterine, ovarian, or cervical cancer; - Pedunculated fibroids; - Hysteroscopically resectable fibroids; - Uterus >24 wks | Baseline dominant fibroid size (mean ml): | Bleeding at 3 mos: | Statistical issues: ++
NR | 3 mo: 193 | Indications: | 240 | Amenorrhea, N: 14, 8 (95% CI, 4–12) | EXTERNAL VALIDITY: good
| 12 mo: 190 | NR | (95% CI, 200.8–279.3) | Mean change in bleeding score: 3.33 (95% CI, 3.04–3.61) | Age: +, reported
| 24 mo: 161 | Preoperative therapy: | Type of fibroid, N (%): | Pain at 3 mos:: | Race: +, reported
| 36 mo: 183 | NR | - Intramural: 108 (54); - Submucosal: 35 (17.5); - Subserosal: 39 (19.5); - Missing: 18 | Mean change pain score: 3.47 (95% CI, 3.17–3.78) | Pregnancy history: +, reported
| 48 mo: 180 | Associated procedure(s): | | Improved symptoms, at 60 mos,N (%): | Surgical history: +, reported
| 60 mo: 182 | NR | | Yes: 133 (73) (95% CI, 66–79) | Fibroid/uterine size: +
| Age, mean yrs: | | | No:10 (5) (95% CI, 3–10) | Number of fibroids: +
| 43.1 (95% CI, 42.4–43.7) | | | Bleeding, at 60 mos, N (%): | Location of fibroids: +
| Race/ethnicity, %: | | | Amenorrhea: 42 (29) (95% CI, 21–37) | Baseline characteristics: +, reported
| Black: 50% | | | Mean change in bleeding score: 3.98 (95% CI, 3.67–4.28) | Length of follow-up: ++
| White: 45% | | | Pain, at 60 mos: | Measurement methods: +
| Asian: 2.5% | | | Mean change in pain score: 3.72 (95% CI, 3.34–4.10) | Measurement reliability: +
| Hispanic: 1.5% Other: 1.0% | | | Subsequent interventions, (Years1 to 5), N (%): | Clinical care: +
| Parity: | | | - Hysteroscopy/ D&C: 19; - Hysterectomy: 25 Myomectomy: 6; - Repeat UAE: 3; - Failed or recurred: 46 (25); - Continued relief: 133 (73)
| NR | | | Modifiers:
| Baseline Hgb/Hct: | | | Baseline imaging variables not associated with failure at 12 mos
| NR | | | Age, race, baseline leiomyoma volume, baseline uterine volume, and subsequent interventions were not associated with satisfaction
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Length of stay, days: | Quality:
Worthington-Kirsch et al., 2005 | Prospective case series | - Women undergoing uterine embolization for fibroids at 1 of 72 sites of FIBROID Registry | 677.7 ± 520.4 | 1.68 | Overall quality score: fair
Myers et al., 2005 | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | (95% CI, 1.21–2.15) | INTERNAL VALIDITY: fair
Country and setting: | UAE | NR | 1 to 2: 1249 (43.4) | Number of AEs, during number of hospitalizations, (% of total pts): | Random: NA
US, Varied sites (72) | Groups: | Indications (predominant symptom), N (%): | 3 to 4: 690 (24.1) | 94 in 90 (3) | Methods and blinding: NA
Enrollment period: | NA | - Heavy menstrual bleeding: 1,932 (64.7)); - Pelvic pain: 314 (10.5); - Bulk symptoms: 694 (23.3); - Other symptoms: 45 (1.5) | ≥ 5: 936 (32.6) | AE between discharge and 30 days, N (%): | Pt selection criteria: ++
12/2000 to 12/2002 | N at enrollment:* | Preoperative therapy, N (%): | Baseline fibroid size: | 710 (26) | Loss to follow-up: 10–20%
Funding: | 3,041 (30-day follow-up eligible) | GnRH agonist: 133 (4.4) | NR | Major events, N (%): | Drop-out rates: <5%
Society of Interventional Radiology Foundation through unrestricted grants from Biosphere Medical, Boston Scientific Corporation, COOK, Inc., and Cordis Endovascular | 2,112 (1-year follow-up eligible) | Additional procedures: | Type of fibroid, N (%): | 111 (4) | Statistical issues: ++
| N at follow-up: | NR | - Intramural: 1231 (42.8); - Transmural: 585 (20.3); - Subserosal: 410 (14.3); - Submucosal: 376 (13.1); - Pedunculated: subserosal: 64 (2.2); - Pedunculated: submucosal: 9 (0.3) | Recurrent pain, N (%): | EXTERNAL VALIDITY: good
| 2,729 (30 days) | | | 65 (2.1) | Age: +, reported
| 1,797 (1 year) | | | Possible infection, N (%): | Race: +, reported
| Age, yrs ± SD: | | | 19 (0.62) | Pregnancy history: +, reported
| 43.5 ± 5.6 | | | Minor events, N (%): | Surgical history: +, reported
| Race/ethnicity, %: | | | 610 (22) | Fibroid/uterine size: +
| African American: 48 | | | Hot flushes, N (%): | Number of fibroids: +
| White: 44.4 | | | 156 (5.7) | Location of fibroids: +
| Hispanic: 3.6 | | | Pain, N (%): | Baseline characteristics: +, reported
| Asian/Pacific Islander: 2.8 | | | 264 (9.6) | Length of follow-up: ++
| Other: 1.3 | | | Mean lost work days: | Measurement methods: +
| Parity, %: | | | 9.63 | Measurement reliability: +
| Nulliparous: 44.1 | | | (95% CI, 9.38–9.88) | Clinical care: +
| Baseline Hgb/Hct: | | | Modifiers:
| NR | | | Increased risk of AEs in hospital:
| | | | Univariate:
| | | | Length of procedure: OR = 1.012; 95% CI, 1.005–1.019
| | | | Core site status: OR = 0.334; 95% CI, 0.15–0.76)
| | | | Size of fibroid: OR = 1.073; 95% CI, 1.013–1.138
| | | | Multivariate:
| | | | Length of procedure: OR = 1.10; 95% CI, 1.005–1.01
| | | | Size of fibroid:
| | | | OR = 1.11; 95% CI, 1.028–1.20
| | | | Uterine volume:
| | | | OR 0.999; 95% CI, 0.998–0.999
| | | | Increased risk of AE at 30 days:
| | | | Univariate:
| | | | Prior procedures or medical therapy: OR = 1.242; 95% CI, 1.113–1.38)
| | | | P < 0.001
| | | | African American: OR = 1.158; 95% CI, 1.048–1.28
| | | | P = 0.004
| | | | Smoking status: OR = 1.139; 95% CI, 1.009–1.286
| | | | P = 0.035
| | | | Multivariate:
| | | | Smoking status: OR = 1.141; 95% CI, 1.007–1.293
| | | | P = 0.039
| | | | African American: OR = 1.129; 95% CI, 1.019–1.251
| | | | P = 0.021
| | | | Prior procedures: OR = 1.235; 95% CI, 1.103–1.383
| | | | P < 0.001
| | | | Duration of procedure: OR = 1.004; 95% CI, 1.001–1.006
| | | | P = 0.009
| | | | DVT prophylaxis: OR = 0.757; 95% CI, 0.622–0.919

* Registry without complete overlap

Evidence Table 14. KQ 6 Comparisons of Treatments

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria and Other Details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Total professional costs, (N): | Quality:
Baker et al., 2002 | Retrospective cohort | - Women > age 21 yr; - Had UAE or myomectomy in 2001 for symptomatic fibroids | NR | G1: $2,220 (19) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: $1,611 (9) | INTERNAL VALIDITY: poor
US, Academic medical center | UAE and abdominal myomectomy | NR | NR | P < 0.002 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Total hospital costs, (N): | Methods and blinding: NA
2001 | G1: UAE | NA | NR | G1: $3,193 (16) | Pt selection criteria: -
Funding: | G2: Abdominal myomectomy | Preoperative therapy: | Type of fibroid: | G2: $5,598 (16) | Loss to follow-up: NA
NR | N at enrollment: | NA | NR | P < 0.0001 | Drop-out rates: NA
| G1: 23 | Additional procedures: | | Total costs without imaging, (N): | Statistical issues: -
| G2: 17 | NA | | G1: $5,371 (12) | EXTERNAL VALIDITY: poor (8)
| N at follow-up: | | | G2: $7,401 (8) | Age: +, reported
| NA | | | P < 0.0001 | Race: -, NR
| Age, yrs ± SD: | | | Total costs with imaging, (N): | Pregnancy history: -, NR
| G1: 42.6 ± 4.4 | | | G1: $6,708 (12) | Surgical history: -, NR
| G2: 35.5 ± 4.6 | | | G2: $7,630 (8) | Fibroid/uterine size: -
| P < 0.001 | | | P = 0.086 | Number of fibroids: -
| Race/ethnicity: | | | Modifiers: | Location of fibroids: -
| NR | | | NR | Baseline characteristics: -, NR
| Parity: | | | | Length of follow-up: NA
| NR | | | | Measurement methods: +
| Baseline Hgb/Hct: | | | | Measurement reliability: +
| NR | | | | Clinical care: -
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Complications, N (%): | Quality:
Beinfeld et al., 2002 | Retrospective cohort | - Patients with principal diagnosis of uterine fibroids; - Principle procedure of hysterectomy based on ICD-9 codes | NR | G1: 2 (3.9) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N ± SD: | G2: 12 (4.8) | INTERNAL VALIDITY: poor
US, Academic medical center | UAE vs. hysterectomy | - Patients whose costs were > 3 SD above mean hospital costs | G1: 2.8 ± 1.4 | P = 1.0 | Random: NA
Enrollment period: | Groups: | Indications: | G2: 2.0 ± 1.1 | Length of stay, days ± SD: | Methods and blinding: NA
10/1998 to 03/2001 | G1: UAE | NR | P < 0.0001 | G1: 0.95 ± 0.4 | Pt selection criteria: -
Funding: | G2: Hysterectomy | Preoperative therapy: | Baseline largest fibroid size, cm ± SD: | G2: 2.6 ± 1.0 | Loss to follow-up: NA
NR | N at enrollment: | NR | G1: 8.0 ± 3.0 | P < 0.0001 | Drop-out rates: NA
| G1: 57 | Additional procedures: | G2: 6.3 ± 3.2 | Cost, $ ± SD: | Statistical issues: -
| G2: 300 | NR | P = 0.001 | G1: $8,223 ± 1,834 | EXTERNAL VALIDITY:poor (5)
| N at follow-up: | | Type of largest fibroid, N (%): | G2: $6,046 ± 1,589 | Age: +, reported
| NA | | Intramural: | P < 0.0001 | Race: +, reported
| Age, yrs ± SD: | | G1: 32 (72.3) | | Pregnancy history: -, NR
| G1: 43.1 ± 4.9 | | G2: 171 (62.0) | | Surgical history: -, NR
| G2: 47.0 ± 6.8 | | Submucosal: | | Fibroid/uterine size: +
| P < 0.0001 | | G1: 9 (19.2) | | Number of fibroids: +
| Race/ethnicity, %: | | G2: 52 (18.9) | | Location of fibroids: +
| White | | Subserosal: | | Baseline characteristics: -, NR
| G1: 69.6 | | G1: 4 (8.5) | | Length of follow-up: NA
| G2: 77.0 | | G2: 53 (19.2) | | Measurement methods: +
| Black | | P = 0.18 | | Measurement reliability: +
| G1: 28.6 | | | | Clinical care: -
| G2: 14.2
| Hispanic
| G1: 0
| G2: 7.0
| Asian
| G1: 1.8
| G2: 1.7
| P = 0.01
| Parity:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Number of fibroids: | Further invasive therapy (hysterectomy, myomectomy, or UAE), N (%): | Quality:
Broder et al., 2002 | Retrospective cohort (survey) | Patients having bilateral uterine artery embolization or abdominal myomectomy at a single institution | NR | G1: 51 (29) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Baseline fibroid size: | G2: 1 (3) | INTERNAL VALIDITY: poor
US, Academic medical center | Uterine artery embolization or abdominal myomectomy | NA | NR | P = 0.004 | Random: NA
Enrollment period: | Groups: | Elapsed time from procedure to survey (mean mos, range): | Type of fibroid: | (AOR: 12.5; 95%CI: 1.4, 110.1) | Methods and blinding: NA
02/1996 to 08/1997 | G1: Uterine artery embolization | G1: 46 (41 to 59) | NR | No improvement/worsening of symptoms, N (%): | Pt selection criteria: -
Funding: | G2: Abdominal myomectomy | G2: 49 (37 to 59) | | G1: 3 (8) | Loss to follow-up: 10–20%
Partial support form NIH (NICHD) BIRCWH Grant | N at procedure: | Indications: | | G2: 3 (10) | Drop-out rates: NA
| G1: 59 | NR | | P = 0.78 | Statistical issues: +
| G2: 38 | Preoperative therapy: | | Somewhat/very dissatisfied, N (%): | EXTERNAL VALIDITY: poor (5)
| N contacted: | NR | | G1: 2 (6) | Age: +, reported
| G1: 53 | Additional procedures: | | G2: 6 (21) | Race: +, reported
| G2: 32 | NR | | P = 0.06 | Pregnancy history: -, NR
| N respondents: | | | Clinical failure (a priori definition as combination of three above outcomes), N (%): | Surgical history: +, reported
| G1: 51 of 59 | | | G1: 20 (39) | Fibroid/uterine size: -
| G2: 30 of 38 | | | G2: 9 (30) | Number of fibroids: -
| Age, mean yrs: | | | P = 0.40 | Location of fibroids: -
| G1: 43.5 (27 to 66) | | | Modifiers: | Baseline characteristics: +, reported
| G2: 37.6 (28 to 45) | | | NR | Length of follow-up: ++
| P = 0.03 | | | (in multivariate models, months elapsed total and between procedure and survey did not predict failure) | Measurement methods: +
| Race/ethnicity, N (%): | | | | Measurement reliability: -
| G1: | | | | Clinical care: +
| White: 23 (45)
| Black: 17 (33)
| Hispanic: 3 (6)
| Asian: 1 (2)
| Other: 7 (14)
| G2:
| White: 14 (47)
| Black: 7 (23)
| Hispanic: 2 (7)
| Asian: 3 (10)
| Other: 4 (13)
| Parity:
| NR
| Baseline uterine size:
| NR
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, cm^3^: | At least 1 adverse event N (%): | Quality:
Goodwin et al., 2006 | Prospective cohort | - Symptomatic fibroids confirmed on MRI; - ≥ 30 yr old; - Regular menses; - Normal Pap smear; - Able to complete follow-up requirements | G1: 658.4 | G1: 33 (22.1) | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 590.6 | G2: 24 (40) | INTERNAL VALIDITY: good
US, Academic medical centers | UAE vs. myomectomy | - Hysteroscopically resectable fibroids; - Pelvic infection; - Gynecologic malignancy; - Undiagnosed pelvic mass outside of uterus; - Unexplained abnormal menstrual bleeding; - Infection; - Coagulopathy; - History of pelvic irradiation; - ASA score ≥ 4; - FSH level > 40 IU/L; - Participation in any other investigational device or drug study; - Desire to become pregnant; - Abnormal serum creatinine level; - Uterine arteriovenous fistula | P > 0.05 | P < 0.01 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids, N (%): | Major adverse event, N: | Methods and blinding: NA
NR | G1: UAE | NR | 0 | G1: 6 | Pt selection criteria: ++
Funding: | G2: Myomectomy | Preoperative therapy: | G1: 2 (1.3) | G2: 1 | Loss to follow-up: 10–20%
Boston Scientific Corporation | N at enrollment: | NR | G2: 1 (1.7) | P > 0.05 | Drop-out rates: <5%
| G1: 149 | Additional procedures: | 1 | Length of stay, mean hrs: | Statistical issues: ++
| G2: 60 | NR | G1: 9 (6.0) | G1: 23.8 | EXTERNAL VALIDITY: fair (3)
| N at follow-up: | | G2: 5 (8.3) | G2: 61.6 | Age: +, reported
| G1: 121 | | 2 | P < 0.0001 | Race: -, NR
| G2: 45 | | G1: 10 (6.7) | Dominant fibroid volume, 3 mos or 6 mos: | Pregnancy history: +, reported
| Age, mean yrs: | | G2: 4 (6.7) | P = NS | Surgical history: -, NR
| G1: 43.9 | | 3 | Quality-of-life assessments, 6 mos: | Fibroid/uterine size: +
| G2: 38.2 | | G1: 10 (6.7) | P = NS | Number of fibroids: +
| P < 0.0001 | | G2: 8 (13.3) | Menstrual bleeding score, 3 mos or 6 mos: | Location of fibroids: +
| Race: | | 4 | P = NS | Baseline characteristics: +, reported
| NR | | G1: 10 (6.7) | Return to normal activities, mean days: | Length of follow-up: ++
| Parity, parous (%): | | G2: 7 (11.7) | G1: 14.6 | Measurement methods: +
| G1: 75.2 | | 5 | G2: 44.4 | Measurement reliability: +
| G2: 48.3 | | G1: 6 (4.0) | P < 0.05 | Clinical care: -
| P < 0.0001 | | G2: 2 (3.3) | Missed workdays:
| Baseline Hgb/Hct: | | 6–10 | G1: 9.9
| NR | | G1: 27 (18.1) | G2: 37.0
| | | G2: 14 (23.3) | P < 0.001
| | | >10 | Modifiers:
| | | G1: 75 (50.3) | NR
| | | G2: 13 (21.7)
| | | P = 0.0001
| | | Baseline dominant fibroid size, cm^3^:
| | | G1: 182.12
| | | G2: 226.92
| | | P = 0.081
| | | Type of fibroid N (%):
| | | Intramural
| | | G1: 88 (59.1)
| | | G2: 26 (43.3)
| | | Submucosal
| | | G1: 1 (0.007)
| | | G2: 3 (5.0)
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Fibroid volume, 3 mos, ml ± SD: | Quality:
Healey et al., 2004 | Prospective cohort | - Healthy premenopausal women; - Age: 39 to 50; - Symptomatic uterine fibroids; - Regular menstrual cycles; - Day 3 serum FSH levels < 40 IU/L | G1: 538 ± 50 | G1: 434.1 ± 51.5 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids, N (%): | G2: NA | INTERNAL VALIDITY: poor
Canada, Academic medical center | UAE vs. hysterectomy | See inclusion criteria | 1: | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications, N (%): | G1: 11 (16.3) | (95% CI, 6–201) | Methods and blinding: NA
08/2000 to 04/2003 | G1: UAE | Bleeding: | G2: NA | Fibroid volume, 6 mos, ml ± SD: | Pt selection criteria: ++
Funding: | G2: Hysterectomy | G1: 42 (61.8) | ≥ 2: | G1: 361.0 ± 38.4 | Loss to follow-up: >20%
NR | N at enrollment: | G2: 16 (100) | 57 (83.8) | G2: NA | Drop-out rates: <5%
| G1: 68 | Pain/pressure: | G2: NA | P < 0.01 | Statistical issues: +
| G2: 16 | G1: 5 (7.4) | Baseline (dominant) fibroid size, ml ± SD: | (95% CI, 44–241) | EXTERNAL VALIDITY: good
| N at follow-up: | G2: 0 | G1: 154 ± 19.9 | Hormone measures at 6 mos | Age: +, reported
| G1: 48 | Urinary symptoms: | G2: NA | FSH (IU/L ± SEM): | Race: +, reported
| G2: 13 | G1: 3 (4.4) | Type of fibroid, N (%): | G1: 9.9 ± 1.0 | Pregnancy history: +, reported
| Age, yrs ± SD: | G2: 0 | Submucosal: | 95% CI, -1.7–1.2 | Surgical history: +, reported
| G1: 44.9 ± 3.8 | Multiple symptoms: | G1: 10 (14.7) | G2: 7.8 ± 1.8 | Fibroid/uterine size: +
| G2: 43.7 ± 3.6 | G1: 14 (20.1) | G2: NA | 95% CI, -0.2–4.0 | Number of fibroids: +
| Race/ethnicity: | G2: 0 | Intramural or subserosal: | LH (IU/L ± SEM): | Location of fibroids: +
| NR | Preoperativetherapy: | G1: 58 (85.3) | G1: 7.0 ± 1.1 | Baseline characteristics: +, reported
| Parity, parous, N (%): | NR | G2: NA | 95% CI, -1.2–0.8 | Length of follow-up: +
| Nulliparous: | Associated procedure(s): | | G2: 11.2 ± 5 | Measurement methods: +
| G1: 11 (22.0) | NR | | 95% CI, -1.91–3.3 | Measurement reliability: +
| G2: 0 | | | E2 (pmol/L ± SEM): | Clinical care: +
| Baseline Hgb/Hct: | | | G1: 214 ± 34.9
| NR | | | 95% CI, -52–36
| | | | G2: 326 ± 79.2
| | | | 95% CI, -39.8–212.6
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine volume, median cm ^ 3 ^ (range): | Procedure time, min: | Quality:
Hehenkamp et al., 2005 | RCT | - Ultrasound confirmation uterine fibroids; - Menorrhagia; - Premenopausal scheduled for hysterectomy | G1: 321 (31 to 3,005) | G1: 79.0 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 313 (58 to 3,617) | G2: 95.4 | INTERNAL VALIDITY: good
The Netherlands, Hospitals | UAE versus hysterectomy | - Other treatment options available; - Future pregnancy desired; - Renal failure; - Active pelvic infection or clotting disorders; - Allergic to contrast material; - Uterine malignancy suspected; - Submucosal fibroids with 50% of diameter within uterine cavity or dominant pedunculated serosal fibroids | Number of fibroids, N (%): | P = 0.007 | Random: +
Enrollment period: | Groups: | Indications, N (%): | 1 fibroid: | Mean estimated blood loss, ml ± SD: | Methods and blinding: NA
03/2002 to 02/2004 | G1: UAE | Dysmenorrhea: | G1: 35 (39.8) | G1: 30.9 ± 23.8 | Pt selection criteria: ++
Funding: | G2: Hysterectomy (abdominal, vaginal, laparoscopically assisted vaginal, and laparoscopic) | G1: 47 (53.4) | G2: 25 (28.1) | G2: 436.1 ± 474.5 | Loss to follow-up: <10%
Netherlands Organisation for Health Research and Development and Boston Scientific Corporation | N at enrollment: | G2: 50 (56.2) | 2 fibroids: | P < 0.001 | Drop-out rates: <5%
| G1: 88 | Pressure/Pain: | G1: 13 (14.8) | Length of stay, days ± SD: | Statistical issues: ++
| G2: 89 | G1: 38 (43.1) | G2: 16 (18.0) | G1: 2.0 ± 2.1 | EXTERNAL VALIDITY: fair (1)
| N at follow-up: | G2: 39 (43.8) | 3 fibroids: | G2: 5.1 ± SD1.3 | Age: +, reported
| G1: 81 | Bladder/Bowel symptoms: | G1: 17 (19.3) | P < 0.001 | Race: +, reported
| G2: 75 | G1: 18 (20.5) | G2: 25 (25.8) | Readmissions, N: | Pregnancy history: +, reported
| Age, yrs ± SD: | G2: 25 (28.1) | >3 fibroids: | G1: 9 | Surgical history: +, reported
| G1: 44.6 ± 4.8 | Anemia: | G1: 18 (20.5) | G2: 0 | Fibroid/uterine size: +
| G2: 45.4 ± 4.2 | G1: 43 (48.9) | G2: 14 (15.7) | P = 0.0032 | Number of fibroids: +
| Race/ethnicity N (%): | G2: 42 (47.2) | Baseline dominant fibroid volume, median cm ^ 3 ^ (range): | Minor complications at surgery, complications/ patients: | Location of fibroids: -
| Black: | Other symptoms: | G1: 59 (1–673) | G1: 23/18 | Baseline characteristics: +, reported
| G1: 24 (27.3) | G1: 6 (6.8) | G2: 87 (4–1641) | G2: 26/23 | Length of follow-up: +
| G2: 20 (22.5) | G2: 11 (12.4) | Type of fibroid: | (RR = 0.72; 95% CI, 0.43–1.23) | Measurement methods: +
| White: | | NR | P = 0.23 | Measurement reliability: +
| G1: 54 (61.4) | | | Minor complications at 6 weeks, complications/ patients: | Clinical care: +
| G2: 57 (64.0) | | | G1: 68/47
| Other: | | | G2: 34/30
| G1: 10 (11.4) | | | (RR = 1.45; 95% CI, 1.04–2.02)
| G2: 12 (13.5) | | | P = 0.024
| Parity, N (%): | | | Major complications at surgery, complications/ patients:
| 0: | | | G1:1/1
| G1: 30 (34.1) | | | G2: 1/1
| G2: 20 (22.5) | | | (RR = 0.93; 95% CI, 0.06–14.54)
| ≥1: | | | P = 0.99
| G1: 58 (65.9)
| G2: 69 (77.5)
| Baseline Hgb/Hct:
| NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Mean size change, cm: | Quality:
Mehl-Madrona, 2002 | Prospective cohort | - Pre-menopausal; - Intact uterus of ≥ 6 to 8 week size with palpable fibroids; - Fibroids 2 to 3 cm in diameter | NR | G1: -0.8 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: +1.9 | INTERNAL VALIDITY: fair
US, Academic medical center | Traditional Chinese medical approach | - Fibroids growing > 6 cm/year; - Hgb < 8g/dL; - Hydronephrosis; - Taking hormonal contraceptives | NR | Size and/or rate of growth of fibroids, 6 mos, mean change in size (cm): | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Cured (gone) | Methods and blinding: NA
NR | G1: Traditional Chinese Medicine with combination of weekly acupuncture, Chinese herbs, and nutritional therapy | - Palpable fibroids; - Fibroids 2 to 3 cm in diameter | NR | G1: 3 | Pt selection criteria: +
Funding: | G2: Matched controls medically managed with any medical treatment | Pre-operative therapy: | Type of fibroid: | G2: 0 | Loss to follow-up: <10%
NR | N at enrollment: | NA | NR | Reduced size (>2cm) | Drop-out rates: <5%
| G1: 37 | Associated procedure(s): | | G1: 11 | Statistical issues: -
| G2: 37 | NA | | G2: 1 | EXTERNAL VALIDITY: poor (5)
| N at follow-up: | | | Stopped growing | Age: +, reported
| G1: 37 | | | (± 1cm) | Race: -, NR
| G2: 37 | | | G1: 8 | Pregnancy history: -, NR
| Age: | | | G2: 2 ) | Surgical history: NA
| Mode: 36 (24 to 45) | | | Decreased rate of growth (change >1cm) | Fibroid/uterine size: +
| Race/ethnicity: | | | G1: 10 (+1.1) | Number of fibroids: -
| NR | | | G2: 9 (+0.9) | Location of fibroids: -
| Parity: | | | Total improved*: | Baseline characteristics: -, NR
| NR | | | G1: 32 | Length of follow-up: +
| Baseline Hgb/Hct: | | | G2: 13 | Measurement methods: +
| NR | | | P < 0.001 | Measurement reliability: +
| | | | No change | Clinical care: +
| | | | G1: 3 (+0.9)
| | | | G2: 20 (+1.9)
| | | | Increased rate of growth (change >1cm)
| | | | G1: 2 (+9.2)
| | | | G2: 4 (+7.0)
| | | | Total unimproved:
| | | | G1: 5
| | | | G2: 24
| | | | P < 0.001
| | | | Symptom change, N:
| | | | Heavy menstrual bleeding, before treatment:
| | | | G1: 20
| | | | G2: 20
| | | | Heavy menstrual bleeding, 6 mos:
| | | | G1: 9
| | | | G2: 11
| | | | Prolonged menstrual bleeding, before treatment:
| | | | G1: 9
| | | | G2: 9
| | | | Prolonged menstrual bleeding, 6 mos:
| | | | G1: 5
| | | | G2: 5
| | | | Dysmenorrhea before treatment, N:
| | | | G1: 9
| | | | G2: 9
| | | | Dysmenorrhea, 6 mos:
| | | | G1: 5
| | | | G2: 7
| | | | Decreased exercise/activity tolerance, before treatment:
| | | | G1: 2
| | | | G2: 2
| | | | Decreased exercise/activity tolerance, before treatment:
| | | | G1: 2
| | | | G2: 2
| | | | Decreased exercise/activity tolerance, 6 mos:
| | | | G1: 1
| | | | G2: 1
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Pain medication use (days): | Quality:
Razavi et al., 2003 | Retrospective cohort | - Abdominal myomectomy; - Uterine fibroid embolization | NR | G1: 5.1 | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 8.7 | INTERNAL VALIDITY: fair
US, Academic medical center | Myomectomy and UFE | - Planned laparoscopic myomectomy within 3 mos of UFE; - Primary reason for surgery was the treatment of infertility without other symptoms | NR | P < 0.05 | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Length of stay, days: | Methods and blinding: NA
07/1998 to 12/2000 | G1: UFE | NR | NR | G1: 0 | Pt selection criteria: +
Funding: | G2: Abdominal myomectomy | Preoperative therapy: | Type of fibroid: | G2: 2.9 | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P < 0.05 | Drop-out rates: NA
| G1: 62 | Associated procedure(s): | | Complications, N (%): | Statistical issues: -
| G2: 40 | NR | | G1: 7 (11) | EXTERNAL VALIDITY: poor (9)
| N at follow-up: | | | G2: 10 (25) | Age: +, reported
| NA | | | P < 0.05 | Race: -, NR
| Age, mean yrs (range): | | | Menorrhagia relief, N (%): | Pregnancy history: -, NR
| G1: 37.7 (28 to 48) | | | G1: 48 (92) | Surgical history: -, NR
| G2: 44.2 (31 to 56) | | | G2:14 (64) | Fibroid/uterine size: -
| Race/ethnicity: | | | P < 0.05 | Number of fibroids: -
| NR | | | Pain relief, N (%): | Location of fibroids: -
| Parity: | | | G1: 25 (74) | Baseline characteristics: -, NR
| NR | | | G2: 14 (54) | Length of follow-up: NA
| Baseline uterine size: | | | P = NS | Measurement methods: +
| NR | | | Mass effect, N (%): | Measurement reliability: -
| Baseline Hct, %: | | | G1: 28 (76) | Clinical care: -
| G1: 35.5 | | | G2: 21 (91)
| G2: 36 | | | P < 0.05
| | | | Time to resume normal activities (days):
| | | | G1: 8
| | | | G2: 36
| | | | P < 0.05
| | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size, ml ± SD: | Procedure time, min: | Quality:
Spies, Cooper, Worthington-Kirsch et al., 2004 | Prospective cohort | - Age: 30 to 50 yrs; - Symptomatic fibroids | G1: 689.4 ± 466.1 | G1: 57.9 | Overall quality score: fair
Country and setting: | Intervention: | Exclusion criteria: | G2: 389.2 ± 521.2 | G2: 93.6 | INTERNAL VALIDITY: poor
US, Community and academic medical centers | UAE and hysterectomy | - Submucosal fibroids with > 50% diameter within uterine cavity; - Dominant pedunculated serosal fibroid | P < 0.001 | P < 0.001 | Random: NA
Enrollment period: | Groups: | Indications: | Number of fibroids, N (%): | At least 1 complication, N (%): | Methods and blinding: NA
NR | G1: UAE | NR | 1 fibroid: | G1: 28 (27.5%; 95% CI, 19.1–37.2) | Pt selection criteria: +
Funding: | G2: Hysterectomy | Preoperative therapy: | G1: 27 (26) | G2: 25 (50%; 95% CI, 35.5–64.5) | Loss to follow-up: >20%
Biosphere Medical Inc. | N at enrollment: | NR | G2: 20 (40) | P = 0.01 | Drop-out rates: NR
| G1: 102 | Additional procedures: | 2 fibroids: | Complications within 30 days, %: | Statistical issues: +
| G2: 50 | NR | G1: 33 (32) | G1: 17.6 | EXTERNAL VALIDITY: good
| (40 TAH, 2 LAVH, and 8 LH) | | G2: 19 (38) | G2: 28 | Age: +, reported
| N at follow-up, 12 months: | | ≥3 fibroids: | P = 0.15 | Race: +, reported
| G1: 76 | | G1: 42 (41) | Complications after 30 days, %: | Pregnancy history: +, reported
| G2: 30 | | G2: 10 (20) | G1: 12.7 | Surgical history: +, reported
| Age, yrs ± SD: | | P = 0.021 | G2: 32 | Fibroid/uterine size: +
| G1: 42.6 ± 4.0 | | Baseline dominant fibroid size (ml ± SD): | P=0.01 | Number of fibroids: +
| G2: 41.6 ± 5.3 | | G1: 146.8 ± 158.5 | Major complications, N (%): | Location of fibroids: +
| P = 0.264 | | G2: 90.6 ± 354.8 | G1: 4 (3.9) | Baseline characteristics: +, reported
| Race/ethnicity, N (%): | | P = 0.330 | G2: 6 (12) | Length of follow-up: ++
| Asian/Pacific Island: | | Type of fibroid, N (%): | P = 0.08 | Measurement methods: +
| G1: 1 (1) | | Intramural: | Life threatening Complications, N: | Measurement reliability: +
| G2: 2 (4) | | G1: 61 (60) | G1: 0 | Clinical care: +
| Black: | | G2: 32 (64) | G2: 0
| G1: 61 (60) | | P = 0.724 | Overall morbidity N (%):
| G2: 9 (18) | | Subserosal: | G1: 15 (14.7)
| Hispanic: | | G1: 19 (19) | G2: 17 (34.0)
| G1: 7 (7) | | G2: 8 (16) | P = 0.01
| G2: 8 (16) | | P = 0.823 | Hemorrhage, N (%):
| White: | | Submucosal: | G1: 0 (0)
| G1: 31 (30) | | G1: 17 (17) | G2: 4 (8)
| G2: 31 (62) | | G2: 13 (26) | P = 0.01
| Other: | | P = 0.197 | Febrile morbidity, N (%):
| G1: 2 (2) | | Transmural: | G1: 13 (12.7)
| G2: 0 (0) | | G1: 11 (11) | G2: 12 (24.0)
| P < 0.001 | | G2: 1 (2) | P = 0.10
| Parity, N (%): | | P = 0.108 | Length of stay, days:
| Nulliparous: | | Pedunculated: | G1: 0.83
| G1: 44 (43) | | G1: 2 (2) | G2: 2.3
| G2: 11 (22) | | G2: 4 (8) | P < 0.001
| Para 1: | | P=0.072 | Readmission, N (%):
| G1: 20 (20) | | | G1: 3 (2.9)
| G2: 10 (20) | | | 4 (8)
| Multiparous: | | | P = 0.22
| G1: 38 (37) | | | Satisfaction with symptom outcome:
| G2: 29 (58) | | | P = NS
| P = 0.025 | | | Mean time to return to work (days):
| Baseline Hgb, (%): | | | G1: 10.7
| <12 g/dL: | | | G2: 32.5
| G1: 59 (58) | | | P < 0.001
| G2: 19 (38) | | | Unintended surgery, N (%):
| ≥12 g/dL: | | | G1: 2 (2)
| G1: 43 (42) | | | G2: 4 (8)
| G2: 31 (63) | | | P = 0.09
| P = 0.025 | | | Modifiers:
| | | | NR
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Fever >38° C, N (%): | Quality:
Vavilis et al., 2005 | Retrospective cohort | - Undergoing abdominal myomectomy or hysterectomy | NR | G1: 17 (16.63) | Overall quality score: poor
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | G2: 14 (13.72) | INTERNAL VALIDITY: fair
Greece, Academic medical center | Abdominal myomectomy vs. abdominal hysterectomy | NR | NR | P = NS | Random: NA
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | Fever lasting > 24 hrs, N (%): | Methods and blinding: NA
01/2000 to 01/2003 | G1: Abdominal myomectomy | NR | NR | G1: 4 (3.92) | Pt selection criteria: -
Funding: | G2: Abdominal hysterectomy | Pre-operative therapy: | Type of fibroid: | G2: 5 (4.9) | Loss to follow-up: NA
NR | N at enrollment: | NR | NR | P = NS | Drop-out rates: NA
| G1: 102 | Associated procedure(s): | | Modifiers: | Statistical issues: +
| G2: 102 | NR | | NR | EXTERNAL VALIDITY: poor (6)
| N at follow-up: | | | | Age: +, reported
| NA | | | | Race: NA, not US study
| Age, yrs ± SD: | | | | Pregnancy history: -, NR
| G1: 35 ± 5.8 | | | | Surgical history: -, NR
| G2: 45 ± 3.4 | | | | Fibroid/uterine size: -
| Race/ethnicity: | | | | Number of fibroids: -
| NR | | | | Location of fibroids: -
| Parity: | | | | Baseline characteristics: -, NR
| NR | | | | Length of follow-up: NA
| Baseline Hgb/Hct: | | | | Measurement methods: +
| NR | | | | Measurement reliability: +
| | | | | Clinical care: +