# Appendix B. Sample Data Abstraction Forms

## Systematic Review of the Management of Uterine Fibroids

Abstract Review Form

First Author, Year: ___________________ Journal: ______________________

Endnote #__________ Abstractor Initials: ___ ___ ___

Primary Inclusion/Exclusion Criteria
1. Original research (Exclude editorials, commentaries, letters to editor, reviews, etc.) | Yes | No | Cannot Determine
2. Study published between February 2000 and February 2006 | Yes | No | Cannot Determine
3. Study published in English | Yes | No | Cannot Determine
4. Is this study located in a developed nation? (US, Canada, UK, Western Europe, Japan, Australia, New Zealand, Israel, Scandinavia) | Yes | No | Cannot Determine
5. Eligible Study type (Include all RCTs and cohorts with comparison); a ___RCT; b ___Cohorts with comparison; c ___Case-control; d ___Case series (N =_____); e ___Incidence/prevalence in US populations; f ___Cost of treatment in US populations | Yes | No | Cannot Determine
6. Applies to research topic (if not select one of the following reasons):; a ___Basic science; b ___Imaging/diagnostic study; c ___Not “uterine” fibroids | Yes | No | Cannot Determine

Retain for:

_____BACKGROUND/DISCUSSION

_____REVIEW OF REFERENCES

_____Other

COMMENTS:

Systematic Review of the Management of Uterine Fibroids

Full-text Review Form

First Author, Year: ___________________Journal: ______________________

Endnote #__________Abstractor Initials: ___ ___ ___

Primary Inclusion/Exclusion Criteria
1. Original research (Exclude editorials, commentaries, letters to editor, reviews, etc.) | Yes | No | Cannot Determine
2. Study published between February 2000 and February 2006 | Yes | No | Cannot Determine
3. Study published in English | Yes | No | Cannot Determine
4. Is this study located in a developed nation? (US, Canada, UK, Western Europe, Japan, Australia, New Zealand, Israel, Scandinavia) | Yes | No | Cannot Determine
5. Eligible Study type (Include all RCTs and cohorts with comparison); g ___RCT; h ___Cohorts with comparison; i ___Case-control; j ___Case series ___N ≥ 100; k ___Incidence/prevalence in US populations; l ___Cost of treatment in US populations | Yes | No | Cannot Determine
6. Addresses one or more topics in the content inventory? | Yes | | No

Content Inventory
1. _____Treatment of women with fibroids with symptoms; a ___Expectant management without intervention; b ___Medical management; c ___Uterine artery embolization; d ___Endometrial ablation (with or without myomectomy; e ___In situ destructive techniques; f ___Myomectomy (abd, lap, and hysteroscopic); g ___Hysterectomy (abd, lap, vag); h ___Complementary and alternative therapies; i ___Other Methods_____________________
2. _____Treatment of women with fibroids without symptoms for:; a ___Enhancing fertility; b ___Reducing adverse pregnancy outcomes; c ___Preventing further growth/recurrence; d ___Ruling out uterine malignancy; e ___Other _____________________
3. _____Modification of short term outcomes by:; 1 ___Age; 2 ___Race/ethnicity; 3 ___Parity; 4 ___Breastfeeding; 5 ___Contraceptive choices; 6 ___Body habitus; 7 ___Insulin resistance; 8 ___Concurrent medical conditions; 9 ___Fibroids size/number; 10 ___Uterine volume; 11 ___Other factors____________________
4. _____Modification of long term outcomes by:; 1 ___Age; 2 ___Race/ethnicity; 3 ___Parity; 4 ___Breastfeeding; 5 ___Contraceptive choices; 6 ___Body habitus; 7 ___Insulin resistance; 8 ___Concurrent medical conditions; 9 ___Fibroids size/number; 10 ___Uterine volume; 11 ___Other factors____________________

Retain for:

_____BACKGROUND/DISCUSSION

_____REVIEW OF REFERENCES

_____Other

COMMENTS:

IF ANY ITEMS IN GRAY BOX, THE ARTICLE IS EXCLUDED.

Study Description | Study Design, Interventions, and Patient Population | Inclusion/ Exclusion Criteria Other details | Fibroids Characteristics | Outcomes | Notes/Quality Rating
Author: | Design: | Inclusion criteria: | Baseline uterine size: | Outcomes: | Direct comparison:
Country and setting: | Intervention: | Exclusion criteria: | Number of fibroids: | Modifiers: | Quality:
Enrollment period: | Groups: | Indications: | Baseline fibroid size: | | INTERNAL VALIDITY
Funding: | N at enrollment: | Pre-operative therapy: | Type of fibroid: | | A. Random:
| N at followup: | Associated procedure(s): | | | B. Methods and blinding:
| Age: | | | | C. Pt selection criteria:
| Race/Ethnicity: | | | | D. Length of follow-up:
| Parity: | | | | E. Loss to follow-up:
| Baseline Hgb/Hct: | | | | F. Drop-out rates:
| | | | | G. Statistical issues:
| | | | | EXTERNAL VALIDITY
| | | | | H. Age:
| | | | | I. Race:
| | | | | J. Route of previous delivery/Pregnancy history:
| | | | | K. Surgical history:
| | | | | L. Fibroid/uterine size:
| | | | | M. Number of fibroids:
| | | | | N. Location of fibroids:
| | | | | O. Baseline characteristics:
| | | | | P. Measurement timing:
| | | | | Q. Measurement methods:
| | | | | R. Measurement reliability:
| | | | | L. Standardized measures:

Notes:

SOME POINTERS ABOUT STUDY DESIGN CLASSIFICATION

Case series, prospective - subjects (ideally consecutive patients) having the same type of procedure or treatment for fibroids are identified prior to surgery/treatment and consented to participate. Pre-and post-treatment evaluation methods tend to be specified more uniformly and in greater detail that retrospective series. At times, carefully timed and implemented evaluation plans are in place, such as every six month ultrasounds to identify fibroid recurrence, and uniform measurements such as blood draws to assess improvement of anemia are used. The components of the study and outcome follow-up are designed before the participants are enrolled. Data analysis is descriptive including the full range of potential outcome measures such as length of stay, satisfaction with care, quality of life, etc. Analysis may include construction of predictive models that seek to examine influences on the risk of outcomes, such as wound breakdown or “treatment failure”, among a group of women who have all had abdominal myomectomy or uterine artery embolization.

Case series, retrospective - investigators obtain permission to review existing clinical records in order to summarize the outcomes from a sequence (ideally consecutive patients) having the same procedure or treatment. Most often post-hoc consenting of individual participants is not required by internal review boards (unless follow-up contact is planned) and data is limited by the availability, quality, and uniformity of record keeping methods used. Some measure such as operative time or transfusion are likely to be of good quality, others such as peri-operative complications or recurrence of fibroids based on office records of follow-up visits are likely to be of lower quality. Follow-up of the members of a case series identified from medical records or databases using methods such as surveys should still be counted as “retrospective” if the design of the study and future data collection were not established prior to the time of the treatment or surgery under study. Such follow-up can achieve very high quality but the case series is still classified as retrospective for classification. As for retrospective case series, analysis is descriptive.

Cohort, prospective - subjects having more than one type of procedure or treatment are identified prior to the surgery/treatment and consented to participate for the purpose of making comparisons of the outcomes of treatment. The prior evidence review inconsistently called such studies “prospective cohorts” or “cohorts with comparisons”. For the purpose of this review, we will term studies with more than one “exposure” group prospective cohorts to distinguish them from case series as described above. Analysis is focused on estimating the risk or odds of the outcome(s) based on the participants' exposure (treatment group status).

Randomized clinical trials - are special instances of prospective cohorts in which the “exposure” or treatment group is assigned by chance through use of an allocation method.

Cohort, retrospective - subjects having more than one type of procedure or treatment (i.e. more than one “exposure”) are identified after having had surgery or intervention. Most often consenting of individual participants is not required by internal review boards (unless follow-up contact is planned) and data is limited by the availability, quality, and uniformity of record keeping methods used. Data limitations are similar to those described above for retrospective case series. Likewise even studies that have some component of follow-up should be classified as retrospective if the intent to follow-up the cohort in the fashion done for the research being reviewed was not designed and future data collection planned prior to the time of the treatment or surgery under study. Analysis estimates the risk or odds of the outcome(s) based on the participants' exposure (treatment group status).

Case-control studies - cases are identified based on the outcome under study, for instance women who required transfusion for fibroid related bleeding, or who had a miscarriage. A control, comparison population is identified that is intended to be a representative sample of similar women. In order to assure similar characteristics overall with respect to covariates not being studied, matching is often used, such as matching on age or race to assure a similar distribution of these potential confounders. Analysis is technically estimating the odds of having had a particular exposure or characteristic given known presence or absence of the outcome.