# Appendix A. Exact Search Strings

## Search Strategy

Medline Focused Search 1: January 2006

#7 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata | 13470
#8 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Field: All Fields, Limits: Publication Date from 2000, English, Humans | 2362
#15 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Field: All Fields, Limits: Publication Date from 2000, English, Editorial, Humans | 12
#16 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Field: All Fields, Limits: Publication Date from 2000, English, Letter, Humans | 127
#17 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Field: All Fields, Limits: Publication Date from 2000, English, Practice Guideline, Humans | 11
#18 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Field: All Fields, Limits: Publication Date from 2000, English, Review, Humans | 356
#19 | Search #15 OR #16 OR #17 OR #18 Limits: Publication Date from 2000, English, Humans | 500
#20 | Search #8 NOT #19 Limits: Publication Date from 2000, English, Humans | 1861

Medline Focused Search 2: February 2006

#4 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata | 13539
#5 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata Field: All Fields, Limits: 60 Days, English, Humans | 10*

Unduplicated in previous searches

Medline Focused Search 3: May 2006

#2 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata | 13690
#3 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata Limits: added to PubMed in the last 1 year, English, Humans | 304
#4 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata Limits: added to PubMed in the last 1 year, English, Editorial, Letter, Practice Guideline, Review, Humans | 63
#5 | Search #3 NOT #4 | 98*

* Unduplicated from previous searches

Medline Focused Search 4: August 2006

#1 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata | 13811
#2 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Limits: added to PubMed in the last 1 year, English, Publication Date from 2000/02 to 2006/02, Humans | 222
#3 | Search “Leiomyoma”[MeSH]OR fibroid* OR leiomyomata Limits: added to PubMed in the last 1 year, English, Publication Date from 2000/02 to 2006/02, Editorial, Letter, Practice Guideline, Review, Humans | 47
#4 | Search #2 NOT #3 | 175
#5 | Search #2 NOT #3 Limits: added to PubMed in the last 180 days | 10*

* Unduplicated in previous searches

Medline Focused Search 5: September 2006

#1 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata | 13887
#2 | Search “Leiomyoma”[MeSH] OR fibroid* OR leiomyomata Limits: added to PubMed in the last 90 days, English, Publication Date from 2000/02 to 2006/02, Humans | 4*

Cochrane

Leiomyoma OR Fibroid* = 3

* Unduplicated in previous searches

EMBASE

Leiomyoma OR Fibroid* = 52

* Unduplicated in previous searches