# List of Acronyms and Abbreviations

[underlined: Abbreviation] | [underlined: Description]
Adj | Adjusted
AHRQ | Agency for Healthcare Research and Quality
ALL | Acute Lymphocytic Leukemia
AML | Acute myeloid leukemia
AOM | Acute Otitis Media
Bayley MDI | Bayley Mental Development Index
BF | Breastfeeding
BMC_arm_ | Forearm bone mineral content
BMD_spine_ | Lumbar spine bone mineral density
BMI | Body mass index
BW | Birth weight
CDC | Centers for Disease Control and Prevention
CES-D | Center for Epidemiological Studies Depression Scale
CI | Confidence interval
C-section | Delivery by cesarean section
CVD | Cardiovascular disease
DBP | Diastolic blood pressure
DIS | Diagnostic Interview Schedule
DM | Donor milk
DSM IV | Diagnostic Statistical Manual
Dx | Diagnosis
EPDS | Edinburgh Postnatal Depression Scale
Exclu | Exclusive
FH | Family history
GA | Gestational age
GDM | Gestational diabetes
H | Hospital or clinic controls
Hosp | Hospitalization
HRT | Hormone replacement therapy
Ht | Height
IHD | Ischemic heart disease
IOM | Institute of Medicine
IQ | Intelligence quotient
LDL | Low-density lipoprotein
LRTI | Lower respiratory track infection
LTC | Long-term recalls
MA | Meta-analysis
MANCOVA | Multivariate analysis of variance
MDI | Bayley Mental Development Index
MM | Exclusive mother's milk
Mo | Months
NA | Not applicable
ND | No data/not documented
NEC | Necrotizing Entercolitis
NLSY79 | National longitudinal survey of youth 1979
NS | Non-significant
OC | Ovarian cancer
OGTT | Oral glucose tolerance test
OR | Odds Ratio
P | Population controls
PA | Physical activity
PIAT | Peabody individual achievement test
PIAR | Poverty index ratio
PPVT-R | Peabody Picture Vocabulary Test
ROM | Recurrent Otitis Media
PF | Preterm formula
RDC | Research Diagnostic Criteria
RR | Relative risk
RTI | Respiratory infection
SBP | Systolic blood pressure
SDS | Standard deviation score
SE | Standard error
SES | Socioeconomic status
SR | Systematic review
SUDAAN | Software adjusted sample
TEP | Technical Expert Panel
Vit D suppl | Vitamin D supplementation
WISC-R | Weschler Intelligence Scale for Children
wk | Week
WPPSI-R | Wechsler Preschool and Primary Scales of Intelligence
Wt | Weight
Yr | Year