# Bibliography

Asthma prevalence in: Health, United States, 2005 With Chartbook on Trends in the Health of Americans. Centers for Disease Control, National Center for Health Statistics Web site. Available at: http://www.cdc.gov/nchs/data/hus/hus05.pdf. Last accessed on March 6, 2007.
Diabetes in Youth. National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention. Web site. Available at: http://www.cdc.gov/diabetes/pubs/factsheets/search.htm. Last accessed on March 6, 2006.
Healthy People 2010 - Breastfeeding Practices. Results from the 2005 National Immunization Survey. Available at: http://www.cdc.gov/breastfeeding/data/NIS_data/data_2005.htm. Last accessed on March 6, 2007.
HHS Blueprint for Action on Breastfeeding.U.S. Department of Health and Human Services, Office of Women's Health Womenshealth.gov.Web site. Available at: http://www.womenshealth.gov/Breastfeeding/bluprntbk2.pdf. Last accessed on March 7, 2007
Mortality Data. National Center for Health Statistics Web site: Available at: http://www.cdc.gov/nchs/deaths.htm. Last accessed March 6, 2007.
National Immunization Survey, 2005. Centers for Disease Control and Prevention Web site. Available at: http://www.cdc.gov/breastfeeding/data/NIS_data/data_2005.htm. Last accessed on March 6, 2007.
Prevalence of Overweight among Children and Adolescents: United States, 1999-2002. National Center ofr Health Statistics, Centers for Disease Control and Prevention Web site. Available at: http://www.cdc.gov/nchs/products/pubs/pubd/hestats/overwght99.htm. Last accessed on March 6, 2007.
WIC Program Guide to WIC Women, Infants, and Children Program. Available at: http://www.wicprogram.org/. Last accessed on March 6, 2007.
World Bank Data & Statistics Page. World Bank Web site. Available at: http://web.worldbank.org/WBSITE/EXTERNAL/DATASTATISTICS/0,,contentMDK:20421402~pagePK:64133150~piPK:64133175~theSitePK:239419,00.html#High_income. Last accessed on March 6, 2007.
Effect of breastfeeding on infant and child mortality due to infectious diseases in less developed countries: a pooled analysis. WHO Collaborative Study Team on the Role of Breastfeeding on the Prevention of Infant Mortality.[see comment][erratum appears in Lancet 2000 Mar 25;355(9209):1104]. Lancet 2000 Feb 5;355(9202):451–5.
American Cancer Society. Cancer Facts and Figures 2006. 2006a. Atlanta, GA, American Cancer Society, 2006.
Eliminate Disparities in Infant Mortality. 2006d. Office of Minority Health:Centers for Disease Control and Prevention.
Sudden, Unexplained Infant Death Initiative (SUIDI): Overview. 2006e. Department for Health and Human Services-Centers for Disease Control and Prevention.
Affinito P, Tommaselli GA, di Carlo C, et al. Changes in bone mineral density and calcium metabolism in breastfeeding women: a one year follow-up study. J Clin Endocrinol Metab. Jun. 1996;81(6):2314-8. [pmid: 8964870].
Agostoni C. Ghrelin, leptin and the neurometabolic axis of breastfed and formula-fed infants. Acta Paediatr. May. 2005;94(5):523-5. [pmid: 16188736].
Agostoni C, Marangoni F, Giovannini M, et al. Prolonged breastfeeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol. 2001;501:137-41. [pmid: 11787675].
Alderman BW, Weiss NS, Daling JR, et al. Reproductive history and postmenopausal risk of hip and forearm fracture. Am J Epidemiol. Aug. 1986;124(2):262-7. [pmid: 3728442].
Alho OP, Laara, Oja H. How should relative risk estimates for acute otitis media in children aged less than 2 years be perceived?. J Clin Epidemiol. Jan. 1996;49(1):9-14. [pmid: 8598517].
Alho OP, Laara E, Oja H. Public health impact of various risk factors for acute otitis media in northern Finland. Am J Epidemiol. Jun 1. 1996;143(11):1149-56. [pmid: 8633605].
Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. Apr 17. 2001;134(8):663-94. [pmid: 11304107].
American Academy of Pediatrics Committee on Nutrition. Pediatric Nutrition Handbook. Kleinman, R. E. Fifth. 2004.
Anderson JW, Johnstone BM, Remley DT. Breastfeeding and cognitive development: a meta-analysis. Am J Clin Nutr. Oct. 1999;70(4):525-35. [pmid: 10500022].
Angelsen NK, Vik T, Jacobsen G, et al. Breast feeding and cognitive development at age 1 and 5 years. Arch Dis Child. Sep. 2001;85(3):183-8. [pmid: 11517096]. [pmcid: 1718901].
Arenz S, Ruckerl R, Koletzko B, et al. Breast-feeding and childhood obesity—a systematic review. [Review] [51 refs]. Int J Obes Relat Metab Disord: Journal of the International Association for the Study of Obesity. Oct. 2004;28(10):1247-56.
Auinger P, Lanphear BP, Kalkwarf HJ, et al. Trends in otitis media among children in the United States. Pediatrics. Sep. 2003;112(3 Pt 1):514-20. [pmid: 12949276].
Bachrach VR, Schwarz E, Bachrach LR. Breastfeeding and the risk of hospitalization for respiratory disease in infancy: a meta-analysis. Arch Pediatr Adolesc Med. Mar. 2003;157(3):237-43. [pmid: 12622672].
Bauchner H, Leventhal JM, Shapiro ED. Studies of breastfeeding and infections. How good is the evidence?. JAMA. Aug 15. 1986;256(7):887-92. [pmid: 3090286].
Beral VaUCCSI. Breastfeeding and childhood cancer. Br J Cancer 2001 Nov 30;85(11):1685–94.
Bernier MO, PluBureau G, Bossard N, et al. Breastfeeding and risk of breast cancer: a metaanalysis of published studies. Hum Reprod Update. Jul. 2000;6(4):374-86. [pmid: 10972524].
Bier JA, Oliver T, Ferguson AE, et al. Human milk improves cognitive and motor development of premature infants during infancy. J Hum Lact. Nov. 2002;18(4):361-7. [pmid: 12449052].
Bland RM, Rollins NC, Solarsh G, et al. Maternal recall of exclusive breast feeding duration. Arch Dis Child. Sep. 2003;88(9):778-83. [pmid: 12937095]. [pmcid: 1719625].
Bluestone, CD and Klein, JO. Otitis media in infants and children. 2nd edition. 1995. WB Saunders.
Braun-Fahrlander C, Riedler J, Herz U, et al. Environmental exposure to endotoxin and its relation to asthma in school-age children. N Engl J Med. Sep 19. 2002;347(12):869-77. [pmid: 12239255].
Brewer MM, Bates MR, Vannoy LP. Postpartum changes in maternal weight and body fat depots in lactating vs nonlactating women. Am J Clin Nutr. Feb. 1989;49(2):259-65. [pmid: 2916446].
Brooke H, Gibson A, Tappin D, et al. Case-control study of sudden infant death syndrome in Scotland, 1992-5.[see comment]. BMJ. May 24. 1997;314(7093):1516-20. [pmid: 9169398]. [pmcid: 2126747].
Burgess SW, Dakin CJ, O'Callaghan MJ. Breastfeeding does not increase the risk of asthma at 14 years. Pediatrics. Apr. 2006;117(4):e787-e792. [pmid: 16510659].
Butte NF, Hopkinson JM. Body composition changes during lactation are highly variable among women. [Review][45 refs]. J Nutr 1998 Feb;128(2:Suppl):Suppl-385S.
Chan HH, Lau EM, Woo J, et al. Dietary calcium intake, physical activity and the risk of vertebral fracture in Chinese. Osteoporos Int. 1996;6(3):228-32. [pmid: 8783297].
Chaudron LH, Klein MH, Remington P, et al. Predictors, prodromes and incidence of postpartum depression. J Psychosom Obstet Gynecol 2001 Juna;22(2):103–12.
Chen A, Rogan WJ. Breastfeeding and the risk of postneonatal death in the United States. Pediatrics 2004 Maya;113(5):e435-e439.
Chiaffarino F, Pelucchi C, Negri E, et al. Breastfeeding and the risk of epithelial ovarian cancer in an Italian population. Gynecol Oncol. Aug. 2005;98(2):304-8. [pmid: 15975644].
Chien PF, Howie PW. Breast milk and the risk of opportunistic infection in infancy in industrialized and non-industrialized settings. [Review] [75 refs]. Adv Nutr Res. 2001;10:69-104. [pmid: 11795054].
Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
Chua S, Arulkumaran S, Lim I, et al. Influence of breastfeeding and nipple stimulation on postpartum uterine activity. Br J Obstet Gynaecol. Sep. 1994;101(9):804-5. [pmid: 7947531].
Collaborative Group on Hormonal Factors in Breast Cancer. Breast cancer and breastfeeding: collaborative reanalysis of individual data from 47 epidemiological studies in 30 countries, including 50302 women with breast cancer and 96973 women without the disease.[see comment][comment]. [Review][68 refs] Lancet 2002 Jul 20;360(9328):187–95.
Cooper PJ, Murray L, Stein A. Psychosocial factors associated with the early termination of breast-feeding. J Psychosom Res. 1993;37(2):171-6. [pmid: 8463993].
Cramer DW, Hutchison GB, Welch WR, et al. Determinants of ovarian cancer risk. I. Reproductive experiences and family history. J Natl Cancer Inst. Oct. 1983;71(4):711-6. [pmid: 6578366].
Cumming RG, Klineberg RJ. Breastfeeding and other reproductive factors and the risk of hip fractures in elderly women.[erratum appears in Int J Epidemiol 1993 Oct;22(5):962]. Int J Epidemiol. Aug. 1993;22(4):684-91. [pmid: 8225744].
Davis MK. Review of the evidence for an association between infant feeding and childhood cancer. Int J Cancer - Suppl. 1998;11:29-33. [pmid: 9876474].
Demmelmair H, von RJ, Koletzko B. Long-term consequences of early nutrition. [Review] [67 refs]. Early Hum Dev. Aug. 2006;82(8):567-74. [pmid: 16887299].
Der G, Batty D, Deary IJ. Effect of breast feeding on intelligence in children: prospective study, sibling pairs analysis, and meta-analysis. BMJ 2006 Oct 4c.
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
Dewey KG. Growth characteristics of breast-fed compared to formula-fed infants. Biol Neonate. 1998;74(2):94-105. [pmid: 9691152].
Dewey KG. Impact of breastfeeding on maternal nutritional status. [Review] [26 refs]. Adv Exp Med Biol. 2004;554:91-100. [pmid: 15384569].
Dewey KG, Heinig MJ, Nommsen LA. Maternal weight-loss patterns during prolonged lactation. Am J Clin Nutr. Aug. 1993;58(2):162-6. [pmid: 8338042].
Dezoete JA, MacArthur BA, Tuck B. Prediction of Bayley and Stanford-Binet scores with a group of very low birthweight children. Child Care Health Dev. Sep. 2003;29(5):367-72. [pmid: 12904244].
Dockerty JD, Skegg DC, Elwood JM, et al. Infections, vaccinations, and the risk of childhood leukaemia. Br J Cancer. Jul. 1999;80(9):1483-9. [pmid: 10424755].
Drane DL, Logemann JA. A critical evaluation of the evidence on the association between type of infant feeding and cognitive development. Paediatr Perinat Epidemiol. Oct. 2000;14(4):349-56. [pmid: 11101022].
Duffy LC, Faden H, Wasielewski R, et al. Exclusive breastfeeding protects against bacterial colonization and day care exposure to otitis media. Pediatrics. Oct. 1997;100(4):E7. [pmid: 9310540].
Duncan B, Ey J, Holberg CJ, et al. Exclusive breastfeeding for at least 4 months protects against otitis media.[see comment]. Pediatrics. May. 1993;91(5):867-72. [pmid: 8474804].
Eder W, Ege MJ, von ME. The asthma epidemic. N Engl J Med. Nov 23. 2006;355(21):2226-35. [pmid: 17124020].
Eidelman AI, Feldman R. Positive effect of human milk on neurobehavioral and cognitive development of premature infants. Adv Exp Med Biol. 2004;554:359-64. [pmid: 15384601].
Elgen I, Sommerfelt K, Ellertsen B. Cognitive performance in a low birth weight cohort at 5 and 11 years of age. Pediatr Neurol. Aug. 2003;29(2):111-6. [pmid: 14580653].
EPSTEIN MA, ACHONG BG, Barry YM. VIirus particles in cultured lymphoblastks from Burkitt's lymphoma. Lancet. Mar 28. 1964;15:702-3. [pmid: 14107961].
EURODIAS S. Rapid early growth is associated with increased risk of childhood type 1 diabetes in various European populations. Diabetes Care. Oct. 2002;25(10):1755-60. [pmid: 12351473].
Evenhouse E, Reilly S. Improved estimates of the benefits of breastfeeding using sibling comparisons to reduce selection bias. Health Serv Res. Dec. 2005;40(6 Pt 1):1781-802. [pmid: 16336548]. [pmcid: 1361236].
Feachem RG, Koblinsky MA. Interventions for the control of diarrhoeal diseases among young children: promotion of breast-feeding 10045. Bull World Health Organ 1984;62(2):271–91.
Feldman R, Eidelman AI. Direct and indirect effects of breast milk on the neurobehavioral and cognitive development of premature infants. Dev Psychobiol. Sep. 2003;43(2):109-19. [pmid: 12918090].
Findeisen M, Vennemann M, Brinkmann B, et al. German study on sudden infant death (GeSID): design, epidemiological and pathological profile. Int J Legal Med. Jun. 2004;118(3):163-9. [pmid: 15042379].
Fleming PJ, Blair PS, Bacon C, et al. Environment of infants during sleep and risk of the sudden infant death syndrome: results of 1993-5 case-control study for confidential inquiry into stillbirths and deaths in infancy. Confidential Enquiry into Stillbirths and Deaths Regional Coordinators and Researchers.[see comment]. BMJ. Jul 27. 1996;313(7051):191-5. [pmid: 8696193]. [pmcid: 2351639].
Forste R, Weiss J, Lippincott E. The decision to breastfeed in the United States: does race matter?[see comment]. Pediatrics. Aug. 2001;108(2):291-6. [pmid: 11483790].
Fraser AB, Grimes DA. Effect of lactation on maternal body weight: a systematic review. [Review] [57 refs]. Obstet Gynecol Survey. Apr. 2003;58(4):265-9.
Furman L, Taylor G, Minich N, et al. The effect of maternal milk on neonatal morbidity of very low-birth-weight infants. Arch Pediatr Adolesc Med. Jan. 2003;157(1):66-71. [pmid: 12517197].
Gammon MD, Neugut AI, Santella RM, et al. The Long Island Breast Cancer Study Project: description of a multiinstitutional collaboration to identify environmental risk factors for breast cancer. Breast Cancer Res Treat. Jun. 2002;74(3):235-54. [pmid: 12206514].
Gartner LM, Morton J, Lawrence RA, et al. Breastfeeding and the use of human milk. Pediatrics. Feb. 2005;115(2):496-506. [pmid: 15687461].
Gdalevich M, Mimouni D, David M, et al. Breast-feeding and the onset of atopic dermatitis in childhood: a systematic review and meta-analysis of prospective studies. J Am Acad Dermatol. Oct. 2001;45(4):520-7. [pmid: 11568741].
Gdalevich M, Mimouni D, Mimouni M. Breast-feeding and the risk of bronchial asthma in childhood: a systematic review with meta-analysis of prospective studies. J Pediatr. Aug. 2001;139(2):261-6. [pmid: 11487754].
Gerstein HC. Cow's milk exposure and type I diabetes mellitus. A critical overview of the clinical literature. Diabetes Care. Jan. 1994;17(1):13-9. [pmid: 8112184].
Gillman MW, Rifas-Shiman SL, Camargo CA Jr, et al. Risk of overweight among adolescents who were breastfed as infants. JAMA. May 16. 2001;285(19):2461-7. [pmid: 11368698].
Gomez-Sanchiz M, Canete R, Rodero I, et al. Influence of breast-feeding on mental and psychomotor development. Clin Pediatr. Jan. 2003;42(1):35-42.
Gomez-Sanchiz M, Canete R, Rodero I, et al. Influence of breast-feeding and parental intelligence on cognitive development in the 24-month-old child. Clin Pediatr. Oct. 2004;43(8):753-61.
Greaves MF. Speculations on the cause of childhood acute lymphoblastic leukemia. Leukemia. Feb. 1988;2(2):120-5. [pmid: 3278171].
Greene GW, Smiciklas-Wright H, Scholl TO, et al. Postpartum weight change: how much of the weight gained in pregnancy will be lost after delivery?. Obstet Gynecol. May. 1988;71(5):701-7. [pmid: 3357658].
Greggi S, Parazzini F, Paratore MP, et al. Risk factors for ovarian cancer in central Italy. Gynecol Oncol. Oct. 2000;79(1):50-4. [pmid: 11006030].
Gross SJ. Growth and biochemical response of preterm infants fed human milk or modified infant formula. N Engl J Med. Feb 3. 1983;308(5):237-41. [pmid: 6848932].
Grummer-Strawn LM, Mei Z. Does breastfeeding protect against pediatric overweight? Analysis of longitudinal data from the Centers for Disease Control and Prevention Pediatric Nutrition Surveillance System. Pediatrics. Feb. 2004;113(2):e81-e86. [pmid: 14754976].
Guise JM, Austin D, Morris CD. Review of case-control studies related to breastfeeding and reduced risk of childhood leukemia. Pediatrics. Nov. 2005;116(5):e724-e731. [pmid: 16263987].
Gwinn ML, Lee NC, Rhodes PH, et al. Pregnancy, breastfeeding, and oral contraceptives and the risk of epithelial ovarian cancer. J Clin Epidemiol. 1990;43(6):559-68. [pmid: 2348208].
Hack M, Taylor HG, Drotar D, et al. Poor predictive validity of the Bayley Scales of Infant Development for cognitive function of extremely low birth weight children at school age. Pediatrics. Aug. 2005;116(2):333-41. [pmid: 16061586].
Haiek LN, Kramer MS, Ciampi A, et al. Postpartum weight loss and infant feeding. J Am Board Fam Pract. Mar. 2001;14(2):85-94. [pmid: 11314929].
Hannah P, Adams D, Lee A, et al. Links between early post-partum mood and post-natal depression. Br J Psychiatry. Jun. 1992;160:777-80. [pmid: 1617360].
Hansen MA, Overgaard K, Riis BJ, et al. Potential risk factors for development of postmenopausal osteoporosis—examined over a 12-year period. Osteoporos Int. Feb. 1991;1(2):95-102. [pmid: 1790399].
Harder T, Bergmann R, Kallischnigg G, et al. Duration of breastfeeding and risk of overweight: a meta-analysis. Am J Epidemiol. Sep 1. 2005;162(5):397-403. [pmid: 16076830].
Hartge P, Schiffman MH, Hoover R, et al. A case-control study of epithelial ovarian cancer. Am J Obstet Gynecol. Jul. 1989;161(1):10-6. [pmid: 2750791].
Hauck FR, Herman SM, Donovan M, et al. Sleep environment and the risk of sudden infant death syndrome in an urban population: the Chicago Infant Mortality Study. Pediatrics. May. 2003;111(5 Part 2):1207-14. [pmid: 12728140].
Henderson JJ, Evans SF, Straton JA, et al. Impact of postnatal depression on breastfeeding duration.[erratum appears in Birth. 2004 Mar;31(1):76]. Birth. Sep. 2003;30(3):175-80. [pmid: 12911800].
Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep 6. 2003;327(7414):557-60. [pmid: 12958120]. [pmcid: 192859].
Higgins JP, Whitehead A, Turner RM, et al. Meta-analysis of continuous outcome data from individual patients. Stat Med. Aug 15. 2001;20(15):2219-41. [pmid: 11468761].
Hoffman S, Grisso JA, Kelsey JL, et al. Parity, lactation and hip fracture. Osteoporos Int. Jul. 1993;3(4):171-6. [pmid: 8338971].
Horwood LJ, Darlow BA, Mogridge N. Breast milk feeding and cognitive ability at 7–8 years. Arch Dis Child Fetal Neonat Ed. Jan. 2001;84(1):F23-F27.
Howie PW, Forsyth JS, Ogston SA, et al. Protective effect of breast feeding against infection. BMJ. Jan 6. 1990;300(6716):11-6. [pmid: 2105113]. [pmcid: 1661904].
Imhoff B, Morse D, Shiferaw B, et al. Burden of self-reported acute diarrheal illness in FoodNet surveillance areas, 1998-1999. Clin Infect Dis. Apr 15. 2004;38(Suppl 3):S219-S226. [pmid: 15095193].
Jain A, Concato J, Leventhal JM. How good is the evidence linking breastfeeding and intelligence?. Pediatrics. Jun. 2002;109(6):1044-53. [pmid: 12042541].
Janney CA, Zhang D, Sowers M. Lactation and weight retention. Am J Clin Nutr. Nov. 1997;66(5):1116-24. [pmid: 9356528].
Jernstrom H, Lubinski J, Lynch HT, et al. Breast-feeding and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. J Natl Cancer Inst. Jul 21. 2004;96(14):1094-8. [pmid: 15265971].
John EM, Whittemore AS, Harris R, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of seven U.S. case-control studies. Epithelial ovarian cancer in black women. Collaborative Ovarian Cancer Group. J Natl Cancer Inst. Jan. 1993;85(2):142-7. [pmid: 8418303].
Johnson DL, Swank PR, Howie VM, et al. Breast feeding and children's intelligence. Psychol Rep. Dec. 1996;79(3 Part 2):1179-85. [pmid: 9009764].
Jones ME, Swerdlow AJ, Gill LE, et al. Pre-natal and early life risk factors for childhood onset diabetes mellitus: a record linkage study. Int J Epidemiol. Jun. 1998;27(3):444-9. [pmid: 9698133].
Karjalainen J, Martin JM, Knip M, et al. A bovine albumin peptide as a possible trigger of insulin-dependent diabetes mellitus. N Engl J Med. Jul 30. 1992;327(5):302-7. [pmid: 1377788].
Keppel KG, Taffel SM. Pregnancy-related weight gain and retention: implications of the 1990 Institute of Medicine guidelines.[see comment]. Am J Public Health. Aug. 1993;83(8):1100-3. [pmid: 8342716]. [pmcid: 1695171].
Kjos SL, Henry O, Lee RM, et al. The effect of lactation on glucose and lipid metabolism in women with recent gestational diabetes. Obstet Gynecol. Sep. 1993;82(3):451-5. [pmid: 8355952].
Kjos SL, Peters RK, Xiang A, et al. Contraception and the risk of type 2 diabetes mellitus in Latina women with prior gestational diabetes mellitus. JAMA. Aug 12. 1998;280(6):533-8. [pmid: 9707143].
Kleinman R. Towards a “new beginning”: dietary fat restrictions in infancy?. Acta Paediatrica. Jan. 2000;89(1):2-4. [pmid: 10677046].
Kovacs CS, Kronenberg HM. Maternal-Fetal Calcium and Bone Metabolism During Pregnancy, Puerperium, and Lactation. Endocr Rev. Dec 1. 1997;18(6):832-72. [pmid: 9408745].
Kramer MS. Does breast feeding help protect against atopic disease? Biology, methodology, and a golden jubilee of controversy. J Pediatr. Feb. 1988;112(2):181-90. [pmid: 3339499].
Kramer MS, Chalmers B, Hodnett ED, et al. Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus. JAMA. Jan 24. 2001;285(4):413-20. [pmid: 11242425].
Kramer MS, Kakuma R. The optimal duration of exclusive breastfeeding: a systematic review. Adv Exp Med Biol. 2004;554:63-77. [pmid: 15384567].
Kreiger N, Kelsey JL, Holford TR, et al. An epidemiologic study of hip fracture in postmenopausal women. Am J Epidemiol. Jul. 1982;116(1):141-8. [pmid: 7102649].
Kull I, Almqvist C, Lilja G, et al. Breast-feeding reduces the risk of asthma during the first 4 years of life.[see comment]. J Allergy Clin Immunol 114(4):755–60, 2004 Oct;114(4):755–60.
Kwan ML, Buffler PA, Abrams B, et al. Breastfeeding and the risk of childhood leukemia: a meta-analysis. Public Health Rep. Nov. 2004;119(6):521-35. [pmid: 15504444]. [pmcid: 1497668].
Lawlor DA, Najman JM, Batty GD, et al. Early life predictors of childhood intelligence: findings from the Mater-University study of pregnancy and its outcomes. Paediatr Perinat Epidemiol. Mar. 2006;20(2):148-62. [pmid: 16466433].
Lee SY, Kim MT, Kim SW, et al. Effect of lifetime lactation on breast cancer risk: a Korean women's cohort study. Int J Cancer. Jun 20. 2003;105(3):390-3. [pmid: 12704674].
Li R, Darling N, Maurice E, et al. Breastfeeding rates in the United States by characteristics of the child, mother, or family: the 2002 National Immunization Survey. Pediatrics. Jan. 2005;115(1):e31-e37. [pmid: 15579667].
Lindsay RS, Hanson RL, Bennett PH, et al. Secular trends in birth weight, BMI, and diabetes in the offspring of diabetic mothers. Diabetes Care. Sep 1. 2000;23(9):1249-54. [pmid: 10977014].
Linne Y, Dye L, Barkeling B, et al. Weight development over time in parous women—the SPAWN study—15 years follow-up. Int J Obes Relat Metab Disord. Dec. 2003;27(12):1516-22. [pmid: 14634683].
Lipworth L, Bailey LR, Trichopoulos D. History of breastfeeding in relation to breast cancer risk: a review of the epidemiologic literature.[see comment]. [Review] [43 refs]. J Natl Cancer Inst. Feb 16. 2000;92(4):302-12. [pmid: 10675379].
Llanos AR, Moss ME, Pinzon MC, et al. Epidemiology of neonatal necrotising enterocolitis: a population-based study. Paediatr Perinat Epidemiol. Oct. 2002;16(4):342-9. [pmid: 12445151].
Lopez JM, Gonzalez G, Reyes V, et al. Bone turnover and density in healthy women during breastfeeding and after weaning. Osteoporos Int. 1996;6(2):153-9. [pmid: 8704355].
Lowe LP, Greenland P, Ruth KJ, et al. Impact of major cardiovascular disease risk factors, particularly in combination, on 22-year mortality in women and men. Arch Intern Med. Oct 12. 1998;158(18):2007-14. [pmid: 9778200].
Lucas A, Cole TJ. Breast milk and neonatal necrotising enterocolitis. Lancet. Dec 22. 1990;336(8730):1519-23. [pmid: 1979363].
Lucas A, Gore SM, Cole TJ, et al. Multicentre trial on feeding low birthweight infants: effects of diet on early growth. Arch Dis Child. Aug. 1984;59(8):722-30. [pmid: 6476868]. [pmcid: 1628628].
Martin RM, Davey SG, Mangtani P, et al. Breastfeeding and cardiovascular mortality: the Boyd Orr cohort and a systematic review with meta-analysis. [Review] [25 refs]. Eur Heart J. May. 2004;25(9):778-86. [pmid: 15120889].
Martin RM, Gunnell D, Smith GD. Breastfeeding in infancy and blood pressure in later life: systematic review and meta-analysis. Am J Epidemiol. Jan 1. 2005;161(1):15-26. [pmid: 15615909].
Matsumoto I, Kosha S, Noguchi S, et al. Changes of bone mineral density in pregnant and postpartum women. J Obstet Gynaecol. Oct. 1995;21(5):419-25. [pmid: 8542463].
Matsushita H, Kurabayashi T, Tomita M, et al. The effect of multiple pregnancies on lumbar bone mineral density in Japanese women. Calcif Tissue Int. Jul. 2002;71(1):10-3. [pmid: 12200655].
McGuire W, Anthony MY. Formula milk versus term human milk for feeding preterm or low birth weight infants. Cochrane Database Syst Rev 2001;(4):CD002971.
McKinney PA, Parslow R, Gurney KA, et al. Perinatal and neonatal determinants of childhood type 1 diabetes. A case-control study in Yorkshire, U.K. Diabetes Care. Jun. 1999;22(6):928-32. [pmid: 10372244].
McManus RM, Cunningham I, Watson A, et al. Beta-cell function and visceral fat in lactating women with a history of gestational diabetes. Metabolism. Jun. 2001;50(6):715-9. [pmid: 11398150].
McVea KL, Turner PD, Peppler DK. The role of breastfeeding in sudden infant death syndrome. J Hum Lact. Feb. 2000;16(1):13-20. [pmid: 11138219].
Meloni T, Marinaro AM, Mannazzu MC, et al. IDDM and early infant feeding. Sardinian case-control study. Diabetes Care 1997;(3):340–2.
Michaelsson K, Baron JA, Farahmand BY, et al. Influence of parity and lactation on hip fracture risk. Am J Epidemiol. Jun 15. 2001;153(12):1166-72. [pmid: 11415951].
Mitchell EA, Taylor BJ, Ford RP, et al. Four modifiable and other major risk factors for cot death: the New Zealand study.[see comment]. J Paediatr Child Health 1992;28:Suppl-8.
Mitchell EA, Tuohy PG, Brunt JM, et al. Risk factors for sudden infant death syndrome following the prevention campaign in New Zealand: a prospective study. Pediatrics. Nov. 1997;100(5):835-40. [pmid: 9346984].
Modugno F, Moslehi R, Ness RB, et al. Reproductive factors and ovarian cancer risk in Jewish BRCA1 and BRCA2 mutation carriers (United States). Cancer Causes Control. Jun. 2003;14(5):439-46. [pmid: 12946038].
Modugno F, Ness RB, Wheeler JE. Reproductive risk factors for epithelial ovarian cancer according to histologic type and invasiveness. Ann Epidemiol. Nov. 2001;11(8):568-74. [pmid: 11709277].
Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. Nov 27. 1999;354(9193):1896-900. [pmid: 10584742].
Moher D, Schulz KF, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. Apr 18. 2001;285(15):1987-91. [pmid: 11308435].
Morrow AL, Ruiz-Palacios GM, Jiang X, et al. Human-milk glycans that inhibit pathogen binding protect breastfeeding infants against infectious diarrhea. J Nutr. May. 2005;135(5):1304-7. [pmid: 15867329].
Mortensen EL, Michaelsen KF, Sanders SA, et al. The association between duration of breastfeeding and adult intelligence.[see comment][erratum appears in JAMA 2002 Jun 12;287(22):2946]. JAMA. May 8. 2002;287(18):2365-71. [pmid: 11988057].
Ness RB, Grisso JA, Cottreau C, et al. Factors related to inflammation of the ovarian epithelium and risk of ovarian cancer.[see comment]. Epidemiology. Mar. 2000;11(2):111-7. [pmid: 11021606].
Neville MC, Keller RP, Seacat J, et al. Studies on human lactation. I. Within-feed and between-breast variation in selected components of human milk. Am J Clin Nutr. Sep. 1984;40(3):635-46. [pmid: 6475828].
Newburg DS, Peterson JA, Ruiz-Palacios GM, et al. Role of human-milk lactadherin in protection against symptomatic rotavirus infection. Lancet. Apr 18. 1998;351(9110):1160-4. [pmid: 9643686].
Newburg DS, Ruiz-Palacios GM, Morrow AL. Human milk glycans protect infants against enteric pathogens. Annu Rev Nutr. 2005;25:37-58. [pmid: 16011458].
Newcomb PA, Storer BE, Longnecker MP, et al. Lactation and a reduced risk of premenopausal breast cancer.[see comment]. N Engl J Med. Jan 13. 1994;330(2):81-7. [pmid: 8259187].
Nommsen LA, Lovelady CA, Heinig MJ, et al. Determinants of energy, protein, lipid, and lactose concentrations in human milk during the first 12 mo of lactation: the DARLING Study. Am J Clin Nutr. Feb. 1991;53(2):457-65. [pmid: 1989413].
Norris JM, Scott FW. A meta-analysis of infant diet and insulin-dependent diabetes mellitus: do biases play a role?. Epidemiology. Jan. 1996;7(1):87-92. [pmid: 8664407].
Nylen, O, Anderson, B, and Aniansson, G. Reduced frequency of acute otitis media in breast-fed infants. Abstract from the 5th International Congress of Pediatric Oto-Rhino-Laryngology Gent, Belgium, June 5–9. 1990. Ref Type: Abstract
O'Connor DL, Jacobs J, Hall R, et al. Growth and development of premature infants fed predominantly human milk, predominantly premature infant formula, or a combination of human milk and premature formula. J Pediatr Gastroenterol Nutr. Oct. 2003;37(4):437-46. [pmid: 14508214].
O'Hara MW, Swain AM. Rates and risk of postpartum depression - a meta-analysis. Int Rev Psychiatry. 1996;8(1):37-54.
Oddy WH, Holt PG, Sly PD, et al. Association between breast feeding and asthma in 6 year old children: findings of a prospective birth cohort study. BMJ. Sep 25. 1999;319(7213):815-9. [pmid: 10496824]. [pmcid: 314207].
Oddy WH, Kendall GE, Blair E, et al. Breastfeeding and cognitive development in children. Adv Exp Med Biol. 2004;554:365-9. [pmid: 15384602].
Oddy WH, Kendall GE, Blair E, et al. Breast feeding and cognitive development in childhood: a prospective birth cohort study. Paediatr Perinatal Epidemiol. Jan. 2003;17(1):81-90.
Ohlin A, Rossner S. Maternal body weight development after pregnancy. Int J Obes. Feb. 1990;14(2):159-73. [pmid: 2341224].
Ohlin A, Rossner S. Factors related to body weight changes during and after pregnancy: the Stockholm Pregnancy and Weight Development Study. Obes Res. May. 1996;4(3):271-6. [pmid: 8732961].
Olson CM, Strawderman MS, Hinton PS, et al. Gestational weight gain and postpartum behaviors associated with weight change from early pregnancy to 1 y postpartum. Int J Obes Relat Metab Disord. Jan. 2003;27(1):117-27. [pmid: 12532163].
Owen CG, Martin RM, Whincup PH, et al. Effect of infant feeding on the risk of obesity across the life course: a quantitative review of published evidence. Pediatrics. May. 2005;115(5):1367-77. [pmid: 15867049].
Owen CG, Martin RM, Whincup PH, et al. Does breastfeeding influence risk of type 2 diabetes in later life? A quantitative analysis of published evidence. Am J Clin Nutr. Nov. 2006;84(5):1043-54. [pmid: 17093156].
Owen CG, Whincup PH, Gilg JA, et al. Effect of breast feeding in infancy on blood pressure in later life: systematic review and meta-analysis. [Review] [26 refs]. BMJ. Nov 22. 2003;327(7425):1189-95. [pmid: 14630752]. [pmcid: 274051].
Owen CG, Whincup PH, Odoki K, et al. Infant feeding and blood cholesterol: a study in adolescents and a systematic review.[see comment]. [Review] [88 refs]. Pediatrics. Sep. 2002;110(3):597-608. [pmid: 12205266].
Pearson D, Kaur M, San P, et al. Recovery of pregnancy mediated bone loss during lactation. Bone. Mar. 2004;34(3):570-8. [pmid: 15003805].
Pinelli J, Saigal S, Atkinson SA. Effect of breastmilk consumption on neurodevelopmental outcomes at 6 and 12 months of age in VLBW infants. Adv Neonat Care. Apr. 2003;3(2):76-87.
Poiesz BJ, Ruscetti FW, Gazdar AF, et al. Detection and isolation of type C retrovirus particles from fresh and cultured lymphocytes of a patient with cutaneous T-cell lymphoma. Proc Natl Acad Sci U S A. Dec. 1980;77(12):7415-9. [pmid: 6261256]. [pmcid: 350514].
Quigley MA, Cumberland P, Cowden JM, et al. How protective is breast feeding against diarrhoeal disease in infants in 1990s England? A case-control study. Arch Dis Child. Mar. 2006;91(3):245-50. [pmid: 16308409]. [pmcid: 2065954].
Quinn PJ, O'Callaghan M, Williams GM, et al. The effect of breastfeeding on child development at 5 years: a cohort study. J Paediatr Child Health. Oct. 2001;37(5):465-9. [pmid: 11885710].
Riman T, Dickman PW, Nilsson S, et al. Risk factors for invasive epithelial ovarian cancer: results from a Swedish case-control study. Am J Epidemiol. Aug 15. 2002;156(4):363-73. [pmid: 12181107].
Risch HA, Marrett LD, Howe GR. Parity, contraception, infertility, and the risk of epithelial ovarian cancer. Am J Epidemiol. Oct 1. 1994;140(7):585-97. [pmid: 7942759].
Risch HA, Weiss NS, Lyon JL, et al. Events of reproductive life and the incidence of epithelial ovarian cancer. Am J Epidemiol. Feb. 1983;117(2):128-39. [pmid: 6681935].
Ronnestad A, Abrahamsen TG, Medbo S, et al. Late-onset septicemia in a Norwegian national cohort of extremely premature infants receiving very early full human milk feeding. Pediatrics. Mar. 2005;115(3):e269-e276. [pmid: 15866862].
Rosenbaum PF, Buck GM, Brecher ML. Early child-care and preschool experiences and the risk of childhood acute lymphoblastic leukemia. Am J Epidemiol. Dec 15. 2000;152(12):1136-44. [pmid: 11130619].
Rosenblatt KA, Thomas DB. Lactation and the risk of epithelial ovarian cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Epidemiol. Apr. 1993;22(2):192-7. [pmid: 8505173].
Saarinen UM, Kajosaari M, Backman A, et al. Prolonged breast-feeding as prophylaxis for atopic disease. Lancet. Jul 28. 1979;2(8135):163-6. [pmid: 89278].
Sassen ML, Brand R, Grote JJ. Breast-feeding and acute otitis media. Am J Otolaryngol. Sep. 1994;15(5):351-7. [pmid: 7978038].
Scariati PD, Grummer-Strawn LM, Fein SB. A longitudinal analysis of infant morbidity and the extent of breastfeeding in the United States. Pediatrics. Jun. 1997;99(6):E5. [pmid: 9164801].
Schanler RJ, Lau C, Hurst NM, et al. Randomized trial of donor human milk versus preterm formula as substitutes for mothers' own milk in the feeding of extremely premature infants. Pediatrics. Aug. 2005;116(2):400-6. [pmid: 16061595].
Schauberger CW, Rooney BL, Brimer LM. Factors that influence weight loss in the puerperium. Obstet Gynecol. Mar. 1992;79(3):424-9. [pmid: 1738527].
Schellscheidt J, Ott A, Jorch G. Epidemiological features of sudden infant death after a German intervention campaign in 1992. Eur J Pediatr. Aug. 1997;156(8):655-60. [pmid: 9266202].
Schultz Larsen F, Hanifin J. Epidemiology of Atopic Dermatitis. Immunol Allergy Clin North Am. 2002;22(1):1-24.
Sears MR, Greene JM, Willan AR, et al. Long-term relation between breastfeeding and development of atopy and asthma in children and young adults: a longitudinal study.[see comment]. Lancet. Sep 21. 2002;360(9337):901-7. [pmid: 12354471].
Seimyr L, Edhborg M, Lundh W, et al. In the shadow of maternal depressed mood: experiences of parenthood during the first year after childbirth. J Psychosom Obstet Gynecol. Mar. 2004;25(1):23-34.
Shay DK, Holman RC, Newman RD, et al. Bronchiolitis-associated hospitalizations among US children, 1980-1996. JAMA. 1999;282(15):1440-6. [pmid: 10535434].
Shu XO, Linet MS, Steinbuch M, et al. Breast-feeding and risk of childhood acute leukemia. J Natl Cancer Inst. Oct 20. 1999;91(20):1765-72. [pmid: 10528028].
Sichieri R, Field AE, Rich-Edwards J, et al. Prospective assessment of exclusive breastfeeding in relation to weight change in women. Int J Obes Relat Metab Disord. Jul. 2003;27(7):815-20. [pmid: 12821967].
Siskind V, Green A, Bain C, et al. Breastfeeding, menopause, and epithelial ovarian cancer. Epidemiology. Mar. 1997;8(2):188-91. [pmid: 9229212].
Smith DE, Lewis CE, Caveny JL, et al. Longitudinal changes in adiposity associated with pregnancy. The CARDIA Study. Coronary Artery Risk Development in Young Adults Study.[see comment]. JAMA. Jun 8. 1994;271(22):1747-51. [pmid: 8196117].
Smith MM, Durkin M, Hinton VJ, et al. Influence of breastfeeding on cognitive outcomes at age 6–8 years: follow-up of very low birth weight infants. Am J Epidemiol. Dec 1. 2003;158(11):1075-82. [pmid: 14630603].
Sowers M. Pregnancy and lactation as risk factors for subsequent bone loss and osteoporosis. J Bone Miner Res. Aug. 1996;11(8):1052-60. [pmid: 8854240].
Sowers M, Corton G, Shapiro B, et al. Changes in bone density with lactation.[see comment]. JAMA. Jun 23. 1993;269(24):3130. [pmid: 8505816].
Sowers MR, Clark MK, Hollis B, et al. Radial bone mineral density in pre- and perimenopausal women: a prospective study of rates and risk factors for loss. J Bone Miner Res. Jun. 1992;7(6):647-57. [pmid: 1414483].
Stamler J, Daviglus ML, Garside DB, et al. Relationship of baseline serum cholesterol levels in 3 large cohorts of younger men to long-term coronary, cardiovascular, and all-cause mortality and to longevity. JAMA. Jul 19. 2000;284(3):311-8. [pmid: 10891962].
Stenstrom C, Ingvarsson L. Otitis-prone children and controls: a study of possible predisposing factors. 1. Heredity, family background and perinatal period. Acta Oto-Laryngologica. Jan. 1997;117(1):87-93. [pmid: 9039487].
Strachan DP. Hay fever, hygiene, and household size. BMJ. Nov 18. 1989;299(6710):1259-60. [pmid: 2513902]. [pmcid: 1838109].
Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr 19. 2000;283(15):2008-12. [pmid: 10789670].
Stuebe AM, Rich-Edwards JW, Willett WC, et al. Duration of lactation and incidence of type 2 diabetes. JAMA. Nov 23. 2005;294(20):2601-10. [pmid: 16304074].
Tai TY, Wang CY, Lin LL, et al. A case-control study on risk factors for Type 1 diabetes in Taipei City. Diabetes Res Clin Pract. Dec. 1998;42(3):197-203. [pmid: 9925351].
Taylor JS, Kacmar JE, Nothnagle M, et al. A systematic review of the literature associating breastfeeding with type 2 diabetes and gestational diabetes. J Am Coll Nutr. Oct. 2005;24(5):320-6. [pmid: 16192255].
Teele DW, Klein JO, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston: a prospective, cohort study. J Infect Dis. Jul. 1989;160(1):83-94. [pmid: 2732519].
Titus-Ernstoff L, Perez K, Cramer DW, et al. Menstrual and reproductive factors in relation to ovarian cancer risk. Br J Cancer. Mar 2. 2001;84(5):714-21. [pmid: 11237375].
Tung KH, Goodman MT, Wu AH, et al. Reproductive factors and epithelial ovarian cancer risk by histologic type: a multiethnic case-control study. Am J Epidemiol. Oct 1. 2003;158(7):629-38. [pmid: 14507598].
Tung KH, Wilkens LR, Wu AH, et al. Effect of anovulation factors on pre- and postmenopausal ovarian cancer risk: revisiting the incessant ovulation hypothesis. Am J Epidemiol. Feb 15. 2005;161(4):321-9. [pmid: 15692075].
Tyson JE, Lasky RE, Mize CE, et al. Growth, metabolic response, and development in very-low-birth-weight infants fed banked human milk or enriched formula. I. Neonatal findings. J Pediatr. Jul. 1983;103(1):95-104. [pmid: 6864403].
U.S.Department of Health and Human Services. Healthy People 2010: Conference Edition. [II], 46–48. 2000. Washington, DC, U.S. Government Printing Office. Ref Type: Book, Whole
Uhari M, Mantysaari K, Niemela M. A meta-analytic review of the risk factors for acute otitis media.[see comment]. Clin Infect Dis. Jun. 1996;22(6):1079-83. [pmid: 8783714].
UusiRasi K, Sievanen H, Pasanen M, et al. Association of physical activity and calcium intake with the maintenance of bone mass in premenopausal women. Osteoporos Int. Mar. 2002;13(3):211-7. [pmid: 11991440].
Vennemann MM, Findeisen M, ButterfassBahloul T, et al. Modifiable risk factors for SIDS in Germany: results of GeSID. Acta Paediatrica. Jun. 2005;94(6):655-60. [pmid: 16188764].
Vernacchio L, Lesko SM, Vezina RM, et al. Racial/ethnic disparities in the diagnosis of otitis media in infancy. Int J Pediatr Otorhinolaryngol. Jun. 2004;68(6):795-804. [pmid: 15126021].
Virtanen SM, Knip M. Nutritional risk predictors of beta cell autoimmunity and type 1 diabetes at a young age 10046. Am J Clin Nutr. Dec. 2003;78(6):1053-67. [pmid: 14668264].
Visalli N, Sebastiani L, Adorisio E, et al. Environmental risk factors for type 1 diabetes in Rome and province. Arch Dis Child. Aug. 2003;88(8):695-8. [pmid: 12876166]. [pmcid: 1719595].
Vohr BR, Poindexter BB, Dusick AM, et al. Beneficial effects of breast milk in the neonatal intensive care unit on the developmental outcome of extremely low birth weight infants at 18 months of age. Pediatrics. Jul. 2006;118(1):e115-e123. [pmid: 16818526].
Walker L, Freeland-Graves JH, Milani T, et al. Weight and behavioral and psychosocial factors among ethnically diverse, low-income women after childbirth: II. Trends and correlates. Women Health. 2004;40(2):19-34.
Warner R, Appleby L, Whitton A, et al. Demographic and obstetric risk factors for postnatal psychiatric morbidity. Br J Psychiatry. May. 1996;168(5):607-11. [pmid: 8733800].
Wennergren G, Alm B, Oyen N, et al. The decline in the incidence of SIDS in Scandinavia and its relation to riskintervention campaigns. Nordic Epidemiological SIDS Study. Acta Paediatrica. Sep. 1997;86(9):963-8. [pmid: 9343276].
West RO. Epidemiologic study of malignancies of the ovaries. Cancer. Jul. 1966;19(7):1001-7. [pmid: 5939299].
Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group.[see comment]. Am J Epidemiol. Nov 15. 1992;136(10):1184-203. [pmid: 1476141].
Wigg NR, Tong S, McMichael AJ, et al. Does breastfeeding at six months predict cognitive development?[see comment]. Aust N Z J Public Health. Apr. 1998;22(2):232-6. [pmid: 9744183].
Wright AL, Holberg CJ, Taussig LM, et al. Factors influencing the relation of infant feeding to asthma and recurrent wheeze in childhood.[see comment]. Thorax. Mar. 2001;56(3):192-7. [pmid: 11182011]. [pmcid: 1758780].
Wynder EL, Dodo H, Barber HR. Epidemiology of cancer of the ovary. Cancer. Feb. 1969;23(2):352-70. [pmid: 5764976].
Yen ML, Yen BL, Bai CH, et al. Risk factors for ovarian cancer in Taiwan: a case-control study in a low-incidence population. Gynecol Oncol. May. 2003;89(2):318-24. [pmid: 12713998].