# References and Included Studies

1 American Academy of Pediatrics Committee on Nutrition. Pediatric Nutrition Handbook. Fifth. 2004.
2 U.S.Department of Health and Human Services. Healthy People 2010: Conference Edition. Washington, DC: U.S. Government Printing Office; 2000.
3 Scariati PD, Grummer-Strawn LM, Fein SB. A longitudinal analysis of infant morbidity and the extent of breastfeeding in the United States. Pediatrics. 1997;99(6):E5. [pmid: 9164801].
4 Gillman MW, Rifas-Shiman SL, Camargo CA Jr, et al. Risk of overweight among adolescents who were breastfed as infants. JAMA. 2001;285(19):2461-7. [pmid: 11368698].
5 Grummer-Strawn LM, Mei Z. Does breastfeeding protect against pediatric overweight? Analysis of longitudinal data from the Centers for Disease Control and Prevention Pediatric Nutrition Surveillance System. Pediatrics. 2004;113(2):e81-e86. [pmid: 14754976].
6 Oddy WH, Holt PG, Sly PD, et al. Association between breast feeding and asthma in 6 year old children: findings of a prospective birth cohort study. BMJ. 1999;319(7213):815-9. [pmid: 10496824]. [pmcid: 314207].
7 Gartner LM, Morton J, Lawrence RA, et al. Breastfeeding and the use of human milk. Pediatrics. 2005;115(2):496-506. [pmid: 15687461].
8 Chua S, Arulkumaran S, Lim I, et al. Influence of breastfeeding and nipple stimulation on postpartum uterine activity. Br J Obstet Gynaecol. 1994;101(9):804-5. [pmid: 7947531].
9 Dewey KG, Heinig MJ, Nommsen LA. Maternal weight-loss patterns during prolonged lactation. Am J Clin Nutr. 1993;58(2):162-6. [pmid: 8338042].
10 Newcomb PA, Storer BE, Longnecker MP, et al. Lactation and a reduced risk of premenopausal breast cancer.[see comment]. N Engl J Med. 1994;330(2):81-7. [pmid: 8259187].
11 Rosenblatt KA, Thomas DB. Lactation and the risk of epithelial ovarian cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Epidemiol. 1993;22(2):192-7. [pmid: 8505173].
12 Gross SJ. Growth and biochemical response of preterm infants fed human milk or modified infant formula. N Engl J Med. 1983;308(5):237-41. [pmid: 6848932].
13 Tyson JE, Lasky RE, Mize CE, et al. Growth, metabolic response, and development in very-low-birth-weight infants fed banked human milk or enriched formula. I. Neonatal findings. J Pediatr. 1983;103(1):95-104. [pmid: 6864403].
14 Li R, Darling N, Maurice E, et al. Breastfeeding rates in the United States by characteristics of the child, mother, or family: the 2002 National Immunization Survey. Pediatrics. 2005;115(1):e31-e37. [pmid: 15579667].
15 Bauchner H, Leventhal JM, Shapiro ED. Studies of breastfeeding and infections. How good is the evidence?. JAMA. 1986;256(7):887-92. [pmid: 3090286].
16 Kramer MS. Does breast feeding help protect against atopic disease? Biology, methodology, and a golden jubilee of controversy. J Pediatr. 1988;112(2):181-90. [pmid: 3339499].
17 Kramer MS, Chalmers B, Hodnett ED, et al. Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus. JAMA. 2001;285(4):413-20. [pmid: 11242425].
18 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
19 Higgins JP, Whitehead A, Turner RM, et al. Meta-analysis of continuous outcome data from individual patients. Stat Med. 2001;20(15):2219-41. [pmid: 11468761].
20 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120]. [pmcid: 192859].
21 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
22 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283(15):2008-12. [pmid: 10789670].
23 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. 2001;134(8):663-94. [pmid: 11304107].
24 Moher D, Schulz KF, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285(15):1987-91. [pmid: 11308435].
25 Auinger P, Lanphear BP, Kalkwarf HJ, et al. Trends in otitis media among children in the United States. Pediatrics. 2003;112(3 Pt 1):514-20. [pmid: 12949276].
26 Bluestone C, Klein J. Otitis media in infants and children. 2nd edition. WB Saunders; 1995.
27 Nylen O, Anderson B, Aniansson G. Reduced frequency of acute otitis media in breast-fed infants. Abstract from the 5th International Congress of Pediatric Oto-Rhino-Laryngology Gent, Belgium, June 5–9. 1990.
28 Uhari M, Mantysaari K, Niemela M. A meta-analytic review of the risk factors for acute otitis media.[see comment]. Clin Infect Dis. 1996;22(6):1079-83. [pmid: 8783714].
29 Duncan B, Ey J, Holberg CJ, et al. Exclusive breastfeeding for at least 4 months protects against otitis media.[see comment]. Pediatrics. 1993;91(5):867-72. [pmid: 8474804].
30 Howie PW, Forsyth JS, Ogston SA, et al. Protective effect of breast feeding against infection. BMJ. 1990;300(6716):11-6. [pmid: 2105113]. [pmcid: 1661904].
31 Teele DW, Klein JO, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston: a prospective, cohort study. J Infect Dis. 1989;160(1):83-94. [pmid: 2732519].
32 Vernacchio L, Lesko SM, Vezina RM, et al. Racial/ethnic disparities in the diagnosis of otitis media in infancy. Int J Pediatr Otorhinolaryngol. 2004;68(6):795-804. [pmid: 15126021].
33 Duffy LC, Faden H, Wasielewski R, et al. Exclusive breastfeeding protects against bacterial colonization and day care exposure to otitis media. Pediatrics. 1997;100(4):E7. [pmid: 9310540].
34 Alho OP, Laara E, Oja H. Public health impact of various risk factors for acute otitis media in northern Finland. Am J Epidemiol. 1996;143(11):1149-56. [pmid: 8633605].
35 Alho OP, Laara, Oja H. How should relative risk estimates for acute otitis media in children aged less than 2 years be perceived?. J Clin Epidemiol. 1996;49(1):9-14. [pmid: 8598517].
36 Sassen ML, Brand R, Grote JJ. Breastfeeding and acute otitis media. Am J Otolaryngol. 1994;15(5):351-7. [pmid: 7978038].
37 Stenstrom C, Ingvarsson L. Otitis-prone children and controls: a study of possible predisposing factors. 1. Heredity, family background and perinatal period. Acta Oto-Laryngologica. 1997;117(1):87-93. [pmid: 9039487].
38 Schultz Larsen F, Hanifin J. Epidemiology of Atopic Dermatitis. Immunol Allergy Clin North Am. 2002;22(1):1-24.
39 Saarinen UM, Kajosaari M, Backman A, et al. Prolonged breastfeeding as prophylaxis for atopic disease. Lancet. 1979;2(8135):163-6. [pmid: 89278].
40 Gdalevich M, Mimouni D, David M, et al. Breastfeeding and the onset of atopic dermatitis in childhood: a systematic review and meta-analysis of prospective studies. J Am Acad Dermatol. 2001;45(4):520-7. [pmid: 11568741].
41 Imhoff B, Morse D, Shiferaw B, et al. Burden of self-reported acute diarrheal illness in FoodNet surveillance areas, 1998-1999. Clin Infect Dis. 2004;38(Suppl 3):S219-S226. [pmid: 15095193].
42 Feachem RG, Koblinsky MA. Interventions for the control of diarrhoeal diseases among young children: promotion of breastfeeding 10045. Bull World Health Organ. 1984;62(2):271-91. [pmid: 6610496]. [pmcid: 2536296].
43 Morrow AL, Ruiz-Palacios GM, Jiang X, et al. Human-milk glycans that inhibit pathogen binding protect breastfeeding infants against infectious diarrhea. J Nutr. 2005;135(5):1304-7. [pmid: 15867329].
44 Newburg DS, Peterson JA, Ruiz-Palacios GM, et al. Role of human-milk lactadherin in protection against symptomatic rotavirus infection. Lancet. 1998;351(9110):1160-4. [pmid: 9643686].
45 Chien PF, Howie PW. Breast milk and the risk of opportunistic infection in infancy in industrialized and non-industrialized settings. [Review] [75 refs]. Adv Nutr Res. 2001;10:69-104. [pmid: 11795054].
46 Quigley MA, Cumberland P, Cowden JM, et al. How protective is breast feeding against diarrhoeal disease in infants in 1990s England? A case-control study. Arch Dis Child. 2006;91(3):245-50. [pmid: 16308409]. [pmcid: 2065954].
47 Shay DK, Holman RC, Newman RD, et al. Bronchiolitis-associated hospitalizations among US children, 1980-1996. JAMA. 1999;282(15):1440-6. [pmid: 10535434].
48 Bachrach VR, Schwarz E, Bachrach LR. Breastfeeding and the risk of hospitalization for respiratory disease in infancy: a meta-analysis. Arch Pediatr Adolesc Med. 2003;157(3):237-43. [pmid: 12622672].
49 Eder W, Ege MJ, von ME. The asthma epidemic. N Engl J Med. 2006;355(21):2226-35. [pmid: 17124020].
50 Strachan DP. Hay fever, hygiene, and household size. BMJ. 1989;299(6710):1259-60. [pmid: 2513902]. [pmcid: 1838109].
51 Braun-Fahrlander C, Riedler J, Herz U, et al. Environmental exposure to endotoxin and its relation to asthma in school-age children. N Engl J Med. 2002;347(12):869-77. [pmid: 12239255].
52 Gdalevich M, Mimouni D, Mimouni M. Breastfeeding and the risk of bronchial asthma in childhood: a systematic review with meta-analysis of prospective studies. J Pediatr. 2001;139(2):261-6. [pmid: 11487754].
53 Burgess SW, Dakin CJ, O'Callaghan MJ. Breastfeeding does not increase the risk of asthma at 14 years. Pediatrics. 2006;117(4):e787-e792. [pmid: 16510659].
54 Kull I, Almqvist C, Lilja G, et al. Breast-feeding reduces the risk of asthma during the first 4 years of life.[see comment]. J Allergy Clin Immunol 114(4):755–60, 2004;114(4):755–60.
55 Sears MR, Greene JM, Willan AR, et al. Long-term relation between breastfeeding and development of atopy and asthma in children and young adults: a longitudinal study.[see comment]. Lancet. 2002;360(9337):901-7. [pmid: 12354471].
56 Wright AL, Holberg CJ, Taussig LM, et al. Factors influencing the relation of infant feeding to asthma and recurrent wheeze in childhood.[see comment]. Thorax. 2001;56(3):192-7. [pmid: 11182011]. [pmcid: 1758780].
57 Drane DL, Logemann JA. A critical evaluation of the evidence on the association between type of infant feeding and cognitive development. Paediatr Perinat Epidemiol. 2000;14(4):349-56. [pmid: 11101022].
58 Jain A, Concato J, Leventhal JM. How good is the evidence linking breastfeeding and intelligence?. Pediatrics. 2002;109(6):1044-53. [pmid: 12042541].
59 Johnson DL, Swank PR, Howie VM, et al. Breast feeding and children's intelligence. Psychol Rep. 1996;79(3 Part 2):1179-85. [pmid: 9009764].
60 Wigg NR, Tong S, McMichael AJ, et al. Does breastfeeding at six months predict cognitive development?[see comment]. Aust N Z J Public Health. 1998;22(2):232-6. [pmid: 9744183].
61 Anderson JW, Johnstone BM, Remley DT. Breastfeeding and cognitive development: a meta-analysis. Am J Clin Nutr. 1999;70(4):525-35. [pmid: 10500022].
62 Der G, Batty D, Deary IJ. Effect of breast feeding on intelligence in children: prospective study, sibling pairs analysis, and meta-analysis. BMJ 2006.
63 Agostoni C, Marangoni F, Giovannini M, et al. Prolonged breastfeeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol. 2001;501:137-41. [pmid: 11787675].
64 Angelsen NK, Vik T, Jacobsen G, et al. Breast feeding and cognitive development at age 1 and 5 years. Arch Dis Child. 2001;85(3):183-8. [pmid: 11517096]. [pmcid: 1718901].
65 Gomez-Sanchiz M, Canete R, Rodero I, et al. Influence of breastfeeding on mental and psychomotor development. Clinical Pediatrics. 2003;42(1):35-42. [pmid: 12635980].
66 Gomez-Sanchiz M, Canete R, Rodero I, et al. Influence of breastfeeding and parental intelligence on cognitive development in the 24-month-old child. Clin Pediatr. 2004;43(8):753-61.
67 Mortensen EL, Michaelsen KF, Sanders SA, et al. The association between duration of breastfeeding and adult intelligence.[see comment][erratum appears in JAMA 2002 Jun 12;287(22):2946]. JAMA. 2002;287(18):2365-71. [pmid: 11988057].
68 Oddy WH, Kendall GE, Blair E, et al. Breast feeding and cognitive development in childhood: a prospective birth cohort study. Paediatr Perinat Epidemiol. 2003;17(1):81-90. [pmid: 12562475].
69 Oddy WH, Kendall GE, Blair E, et al. Breastfeeding and cognitive development in children. Adv Exp Med Biol. 2004;554:365-9. [pmid: 15384602].
70 Quinn PJ, O'Callaghan M, Williams GM, et al. The effect of breastfeeding on child development at 5 years: a cohort study. J Paediatr Child Health. 2001;37(5):465-9. [pmid: 11885710].
71 Lawlor DA, Najman JM, Batty GD, et al. Early life predictors of childhood intelligence: findings from the Mater-University study of pregnancy and its outcomes. Paediatr Perinat Epidemiol. 2006;20(2):148-62. [pmid: 16466433].
72 Evenhouse E, Reilly S. Improved estimates of the benefits of breastfeeding using sibling comparisons to reduce selection bias. Health Serv Res. 2005;40(6 Pt 1):1781-802. [pmid: 16336548]. [pmcid: 1361236].
73 Agostoni C. Ghrelin, leptin and the neurometabolic axis of breastfed and formula-fed infants. Acta Paediatr. 2005;94(5):523-5. [pmid: 16188736].
74 Dewey KG. Growth characteristics of breast-fed compared to formula-fed infants. Biol Neonate. 1998;74(2):94-105. [pmid: 9691152].
75 Demmelmair H, von RJ, Koletzko B. Long-term consequences of early nutrition. [Review] [67 refs]. Early Hum Dev. 2006;82(8):567-74. [pmid: 16887299].
76 Arenz S, Ruckerl R, Koletzko B, et al. Breastfeeding and childhood obesity—a systematic review. [Review] [51 refs]. Int J Obes Relat Metab Disord: Journal of the International Association for the Study of Obesity. 2004;28(10):1247-56.
77 Harder T, Bergmann R, Kallischnigg G, et al. Duration of breastfeeding and risk of overweight: a meta-analysis. Am J Epidemiol. 2005;162(5):397-403. [pmid: 16076830].
78 Owen CG, Martin RM, Whincup PH, et al. Effect of infant feeding on the risk of obesity across the life course: a quantitative review of published evidence. Pediatrics. 2005;115(5):1367-77. [pmid: 15867049].
79 Lowe LP, Greenland P, Ruth KJ, et al. Impact of major cardiovascular disease risk factors, particularly in combination, on 22-year mortality in women and men. Arch Intern Med. 1998;158(18):2007-14. [pmid: 9778200].
80 Stamler J, Daviglus ML, Garside DB, et al. Relationship of baseline serum cholesterol levels in 3 large cohorts of younger men to long-term coronary, cardiovascular, and all-cause mortality and to longevity. JAMA. 2000;284(3):311-8. [pmid: 10891962].
81 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
82 Owen CG, Whincup PH, Odoki K, et al. Infant feeding and blood cholesterol: a study in adolescents and a systematic review.[see comment]. [Review] [88 refs]. Pediatrics. 2002;110(3):597-608. [pmid: 12205266].
83 Martin RM, Gunnell D, Smith GD. Breastfeeding in infancy and blood pressure in later life: systematic review and meta-analysis. Am J Epidemiol. 2005;161(1):15-26. [pmid: 15615909].
84 Owen CG, Whincup PH, Gilg JA, et al. Effect of breast feeding in infancy on blood pressure in later life: systematic review and meta-analysis. [Review] [26 refs]. BMJ. 2003;327(7425):1189-95. [pmid: 14630752]. [pmcid: 274051].
85 Martin RM, Davey SG, Mangtani P, et al. Breastfeeding and cardiovascular mortality: the Boyd Orr cohort and a systematic review with meta-analysis. [Review] [25 refs]. Eur Heart J. 2004;25(9):778-86. [pmid: 15120889].
86 Kleinman R. Towards a “new beginning”: dietary fat restrictions in infancy?. Acta Paediatrica. 2000;89(1):2-4. [pmid: 10677046].
87 Virtanen SM, Knip M. Nutritional risk predictors of beta cell autoimmunity and type 1 diabetes at a young age 10046. Am J Clin Nutr. 2003;78(6):1053-67. [pmid: 14668264].
88 Karjalainen J, Martin JM, Knip M, et al. A bovine albumin peptide as a possible trigger of insulin-dependent diabetes mellitus. N Engl J Med. 1992;327(5):302-7. [pmid: 1377788].
89 Gerstein HC. Cow's milk exposure and type I diabetes mellitus. A critical overview of the clinical literature. Diabetes Care. 1994;17(1):13-9. [pmid: 8112184].
90 Norris JM, Scott FW. A meta-analysis of infant diet and insulin-dependent diabetes mellitus: do biases play a role?. Epidemiology. 1996;7(1):87-92. [pmid: 8664407].
91 EURODIAS S. Rapid early growth is associated with increased risk of childhood type 1 diabetes in various European populations. Diabetes Care. 2002;25(10):1755-60. [pmid: 12351473].
92 Jones ME, Swerdlow AJ, Gill LE, et al. Pre-natal and early life risk factors for childhood onset diabetes mellitus: a record linkage study. Int J Epidemiol. 1998;27(3):444-9. [pmid: 9698133].
93 McKinney PA, Parslow R, Gurney KA, et al. Perinatal and neonatal determinants of childhood type 1 diabetes. A case-control study in Yorkshire, U.K. Diabetes Care. 1999;22(6):928-32. [pmid: 10372244].
94 Meloni T, Marinaro AM, Mannazzu MC, et al. IDDM and early infant feeding. Sardinian case-control study. Diabetes Care 1997;(3):340–2.
95 Tai TY, Wang CY, Lin LL, et al. A case-control study on risk factors for Type 1 diabetes in Taipei City. Diabetes Res Clin Pract. 1998;42(3):197-203. [pmid: 9925351].
96 Visalli N, Sebastiani L, Adorisio E, et al. Environmental risk factors for type 1 diabetes in Rome and province. Arch Dis Child. 2003;88(8):695-8. [pmid: 12876166]. [pmcid: 1719595].
97 Lindsay RS, Hanson RL, Bennett PH, et al. Secular trends in birth weight, BMI, and diabetes in the offspring of diabetic mothers. Diabetes Care. 2000;23(9):1249-54. [pmid: 10977014].
98 Taylor JS, Kacmar JE, Nothnagle M, et al. A systematic review of the literature associating breastfeeding with type 2 diabetes and gestational diabetes. J Am Coll Nutr. 2005;24(5):320-6. [pmid: 16192255].
99 Owen CG, Martin RM, Whincup PH, et al. Does breastfeeding influence risk of type 2 diabetes in later life? A quantitative analysis of published evidence. Am J Clin Nutr. 2006;84(5):1043-54. [pmid: 17093156].
100 EPSTEIN MA, ACHONG BG, Barry YM. VIirus particles in cultured lymphoblastks from Burkitt's lymphoma. Lancet. 1964;15:702-3. [pmid: 14107961].
101 Poiesz BJ, Ruscetti FW, Gazdar AF, et al. Detection and isolation of type C retrovirus particles from fresh and cultured lymphocytes of a patient with cutaneous T-cell lymphoma. Proc Natl Acad Sci U S A. 1980;77(12):7415-9. [pmid: 6261256]. [pmcid: 350514].
102 Greaves MF. Speculations on the cause of childhood acute lymphoblastic leukemia. Leukemia. 1988;2(2):120-5. [pmid: 3278171].
103 Beral VaUCCSI. Breastfeeding and childhood cancer. Br J Cancer 2001;85(11):1685–94.
104 Guise JM, Austin D, Morris CD. Review of case-control studies related to breastfeeding and reduced risk of childhood leukemia. Pediatrics. 2005;116(5):e724-e731. [pmid: 16263987].
105 Davis MK. Review of the evidence for an association between infant feeding and childhood cancer. Int J Cancer - Suppl. 1998;11:29-33. [pmid: 9876474].
106 Kwan ML, Buffler PA, Abrams B, et al. Breastfeeding and the risk of childhood leukemia: a meta-analysis. Public Health Rep. 2004;119(6):521-35. [pmid: 15504444]. [pmcid: 1497668].
107 Shu XO, Linet MS, Steinbuch M, et al. Breastfeeding and risk of childhood acute leukemia. J Natl Cancer Inst. 1999;91(20):1765-72. [pmid: 10528028].
108 Dockerty JD, Skegg DC, Elwood JM, et al. Infections, vaccinations, and the risk of childhood leukaemia. Br J Cancer. 1999;80(9):1483-9. [pmid: 10424755].
109 Rosenbaum PF, Buck GM, Brecher ML. Early child-care and preschool experiences and the risk of childhood acute lymphoblastic leukemia. Am J Epidemiol. 2000;152(12):1136-44. [pmid: 11130619].
110 Eliminate Disparities in Infant Mortality. Office of Minority Health:Centers for Disease Control and Prevention. 2006.
111 Effect of breastfeeding on infant and child mortality due to infectious diseases in less developed countries: a pooled analysis. WHO Collaborative Study Team on the Role of Breastfeeding on the Prevention of Infant Mortality.[see comment][erratum appears in Lancet 2000 Mar 25;355(9209):1104]. Lancet 2000;355(9202):451–5.
112 Chen A, Rogan WJ. Breastfeeding and the risk of postneonatal death in the United States. Pediatrics. 2004;113(5):e435-e439. [pmid: 14993531].
113 Forste R, Weiss J, Lippincott E. The decision to breastfeed in the United States: does race matter?[see comment]. Pediatrics. 2001;108(2):291-6. [pmid: 11483790].
114 Sudden, Unexplained Infant Death Initiative (SUIDI): Overview. Department for Health and Human Services-Centers for Disease Control and Prevention. 2006.
115 McVea KL, Turner PD, Peppler DK. The role of breastfeeding in sudden infant death syndrome. J Hum Lact. 2000;16(1):13-20. [pmid: 11138219].
116 Findeisen M, Vennemann M, Brinkmann B, et al. German study on sudden infant death (GeSID): design, epidemiological and pathological profile. Int J Legal Med. 2004;118(3):163-9. [pmid: 15042379].
117 Hauck FR, Herman SM, Donovan M, et al. Sleep environment and the risk of sudden infant death syndrome in an urban population: the Chicago Infant Mortality Study. Pediatrics. 2003;111(5 Part 2):1207-14. [pmid: 12728140].
118 Mitchell EA, Tuohy PG, Brunt JM, et al. Risk factors for sudden infant death syndrome following the prevention campaign in New Zealand: a prospective study. Pediatrics. 1997;100(5):835-40. [pmid: 9346984].
119 Schellscheidt J, Ott A, Jorch G. Epidemiological features of sudden infant death after a German intervention campaign in 1992. Eur J Pediatr. 1997;156(8):655-60. [pmid: 9266202].
120 Vennemann MM, Findeisen M, ButterfassBahloul T, et al. Modifiable risk factors for SIDS in Germany: results of GeSID. Acta Paediatrica. 2005;94(6):655-60. [pmid: 16188764].
121 Wennergren G, Alm B, Oyen N, et al. The decline in the incidence of SIDS in Scandinavia and its relation to risk-intervention campaigns. Nordic Epidemiological SIDS Study. Acta Paediatrica. 1997;86(9):963-8. [pmid: 9343276].
122 Brooke H, Gibson A, Tappin D, et al. case-control study of sudden infant death syndrome in Scotland, 1992-5.[see comment]. BMJ. 1997;314(7093):1516-20. [pmid: 9169398]. [pmcid: 2126747].
123 Mitchell EA, Taylor BJ, Ford RP, et al. Four modifiable and other major risk factors for cot death: the New Zealand study.[see comment]. J Paediatr Child Health 1992;28:Suppl-8.
124 Fleming PJ, Blair PS, Bacon C, et al. Environment of infants during sleep and risk of the sudden infant death syndrome: results of 1993-5 case-control study for confidential inquiry into stillbirths and deaths in infancy. Confidential Enquiry into Stillbirths and Deaths Regional Coordinators and Researchers.[see comment]. BMJ. 1996;313(7051):191-5. [pmid: 8696193]. [pmcid: 2351639].
125 Llanos AR, Moss ME, Pinzon MC, et al. Epidemiology of neonatal necrotising enterocolitis: a population-based study. Paediatr Perinat Epidemiol. 2002;16(4):342-9. [pmid: 12445151].
126 McGuire W, Anthony MY. Formula milk versus term human milk for feeding preterm or low birth weight infants. Cochrane Database Syst Rev 2001;(4):CD002971.
127 Schanler RJ, Lau C, Hurst NM, et al. Randomized trial of donor human milk versus preterm formula as substitutes for mothers' own milk in the feeding of extremely premature infants. Pediatrics. 2005;116(2):400-6. [pmid: 16061595].
128 Furman L, Taylor G, Minich N, et al. The effect of maternal milk on neonatal morbidity of very low-birth-weight infants. Arch Pediatr Adolesc Med. 2003;157(1):66-71. [pmid: 12517197].
129 Ronnestad A, Abrahamsen TG, Medbo S, et al. Late-onset septicemia in a Norwegian national cohort of extremely premature infants receiving very early full human milk feeding. Pediatrics. 2005;115(3):e269-e276. [pmid: 15866862].
130 Lucas A, Gore SM, Cole TJ, et al. Multicentre trial on feeding low birthweight infants: effects of diet on early growth. Arch Dis Child. 1984;59(8):722-30. [pmid: 6476868]. [pmcid: 1628628].
131 Lucas A, Cole TJ. Breast milk and neonatal necrotising enterocolitis. Lancet. 1990;336(8730):1519-23. [pmid: 1979363].
132 Dezoete JA, MacArthur BA, Tuck B. Prediction of Bayley and Stanford-Binet scores with a group of very low birthweight children. Child Care Health Dev. 2003;29(5):367-72. [pmid: 12904244].
133 Hack M, Taylor HG, Drotar D, et al. Poor predictive validity of the Bayley Scales of Infant Development for cognitive function of extremely low birth weight children at school age. Pediatrics. 2005;116(2):333-41. [pmid: 16061586].
134 Eidelman AI, Feldman R. Positive effect of human milk on neurobehavioral and cognitive development of premature infants. Adv Exp Med Biol. 2004;554:359-64. [pmid: 15384601].
135 Elgen I, Sommerfelt K, Ellertsen B. Cognitive performance in a low birth weight cohort at 5 and 11 years of age. Pediatr Neurol. 2003;29(2):111-6. [pmid: 14580653].
136 Feldman R, Eidelman AI. Direct and indirect effects of breast milk on the neurobehavioral and cognitive development of premature infants. Dev Psychobiol. 2003;43(2):109-19. [pmid: 12918090].
137 Pinelli J, Saigal S, Atkinson SA. Effect of breastmilk consumption on neurodevelopmental outcomes at 6 and 12 months of age in VLBW infants. Adv Neonat Care. 2003;3(2):76-87.
138 Vohr BR, Poindexter BB, Dusick AM, et al. Beneficial effects of breast milk in the neonatal intensive care unit on the developmental outcome of extremely low birth weight infants at 18 months of age. Pediatrics. 2006;118(1):e115-e123. [pmid: 16818526].
139 Bier JA, Oliver T, Ferguson AE, et al. Human milk improves cognitive and motor development of premature infants during infancy. J Hum Lact. 2002;18(4):361-7. [pmid: 12449052].
140 Smith MM, Durkin M, Hinton VJ, et al. Influence of breastfeeding on cognitive outcomes at age 6–8 years: follow-up of very low birth weight infants. Am J Epidemiol. 2003;158(11):1075-82. [pmid: 14630603].
141 Horwood LJ, Darlow BA, Mogridge N. Breast milk feeding and cognitive ability at 7–8 years. Arch Dis Child Fetal Neonatal Ed. 2001;84(1):F23-F27. [pmid: 11124919].
142 O'Connor DL, Jacobs J, Hall R, et al. Growth and development of premature infants fed predominantly human milk, predominantly premature infant formula, or a combination of human milk and premature formula. J Pediatr Gastroenterol Nutr. 2003;37(4):437-46. [pmid: 14508214].
143 Smith DE, Lewis CE, Caveny JL, et al. Longitudinal changes in adiposity associated with pregnancy. The CARDIA Study. Coronary Artery Risk Development in Young Adults Study.[see comment]. JAMA. 1994;271(22):1747-51. [pmid: 8196117].
144 Ohlin A, Rossner S. Maternal body weight development after pregnancy. Int J Obes. 1990;14(2):159-73. [pmid: 2341224].
145 Olson CM, Strawderman MS, Hinton PS, et al. Gestational weight gain and postpartum behaviors associated with weight change from early pregnancy to 1 y postpartum. Int J Obes Relat Metab Disord. 2003;27(1):117-27. [pmid: 12532163].
146 Schauberger CW, Rooney BL, Brimer LM. Factors that influence weight loss in the puerperium. Obstet Gynecol. 1992;79(3):424-9. [pmid: 1738527].
147 Greene GW, Smiciklas-Wright H, Scholl TO, et al. Postpartum weight change: how much of the weight gained in pregnancy will be lost after delivery?. Obstet Gynecol. 1988;71(5):701-7. [pmid: 3357658].
148 Keppel KG, Taffel SM. Pregnancy-related weight gain and retention: implications of the 1990 Institute of Medicine guidelines.[see comment]. Am J Public Health. 1993;83(8):1100-3. [pmid: 8342716]. [pmcid: 1695171].
149 Fraser AB, Grimes DA. Effect of lactation on maternal body weight: a systematic review. [Review] [57 refs]. Obstet Gynecol Survey. 2003;58(4):265-9.
150 Butte NF, Hopkinson JM. Body composition changes during lactation are highly variable among women. [Review][45 refs]. J Nutr 1998;128(2:Suppl):Suppl-385S.
151 Dewey KG. Impact of breastfeeding on maternal nutritional status. [Review] [26 refs]. Advs Exp Med Biol. 2004;554:91-100.
152 Sichieri R, Field AE, Rich-Edwards J, et al. Prospective assessment of exclusive breastfeeding in relation to weight change in women. Int J Obes Relat Metab Disord. 2003;27(7):815-20. [pmid: 12821967].
153 Janney CA, Zhang D, Sowers M. Lactation and weight retention. Am J Clin Nutr. 1997;66(5):1116-24. [pmid: 9356528].
154 Linne Y, Dye L, Barkeling B, et al. Weight development over time in parous women—the SPAWN study—15 years follow-up. Int J Obes Relat Metab Disord. 2003;27(12):1516-22. [pmid: 14634683].
155 Walker L, Freeland-Graves JH, Milani T, et al. Weight and behavioral and psychosocial factors among ethnically diverse, low-income women after childbirth: II. Trends and correlates. Women Health. 2004;40(2):19-34.
156 Brewer MM, Bates MR, Vannoy LP. Postpartum changes in maternal weight and body fat depots in lactating vs nonlactating women. Am J Clin Nutr. 1989;49(2):259-65. [pmid: 2916446].
157 Ohlin A, Rossner S. Factors related to body weight changes during and after pregnancy: the Stockholm Pregnancy and Weight Development Study. Obes Res. 1996;4(3):271-6. [pmid: 8732961].
158 Haiek LN, Kramer MS, Ciampi A, et al. Postpartum weight loss and infant feeding. J Am Board Fam Pract. 2001;14(2):85-94. [pmid: 11314929].
159 Kjos SL, Henry O, Lee RM, et al. The effect of lactation on glucose and lipid metabolism in women with recent gestational diabetes. Obstet Gynecol. 1993;82(3):451-5. [pmid: 8355952].
160 McManus RM, Cunningham I, Watson A, et al. Beta-cell function and visceral fat in lactating women with a history of gestational diabetes. Metabolism. 2001;50(6):715-9. [pmid: 11398150].
161 Kjos SL, Peters RK, Xiang A, et al. Contraception and the risk of type 2 diabetes mellitus in Latina women with prior gestational diabetes mellitus. JAMA. 1998;280(6):533-8. [pmid: 9707143].
162 Stuebe AM, Rich-Edwards JW, Willett WC, et al. Duration of lactation and incidence of type 2 diabetes. JAMA. 2005;294(20):2601-10. [pmid: 16304074].
163 Sowers M. Pregnancy and lactation as risk factors for subsequent bone loss and osteoporosis. J Bone Miner Res. 1996;11(8):1052-60. [pmid: 8854240].
164 Kovacs CS, Kronenberg HM. Maternal-Fetal Calcium and Bone Metabolism During Pregnancy, Puerperium, and Lactation. Endocr Rev. 1997;18(6):832-72. [pmid: 9408745].
165 Affinito P, Tommaselli GA, di Carlo C, et al. Changes in bone mineral density and calcium metabolism in breastfeeding women: a one year follow-up study. J Clin Endocrinol Metab. 1996;81(6):2314-8. [pmid: 8964870].
166 Matsumoto I, Kosha S, Noguchi S, et al. Changes of bone mineral density in pregnant and postpartum women. J Obstet Gynaecol. 1995;21(5):419-25. [pmid: 8542463].
167 Pearson D, Kaur M, San P, et al. Recovery of pregnancy mediated bone loss during lactation. Bone. 2004;34(3):570-8. [pmid: 15003805].
168 Sowers M, Corton G, Shapiro B, et al. Changes in bone density with lactation.[see comment]. JAMA. 1993;269(24):3130. [pmid: 8505816].
169 Lopez JM, Gonzalez G, Reyes V, et al. Bone turnover and density in healthy women during breastfeeding and after weaning. Osteoporos Int. 1996;6(2):153-9. [pmid: 8704355].
170 Alderman BW, Weiss NS, Daling JR, et al. Reproductive history and postmenopausal risk of hip and forearm fracture. Am J Epidemiol. 1986;124(2):262-7. [pmid: 3728442].
171 Chan HH, Lau EM, Woo J, et al. Dietary calcium intake, physical activity and the risk of vertebral fracture in Chinese. Osteoporos Int. 1996;6(3):228-32. [pmid: 8783297].
172 Cumming RG, Klineberg RJ. Breastfeeding and other reproductive factors and the risk of hip fractures in elderly women.[erratum appears in Int J Epidemiol 1993 Oct;22(5):962]. Int J Epidemiol. 1993;22(4):684-91. [pmid: 8225744].
173 Hoffman S, Grisso JA, Kelsey JL, et al. Parity, lactation and hip fracture. Osteoporos Int. 1993;3(4):171-6. [pmid: 8338971].
174 Kreiger N, Kelsey JL, Holford TR, et al. An epidemiologic study of hip fracture in postmenopausal women. Am J Epidemiol. 1982;116(1):141-8. [pmid: 7102649].
175 Michaelsson K, Baron JA, Farahmand BY, et al. Influence of parity and lactation on hip fracture risk. Am J Epidemiol. 2001;153(12):1166-72. [pmid: 11415951].
176 Hansen MA, Overgaard K, Riis BJ, et al. Potential risk factors for development of postmenopausal osteoporosis—examined over a 12-year period. Osteoporos Int. 1991;1(2):95-102. [pmid: 1790399].
177 Matsushita H, Kurabayashi T, Tomita M, et al. The effect of multiple pregnancies on lumbar bone mineral density in Japanese women. Calcif Tissue Int. 2002;71(1):10-3. [pmid: 12200655].
178 Sowers MR, Clark MK, Hollis B, et al. Radial bone mineral density in pre- and perimenopausal women: a prospective study of rates and risk factors for loss. J Bone Miner Res. 1992;7(6):647-57. [pmid: 1414483].
179 Uusi-Rasi K, Sievanen H, Pasanen M, et al. Association of physical activity and calcium intake with the maintenance of bone mass in premenopausal women. Osteoporos Int. 2002;13(3):211-7. [pmid: 11991440].
180 O'Hara MW, Swain AM. Rates and risk of postpartum depression - a meta-analysis. Int Rev Psychiatry. 1996;8(1):37-54.
181 Warner R, Appleby L, Whitton A, et al. Demographic and obstetric risk factors for postnatal psychiatric morbidity. Br J Psychiatry. 1996;168(5):607-11. [pmid: 8733800].
182 Chaudron LH, Klein MH, Remington P, et al. Predictors, prodromes and incidence of postpartum depression. J Psychosom Obstet Gynecol. 2001;22(2):103-12.
183 Cooper PJ, Murray L, Stein A. Psychosocial factors associated with the early termination of breastfeeding. J Psychosom Res. 1993;37(2):171-6. [pmid: 8463993].
184 Hannah P, Adams D, Lee A, et al. Links between early post-partum mood and post-natal depression. Br J Psychiatry. 1992;160:777-80. [pmid: 1617360].
185 Henderson JJ, Evans SF, Straton JA, et al. Impact of postnatal depression on breastfeeding duration.[erratum appears in Birth. 2004 Mar;31(1):76]. Birth. 2003;30(3):175-80. [pmid: 12911800].
186 Seimyr L, Edhborg M, Lundh W, et al. In the shadow of maternal depressed mood: experiences of parenthood during the first year after childbirth. J Psychosom Obstet Gynecol. 2004;25(1):23-34.
187 American Cancer Society: Cancer Facts and Figures 2006. Atlanta, GA. American Cancer Society, 2006.
188 Bernier MO, PluBureau G, Bossard N, et al. Breastfeeding and risk of breast cancer: a metaanalysis of published studies. Hum Reprod Update. 2000;6(4):374-86. [pmid: 10972524].
189 Collaborative Group on Hormonal Factors in Breast Cancer. Breast cancer and breastfeeding: collaborative reanalysis of individual data from 47 epidemiological studies in 30 countries, including 50302 women with breast cancer and 96973 women without the disease.[see comment]. [Review][68 refs]. Lancet2002;360(9328):187–95.
190 Lipworth L, Bailey LR, Trichopoulos D. History of breastfeeding in relation to breast cancer risk: a review of the epidemiologic literature.[see comment]. [Review] [43 refs]. J Natl Cancer Inst. 2000;92(4):302-12. [pmid: 10675379].
191 Gammon MD, Neugut AI, Santella RM, et al. The Long Island Breast Cancer Study Project: description of a multi-institutional collaboration to identify environmental risk factors for breast cancer. Breast Cancer Res Treat. 2002;74(3):235-54. [pmid: 12206514].
192 Jernstrom H, Lubinski J, Lynch HT, et al. Breastfeeding and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. J Natl Cancer Inst. 2004;96(14):1094-8. [pmid: 15265971].
193 Lee SY, Kim MT, Kim SW, et al. Effect of lifetime lactation on breast cancer risk: a Korean women's cohort study. Int J Cancer. 2003;105(3):390-3. [pmid: 12704674].
194 Riman T, Dickman PW, Nilsson S, et al. Risk factors for invasive epithelial ovarian cancer: results from a Swedish case-control study. Am J Epidemiol. 2002;156(4):363-73. [pmid: 12181107].
195 Chiaffarino F, Pelucchi C, Negri E, et al. Breastfeeding and the risk of epithelial ovarian cancer in an Italian population. Gyneco Oncol. 2005;98(2):304-8.
196 Cramer DW, Hutchison GB, Welch WR, et al. Determinants of ovarian cancer risk. I. Reproductive experiences and family history. J Natl Cancer Inst. 1983;71(4):711-6. [pmid: 6578366].
197 Greggi S, Parazzini F, Paratore MP, et al. Risk factors for ovarian cancer in central Italy. Gynecol Oncol. 2000;79(1):50-4. [pmid: 11006030].
198 Gwinn ML, Lee NC, Rhodes PH, et al. Pregnancy, breast feeding, and oral contraceptives and the risk of epithelial ovarian cancer. J Clin Epidemiol. 1990;43(6):559-68. [pmid: 2348208].
199 Hartge P, Schiffman MH, Hoover R, et al. A case-control study of epithelial ovarian cancer. Am J Obstet Gynecol. 1989;161(1):10-6. [pmid: 2750791].
200 Modugno F, Ness RB, Wheeler JE. Reproductive risk factors for epithelial ovarian cancer according to histologic type and invasiveness. Ann Epidemiol. Nov. 2001;11(8):568-74. [pmid: 11709277].
201 Ness RB, Grisso JA, Cottreau C, et al. Factors related to inflammation of the ovarian epithelium and risk of ovarian cancer.[see comment]. Epidemiology. 2000;11(2):111-7. [pmid: 11021606].
202 Risch HA, Weiss NS, Lyon JL, et al. Events of reproductive life and the incidence of epithelial ovarian cancer. Am J Epidemiol. 1983;117(2):128-39. [pmid: 6681935].
203 Risch HA, Marrett LD, Howe GR. Parity, contraception, infertility, and the risk of epithelial ovarian cancer. Am J Epidemiol. 1994;140(7):585-97. [pmid: 7942759].
204 Siskind V, Green A, Bain C, et al. Breastfeeding, menopause, and epithelial ovarian cancer. Epidemiology. 1997;8(2):188-91. [pmid: 9229212].
205 Titus-Ernstoff L, Perez K, Cramer DW, et al. Menstrual and reproductive factors in relation to ovarian cancer risk. Br J Cancer. 2001;84(5):714-21. [pmid: 11237375].
206 Tung KH, Goodman MT, Wu AH, et al. Reproductive factors and epithelial ovarian cancer risk by histologic type: a multiethnic case-control study. Am J Epidemiol. 2003;158(7):629-38. [pmid: 14507598].
207 Tung KH, Wilkens LR, Wu AH, et al. Effect of anovulation factors on pre- and postmenopausal ovarian cancer risk: revisiting the incessant ovulation hypothesis. Am J Epidemiol. 2005;161(4):321-9. [pmid: 15692075].
208 West RO. Epidemiologic study of malignancies of the ovaries. Cancer. 1966;19(7):1001-7. [pmid: 5939299].
209 Wynder EL, Dodo H, Barber HR. Epidemiology of cancer of the ovary. Cancer. 1969;23(2):352-70. [pmid: 5764976].
210 Yen ML, Yen BL, Bai CH, et al. Risk factors for ovarian cancer in Taiwan: a case-control study in a low-incidence population. Gynecologic Oncology. 2003;89(2):318-24. [pmid: 12713998].
211 John EM, Whittemore AS, Harris R, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of seven U.S. case-control studies. Epithelial ovarian cancer in black women. Collaborative Ovarian Cancer Group. Journal of the National Cancer Institute. 1993;85(2):142-7. [pmid: 8418303].
212 Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group.[see comment]. Am J Epidemiol. 1992;136(10):1184-203. [pmid: 1476141].
213 Modugno F, Moslehi R, Ness RB, et al. Reproductive factors and ovarian cancer risk in Jewish BRCA1 and BRCA2 mutation carriers (United States). Cancer Causes Control. 2003;14(5):439-46. [pmid: 12946038].
214 Kramer MS, Kakuma R. The optimal duration of exclusive breastfeeding: a systematic review. Adv Exp Med Biol. 2004;554:63-77. [pmid: 15384567].
215 Bland RM, Rollins NC, Solarsh G, et al. Maternal recall of exclusive breast feeding duration. Arch Dis Child. 2003;88(9):778-83. [pmid: 12937095]. [pmcid: 1719625].
216 Neville MC, Keller RP, Seacat J, et al. Studies on human lactation. I. Within-feed and between-breast variation in selected components of human milk. Am J Clin Nutr. 1984;40(3):635-46. [pmid: 6475828].
217 Nommsen LA, Lovelady CA, Heinig MJ, et al. Determinants of energy, protein, lipid, and lactose concentrations in human milk during the first 12 mo of lactation: the DARLING Study. Am J Clin Nutr. 1991;53(2):457-65. [pmid: 1989413].
218 Newburg DS, Ruiz-Palacios GM, Morrow AL. Human milk glycans protect infants against enteric pathogens. Annu Rev Nutr. 2005;25:37-58. [pmid: 16011458].