# Acknowledgments

We acknowledge with appreciation the members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center (EPC) during preparation of this report. In designing the study questions and methodology at the outset of this report, the EPC consulted these technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Technical Expert Panel

David Chelmow, M.D. | Ronald E. Kleinman, M.D.
Obstetrician-Gynecologist | Pediatric Gastroenterology and Nutrition
Tufts-New England Medical Center | Department of Pediatrics
Tufts University School of Medicine | MassGeneral Hospital for Children
Kathryn G. Dewey, Ph.D. | Michael Kramer, M.D.
Department of Nutrition | McGill University Faculty of Medicine
University of California, Davis | Institute of Human Development, Child and Youth Health
| The Montreal Children's Hospital
Gillman Grave, M.D. | Katy Lebbing, B.S., IBCLC, RLC
Endocrinology, Nutrition & Growth | Center for Breastfeeding Information
National Institute of Child Health and Human Development | La Leche League International
Larry Grummer-Strawn, Ph.D. | Ardythe L. Morrow, Ph.D., M.Sc.
National Center for Chronic Disease Prevention and Health Promotion | Cincinnati Children's Hospital Medical Center
Centers for Disease Control and Prevention
Katherine E. Hartmann, M.D., Ph.D. | David Meyers, M.D.
Obstetrician-Gynecologist | Center for Primary Care, Prevention, and Clinical
Vanderbilt University | Partnerships, (CPPO)
Representative, American College of Obstetricians and Gynecologists | Agency for Healthcare Research and Quality
Suzanne Haynes, Ph.D. | Barbara L. Philipp, M.D.
Senior Science Advisor | The Breastfeeding Center
Office on Women's Health | Boston Medical Center
U.S. Department of Health and Human Services
Jill Janke, RNC, D.NSc. | Lori Feldman-Winter, M.D., M.P.H., IBCLC, FAAP, FABM
University of Alaska | Robert Wood Johnson Medical School
Representative, Association of Women's Health, | University of Medicine and Dentistry of New Jersey
Obstetrical and Neonatal Nurses | Representative, AAP and the Section on Breastfeeding