# Addendum (5-15-2009)

It has been brought to our attention that Ranjit K Chandra may be involved in fraudulent publications (2;3). Dr. Chandra is an author of a primary study (4) included in our update meta-analysis on the association of breastfeeding and asthma risk published in AHRQ Evidence Report Number 153 (1). To assess the impact of this potentially fraudulent study, we repeated the meta-analysis by removing this study. Our original meta-analysis was conducted with and without a study that reported a very large adjusted odds ratio (5). Our re-analysis excluding Chandra 1991 and Wright 2001 (the one with the very large adjusted odds ratio) showed that the overall summary odds ratio remains significant (adjusted OR 0.63; 95%CI 0.45 – 0.89) (Figure 1). Our re-analysis excluding Chandra 1991 but including Wright 2001 showed that the overall summary odds ratio remains non-significant (adjusted OR 0.86; 95%CI 0.62 – 1.18) (Figure 2). These findings are similar to what were reported in the AHRQ Evidence Report. We conclude that excluding Chandra 1991 from our meta-analysis does not affect conclusions concerning breastfeeding and asthma risk made in the report.

Figure 1. The relationship between breastfeeding and health outcomes in term infants - meta-analysis results

MA, meta-analysis; AOM, acute otitis media; GI, gastrointestinal; CC, case-control studies; FH, family history; CVD, cardiovascular disease; IHD, ischemic heart disease; DM, diabetes; adj, adjusted

*17 studies in total were included in Norris 1996 meta-analyses. The number of studies per comparison was not reported.

†Four historical cohort studies reported data on the relationship between breastfeeding and both CVD and IHD mortality.

Figure 2. The relationship between exclusive breastfeeding and health outcomes in term infants - meta-analysis results

MA, meta-analysis; AOM, acute otitis media; FH, family history; Hosp, hospitalization; exclu, exclusive; LRTI, lower respiratory track infection

*18 studies in total were included in Gdalevich 2001 meta-analyses. The number of studies per comparison was not reported.

- Stanley Ip
- Mei Chung
- Joseph Lau

- Tufts Evidence-based Practice Center,
- Tufts Medical Center,
- Boston, MA

[image]

[image]

## Reference List

1 Ip, S., Chung, M., Raman, G., Chew, P., Magula, N., DeVine, D., Trikalinos, T., and Lau, J. Breastfeeding and Maternal and Infant Health Outcomes in Developed Countries. 153. 4-20-2007. Rockville, MD, Agency for Healthcare Research and Quality. Evidence Report/Technology Assessment. Ref Type: Report
2 Roberts S. Dealing with scientific fraud: a proposal. Public Health Nutr. 2006;9:664-65. [pmid: 16923304].
3 Sternberg S, Roberts S. Nutritional supplements and infection in the elderly: why do the findings conflict?. Nutr J. 2006;5:30. [pmid: 17123445]. [pmcid: 1676012].
4 Chandra RK, Hamed A. Cumulative incidence of atopic disorders in high risk infants fed whey hydrolysate, soy, and conventional cow milk formulas. Ann Allergy. 1991;67:129-132. [pmid: 1867449].
5 Wright AL, Holberg CJ, Taussig LM, Martinez FD. Factors influencing the relation of infant feeding to asthma and recurrent wheeze in childhood. [see comment]. Thorax. 2001;56:192-197. [pmid: 11182011]. [pmcid: 1758780].