# Discussion

Twenty-three outcomes were analyzed in this report. Approximately 400 articles would needed to be reviewed if only articles with primary data were included; this is a much larger volume of literature than can be feasibly reviewed within the time period of this report. With the availability of many published systematic reviews on breastfeeding, we used this literature as the evidence for a large number of outcomes, supplemented by updates of these systematic reviews with new primary studies. We performed several new systematic reviews on outcomes not previously reported. The existing systematic reviews were conducted over a wide span of time and by diverse groups of investigators; there were large variations in the approach and quality of these reviews.

Even though we have assessed the reporting quality of these systematic reviews (using standards of reporting of systematic reviews of observational studies - MOOSE statement^22^ and additional parameters that we devised), we cannot reliably know the validity of the reported summary data without knowing the details of the primary studies. A number of systematic reviews reported that inclusion and exclusion of some primary studies were reached by consensus between at least two investigators. Without knowing the details of how those consensuses were reached, it would be difficult to replicate the findings in those reviews as it is quite plausible that someone who is not familiar with the details of the consensus might have come up with a different set of studies for inclusion in the review. It should also be stressed that a well-performed systematic review does not necessarily imply that the body of evidence for a particular outcome of interest is of high quality. While some systematic reviews assessed the quality of the individual studies, the methods used varied. Any systematic review is limited by the quality of the primary studies included in the review. Unless the method used to assess the quality of the primary studies is transparent and the details made available for examination, it would be difficult to reliably determine the validity of the conclusions.

In most circumstances, it would be unethical to randomize mother-infant pair into breastfeeding (or breast milk feeding) or not breastfeeding arm in a trial. Therefore, the breastfeeding literature is primarily comprised of observational studies, either cohort or case-control studies. There are a number of potential deficiencies related to the study designs that could limit the internal validity and the generalizability of the findings. Some of these potential deficiencies include (1) misclassification of exposure; (2) confounding from the process of self-selection; (3) residual confounding; and (4) insufficient statistical power.

Misclassification of exposure (breastfeeding status/duration) is likely in the studies reviewed in this report. Most studies relied on mothers' recall for the data on breastfeeding. Recall is prone to error. One study from South Africa reported that at 6 to 9 months post-delivery, 13 percent of mothers could not remember the specific timing when they gave something other than breast milk to their infant. In those mothers who could remember, 57 percent of them overestimated the duration of exclusive breastfeeding by about 8 weeks, and 15 percent underestimated the duration by about 3 weeks.^215^ Misclassification, may bias the effect estimate; particularly if the recall error is nonrandom, such as in studies where cases are more likely to underestimate the amount of breastfeeding than controls (for an example, see Norris and Scott 1996^90^).

In studies where subjects were self-selected, there could be confounding from the process of self-selection (e.g., if subjects who perceive their diseases are due to a lack of breastfeeding were more likely to participate in the study).

Residual confounding is a possibility for all observational studies, because it is difficult (if not impossible) to control for all potential confounding variables in these studies. Although it is possible to control for differences in demographic factors, it may not be possible to control for behavioral factors intrinsic in the desire to breastfeed.

Large sample size is often needed to examine the relationship between breastfeeding and various diseases and health conditions because of the need to adjust for numerous confounders to minimize all the potential biases described earlier. It is impossible to predict how these different limitations may interact to increase or decrease the effect estimate.

Compounding the issue of less-than-ideal study design are the heterogeneity of the breast milk itself and differences in how the feedings of breast milk were defined across different studies. The composition of breast milk varies both within and between individuals.^216,^ ^217^ The composition could vary depending on preterm versus term delivery, the maternal diet, maternal body weight, time of day, beginning versus near the end of feed, first few months of lactation versus later lactation, milk volume, and numerous other factors. On the other hand, the composition of formulas has also changed significantly over the last twenty years. For example, contemporary formulas have added ingredients like nucleotides and long-chain polyunsaturated fatty acids that were absent from older formulations. How the heterogeneity both within and between comparators would affect the effect estimate is unclear. Also, studies defined breastfeeding differently. Many studies did not have a category of “exclusive breastfeeding”. In the ones that did have this category, “exclusive” could mean no supplement of any kind including water or it could mean occasional formula supplement is permissible. This mixing in of formula in the “exclusive” breastfeeding group may potentially dilute the true effect of breast milk and bias the results toward the null finding. In addition, no study in this review examined the differences between actually breastfeeding an infant and bottle or gavage feeding an infant with breast milk. How the act of breastfeeding itself plays a role in the different effects measured is unknown.

We have summarized the effects of breastfeeding (or breast milk feeding) on a large number of infant and maternal outcomes. Some of the outcomes are well defined and specific (e.g., childhood acute lymphocytic leukemia, breast cancer); and some are not so well defined and non-specific (e.g., asthma, gastrointestinal infections). When the reported outcome is well defined and specific, it lends confidence that the effect reported is valid for that outcome. When the reported outcome is not well defined, one might have some reservation regarding the validity of the measured effect for that outcome.

For all the above reasons, we find that there is a wide range of quality of evidence for the different outcomes examined in this review.

For severe lower respiratory tract diseases, good quality studies did find a relationship between breastfeeding and a reduction in the risk of hospitalization secondary to lower respiratory tract diseases.

For acute otitis media, the results from our meta-analyses of cohort studies of good and moderate methodological quality showed that breastfeeding was associated with a significant reduction in the risk of acute otitis media. Comparing ever breastfeeding with exclusive bottle-feeding, the pooled adjusted odds ratio of acute otitis media was 0.77 (95%CI 0.64 – 0.91). When comparing exclusive breastfeeding with exclusive bottle-feeding, either for more than 3 or 6 months duration, the pooled odds ratio was 0.50 (95%CI 0.36 – 0.70).

For non-specific gastroenteritis, one systematic review identified three primary studies that controlled for potential confounders. These studies reported that there was a reduction in the risk of non-specific gastrointestinal infections during the first year of life in breastfed infants from developed countries, although the observed range of risk reduction was wide. However, one recent case-control study of 304 infants (167 cases and 137 controls) from England showed that the infants who were breastfeeding had a reduced risk of diarrhea compared to infants who were not breastfeeding (adjusted OR 0.36, 95% CI 0.18 to 0.74, P=0.005). The result was adjusted for age, sex, social class, contact with person in and outside household, and other factors. Also, analysis of nested observational cohorts from the Belarus trial showed that the group of infants who were exclusively breastfed for at least 6 months compared to the group of infants who were breastfed for 3 to 6 months had a statistically significant reduced risk of one or more episodes of gastrointestinal infection in the first 12 months of life (adjusted OR = 0.61; 95%CI 0.41–0.93).214 The result was adjusted for geographic origin, urban versus rural location, maternal education, and number of siblings in the household.

For necrotizing enterocolitis (NEC) in preterm infants, our meta-analysis of four RCTs found a marginally statistically significant reduction (5% risk difference) of the NEC risk with breast milk feeding. Taking into account the high case-fatality rate of NEC, we consider this estimate is of meaningful clinical difference. However, One must be cognizant of the clinical heterogeneity underlying these RCTs in interpreting the findings of the meta-analysis. Three of the four RCTs were published in the 1980's. Whether infants born in the early 1980's should be combined with infants born in the late 1990's into a meta-analysis is debatable. Neonatal care has made tremendous strides in the last 20 years. Present day preterm formula milk is vastly different from preterm formula milk 20 years ago. All the studies had patient populations that were quite heterogeneous, gestational age ranged from 23 weeks to more than 33 weeks and birth weight ranged from less than 1000 g to more than 1,600 g. One study included only “healthy” infants, another included both “healthy” and “ill” infants. In addition, the types of breast milk, the methods of feedings, and the times of enrollments into the trials were all different. How the heterogeneity in the studies affected the findings is not clear. In addition, studies examining the issue of NEC were frequently also examining the issue of neonatal sepsis, as it is not possible to have NEC without concomitant sepsis. In future studies, it would be worthwhile to examine the relationship of breast milk exposure and sepsis in preterm infants.

For asthma, our subgroup analysis showed that breastfeeding was associated with a reduced risk in children under 10 years of age with a positive family history. However, this association does not hold true for older children as one publication reported a very large adjusted odds ratio (OR 8.7, 95%CI 3.4 – 22.2) for developing asthma in children 6 to 13 years of age who were exclusively breastfed for at least 4 months and had a positive history of maternal asthma.^56^ The relationship of breastfeeding, maternal history, and long-term outcome of asthma bears further investigation.

For atopic dermatitis, available evidence from one well-performed systematic review on full term infants in developed countries suggest that exclusive breastfeeding for at least 3 months confer a protective advantage in the development of atopic dermatitis in those subjects with a family history of atopy. The systematic review did not make a distinction between atopic dermatitis of infancy (under 2 years of age) and persistent or new atopic dermatitis at older ages. This is important because the diagnosis of atopic dermatitis in patients younger than 2 years of age are sometimes attributed to symptoms of infectious origin and breastfeeding may have a protective effect against infections. But a stratified analysis by different durations of followup showed that the risk reduction was similar in those with less than 2 years compared with more than 2 years of followup.

For cognitive outcome in term infants from developed countries, sibling analysis and prospective studies that controlled specifically for maternal intelligence found little or no evidence to support an association between breastfeeding and cognitive performance in children. Most of the published studies adjusted their analyses for socioeconomic status and maternal education but not specifically for maternal intelligence. For those studies that still reported a significant effect after specific adjustment for maternal intelligence, residual confounding from other factors like different home environments cannot be ruled out.

No definitive conclusion regarding the relationship of breast milk exposure and cognitive development in preterm infants can be drawn at this time. Studies that controlled for maternal intelligence reported conflicting results. In addition to maternal intelligence, comorbidities (e.g., neurological impairment, extremely low birth weight, other neonatal illnesses), early intervention, environmental, and socioeconomic factors should also be controlled for in future investigation of this relationship.

For adult blood pressure, evidence suggests that there is an association between a history of breastfeeding during pregnancy and a small reduction in adult blood pressure, but the clinical or public health implication of this finding is unclear. Furthermore, The association weakened after stratification by study size, suggesting the possibility of bias.

For adult cholesterol, a lack of explicit analysis of potential confounders in the meta-analysis hampered the conclusion drawn from the study. Therefore, the relationship between breastfeeding and adult cholesterol levels cannot be adequately addressed at this time.

For cardiovascular mortality in adults, the meta-analysis was limited by the statistical heterogeneity across studies, apparent outcome modification by differences in gender (and therefore, calls into question the appropriateness of combining outcomes from men and women into a single analysis), and more than 30% of the subjects dropped out in the studies. Because of these reasons, no definitive conclusions can be drawn regarding the relationship between breastfeeding and cardiovascular mortality. Further investigation is warranted.

For Sudden Infant Death Syndrome (SIDS), our meta-analysis included only studies that reported clear definitions of exposure, outcomes, and results adjusted for well-known confounders or risk factors for SIDS. The summary estimate found a statistically significant adjusted odds ratio for an association between breastfeeding and a reduced risk of SIDS (adjusted OR 0.64, 95%CI 0.51 – 0.81). We conclude that there is a relationship between breastfeeding and a reduced risk of SIDS. One must be cautious in interpreting this relationship, however. As this finding stems from analysis of observational studies, this finding cannot prove causality. It is plausible that infants who breastfed and breastfed well are less prone to SIDS because of some yet unclarified neurophysiological reasons, and not because breastfeeding itself directly confers a protective effect. Further investigation is warranted.

For post-neonatal mortality (excluding SIDS), there are insufficient data to characterize the relationship between breastfeeding and post-neonatal infant mortality adequately. Further investigation is warranted.

For childhood leukemia, available evidence suggests that there is an association between breastfeeding and a reduced risk of acute lymphocytic leukemia and acute myelogenous leukemia. Our findings from the meta-analyses of the three case-controlled studies that were graded good or fair quality by one systematic review were consistent with the results from the other meta-analysis, but with smaller effect size and smaller statistical significance. Further evaluation of the biological mechanisms underpinning this relationship while taking into consideration potential biases can be achieved with more large-scale case-controlled studies utilizing population-based and socioeconomic status-matched controls.

For obesity, evidence from three systematic reviews and meta-analyses suggests that a history of breastfeeding is associated with a reduction in the risk of obesity in later life. However, one must be aware of the possibility of residual confounding in interpreting this association. The pooled adjusted odds ratio of obesity comparing ever breastfed to never breastfed was 0.76 (95%CI 0.67–0.86) in one meta-analysis and 0.93 (95%CI: 0.88–0.99) in the other. The magnitude of effects was reduced when more confounders were adjusted in these analyses.

For type 2 diabetes, based on findings from a high-quality systematic review and meta-analyses of seven studies, early breastfeeding was associated with a lower risk of type 2 diabetes in later life compared with those initially formula-fed. However, only three studies appropriately adjusted for all the important confounders, including birth weight, parental diabetes, socioeconomic status, and individual or maternal body size. Even though these three studies found that adjustment did not alter the crude estimate, we cannot be completely confident that potential confounding by birth weight and maternal factors has been ruled out for the overall pooled estimate. This potentially could exaggerate the magnitude of the association.

For type 1 diabetes, even though there are some data to support that breastfeeding for more than 3 months is associated with a reduced risk of type 1 diabetes, this finding must be interpreted with caution because of the likelihood of recall biases and suboptimal adjustments for potential confounders in the primary studies.

For postpartum depression, studies of moderate quality reported an association between not breastfeeding or short duration of breastfeeding and postpartum depression. It is plausible that postpartum depression led to early cessation of breastfeeding, as opposed to breastfeeding altering the risk of depression. Both effects might occur concurrently. Additional factors that may have a bearing on both postpartum depression and the decision to initiate or terminate breastfeeding should be sought. Documentation of baseline mental health status before the initiation of breastfeeding and detailed recording of breastfeeding data will improve the quality of the studies and help understand the nature of the association.

There is no evidence of an association between lifetime breastfeeding duration and maternal osteoporosis. Lactation does not appear to have an effect on long-term changes in bone mineral densities. However, this conclusion is limited by the fact that the feeding history in the studies was obtained by maternal recall and no data on exclusivity of breastfeeding were available. Further investigation with accurate breastfeeding data is warranted.

For breast cancer, there is good evidence to support the observation that breastfeeding is associated with a reduction in the risk of breast cancer. This association is more likely in those women with increased lifetime months of breastfeeding their infants.

For ovarian cancer, there is some evidence to suggest an association between breastfeeding and a reduction in the risk of maternal ovarian cancer. However, one must be cautious in interpreting this association because it was largely based on estimations of the odds ratios from retrospective studies.

For postpartum weight change, we found that the overall effect of breastfeeding on return-to-pre-pregnancy weight (weight change from pre-pregnancy or first trimester to 1 to 2 year postpartum) was negligible (less than 1 kg), and the effect of breastfeeding on postpartum weight change was unclear. Results from the studies also suggest that many other factors have larger effects on weight retention or postpartum weight loss than breastfeeding. Methodological challenges in these studies include the accurate measurement of energy balance, adequate control for numerous covariables, and quantifying accurately the exclusivity and the duration of breastfeeding. None of the included studies tackled all of these challenges.

Concerning the risk of maternal type 2 diabetes, a longer duration of lifetime breastfeeding is associated with a reduced risk of developing type 2 diabetes among parous women who did not have a history of gestational diabetes (GDM). There was a difference in the risk of developing type 2 diabetes between women with and without GDM in relation to lactation. Compared with women who did not have a history of GDM, women with a history of GDM had a markedly increased risk of type 2 diabetes; and lactation showed no significant relationship with diabetes risk among this group of women. One must be cautious in interpreting these findings, as they are only generalizable to population with characteristics similar to that of the Nurses' Health cohort.

An important area of research that is not systematically reviewed in this report is the use of breastfeeding promotion intervention trial to measure health effects (this topic is not part of the scope of this report and it will be covered in a separate report). The best known of these types of studies is the previously described Promotion of Breastfeeding Intervention Trial (PROBIT) conducted in the Republic of Belarus.^17^ Data from this study provided good evidence that breastfeeding is associated with a reduction in the risk of gastrointestinal infection and atopic dermatitis. Whether results from studies conducted in other countries are applicable to the United States is unclear. In Belarus, mothers often stay in the hospital close to one week post delivery, infant formulas can cost as much as 20% of an average salary, and there is an obligatory prolonged maternity leave (approximately 3 years in most cases). In contrast, in the United States, mothers are often discharged within 48 hours post delivery and formula manufacturers provide rebates to the Special Supplemental Nutrition Program for Women, Infants, and Children (www.wicprogram.org). The factors in Belarus could work in conjunction with the intervention to help promote the increase in the rate of exclusive breastfeeding. On the other hand, one may argue that the results reported in the Belarus study could serve as a best-case scenario in terms of the potential benefits of breastfeeding when optimal promotion and support of breastfeeding are in place. More research in this country along the line of the Belarus study should be considered.

Of note, there were a few individual primary studies on asthma, cardiovascular mortality, and type 1 diabetes that reported increase in risk of those diseases in subjects who had been breastfed. Even though those studies were few in numbers, those findings should not be ignored and further investigation should be done.

Lastly, the outcomes analyzed in this review represent only a portion of all possible health outcomes related to breastfeeding reported by investigators worldwide. To work within the constraints of resources, we relied on the advice from our panel of technical experts in finalizing the list of outcomes included in this review. Thus, some important outcomes (e.g., growth and nutrition) have, by necessity, not been included in this review. Additional systematic reviews germane to those important outcomes would be of value.

## Future Research

Assessment of the association between breastfeeding and health outcomes

Observational studies will remain the major source of information in this field. Clear subject selection criteria, adopting a common definition of “exclusive breastfeeding”, reliable collection of feeding data, specific and properly quantifiable outcomes of interest, controlling for important potential confounders including child-specific factors, and blinded assessment of the outcome measures will help immeasurably to improve the quality of these studies. Traditional retrospective case-control studies, usually used when the disease is rare, are less desirable because of the many caveats noted earlier. Prospective nested case-control studies with blinded assessment of the outcome measures would provide more reliable results.

As have been mentioned previously, it is not possible to eliminate self-selection bias in observational studies because of behavioral or attitudinal factors intrinsic in the desire to breastfeed. Thus, it is worthwhile to study these factors to further understand the reasons for the decision to breastfeed.

Sibling analysis provides a method to control for hereditary and household factors that are important in certain outcomes, provided that those factors are similar for the siblings of interest. Although such analysis may be less susceptible to confounders and effect modifiers that are shared by siblings, one must remember that it is not immune to biases. This method should be used when the appropriate data are available.

There is a large degree of heterogeneity across studies among many of the outcomes. The heterogeneity persisted after adjusting for potential confounders. It might be helpful to study breast milk composition (e.g., oligosaccharides, nucleotides, and others) with respect to the residual heterogeneity. In addition, maternal genetic variations in the production of those factors of interest from breast milk can be studied (for an example, see the discussion by Newburg 2005^218^ concerning the variability of antidiarrheal effect of breastfeeding according to the prevalence of the secretor gene (fucosyltransferase 2) and the Lewis gene (fucosyltransferase 3) in the study population).

Assessment of the efficacy/effectiveness of breastfeeding promotion interventions

Cluster randomized controlled studies similar to the Belarus trial will provide understanding of the effectiveness of various breastfeeding promotion interventions. Any substantial differences in the degree of breastfeeding between the two groups as a result of the intervention will provide further opportunity to investigate any disparity in health outcomes between the two groups.